# References

1 O’Connor E, Rossom RC, Henninger M, . Screening for Depression in Adults: An Updated Systematic Evidence Review for the U.S. Preventive Services Task Force. 2016.
2 O’Connor E, Gaynes B, Burda BU, . Screening for Suicide Risk in Primary Care: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD): 2013.
3 Centers for Disease Control and Prevention. Mental Health Conditions: Depression and Anxiety. https://www.cdc.gov/tobacco/campaign/tips/diseases/depression-anxiety.html. Accessed: 1/7/2019.
4 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, Fifth Edition. Arlington, VA: American Psychiatric Association; 2013.
5 Committee on Obstetric Practice. ACOG Committee Opinion No. 757: Screening for Perinatal Depression. Obstetrics & Gynecology. 2018;132(5):e208–e12. PMID: 30629567. 10.1097/AOG.0000000000002927 30629567
6 National Institute of Mental Health. Perinatal Depression. https://www.nimh.nih.gov/health/publications/perinatal-depression. Accessed: August 12, 2021.
7 Stone D, Holland K, Bartholow B, . Preventing Suicide: A Technical Package of Policies, Programs, and Practices. Atlanta, GA: National Center for Injury Prevention and Control, Centers for Disease Control and Prevention; 2017.
8 Substance Abuse and Mental Health Services Administration. Key substance use and mental health indicators in the United States: Results from the 2019 National Survey on Drug Use and Health (HHS Publication No. PEP20-07-01-001, NSDUH Series H-55). Rockville, MD: Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration; 2020.
9 Bauman BL, Ko JY, Cox S, . Vital signs: Postpartum depressive symptoms and provider discussions about perinatal depression—United States, 2018. Morbidity and Mortality Weekly Report. 2020;69(19):575. 10.15585/mmwr.mm6919a2external 32407302
10 Centers for Disease Control and Prevention. Prevalence of Selected Maternal and Child Health Indicators for All PRAMS Sites, Pregnancy Risk Assessment Monitoring System (PRAMS), 2016–2019. https://www.cdc.gov/prams/prams-data/2019-selected-mch-indicators.html. Accessed: 4/10/2023.
11 Greenberg PE, Fournier A-A, Sisitsky T, . The economic burden of adults with major depressive disorder in the United States (2010 and 2018). Pharmacoeconomics. 2021;39(6):653–65. 10.1007/s40273-021-01019-4 33950419
12 Albert PR. Why is depression more prevalent in women? Journal of psychiatry & neuroscience : JPN. 2015;40(4):219–21. PMID: 26107348. 10.1503/jpn.150205 26107348
13 Ma L, Xu Y, Wang G, . What do we know about sex differences in depression: A review of animal models and potential mechanisms. Progress in Neuro-Psychopharmacology and Biological Psychiatry. 2019;89:48–56. 10.1016/j.pnpbp.2018.08.026 30165122
14 National Institute of Mental Health. Major Depression. https://www.nimh.nih.gov/health/statistics/major-depression.shtml. Accessed: Jan 9, 2020.
15 Kessler RC, Merikangas KR, Wang PS. Prevalence, comorbidity, and service utilization for mood disorders in the United States at the beginning of the twenty-first century. Annual review of clinical psychology. 2007;3:137–58. PMID: 17716051. 10.1146/annurev.clinpsy.3.022806.091444 17716051
16 The Mayo Clinic. Depression (Major Depressive Disorder). https://www.mayoclinic.org/diseases-conditions/depression/symptoms-causes/syc-20356007. Accessed: 1/7/2019.
17 Gilman SE, Sucha E, Kingsbury M, . Depression and mortality in a longitudinal study: 1952–2011. CMAJ : Canadian Medical Association journal = journal de l’Association medicale canadienne. 2017;189(42):E1304–e10. PMID: 29061855. 10.1503/cmaj.170125 29061855
18 Gallo JJ, Hwang S, Joo JH, . Multimorbidity, Depression, and Mortality in Primary Care: Randomized Clinical Trial of an Evidence-Based Depression Care Management Program on Mortality Risk. Journal of general internal medicine. 2016;31(4):380–6. PMID: 26432693. 10.1007/s11606-015-3524-y 26432693
19 Szegda K, Markenson G, Bertone-Johnson ER, . Depression during pregnancy: a risk factor for adverse neonatal outcomes? A critical review of the literature. J Matern Fetal Neonatal Med. 2014;27(9):960–7. PMID: 24044422. 10.3109/14767058.2013.845157 24044422
20 Jarde A, Morais M, Kingston D, . Neonatal Outcomes in Women With Untreated Antenatal Depression Compared With Women Without Depression: A Systematic Review and Meta-analysis. JAMA Psychiatry. 2016;73(8):826–37. PMID: 27276520. 10.1001/jamapsychiatry.2016.0934 27276520
21 National Academies of Sciences E, Medicine, Division of B, . The National Academies Collection: Reports funded by National Institutes of Health. Fostering Healthy Mental, Emotional, and Behavioral Development in Children and Youth: A National Agenda. Washington (DC): National Academies Press (US) Copyright 2019 by the National Academy of Sciences. All rights reserved.; 2019.
22 Wall-Wieler E, Roos LL, Gotlib IH. Maternal depression in early childhood and developmental vulnerability at school entry. Pediatrics. 2020;146(3). PMID: 32817440. 10.1542/peds.2020-0794 32817440
23 National Institute of Mental Health. Mental Health Statistics. 2017. PMID.
24 Kessler RC, Petukhova M, Sampson NA, . Twelve-month and lifetime prevalence and lifetime morbid risk of anxiety and mood disorders in the United States. International journal of methods in psychiatric research. 2012;21(3):169–84. PMID: 22865617. 10.1002/mpr.1359 22865617
25 Terlizzi EP, Villarroel MA. Symptoms of Generalized Anxiety Disorder Among Adults: United States, 2019. NCHS data brief. 2020;378:1–8. PMID: 33054928.33054928
26 Misri S, Abizadeh J, Sanders S, . Perinatal Generalized Anxiety Disorder: Assessment and Treatment. J Womens Health (Larchmt). 2015;24(9):762–70. PMID: 26125602. 10.1089/jwh.2014.5150 26125602
27 Vahratian A, Blumberg SJ, Terlizzi EP, . Symptoms of anxiety or depressive disorder and use of mental health care among adults during the COVID-19 pandemic—United States, August 2020–February 2021. Morbidity and Mortality Weekly Report. 2021;70(13):490. PMID: 33793459. 10.15585/mmwr.mm7013e2 33793459
28 Olatunji BO, Cisler JM, Tolin DF. Quality of life in the anxiety disorders: a meta-analytic review. Clin Psychol Rev. 2007;27(5):572–81. PMID: 17343963. 10.1016/j.cpr.2007.01.015 17343963
29 Kroenke K, Spitzer RL, Williams JB, . Anxiety disorders in primary care: prevalence, impairment, comorbidity, and detection. Ann Intern Med. 2007;146(5):317–25. PMID: 17339617. 10.7326/0003-4819-146-5-200703060-00004 17339617
30 Hoffman DL, Dukes EM, Wittchen HU. Human and economic burden of generalized anxiety disorder. Depress Anxiety. 2008;25(1):72–90. PMID: 17146763. 10.1002/da.20257 17146763
31 Konnopka A, Konig H. Economic Burden of Anxiety Disorders: A Systematic Review and Meta-Analysis. Pharmacoeconomics. 2020;38(1):25–37. PMID: 31646432. 10.1007/s40273-019-00849-7 31646432
32 Bentley KH, Franklin JC, Ribeiro JD, . Anxiety and its disorders as risk factors for suicidal thoughts and behaviors: A meta-analytic review. Clin Psychol Rev. 2016;43:30–46. PMID: 26688478. 10.1016/j.cpr.2015.11.008 26688478
33 Baxter AJ, Vos T, Scott KM, . The global burden of anxiety disorders in 2010. Psychol Med. 2014;44(11):2363–74. 10.1017/S0033291713003243 24451993
34 Simning A, Seplaki CL. Association of the cumulative burden of late-life anxiety and depressive symptoms with functional impairment. Int J Geriatr Psychiatry. 2020;35(1):80–90. PMID: 31650615. 10.1002/gps.5221 31650615
35 Dong L, Freedman VA, Mendes de Leon CF. The Association of Comorbid Depression and Anxiety Symptoms With Disability Onset in Older Adults. Psychosom Med. 2020;82(2):158–64. PMID: 31688675. 10.1097/PSY.0000000000000763 31688675
36 Avraham L, Tamar W, Eyal S, . Perinatal outcomes and offspring long-term neuropsychiatric hospitalizations of mothers with anxiety disorder. Arch Womens Ment Health. 2020. PMID: 3199374231993742. 10.1007/s00737-020-01018-y
37 Stone DM, Jones CM, Mack KA. Changes in Suicide Rates—United States, 2018–2019. Morbidity and Mortality Weekly Report. 2021;70(8):261. PMID: 33630824. 10.15585/mmwr.mm7008a1 33630824
38 Ivey-Stephenson AZ, Crosby AE, Hoenig JM, . Suicidal Thoughts and Behaviors Among Adults Aged >/=18 Years - United States, 2015-2019. MMWR Surveill Summ. 2022;71(1):1–19. PMID: 34990443. 10.15585/mmwr.ss7101a1 34990443
39 Centers for Disease Control and Prevention. Web-based Injury Statistics Query and Reporting System (WISQARS) Injury Mortality Reports, 2017. Atlanta, GA: Centers for Disease Control and Prevention; 2019. PMID.
40 Hedegaard H, Curtin SC, Warner M. Suicide Mortality in the United States, 1999-2019. NCHS data brief. 2021;398:1–8. PMID: 33663651.33663651
41 Curtin SC, Hedegaard H, Ahmad FB. Provisional Numbers and Rates of Suicide by Month and Demographic Characteristics: United States, 2020. U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Health Statistics, National Vital Statistics System; 2021.
42 Curtin S, Brown K, Jordan M. Suicide Rates for the Three Leading Methods by Race and Ethnicity: United States, 2000–2020. NCHS Data Brief, no 450. Hyattsville, MD: National Center for Health Statistics; 2022.
43 Centers for Disease Control and Prevention. Years of Potential Life Lost (YPLL) Before Age 85, 2017. Atlanta, GA: Centers for Disease Control and Prevention; 2019. PMID.
44 Klonsky ED, May AM, Saffer BY. Suicide, Suicide Attempts, and Suicidal Ideation. Annual review of clinical psychology. 2016;12:307–30. PMID: 26772209. 10.1146/annurev-clinpsy-021815-093204 26772209
45 Curtin S, Hedegaard H. Suicide rates for females and males by race and ethnicity: United States, 1999–2017. NCHS Health E-Stat; 2019. PMID.
46 Ramchand R, Gordon JA, Pearson JL. Trends in Suicide Rates by Race and Ethnicity in the United States. JAMA netw. 2021;4(5):e2111563–e. 10.1001/jamanetworkopen.2021.11563
47 Office of Mental Health and Suicide Prevention. National Veteran Suicide Prevention Annual Report. In: Affairs UDoV, editor.2019. PMID.
48 Bommersbach TJ, Rosenheck RA, Rhee TG. National Trends of Mental Health Care Among US Adults Who Attempted Suicide in the Past 12 Months. JAMA Psychiatry. 2022;79(3):219–31. PMID: 35044428. 10.1001/jamapsychiatry.2021.3958 35044428
49 Substance Abuse and Mental Health Services Administration. Key Substance Use and Mental Health Indicators in the United States: Results from the 2017 National Survey on Drug Use and Health. In: Services USDoHH, editor.2018. PMID.
50 Shepard DS, Gurewich D, Lwin AK, . Suicide and Suicidal Attempts in the United States: Costs and Policy Implications. Suicide Life Threat Behav. 2015/10/30 ed2016. p. 352–62. PMID: 2651178826511788. 10.1111/sltb.12225
51 Harvard Health Publishing. What causes depression? Onset of depression more complex than a brain chemical imbalance. https://www.health.harvard.edu/mind-and-mood/what-causes-depression. Accessed: 1/9/2020.
52 Kessler RC, Berglund P, Demler O, . Lifetime prevalence and age-of-onset distributions of DSM-IV disorders in the National Comorbidity Survey Replication. Archives of general psychiatry. 2005;62(6):593–602. PMID: 15939837. 10.1001/archpsyc.62.6.593 15939837
53 de Girolamo G, Dagani J, Purcell R, . Age of onset of mental disorders and use of mental health services: needs, opportunities and obstacles. Epidemiol Psychiatr Sci. 2012;21(1):47–57. PMID: 22670412. 10.1017/s2045796011000746 22670412
54 Kendler KS, Aggen SH, Neale MC. Evidence for Multiple Genetic Factors Underlying DSM-IV Criteria for Major Depression. JAMA Psychiatry. 2013;70(6):599–607. 10.1001/jamapsychiatry.2013.751 23740048
55 Tsuang MT, Bar JL, Stone WS, . Gene-environment interactions in mental disorders. World psychiatry : official journal of the World Psychiatric Association (WPA). 2004;3(2):73–83. PMID: 16633461.16633461
56 Genetics Home Reference. Depression. https://ghr.nlm.nih.gov/condition/depression#inheritance. Accessed: 1/9/2020.
57 Fernandez-Pujals AM, Adams MJ, Thomson P, . Epidemiology and Heritability of Major Depressive Disorder, Stratified by Age of Onset, Sex, and Illness Course in Generation Scotland: Scottish Family Health Study (GS:SFHS). PloS one. 2015;10(11):e0142197. PMID: 26571028. 10.1371/journal.pone.0142197 26571028
58 Weiss EL, Longhurst JG, Mazure CM. Childhood sexual abuse as a risk factor for depression in women: psychosocial and neurobiological correlates. Am J Psychiatry. 1999/06/09 ed1999. p. 816–28. PMID: 1036011810360118. 10.1176/ajp.156.6.816
59 Dillon G, Hussain R, Loxton D, . Mental and Physical Health and Intimate Partner Violence against Women: A Review of the Literature. Int J Family Med. 2013;2013:313909. PMID: 23431441. 10.1155/2013/313909 23431441
60 Harshfield EL, Pennells L, Schwartz JE, . Association Between Depressive Symptoms and Incident Cardiovascular Diseases. JAMA. 2020;324(23):2396–405. 10.1001/jama.2020.23068 33320224
61 Qato DM, Ozenberger K, Olfson M. Prevalence of Prescription Medications With Depression as a Potential Adverse Effect Among Adults in the United States. JAMA. 2018;319(22):2289–98. PMID: 29896627. 10.1001/jama.2018.6741 29896627
62 Skovlund CW, Morch LS, Kessing LV, . Association of Hormonal Contraception With Depression. JAMA Psychiatry. 2016;73(11):1154–62. PMID: 27680324. 10.1001/jamapsychiatry.2016.2387 27680324
63 National Academies of Sciences E, and Medicine;. Social Isolation and Loneliness in Older Adults: Opportunities for the Health Care System. Washington, DC: The National Academies Press; 2020.
64 Hutchens BF, Kearney J. Risk Factors for Postpartum Depression: An Umbrella Review. J Midwifery Womens Health. 2020;65(1):96–108. PMID: 31970924. 10.17226/25663.10.1111/jmwh.13067 31970924
65 Bailey ZD, Krieger N, Agénor M, . Structural racism and health inequities in the USA: evidence and interventions. Lancet (London, England). 2017;389(10077):1453–63. PMID: 28402827 10.1016/s0140-6736(17)30569-x 28402827
66 Muramatsu N. County-level income inequality and depression among older Americans. Health Serv Res. 2003;38(6 Pt 2):1863–83. PMID: 14727801 10.1111/j.1475-6773.2003.00206.x 14727801
67 Messias E, Eaton WW, Grooms AN. Economic grand rounds: Income inequality and depression prevalence across the United States: an ecological study. Psychiatr Serv. 2011;62(7):710–2. PMID: 21724781 10.1176/ps.62.7.pss6207_0710 21724781
68 Alegría M, NeMoyer A, Falgàs Bagué I, . Social Determinants of Mental Health: Where We Are and Where We Need to Go. Curr Psychiatry Rep. 2018;20(11):95. PMID: 30221308. 10.1007/s11920-018-0969-9.30221308
69 Assari S. Social Determinants of Depression: The Intersections of Race, Gender, and Socioeconomic Status. Brain sci. 2017;7(12). PMID: 29186800. 10.3390/brainsci7120156 29186800
70 Esterwood E, Saeed SA. Past Epidemics, Natural Disasters, COVID19, and Mental Health: Learning from History as we Deal with the Present and Prepare for the Future. Psychiatr Q2020. p. 1121–33. PMID: 3280347232803472. 10.1007/s11126-020-09808-4
71 Paykel ES. Partial remission, residual symptoms, and relapse in depression. Dialogues in clinical neuroscience. 2008;10(4):431–7. PMID: 19170400. 10.31887/DCNS.2008.10.4/espaykel 19170400
72 Angstman KB, Pietruszewski P, Rasmussen NH, . Depression remission after six months of collaborative care management: role of initial severity of depression in outcome. Mental health in family medicine. 2012;9(2):99–106. PMID: 23730334.23730334
73 Novick D, Montgomery W, Vorstenbosch E, . Recovery in patients with major depressive disorder (MDD): results of a 6-month, multinational, observational study. Patient preference and adherence. 2017;11:1859–68. PMID: 29184393. 10.2147/ppa.S138750 29184393
74 Fuller-Thomson E, Agbeyaka S, LaFond DM, . Flourishing after depression: Factors associated with achieving complete mental health among those with a history of depression. Psychiatry Res. 2016;242:111–20. PMID: 27267442. 10.1016/j.psychres.2016.04.041 27267442
75 Bandelow B, Michaelis S. Epidemiology of anxiety disorders in the 21st century. Dialogues in clinical neuroscience. 2015;17(3):327–35. PMID: 26487813. 10.31887/DCNS.2015.17.3/bbandelow 26487813
76 Moreno-Peral P, Conejo-Ceron S, Motrico E, . Risk factors for the onset of panic and generalised anxiety disorders in the general adult population: a systematic review of cohort studies. Journal of affective disorders. 2014;168:337–48. PMID: 25089514. 10.1016/j.jad.2014.06.021 25089514
77 Lamers F, van Oppen P, Comijs HC, . Comorbidity patterns of anxiety and depressive disorders in a large cohort study: the Netherlands Study of Depression and Anxiety (NESDA). The Journal of clinical psychiatry. 2011;72(3):341–8. PMID: 21294994. 10.4088/JCP.10m06176blu 21294994
78 Fuller-Thomson E, Ryckman K. Achieving complete mental health despite a history of generalized anxiety disorders: Findings from a large, nationally representative Canadian survey. Journal of affective disorders. 2020;265:687–94. PMID: 32090786. 10.1016/j.jad.2019.12.004 32090786
79 World Health Organization. Preventing Suicide: A Global Imperative. Geneva, Switzerland 2014. PMID.
80 Barzilay S, Apter A. Psychological models of suicide. Arch Suicide Res. 2014;18(4):295–312. PMID: 24568371. 10.1080/13811118.2013.824825 24568371
81 National Institute of Mental Health. Suicide Prevention. https://www.nimh.nih.gov/health/topics/suicide-prevention. Accessed: Mar 4, 2020.
82 Berman AL. Risk Factors Proximate to Suicide and Suicide Risk Assessment in the Context of Denied Suicide Ideation. Suicide & life-threatening behavior. 2018;48(3):340–52. PMID: 28429385. 10.1111/sltb.12351 28429385
83 Trost SL, Beauregard JL, Smoots AN, . Preventing Pregnancy-Related Mental Health Deaths: Insights From 14 US Maternal Mortality Review Committees, 2008–17. Health Aff (Millwood). 2021/10/05 ed2021. p. 1551–9. PMID: 3460635434606354. 10.1377/hlthaff.2021.00615
84 Mitchell AJ, Vaze A, Rao S. Clinical diagnosis of depression in primary care: a meta-analysis. Lancet. 2009/07/31 ed2009. p. 609–19. PMID: 1964057919640579. 10.1016/s0140-6736(09)60879-5
85 Roberge P, Normand-Lauziere F, Raymond I, . Generalized anxiety disorder in primary care: mental health services use and treatment adequacy. BMC Fam Pract. 2015;16:146. PMID: 26492867. 10.1186/s12875-015-0358-y 26492867
86 Wang PS, Angermeyer M, Borges G, . Delay and failure in treatment seeking after first onset of mental disorders in the World Health Organization’s World Mental Health Survey Initiative. World psychiatry : official journal of the World Psychiatric Association (WPA). 2007;6(3):177–85. PMID: 18188443.18188443
87 Olbert CM, Nagendra A, Buck B. Meta-analysis of Black vs. White racial disparity in schizophrenia diagnosis in the United States: Do structured assessments attenuate racial disparities? J Abnorm Psychol. 2018;127(1):104–15. PMID: 29094963. 10.1037/abn0000309 29094963
88 Strakowski SM, Keck PE, Jr., Arnold LM, . Ethnicity and diagnosis in patients with affective disorders. The Journal of clinical psychiatry. 2003;64(7):747–54. PMID: 12934973. 10.4088/jcp.v64n0702 12934973
89 Strakowski SM, Hawkins JM, Keck PE, Jr., . The effects of race and information variance on disagreement between psychiatric emergency service and research diagnoses in first-episode psychosis. The Journal of clinical psychiatry. 1997;58(10):457–63; quiz 64–5. PMID: 9375599. 10.4088/jcp.v58n1010a 9375599
90 Parkerson HA, Thibodeau MA, Brandt CP, . Cultural-based biases of the GAD-7. Journal of Anxiety Disorders. 2015;31:38–42. 10.1016/j.janxdis.2015.01.005 25725310
91 Huang FY, Chung H, Kroenke K, . Using the Patient Health Questionnaire-9 to measure depression among racially and ethnically diverse primary care patients. Journal of general internal medicine. 2006;21(6):547–52. PMID: 16808734. 10.1111/j.1525-1497.2006.00409.x 16808734
92 Maurer DM. Screening for depression. American family physician. 2012;85(2):139–44. PMID: 22335214.22335214
93 Runeson B, Odeberg J, Pettersson A, . Instruments for the assessment of suicide risk: A systematic review evaluating the certainty of the evidence. PLoS One. 2017/07/21 ed2017. p. e0180292. PMID: 2872397828723978. 10.1371/journal.pone.0180292
94 Plummer F, Manea L, Trepel D, . Screening for anxiety disorders with the GAD-7 and GAD-2: a systematic review and diagnostic metaanalysis. Gen Hosp Psychiatry. 2016/01/01 ed2016. p. 24–31. PMID: 2671910526719105. 10.1016/j.genhosppsych.2015.11.005
95 Substance Abuse and Mental Health Services Administration. Clinical Practice: Screening Tools. https://www.integration.samhsa.gov/clinical-practice/screening-tools. Accessed: Mar 3, 2020.
96 Quinlivan L, Cooper J, Davies L, . Which are the most useful scales for predicting repeat self-harm? A systematic review evaluating risk scales using measures of diagnostic accuracy. BMJ Open. 2016;6(2):e009297. PMID: 26873046. 10.1136/bmjopen-2015-009297 26873046
97 Pence BW, O’Donnell JK, Gaynes BN. The depression treatment cascade in primary care: a public health perspective. Curr Psychiatry Rep. 2012;14(4):328–35. PMID: 22580833. 10.1007/s11920-012-0274-y 22580833
98 Substance Abuse and Mental Health Services Administration. Behavioral Health Treatments and Services. https://www.samhsa.gov/find-help/treatment. Accessed: Mar 3, 2020.
99 Simon G. Unipolar major depression in adults: Choosing initial treatment. https://www.uptodate.com/contents/unipolar-major-depression-in-adults-choosing-initial-treatment?search=depression%20treatment&source=search_result&selectedTitle=1~150&usage_type=default&display_rank=1. Accessed: Mar 3, 2020.
100 Craske MG, Bystritsky A. Approach to treating generalized anxiety disorder. https://www.uptodate.com/contents/approach-to-treating-generalized-anxiety-disorder-in-adults?search=anxiety%20treatment&source=search_result&selectedTitle=2~150&usage_type=default&display_rank=2. Accessed: Mar 3, 2020.
101 Prada P, Perroud N, Rüfenacht E, . Strategies to deal with suicide and non-suicidal self-injury in borderline personality disorder, the case of DBT. Front Psychol. 2018;9:2595. PMID: 30619004. 10.3389/fpsyg.2018.02595 30619004
102 Paris J. Suicidality in borderline personality disorder. Medicina (Kaunas). 2019;55(6):223. PMID: 31142033. 10.3390/medicina55060223 31142033
103 Barlow DH, Farchione TJ, Bullis JR, . The Unified Protocol for Transdiagnostic Treatment of Emotional Disorders Compared With Diagnosis-Specific Protocols for Anxiety Disorders: A Randomized Clinical Trial. JAMA Psychiatry. 2017;74(9):875–84. PMID: 28768327. 10.1001/jamapsychiatry.2017.2164 28768327
104 National Institute of Mental Health. Research Domain Criteria (RDoC). https://www.nimh.nih.gov/research/research-funded-by-nimh/rdoc/index.shtml. Accessed: Mar 3, 2020.
105 Kato E, Borsky AE, Zuvekas SH, . Missed Opportunities for Depression Screening and Treatment in the United States. Journal of the American Board of Family Medicine : JABFM. 2018;31(3):389–97. PMID: 29743222. 10.3122/jabfm.2018.03.170406 29743222
106 Akincigil A, Matthews EB. National Rates and Patterns of Depression Screening in Primary Care: Results From 2012 and 2013. Psychiatr Serv. 2017;68(7):660–6. PMID: 28196461. 10.1176/appi.ps.20160009610.1176/appi.ps.201600096 28196461
107 Bhattacharjee S, Goldstone L, Vadiei N, . Depression Screening Patterns, Predictors, and Trends Among Adults Without a Depression Diagnosis in Ambulatory Settings in the United States. Psychiatr Serv. 2018;69(10):1098–100. PMID: 29983110. 10.1176/appi.ps.201700439 29983110
108 Ko J, Farr S, Dietz P, . Depression and treatment among U.S. pregnant and nonpregnant women of reproductive age, 2005–2009. J Womens Health (Larchmt). 2012;21(8):830–6. PMID: 22691031. 10.1089/jwh.2011.3466 22691031
109 Wittchen HU, Kessler RC, Beesdo K, . Generalized anxiety and depression in primary care: prevalence, recognition, and management. The Journal of clinical psychiatry. 2002;63 Suppl 8:24–34. PMID: 12044105.12044105
110 Feldman MD, Franks P, Duberstein PR, . Let’s not talk about it: suicide inquiry in primary care. Ann Fam Med. 2007/09/26 ed2007. p. 412–8. PMID: 1789338217893382. 10.1370/afm.719
111 Ahmedani BK, Simon GE, Stewart C, . Health care contacts in the year before suicide death. J Gen Intern Med. 2014/02/26 ed2014. p. 870–7. PMID: 2456719924567199. 10.1007/s11606-014-2767-3
112 Colorafi K, Vanselow J, Nelson T. Treating Anxiety and Depression in Primary Care: Reducing Barriers to Access. Family practice management. 2017;24(4):11–6. PMID: 28812852.28812852
113 Substance Abuse and Mental Health Services Administration. Key substance use and mental health indicators in the United States: Results from the 2018 National Survey on Drug Use and Health (HHS Publication No. PEP19-5068, NSDUH Series H-54). Rockville, MD: Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration; 2019.
114 Grenard JL, Munjas BA, Adams JL, . Depression and medication adherence in the treatment of chronic diseases in the United States: a meta-analysis. Journal of general internal medicine. 2011;26(10):1175–82. PMID: 21533823. 10.1007/s11606-011-1704-y 21533823
115 Maurer DM, Raymond TJ, Davis BN. Depression: Screening and Diagnosis. American family physician. 2018;98(8):508–15. PMID: 30277728.30277728
116 Nimalasuriya K, Compton MT, Guillory VJ. Screening adults for depression in primary care: A position statement of the American College of Preventive Medicine. The Journal of family practice. 2009;58(10):535–8. PMID: 19874732.19874732
117 Community Preventive Services Task Force. Mental Health and Mental Illness: Collaborative Care for the Management of Depressive Disorders. Atlanta, GA: The Community Guide; 2010. PMID.
118 Trangle M, Gursky J, Haight R, . Adult Depression in Primary Care Bloomington, MN: Institute for Clinical Systems Improvement; 2016.
119 Department of Veterans Affairs, Department of Defense. VA/DoD Clinical Practice Guideline. The Management of Major Depressive Disorder. Washington, DC: U.S. Government Printing Office; 2022.
120 Joffres M, Jaramillo A, Dickinson J, . Recommendations on screening for depression in adults. CMAJ : Canadian Medical Association journal = journal de l’Association medicale canadienne. 2013;185(9):775–82. PMID: 23670157. 10.1503/cmaj.130403 23670157
121 National Institute for Health and Care Excellence. Depression in adults: treatment and management (update) - In development [GID-CGWAVE0725]. 2021.
122 UK National Screening Committee. Adult Screening Programme Depression. https://view-health-screening-recommendations.service.gov.uk/depression/. Accessed: 3/18/2022.
123 Earls MF, Yogman MW, Mattson G, . Incorporating Recognition and Management of Perinatal Depression Into Pediatric Practice. Pediatrics. 2019;143(1):e20183259. 10.1542/peds.2018-3259 30559120
124 Austin M, Highet N, Expert Writing Group. Mental Health Care in the Perinatal Period: Australian Clinical Practice Guideline. Melbourne: Centre of Perinatal Excellence; 2017.
125 National Institute for Health and Care Excellence. Common mental health problems: identification and pathways to care: Clinical guideline [CG123]. 2011. PMID.
126 Gregory KD, Chelmow D, Nelson HD, . Screening for Anxiety in Adolescent and Adult Women: A Recommendation From the Women’s Preventive Services Initiative. Annals of Internal Medicine. 2020;09:09. PMID: 32510990. 10.7326/M20-0580 32510990
127 U.S. Department of Veterans Affairs. Assessment and Management of Patients at Risk for Suicide 2019. PMID.
128 The Joint Commission. Suicide Prevention. 2019. PMID.
129 Heisel M, Grek A, Moore S, . National Guidelines for Seniors’ Mental Health: The Assessment of Suicide Risk and Prevention of Suicide. Canadian Journal of Geriatrics. 2006.
130 Michigan Quality Improvement Consortium. Michigan Quality Improvement Consortium Guideline: Primary Care Diagnosis and Management of Adults with Depression. Detroit, MI: Michigan Quality Improvement Consortium; 2020.
131 U.S. Department of Health and Human Services. Health People 2030 [Website]. https://health.gov/healthypeople. Accessed: Sep 9, 2021.
132 National Committee for Quality Assurance. Healthcare Effectiveness Data and Information Set [HEDIS] Measures and Technical Resources. https://www.ncqa.org/hedis/measures/. Accessed: Mar 9, 2020.
133 Siu AL, Force USPST, Bibbins-Domingo K, . Screening for Depression in Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;315(4):380–7. PMID: 26813211. 10.1001/jama.2015.18392 26813211
134 US Preventive Services Task Force, Mangione C, Barry M, . Screening for Depression and Suicide Risk in Children and Adolescents: US Preventive Services Task Force Recommendation Statement. JAMA. 2022;328(15):1534–42. PMID: 36219440. 10.1001/jama.2022.16946 36219440
135 US Preventive Services Task Force, Curry SJ, Krist AH, . Interventions to Prevent Perinatal Depression: US Preventive Services Task Force Recommendation Statement. Jama. 2019;321(6):580–7. PMID: 30747971. 10.1001/jama.2019.0007 30747971
136 U. S. Preventive Services Task Force, Mangione CM, Barry MJ, . Screening for Anxiety in Children and Adolescents: US Preventive Services Task Force Recommendation Statement. JAMA. 2022;328(14):1438–44. PMID: 36219403. 10.1001/jama.2022.16936 36219403
137 LeFevre ML, Force USPST. Screening for suicide risk in adolescents, adults, and older adults in primary care: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2014;160(10):719–26. PMID: 24842417. 10.7326/M14-0589 24842417
138 U.S. Preventive Services Task Force. Screening for Depression, Anxiety, and Suicide Risk in Children and Adolescents: Research Plan [Website]. https://www.uspreventiveservicestaskforce.org/uspstf/draft-update-summary/screening-depression-anxiety-suicide-risk-children-adolescents. Accessed: June 14, 2022.
139 Pollock M, Fernandes R, Newton A, . A decision tool to help researchers make decisions about including systematic reviews in overviews of reviews of healthcare interventions. Syst Rev. 2019;8. 10.1186/s13643-018-0768-8
140 Cuijpers P, Karyotaki E, Ciharova M. A meta-analytic database of randomised trials on psychotherapies for depression. Open Science Foundation. 2019. 10.17605/OSF.IO/825C6
141 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville (MD): Agency for Healthcare Research and Quality (US); 2021.
142 Whiting P, Savovic J, Higgins JP, . ROBIS: A new tool to assess risk of bias in systematic reviews was developed. J Clin Epidemiol. 2016;69:225–34. PMID: 26092286. 10.1016/j.jclinepi.2015.06.005 26092286
143 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529–36. PMID: 22007046. 10.7326/0003-4819-155-8-201110180-00009 22007046
144 Raudenbush SW. Analyzing effect sizes: Random-effects models. In: Cooper H, Hedges LV, Valentine JC, editors. The Handbook of Research Synthesis and Meta-Analysis. 2nd ed. New York, New York: Russell Sage Foundation; 2009. p. 296–314.
145 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. 2003;22(17):2693–710. PMID: 12939780. 10.1002/sim.1482 12939780
146 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177–88. PMID: 3802833. 10.1016/0197-2456(86)90046-2 3802833
147 Berkman ND, Lohr KN, Ansari MT, . Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2015;68(11):1312–24. PMID: 25721570. 10.1016/j.jclinepi.2014.11.023 25721570
148 Atkins D, Best D, Briss PA, . Grading quality of evidence and strength of recommendations. BMJ (Clinical research ed). 2004;328(7454):1490. PMID: 15205295. 10.1136/bmj.328.7454.1490 15205295
149 Bergus GR, Hartz AJ, Noyes R, Jr., . The limited effect of screening for depressive symptoms with the PHQ-9 in rural family practices. J Rural Health. 2005;21(4):303–9. PMID: 16294652. 10.1111/j.1748-0361.2005.tb00099.x 16294652
150 Jarjoura D, Polen A, Baum E, . Effectiveness of screening and treatment for depression in ambulatory indigent patients. Journal of general internal medicine. 2004;19(1):78–84. PMID: 14748864. 10.1111/j.1525-1497.2004.21249.x 14748864
151 Rost K, Nutting P, Smith J, . Improving depression outcomes in community primary care practice: a randomized trial of the quEST intervention. Quality Enhancement by Strategic Teaming. Journal of general internal medicine. 2001;16(3):143–9. PMID: 11318908. 10.1111/j.1525-1497.2001.00537.x 11318908
152 Wells KB, Sherbourne C, Schoenbaum M, . Impact of disseminating quality improvement programs for depression in managed primary care: A randomized controlled trial. JAMA. 2000;283(2):212–20. PMID: 10634337. 10.1001/jama.283.2.212 10634337
153 Williams J, CD M, Kroenke K. Case-finding for depression in primary care: A randomized trial. The American journal of medicine. 1999;106(1):36–43. PMID: 10320115. 10.1016/s0002-9343(98)00371-4 10320115
154 Bijl D, van Marwijk HWJ, Ader HJ, . A randomised controlled trial to improve the recognition, diagnosis and treatment of major depression in elderly people in general practice - primary and secondary outcomes of the West Friesland Study. Diemen: College Voor Zortgverskeringen; 2003.
155 Callahan CM, Hendrie HC, Dittus RS, . Improving treatment of late life depression in primary care: a randomized clinical trial. J Am Geriatr Soc. 1994;42(8):839–46. PMID: 8046193. 10.1111/j.1532-5415.1994.tb06555.x 8046193
156 van der Weele GM, de Waal MW, van den Hout WB, . Effects of a stepped-care intervention programme among older subjects who screened positive for depressive symptoms in general practice: the PROMODE randomised controlled trial. Age Ageing. 2012;41(4):482–8. PMID: 22427507. 10.1093/ageing/afs027 22427507
157 Whooley M, Stone B. Randomized trial of case-finding for depression in elderly primary care patients. Journal of general internal medicine. 2000;15(5):293–300. PMID: 10840264. 10.1046/j.1525-1497.2000.04319.x 10840264
158 Glavin K, Smith L, Sorum R, . Redesigned community postpartum care to prevent and treat postpartum depression in women-a one-year follow-up study. J Clin Nurs. 2010;19(21-22):3051–62. PMID: 20726926. 10.1111/j.1365-2702.2010.03332.x 20726926
159 Leung SS, Leung C, Lam TH, . Outcome of a postnatal depression screening programme using the Edinburgh Postnatal Depression Scale: a randomized controlled trial. J Public Health (Oxf). 2011;33(2):292–301. PMID: 20884642. 10.1093/pubmed/fdq075 20884642
160 MacArthur C, Winter HR, Bick DE, . Effects of redesigned community postnatal care on womens’ health 4 months after birth: a cluster randomised controlled trial. Lancet (London, England). 2002;359(9304):378–85. PMID: 11844507. 10.1016/s0140-6736(02)07596-7 11844507
161 Morrell CJ, Slade P, Warner R, . Clinical effectiveness of health visitor training in psychologically informed approaches for depression in postnatal women: pragmatic cluster randomised trial in primary care. BMJ (Clinical research ed). 2009;338:a3045. PMID: 19147636. 10.1136/bmj.a3045 19147636
162 van der Zee-van den Berg AI, Boere-Boonekamp MM, Groothuis-Oudshoorn CG, . Post-up study: Postpartum depression screening in well-child care and maternal outcomes. Pediatrics. 2017;140(4):1–8. PMID: 28882876. 10.1542/peds.2017-0110 28882876
163 Wickberg B, Tjus T, Hwang P. Using the EPDS in routine antenatal care in Sweden: a naturalistic study. J Reprod Infant Psychol. 2005;23(1):33–41. 10.1080/02646830512331330956
164 Yawn BP, Dietrich AJ, Wollan P, . TRIPPD: a practice-based network effectiveness study of postpartum depression screening and management. Annals of family medicine. 2012;10(4):320–9. PMID: 22778120. 10.1370/afm.1418 22778120
165 Kroenke K, Talib TL, Stump TE, . Incorporating PROMIS Symptom Measures into Primary Care Practice-a Randomized Clinical Trial. Journal of general internal medicine. 2018;33(8):1245–52. PMID: 29623512. 10.1007/s11606-018-4391-0 29623512
166 Alves Apostolo JL, Bobrowicz-Campos EM, Carvalho dos Reis IA, . Exploring the screening capacity of the European Portuguese version of the 15-item Geriatric Depression Scale. Revista de Psicopatologia y Psicologia Clinica. 2018;23(2):99–107. 10.5944/rppc.vol.23.num.2.2018.21050
167 Blank K, Gruman C, Robison JT. Case-finding for depression in elderly people: balancing ease of administration with validity in varied treatment settings. J Gerontol A Biol Sci Med Sci. 2004;59(4):378–84. PMID: 15071082. 10.1093/gerona/59.4.m378 15071082
168 Broekman BF, Niti M, Nyunt MS, . Validation of a brief seven-item response bias-free geriatric depression scale. Am J Geriatr Psychiatry. 2011;19(6):589–96. PMID: 21606902. 10.1097/JGP.0b013e3181f61ec9 21606902
169 Davison TE, McCabe MP, Mellor D. An examination of the “gold standard" diagnosis of major depression in aged-care settings. Am J Geriatr Psychiatry. 2009;17(5):359–67. PMID: 19390293. 10.1097/JGP.0b013e318190b901 19390293
170 Eriksen S, Bjorklof GH, Helvik AS, . The validity of the hospital anxiety and depression scale and the geriatric depression scale-5 in home-dwelling old adults in Norway. Journal of affective disorders. 2019;256:380–5. PMID: 31212233. 10.1016/j.jad.2019.05.049 31212233
171 Izal M, Montorio I, Nuevo R, . Optimising the diagnostic performance of the Geriatric Depression Scale. Psychiatry Res. 2010;178(1):142–6. PMID: 20452060. 10.1016/j.psychres.2009.02.018 20452060
172 Jung YE, Kim MD, Bahk WM, . Validation of the Korean Version of the Depression in Old Age Scale and Comparison with Other Depression Screening Questionnaires Used in Elderly Patients in Medical Settings. Clin. 2019;17(3):369–76. PMID: 31352703. 10.9758/cpn.2019.17.3.369 31352703
173 Licht-Strunk E, van der Kooij KG, van Schaik DJ, . Prevalence of depression in older patients consulting their general practitioner in The Netherlands. Int J Geriatr Psychiatry. 2005;20(11):1013–9. PMID: 16250082. 10.1002/gps.1391 16250082
174 Marc LG, Raue PJ, Bruce ML. Screening performance of the 15-item geriatric depression scale in a diverse elderly home care population. Am J Geriatr Psychiatry. 2008;16(11):914–21. PMID: 18978252. 10.1097/JGP.0b013e318186bd67 18978252
175 Pellas J, Damberg M. Accuracy in detecting major depressive episodes in older adults using the Swedish versions of the GDS-15 and PHQ-9. Ups J Med Sci. 2021;126. PMID: 34754407. 10.48101/ujms.v126.7848 34754407
176 Rait G, Burns A, Baldwin R, . Screening for depression in African-Caribbean elders. Fam Pract. 1999;16(6):591–5. PMID: 10625132. 10.1093/fampra/16.6.591 10625132
177 Shin C, Park MH, Lee SH, . Usefulness of the 15-item geriatric depression scale (GDS-15) for classifying minor and major depressive disorders among community-dwelling elders. Journal of affective disorders. 2019;259:370–5. PMID: 31470180. 10.1016/j.jad.2019.08.053 31470180
178 Stefan AM, Baban A. The Romanian version of the Geriatric Depression Scale: Reliability and validity. Cognition, Brain, Behavior: An Interdisciplinary Journal. 2017;21(3):175–87. 10.24193/cbb.2017.21.10
179 van Marwijk HW, Wallace P, de Bock GH, . Evaluation of the feasibility, reliability and diagnostic value of shortened versions of the geriatric depression scale. The British journal of general practice : the journal of the Royal College of General Practitioners. 1995;45(393):195–9. PMID: 7612321.7612321
180 Bosanquet K, Bailey D, Gilbody S, . Diagnostic accuracy of the Whooley questions for the identification of depression: a diagnostic meta-analysis. BMJ Open. 2015;5(12):e008913. PMID: 26656018. 10.1136/bmjopen-2015-008913 26656018
181 He C, Levis B, Riehm KE, . The Accuracy of the Patient Health Questionnaire-9 Algorithm for Screening to Detect Major Depression: An Individual Participant Data Meta-Analysis. Psychother Psychosom. 2020;89(1):25–37. PMID: 31593971. 10.1159/000502294 31593971
182 Levis B, Negeri Z, Sun Y, . Accuracy of the Edinburgh Postnatal Depression Sscale (EPDS) for Screening to Detect Major Depression among Pregnant and Postpartum Women: Systematic Review and Meta-analysis of Individual Participant Data. BMJ (Clinical research ed). 2020;371:m4022. PMID: 33177069. 10.1136/bmj.m4022 33177069
183 Levis B, Sun Y, He C, . Accuracy of the PHQ-2 Alone and in Combination With the PHQ-9 for Screening to Detect Major Depression: Systematic Review and Meta-analysis. JAMA. 2020;323(22):2290–300. PMID: 32515813. 10.1001/jama.2020.6504 32515813
184 Vilagut G, Forero CG, Barbaglia G, . Screening for Depression in the General Population with the Center for Epidemiologic Studies Depression (CES-D): A Systematic Review with Meta-Analysis. PLoS ONE [Electronic Resource]. 2016;11(5):e0155431. PMID: 27182821. 10.1371/journal.pone.0155431 27182821
185 Wang L, Kroenke K, Stump TE, . Screening for perinatal depression with the Patient Health Questionnaire depression scale (PHQ-9): A systematic review and meta-analysis. General hospital psychiatry. 2021;68:74–82. PMID: 33360526. 10.1016/j.genhosppsych.2020.12.007 33360526
186 Wu Y, Levis B, Riehm KE, . Equivalency of the diagnostic accuracy of the PHQ-8 and PHQ-9: a systematic review and individual participant data meta-analysis. Psychol Med. 2019:1–13. PMID: 3129818031298180. 10.1017/S0033291719001314
187 Harel D, Levis B, Sun Y, . External validation of a shortened screening tool using individual participant data meta-analysis: A case study of the Patient Health Questionnaire-Dep-4. Methods. 2022;204:300–11. PMID: 34780986. 10.1016/j.ymeth.2021.11.005 34780986
188 Negeri ZF, Levis B, Sun Y, . Accuracy of the Patient Health Questionnaire-9 for screening to detect major depression: updated systematic review and individual participant data meta-analysis. BMJ (Clinical research ed). 2021;375:n2183. PMID: 34610915. 10.1136/bmj.n2183 34610915
189 Smith RD, Shing JSY, Lin J, . Meta-analysis of diagnostic properties of the Whooley questions to identify depression in perinatal women. Journal of affective disorders. 2022;315:148–55. PMID: 35931230. 10.1016/j.jad.2022.07.026 35931230
190 Levis B, Benedetti A, Thombs BD, . Accuracy of Patient Health Questionnaire-9 (PHQ-9) for screening to detect major depression: individual participant data meta-analysis. BMJ (Clinical research ed). 2019;365:l1476. PMID: 30967483. 10.1136/bmj.l1476 30967483
191 Aherne D, Fitzgerald A, Aherne C, . Evidence for the treatment of moderate depression: a systematic review. Ir J Psychol Med. 2017;34(3):197–204. PMID: 30115148. 10.1017/ipm.2017.10 30115148
192 Castro A, Gili M, Ricci-Cabello I, . Effectiveness and adherence of telephone-administered psychotherapy for depression: A systematic review and meta-analysis. Journal of affective disorders. 2020;260:514–26. PMID: 31539688. 10.1016/j.jad.2019.09.023 31539688
193 Collado A, Lim AC, MacPherson L. A systematic review of depression psychotherapies among Latinos. Clin Psychol Rev. 2016;45:193–209. PMID: 27113679. 10.1016/j.cpr.2016.04.001 27113679
194 Cuijpers P. Four decades of outcome research on psychotherapies for adult depression: An overview of a series of meta-analyses. Canadian Psychology/Psychologie canadienne. 2017;58(1):7–19. 10.1037/cap0000096
195 Cuijpers P, Karyotaki E, de Wit L, . The effects of fifteen evidence-supported therapies for adult depression: A meta-analytic review. Psychother. 2020;30(3):279–93. PMID: 31394976. 10.1080/10503307.2019.1649732 31394976
196 Cuijpers P, Karyotaki E, Reijnders M, . Was Eysenck right after all? A reassessment of the effects of psychotherapy for adult depression. Epidemiol Psychiatr Sci. 2019;28(1):21–30. PMID: 29486804. 10.1017/s2045796018000057 29486804
197 Cuijpers P, Karyotaki E, Reijnders M, . Who benefits from psychotherapies for adult depression? A meta-analytic update of the evidence. Cognitive Behav Ther. 2018;47(2):91–106. PMID: 29345530. 10.1080/16506073.2017.1420098 29345530
198 Cuijpers P, Quero S, Papola D, . Care-as-usual control groups across different settings in randomized trials on psychotherapy for adult depression: a meta-analysis. Psychol Med. 2019:1–11. PMID: 3184303131843031. 10.1017/S0033291719003581
199 Driessen E, Hollon SD, Bockting CL, . Does Publication Bias Inflate the Apparent Efficacy of Psychological Treatment for Major Depressive Disorder? A Systematic Review and Meta-Analysis of US National Institutes of Health-Funded Trials. PLoS ONE [Electronic Resource]. 2015;10(9):e0137864. PMID: 26422604. 10.1371/journal.pone.0137864 26422604
200 Harerimana B, Forchuk C, O’Regan T. The use of technology for mental healthcare delivery among older adults with depressive symptoms: A systematic literature review. Int J Ment Health Nurs. 2019;28(3):657–70. PMID: 30666762. 10.1111/inm.12571 30666762
201 Harper Shehadeh M, Heim E, Chowdhary N, . Cultural Adaptation of Minimally Guided Interventions for Common Mental Disorders: A Systematic Review and Meta-Analysis. JMIR Ment Health. 2016;3(3):e44. PMID: 27670598. 10.2196/mental.5776 27670598
202 Holvast F, Massoudi B, Oude Voshaar RC, . Non-pharmacological treatment for depressed older patients in primary care: A systematic review and meta-analysis. PLoS ONE [Electronic Resource]. 2017;12(9):e0184666. PMID: 28938015. 10.1371/journal.pone.0184666 28938015
203 Huang L, Zhao Y, Qiang C, . Is cognitive behavioral therapy a better choice for women with postnatal depression? A systematic review and meta-analysis. PLoS ONE [Electronic Resource]. 2018;13(10):e0205243. PMID: 30321198. 10.1371/journal.pone.0205243 30321198
204 Karyotaki E, Ebert DD, Donkin L, . Do guided internet-based interventions result in clinically relevant changes for patients with depression? An individual participant data meta-analysis. Clin Psychol Rev. 2018;63:80–92. PMID: 29940401. 10.1016/j.cpr.2018.06.007 29940401
205 Karyotaki E, Riper H, Twisk J, . Efficacy of Self-guided Internet-Based Cognitive Behavioral Therapy in the Treatment of Depressive Symptoms: A Meta-analysis of Individual Participant Data. JAMA Psychiatry. 2017;74(4):351–9. PMID: 28241179. 10.1001/jamapsychiatry.2017.0044 28241179
206 Letourneau NL, Dennis CL, Cosic N, . The effect of perinatal depression treatment for mothers on parenting and child development: A systematic review. Depress Anxiety. 2017;34(10):928–66. PMID: 28962068. 10.1002/da.22687 28962068
207 Massoudi B, Holvast F, Bockting CLH, . The effectiveness and cost-effectiveness of e-health interventions for depression and anxiety in primary care: A systematic review and meta-analysis. Journal of affective disorders. 2019;245:728–43. PMID: 30447572. 10.1016/j.jad.2018.11.050 30447572
208 Nair U, Armfield NR, Chatfield MD, . The effectiveness of telemedicine interventions to address maternal depression: A systematic review and meta-analysis. Journal of Telemedicine & Telecare. 2018;24(10):639–50. PMID: 30343660. 10.1177/1357633X18794332 30343660
209 Nieuwenhuijsen K, Verbeek JH, Neumeyer-Gromen A, . Interventions to improve return to work in depressed people. Cochrane Database Syst Rev. 2020;10:CD006237. PMID: 33052607. 10.1002/14651858.CD006237.pub4 33052607
210 Pineros-Leano M, Liechty JM, Piedra LM. Latino immigrants, depressive symptoms, and cognitive behavioral therapy: A systematic review. Journal of affective disorders. 2017;208:567–76. PMID: 27810273. 10.1016/j.jad.2016.10.025 27810273
211 Ponting C, Mahrer NE, Zelcer H, . Psychological interventions for depression and anxiety in pregnant Latina and Black women in the United States: A systematic review. Clinical Psychology & Psychotherapy. 2020;27(2):249–65. PMID: 31960525. 10.1002/cpp.2424 31960525
212 Rojas-Garcia A, Ruiz-Perez I, Rodriguez-Barranco M, . Healthcare interventions for depression in low socioeconomic status populations: A systematic review and meta-analysis. Clin Psychol Rev. 2015;38:65–78. PMID: 25797906. 10.1016/j.cpr.2015.03.001 25797906
213 Roman M, Constantin T, Bostan CM. The efficiency of online cognitive-behavioral therapy for postpartum depressive symptomatology: a systematic review and meta-analysis. Women Health. 2020;60(1):99–112. PMID: 31057080. 10.1080/03630242.2019.1610824 31057080
214 Thomas WJ, Hauson AO, Lambert JE, . A meta-analysis of the effectiveness of cognitive-behavioural therapies for late-life depression. Canadian Journal of Counselling and Psychotherapy. 2018;52(1):78–117.
215 Weaver A, Himle JA. Cognitive-behavioral therapy for depression and anxiety disorders in rural settings: A review of the literature. Journal of Rural Mental Health. 2017;41(3):189–221. 10.1037/rmh0000075
216 Weitz E, Kleiboer A, van Straten A, . The effects of psychotherapy for depression on anxiety symptoms: a meta-analysis. Psychol Med. 2018;48(13):2140–52. PMID: 29361995. 10.1017/s0033291717003622 29361995
217 Xiang X, Wu S, Zuverink A, . Internet-delivered cognitive behavioral therapies for late-life depressive symptoms: a systematic review and meta-analysis. Aging Ment Health. 2019:1–11. PMID: 3091389830913898. 10.1080/13607863.2019.1590309
218 Zhang A, Borhneimer LA, Weaver A, . Cognitive behavioral therapy for primary care depression and anxiety: a secondary meta-analytic review using robust variance estimation in meta-regression. J Behav Med. 2019;42(6):1117–41. PMID: 31004323. 10.1007/s10865-019-00046-z 31004323
219 Zhang A, Franklin C, Jing S, . The effectiveness of four empirically supported psychotherapies for primary care depression and anxiety: A systematic review and meta-analysis. Journal of affective disorders. 2019;245:1168–86. PMID: 30699860. 10.1016/j.jad.2018.12.008 30699860
220 Li X, Laplante DP, Paquin V, . Effectiveness of cognitive behavioral therapy for perinatal maternal depression, anxiety and stress: A systematic review and meta-analysis of randomized controlled trials. Clin Psychol Rev. 2022;92:102129. PMID: 35123346. 10.1016/j.cpr.2022.102129 35123346
221 Arroll B, Chin WY, Martis W, . Antidepressants for treatment of depression in primary care: a systematic review and meta-analysis. J Prim Health Care. 2016;8(4):325–34. PMID: 29530157. 10.1071/HC16008 29530157
222 Baune BT, Brignone M, Larsen KG. A Network Meta-Analysis Comparing Effects of Various Antidepressant Classes on the Digit Symbol Substitution Test (DSST) as a Measure of Cognitive Dysfunction in Patients with Major Depressive Disorder. Int J Neuropsychopharmcol. 2018;21(2):97–107. PMID: 29053849. 10.1093/ijnp/pyx070 29053849
223 Boesen K, Paludan-Muller AS, Munkholm K. Network meta-analysis of antidepressants. The Lancet. 2018;392(10152):1011. 10.1016/S0140-6736%2818%2931783-5
224 Cipriani A, Furukawa TA, Salanti G, . Comparative efficacy and acceptability of 21 antidepressant drugs for the acute treatment of adults with major depressive disorder: a systematic review and network meta-analysis. Lancet (London, England). 2018;391(10128):1357–66. PMID: 29477251. 10.1016/S0140-6736(17)32802-7 29477251
225 Cipriani A, Furukawa TA, Salanti G, . Comparative Efficacy and Acceptability of 21 Antidepressant Drugs for the Acute Treatment of Adults With Major Depressive Disorder: A Systematic Review and Network Meta-Analysis. Focus. 2018;16(4):420–9. PMID: 32021580. 10.1176/appi.focus.16407 32021580
226 Cuijpers P, de Wit L, Weitz E, . The combination of psychotherapy and pharmacotherapy in the treatment of adult depression: A comprehensive meta-analysis. Journal of Evidence-Based Psychotherapies. 2015;15(2):147–68.
227 Krause M, Gutsmiedl K, Bighelli I, . Efficacy and tolerability of pharmacological and non-pharmacological interventions in older patients with major depressive disorder: A systematic review, pairwise and network meta-analysis. Eur Neuropsychopharmacol. 2019;29(9):1003–22. PMID: 31327506. 10.1016/j.euroneuro.2019.07.130 31327506
228 Lee Y, Rosenblat JD, Lee J, . Efficacy of antidepressants on measures of workplace functioning in major depressive disorder: A systematic review. Journal of affective disorders. 2018;227:406–15. PMID: 29154157. 10.1016/j.jad.2017.11.003 29154157
229 Lisinski A, Hieronymus F, Naslund J, . Item-based analysis of the effects of duloxetine in depression: A patient-level post hoc study. Neuropsychopharmacology. 2020;45(3):553–60. PMID: 31521062. 10.1038/s41386-019-0523-4 31521062
230 Munkholm K, Paludan-Muller AS, Boesen K. Considering the methodological limitations in the evidence base of antidepressants for depression: a reanalysis of a network meta-analysis. BMJ Open. 2019;9(6):e024886. PMID: 31248914. 10.1136/bmjopen-2018-024886 31248914
231 Rabinowitz J, Werbeloff N, Mandel FS, . Initial depression severity and response to antidepressants v. placebo: patient-level data analysis from 34 randomised controlled trials. Br J Psychiatry. 2016;209(5):427–8. PMID: 27198482. 10.1192/bjp.bp.115.173906 27198482
232 Viswanathan M, Middleton JC, Stuebe AM, . Maternal, Fetal, and Child Outcomes of Mental Health Treatments in Women: A Meta-Analysis of Perinatal Pharmacotherapy. Psychiatric Research and Clinical Practice. 2021;3(3):123–40. 10.1176/appi.prcp.20210001 36101835
233 Cuijpers P, Reijnders M, Karyotaki E, . Negative effects of psychotherapies for adult depression: A meta-analysis of deterioration rates. Journal of affective disorders. 2018;239:138–45. PMID: 30005327. 10.1016/j.jad.2018.05.050 30005327
234 Ebert DD, Donkin L, Andersson G, . Does Internet-based guided-self-help for depression cause harm? An individual participant data meta-analysis on deterioration rates and its moderators in randomized controlled trials. Psychol Med. 2016;46(13):2679–93. PMID: 27649340. 10.1017/S0033291716001562 27649340
235 Jonsson U, Bertilsson G, Allard P, . Psychological Treatment of Depression in People Aged 65 Years and Over: A Systematic Review of Efficacy, Safety, and Cost-Effectiveness. PLoS ONE [Electronic Resource]. 2016;11(8):e0160859. PMID: 27537217. 10.1371/journal.pone.0160859 27537217
236 Karyotaki E, Kemmeren L, Riper H, . Is self-guided internet-based cognitive behavioural therapy (iCBT) harmful? An individual participant data meta-analysis. Psychol Med. 2018;48(15):2456–66. PMID: 29540243. 10.1017/s0033291718000648 29540243
237 Valuck RJ, Libby AM, Anderson HD, . Comparison of antidepressant classes and the risk and time course of suicide attempts in adults: propensity matched, retrospective cohort study. Br J Psychiatry. 2016;208(3):271–9. PMID: 26635328. 10.1192/bjp.bp.114.150839 26635328
238 Braun C, Bschor T, Franklin J, . Suicides and Suicide Attempts during Long-Term Treatment with Antidepressants: A Meta-Analysis of 29 Placebo-Controlled Studies Including 6,934 Patients with Major Depressive Disorder. Psychother Psychosom. 2016;85(3):171–9. PMID: 27043848. 10.1159/000442293 27043848
239 Chan JYC, Yiu KKL, Kwok TCY, . Depression and Antidepressants as Potential Risk Factors in Dementia: A Systematic Review and Meta-analysis of 18 Longitudinal Studies. J Am Med Dir Assoc. 2019;20(3):279–86.e1. PMID: 30711460. 10.1016/j.jamda.2018.12.004 30711460
240 Gibbons RD, Brown CH, Hur K, . Suicidal thoughts and behavior with antidepressant treatment: reanalysis of the randomized placebo-controlled studies of fluoxetine and venlafaxine. Archives of general psychiatry. 2012;69(6):580–7. PMID: 22309973. 10.1001/archgenpsychiatry.2011.2048 22309973
241 Hengartner MP, Amendola S, Kaminski JA, . Suicide risk with selective serotonin reuptake inhibitors and other new-generation antidepressants in adults: a systematic review and meta-analysis of observational studies. J Epidemiol Community Health. 2021. PMID: 3368596433685964. 10.1136/jech-2020-214611
242 Jacobsen PL. Antidepressant-associated sexual dysfunction in patients with depression: A meta-analysis of sexual functioning data collected via prospective questionnaires. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2019;80(8-B(E)):No Pagination Specified.
243 Jakobsen JC, Katakam KK, Schou A, . Selective serotonin reuptake inhibitors versus placebo in patients with major depressive disorder. A systematic review with meta-analysis and Trial Sequential Analysis. BMC Psychiatry. 2017;17(1):58. PMID: 28178949. 10.1186/s12888-016-1173-2 28178949
244 Jensen MP, Ziff OJ, Banerjee G, . The impact of selective serotonin reuptake inhibitors on the risk of intracranial haemorrhage: A systematic review and meta-analysis. European Stroke Journal. 2019;4(2):144–52. PMID: 31259262. 10.1177/2396987319827211 31259262
245 Kaminski JA, Bschor T. Antidepressants and suicidality: A re-analysis of the re-analysis. Journal of affective disorders. 2020;266:95–9. PMID: 32056952. 10.1016/j.jad.2020.01.107 32056952
246 Khanassov V, Hu J, Reeves D, . Selective serotonin reuptake inhibitor and selective serotonin and norepinephrine reuptake inhibitor use and risk of fractures in adults: A systematic review and meta-analysis. Int J Geriatr Psychiatry. 2018;33(12):1688–708. PMID: 30247774. 10.1002/gps.4974 30247774
247 KoKoAung E, Cavenett S, McArthur A, . The association between suicidality and treatment with selective serotonin reuptake inhibitors in older people with major depression: a systematic review. JBI Database System Rev Implement Rep. 2015;13(3):174–205. PMID: 26447056. 10.11124/jbisrir-2015-2272 26447056
248 Kunutsor SK, Seidu S, Khunti K. Depression, antidepressant use, and risk of venous thromboembolism: systematic review and meta-analysis of published observational evidence. Ann Med. 2018;50(6):529–37. PMID: 30001640. 10.1080/07853890.2018.1500703 30001640
249 Maslej MM, Bolker BM, Russell MJ, . The Mortality and Myocardial Effects of Antidepressants Are Moderated by Preexisting Cardiovascular Disease: A Meta-Analysis. Psychother Psychosom. 2017;86(5):268–82. PMID: 28903117. 10.1159/000477940 28903117
250 Na KS, Jung HY, Cho SJ, . Can we recommend mirtazapine and bupropion for patients at risk for bleeding?: A systematic review and meta-analysis. Journal of affective disorders. 2018;225:221–6. PMID: 28841484. 10.1016/j.jad.2017.08.002 28841484
251 Naslund J, Hieronymus F, Lisinski A, . Effects of selective serotonin reuptake inhibitors on rating-scale-assessed suicidality in adults with depression. The British Journal of Psychiatry. 2018;212(3):148–54. 10.1192/bjp.2017.24 29436321
252 Sobieraj DM, Martinez BK, Hernandez AV, . Adverse Effects of Pharmacologic Treatments of Major Depression in Older Adults. J Am Geriatr Soc. 2019;67(8):1571–81. PMID: 31140587. 10.1111/jgs.15966 31140587
253 Trajkova S, d’Errico A, Soffietti R, . Use of Antidepressants and Risk of Incident Stroke: A Systematic Review and Meta-Analysis. Neuroepidemiology. 2019;53(3-4):142–51. PMID: 31216542. 10.1159/000500686 31216542
254 Wang YC, Tai PA, Poly TN, . Increased Risk of Dementia in Patients with Antidepressants: A Meta-Analysis of Observational Studies. Behav. 2018;2018:5315098. PMID: 30123386. 10.1155/2018/5315098 30123386
255 Gumusoglu SB, Schickling BM, Vignato JA, . Selective serotonin reuptake inhibitors and preeclampsia: A quality assessment and meta-analysis. Pregnancy Hypertens. 2022;30:36–43. PMID: 35963154. 10.1016/j.preghy.2022.08.001 35963154
256 Khan A, Fahl Mar K, Gokul S, . Decreased suicide rates in recent antidepressant clinical trials. Psychopharmacology (Berl). 2018;235(5):1455–62. PMID: 29480436. 10.1007/s00213-018-4856-1 29480436
257 Vlenterie R, van Gelder M, Anderson HR, . Associations Between Maternal Depression, Antidepressant Use During Pregnancy, and Adverse Pregnancy Outcomes: An Individual Participant Data Meta-analysis. Obstetrics and gynecology. 2021;138(4):633–46. PMID: 34623076. 10.1097/AOG.0000000000004538 34623076
258 Fifer S, Mathias S, Patrick D, . Untreated anxiety among adult primary care patients in a Health Maintenance Organization. Archives of general psychiatry. 1994;51(9):740–50. PMID: CN-00713166.8080351
259 Mathias SD, Fifer SK, Mazonson PD, . Necessary but not sufficient: the effect of screening and feedback on outcomes of primary care patients with untreated anxiety. Journal of general internal medicine. 1994;9(11):606–15. PMID: 7853069. 10.1007/BF02600303 7853069
260 Yelin E, Mathias SD, Buesching DP, . The impact on unemployment of an intervention to increase recognition of previously untreated anxiety among primary care physicians. Soc Sci Med. 1996;42(7):1069–75. PMID: 8730912. 10.1016/0277-9536(95)00297-9 8730912
261 Ahn JK, Kim Y, Choi KH. The Psychometric Properties and Clinical Utility of the Korean Version of GAD-7 and GAD-2. Front Psychiatr. 2019;10:127. PMID: 30936840. 10.3389/fpsyt.2019.00127 30936840
262 Austin MV, Mule V, Hadzi-Pavlovic D, . Screening for anxiety disorders in third trimester pregnancy: a comparison of four brief measures. Arch Women Ment Health. 2021;05:05. PMID: 34350480. 10.1007/s00737-021-01166-9 34350480
263 Gould CE, Segal DL, Yochim BP, . Measuring anxiety in late life: a psychometric examination of the geriatric anxiety inventory and geriatric anxiety scale. Journal of Anxiety Disorders. 2014;28(8):804–11. PMID: 25271176. 10.1016/j.janxdis.2014.08.001 25271176
264 Kujanpaa T, Ylisaukko-Oja T, Jokelainen J, . Prevalence of anxiety disorders among Finnish primary care high utilizers and validation of Finnish translation of GAD-7 and GAD-2 screening tools. Scand J Prim Health Care. 2014;32(2):78–83. PMID: 24920316. 10.3109/02813432.2014.920597 24920316
265 Makulowich AA. Identification of patients with anxiety symptoms in an integrated community care clinic among a predominantly Latino patient population. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2019;80(1-B(E)):No Pagination Specified.
266 Matthey S, Valenti B, Souter K, . Comparison of four self-report measures and a generic mood question to screen for anxiety during pregnancy in English-speaking women. Journal of affective disorders. 2013;148(2-3):347–51. PMID: 23380518. 10.1016/j.jad.2012.12.022 23380518
267 Nath S, Ryan EG, Trevillion K, . Prevalence and identification of anxiety disorders in pregnancy: the diagnostic accuracy of the two-item Generalised Anxiety Disorder scale (GAD-2). BMJ Open. 2018;8(9):e023766. PMID: 30185582. 10.1136/bmjopen-2018-023766 30185582
268 Preville M, Boyer R, Grenier S, . The epidemiology of psychiatric disorders in Quebec’s older adult population. Can J Psychiatry. 2008;53(12):822–32. PMID: 19087480. 10.1177/070674370805301208 19087480
269 Spitzer RL, Kroenke K, Williams JB. Validation and utility of a self-report version of PRIME-MD: the PHQ primary care study. Primary Care Evaluation of Mental Disorders. Patient Health Questionnaire. Jama. 1999/11/24 ed1999. p. 1737–44. PMID: 1056864610568646. 10.1001/jama.282.18.1737
270 Spitzer RL, Kroenke K, Williams JB, . A brief measure for assessing generalized anxiety disorder: the GAD-7. Arch Intern Med. 2006;166(10):1092–7. PMID: 16717171. 10.1001/archinte.166.10.1092 16717171
271 Vasiliadis HM, Chudzinski V, Gontijo-Guerra S, . Screening instruments for a population of older adults: The 10-item Kessler Psychological Distress Scale (K10) and the 7-item Generalized Anxiety Disorder Scale (GAD-7). Psychiatry Res. 2015;228(1):89–94. PMID: 25956759. 10.1016/j.psychres.2015.04.019 25956759
272 Brettschneider C, Gensichen J, Hiller TS, . Cost-effectiveness of Practice Team-Supported Exposure Training for Panic Disorder and Agoraphobia in Primary Care: a Cluster-Randomized Trial. Journal of general internal medicine. 2020;35(4):1120–6. PMID: 31965532. 10.1007/s11606-020-05658-9 31965532
273 Brown LA, Krull JL, Roy-Byrne P, . An examination of the bidirectional relationship between functioning and symptom levels in patients with anxiety disorders in the CALM study. Psychol Med. 2015;45(3):647–61. PMID: 25272965. 10.1017/S0033291714002062 25272965
274 Burger H, Verbeek T, Aris-Meijer JL, . Effects of psychological treatment of mental health problems in pregnant women to protect their offspring: randomised controlled trial. Br J Psychiatry. 2020;216(4):182–8. PMID: 31806071. 10.1192/bjp.2019.260 31806071
275 Corpas J, Moriana JA, Vencesla JF, . Effectiveness of brief group transdiagnostic therapy for emotional disorders in primary care: A randomized controlled trial identifying predictors of outcome. Psychother. 2021:1–14. PMID: 3426964034269640. 10.1080/10503307.2021.1952331
276 Craske MG, Stein MB, Sullivan G, . Disorder-specific impact of coordinated anxiety learning and management treatment for anxiety disorders in primary care. Archives of general psychiatry. 2011;68(4):378–88. PMID: 21464362. 10.1001/archgenpsychiatry.2011.25 21464362
277 Fletcher J, Lovell K, Bower P, . Process and Outcome of a Non-Guided Self-Help Manual for Anxiety and Depression in Primary Care: A Pilot Study. Behav. 2005;33(3):319–31. 10.1017/S1352465805002079
278 Gensichen J, Hiller TS, Breitbart J, . Panic Disorder in Primary Care. Dtsch. 2019;116(10):159–66. PMID: 30995952. 10.3238/arztebl.2019.0159 30995952
279 Geramita EM, Herbeck Belnap B, Abebe KZ, . The Association Between Increased Levels of Patient Engagement With an Internet Support Group and Improved Mental Health Outcomes at 6-Month Follow-Up: Post-Hoc Analyses From a Randomized Controlled Trial. J Med Internet Res. 2018;20(7):e10402. PMID: 30021711. 10.2196/10402 30021711
280 Graham AK, Greene CJ, Kwasny MJ, . Coached Mobile App Platform for the Treatment of Depression and Anxiety Among Primary Care Patients: A Randomized Clinical Trial. JAMA Psychiatry. 2020;20:20. PMID: 32432695. 10.1001/jamapsychiatry.2020.1011 32432695
281 Jonassaint CR, Belnap BH, Huang Y, . Racial Differences in the Effectiveness of Internet-Delivered Mental Health Care. Journal of general internal medicine. 2020;35(2):490–7. PMID: 31745855. 10.1007/s11606-019-05542-1 31745855
282 Jonassaint CR, Gibbs P, Belnap BH, . Engagement and outcomes for a computerised cognitive-behavioural therapy intervention for anxiety and depression in African Americans. BJPsych open. 2017;3(1):1–5. PMID: 28058109. 10.1192/bjpo.bp.116.003657 28058109
283 Kendrick T, Simons L, Mynors-Wallis L, . A trial of problem-solving by community mental health nurses for anxiety, depression and life difficulties among general practice patients. The CPN-GP study. Health Technol Assess. 2005;9(37):1–104, iii. PMID: 16153354. 10.3310/hta9370 16153354
284 King M, Sibbald B, Ward E, . Randomised controlled trial of non-directive counselling, cognitive-behaviour therapy and usual general practitioner care in the management of depression as well as mixed anxiety and depression in primary care. Health Technol Assess. 2000;4(19):1–83. PMID: 11086269.11086269
285 Lam CLK, Fong DYT, Chin WY, . Brief problem-solving treatment in primary care (PST-PC) was not more effective than placebo for elderly patients screened positive of psychological problems. Int J Geriatr Psychiatry. 2010;25(10):968. 10.1002/gps.2435 20033901
286 Lang AJ, Norman GJ, Casmar PV. A randomized trial of a brief mental health intervention for primary care patients. J Consult Clin Psychol. 2006;74(6):1173–9. PMID: 17154746. 10.1037/0022-006x.74.6.1173 17154746
287 Lenox-Smith AJ, Reynolds A. A double-blind, randomised, placebo controlled study of venlafaxine XL in patients with generalised anxiety disorder in primary care. Br J Gen Pract. 2003;53(495):772–7. PMID: 14601352.14601352
288 Lenze EJ, Rollman BL, Shear MK, . Escitalopram for older adults with generalized anxiety disorder: a randomized controlled trial. Jama. 2009;301(3):295–303. PMID: 19155456. 10.1001/jama.2008.977 19155456
289 Linden M, Zubraegel D, Baer T, . Efficacy of cognitive behaviour therapy in generalized anxiety disorders. Results of a controlled clinical trial (Berlin CBT-GAD Study). Psychother Psychosom. 2005;74(1):36–42. PMID: 15627855. 10.1159/000082025 15627855
290 Nordgren LB, Hedman E, Etienne J, . Effectiveness and cost-effectiveness of individually tailored Internet-delivered cognitive behavior therapy for anxiety disorders in a primary care population: a randomized controlled trial. Behav Res Ther. 2014;59:1–11. PMID: 24933451. 10.1016/j.brat.2014.05.007 24933451
291 Proudfoot J, Goldberg D, Mann A, . Computerized, interactive, multimedia cognitive-behavioural program for anxiety and depression in general practice. Psychol Med. 2003;33(2):217–27. PMID: 12622301. 10.1017/s0033291702007225 12622301
292 Proudfoot J, Ryden C, Everitt B, . Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry. 2004;185:46–54. PMID: 15231555. 10.1192/bjp.185.1.46 15231555
293 Rollman BL, Herbeck Belnap B, Abebe KZ, . Effectiveness of Online Collaborative Care for Treating Mood and Anxiety Disorders in Primary Care: A Randomized Clinical Trial. JAMA Psychiatry. 2018;75(1):56–64. PMID: 29117275. 10.1001/jamapsychiatry.2017.3379 29117275
294 Roy-Byrne P, Craske MG, Sullivan G, . Delivery of evidence-based treatment for multiple anxiety disorders in primary care: a randomized controlled trial. JAMA. 2010;303(19):1921–8. PMID: 20483968. 10.1001/jama.2010.608 20483968
295 Schreuders B, van Marwijk H, Smit J, . Primary care patients with mental health problems: outcome of a randomised clinical trial. British Journal of General Practice. 2007;57(544):886–91. PMID: 17976289. 10.3399/096016407782317829 17976289
296 Seekles W, van Straten A, Beekman A, . Effectiveness of guided self-help for depression and anxiety disorders in primary care: a pragmatic randomized controlled trial. Psychiatry Res. 2011;187(1-2):113–20. PMID: 21145112. 10.1016/j.psychres.2010.11.015 21145112
297 Stanley MA, Wilson NL, Amspoker AB, . Lay providers can deliver effective cognitive behavior therapy for older adults with generalized anxiety disorder: a randomized trial. Depress Anxiety. 2014;31(5):391–401. PMID: 24577847. 10.1002/da.22239 24577847
298 Stanley MA, Wilson NL, Novy DM, . Cognitive behavior therapy for generalized anxiety disorder among older adults in primary care: a randomized clinical trial. Jama. 2009;301(14):1460–7. PMID: 19351943. 10.1001/jama.2009.458 19351943
299 Sundquist J, Lilja Å, Palmér K, . Mindfulness group therapy in primary care patients with depression, anxiety and stress and adjustment disorders: randomised controlled trial. Br J Psychiatry. 2015;206(2):128–35. PMID: 25431430. 10.1192/bjp.bp.114.150243 25431430
300 Sundquist J, Palmer K, Johansson LM, . The effect of mindfulness group therapy on a broad range of psychiatric symptoms: A randomised controlled trial in primary health care. Eur Psychiatry. 2017;43:19–27. PMID: 28365464. 10.1016/j.eurpsy.2017.01.328 28365464
301 Sundquist J, Palmér K, Memon AA, . Long-term improvements after mindfulness-based group therapy of depression, anxiety and stress and adjustment disorders: a randomized controlled trial. Early intervention in psychiatry. 2018. PMID: CN-01628896. 10.1111/eip.12715
302 Torres-Platas SG, Escobar S, Belliveau C, . Mindfulness-Based Cognitive Therapy Intervention for the Treatment of Late-Life Depression and Anxiety Symptoms in Primary Care: A Randomized Controlled Trial. Psychother Psychosom. 2019;88(4):254–6. PMID: 31288245. 10.1159/000501214 31288245
303 Wolitzky-Taylor K, Brown LA, Roy-Byrne P, . The impact of alcohol use severity on anxiety treatment outcomes in a large effectiveness trial in primary care. Journal of Anxiety Disorders. 2015;30:88–93. PMID: 25615523. 10.1016/j.janxdis.2014.12.011 25615523
304 Vera M, Oben A, Juarbe D, . Randomized pilot trial of cognitive-behavioral therapy and acceptance-based behavioral therapy in the treatment of Spanish-speaking Latino primary care patients with generalized anxiety disorder. Journal of Behavioral and Cognitive Therapy. 2021;31(2):91–103. PMID: 35813157. 10.1016/j.jbct.2020.11.007 35813157
305 Clark DM, Wild J, Warnock-Parkes E, . More than doubling the clinical benefit of each hour of therapist time: a randomised controlled trial of internet cognitive therapy for social anxiety disorder. Psychol Med. 2022:1–11. PMID: 3583572635835726. 10.1017/S0033291722002008
306 O’Mahen HA, Ramchandani PG, King DX, . Adapting and testing a brief intervention to reduce maternal anxiety during pregnancy (ACORN): report of a feasibility randomized controlled trial. BMC Psychiatry. 2022;22(1):129. PMID: 35177019. 10.1186/s12888-022-03737-1 35177019
307 Suchan V, Peynenburg V, Thiessen D, . Transdiagnostic Internet-Delivered Cognitive Behavioral Therapy for Symptoms of Postpartum Anxiety and Depression: Feasibility Randomized Controlled Trial. JMIR Form Res. 2022;6(9):e37216. PMID: 36066958. 10.2196/37216 36066958
308 Suchan VAM. Examining the acceptability and effectiveness of transdiagnostic, internet-delivered cognitive behaviour therapy for symptoms of postpartum anxiety and depression: A randomized controlled trial. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2022;83(10-B):No Pagination Specified.
309 Balasubramaniam M, Joshi P, Alag P, . Antidepressants for anxiety disorders in late-life: A systematic review. Ann Clin Psychiatry. 2019;31(4):277–91. PMID: 31369663.31369663
310 Bighelli I, Castellazzi M, Cipriani A, . Antidepressants versus placebo for panic disorder in adults. Cochrane Database Syst Rev. 2018;4:CD010676. PMID: 29620793. 10.1002/14651858.CD010676.pub2 29620793
311 Breilmann J, Girlanda F, Guaiana G, . Benzodiazepines versus placebo for panic disorder in adults. Cochrane Database Syst Rev. 2019;3:CD010677. PMID: 30921478. 10.1002/14651858.CD010677.pub2 30921478
312 Chen TR, Huang HC, Hsu JH, . Pharmacological and psychological interventions for generalized anxiety disorder in adults: A network meta-analysis. J Psychiatr Res. 2019;118:73–83. PMID: 31494377. 10.1016/j.jpsychires.2019.08.014 31494377
313 Cuijpers P, Cristea IA, Karyotaki E, . How effective are cognitive behavior therapies for major depression and anxiety disorders? A meta-analytic update of the evidence. World psychiatry : official journal of the World Psychiatric Association (WPA). 2016;15(3):245–58. PMID: 27717254. 10.1002/wps.20346 27717254
314 Cuijpers P, Cristea IA, Weitz E, . The effects of cognitive and behavioural therapies for anxiety disorders on depression: a meta-analysis. Psychol Med. 2016;46(16):3451–62. PMID: 27659840. 10.101https://dx.doi.org/7/S0033291716002348 27659840
315 Gould RL, Coulson MC, Howard RJ. Efficacy of cognitive behavioral therapy for anxiety disorders in older people: a meta-analysis and meta-regression of randomized controlled trials. J Am Geriatr Soc. 2012;60(2):218–29. PMID: 22283717. 10.1111/j.1532-5415.2011.03824.x 22283717
316 Gupta A, Bhattacharya G, Farheen SA, . Systematic review of benzodiazepines for anxiety disorders in late life. Ann Clin Psychiatry. 2020;32(2):114–27. PMID: 32343283.32343283
317 Hofmann SG, Wu JQ, Boettcher H. Effect of cognitive-behavioral therapy for anxiety disorders on quality of life: a meta-analysis. J Consult Clin Psychol. 2014;82(3):375–91. PMID: 24447006. 10.1037/a0035491 24447006
318 Imai H, Tajika A, Chen P, . Azapirones versus placebo for panic disorder in adults. Cochrane Database Syst Rev. 2014(9). PMID: CD010828. 10.1002/14651858.CD010828.pub2
319 Roest AM, de Jonge P, Williams CD, . Reporting Bias in Clinical Trials Investigating the Efficacy of Second-Generation Antidepressants in the Treatment of Anxiety Disorders: A Report of 2 Meta-analyses. JAMA Psychiatry. 2015;72(5):500–10. PMID: 25806940. 10.1001/jamapsychiatry.2015.15 25806940
320 Slee A, Nazareth I, Bondaronek P, . Pharmacological treatments for generalised anxiety disorder: a systematic review and network meta-analysis. Lancet (London, England). 2019;393(10173):768–77. PMID: 30712879. 10.1016/S0140-6736(18)31793-8 30712879
321 van Dis EAM, van Veen SC, Hagenaars MA, . Long-term Outcomes of Cognitive Behavioral Therapy for Anxiety-Related Disorders: A Systematic Review and Meta-analysis. JAMA Psychiatry. 2020;77(3):265–73. PMID: 31758858. 10.1001/jamapsychiatry.2019.3986 31758858
322 Williams T, Hattingh CJ, Kariuki CM, . Pharmacotherapy for social anxiety disorder (SAnD). Cochrane Database Syst Rev. 2017;10:CD001206. PMID: 29048739. 10.1002/14651858.CD001206.pub3 29048739
323 Maguire PN, Clark GI, Wootton BM. The efficacy of cognitive behavior therapy for the treatment of perinatal anxiety symptoms: A preliminary meta-analysis. Journal of Anxiety Disorders. 2018;60:26–34. PMID: 30388545. 10.1016/j.janxdis.2018.10.002 30388545
324 Lader M, Scotto JC. A multicentre double-blind comparison of hydroxyzine, buspirone and placebo in patients with generalized anxiety disorder. Psychopharmacology (Berl). 1998;139(4):402–6. PMID: 9809861. 10.1007/s002130050731 9809861
325 Cato V, Hollandare F, Nordenskjold A, . Association between benzodiazepines and suicide risk: a matched case-control study. BMC Psychiatry. 2019;19(1):317. PMID: 31655565. 10.1186/s12888-019-2312-3 31655565
326 Sheehy O, Zhao JP, Berard A. Association Between Incident Exposure to Benzodiazepines in Early Pregnancy and Risk of Spontaneous Abortion. JAMA Psychiatry. 2019;15:15. PMID: 31090881. 10.1001/jamapsychiatry.2019.0963 31090881
327 Crawford MJ, Thana L, Methuen C, . Impact of screening for risk of suicide: randomised controlled trial. Br J Psychiatry. 2011;198:379–84. PMID: 21525521. 10.1192/bjp.bp.110.083592 21525521
328 Desjardins I, Cats-Baril W, Maruti S, . Suicide Risk Assessment in Hospitals: An Expert System-Based Triage Tool. Journal of Clinical Psychiatry. 2016;77(7):e874–82. PMID: 27314465. 10.4088/JCP.15m09881 27314465
329 Heisel MJ, Duberstein PR, Lyness JM, . Screening for suicide ideation among older primary care patients. Journal of the American Board of Family Medicine : JABFM. 2010;23(2):260–9. PMID: 20207936. 10.3122/jabfm.2010.02.080163 20207936
330 Olfson M, Weissman MM, Leon AC, . Suicidal ideation in primary care. Journal of general internal medicine. 1996;11(8):447–53. PMID: 8872781. 10.1007/BF02599038 8872781
331 Alexopoulos GS, Reynolds CF, III, Bruce ML, . Reducing suicidal ideation and depression in older primary care patients: 24-month outcomes of the PROSPECT study. Am J Psychiatry. 2009;166(8):882–90. PMID: 19528195. 10.1176/appi.ajp.2009.08121779 19528195
332 Bao Y, Alexopoulos GS, Casalino LP, . Collaborative depression care management and disparities in depression treatment and outcomes. Archives of General Psychiatry2011. p. 627–36. PMID: 2164657921646579. 10.1001/archgenpsychiatry.2011.55
333 Barnicot K, Savill M, Bhatti N, . A pragmatic randomised controlled trial of dialectical behaviour therapy: effects on hospitalisation and post-treatment follow-up. Psychother Psychosom. 2014;83(3):192–3. PMID: 24752222. 10.1159/000357365 24752222
334 Bogner HR, Joo JH, Hwang S, . Does a Depression Management Program Decrease Mortality in Older Adults with Specific Medical Conditions in Primary Care? An Exploratory Analysis. J Am Geriatr Soc. 2016;64(1):126–31. PMID: 26782861. 10.1111/jgs.13711 26782861
335 Bogner HR, Morales KH, Post EP, . Diabetes, depression, and death: a randomized controlled trial of a depression treatment program for older adults based in primary care (PROSPECT). Diabetes Care. 2007;30(12):3005–10. PMID: 17717284. 10.2337/dc07-0974 17717284
336 Borschmann R, Barrett B, Hellier JM, . Joint crisis plans for people with borderline personality disorder: feasibility and outcomes in a randomised controlled trial. Br J Psychiatry. 2013;202(5):357–64. PMID: 23637110. 10.1192/bjp.bp.112.117762 23637110
337 Bruce ML, Ten Have TR, Reynolds CF, III, . Reducing suicidal ideation and depressive symptoms in depressed older primary care patients: a randomized controlled trial. JAMA. 2004;291(9):1081–91. PMID: 14996777. 10.1001/jama.291.9.1081 14996777
338 Bush NE, Smolenski DJ, Denneson LM, . A Virtual Hope Box: Randomized Controlled Trial of a Smartphone App for Emotional Regulation and Coping With Distress. Psychiatr Serv. 2017;68(4):330–6. PMID: 27842473. 10.1176/appi.ps.201600283 27842473
339 Byers AL, Bruce ML, Raue P. Suicidal ideation in non-depressed elderly primary care patients: The PROSPECT Study. Am J Geriatr Psychiatry. 2009;17:A86.
340 Carter GL, Willcox CH, Lewin TJ, . Hunter DBT project: randomized controlled trial of dialectical behaviour therapy in women with borderline personality disorder. Aust N Z J Psychiatry. 2010;44(2):162–73. PMID: 20113305. 10.3109/00048670903393621 20113305
341 Coyne JC, Koppel J, Colenda CC, . Interventions for treatment of depression in primary care. JAMA. 2004;291(23):2814–6. PMID: 15199023. 10.1001/jama.291.23.2814-a 15199023
342 Davidson K, Norrie J, Tyrer P, . The effectiveness of cognitive behavior therapy for borderline personality disorder: results from the borderline personality disorder study of cognitive therapy (BOSCOT) trial. J Pers Disord. 2006;20(5):450–65. PMID: 17032158. 10.1521/pedi.2006.20.5.450 17032158
343 Franklin JC, Fox KR, Franklin CR, . A brief mobile app reduces nonsuicidal and suicidal self-injury: Evidence from three randomized controlled trials. J Consult Clin Psychol. 2016;84(6):544–57. PMID: 27018530. 10.1037/ccp0000093 27018530
344 Gallo JJ, Bogner HR, Morales KH, . The effect of a primary care practice-based depression intervention on mortality in older adults: a randomized trial. Ann Intern Med. 2007;146(10):689–98. PMID: 17502629. 10.7326/0003-4819-146-10-200705150-00002 17502629
345 Goodman M, Banthin D, Blair NJ, . A Randomized Trial of Dialectical Behavior Therapy in High-Risk Suicidal Veterans. Journal of Clinical Psychiatry. 2016;77(12):e1591–e600. PMID: 27780335. 10.4088/JCP.15m10235 27780335
346 Harned MS, Jackson SC, Comtois KA, . Dialectical behavior therapy as a precursor to PTSD treatment for suicidal and/or self-injuring women with borderline personality disorder. Journal of Traumatic Stress2010. p. 421–9. PMID: 2064856420648564. 10.1002/jts.20553
347 Jobes D, Comtois K, Gutierrez P, . A Randomized Controlled Trial of the Collaborative Assessment and Management of Suicidality versus Enhanced Care as Usual With Suicidal Soldiers. Psychiatry (new york). 2017;80(4):339–56. PMID: CN-01466006. 10.1080/00332747.2017.1354607
348 Kovac SH, Range LM. Does writing about suicidal thoughts and feelings reduce them? Suicide & life-threatening behavior. 2002;32(4):428–40. PMID: 12501967. 10.1521/suli.32.4.428.22335 12501967
349 Linehan MM, Comtois KA, Murray AM, . Two-year randomized controlled trial and follow-up of dialectical behavior therapy vs therapy by experts for suicidal behaviors and borderline personality disorder. Archives of general psychiatry. 2006;63(7):757–66. PMID: 16818865. 10.1001/archpsyc.63.7.757 16818865
350 McMain SF, Guimond T, Barnhart R, . A randomized trial of brief dialectical behaviour therapy skills training in suicidal patients suffering from borderline disorder. Acta Psychiatr Scand. 2017;135(2):138–48. PMID: 27858962. 10.1111/acps.12664 27858962
351 Muhlmann C, Madsen T, Hjorthoj C, . Effectiveness of an Internet-Based Self-help Therapy Program for Suicidal Ideation With Follow-up at 6 Months: Results of a Randomized Controlled Trial. Journal of Clinical Psychiatry. 2021;82(5):31. PMID: 34464522. 10.4088/JCP.20m13803 34464522
352 Norrie J, Davidson K, Tata P, . Influence of therapist competence and quantity of cognitive behavioural therapy on suicidal behaviour and inpatient hospitalisation in a randomised controlled trial in borderline personality disorder: further analyses of treatment effects in the BOSCOT study. Psychol Psychother. 2013;86(3):280–93. PMID: 23420622. 10.1111/papt.12004 23420622
353 Pigeon WR, Funderburk JS, Cross W, . Brief CBT for insomnia delivered in primary care to patients endorsing suicidal ideation: a proof-of-concept randomized clinical trial. Transl Behav Med. 2019;9(6):1169–77. PMID: 31271210. 10.1093/tbm/ibz108 31271210
354 Pistorello J, Fruzzetti AE, Maclane C, . Dialectical behavior therapy (DBT) applied to college students: a randomized clinical trial. J Consult Clin Psychol. 2012;80(6):982–94. PMID: 22730955. 10.1037/a0029096 22730955
355 Priebe S, Bhatti N, Barnicot K, . Effectiveness and cost-effectiveness of dialectical behaviour therapy for self-harming patients with personality disorder: a pragmatic randomised controlled trial. Psychother Psychosom. 2012;81(6):356–65. PMID: 22964561. 10.1159/000338897 22964561
356 Reynolds SK, Lindenboim N, Comtois KA, . Risky assessments: participant suicidality and distress associated with research assessments in a treatment study of suicidal behavior. Suicide Life Threat Behav. 2006;36(1):19–34. PMID: 16676622. 10.1521/suli.2006.36.1.19 16676622
357 Thombs BD, Ziegelstein RC. Diabetes, depression, and death: a randomized controlled trial of a depression treatment program for older adults based in primary care (PROSPECT): response to Bogner et al. Diabetes Care. 2008;31(6):e54–e. PMID: 18509141. 10.2337/dc08-0446 18509141
358 van Spijker B, van Straten A, Kerkhof A. Effectiveness of online self-help for suicidal thoughts: results of a randomised controlled trial. PloS one. 2014;9(2):e90118. PMID: 24587233. 10.1371/journal.pone.0090118 24587233
359 van Orden KA, Arean PA, Conwell Y. A Pilot Randomized Trial of Engage Psychotherapy to Increase Social Connection and Reduce Suicide Risk in Later Life. Am J Geriatr Psychiatry. 2021;29(8):789–800. PMID: 33952416. 10.1016/j.jagp.2021.03.009 33952416
360 Ward-Ciesielski EF. An open pilot feasibility study of a brief dialectical behavior therapy skills-based intervention for suicidal individuals. Suicide & life-threatening behavior. 2013;43(3):324–35. PMID: 23409778. 10.1111/sltb.12019 23409778
361 Ward-Ciesielski EF, Tidik JA, Edwards AJ, . Comparing brief interventions for suicidal individuals not engaged in treatment: A randomized clinical trial. Journal of affective disorders. 2017;222:153–61. PMID: 28709022. 10.1016/j.jad.2017.07.011 28709022
362 Katz IR, Rogers MP, Lew R, . Lithium Treatment in the Prevention of Repeat Suicide-Related Outcomes in Veterans With Major Depression or Bipolar Disorder: A Randomized Clinical Trial. JAMA Psychiatry. 2022;79(1):24–32. PMID: 34787653. 10.1001/jamapsychiatry.2021.3170 34787653
363 Pistorello J, Jobes DA, Gallop R, . A Randomized Controlled Trial of the Collaborative Assessment and Management of Suicidality (CAMS) Versus Treatment as Usual (TAU) for Suicidal College Students. Arch. 2021;25(4):765–89. PMID: 32275480. 10.1080/13811118.2020.1749742 32275480
364 Riblet NB, Kenneally L, Stevens S, . A virtual, pilot randomized trial of a brief intervention to prevent suicide in an integrated healthcare setting. General hospital psychiatry. 2022;75:68–74. PMID: 35202942. 10.1016/j.genhosppsych.2022.02.002 35202942
365 Simon GE, Shortreed SM, Rossom RC, . Effect of Offering Care Management or Online Dialectical Behavior Therapy Skills Training vs Usual Care on Self-harm Among Adult Outpatients With Suicidal Ideation: A Randomized Clinical Trial. JAMA. 2022;327(7):630–8. PMID: 35166800. 10.1001/jama.2022.0423 35166800
366 Torok M, Han J, McGillivray L, . The effect of a therapeutic smartphone application on suicidal ideation in young adults: Findings from a randomized controlled trial in Australia. PLoS Med. 2022;19(5):e1003978. PMID: 35639672. 10.1371/journal.pmed.1003978 35639672
367 Hewitt C, Gilbody S, Brealey S, . Methods to identify postnatal depression in primary care: an integrated evidence synthesis and value of information analysis. Health Technol Assess. 2009;13(36):1–145, 7–230. PMID: 19624978. 10.3310/hta13360 19624978
368 Rhee TG, Wilkinson ST, Steffens DC, . Prevalence of Treatment for Depression Among US Adults Who Screen Positive for Depression, 2007-2016. JAMA Psychiatry. 2020;77(11):1193–5. 10.1001/jamapsychiatry.2020.1818 32609306
369 Administration SAaMHS. Key Substance Use And Mental Health Indicators In The United States: Results From The 2015 National Survey On Drug Use And Health. Rockville, MD: Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration; 2017.
370 Canadian Task Force on Preventive Health Care. Summary of recommendations for clinicians and policy-makers. https://canadiantaskforce.ca/guidelines/published-guidelines/depression/. Accessed: 3/18/2022.
371 Cohen J. A power primer. Psychol Bull. 1992;112(1):155–9. PMID: 19565683. 10.1037//0033-2909.112.1.155 19565683
372 Cuijpers P, Karyotaki E, Ciharova M, . The effects of psychotherapies for depression on response, remission, reliable change, and deterioration: A meta-analysis. Acta Psychiatr Scand2021. p. 288–99. PMID: 3410705034107050. 10.1111/acps.13335
373 Zimmerman M, McGlinchey JB, Posternak MA, . How should remission from depression be defined? The depressed patient’s perspective. Am J Psychiatry. 2006;163(1):148–50. PMID: 16390903. 10.1176/appi.ajp.163.1.148 16390903
374 Zimmerman M, Martinez JA, Attiullah N, . Why do some depressed outpatients who are in remission according to the Hamilton Depression Rating Scale not consider themselves to be in remission? The Journal of clinical psychiatry. 2012;73(6):790–5. PMID: 22569085. 10.4088/JCP.11m07203 22569085
375 Zimmerman M, Martinez JH, Attiullah N, . A new type of scale for determining remission from depression: the Remission from Depression Questionnaire. J Psychiatr Res. 2013;47(1):78–82. PMID: 23102820. 10.1016/j.jpsychires.2012.09.006 23102820
376 Barkham M, Moller NP, Pybis J. How should we evaluate research on counselling and the treatment of depression? A case study on how the National Institute for Health and Care Excellence’s draft 2018 guideline for depression considered what counts as best evidence. Counselling & Psychotherapy Research. 2017;17(4):253–68. 10.1002/capr.12141 29151815
377 Glue P, Donovan MR, Kolluri S, . Meta-analysis of relapse prevention antidepressant trials in depressive disorders. Aust N Z J Psychiatry. 2010;44(8):697–705. PMID: 20636190. 10.3109/00048671003705441 20636190
378 Furukawa TA, Shinohara K, Sahker E, . Initial treatment choices to achieve sustained response in major depression: a systematic review and network meta-analysis. World psychiatry : official journal of the World Psychiatric Association (WPA). 2021;20(3):387–96. PMID: 34505365. 10.1002/wps.20906 34505365
379 Dingfelder S.F. Stigma: Alive and well. Monitor on Psycology. 2009;40(6).
380 Henderson C, Evans-Lacko S, Thornicroft G. Mental illness stigma, help seeking, and public health programs. Am J Public Health. 2013;103(5):777–80. PMID: 23488489. 10.2105/ajph.2012.301056 23488489
381 Kluemper A, Heath L, Loeb D, . Depression-related stigma among primary care providers. Ment Health Clin. 2021;11(3):175–80. PMID: 34026392. 10.9740/mhc.2021.05.175 34026392
382 Thornicroft G, Mehta N, Clement S, . Evidence for effective interventions to reduce mental-health-related stigma and discrimination. Lancet (London, England). 2016;387(10023):1123–32. PMID: 26410341. 10.1016/s0140-6736(15)00298-6 26410341
383 Stone M, Laughren T, Jones ML, . Risk of suicidality in clinical trials of antidepressants in adults: analysis of proprietary data submitted to US Food and Drug Administration. BMJ (Clinical research ed). 2009;339:b2880. PMID: 19671933. 10.1136/bmj.b2880 19671933
384 Food and Drug Administration. Revisions to Product Labeling. https://www.fda.gov/media/77404/download. Accessed: 08/31/2021.
385 Lemay KR, Tulloch HE, Pipe AL, . Establishing the Minimal Clinically Important Difference for the Hospital Anxiety and Depression Scale in Patients With Cardiovascular Disease. J Mol Signal. 2019;39(6):E6–E11. PMID: 30489438. 10.1097/HCR.0000000000000379 30489438
386 Cosco TD, Lachance CC, Blodgett JM, . Latent structure of the Centre for Epidemiologic Studies Depression Scale (CES-D) in older adult populations: a systematic review. Aging Ment Health. 2020;24(5):700–4. PMID: 30661386. 10.1080/13607863.2019.1566434 30661386
387 Coyne JC, van Sonderen E. The Hospital Anxiety and Depression Scale (HADS) is dead, but like Elvis, there will still be citings. Journal of psychosomatic research. 2012;73(1):77–8. 10.1016/j.jpsychores.2012.04.002
388 Casarella J. Understanding Generalized Anxiety Disorder - Diagnosis and Treatment. https://www.webmd.com/anxiety-panic/guide/understanding-anxiety-treatment. Accessed: 8/31/2021.
389 Dodds TJ. Prescribed Benzodiazepines and Suicide Risk: A Review of the Literature. Prim Care Companion CNS Disord. 2017;19(2):02. PMID: 28257172. 10.4088/PCC.16r02037 28257172
390 U.S. Food and Drug Administration. FDA requiring Boxed Warning updated to improve safe use of benzodiazepine drug class: Includes potential for abuse, addiction, and other serious risks. https://www.fda.gov/drugs/drug-safety-and-availability/fda-requiring-boxed-warning-updated-improve-safe-use-benzodiazepine-drug-class. Accessed: 08/31/2021.
391 U.S. Food and Drug Administration. FDA Drug Safety Communication: FDA warns about serious risks and death when combining opioid pain or cough medicines with benzodiazepines; requires its strongest warning. https://www.fda.gov/drugs/drug-safety-and-availability/fda-drug-safety-communication-fda-warns-about-serious-risks-and-death-when-combining-opioid-pain-or. Accessed: 08/31/2021.
392 Liu S, O’Donnell J, Gladden RM, . Trends in Nonfatal and Fatal Overdoses Involving Benzodiazepines - 38 States and the District of Columbia, 2019-2020. MMWR Morb Mortal Wkly Rep. 2021;70(34):1136–41. PMID: 34437522. 10.15585/mmwr.mm7034a2 34437522
393 Longo L, Johnson B. Addiction: Part I. Benzodiazepines—Side Effects, Abuse Risk and Alternatives. Am Fam Physician2000. p. 2121–8. PMID: 1077925310779253.
394 Crowe SF, Stranks EK. The residual medium and long-term cognitive effects of benzodiazepine use: An updated meta-analysis. Arch Clin Neuropsychol. 2018;33(7):901–11. 10.1093/arclin/acx120 29244060
395 Cukrowicz K, Smith P, Poindexter E. The effect of participating in suicide research: does participating in a research protocol on suicide and psychiatric symptoms increase suicide ideation and attempts? Suicide & life-threatening behavior. 2010;40(6):535–43. PMID: 21198322. 10.1521/suli.2010.40.6.535 21198322
396 Lang M, Uttaro T, Caine E, . Implementing routine suicide risk screening for psychiatric outpatients with serious mental disorders: II. Quantitative results. Arch Suicide Res. 2009;13(2):169–77. PMID: 19363753. 10.1080/13811110902835106 19363753
397 Law MK, Furr RM, Arnold EM, . Does assessing suicidality frequently and repeatedly cause harm? A randomized control study. Psychol Assess. 2015;27(4):1171–81. 10.1037/pas0000118 25894705
398 Department of Veterans Affairs, Department of Defense. VA/DoD Clinical Practice Guideline for the Assessment and Management of Patients at Risk for Suicide. Version 2.0-2019. Washington, DC: Department of Veterans Affairs, Department of Defense; 2019.
399 Chickasaw Nation Departments of Health and Family Services. Zero Suicide. https://zerosuicide.edc.org/evidence/outcome-story/chickasaw-nation-departments-health-and-family-services. Accessed: 08/31/2021.
400 Richards JE, Hohl SD, Whiteside U, . If You Listen, I Will Talk: the Experience of Being Asked About Suicidality During Routine Primary Care. Journal of general internal medicine. 2019;34(10):2075–82. PMID: 31346911. 10.1007/s11606-019-05136-x 31346911
401 Andrews M. Despite Law, Health Plans Refuse Medical Claims Related To Suicide. Shots-Health News [serial on the Internet]. 2014 [cited Writing: Available from: https://www.npr.org/sections/health-shots/2014/02/18/279014945/despite-law-health-plans-refuse-medical-claims-related-to-suicide.
402 Koons C, Tozzi J. As Suicides Rise, Insurers Find Ways to Deny Mental Health Coverage: Red tape and a lack of in-network providers frustrate those seeking treatment. Bloomberg Businessweek. 2019 10/21/2021 (col. Writing).
403 Lee R. Does life insurance cover death by suicide? https://www.businessinsider.com/personal-finance/does-life-insurance-cover-suicide. Accessed: Jan 7, 2023.
404 National Alliance on Mental Illness. Factsheet: Suicide and Life Insurance. St. Paul, MN: National Alliance on Mental Illness: Minnesota; 2021. PMID.
405 Simpson S, Berman L, Stefan S. Legal and Liability Issues in Suicide Care. In: Moderator: Julie Goldstein Grumet PhD, Director of Prevention and Practice, Suicide Prevention Resource Center, editors. ZeroSuicide in Health and Behavioral Health Care; 2015.
406 Ribeiro JD, Franklin JC, Fox KR, . Self-injurious thoughts and behaviors as risk factors for future suicide ideation, attempts, and death: a meta-analysis of longitudinal studies. Psychol Med. 2016;46(2):225–36. PMID: 26370729. 10.1017/s0033291715001804 26370729
407 Rossom RC, Coleman KJ, Ahmedani BK, . Suicidal ideation reported on the PHQ9 and risk of suicidal behavior across age groups. Journal of affective disorders. 2017;215:77–84. 10.1016/j.jad.2017.03.037 28319695
408 Simon GE, Rutter CM, Peterson D, . Does response on the PHQ-9 Depression Questionnaire predict subsequent suicide attempt or suicide death? Psychiatric Services. 2013;64(12):1195–202. PMID: 24036589. 10.1176/appi.ps.201200587 24036589
409 Hubers AAM, Moaddine S, Peersmann SHM, . Suicidal ideation and subsequent completed suicide in both psychiatric and non-psychiatric populations: a meta-analysis. Epidemiol Psychiatr Sci. 2018;27(2):186–98. PMID: 27989254. 10.1017/s2045796016001049 27989254
410 Louzon SA, Bossarte R, McCarthy JF, . Does Suicidal Ideation as Measured by the PHQ-9 Predict Suicide Among VA Patients? Psychiatr Serv. 2016;67(5):517–22. PMID: 26766757. 10.1176/appi.ps.201500149 26766757
411 Belsher BE, Smolenski DJ, Pruitt LD, . Prediction Models for Suicide Attempts and Deaths: A Systematic Review and Simulation. JAMA Psychiatry. 2019;76(6):642–51. PMID: 30865249. 10.1001/jamapsychiatry.2019.0174 30865249
412 Simon GE, Johnson E, Lawrence JM, . Predicting Suicide Attempts and Suicide Deaths Following Outpatient Visits Using Electronic Health Records. Am J Psychiatry. 2018;175(10):951–60. PMID: 29792051. 10.1176/appi.ajp.2018.17101167 29792051
413 Large M, Kaneson M, Myles N, . Meta-Analysis of Longitudinal Cohort Studies of Suicide Risk Assessment among Psychiatric Patients: Heterogeneity in Results and Lack of Improvement over Time. PloS one. 2016;11(6):e0156322. PMID: 27285387. 10.1371/journal.pone.0156322 27285387
414 Coley RY, Johnson E, Simon GE, . Racial/Ethnic Disparities in the Performance of Prediction Models for Death by Suicide After Mental Health Visits. JAMA Psychiatry. 2021;78(7):726–34. PMID: 33909019. 10.1001/jamapsychiatry.2021.0493 33909019
415 National Collaborating Centre for Mental Health (UK). Self-Harm: Longer-Term Management. Leicester (UK): 2012.
416 National Action Alliance for Suicide Prevention: Research Prioritization Task Force. A prioritized research agenda for suicide prevention: An action plan to save lives. Rockville, MD: National Institute of Mental Health and the Research Prioritization Task Force; 2014.
417 Brodsky BS, Spruch-Feiner A, Stanley B. The Zero Suicide Model: Applying Evidence-Based Suicide Prevention Practices to Clinical Care. Front Psychiatry. 2018;9:33. PMID: 29527178. 10.3389/fpsyt.2018.00033 29527178
418 Sall J, Brenner L, Millikan Bell AM, . Assessment and Management of Patients at Risk for Suicide: Synopsis of the 2019 U.S. Department of Veterans Affairs and U.S. Department of Defense Clinical Practice Guidelines. Ann Intern Med. 2019;171(5):343–53. PMID: 31450237. 10.7326/m19-0687 31450237
419 D’Anci KE, Uhl S, Giradi G, . Treatments for the Prevention and Management of Suicide: A Systematic Review. Annals of Internal Medicine. 2019;171(5):334–42. PMID: 31450239. 10.7326/M19-0869 31450239
420 Calati R, Courtet P. Is psychotherapy effective for reducing suicide attempt and non-suicidal self-injury rates? Meta-analysis and meta-regression of literature data. J Psychiatr Res. 2016;79:8–20. PMID: 27128172. 10.1016/j.jpsychires.2016.04.003 27128172
421 Meerwijk EL, Parekh A, Oquendo MA, . Direct versus indirect psychosocial and behavioural interventions to prevent suicide and suicide attempts: a systematic review and meta-analysis. Lancet Psychiatry. 2016;3(6):544–54. PMID: 27017086. 10.1016/S2215-0366(16)00064-X 27017086
422 Xiong J, Lipsitz O, Chen-Li D, . The acute antisuicidal effects of single-dose intravenous ketamine and intranasal esketamine in individuals with major depression and bipolar disorders: A systematic review and meta-analysis. J Psychiatr Res. 2021;134:57–68. PMID: 33360864. 10.1016/j.jpsychires.2020.12.038 33360864
423 Ceban F, Rosenblat JD, Kratiuk K, . Prevention and Management of Common Adverse Effects of Ketamine and Esketamine in Patients with Mood Disorders. CNS Drugs. 2021;35(9):925–34. PMID: 34363603. 10.1007/s40263-021-00846-5 34363603
424 Gordon JA, Avenevoli S, Pearson JL. Suicide Prevention Research Priorities in Health Care. JAMA Psychiatry. 2020;77(9):885–6. PMID: 32432690. 10.1001/jamapsychiatry.2020.1042 32432690
425 Education Development Center, The Suicide Prevention Resource Center, The National Action Alliance for Suicide Prevention. Zero Suicide. https://zerosuicide.edc.org/. Accessed: 08/31/2021.
426 Layman DM, Kammer J, Leckman-Westin E, . The Relationship Between Suicidal Behaviors and Zero Suicide Organizational Best Practices in Outpatient Mental Health Clinics. Psychiatr Serv. 2021:appips202000525. PMID: 3373088633730886. 10.1176/appi.ps.202000525
427 Ahmedani B, Simon G, Boggs J, . An Evaluation of the National Zero Suicide Model Across Learning Healthcare Systems. NIMH; 2017. PMID.
428 Stockdale SE, Lagomasino IT, Siddique J, . Racial and ethnic disparities in detection and treatment of depression and anxiety among psychiatric and primary health care visits, 1995-2005. Med Care. 2008;46(7):668–77. PMID: 18580385 10.1097/MLR.0b013e3181789496 18580385
429 Hines AL, Cooper LA, Shi L. Racial and ethnic differences in mental healthcare utilization consistent with potentially effective care: The role of patient preferences. General hospital psychiatry. 2017;46:14–9. PMID: 28622809. 10.1016/j.genhosppsych.2017.02.002 28622809
430 Coleman KJ, Stewart C, Waitzfelder BE, . Racial-Ethnic Differences in Psychiatric Diagnoses and Treatment Across 11 Health Care Systems in the Mental Health Research Network. Psychiatr Serv. 2016;67(7):749–57. PMID: 27079987. 10.1176/appi.ps.201500217 27079987
431 Substance Abuse and Mental Health Services Administration. Racial/Ethnic Differences in Mental Health Service Use among Adults. Rockville, MD: 2015.
432 McIntosh K, Moss E, Nunn R, . Examining the Black-white wealth gap. Up Front [serial on the Internet]. 2020 [cited Writing: Available from: https://www.brookings.edu/blog/up-front/2020/02/27/examining-the-black-white-wealth-gap/.
433 Garcia ME HL, Neuhaus J, Feldman M, Livaudais-Toman J, Karliner LS,. Equitability of Depression Screening After Implementation of General Adult Screening in Primary Care. JAMA Netw Open. 2022;5(8):e2227658. PMID: 35980633. 10.1001/jamanetworkopen.2022.27658 35980633
434 Patel JS, Oh Y, Rand KL, . Measurement invariance of the patient health questionnaire-9 (PHQ-9) depression screener in U.S. adults across sex, race/ethnicity, and education level: NHANES 2005-2016. Depress Anxiety. 2019;36(9):813–23. PMID: 31356710. 10.1002/da.22940 31356710
435 Harry ML, Waring SC. The measurement invariance of the Patient Health Questionnaire-9 for American Indian adults. Journal of affective disorders. 2019;254:59–68. PMID: 31108281. 10.1016/j.jad.2019.05.017 31108281
436 Di Florio A, Putnam K, Altemus M, . The impact of education, country, race and ethnicity on the self-report of postpartum depression using the Edinburgh Postnatal Depression Scale. Psychol Med. 2017;47(5):787–99. 10.1017/S0033291716002087 27866476
437 Kim G, Decoster J, Huang CH, . Race/ethnicity and the factor structure of the Center for Epidemiologic Studies Depression Scale: a meta-analysis. Cultur Divers Ethnic Minor Psychol. 2011;17(4):381–96. PMID: 21988578. 10.1037/a0025434 21988578
438 Moazen-Zadeh E, Assari S. Depressive Symptoms Predict Major Depressive Disorder after 15 Years among Whites but Not Blacks. Front Public Health. 2016;4:13. PMID: 26925396. 10.3389/fpubh.2016.00013 26925396
439 Platform; WHOICTR. Stepped care to support trauma recovery: a feasibility study2019 [cited KQ Search_Diag Acc - Cochrane NCT]: Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-02064817/full.
440 Menear M, Dugas M, Careau E, . Strategies for engaging patients and families in collaborative care programs for depression and anxiety disorders: A systematic review. Journal of affective disorders. 2020;263:528–39. PMID: 31744737. 10.1016/j.jad.2019.11.008 31744737
441 Jackson-Triche ME, Unützer J, Wells KB. Achieving Mental Health Equity: Collaborative Care. Psychiatr Clin North Am. 2020;43(3):501–10. PMID: 32773077. 10.1016/j.psc.2020.05.008 32773077
442 Moise N, Wainberg M, Shah RN. Primary care and mental health: Where do we go from here? World J Psychiatry. 2021;11(7):271–6. PMID: 34327121. 10.5498/wjp.v11.i7.271 34327121
443 Gilbody S, Whitty P, Grimshaw J, . Educational and organizational interventions to improve the management of depression in primary care: a systematic review. Jama. 2003;289(23):3145–51. PMID: 12813120. 10.1001/jama.289.23.3145 12813120
444 Moise N, Falzon L, Obi M, . Interventions to Increase Depression Treatment Initiation in Primary Care Patients: a Systematic Review. Journal of general internal medicine. 2018;33(11):1978–89. PMID: 30109586. 10.1007/s11606-018-4554-z 30109586
445 Gilbody S, Bower P, Fletcher J, . Collaborative care for depression: a cumulative meta-analysis and review of longer-term outcomes. Arch Intern Med. 2006;166(21):2314–21. PMID: 17130383. 10.1001/archinte.166.21.2314 17130383
446 Carron T, Rawlinson C, Arditi C, . An Overview of Reviews on Interprofessional Collaboration in Primary Care: Effectiveness. Int J Integr Care. 2021;21(2):31. PMID: 34220395. 10.5334/ijic.5588 34220395
447 Archer J, Bower P, Gilbody S, . Collaborative care for depression and anxiety problems. Cochrane Database Syst Rev. 2012;10:CD006525. PMID: 23076925. 10.1002/14651858.CD006525.pub2 23076925
448 Grigoroglou C, van der Feltz-Cornelis C, Hodkinson A, . Effectiveness of collaborative care in reducing suicidal ideation: An individual participant data meta-analysis. General hospital psychiatry. 2021;71:27–35. PMID: 33915444. 10.1016/j.genhosppsych.2021.04.004 33915444
449 Lee-Tauler SY, Eun J, Corbett D, . A Systematic Review of Interventions to Improve Initiation of Mental Health Care Among Racial-Ethnic Minority Groups. Psychiatr Serv. 2018;69(6):628–47. PMID: 29716446. 10.1176/appi.ps.201700382 29716446
450 Garcia ME, Ochoa-Frongia L, Moise N, . Collaborative Care for Depression among Patients with Limited English Proficiency: a Systematic Review. Journal of general internal medicine. 2018;33(3):347–57. PMID: 29256085. 10.1007/s11606-017-4242-4 29256085
451 Hu J, Wu T, Damodaran S, . The Effectiveness of Collaborative Care on Depression Outcomes for Racial/Ethnic Minority Populations in Primary Care: A Systematic Review. Psychosomatics. 2020;61(6):632–44. PMID: 32381258. 10.1016/j.psym.2020.03.007 32381258
452 Lagomasino IT, Dwight-Johnson M, Green JM, . Effectiveness of Collaborative Care for Depression in Public-Sector Primary Care Clinics Serving Latinos. Psychiatric Services. 2017;68(4):353–9. PMID: 27842470. 10.1176/appi.ps.201600187 27842470
453 Whitfield J, Lepoire E, Stanczyk B, . Remote Collaborative Care with Off-Site Behavioral Health Care Managers: A Systematic Review of Clinical Trials. J Acad Consult Liaison Psychiatry. 2021. PMID: 3438950934389509. 10.1016/j.jaclp.2021.07.012
454 Peters L, Peters A, Andreopoulos E, . Comparison of DASS-21, PHQ-8, and GAD-7 in a virtual behavioral health care setting. Heliyon. 2021;7(3):e06473. PMID: 33817367. 10.1016/j.heliyon.2021.e06473 33817367
455 Substance Abuse and Mental Health Services Administration. National Survey on Drug Use and Health, 2019. Rockville, MD: Center for Behavioral Health Statistics and Quality; 2020.
456 Harvard Medical School. National Comorbidity Survey (NCS). https://www.hcp.med.harvard.edu/ncs/index.php. Accessed.
457 Kroenke K, Spitzer RL, Williams JB. The PHQ-9: validity of a brief depression severity measure. Journal of general internal medicine. 2001;16(9):606–13. PMID: 11556941. 10.1046/j.1525-1497.2001.016009606.x 11556941
458 Kroenke K, Spitzer RL, Williams JB. The Patient Health Questionnaire-2: validity of a two-item depression screener. Med Care. 2003;41(11):1284–92. PMID: 14583691. 10.1097/01.MLR.0000093487.78664.3C 14583691
459 Radloff L. The CES-D scale: A self report depression scale for research in the general population. Applied Psychological Measurements. 1977;1:385–401. 10.1177/014662167700100306
460 Lewinsohn P, Seeley J, Roberts R, . Center for Epidemiological Studies-Depression Scale (CES-D) as a screening instrumetn for depression among community-residing older adults. Psychology and Aging. 1997;12:277–87. PMID: 9189988. 10.1037//0882-7974.12.2.277 9189988
461 Cox JL, Holden JM, Sagovsky R. Detection of postnatal depression. Development of the 10-item Edinburgh Postnatal Depression Scale. Br J Psychiatry. 1987;150:782–6. PMID: 3651732. 10.1192/bjp.150.6.782 3651732
462 Sheikh J, Yesavage J. Geriatric Depression Scale (GDS): Recent evidence and development of a shorter version. Clinical Gerontologist. 1986;5:165. 10.1300/J018v05n01_09
463 Matthey S. Using the Edinburgh Postnatal Depression Scale to screen for anxiety disorders. Depress Anxiety. 2008;25:926–31. PMID: 18041072. 10.1002/da.20415 18041072
464 Segal DL, June A, Payne M, . Development and initial validation of a self-report assessment tool for anxiety among older adults: the Geriatric Anxiety Scale. J Anxiety Disord. 2010;24(7):709–14. PMID: 20558032. 10.1016/j.janxdis.2010.05.002 20558032
465 Pachana NA, Byrne GJ, Siddle H, . Development and validation of the Geriatric Anxiety Inventory. Int Psychogeriatr. 2007;19(1):103–14. PMID: 16805925. 10.1017/S1041610206003504 16805925
466 Byrne GJ, Pachana NA. Development and validation of a short form of the Geriatric Anxiety Inventory-the GAI-SF. Int Psychogeriatr. 2011;23(1):125–31. PMID: 20561386. 10.1017/S1041610210001237 20561386
467 Kroenke K, Baye F, Lourens SG. Comparative validity and responsiveness of PHQ-ADS and other composite anxiety-depression measures. Journal of affective disorders. 2019;246:437–43. PMID: 30599366. 10.1016/j.jad.2018.12.098 30599366
468 The Columbia Lighthouse Project, Center for Suicide Risk Assessment. The Columbia Suicide Severity Rating Scale (C-SSRS). http://cssrs.columbia.edu/the-columbia-scale-c-ssrs/evidence/. Accessed: Mar 3, 2020.
469 Patterson WM, Dohn HH, Bird J, . Evaluation of suicidal patients: the SAD PERSONS scale. Psychosomatics. 1983;24(4):343–5, 8–9. PMID: 6867245. 10.1016/S0033-3182(83)73213-5 6867245
470 Cooper J, Kapur N, Dunning J, . A clinical tool for assessing risk after self-harm. Ann Emerg Med. 2006;48(4):459–66. PMID: 16997684. 10.1016/j.annemergmed.2006.07.944 16997684
471 Steeg S, Kapur N, Webb R, . The development of a population-level clinical screening tool for self-harm repetition and suicide: the ReACT Self-Harm Rule. Psychol Med. 2012;42(11):2383–94. PMID: 22394511. 10.1017/S0033291712000347 22394511
472 Beck A, Steer R. BHS, Beck hopelessness scale: manual. New York, NY: Psychological Corp.; Harcourt Brace Jovanovich; 1988.
473 Jacobs D. Suicide Assessment Five-step Evaluation and Triage. Screenign for Mental Health, Inc in collaboration with the Suicide Prevention Resource Center: 2007.
474 McCarron RM, Vanderlip ER, Rado J. Depression. Annals of Internal Medicine. 2016;165(7):ITC49–ITC64. 10.7326/aitc201610040 27699401
475 American College of Obstetricians and Gynecologists. Guidelines for Women’s Health Care. 4 ed2014.
476 American Psychiatric Association. Position Statement on Screening and Treatment of Mood and Anxiety Disorders During Pregnancy and Postpartum. APA Official Actions2018. PMID.
477 Association of Women’s Health OaNNPS. Mood and Anxiety Disorders in Pregnant and Postpartum Women. Journal of Obstetrics, Gynecologic & Neonatal Nursing. 2015;44(5):687–9. 10.1111/1552-6909.12734
478 National Institute for Health and Care Excellence. Clinical Guideline [90]: Depression in adults: recognition and management. London: National Institute for Health and Care Excellence; 2009.
479 UK National Screening Committee. UK NSC Recommendations. https://view-health-screening-recommendations.service.gov.uk/. Accessed: 3/18/2022.
480 Tompkins EL, O’Malley PG. Women’s Preventive Services Initiative recommends screening women for anxiety. Annals of Internal Medicine. 2020;173(10):JC50. PMID: 33197351. 10.7326/ACPJ202011170-050 33197351
481 Michigan Quality Improvement Consortium. Michigan Quality Improvement Consortium Guideline: Routine Preventive Services for Children and Adolescents (Ages 2–21). Detroit, MI: Michigan Quality Improvement Consortium; 2019.