# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Iris Mabry-Hernandez, MD, MPH, and Tina Fan, MD, MPH, at the Agency for Healthcare Research and Quality; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Ramin Mojtabai, MD, PhD, MPH, Pim Cuijpers, PhD, Tiffany A. Moore Simas, MD, MPH, FACOG, Raquel Halfond, PhD, and Bobbi Jo Yarborough, PsyD, who provided expert review of the draft report; Rebecca DelCarmen-Wiggins, PhD, Regine Douthard, MD, MPH, Shilpa H. Amin, MD, MJ, CAQ, FAAFP, Damiya E. Whitaker, PsyD, MA, and Elena Gorodetsky, MD, PhD, with the National Institutes of Health Office of Research on Women’s Health, Jackie Wallace MD, MPH, with the National Institute of Child Health and Human Development, and Erin M. Abramsohn, DrPH, MPH, with the Centers for Disease Control and Prevention for providing federal partner review of the draft report; and Melinda Davies, MAIS, and Jill Pope, BA, at the Kaiser Permanente Center for Health Research for technical and editorial assistance.