# Chapter 4 Discussion

## Summary of Evidence

We addressed five key questions for each of anxiety, depression, and suicide risk, with varying levels of support for mental health screening (Table 50). We found both direct and indirect evidence to support screening for depression. The direct evidence is more equivocal than the indirect evidence, being a smaller body of evidence and having fewer statistically significant findings. There were some important limitations to the evidence for depression screening among older adults, where benefits were generally not seen. In addition, the lack of an unscreened control group and presence of additional program components beyond screening in many of the depression screening studies made it difficult to isolate the specific effects of screening alone in these studies. However, the indirect evidence is robust that feasible screening tools with reasonable accuracy are available, and that treatment is effective. The evidence on depression screening tools and benefits and harms of depression treatment in general and older adults were not addressed in the previous review so are newly considered. Since the USPSTF has a long-standing “B” recommendation and depression screening is becoming of the standard of care, it will grow increasingly difficult to add substantively to the evidence base of direct evidence.

Table 50 Summary of Evidence

Key Question; Condition | No. of studies (N randomized) | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
Depression KQ1; (screening benefits) | 14 RCTs, 3 CCTs (n=18,437) | Evidence supported the benefits of screening for depression. For example, ORs (95% CI) at 6 months post-baseline or 6 months postpartum (or the closest followup timepoint to 6 months) include:; - Prevalence of depression or clinically important symptomatology: 0.60 ([0.50 to 0.73]; 8 studies [n=10,244]; I^2^=0%); - Remission or falling below a specific level of depression symptomatology: 1.58 ([1.23 to 2.02]; 8 studies [n=2,302]; I^2^=0%); However, no clear benefit in symptom severity measures was found (pooled MD in change, −1.0 [-2.3 to 0.3]; 9 studies; [n=5,543], I^2^=74.4%) | Reasonably consistent, reasonably precise | Few studies with unscreened control groups and limited capacity for conducting such studies, as screening for depression becomes the standard of care; heterogeneity in interventions and limited evidence on screening without further practice supports | Moderate for benefit | Most studies either conducted outside the US or, among USbased studies, published >15 years ago. Applicability to current US healthcare systems unclear.
Depression KQ2; (accuracy of screening tools) | 10 ESRs (~196 studies, N~75,000), 14 test accuracy studies (N=8,819) | Adequate sensitivity and specificity for the PHQ-9 Linear, PHQ-8, PHQ-2, Whooley, CES-D, EPDS, and GDS. | Consistent, precise | Most of the ESRs were not restricted to primary care populations | High | Most of the studies were not conducted in the US.
Depression KQ3; (harms of screening) | Directly assessed harms: 1 (n=642) Indirectly used to infer harms: 14 RCTs, 3 CCTs (n=18,437) | One study reported no adverse events in either group. Studies included for KQ1 did not show a pattern of results indicating harmful impact. | Consistent, imprecise | Adverse events rarely directly assessed | Moderate for little to no harm | Most studies either conducted outside the US or, among USbased studies, published >15 years ago. Applicability to current US healthcare systems unclear.
Depression KQ4; (benefits of treatment) | 30 ESRs of psychological treatment (≥346 RCTs, N~45,078); 10 ESRs of pharmacologic treatment (≥522 studies, N ≥ 6,477) | Psychological treatment improved depression and other health outcomes such as anxiety symptoms, hopelessness, quality of life, and functioning. The broadest analysis indicated a moderate to large effect on depression (SMD, −0.72 [95% CI, −0.78 to −0.67]; k=385, N not reported, but estimated at approximately 33,000). The effect was smaller when limited to studies in primary care patients, but clearly statistically significant (SMD, −0.42 [95% CI, −0.56 to −0.29]; k=59, N not reported).; Antidepressant medications consistently demonstrated increased rates of remission and response to treatment, and small but statistically significant reductions in depressive symptom severity. For example, fluoxetine, which had the largest body of evidence with 117 studies, was associated with a small reduction in symptom severity (SMD, −0.23 [95% CI, −0.28 to −0.19]), a 46% increase in the odds of remission (OR, 1.46 [95% CI, 1.34 to 1.60]) and a 52% increase in the odds treatment response (OR, 1.52 [95% CI, 1.40 to 1.66], number of studies and individuals included in each specific analysis was not reported, nor were I^2^ values); . | Consistent, precise | Most ESRs examined posttreatment outcomes with little information on longer-term followup.; There was evidence of publication/reporting bias, however effects were still statistically significant after adjusting for these biases.; Evidence for benefit in a priori populations of interest was very limited in the synthesized literature, particularly on the effect of antidepressant medications. | High for benefit | Studies recruited from a wide range of community, online, and clinic sources, wide range of countries, and effect sizes in subgroup analyses limited to primary care settings tended to be smaller than broad-based analyses.
Depression KQ5; (harms of treatment) | 4 ESRs of psychological treatment (~63 RCTs, N~8,466); 22 ESRs of pharmacologic treatment k~697 studies, N >9 million; 1 cohort study of pharmacologic (N=358,351) | In 3 ESRs, deterioration rates were either lower with psychological interventions or did not differ statistically from control groups. A separate review among older adults reported that none of the 14 included trials reported safety data.; Pharmacologic treatment was associated with a higher risk of dropout due of adverse events with all agents examined and a higher risk of serious adverse events with SSRI use (OR, 1.39 [95% CI 1.12 to 1.72], 44 RCTs, N not reported, I^2^=0%). There were too few suicide deaths to determine the association between antidepressant use and suicide death, but both RCT and observational evidence supported an increased risk of suicide attempts with second generation antidepressant use among adults up to age 65 (OR, 1.53 [95% CI, 1.09 to 2.15]; N=41,861; 0.7% of antidepressants vs. 0.3% of placebo users). Other outcomes were largely limited to observational evidence. | Dropout due to adverse effects: Consistent, reasonably precise; Suicide attempt: Consistent, Imprecise; Other serious harms: Inconsistent, imprecise | Psychological: Harms not directly reported; Pharmacologic: RCTs underpowered to identify rare serious outcomes, observational studies could not control for important confounders | Psychological: Low for little to no harm; Pharmacologic: Moderate for increased risk of nonserious harms; Low for increased risk of serious harm | Population and settings characteristics were not reported in the ESRs.
Anxiety KQ1; (screening benefits) | 2 RCTs (n=918) | Both studies found no group differences in anxiety or general mental health symptom severity at 13 to 22 weeks of followup. Absolute differences in change ranged from −1.5 to 0.3 on 16- and 40point scales. | Reasonably consistent, Imprecise | Limited number of studies | Insufficient | Both conducted in US primary care settings, one study published in 1994 so may not reflect current practice.
Anxiety KQ2; (accuracy of screening tools) | 10 test accuracy studies (n=6,463) | Adequate sensitivity and specificity for the GAD-7 to detect GAD. More limited evidence for the GAD-2 to detect GAD.; GAD-7 and GAD-2 were less accurate for identifying any anxiety disorder.; Limited evidence for the GAD-7, GAD-2, and PHQ-PD to detect PD.; Limited evidence for the GAD-7 and GAD-2 to detect SAnD. | Reasonably consistent, reasonably precise | Few studies, limited replication | Moderate for the GAD-2/7 to detect GAD; Low for all other instruments and conditions | Many studies were conducted in the US, but those limited to older adults and pregnant women and the largest general adult study were conducted outside of the US.
Anxiety KQ3; (harms of screening) | Directly assessed harms: 0 Indirectly used to infer harms: 2 RCTs (n=918) | No studies reported on harms of screening for anxiety. Studies included for KQ1 did not show a pattern of results indicating harmful impact. | Consistent, imprecise | Minimal evidence | Insufficient | Both studies included for KQ1 outcomes conducted in US primary care settings, one study published in 1994 so may not reflect current practice.
Anxiety KQ4; (benefits of treatment) | Psychological: 24 RCTs (N=5,307), 8 ESRs (~144 RCTs, N~11,030); Pharmacolog ic: 2 RCTs (N=423), 10 ESRs (~227 RCTs, N~40,803) | Psychological interventions showed a relatively small but statistically significant reduction in anxiety symptom severity in primary care patients with anxiety (SMD, −0.41 [95% CI, −0.58 to −0.23]; 10 RCTs [n=2,075]; I^2^=40.2%), but not among mixed populations of people with anxiety or depression (SMD, −0.18 [95% CI, −0.39 to 0.03]; 12 RCTs [n=1,868]; I^2^=66.7%). In the ESRs (not limited to primary care patients), psychological treatment was associated with reduced anxiety symptoms; SMDs at post treatment among broad adult populations were −0.80 and larger and CBT was also associated with improved depression symptom severity and quality of life. More limited evidence suggested a benefit in older and perinatal patients as well.; For pharmacologic treatment, 2 RCTs of venlafaxine and escitalopram in primary care patients both showed a benefit with antidepressant use. ESRs, not limited to primary care patients, reported improved anxiety and other outcomes for people taking antidepressants and benzodiazepines compared to placebo. For example, among patients with generalized anxiety disorder, the SMD for change in anxiety symptom severity with SSRIs was −0.66 (95% CI, −0.90 to −0.43, 31 studies, N and I^2^ not reported). | Consistent, reasonably precise | Only 10 studies were among anxiety patients, others were in mixed populations with anxiety or depression; limited evidence in older adults, limited evidence in perinatal patients; little information on outcomes beyond 8–12 weeks.; There was evidence of publication and reporting bias among pharmacotherapy trials, however statistical significance remained after adjustment. | High for benefit | 24 studies in primary care populations, but only 7 conducted in the US; all studies reporting race or ethnicity included majority (57% to 82%) White participants.
Anxiety KQ5; (harms of treatment) | Psychological: 0 directly reported Inferred from KQ4 studies; Pharmacologic: 3 RCTs (N=669), 8 ESRs (~112 RCTs, N~29,674), 2 case-control (N=262,3780) | None of the RCTs or ESRs of psychological treatment reported on adverse events, but there was no pattern of effects indicating an elevated risk of harm.; For pharmacologic treatment, evidence indicated an increase in non-serious harms as measured by a higher percent of participants taking medication (vs. placebo) experiencing any adverse events and withdrawals due to adverse events. Serious adverse events were rare; case-control studies suggested a possible increased risk in suicide deaths and spontaneous abortion with benzodiazepine, but these data had important limitations. | Psychological: Consistent, imprecise; Pharmacologic, nonserious: Consistent, reasonably precise; Pharmacologic, serious: Consistent, imprecise | Specific serious outcomes were rare and studies were underpowered to identify; little information on outcomes beyond 8–12 weeks. Case-control studies could not fully control for important confounders and study on suicide used only prescription as an exposure (rather than dispensings) | Low for psychological for little to no harm; Moderate for non-serious harms of pharmacotherapy; Insufficient for serious harms of pharmacotherapy | Population and settings characteristics were not reported in the ESRs.
Suicide risk KQ1; (screening benefits) | 1 RCT (n=443) | Among primary care patients who screened positive for depression, there was 1 suicide attempt after 2 weeks; there were no group differences on any of 3 items measuring suicidal ideation. | Consistency NA, imprecise | Single study, very short-term followup, limited to people who screened positive for depression | Insufficient | Conducted in the UK and limited to people with symptoms of depression.
Suicide risk KQ2; (accuracy of screening tools) | 3 test accuracy studies (n=1,751) | GDS-15, GDS-SI, and the SDDS-PC had adequate test accuracy to detect suicidal ideation. | Consistency NA, precision, NA | Not replicated in more than 1 study. | Insufficient | All studies took place in the US, 2 in primary care.
Suicide risk KQ3; (harms of screening) | 1 RCT (n=443) | Two of three suicidal ideation items indicated a possible higher risk with screening; however, the findings were inconclusive due to the lack of statistical significance and very wide confidence intervals. | Consistency NA, imprecise | Single study, very short-term followup, limited to people who screened positive for depression | Insufficient | Conducted in the UK and limited to people with symptoms of depression.
Suicide risk KQ4; (benefits of treatment) | 23 RCTs (n=22,632) | A very large (n=18,882) study conducted in 4 US healthcare systems found that two separate suicide prevention interventions were associated with either no impact on suicide attempts (HR, 1.07 [97.5% CI, 0.84 to 1.37] for a care management intervention) or an increased risk of suicide attempts (HR, 1.29 [97.5% CI, 1.02 to 1.64] for a lowintensity online intervention). Most other studies had very few participants with suicide attempts and the pooled effect was not statistically significant (OR, 0.94 [95% CI, 0.73 to 1.22]; 12 RCTs [n=14,573]; I^2^=11.2%).; The impact of psychological interventions (e.g., dialectical and cognitive behavioral therapy) on suicide deaths could not be determined due to the small number of events.; Although there was a small statistically significant benefit for depression symptom severity, there was no clear improvement over usual care for suicidal ideation, self-harm, other mental outcomes, or emergency or inpatient healthcare utilization.; No studies tested a pharmacologic intervention compared with a placebo control. | Inconsistent, imprecise | Control groups were typically usual specialty mental health care (enhanced or optimized in some cases) so may be considered comparative effectiveness studies; some trials had primary aims of broad selfharm reduction (i.e., not focused on self-harm with suicidal intent) | Suicide death: Insufficient Suicide attempts: Moderate that some interventions are associated with no benefit or increased risk of harm compared with usual mental health care Suicide ideation, depression, other mental health: Low for small to no benefit compared with usual specialty mental health care | 15 trials conducted in the US; primarily- White non-Hispanic participants; studies were required to have identified participants through outpatient or community settings, rather than through emergency or inpatient settings.
Suicide risk KQ5; (harms of treatment) | Directly assessed harms: 2 (n=607); Indirectly used to infer harms: 15 RCTs (n=1,994) | Two studies reported on harms. There were no differences between groups at followup on an instrument designed to assess the perceived level of coercion experienced by service users during hospital admission. The study of lithium found a higher rate of non-serious adverse events (75.7% with lithium, 69% with placebo, p-value not reported), a slightly higher rates of serious adverse events (38.8% with lithium, 34.1% with placebo, p-value not reported) but no difference in withdrawals due to adverse events (1.2% with lithium, 1.5% with placebo, p-value not reported). There was no pattern of effect in the studies included for KQ4 to indicate paradoxical harms of treatment. | Consistent, imprecise | Minimal evidence | Low | 15 trials conducted in the US; primarily- White non-Hispanic participants; studies were required to have identified participants through outpatient or community settings, rather than through emergency or inpatient settings.

Abbreviations: CBT = cognitive behavioral therapy; CCTs = controlled clinical trials; CES-D = Center for Epidemiologic Studies Depression Scale; CI = confidence interval; EPDS = Edinburgh Postnatal Depression Scale; ESRs = existing systematic reviews; GAD = generalized anxiety disorder; GAD-2 = Generalized Anxiety Disorder 2-Item Scale; GAD-7 = Generalized Anxiety Disorder 7-Item Scale; GDS = Geriatric Depression Scale; HR = hazard ratio; k = number of trials; KQ = key question; MD = mean difference; N = number of participants; NA = not applicable; OR = odds ratio; PD = panic disorder; PHQ = Patient Health Questionnaire; PHQ-PD = Patient Health Questionnaire-Panic Disorder; RCTs = randomized controlled trials; SAnD = social anxiety disorder; SDDS-PC = Symptom Driven Diagnostic System for Primary Care; SMD = standardized mean difference; SSRIs = selective serotonin reuptake inhibitors; UK = United Kingdom; US = United States

We found clear evidence that there are effective treatments available to treat anxiety, particularly CBT, antidepressants, and benzodiazepines, but the direct evidence for screening for anxiety was extremely limited and did not suggest a benefit. Further, the evidence on the diagnostic accuracy of screening tools had minimal replication for anxiety disorders other than generalized anxiety disorder. Because we focused on a limited number of screening tools, there may be additional diagnostic accuracy studies available, however we believe they are unlikely to provide more robust evidence than we found.

The direct and indirect evidence on screening for suicide risk was limited, and the indirect evidence indicated that implementation of some interventions that are feasible for wide-spread use in health care systems may either have no impact on suicide attempts or may paradoxically increase the risk of a suicide attempt. However, the treatment evidence is predominantly compared with usual specialty mental health care, making it difficult to understand the absolute treatment effects. Unlike the previous review, the current review did not include treatment studies in persons seeking treatment in urgent or emergency settings due to their low applicability to screening in primary care settings, but with the completion of a very large implementation trial we are able to conclude that some interventions are likely ineffective or potentially harmful.

### Screening for Depression

The direct evidence for the benefits of screening for depression was very similar to that in the previous review, with only two new studies added.^162,^ ^165^ Trials in general and perinatal populations demonstrate increased rates of depression remission or falling below a specified symptom severity level after six to twelve months. The evidence in older adult populations is more limited and did not show a clear benefit. Only four studies examined screening in older adults and only one used a depression measure that was specifically designed for older adults.^157^ There is ample evidence that screening instruments can identify people with MDD with reasonable accuracy, and cutoffs could be optimized for specific local settings and populations. The studies included in our review generally confirmed previously determined optimal cut-points. However, the evidence did raise some questions about the typical EPDS cutoff. While a previous meta-analysis^367^ had identified a cutoff of ≥12 as optimal to identify postpartum depression using the EPDS, the IPD meta-analysis included in our review determined that an EPDS cutoff of ≥11 yielded the best balance of sensitivity and specificity (Figure 8).

Aside from test accuracy studies, an independent stream of evidence supports the PHQ-9 for depression screening as well, based on broad positivity rates. From 2015–2016, 7.5 percent of US adults scored ≥10 on the PHQ-9, according to National Health and Nutrition Examination Survey (NHANES) data.^368^ This is only slightly higher than the estimated percent of US adults with a major depressive episode in 2015 (6.7%),^369^ supporting the relative accuracy of the PHQ-9.

In contrast to our findings, the Canadian Task Force on Preventive Health Care (CTFPHC) does not recommend screening for depression, based on the lack of direct evidence on the benefits and harms of routinely screening asymptomatic adults.^370^ The review that this recommendation was based on only included studies in which the screening intervention was a normal part of care and that had an unscreened comparison group. Thus, only three of the screening studies included in our review could have met their inclusion criteria and were published at the time this review was conducted, and only one^153^ of these was explicitly listed as examined and excluded from their review. This study did not integrate screening into the normal care process, but instead screening was undertaken by study staff. In addition, CTFPHC stated that it “had concerns about the potential harms of screening (e.g., false positive, unnecessary treatment, labelling and stigma) and appropriate use of limited resources.”

### Depression Treatment

We found evidence that psychological and pharmacologic treatment for depression improve depression as well as other outcomes (e.g., quality of life), in broad patient samples as well as in studies among primary care patients. The included reviews generally reported improvements in depression symptom severity in standardized units because specific measurement tools varied across studies. Unfortunately, it is difficult to understand the clinical importance of these effect sizes, beyond Cohen’s rules of thumb that 0.20, 0.50, and 0.80 could correspond to small, medium, and large effects.^371^ In several of the reviews by Cuijpers and colleagues, they estimated a Number Needed to Treat (NNT) to benefit one extra person with psychological interventions compared to control conditions.^195^ For the broadest finding (SMD, −0.72 [95% CI, −0.78 to −0.67]), the review authors reported a NNT of 4.0 at the end of the acute treatment phase (typically 2–6 months), assuming a control group recovery rate of 19%. NNTs ranged from 2.5 to 8.4 in this review, across sensitivity analyses and subgroup analyses for different specific types of psychological interventions, suggesting clinically important effect sizes. A separate review reported pooled response rates for psychological treatment, defined as the proportion with 50% reduction in depression symptoms.^372^ The overall response rate in psychotherapies at two months after baseline was 41% (95% CI, 38 to 43), compared with 17% (95% CI, 15 to 20) for usual care and 16% (95% CI, 14 to 18) for waitlist.^372^ We also found evidence that depression treatment improves quality of life and other outcomes that may be even more important to people with depression than depressive symptoms.^373–375^ While CBT was the most commonly studied specific psychological intervention and had the most support, the use of other counseling approaches was supported as well, both within our included evidence and as examined by other reviewers.^376^

While we found evidence that psychological treatment improved treatment response at one year and beyond, we found little synthesized information on the longer-term efficacy of pharmacologic treatment of depression. A network meta-analysis is underway to explore the efficacy, tolerability and acceptability of antidepressants in studies with 3-month followup or longer.^225^ However, the published studies with longer-term outcomes appear to be primarily focused on whether it is beneficial to remain on antidepressants after remission, rather than on demonstrating a long-term benefit of the original course of antidepressants. Relapse prevention is outside the scope of our review; however, as an example, we did find an older review of pharmacotherapy for relapse prevention reporting that continued antidepressant use was associated with a reduction in relapse (OR = 0.35; 95% CI 0.32–0.39^377^). The review found that the effect size was not affected by patient age, drug class, depression subtype, or treatment duration. Another review that conducted a network meta-analysis examining sustained response for pharmacologic, psychological, and combination treatment, using outcomes reported at one year post-treatment initiation (or the closest available).^378^ This review reported that sustained response was most likely with combination treatment, followed by psychological treatment alone. Pharmacologic treatment alone had lower rates of sustained response than either combination or psychological treatment and did not differ from usual care.

The synthesized evidence also reported effects in important patient populations. Benefits were reported for psychological treatment among studies limited to younger adults, older adults, perinatal patients, patients with or without medical comorbidities, primary care patients, and for adults who are not White (but specific race and ethnic groups were not further specified).

One important practice consideration for maximizing the effectiveness of treatment for depression is recognizing and minimizing stigma associated with depression^379^ and other mental health conditions. Stigma can impede access to care via multiple mechanisms.^380^ Like many Americans, some primary care clinicians carry stigmatizing attitudes toward depression, which may reduce their effectiveness in helping their patients with depression.^381^ A recent survey of 71 primary care clinicians confirmed that clinicians varied in the level of stigma they felt about depression, and higher levels of stigma were found in men, medical residents, those without personal exposure to mental illness, younger clinicians, and those who reported treating depression less frequently than their counterparts. We found no studies that aimed to reduce mental health-related stigma in healthcare providers, but at the population level, anti-stigma campaigns can help reduce stigma, at least in the short term.^382^

### Harms Associated With Treatment for Depression

We found that the risk of non-serious side effects is increased with the use of antidepressants, but the evidence on serious harms was more equivocal. The risk of suicide with the use of SSRIs is difficult to determine. A 2009 analysis of data from RCTs by the FDA concluded that there was an increase in the risk of suicidal behavior (suicide deaths, attempts, preparatory acts, and ideation combined) for persons younger than 25, no association for adults age 25 to 64, and a reduced risk in older adults.^383^ This finding is consistent with the black-box warning on antidepressants for persons age 24 years and younger.^384^ More recent evidence covered by our review, including both RCTs and observational data, suggest an increased risk of suicide attempts in adult populations younger than age 65, with a very low level of absolute risk (0.7% with second generation antidepressants vs. 0.3% with placebo in RCTs).^256^ The review that reported this finding conducted a number of analyses using different pooling methods. We selected the effect we believed to be most consistent with the AHRQ Evidence-based Practice Center (EPC) program guidance, which was the Peto OR. Other methods reported in the review and supported by the EPC program guidance included a fixed effect Mantel-Haenszel model and Bayesian approaches, and these models also demonstrated statistically significant increases in risk. However, this analysis was not stratified to determine effects in adults younger than 25 compared with those age 25 and older. We did find weak evidence that suicidal ideation is more likely to increase with antidepressant use in adults ages 18–24 than for those age 25 years and older, in whom suicidal ideation typically declined.

Suicide deaths in treatment studies are very rare, and analyses were typically underpowered. Based on an analysis of FDA regulatory data, the increased risk of suicide death was not statistically significant in placebo-controlled trials, but was based on only 41 deaths altogether, 37 of which occurred among participants taking SSRIs and other second-generation antidepressants. Both RCTs and observational studies found increases in the risk of suicide attempts among those taking second generation antidepressants. In RCTs, followup with typically only 8 weeks and was limited to people taking SSRIs for MDD. In observational studies, the increase in risk for the composite outcome suicide attempts or death was confirmed when antidepressants were used for depression as well as other indications. Interestingly, observational studies indicated no harmful association among 21 studies conducted in North America, but there was a harmful association among 36 studies conducted in Europe. Further, the harmful effect was present only among the 33 studies without a financial conflict of interest declared. These findings suggest a risk of publication or reporting bias among observational studies as we identified among RCTs. Observational studies are inherently limited, however, due to confounding by indication, disease severity, and other variables that are difficult or impossible to control for.

We found no recent ESRs that examined suicide outcomes of non-pharmacologic treatment of depression, and we have found no other evidence indicating the psychological treatment of depression may be associated with an increased risk of suicidality or any other harms.

### Screening for Anxiety

The direct evidence for anxiety screening was extremely limited and did not suggest a benefit. In our examination of the accuracy of anxiety screening tools, we made an a priori decision to focus on a limited number of tools we believed to be most widely used, but only one of them was designed to detect panic disorder and none were designed for social anxiety disorder, specifically. The anxiety screening studies (KQ1) used a single item screener and the 90-item Symptom Checklist-90 to screen for anxiety, neither of which were included in our review for diagnostic accuracy. Two of our included anxiety treatment studies used the five-item Overall Anxiety Severity and Impairment Scale (OASIS) as a screening tool for identifying potential participants. We did not find any diagnostic accuracy studies for this tool among general (non-clinical) adult samples; however, a US-based study among primary care patients whose clinician suspected that they had anxiety reported a sensitivity of 0.89 and specificity of 0.71 at a cut-point of 8 for the OASIS, compared to a structured interview using the MINI. Because there are many disorders that manifest with anxiety symptoms (e.g., PTSD, OCD, ADHD, depression, autism-spectrum disorders), sensitivity may be the more important than specificity when evaluating these tools. If tools identify patients with other conditions that need treatment as well as anxiety disorders, there could still be a net value of screening.

### Anxiety Treatment

We found broad evidence that treatment for anxiety disorders is effective, including samples with social anxiety disorder, panic disorder, generalized anxiety disorder and mixed samples with any of these anxiety disorders. We also found evidence to support a benefit of psychological treatment among primary care patients, albeit with a smaller effect size than that for anxiety treatment overall. The clinical importance of the effect among primary care patients is difficult to determine but may be judged by the findings in studies with effects close to the size of the overall pooled effect. In one study with a standardized symptom change score very close to the overall pooled effect, 57 percent of the intervention group participants had reduced their anxiety symptom score by 50 percent or more, compared to 37 percent in the usual care group, which suggests a clinically important effect.^294^ The other study with an effect very close to the pooled effect reported a difference in change between groups on the GAD-SS of 0.3 points, which was not statistically significant. However, the intervention group on average met this study’s stated criteria for clinically important change of two or more points, with a mean (SD) change of −2.8 (3.8) points from baseline to followup; the control group did not meet this criterion (mean [SD] change, −1.6 [4.2]).^298^

Among studies in mixed populations of people with depression or anxiety, several studies used the Hospital Anxiety and Depression Scale (HADS) as the outcome measure, and differences between groups in absolute change scores were universally smaller than estimates of minimal clinically important difference^385^ of 1.7. However, we excluded the HADS in our examination of diagnostic accuracy because another review concluded that the underlying structure of the HADS is inconsistent across samples and highly dependent on the statistical methods used to establish that structure.^386^ The reviewers concluded that it should not be used to measure depression and anxiety specifically, but should only be used as a measure of general distress. Commentators have suggested discontinuing the use of the HADS because it is not a dependable tool for assessing the absolute or relative levels of anxiety or depression.^387^

Most of the primary studies were conducted outside the US. Most participants included were White, and most studies targeted general adult (versus older adult or perinatal) populations. Most studies utilized CBT-based interventions and few studies directly involved primary care providers in the delivery of treatment. Few studies reported effect modification in specific populations of interest, but one US-based RCT reported that treatment was more effective in persons 35–59 years of age (relative to younger or older age groups), in White individuals (relative to persons of other racial or ethnic groups), and persons who live alone. A separate review found a standardized mean difference of −0.39 (95% CI, −0.63 to −0.15) for primary care patients with depression or anxiety treated with CBT.^218^ This effect size is slightly larger than our findings of −0.21 (95% CI, −0.35 to −0.06) among people with anxiety or depression, and −0.31 [95% CI, −0.44 to −0.19] when limited to individuals with anxiety. Their analysis included some studies excluded from our review because they were limited to people with certain medical conditions or because they received poor-quality ratings.

Potential pharmacological treatments for anxiety include antidepressants (particularly SSRIs and SNRIs), antihistamines (such as hydroxyzine), beta-blockers (such as propranolol), and anti-convulsant medications (such as gabapentin).^388^ Benzodiazepines, such as alprazolam or clonazepam, are often prescribed for acute anxiety or panic attacks. Buspirone is often used as an alternative to benzodiazepines because it is associated with a lower risk of dependence. Despite the variety of treatment options, we found only two RCTs of pharmacotherapy in primary care patient populations; both studies reported benefits of treatment with antidepressants (specifically venlafaxine and escitalopram) for up to 24 weeks. Broad ESR evidence (not limited to primary care populations) also suggested improvements in anxiety and other outcomes (such as depression and social functioning) for general adults or older adults taking antidepressants or benzodiazepines for one to three months. Additional research is needed to address the benefit of pharmacological treatment for anxiety in perinatal populations.

### Harms Associated With Treatment for Anxiety

Antidepressants are widely used for the treatment of anxiety, and many of the reviews we included examined the risk of harm for any indication (including anxiety). Thus, many of the findings on antidepressant use for depression also apply to antidepressant use for anxiety. Beyond antidepressants, we found very limited evidence on risk of serious harm with pharmacologic treatment for anxiety, in both primary studies and existing systematic reviews. One included study examined the risk of suicide with benzodiazepine use as a treatment for anxiety; this was a relatively small case-control study that included information on 154 suicide deaths. We also found a systematic review that examined studies reporting the association between benzodiazepines and suicide, although it did not meet our quality criteria because it searched only one database and did not examine risk of bias (which we felt was particularly important when synthesizing observational studies).^389^ However, it did identify 17 studies, most of which found an association between benzodiazepine use and suicide, covering a range of study populations. Although we did not find synthesized evidence on the risk of addiction or misuse of benzodiazepines in our search window, the FDA issued a warning in 2020:

“…even when taken at recommended dosages, [benzodiazepine] use can lead to misuse, abuse, and addiction. Abuse and misuse can result in overdose or death, especially when benzodiazepines are combined with other medicines, such as opioid pain relievers, alcohol, or illicit drugs. Physical dependence can occur when benzodiazepines are taken steadily for several days to weeks, even as prescribed. Stopping them abruptly or reducing the dosage too quickly can result in withdrawal reactions, including seizures, which can be life-threatening.”^390^

In addition, the FDA has issued a warning on the dangers of combined use of benzodiazepines with opioid medicines (including prescription pain and cough medications that contain opioids) and other central nervous system depressants.^391^ This combination can result in slowed or difficult breathing and death. While the absolute number of overdose deaths associated with prescription benzodiazepine use is low, it increased by 21% between 2019 and 2020, from 921 to 1,122 per 100,000; 92.7% of these overdoses also involved opioids.^392^ Thus, while effective, multiple streams of evidence suggested a need for caution and close monitoring for benzodiazepines. Benzodiazepines are controlled substances with the potential for abuse, and are known to be misused, particularly among people with a history of alcohol and substance misuse.^393^ They can also negatively affect cognition, even after discontinuation of use, although the clinical significance of the cognitive effects are unclear.^394^ Among older adults, benzodiazepines are association with harmful drug interactions, psychomotor slowing, cognitive dysfunction, an increased risk of falls at attendant hip and femur fractures, and an increased risk of motor vehicle crashes.^393^ We did not find any evidence on risks of treatment using anxiolytic medications other than benzodiazepines.

### Screening for Suicide Risk

Suicide prevention efforts have the potential to save many American lives, and according to the CDC, success in preventing suicide is most likely if addressed at multiple levels and in multiple sectors.^7^ While there is surely an important role for healthcare settings, we found only one trial reporting direct evidence on suicide risk screening, in primary care patients who had screened positive for depression. The findings were inconclusive. We scoped the review to include evidence on screening in broad populations (not only those who screen positive for depression), but we found no such evidence. In addition, we found minimal evidence on the test performance of suicide risk screening instruments; no instrument was addressed in more than one study.

Studies without control groups (and therefore not included in our review) have indicated that asking adults about suicidality in mental health settings does not increase suicidality.^356,^ ^395,^ ^396^ Similarly, a randomized trial among adults with borderline personality disorder comparing frequent and repeated mental health assessment (five times per day initially, then daily, then weekly) with or without items assessing suicidal ideation, found no increase in suicidal thoughts or behaviors with suicide-related screening compared with mental health screening without suicide-related items.^397^ Some healthcare systems have implemented suicide risk screening in primary care settings, without reports of harms. These include the VA system, which recommends using the PHQ-9,^398^ a depression screener that includes a suicide-related item, and the Chickasaw Nation Departments of Health and Family Services,^399^ which recommends administering the full PHQ-9 to those who screen positive on the PHQ-2. Given the risks associated with suicidal ideation and significant wait times between referral and receipt of appropriate mental health care that may occur in many settings, developing a safety plan for suicidal individuals while awaiting care must be considered.

Qualitative patient interviews among people who screened positive for depression on the PHQ-2 in primary care settings and subsequently completed the PHQ-9 indicated that being asked about suicidal thoughts felt appropriate and valuable, given the context of their positive depression screen.^400^ One theme that emerged, however, was difficulty answering the PHQ-9 item about suicide (“Thoughts that you would be better off dead, or thoughts of hurting yourself in some way”). For example, some felt that while they thought about suicide or wishing they were dead, they felt strongly that they would never attempt suicide. Another theme that emerged was that disclosing their thoughts of suicide or wishing to be dead involved weighing the hope for help against fears of negative consequences, such as fear of loss of autonomy, stigma, judgment, and feelings of shame and vulnerability. Another theme reinforced the importance of a trusting relationship with the provider and the value of the provider’s willingness to listen without judgement.

However, there may be other potential harms of screening for suicide risk in primary care settings. For example, there are documented cases in which health care associated with suicide attempts has been denied coverage^401,^ ^402^ by medical insurance, and having a positive suicide risk screener may increase the risk that some types of injuries could be interpreted as suicide attempts. Similarly, life insurance payouts could potentially be affected by findings of increased suicide risk in medical records, since most policies do not pay out for suicide deaths in the first two years of coverage.^403,^ ^404^ Thus, a screening result in the medical record indicating an elevated risk of suicide could result in serious financial implications for people who struggle with mental health issues and their families. In addition, clinicians who fail to adequately intervene to prevent suicide in patients screening positive for suicidal ideation may be vulnerable to malpractice suits if a patient dies by suicide who screened positive for suicidal ideation,^405^ despite the fact that suicidal ideation has very limited accuracy in predicting suicide attempts and death in primary care settings. These types of structural barriers for patients and clinicians are examples of why multi-level and multi-sector efforts are needed to make suicide prevention programs as effective as possible.

### Predicting Future Suicide Attempts (Contextual Question 4)

For the accuracy of suicide risk screening tools, our review focused on tools to determine the presence of current suicidal ideation, but we did not address the ability of these tools to predict future suicide attempts and deaths. The odds of a future suicide attempt and suicide death approximately double in the presence of suicidal ideation.^406^ One study found that mental health patients with nearly daily suicidal ideation according to the PHQ-9 suicidality item were five to eight times more likely to attempt suicide and three to eleven times more likely to die by suicide within 30 days than those without suicidal ideation.^407^ Similarly, the same group of researchers found that the 13% of patients in a large managed care system who reported thoughts of death or self-harm “more than half the days” or “nearly every day” according to the suicidality item of the PHQ-9 accounted for 53% of suicide attempts and 54% of suicide deaths over the 5 years of observation.^408^ In this health system, clinicians in all settings were encouraged to administer the PHQ-9 to patients with depression for symptom monitoring, so this was largely a sample of patients known to have depression. The relationships between suicide thoughts and attempts and deaths were similar across age groups.

However, given the very rare nature of suicide (14/100,000 persons annually), the absolute predictive value of suicidal ideation to predict suicide attempts and deaths is very low, especially among non-psychiatric patients. Non-psychiatric patients with suicidal ideation have an estimated 0.23% absolute risk of suicide over the next year.^409^ Studies indicate that approximately 70% of people who die by suicide will have denied suicidal ideation at their last clinical contact.^82,^ ^410^ For example, 67% of decedents in a study of 157 people who had died by suicide had denied suicidal ideation at last contact, and fifty percent of those who had been asked and denied suicidal ideation died within 2 days of that encounter.^82^ Thus, assessing for suicidal ideation is only part of the risk assessment process. A comprehensive risk assessment is needed to estimate future suicide risk, including access to means of suicide and factors such as depression, anxiety, substance use, chronic and current stressors, sleep, prior history of self-harm, and physical health.

We did not examine studies of suicide risk prediction models, which use electronic algorithms based on information in medical and administrative databases to estimate suicide risk. These approaches have the potential benefit of broad reach since they could be implemented across an entire health system at relatively low cost. However, a review of modern-generation risk prediction models, including those that use machine learning algorithms, concluded that these tools are also likely inadequate for widespread use.^411^ This review found that PPVs for suicide deaths ranged from <0.1% to 19%, and ranged from 0% to 78% in predicting suicide attempts.^411^ Risk prediction appears to be more successful in the context of specialty mental health, where one study found that people with risk scores in the top 5% accounted for 43% of subsequent suicide attempts and 48% of suicide deaths.^412^ However, PPV is still quite low even among mental health patients. A systematic review of the PPV of tools for predicting suicide deaths or self-harm in cohorts of psychiatric patients found that an estimated 5.5% of patients stratified as high risk will die by suicide, compared with 0.9% of lower-risk patients, over an average followup of 63 months.^413^ In this review, an estimated 44 percent of suicide decedents would have been classified as low risk.^413^

Unfortunately, there may also be a risk of promoting health inequities with the use of some electronic prediction tools. Recent research showed that two different algorithms performed much more poorly in Black and Native American or Alaska Native patients than in White patients.^414^ For example, one algorithm had sensitivity of 62.2% for White patients compared with 10.0% for Black patients, and 6.7% for Native American or Alaska Native patients at the 90th percentile of risk. Results were very similar for the other algorithm examined in this study. Future studies of risk prediction tools should carefully assess the performance across racial, ethnic, and other important subgroups, such as age, gender and gender identity, and sexual orientation.

Given the limits of screening instruments and risk prediction tools for predicting suicide risk, the UK’s National Institute for Health and Care Excellence guidance on longer-term management of self-harm suggests that clinicians “Do not use risk assessment tools and scales to predict future suicide or repetition of self-harm” and instead recommends conducting a ‘needs assessment’ to determine allocation of clinical aftercare.^415^ Similarly, The Prioritized Research Agenda for Suicide Prevention^416^ concluded that “there is great urgency to finding adequate suicide screening approaches for various sectors of medical care” and notes that the “science of screening is lagging behind practice” (p. 25).^416^ This group has proposed a number of research needs to help improve suicide risk prediction, including understanding current practice, developing intensive monitoring of lifetime high-risk patients, and testing combinations of potential markers for near-term suicide risk, among other recommendations.

### Suicide Prevention Treatment

Although the studies of treatment to prevent suicide included in our review did not demonstrate a benefit and indicated a possible increase in risk for one intervention feasible for wide-spread implementation, the included body of evidence had some important limitations. Chiefly, the control groups for the included studies were usual care, typically including specialty mental health care, which is likely effective in reducing the risk of suicide attempts and deaths. Further, “usual care” was sometimes optimized, such as through increased training or selection of known community experts to act as control group clinicians. The very large study with negative findings enrolled participants based on PHQ-9 scores that had been entered into the electronic medical record, and most of these were in the context of usual depression care. Thus, the applicability of these findings to screening in people without known depression is uncertain. In addition, we excluded studies of people who were seeking treatment in acute care settings due to their suicide risk, as well as studies limited to people with substance use or serious mental health conditions like schizophrenia or bipolar disorder, to enhance applicability of our findings to persons who would be identified through screening in general primary care settings. Thus, we examined a fairly narrow slice of the larger body of suicide prevention intervention trials. Given the need for safety among research participants, it would be very difficult to design a study meeting ethical guidelines has a less intensive control group, so it will always be difficult to determine the absolute effectiveness of suicide prevention interventions.

Broader examination of the literature indicates that some treatment approaches are considered effective evidence-based approaches, such as CBT, dialectical behavioral therapy, pharmacologic treatment, and means restriction.^417–419^ For example, a meta-analysis of 32 RCTs^420^ found that adults who had received psychological treatment were less likely to attempt suicide during followup compared to those who received pharmacological interventions, general supportive interventions, telephone interviews, or treatment as usual. Another systematic review^421^ concluded that interventions that directly targeted suicidal thoughts and behaviors were more effective in reducing suicide attempts and suicide compared to interventions that only addressed these factors indirectly. Psychotropic medications also have an important role to play in suicide prevention. Medications may be used for addressing specific mental health conditions that can increase the risk of suicide such as depression, anxiety, PTSD, and bipolar disorder. In addition, acute administration of ketamine and esketamine have been approved for suicide prevention, with onset of benefit within minutes to hours.^422^ However, the risk of adverse effects must still be considered.^423^

In 2020, NIMH stated that one of its high priority research areas is “research aimed at implementing evidence-based practices in routine care”^424^ and endorsed the Zero Suicide approach. The Zero Suicide initiative has developed a framework, roadmap, and implementation toolkit that includes elements addressing all levels of healthcare organizations.^425^ One of the elements of this approach is comprehensive suicide risk screening. The elements of Zero Suicide are:

- Lead system-wide culture change committed to reducing suicides
- Train a competent, confident, and caring workforce
- Identify individuals with suicide risk via comprehensive screening and assessment
- Engage all individuals at-risk of suicide using a suicide care management plan
- Treat suicidal thoughts and behaviors directly using evidence-based treatments
- Transition individuals through care with warm hand-offs and supportive contacts
- Improve policies and procedures through continuous quality improvement

According to this model, screening alone would be unlikely to have an impact on suicide rates, but it may be a valuable piece of a whole-system intervention. An observational study of 110 outpatient mental health clinics demonstrated that using the Zero Suicide Initiative practices was associated with lower rates of suicide attempts and deaths.^426^ A multisite implementation study is underway examining the efficacy the Zero Suicide Initiative framework of care in six different healthcare systems.^65,^ ^427^ It is unclear whether these implementation studies will include broad screening in primary care settings or whether they are focused on mental health settings. However, the findings of the large, included suicide prevention study indicates that further study is needed to determine effective suicide prevention interventions that could be feasible for widespread implementation in healthcare systems.

### Screening for Depression, Anxiety, or Suicide Risk Separately Compared With Screening for One or More of These Conditions at the Same Time (Contextual Question 1)

We found no evidence on whether there are relative advantages to screening for a single condition versus multiple conditions simultaneously. One included screening (KQ1) study screened for both depression and anxiety, and found no differences between participants whose clinician received a report showing their symptom profiles and those who did not, but whether this was related to the combined versus single-condition screening approach cannot be determined.^165^ The commonly-used PHQ-9 screening tool includes an item addressing suicidal ideation, and while some patients reported having difficulty answering that item (as described above), the performance characteristics of the PHQ were very similar with or without the suicide-related item according to studies included in our review. In addition, among our included studies of anxiety treatment in primary care settings, studies that included people with anxiety or depression generally had smaller effect sizes on both anxiety and depression outcomes than studies that were limited to people with anxiety. This finding could be due to differences across the two groups of studies in mean baseline symptom severity, measures used, or other study characteristics. Our searches did not turn up any additional studies that helped address this question.

### Mental Health Equity Across Racial and Ethnic Groups

We found minimal information on the effects of mental health screening in some important specific patient populations. The long history of discriminatory policies and institutions in the US have left an impact on the mental health of traditionally underserved communities, such as among people who identify as Black, Hispanic/Latino, Native American, and Asian American. The health care system has contributed to these inequities through inadvertent biases in diagnosis and by tolerating differential barriers to receiving appropriate treatment. For example, compared to White patients, misdiagnosis of mental health conditions appears to be more common in Black and Hispanic/Latino patients,^87,^ ^88,^ ^428^ who are also less likely to receive mental health services than White or Asian Americans.^429,^ ^430^ Cost of treatment and lack of insurance are among the main barriers to receiving mental health services,^431^ which tend to have a greater impact on Black Americans and other race and ethnic groups than on White Americans, given the structural policies in the US that have contributed to large inequities in wealth.^432^ Implementation of routine depression screening may help in reducing inequities that stem from differential screening, as one large implementation study showed that a program of routine screening eliminated disparities between Black and other English-speaking primary care patients in a large health system.^433^ See Appendix H for a more detailed examination of mental health inequities related to racial and ethnic background. More research is needed on the impact of mental health screening in Black, Hispanic/Latino, Native American, and Asian American communities in the US.

### Validity of Screening Instruments Across Race and Ethnic Groups (Contextual Question 5)

Several studies noted similar psychometric properties of English versions of the PHQ-9^91,^ ^434,^ ^435^ and the EPDS^436^ across different American race and ethnic groups. However, we identified some variation in factor structure for some instruments, and differences in the relative patterns of item endorsement across race and ethnic groups, suggesting that some mental health screeners may perform differentially across cultural groups. For example, one study found a slightly different pattern of symptom endorsement for Chinese American and Hispanic/Latino participants compared to White participants, but no differences between White and Black participants for the PHQ-9.^91^ The 20-item CESD showed factor structure variability across American cultural groups in measuring depression,^437,^ ^438^ and poorer predictive ability for Black than for White adults. In addition, Black Americans had a different pattern of endorsement of anxiety symptoms on the GAD-7 than White Americans.^90^ The GAD-7 factor structure was similar across Black, White, and Hispanic groups, however, indicating a single underlying factor. See Appendix H for a more detailed discussion on the validity of screening instruments across race and ethnic groups.

### Mental Health Screening and Increased Recognition or Treatment of Depression (Contextual Question 2)

Some of the depression screening trials reported on whether screening increased the likelihood that patients’ depression was recognized by their providers, whether they were offered treatment or referred for treatment, and whether they received treatment (Appendix I). Five studies of depression screening reported on whether screening increased the likelihood that patients’ depression was recognized by their clinician, typically measured by the presence of a diagnosis in the medical record.^153,^ ^155,^ ^159,^ ^164,^ ^439^ Four of these five studies found an increased likelihood of clinician recognition, covering general, older, and perinatal populations.^153,^ ^155,^ ^159,^ ^164^ Three studies reported an increased likelihood of receiving psychological treatment for depression, among perinatal^159,^ ^164^ and general adult populations.^152^ However, three other studies reported on whether patients were advised or referred for psychological treatment, and while they found effects in the direction of benefit, none of these findings were statistically significant.^149,^ ^151,^ ^163^ Eight trials reported on prescriptions for or use of antidepressant medications. Across all populations, studies were evenly split between finding an increased likelihood of antidepressant prescription or use and finding no group differences (among general,^149–152^ older,^155,^ ^157^ and perinatal^161,^ ^164^ populations). None of the studies of anxiety or suicide risk screening reported on these outcomes.

### Healthcare System Supports to Ensure Appropriate Diagnosis, Followup, and Treatment (Contextual Question 3)

Relatedly, an ongoing issue of concern has been ensuring that primary care patients who are identified as needing mental health services receive the appropriate mental health care. This concern is expressed in the current USPSTF recommendations on screening for depression, which state “Screening should be implemented with adequate systems in place to ensure accurate diagnosis, effective treatment, and appropriate followup.”^133^ Integrated care models, such as collaborative care, have been designed to help address gaps in access to mental health treatment in primary care through the addition of behavioral health professionals (on- or off-site). Collaborative care programs use a multidisciplinary approach that includes behavioral health and psychiatric consultation within the care team. This model of care focuses on population-based care, patient-centered goal setting, stepped care, and measurement-based assessment.^440–442^ Collaborative Care programs have been shown to be more effective than usual care for the initiation of treatment and improved outcomes for depression and anxiety.^443–447^ For example, a 2012 Cochrane Collaboration review of 29 randomized trials (N=24,308) found Collaborative Care resulted in greater depression response (RR 1.32 [95% CI, 1.22 to 1.43], anxiety response (RR 1.50 [95% CI, 1.21 to 1.87]), and antidepressant medication use (RR 1.45 [95% CI, 1.33 to 1.63^447^]) compared with usual care at zero to six months. A 2021 IPDMA identified that while collaborative care has been shown to reduce suicidal ideation in patients with depression compared with usual care, the overall effect size is small^448^ (SMD, −0.11 [95% CI, −0.15 to −0.08]).

Patient education, shared decision making, and family supports within Collaborative Care models can be used to increase patient and family involvement in the management of depression and anxiety.^440^ A systematic review from 2020 of Collaborative Care programs found that the most common engagement strategies employed across programs were patient education (87%) and self-management/self-help supports (47%). Care managers were largely responsible for delivering patient and family engagement and supports with engagement occurring most frequently within the first six- or twelve-months following treatment initiation.^440^

The use of Collaborative care has been shown to improve the initiation of mental health care for individuals in traditionally underserved racial and ethnic groups, with the largest amount of evidence supporting benefits in Black and Hispanic/Latino patients.^449–451^ A systematic review from 2020 found that among 12 studies comparing collaborative care to usual care for Black, Hispanic/Latino, Native, and Asian American patients, eight showed evidence for a benefit in depression symptoms.^451^ For example, one study of 400 primarily Hispanic/Latino adults in Los Angeles found that a culturally adapted CBT delivered through collaborative care showed significantly lower PHQ-9 scores at 16 weeks compared with usual care (8.6 vs 13.3, p<0.001).^452^ For patients with limited English proficiency, collaborative care delivered by bilingual providers may be more effective than usual care. Within a 2018 systematic review, three of four high-quality RCTs reported that 13 to 25 percent more patients had improved depressive symptoms when treated with culturally tailored collaborative care compared to usual care.^450^

Despite these benefits shown by integrated care models, most care settings report insufficient resources to address the needs of the large number of patients in primary care. Telemedicine may offer an opportunity for integrated care within rural and lower resourced care settings. Remote Collaborative Care teams have shown effectiveness in treating depression and anxiety across settings.^453^ While the spread of telemedicine may help increase access to these integrated behavioral and medical care programs in mental health, it may also be a driver of disparities in access to care, particularly among lower SES populations;^442^ therefore, flexibility in treatment setting will remain important.

### Limitations of Our Approach

This report is not an exhaustive review of all evidence related to screening for depression, anxiety, and suicide risk. Given time and resource constraints, we focused on the evidence necessary to support the USPSTF in making a recommendation. That is, we made a priori decisions to focus this review on evidence to determine: whether screening in primary care (or similarly broad) populations improves health outcomes or causes harm; whether there are screening tools that are valid and feasible to use in primary care populations; and whether there are treatments available for persons with these conditions that are effective and not harmful. We did not aim to determine all possible screening instruments and treatments and their comparative effectiveness. We also excluded studies in narrow populations that were not widely applicable to screening in primary care settings, but are seen regularly in primary care settings nevertheless. For example, we did not include studies limited to persons with physical or developmental disabilities or to people with medical or other mental health comorbidities such as heart disease, cancer, substance use disorders, bipolar disorder, or PTSD. Similarly, the screening instruments selected for review may not apply to some important groups of patients, such as those with low literacy, low health literacy, limited verbal language, or patients who do not speak English. We also did not aim to provide an exhaustive exploration of variability in treatment effects and instrument accuracy across all possible patient subgroups and settings. As such, we can provide little guidance on matching tools and treatment to individual patient characteristics, nor can we provide guidance on specific necessary and sufficient intervention components. We also did not examine intervention approaches other than psychological and FDA approved pharmacologic agents. There may be other interventions that could be beneficial, such as physical activity. We also did not include examination of some potentially valuable intervention tools such as virtual reality programs unless they were embedded in a broader psychological intervention.

For the accuracy of suicide risk screening tools, our review focused on tools to determine the presence of suicidal ideation, but we did not address the ability of these tools to predict future suicide attempts and deaths. Risk prediction requires a more extensive, multi-dimensional approach that would likely not be feasible for broad screening in primary care settings. We provide information above on a separate body of literature on the accuracy of tools to predict suicide attempts and deaths.

While not widely used to our knowledge, tools have been developed that simultaneously screen for anxiety, depression, or suicide risk with a single instrument, such as the 21-item DASS-21. Among adults from a virtual behavioral healthcare setting,^454^ the depression and anxiety domains of the DASS-21 were strongly correlated with the PHQ-8 and the GAD-7, respectively. We did not, however, include test accuracy evidence for the DASS-21 or other combined screening instruments. While we recognize the utility of a single screening instrument, in practice these multi-condition instruments typically have a set of questions for each condition that are scored separately and would be similar to administering the PHQ and the GAD at the same clinical encounter.

Another limitation of our review is that, for the harms of included medications, we focused on synthesized literature published in the past 5 years, with the exception of some Cochrane reviews of well-established medications. In addition, we examined only observational studies published in our search window. To help mitigate these limitations, we supplemented our evidence with information from FDA safety monitoring materials in the Discussion above.

### Limitations of the Studies and Future Research Needs

For depression screening, there is still uncertainty about the benefits of screening in older adults, and studies are needed that report outcomes using instruments specifically designed for older adults, and both short-term (<6-month) and long-term (2 years or more) outcomes. There are also limitations to our understanding of the direct impact of screening relative to other depression management supports. As depression screening becomes the standard of care, this is increasingly difficult to study. Nevertheless, rigorous examination of implementation programs are needed that report the percent of patients being screened, referred, and treated as well as patient health outcomes such as depression symptoms and quality of life, prior to program implementation and in control clinics. In addition, more research is needed to understand the impact of depression screening and most appropriate tools among Black, Hispanic/Latino, Asian-American, and Native American/Alaska Native communities. Native Americans/Alaska Native communities were not represented in the included studies, despite disproportionately high depression prevalence. Similarly, more information is needed on screening in other underrepresented groups such as gender non-conforming, immigrant, and non-English speaking communities. Relatedly, research is needed on whether implicit bias among primary care clinicians is associated with lower likelihood of screening some patients or the likelihood of appropriate diagnosis and treatment.

For anxiety screening, more studies are needed on the diagnostic accuracy of screening tools that are feasible for use in primary care settings, tested among primary care patients or similar populations, using valid reference standards, and determining (and replicating) optimal cutoffs for any anxiety disorder. Additionally, more studies are needed that specifically address panic disorder and social anxiety disorder, where evidence was the weakest.

The evidence base to support broad suicide screening in primary care settings is limited and indicates that some approaches may be unhelpful or even potentially harmful. Foundational research is urgently needed in primary care populations, including determining which tools should be used, how screening should be implemented, and what interventions should be provided to people who screen positive. For example, what training is needed and for whom, what system-level supports are needed, and how to minimize the risk of harms such as feeling judged or stigmatized, feeling that a cry for help was ignored, or suffering unnecessary loss of autonomy. We support the NIMH call for research examining the use of the Zero Suicide approach described above under “Suicide prevention treatment.” Patients who are considering suicide are seen in primary care settings on a regular basis, but it is important to determine what approaches are effective in helping these patients before making recommendations.

We identified several studies currently underway that address depression, anxiety, and suicide screening (Appendix J Table 1). Seven studies address implementation of depression screening programs, three of which focus on the effects of depression screening feedback to the patient or primary care clinician on depression severity, and three that address both depression and anxiety screening in perinatal populations. Two studies were identified that address suicide screening and focus on quality improvement within health systems where suicide-related interventions were previously implemented.

### Conclusions

Both direct and indirect evidence support depression screening in primary care settings, including during pregnancy and postpartum. While there is clear evidence that treatment for anxiety is beneficial, there are important evidence gaps surrounding the direct benefits of screening and the best screening tools. There are numerous important gaps in the evidence for suicide risk screening in primary care settings.