# Chapter 3 Results

## Overview of Included Studies

The results for this review will be presented by condition: depression, anxiety, and suicide risk. Within each condition, results are organized by KQ.

We reviewed 23,497 abstracts and assessed 1237 full-text articles for inclusion (Appendix B Figure 1). Overall, we included 185 original research studies or ESRs (reported in 231 publications) across conditions and KQs. This includes 99 primary studies and 86 existing systematic reviews, which collectively include approximately 5000 studies and 10.6 million participants (Figure 2). For depression we included a total of 105 studies [32 original studies (n=385,607) and 73 ESRs (including approximately 2,138 studies and an estimated 9.8 million participants), including the following: KQ1 included 17 RCTs, KQ2 included 14 primary studies and 10 ESRs; KQ3 included 1 RCT, KQ4 included 39 ESRs, and KQ5 included 27 ESRs (reported in 34 publications) and 1 cohort study. For anxiety, we included 59 studies [40 original studies (n=275,489) and 19 ESRs (including approximately 483 studies and an estimated 81,507 participants)] including the following: KQ1 included 2 RCTs, KQ2 included 10 studies, KQ3 had no included studies, KQ4 included 26 primary studies and 18 ESRs, and KQ5 included 3 RCTs, 8 ESRs, and 2 case-control studies. For suicide risk, we included 27 original studies (n=24,826), including the following: For KQ1, we included 1 RCT, KQ2 included 3 primary studies, KQ3 included 1 RCT, KQ4 included 23 RCTs, KQ5 had no additional included studies. The full lists of included studies (by condition) and excluded studies (with reasons for exclusion) are available in Appendix C and Appendix D, respectively.

Figure 2 Overview of Included Studies

NOTE: Studies may be counted under multiple Key Questions and/or conditions.

Abbreviations: ESR = existing systematic review; no. = number.

This figure shows an overview of the number of included studies by condition, key question, study design, and intervention type.

## Depression

### KQ1. Do Depression Screening Programs in Primary Care or Comparable Settings Result in Improved Health Outcomes in Adults, Including Pregnant and Postpartum Persons?

### KQ1a. Does Sending Depression Screening Test Results to Providers (With or Without Additional Care Management Supports) Result in Improved Health Outcomes?

#### Summary

Seventeen trials (reported in 28 publications) examined depression screening,^149–164^ including one that examined screening for depression and several other conditions^165^ (Table 8). The included trials covered general adult,^149–153,^ ^165^ older adult,^154–157^ and perinatal populations.^158–164^ Evidence supported the benefits of screening for depression (Table 9). For example, screening interventions, most of which also included other care management components, were associated with a lower prevalence of depression or clinically important depressive symptomatology (OR, 0.60 [95% CI, 0.50 to 0.73]; 8 RCTs [n=10,244]; I^2^=0%), and, among participants above a specified symptom level at baseline, a greater likelihood of remission or falling below a specified level of depression symptomatology (OR, 1.58 [95% CI, 1.23 to 2.02]; 8 RCTs [n=2,302]; I^2^=0%) at 6 months post-baseline or postpartum (or the closest followup to 6 months).

Table 8 Characteristics of Depression Screening Studies (KQ1)

Author, Year | Quality rating | Study design (unscreened control?) | All have sx? | Study N | Broad population | Country | Specific population | FUP, wks | Screening approach | Condition criteria | Benefit (KQ1) | Harm (KQ3)
Bergus, 2005^149^ | Fair | RCT (No) | Yes | 59 | General adults | USA | Adult primary care patients in rural clinics screening positive for depression. | 4, 10, 24 | Screening results | PHQ-2 positive | X
Bijl, 2003^154^ | Fair | Cluster RCT (No) | Yes | 145 | Older adults | NLD | Primary care patients age ≥55 years with MDD. | 8, 26, 52 | Screening results, GP training | GDS ≥5 and PRIME-MD interview positive | X
Callahan, 1994^155^ | Fair | Cluster RCT (No) | Yes | 175 | Older adults | USA | Medically indigent primary care patients age ≥60 years screening positive for depression. | 4, 13, 26, 39 | Screening results, treatment protocol | CES-D ≥16 and HAM-D ≥15 | X
Glavin, 2010^158^ | Fair | CCT (No) | No | 2,247 | Postpartum | NOR | Postpartum patients age ≥ years in participating municipality. | p13, p26 | Screening results, redesigned postpartum care | NA (all included) | X
Jarjoura, 2004^150^ | Fair | RCT (No) | Yes | 61 | General adults | USA | Primary care patients age ≥18 years screening positive for depression and not currently receiving or seeking mental health treatment. | 26, 52 | Screening results, treatment protocol | Positive response on the PRIME-MD | X
Kroenke, 2018^165^ | Good | RCT (No) | Yes | 300 | General adults | USA | Primary care patients age ≥18 years screening positive for sleep, pain, anxiety, depression, or fatigue symptoms. | 13 | Screening results | Scored ≥4 (out of 10) on anxiety, depression, sleep, fatigue, or pain sx | X
Leung, 2011^159^ | Good | RCT (Yes) | No | 462 | Postpartum | HKG | Patients at 8 weeks postpartum at participating maternal health centers. | p26, p78 | Screening | NA (all included) | X | X
MacArthur, 2002^160^ | Fair | Cluster RCT (Yes) | No | 2,064 | Postpartum | GBR | General practice patients at 4 weeks postpartum. | p17 | Screening, midwife training in depression care | NA (all included) | X
Morrell, 2009^161^ | Fair | Cluster RCT (No) | No | 3,449 | Postpartum | GBR | Adults age ≥ years at 6 weeks postpartum at participating practices. | p26 | Screening results, health visitor-delivered counseling | NA (all included) | X
Rost, 2001^151^ | Good | Cluster RCT (No) | Yes | 479 | General adults | USA | Primary care patients age ≥18 years screening positive for depression. | 26, 52, 104 | Screening results, provider training and supports | WHO-CIDI-positive and IDD ≥5 | X
van der Weele, 2012^156^ | Good | Cluster RCT (No) | Yes | 239 | Older adults | NLD | Adults age ≥75 years registered at participating practices screening positive for untreated depression. | 26, 52 | Screening results, referral for stepped care | GDS- 5 ≥5 | X
van der Zee, 2017^162^ | Fair | CCT (Yes) | No | 3,089 | Postpartum | NLD | Patients at 2–3 weeks postpartum visiting participating well-child care centers. | p39, p52 | Screening, PCP training and supports | NA (all included) | X
Wells, 2000^152^ | Fair | Cluster RCT (No) | Yes | 1,356 | General adults | USA | Primary care patients age ≥18 years screening positive for depression. | 26, 52, 104, 290 | IG1: Screening results, PCP training and supports, tx | Positive on WHO CIDI-2 | X
Wells, 2000^152^ | Fair | Cluster RCT (No) | Yes | 1,356 | General adults | USA | Primary care patients age ≥18 years screening positive for depression. | 26, 52, 104, 290 | IG2: Screening results, PCP training and supports, CBT | Positive on WHO CIDI-2 | X
Wells, 2000^152^ | Fair | Cluster RCT (No) | Yes | 1356 | General adults | USA | Primary care patients age ≥18 years screening positive for depression. | 26, 52, 104, 290 | IG3: Screening results, PCP training and supports, medication adherence | Positive on WHO CIDI-2 | X
Whooley, 2000^157^ | Fair | Cluster RCT (No) | Yes | 331 | Older adults | USA | Primary care patients age ≥65 years screening positive for depression. | 104 | Screening results, brief provider training | GDS ≥6 | X
Wickberg, 2005^163^ | Fair | Cluster CCT (No) | No | 669 | Pregnant | SWE | Pregnant patients registered at participating prenatal care centers. | g36 | Screening results, brief midwife training | NA (all included) | X
Williams, 1999^153^ | Fair | RCT (Yes) | No | 969 | General adults | USA | Adult primary care patients. | 13 | IG1: Case-finding (1- or 20-item) | NA (all included) | X
Williams, 1999^153^ | Fair | RCT (Yes) | No | 969 | General adults | USA | Adult primary care patients. | 13 | IG2: Case-finding (20-item) | NA (all included) | X
Williams, 1999^153^ | Fair | RCT (Yes) | No | 969 | General adults | USA | Adult primary care patients. | 13 | IG3: Case-finding (1-item) | NA (all included) | X
Yawn, 2012^164^ | Fair | Cluster RCT (No) | No | 2,343 | Postpartum | USA | Patients aged ≥18 years, 5–12 weeks postpartum, receiving care at the participating family practice. | p52 | Screening results, provider training and supports | NA (all included) | X

Abbreviations: CBT = cognitive behavioral therapy; CCT = controlled clinical trial; CES-D = Center for Epidemiologic Studies Depression scale; FUP = followup; GBR = Great Britain; GDS = Geriatric Depression Scale; GP = general practice ; HAM-D = Hamilton Rating Scale for Depression; HKG = Hong Kong; IDD = Inventory to Diagnose Depression ; IG1 = intervention group 1; IG2 = intervention group 2; IG3 = intervention group 3; MDD = major depressive disorder; NA = not applicable; NLD = Netherlands; NOR = Norway; PCP = primary care provider; PHQ = Patient Health Questionnaire; PRIME-MD = Primary Care Evaluation of Mental Disorders; RCTs = randomized controlled trials; SWE = Sweden; sx = symptoms; tx = treatment; USA = United States of America; WHO CIDI = World Health Organization Composite International Diagnostic Interview; WHO CIDI-2 = World Health Organization World Mental Health Composite International Diagnostic Interview.

Table 9 Summary of Meta-Analysis Results for Depression Outcomes Among Depression Screening Studies (KQ1)

Outcome | No. studies (n analyzed) | Type of effect | Pooled result (95% CI)^*^ | I^2^, % | Tau^2^ | Range of effects^†^ | Median (IQR) effects^†^
Prevalence (met criteria for depression or score above cutoff)
All studies | 8 (10,244) | OR | 0.60 (0.50 to 0.73) | 0 | 0.0 | 0.30 to 1.11; ARD: −9.1 to +1.4 | 0.67 (0.47 to 0.80); ARD: −5.2 (−6.8 to −2)
General | 1 (218) | OR | 0.67 (0.37 to 1.21) | NA | NA | 0.67; ARD: −9 | NA (1 effect total)
Older | 1 (206) | OR | 0.70 (0.38 to 1.26) | NA | NA | 0.70 to 0.80; ARD: −8 to −5 | NA (2 effects total)
Postpartum | 5 (9,202) | OR | 0.54 (0.40 to 0.73) | 25.6 | 0.02 | 0.30 to 1.11; ARD: −9.1 to +1.4 | 0.50 (0.40 to 0.67); ARD: −5.2 (−6.1 to −1.9)
Pregnant | 1 (618) | OR | 0.80 (0.48 to 1.35) | NA | NA | 0.80; ARD: −2 | NA (1 effect total)
Remission (did not meet criteria for depression or score below cutoff, among those with symptoms at baseline)
All studies | 8 (2,302) | OR | 1.58 (1.23 to 2.02) | 0 | 0 | 0.81 to 4.81; ARD: −18 to +33.8 | 1.41 (1.14 to 1.95); ARD: 7.2 (2.9 to 15.2)
General | 3 (1,396) | OR | 1.52 (1.41 to 1.63) | 0 | 0 | 0.81 to 4.06; ARD: −5 to +33 | 1.41 (1.14 to 1.70); ARD: 7.7 (3 to 14)
Older | 2 (259) | OR | 0.97 (0.21 to 4.41) | 0 | 0 | 0.83 to 2.49; ARD: −18 to +5 | 1.14 (0.89 to 1.33); ARD: −0.6 (−4.7 to +3)
Postpartum | 2 (562) | OR | 1.83 (0.27 to 12.27) | 0 | 0 | 1.67 to 2.34; ARD: 11.7 to 19 | 2.34 (1.67 to 2.34); ARD: 17.7 (11.7 to 19)
Pregnant | 1 (85) | OR | 4.81 (1.81 to 12.80) | NA | NA | 4.81; ARD: 33.8 | NA (1 effect total)
Combined reduced depression^‡^
All studies | 16 (8,448) | OR | 1.63 (1.37 to 1.95) | 0.5 | 0 | --^§^ | --^§^
General | 5 (1,675) | OR | 1.53 (1.38 to 1.70) | 0 | 0 | --^§^ | --^§^
Older | 4 (675) | OR | 1.00 (0.56 to 1.78) | 15.2 | 0.02 | --^§^ | --^§^
Postpartum | 6 (6,013) | OR | 1.98 (1.60 to 2.43) | 0 | 0 | --^§^ | --^§^
Pregnant | 1 (85) | OR | 4.81 (1.81 to 12.80) | NA | NA | --^§^ | --^§^
Symptom severity (change in depression symptom scores)
All studies | 9 (5,543) | Mean difference in change | −1.0 (−2.3 to 0.3) | 74.4 | 1.1 | −8.2 to +2.6 | −1 (−2.5 to +0.3)
All studies | 6 (3,790) | SMD | −.09 (−0.36 to 0.18) | 79.6 | 0.04 | NR | NR

* Effect based on restricted maximum likelihood model with the Knapp-Hartung adjustment for small samples.

† Range of effects for all study arms, subgroup analyses, and timepoints (i.e., not limited to records in the meta-analysis).

‡ As available, selected depression remission or scoring below a cutoff first, depression prevalence or scoring above a cutoff (reversed) second, and depression response third.

§ Not shown because reversal of results from some studies creates misleading ARD values.

Abbreviations: ARD = absolute risk difference; CI = confidence interval; IQR =interquartile range; NA = not applicable; NR = not reported; OR = odds ratio; SMD = standardized mean difference.

#### Study Characteristics

Seventeen studies (n=18,437) examined the benefits of screening for depression,^149–165^ including one that also screened for symptoms of anxiety, sleep problems, pain, or fatigue and enrolled patients endorsing any of these concerns (Table 8). Six of the included studies covered general adult populations,^149–153,^ ^165^ four were limited to older adults,^154–157^ six were limited to postpartum patients (generally between 2 and 12 weeks postpartum),^158–162,^ ^164^ and one was limited to pregnant patients.^163^ Only four^153,^ ^159,^ ^160,^ ^162^ of the included studies had a control group that was not screened for depression and are considered KQ1 studies (Figure 3). The remaining studies screened all participants but only gave the screening results to clinicians of intervention group participants, meeting criteria for KQ1 and KQ1a are combined and not discussed separately. Nine^149–152,^ ^154–157,^ ^165^ of the included studies only enrolled patients who screened positive for depression. The remaining eight studies included all patients, regardless of the depression screening results,^153,^ ^158–164^ including all of the studies conducted in perinatal populations. All of the studies used some type of individual outreach from a predefined pool of potentially eligible persons for study recruitment, typically patients who were visiting or were registered with participating clinicians or clinics; none relied on interested individuals to contact the study in order to join the study. All but two^162,^ ^165^ of the included studies were also included in the previous USPSTF review on screening for depression.^1^

Figure 3 Key Study Design Features Among Depression Screening Studies (KQ1)

Abbreviations: CG = control group; KQ = key question.

This figure shows the key study design features among depression screening studies for KQ1 by control group type.

Nine of the studies were conducted in the US,^149–153,^ ^155,^ ^157,^ ^164^ and the remaining were conducted in the UK (among postpartum patients),^160,^ ^161^ Hong Kong (among postpartum patients),^159^ or Northern European countries (covering older adult,^154,^ ^156^ postpartum,^158,^ ^162^ and pregnant^163^ patients). Only one of the studies conducted in the US was focused on a perinatal population, conducted among postpartum patients^164^; the remaining US-based studies covered general^149–153,^ ^165^ and older^155,^ ^157^ adult populations. All studies took place in primary care, general practice, OB-GYN, or other maternal/child wellness contexts.

Information about the included samples is summarized in Table 10 (see Appendix E Table 1 for details by study). Across all 17 studies, the average age of participants was 38.2 and this varied by target population. Ninety-three percent of all participants were women; and a majority were women even among studies focused on general adult populations (73% women) and older adults (66% women). Among the nine studies conducted in the US, the percent of participants who were Black ranged from 7.1 to 51.2 (among the six studies reporting), the percent who were Hispanic/Latino ranged from 4.5 to 59.3 (among four reporting), and the percent who were White ranged from 29 to 94.1 (among the six reporting). Only one study reported the percent of participants of Asian descent, and none reported the percent who were Native American or Alaska Native. Three studies had a relatively high proportion of Black participants, with 49.3 percent^165^ (among a general adult population), 51.2 percent^155^ (older adults), and 32.6 percent^157^ (older adults). One study^153^ had a relatively high proportion of Hispanic/Latino participants (59.3%, general adult population). One study focused on primary care patients in rural clinics^149^ and three had samples who were largely economically disadvantaged, as evidenced by being on Medicaid or uninsured and below the poverty line,^150^ being medically indigent^155^ or having low annual income levels (e.g., 76% earning less than $17,000 in the late 1990s).^153^

Table 10 Summary of Participant Demographic Characteristics Among Studies of Depression Screening (KQ1): Weighted Mean (Number of Studies Reporting), Unless Otherwise Indicated

Population | No. of studies (No. US-based studies) | Total N | Mean age | % Women^*^ | Race or ethnicity (US-based studies only [k=9]) | Race or ethnicity, range of % of participants among US-based studies
All | 17 (9) | 18,437 | 38.2 (13) | 93.6 (17) | Black: 17.6 (6); Asian/Asian-Amer: 7.5 (1); Native Amer/AN: NR (0); Hispanic/Latino: 25.4 (4); White: 51.3 (6) | Black: 7.1 to 51.2; Asian/Asian-Amer: NA; Native Amer/AN: NA; Hispanic/Latino: 4.5 to 59.3; White: 29 to 94.1
General | 6 (6) | 3,224 | 48.3 (6) | 72.7 (6) | Black: 13.1 (3); Asian/Asian-Amer: NR (0); Native Amer/AN: NR (0); Hispanic/Latino: 25.4 (2); White: 51.3 (5) | Black: 7.1 to 49.3; Asian-Amer/PI: NA; Native Amer/AN: NA; Hispanic/Latino: 29.6 to 59.3; White: 29 to 94.1
Older | 4 (2) | 890 | 73.3 (4) | 66.3 (4) | Black: 39.0 (2); Asian/Asian-Amer: 7.5 (1); Native Amer/AN: NR (0); Hispanic/Latino: 4.5 (1); White: 43.9 (1) | Black: 32.6 to 51.2; Asian-Amer/PI: NA; Native Amer/AN: NA; Hispanic/Latino: NA; White: NA
Postpartum | 6 (1) | 13,654 | 29.9 (3) | 100^*^ (0) | Black: 18.0 (1); Asian/Asian-Amer: NR (0); Native Amer/AN: NR (0); Hispanic/Latino: 12.0 (1); White: NR (0) | NA
Pregnant | 1 (0) | 669 | NR | 100^*^ (0) | NR | NA

* Gender was not reported in studies of perinatal patients so participants are counted as women, recognizing that there may be some individuals who do not identify as women; non-binary/gender nonconforming categories were not reported in any studies.

Abbreviations: Amer = American; Native Amer/AN = Native American/Alaska Native; NA = not applicable; NR = not reported; US = United States.

The included interventions were very heterogeneous (Table 11, Appendix E Table 2). Four trials studied the effects of screening (or receipt of screening results) with little or no further training or intervention components, conducted in general,^153,^ ^149,^ ^165^ and postpartum^159^ populations.^163^ In these studies, primary care clinicians typically confirmed the diagnosis and made decisions about the need for treatment according to their usual approach. Additional components beyond screening variously offered in other studies included training and materials to improve clinicians’ knowledge and skills surrounding diagnosis and treatment of depression, facilitation or improvement of the referral process, and patient-specific treatment recommendations based on screening results. Four studies offered one-on-one psychological counseling, medication adherence counseling, or symptom monitoring sessions by specially trained staff.^151,^ ^152,^ ^164,^ ^156^ Three of these included regular monitoring both of symptoms and medication use as well counseling sessions.^151,^ ^152,^ ^164^

Table 11 Summary of Intervention Components in Addition to Screening in Depression Screening Studies (KQ1)

Author, Year | Tng in Screening | Tng in Diagnosis | Tng in treatment | Generic tx guide | Generic handout | Pt-specific tx rec | Referral support | Sx monitoring | Monitoring med use | Med use counseling | Therapeutic approach | IG Num Sessions | PCP Role
General adults
Bergus, 2005^149^ | | | | | | | | | | | NA | NA | Most/all
Jarjoura, 2004^150^ | | | X | X | X | | X | | | | NA | NA | Most/all
Kroenke, 2018^165^ | | | | | | | | | | | NR | NA | Most/all
Rost, 2001^151^ | X | X | X | X | X | | X | X | X | X | NA | NA | Some
Wells, 2000^152^ | | X | X | X | X | | X | X | X | X | CBT, Medication management | NR | Some
Wells, 2000^152^ | | X | X | X | X | | X | X | X | X | CBT | NR | Some
Wells, 2000^152^ | | X | X | X | X | | X | X | X | X | Medication management | NR | Some
Williams, 1999^153^ | | | | | | | | | | | NA | NA | Most/all
Williams, 1999^153^ | | | | | | | | | | | NA | NA | Most/all
Williams, 1999^153^ | | | | | | | | | | | NA | NA | Most/all
Older adults
Bijl, 2003^154^ | X | X | X | | | | | | | | NA | NA | Most/all
Callahan, 1994^155^ | | | | X | X | X | | | | | PCP followup visits | 3 | Most/all
van der Weele, 2012^156^ | | | | | | | | | | X | CBT | 1–2 (home visits), 10 (group) | Some
Whooley, 2000^157^ | | X | X | X | | | | | | | Psychoeducation group | 6 (group), 1 (booster group) | Some
Perinatal
Glavin, 2010^158^ | | X | X | X | X | | | | | | Non-directive | ≥1 | None
Leung, 2011^159^ | | | | | | | | | | | Non-directive | NR | Most/all
MacArthur, 2002^160^ | | | X | X | | | | | | | NA | NA | None
Morrell, 2009^161^ | | X | X | X | | | | | | | CBT | ≤8 | None
van der Zee, 2017^162^ | X | | | X | | | X | | | | NA | NA | Some
Wickberg, 2005^163^ | | X | X | | | | | | | | NA | NA | None
Yawn, 2012^164^ | X | X | X | X | X | | X | X | X | X | NR | 1–6 (median: 1) | Some

Abbreviations: CBT = cognitive behavioral therapy; IG = intervention group; NA = not applicable; NR = not reported; Num = number; PCP = primary care provider; pt = patient; sx = symptoms; Tng = training; tx = treatment.

Four studies were rated as good quality^151,^ ^156,^ ^165^ and the remaining were rated as fair quality. The most common issue that warranted a “fair” rating was attrition higher than ten percent. Some fair-quality studies had few other concerns besides attrition (i.e., all or most of the following: adequate randomization methods, baseline comparability between groups, blinding of outcomes assessment, conservative handling of missing data, acceptable statistical methods, and no apparent selective reporting of outcomes).^152,^ ^157,^ ^161^ Other common issues among fair-quality studies were lack of information about whether allocation was blinded and small sample sizes leading to uncertainty about baseline comparability between groups. One of the studies used a quasi-experimental design which assigned two comparable municipalities in Norway to be intervention and control areas,^158^ but the remaining studies were either individual or cluster-randomized trials.

#### Results

Detailed results for all outcomes are reported in Appendix E Tables.

##### Depression Outcomes

Sixteen of the seventeen studies reported the percent of patients who (a) met criteria for a depression diagnosis or were above a specified symptom score at followup (“prevalence,” Appendix E Table 3), (b) did not meet criteria for a depressive disorder or were below a specified symptom score at followup (“remission,” Appendix E Table 4), or (c) showed a prespecified level of symptom reduction, such as a certain number of points or a percentage decline relative to their baseline score (“response,” Appendix E Table 5). Pooled results for the first two of these are shown in Table 9. Pooled analyses showed that screening programs were associated with a lower prevalence of depression compared with no screening or no screening results being given to participants’ clinicians (OR, 0.60 [95% CI, 0.50 to 0.73]; 8 RCTs [n=10,244]; I^2^=0%), and, among participants above a specified symptom level at baseline, a greater likelihood of remission (OR, 1.58 [95% CI, 1.23 to 2.02]; 8 RCTs [n=2,302]; I^2^=0%) at 6 months post-baseline or 6 months postpartum (or the closest followup timepoint to 6 months). Absolute prevalence and remission rates were highly variable, presumably reflecting differences in how the outcome was measured and differences among the study samples. At followup, depression prevalence ranged from 2.5 percent to 67 percent in the control groups and from 0.6 percent to 62 percent in the intervention groups; the median (interquartile range) absolute difference in percentage points between groups was −5.2 (-6.8 to −2.0), favoring the screening groups. Depression remission ranged from 11.7 percent to 66 percent in the control groups and from 13.2 percent to 78.1 percent in the screening groups; the median (interquartile range) absolute difference in percentage points between groups was 7.2 (2.9 to 15.2), favoring the screening groups.

We also conducted a combined analysis, in which remission was entered if it was reported, prevalence (reversed) if remission was not reported, and the percent of participants meeting criteria for a “response” to treatment (typically 50% reduction in symptoms) if neither remission nor prevalence were reported (Figure 4). The combined analysis also demonstrated that the screening programs were associated with a 63 percent increase in the odds of improved depression (OR, 1.63 [95% CI, 1.37 to 1.95]; 16 RCTs [n=8,448]; I^2^=0%). The most robust evidence is among general adult and postpartum populations. Only one trial was limited to pregnant persons, but those findings were consistent with the findings among general and postpartum populations. Among studies of general, postpartum, and pregnant patients, effect sizes were consistently in the direction of benefit, and many were statistically significant for at least one timepoint, particularly among perinatal women. The results in four trials limited to older adults (with lower age cutoffs ranging from 55 to 75 years) were inconsistent with point estimates on both sides of 1.0 and there were no studies reporting statistically significant differences between groups. Stratified analyses indicated statistically different pooled effects across populations and, in a separate analysis, that effect sizes were larger among trials that were not limited to people with symptoms of depression. These findings are discussed further below under “Effect modification and Findings in Specific Populations.”

Figure 4 Forest Plot Showing a Combined Outcome Representing Reduced Depression From Depression Screening Studies (KQ1): Depression Remission or Scoring Below a Cutoff, Depression Prevalence or Scoring Above a Cutoff (Reversed), and Depression Response

(r)Reversal of a study-provided result from above to below cutoff

Abbreviations: BDI = Beck Depression Inventory; CES-D = Center for Epidemiologic Studies Depression scale; CIDI = Composite International Diagnostic Interview; CG = control group; CI = confidence interval; EPDS = Edinburgh Postnatal Depression Scale; GDS = Geriatric Depression Scale; HAM-D = Hamilton Rating Scale for Depression; IG = intervention group MADRS = Montgomery–Asberg Depression Rating Scale; MDD = major depressive disorder; OR = odds ratio; PHQ = Patient Health Questionnaire; PRIME-MD = Primary Care Evaluation of Mental Disorders.

This figure is a forest plot showing a combined outcome representing reduced depression from depression screening studies (key question 1): depression remission or scoring below a cut-off, depression prevalence or scoring above a cut-off (reversed), and depression response.

Thirteen studies also reported a continuous measure of the level of depression symptoms (Figure 5, Appendix E Table 6).^149–151,^ ^154–161,^ ^163,^ ^165^ All of the studies in perinatal patients reported greater reductions in depression symptoms in screening groups than the control groups at one or more time points.^158–161,^ ^163^ Differences between group were typically 1 to 3 points on the Edinburgh Postnatal Depression Scale (EPDS) at 6 to 26 weeks postpartum, and findings were statistically significant for one or more time points in all studies of perinatal women. Only one of the eight studies in non-perinatal populations found a statistically significantly greater reduction in depression symptoms,^151^ although differences trended in the direction of a small benefit in most of the other studies. Several studies did not provide sufficiently detailed results for pooled analysis.

Figure 5 Forest Plot Showing the Difference Between Groups in Change From Baseline Depression Symptom Score in Depression Screening Studies (KQ1)

Abbreviations: BDI = Beck Depression Inventory; CES-D = Center for Epidemiologic Studies Depression scale; CG = control group; CI = confidence interval; EPDS = Edinburgh Postnatal Depression Scale; GDS = Geriatric Depression Scale; IG = intervention group; MADRS = Montgomery–Asberg Depression Rating Scale; MD = mean difference; NR = not reported; PRIME-MD = Primary Care Evaluation of Mental Disorders.

This figure is a forest plot showing the difference between groups in change from baseline depression symptom score in depression screening studies (key question 1)

##### Other Mental Health Outcomes, Quality of Life, and Functioning

Some studies reported on anxiety (Appendix E Table 7),^161,^ ^162,^ ^165^ broad mental health symptom levels (Appendix E Table 7),^159,^ ^161^ or quality of life (Appendix E Table 8).^150–152,^ ^154,^ ^156,^ ^160–162^ Consistent with the findings on depression symptoms, the studies limited to postpartum women typically found small statistically significant benefits of the screening program, but the studies in general and older adults did not. One exception, however was that two studies in general adults with extensive screening supports both found improvements in mental health-related quality of life, as measure by the SF-36 mental health component scores.^151,^ ^152^ Two studies in older adults reported very similar effects on functioning in their screening and control groups (Appendix E Table 9).^154,^ ^155^

##### Other Health Outcomes

One study of older adults reported all-cause mortality (Appendix E Table 10).^156^ This study found fewer deaths in the screening group (5.8%) than in the control group (14.4%, OR, 0.36 [95% CI, 0.15–0.92]), however this was a small study with only 239 participants and 24 deaths. One study in postpartum women found no differences in the rate of hospitalization of their children or the child’s body weight through age 18 months (Appendix E Table 11).^159^

##### Effect Modification and Findings in Specific Populations

No studies reported subgroup analyses exploring results by gender. Only one study each reported findings by age group (in a study limited to adults age 75 years and older^156^) and race/ethnicity.^152^ No differential impact was identified for any outcome in either of these studies. Among studies that were limited to specific populations, stratified analyses of the combined depression outcome (i.e., including remission/below a cutoff, response, or prevalence/above a cutoff [reversed]) indicated statistically significant differences among the populations tested, with larger effects in studies limited to pregnant or postpartum patients (p=0.005), and smaller effects in studies limited to older adults (p=0.007). However, study design differed across populations, as well as other features, making it impossible to determine whether the population or the other study features drove the association with effect size. For example, studies in perinatal women were also more likely to include unscreened control groups and not to restrict their samples to patients with depressive symptoms, a factor that was also associated with larger effect sizes in stratified analyses (p=0.01). In addition, the relatively small number of included studies warrants caution in interpreting meta-analytic differences by study characteristics.

##### Effects in Older Adults

The trials among general adult populations included older adults but none of them reported subgroup effects by age. However, one of the trials in general adults had an average age of 58, indicating that a substantial minority were at least age 60 and older.^153^ In this study, intervention group patients who were depressed at baseline were more likely to be in complete remission at followup than unscreened depressed patients. Specifically, 48 percent of screened participants had ≤1 symptom of depression compared to 27 percent of those not screened (p<0.05). Among the trials limited to older adults, only one used a measure of depression symptoms that was specifically designed for older adults.^157^ This may be an important limitation because older adults commonly suffer from loss of energy, sleep disturbance, and other somatic symptoms of depression that are due to aging or medical conditions, so general symptom severity instruments may be less sensitive to treatment response. Additionally, none of the trials in older adults offered individual psychological counseling by someone with training in psychological treatment in older adults, and the participation in psychoeducational groups offered in two studies was less than 20 percent in both cases.^156,^ ^157^ Thus, interventions in the studies of older adults fell almost entirely to the primary care provider.

### KQ2. Do Instruments to Screen for Depression Accurately Identify Adults, Including Pregnant and Postpartum Persons, With Depression, in Primary Care or Comparable Settings?

#### Summary

We included 14 primary studies^166–179^ and 10 existing systematic reviews (ESRs)^180–189^ that examined the test accuracy of screening for depression (Tables 12 and 13). The 14 primary studies covered multiple versions of the Geriatric Depression Scale (GDS); the GDS-15 was the most common version. The standard cutoff of ≥5 (to identify mild to severe depression) had an acceptable balance of sensitivity and specificity with the GDS-15 accurately identifying 94 percent of those with major depression and 81 percent of those without (Figure 6).

Figure 6 Test Accuracy of the GDS-15 to Detect MDD, at Cutoffs of 5, 6, and 7 (KQ2)

Abbreviations: CI = confidence interval; MDD = major depressive disorder.

This figure is a plot showing the test accuracy of the GDS-15 to detect MDD, at cutoffs of 5, 6, and 7 (key question 2)

Table 12 Characteristics of Primary Studies Examining Test Accuracy of the Geriatric Depression Scale for Detecting Depression (KQ2)

Author, year | Quality | Country | Brief population description | N Screened and analyzed | Diagnostic interview | Diagnostic criteria | Screening test | Condition
Alves Apostolo, 2018^166^ | Fair | Portugal | Older than 65 years^*^ | 139 | Unspecified semistructured interview | DSM-5 | GDS-15 | MDD
Blank, 2004^167^ | Fair | USA | 60 years and older^*^ | 360 | DIS | DSM-IV | GDS-15 | MDD
Blank, 2004^167^ | Fair | USA | 60 years and older^*^ | 360 | DIS | DSM-IV | GDS-30 | MDD
Broekman, 2011^168^ | Fair | Singapore | Regular social services users 60 years and older^*^ | 4253 | SCID | DSM-IV | GDS-15 | MDD
Broekman, 2011^168^ | Fair | Singapore | Regular social services users 60 years and older^*^ | 4253 | SCID | DSM-IV | GDS-7 | MDD
Davison, 2009^169^ | Good | Australia | Assisted living residents^*^ | 168 | SCID | DSM-IV | GDS-15 | MDD
Eriksen, 2019^170^ | Fair | Norway | Community-dwelling adults 60 years and older | 194 | Unspecified structured interview | ICD-10 | GDS-5 | Any symptom of depression
Izal, 2010^171^ | Fair | Spain | 60 years or older | 105 | SCID | DSM-IV | GDS-5 | MDD
Izal, 2010^171^ | Fair | Spain | 60 years or older | 105 | SCID | DSM-IV | GDS-10 | MDD
Izal, 2010^171^ | Fair | Spain | 60 years or older | 105 | SCID | DSM-IV | GDS-15 | MDD
Izal, 2010^171^ | Fair | Spain | 60 years or older | 105 | SCID | DSM-IV | GDS-30 | MDD
Izal, 2010^171^ | Fair | Spain | 60 years or older | 105 | SCID | DSM-IV | GDS-R | MDD
Jung, 2019^172^ | Fair | The Republic of Korea | Outpatients 60 years and older^*^ | 385 | MINI | DSM-IV | GDS-15 | Minor and major depressive disorder
Jung, 2019^172^ | Fair | The Republic of Korea | Outpatients 60 years and older^*^ | 385 | MINI | DSM-IV | GDS-15 | MDD
Licht-Strunk, 2005^173^ | Fair | The Netherlands | Visiting the GP age 55 and older^*^ | 948 | PRIME-MD | DSM-IV | GDS-15 | MDD
Marc, 2008^174^ | Fair | USA | New admission age 65 years and older | 492 | SCID | DSM-IV | GDS-15 | MDD
Pellas, 2021^175^ | Fair | Sweden | 65 years and older | 113 | MINI | DSM-5 | GDS-15 | MDE
Rait, 1999^176^ | Fair | UK | Community African Caribbean resident age 60 years or older | 130 | GMS-AGECAT | Geriatric Mental Scale | GDS-15 | Score ≥3 (depression)
Shin, 2019^177^ | Fair | The Republic of Korea | 60 years and older^*^ | 774 | Unspecified structured interview | DSM-IV | GDS-15 | MDD
Stefan, 2017^178^ | Fair | Romania | 60 years and older^*^ | 172 | Unspecified semi-structured interview | DSM-IV | GDS-15 | MDD
Stefan, 2017^178^ | Fair | Romania | 60 years and older^*^ | 172 | Unspecified semi-structured interview | DSM-IV | GDS-30 | MDD
van Marwijk, 1995^179^ | Fair | The Netherlands | 65 years and older^*^ | 586 | DIS | DSM-IV | GDS-1 | MDD
van Marwijk, 1995^179^ | Fair | The Netherlands | 65 years and older^*^ | 586 | DIS | DSM-IV | GDS-4 | MDD
van Marwijk, 1995^179^ | Fair | The Netherlands | 65 years and older^*^ | 586 | DIS | DSM-IV | GDS-10 | MDD
van Marwijk, 1995^179^ | Fair | The Netherlands | 65 years and older^*^ | 586 | DIS | DSM-IV | GDS-15 | MDD
van Marwijk, 1995^179^ | Fair | The Netherlands | 65 years and older^*^ | 586 | DIS | DSM-IV | GDS-30 | MDD

* Excluded participants with low cognitive function scores or with a diagnosis of major neurocognitive disorder or dementia.

Abbreviations: DIS = diagnostic interview schedule; DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, 4^th^ edition; DSM-5 = Diagnostic and Statistical Manual of Mental Disorders, 5^th^ edition; GDS = Geriatric Depression Scale; GMS AGECAT = Geriatric Mental State-Automated Geriatric Examination for Computer Assisted Taxonomy; GP = general practice; ICD = International Statistical Classification of Diseases; MDD = major depressive disorder; MDE = major depressive episodes; MINI = Mini-International Neuropsychiatric Interview; N = number of participants; PRIME-MD = Primary Care Evaluation of Mental Disorders; SCID = Structured Clinical Interview for DSM Disorders; UK = United Kingdom; USA = United States of America.

Table 13 Characteristics of ESRs of Test Accuracy of Screening Tools to Detect Major Depression

Screening Test | Author, year | No. of studies | Reference standards | No. of participants | No. with depression (%)
PHQ-9 Linear | Negeri, 2021^188,*^ | 100 | Fully structured diagnostic interview; Semi-structured diagnostic interview (excluding MINI), MINI | 44,503 | 4,541 (10.2)
PHQ-9 Linear | Wang, 2021^185^ | 4 | Fully structured diagnostic interview; Semi-structured diagnostic interview | 2,344 | 85 (5.8)^†^
PHQ-9 Algorithm | He, 2020^181,*^ | 54 | Fully structured diagnostic interview; Semi-structured diagnostic interview (excluding MINI), MINI | 16,688 | 2,091 (13)
PHQ-8 | Wu, 2020^186,*^ | 54 | Fully structured diagnostic interview; Semi-structured diagnostic interview (excluding MINI), MINI | 16,742 | 2,097 (12.5)
PHQ-4 | Harel, 2022^187,*^ | 75 | Fully structured diagnostic interview; Semi-structured diagnostic interview (excluding MINI), MINI | 34,698 | 3,392 (9.8)
PHQ-2, PHQ-2+PHQ-9 | Levis, 2020^183,*^ | 100 | Fully structured diagnostic interview; Semi-structured diagnostic interview (excluding MINI), MINI | 44,318 | 4,572 (10.3)
Whooley | Bosanquet, 2015^180^ | 10 | Diagnostic interview | 4,618 | 602 (13.0)
Whooley | Smith, 2022^189^ | 5 | Diagnostic interview | 1,402 | 115 (9.6)
CES-D | Vilagut, 2016^184^ | 28 | Standardized diagnostic interview | 10,617 | 807 (7.6)
EPDS | Levis, 2020^183,*^ | 58 | Fully structured diagnostic interview; Semi-structured diagnostic interview (excluding MINI), MINI | 15,557 | 2,069 (13.3)

* IPD meta-analysis.

† k=3, n=1,465.

Abbreviations: CES-D = Center for Epidemiologic Studies Depression scale; EPDS = Edinburgh Postnatal Depression Scale; MINI = Mini International Neuropsychiatric Interview; PHQ = Patient Health Questionnaire.

The ESRs we identified covered various versions of the PHQ, 2- and 3-item Whooley screening questions, CES-D, and EPDS (Figure 7). The PHQ-9 correctly identified 85 percent of those with major depression and 85 percent of those without major depression, at the standard cutoff of ≥10, when compared to a semi-structured interview reference standard (Figure 8, for a more detailed depiction of the evidence). At the standard cutoff of ≥2 and when compared to a semi-structured interview, the PHQ-2 was more sensitive than the PHQ-9, correctly identifying 91 percent of people with major depression. But specificity at that cutoff was lower, accurately identifying only 67 percent of people without depression. The Whooley, CES-D, and EPDS demonstrated accuracy comparable to the PHQ-2.

Figure 7 Summary of Included ESR and Primary Evidence for Test Accuracy of Screening Instruments to Detect Depression (KQ2)

Abbreviations: CES-D = Center for Epidemiologic Studies Depression scale; CI = confidence interval; EPDS = Edinburgh Postnatal Depression Scale; GAD = Generalized Anxiety Disorder; GDS = Geriatric Depression Scale; GDS-SI = Geriatric Depression Scale – Suicide Ideation; NA = not applicable; PHQ = Patient Health Questionnaire; SDDS-PC = Symptom Driven Diagnostic System for Primary Care.

This figure is a shows a summary of included ESR and primary evidence for test accuracy of screening instruments to detect depression (key question 2)

Figure 8 Test Accuracy of PHQ, CES-D, Whooley, and the EPDS From Published SERs (KQ2)

Abbreviations: CES-D = Center for Epidemiologic Studies Depression scale; CI = Confidence interval; EPDS = Edinburgh Postnatal Depression Scale; MINI = Mini International Neuropsychiatric Interview; NA = Not applicable; NR = Not reported; PHQ = Patient Health Questionnaire; SER = systematic evidence review.

This figure shows a plot of test accuracy of PHQ, CES-D, Whooley, and the EPDS from published SERs (key question 2)

#### Study Characteristics of Primary Research Studies

Fourteen primary studies (n=8819) were included that provided test accuracy results for the Geriatric Depression Scale (GDS, Table 12).^166–179^ None of these studies were included in the previous review, as the previous review only addressed screening instrument accuracy for pregnant individuals. The GDS-15 was the most common version, but several other versions were also included. Two studies were conducted in the US.^167,^ ^174^ The others were conducted in Norway, Sweden, the Netherlands, the United Kingdom, Spain, Portugal, Romania, Australia, the Republic of Korea, and Singapore. Sample size ranged from 105 to 4,253; most studies (k=10) analyzed a sample of 500 participants or less.

Ten studies explicitly excluded those with cognitive impairment or those scoring low on cognitive function tests (e.g., MMSE) (Table 12). All studies recruited adults aged 55, 60, or 65 years and older or assisted living residents. Mean age ranged from 69 to 85 years (k=13) (Table 14). Women were represented in higher proportions than men: 50 to 77 percent of participants were women. Race and ethnicity were sparsely reported (k=4). One study conducted in Singapore recruited only participants of Chinese (90%) or Malaysian and South Asian Indian (10%) ethnicity^168^ and another study in the UK recruited only participants of African Caribbean ethnicity.^176^ The two other studies reporting race or ethnicity recruited primarily White participants (85% and 90%).^167,^ ^174^ SES was variably reported; mean years of education ranged from 5.6 to 10 (k=3) and those with 12 or more years of education ranged from 65 to 69 percent (k=2).

Table 14 Participant Characteristics for Studies of Test Accuracy of Depression Screening Instruments (KQ2)

Author, year | N analyzed | Major depressive disorder, n (%) | Mean age, years | Age range, years | % Women^*^ | Race or ethnicity, % | SES
Alves Apostolo, 2018^166^ | 139 | 23 (16.5) | 78 | 65–96 | 60 | NR | Mean education, years: 5.6
Blank, 2004^167^ | 125 | 14 (11.2) | 76.8 | ≥60 | 76 | White: 90; Other: 10 | Education, %; 6th grade or less: 0; 7–11th grade: 35; 12th grade or more: 65; Annual income, %; <10,000: 19; 10–19,999: 52; 20–29,999: 9; 30–39,999: 11; ≥40,000: 9
Broekman, 2011^168^ | 4,253 | 147 (3.5) | 74 | ≥60 | 59 | Asian: 100 | NR
Davison, 2009^169^ | 168 | 27 (16.1) | 85 | 67–97 | 77 | NR | NR
Eriksen, 2019^170^ | 194 | 56 (28.9)^†^ | 73.4 | ≥60 | 74 | NR | NR
Izal, 2010^171^ | 105 | 9 (8.6) | 73 | ≥60 | 58 | NR | NR
Jung, 2019^172^ | 385 | 45 (11.7) | 70.2 | 60–85 | 60.0 | NR | Education, %; <6 years: 45.0; 6–12 years: 45.2; >12 years: 9.8; Self-reported SES, %; High: 5.8; Middle: 71.1; Low: 22.1
Licht-Strunk, 2005 | 948 | NA (13.7)^‡^ | NR | ≥55 | 64.5 | NR | NR
Marc, 2008^174^ | 492 | 71 (14.4) | 78.3 | ≥65 | 65.1 | White: 85.0; Black: 10.4; Hispanic: 3.9 | Educational attainment, %; <High school: 30.6; High school: 31.7; Some college: 17.0; College: 9.9; Post-college: 10.8
Pellas, 2021^175^ | 113 | 17 (15.0)^§^ | 76 | ≥65 | 74 | NR | NR
Rait, 1999^176^ | 130 | 13 (10)^**^ | 69 (Jamaican only) | ≥60 | 50 (Jamaican only) | Black: 100 | NR
Shin, 2019^177^ | 774 | 30 (3.9) | 69 | ≥60 | 60 | NR | Mean total educational years: 7.19
Stefan, 2017^178^ | 172 | 24 (14.0) | 74 | 60–89 | 60 | NR | Average years of education: 10
van Marwijk, 1995^179^ | 586 | 33 (5.6) | 74 | 65–94 | 60 | NR | NR

* Non-binary/gender nonconforming categories were not reported in any studies.

† Any symptom of depression, identified using ICD-10.

‡ Adjusted for partial verification.

§ Major depressive episodes.

** Depression identified using the Geriatric Mental Scale with a depression score of 3 or more.

Abbreviations: ICD-10 = International Statistical Classification of Diseases, 10^th^ revision; N = number of participants; NA = not applicable; NR = not reported; SES = socioeconomic status.

All studies used a structured or semi-structured interview at no more than two weeks after the screener to diagnose depression. The most common interviews were the Structured Clinical Interview for DSM Disorders (SCID) (k=3), the Diagnostic Interview Schedule (DIS) (k=2), and the Mini International Neuropsychiatric Interview (MINI) (k=2); four studies did not report the specific interview used. The proportion of participants who were diagnosed with major depressive disorder ranged from 3.5 percent to 16.5 percent. Two studies did not use DSM to identify participants with major depression and instead defined depression as any symptom of depression based on ICD-10 (found in 10% of the sample)^170^ and a depression score of 3 or more on the Geriatric Mental Scale (28.9%).^170,^ ^176^

#### Results of Primary Research Studies

##### GDS-15

Thirteen studies reported the accuracy of GDS-15 to detect major depressive disorder or depression. Reported cutoffs ranged from ≥0 to ≥14, but the most common cutoff was ≥5 (k=8). The cutoff of ≥5 also had the best balance between sensitivity and specificity with a pooled sensitivity of 0.94 (95% CI, 0.85 to 0.98; I^2^=84.4%; k=7; n=5,655) and pooled specificity of 0.81 (95% CI, 0.70 to 0.89; I^2^=98.9%) to detect MDD (Figure 6, Appendix E Table 12). At a cutoff of ≥5, sensitivity from seven individual studies ranged from 0.72 to 1.0 and specificity ranged from 0.53 to 0.95. Area under the curve (AUC) for the GDS-15 was reported in eight studies and ranged from 0.79 (95% CI, 0.73 to 0.85) to 0.98 (95% CI, 0.97 to 0.99) (Appendix E Table 12).

One additional study—with an aim to estimate the prevalence of depression in the Netherlands—needed extrapolation of their random sample of participants screening negative back to the full screened sample.^173^ After that adjustment, the study had the lowest sensitivity to detect MDD at a cutoff of ≥5: 0.58 (95% CI, 0.54 to 0.62). The corresponding specificity was 0.91 (95% CI, 0.90 to 0.91) (Appendix Table C). With this study included in the meta-analysis (k=8; n=11,095), at a cutoff of ≥5, the pooled sensitivity decreased and the pooled specificity increased: they were 0.92 (95% CI, 0.80 to 0.97; I^2^=94.8%) and 0.83 (95% CI, 0.73 to 0.89; I^2^=98.7%), respectively (pooled data not shown).

Lower cutoffs yielded higher sensitivity but lower specificity. Higher cutoffs were more variable but tended to yield higher specificities and lower sensitivities (Figure 6, Appendix E Table 12).

##### GDS-30

Four studies reported the accuracy of GDS-30 to detect major depressive disorder (MDD). Reported cutoffs ranged from ≥7 to ≥17 with only one cutoff used in more than one study (≥17). Sensitivity ranged from 0.55 at a cutoff of ≥11 to 1.0 at a cutoff of ≥15 and ≥17 (95% CI range, 0.38 to 1.0). Specificity was less variable and ranged from 0.67 at cutoff of ≥7 and ≥10 to 0.96 at a cutoff of ≥15 (95% CI range, 0.62 to 0.99) (Appendix E Table 12). With few studies and few cutoffs reported, a consistent relationship between cutoff and test performance was not identified.

##### Other GDS Versions

Six other versions of the GDS were reported in four studies (Appendix E Table 12). These versions included a revised 10-item version referred to as the GDS-R, and versions with one, four, five, seven, and ten questions. None of these GDS versions were used in more than two studies. In one study, the versions with fewer questions had lower sensitivity and specificity when compared to longer versions of the GDS.^171^ In another study, the single-item GDS did not perform well (sensitivity 0.18 [95% CI, 0.09 to .34]), but the test accuracy of the GDS-4, GDS-10, and GDS-15 were comparable to each other in that sample.^179^ The revised version (GDS-R) performed well in comparison to the GDS-15 and GDS-30, but the test performance of the GDS-R has not been replicated in other studies.

#### Study Characteristics of Existing Systematic Reviews

We included ten ESRs (estimated n=75,000) examining various versions of the PHQ, 2- and 3-item Whooley screening questions, CES-D, and EPDS (Table 13).^180–189^ For the PHQ family of instruments, we included a series of IPD meta-analyses—all conducted by the same group using very similar methods. These reviews examined the accuracy of various versions of the PHQ among adults 18 years and older to screen for major depression. Participants could not be recruited from youth settings, psychiatric settings, or due to their symptoms of depression. Studies taking place in any country were eligible, although the majority took place in countries with a very high human development index. All studies were required to use either a fully structured (including the MINI) or semi-structured interview to determine the diagnosis of major depression; the interview also had to take place within 2 weeks of PHQ administration. The diagnosis of MDD or major depressive episode was determined by DSM or ICD criteria.

#### Results of Existing Systematic Reviews

##### PHQ-9

###### Linear Scoring

The IPD meta-analysis examining the linear scoring algorithm of the PHQ-9 included 100 studies (76 in very high HDI countries) with 44,503 participants.^188^ Thirty-seven studies took place in primary care or included a general population sample, but the majority took place in inpatient or outpatient specialty care (k=63). Among the 44,503 included participants, 4,541 were diagnosed with major depression (10.2%).^190^ IPD meta-analyses were conducted for PHQ cutoffs ranging from ≥5 to ≥15, grouped by the reference standard used (semi-structured, fully structured excluding the MINI, or the MINI).^190^

The standard cutoff for the PHQ-9 to identify depression is ≥10. The IPD meta-analysis confirmed a cutoff of 10 as yielding the best balance of sensitivity and specificity when compared to a semi-structured diagnostic interview (Figure 8). ^190^ For studies using a semi-structured reference standard (k=47, n=11,234) and a PHQ-9 cutoff of ≥10, sensitivity was 0.85 (95% CI, 0.79 to 0.89) and specificity was 0.85 (95% CI, 0.82 to 0.87) (Figure 8, Appendix E Table 13). For studies that used a fully structured reference standard excluding the MINI (k=20, n=17,167) and a PHQ-9 cutoff of ≥10, sensitivity to detect major depression was 0.64 (95% CI, 0.53 to 0.74) and specificity was 0.88 (95% CI, 0.83 to 0.92) (Figure 8, Appendix E Table 13). For studies that used the MINI for a reference standard (k=33, n=16,102) and a PHQ-9 cutoff of ≥10, the sensitivity to detect major depression was 0.74 (95% CI, 0.67 to 0.79) and specificity was 0.89 (95% CI, 0.86 to 0.91) (Figure 8, Appendix E Table 13). The AUC for all reference standards ranged from 0.84 (fully structured, excluding the MINI) to 0.90 (semi-structured) (Appendix E Table 13). The authors noted that older age and male sex were associated with higher specificity.^188^

A systematic review reporting the accuracy of the PHQ-9 to identify prenatal or postnatal depression was also identified. This small review (including only 4 studies from the US) reported sensitivity and specificity consistent with the results of the IPD meta-analysis of PHQ-9 among adults 18 years and older.^185^ Sensitivity to identify prenatal or postnatal depression at a cutoff of ≥10 (k=3) ranged from 0.77 to 0.85 and specificity ranged from 0.62 to 0.84.^185^

###### Algorithm

The IPD meta-analysis examining the test accuracy of the PHQ-9 diagnostic algorithm included 54 studies (40 in very high HDI countries) with 16,688 participants.^181^ Eighteen studies took place in primary care, but the majority took place in inpatient or outpatient specialty care (k=33). Two-thirds of participants (67%; n=11,130) were less than 60 years of age and 57 percent were women (n=9,512). Among the 16,688 included participants, 2,091 were diagnosed with major depression (12.5%). The diagnostic algorithm requires five or more items, each scored with 2 or more points, where at least one of these items is depressed mood or anhedonia. IPD meta-analyses were conducted for the standard algorithm scoring as well as modified scoring (only 1 point required for item 9: “Thoughts that you would be better off dead or of hurting yourself in some way”), grouped by the reference standard used (semi-structured, fully structured excluding the MINI, or the MINI).^181^

For studies using a semi-structured reference standard (k=27, n=6,331) and the original scoring, sensitivity was 0.57 (95% CI, 0.49 to 0.64) and specificity was 0.95 (95% CI, 0.94 to 0.97) (Figure 8, Appendix E Table 13).^181^ For studies that used a fully structured reference standard excluding the MINI (k=13, n=7,577) and the original scoring, sensitivity to detect major depression was 0.35 (95% CI, 0.26 to 0.46) and specificity was 0.95 (95% CI, 0.93 to 0.97) (Figure 8, Appendix E Table 13). For studies that used the MINI for a reference standard (k=15, n=2,952) and the original scoring, the sensitivity to detect major depression was 0.51 (95% CI, 0.49 to 0.53) and specificity was 0.97 (95% CI, 0.96 to 0.98) (Figure 8, Appendix E Table 13). The modified scoring resulted in marginally higher sensitivities and similar specificities (Appendix E Table 13).^181^

##### PHQ-8

The IPD meta-analysis examining the test accuracy of the PHQ-8 included 54 studies with 16,742 participants.^186^ The PHQ-8 differs from the PHQ-9 only by omission of Item 9 (“Thoughts that you would be better off dead or of hurting yourself in some way”). Forty-six percent of participants were recruited from primary care and the remaining were recruited from inpatient or outpatient specialty care. Two-thirds of participants were less than 60 years of age (n=11,144; 67%) and 57 percent were women (n=9,552). Among the 16,742 included participants, 2,097 were diagnosed with major depression (12.5%). IPD meta-analyses were conducted for PHQ-8 cutoffs ranging from ≥9 to ≥15, grouped by the reference standard used (semi-structured, fully structured excluding the MINI, or the MINI).^186^

As found for the PHQ-9, the cutoff yielding the best balance of sensitivity and specificity for the PHQ-8 was ≥10 (Figure 8). For studies using a semi-structured reference standard (k=27, n=6,362) and a PHQ-8 cutoff of ≥10, sensitivity was 0.86 (95% CI, 0.80 to 0.90) and specificity was 0.86 (95% CI, 0.83 to 0.89) (Figure 8, Appendix E Table 13).^186^ For studies that used a fully structured reference standard excluding the MINI (k=13, n=7,596) and a PHQ-8 cutoff of ≥10, sensitivity to detect major depression was 0.63 (95% CI, 0.52 to 0.72) and specificity was 0.86 (95% CI, 0.81 to 0.90) (Appendix E Table 13). For studies that used the MINI for a reference standard (k=14, n=2,784) and a PHQ-8 cutoff of ≥10, the sensitivity to detect major depression was 0.72 (95% CI, 0.63 to 0.79) and specificity was 0.88 (95% CI, 0.84 to 0.91) (Appendix E Table 13). The AUC for all reference standards ranged from 0.852 (fully structured, excluding the MINI) to 0.930 (semi-structured) (Appendix E Table 13).^186^

##### PHQ-4

The IPD meta-analysis examining the test accuracy of the PHQ-4 included 75 studies (51 from very high HDI countries) with 34,698 participants.^187^ The PHQ-4 is comprised of four items from the PHQ-9: depressed mood, loss of interest/pleasure, low self-esteem/guilt, and psychomotor agitation. Thirty-one studies recruited participants from the general population or primary care. The age of participants ranged from 18 to 98 years with a mean of 48 years and 59 percent were women (n=20,678). Among the 34,698 included participants, 3,392 were diagnosed with major depression (9.8%). IPD meta-analyses were conducted for PHQ-4 cutoffs ranging from ≥1 to ≥12, grouped by the reference standard used (semi-structured, fully structured excluding the MINI, or the MINI).^187^

The optimal cutoff for the PHQ-4 was identified as ≥4. For studies using a semi-structured reference standard (k=29, n=7,719) and an PHQ-4 cutoff of ≥2, sensitivity was 0.88 (95% CI, 0.81 to 0.93) and specificity was 0.79 (95% CI, 0.74 to 0.83) (Figure 8, Appendix E Table 13). For studies that used a fully structured reference standard excluding the MINI (k=15, n=12,109) and a PHQ-4 cutoff of ≥2, sensitivity to detect major depression was 0.68 (95% CI, 0.56 to 0.78) and specificity was 0.85 (95% CI, 0.78 to 0.90) (Figure 8, Appendix E Table 13). For studies that used the MINI for a reference standard (k=31, n=14,870) and a PHQ-4 cutoff of ≥2, the sensitivity to detect major depression was 0.80 (95% CI, 0.73 to 0.85) and specificity was 0.83 (95% CI, 0.80 to 0.86) (Figure 8, Appendix E Table 13). The AUC was not reported.^187^

##### PHQ-2

The IPD meta-analysis examining the test accuracy of the PHQ-2 included 100 studies (74 from very high HDI countries) with 44,318 participants.^183^ The PHQ-2 is comprised of the first two items of the PHQ-9 (“Little interest or pleasure in doing things” and “Feeling down, depressed, or hopeless”). 14,450 of participants were recruited from primary care (33%), but nearly as many were recruited from inpatient or outpatient specialty care (n=14,063; 32%). Seventy-two percent of participants were less than 60 years of age (n=31,739) and 59 percent were women (n=26,034). Among the 44,318 included participants, 4,572 were diagnosed with major depression (10.3%). IPD meta-analyses were conducted for PHQ-2 cutoffs ranging from ≥1 to ≥6, grouped by the reference standard used (semi-structured, fully structured excluding the MINI, or the MINI).^183^

Optimal cutoffs for the PHQ-2 have been identified as ≥2 or ≥3, with a cutoff of ≥2 favoring sensitivity over specificity. For studies using a semi-structured reference standard (k=48, n=11,703) and an PHQ-2 cutoff of ≥2, sensitivity was 0.91 (95% CI, 0.88 to 0.94) and specificity was 0.67 (95% CI, 0.64 to 0.71) (Figure 8, Appendix E Table 13).^183^ For studies that used a fully structured reference standard excluding the MINI (k=20, n=17,319) and a PHQ-2 cutoff of ≥2, sensitivity to detect major depression was 0.82 (95% CI, 0.75 to 0.87) and specificity was 0.71 (95% CI, 0.63 to 0.77) (Figure 8, Appendix E Table 13). For studies that used the MINI for a reference standard (k=32, n=15,296) and a PHQ-2 cutoff of ≥2, the sensitivity to detect major depression was 0.89 (95% CI, 0.84 to 0.92) and specificity was 0.68 (95% CI, 0.64 to 0.73) (Figure 8, Appendix E Table 13). At a cutoff of ≥3, sensitivity among reference standards ranged from 0.53 to 0.72 and specificity ranged from 0.85 to 0.89 (Appendix E Table 13). The AUC for all reference standards ranged from 0.82 (fully structured, excluding the MINI) to 0.88 (semi-structured).^183^

###### Sequential Administration of the PHQ-2 and PHQ-9

The systematic review and IPD meta-analysis identified for the PHQ-2 also examined the PHQ-2 in combination with the PHQ-9 (i.e., the PHQ-9 is administered if the PQH-2 is positive).^183^ Forty-four studies using a semi-structured reference standard with 10,627 participants were included. Of those participants, 1,361 were diagnosed with major depression (12.8).^183^ Using a cutoff of ≥2 for the PHQ-2 in combination with the PHQ-9 and a cutoff of ≥10, sensitivity to detect major depression was 0.82 (95% CI, 0.76 to 0.86) and specificity was 0.87 (95% CI, 0.84 to 0.89) (Figure 8, Appendix Table E).^183^ Versus the PHQ-9 alone, the difference in sensitivity was −0.04 (95% CI, −0.09 to 0.01) and the difference in specificity was 0.02 (95% CI, 0.00 to 0.03).^183^

###### Whooley

We identified two systematic reviews examining the accuracy of the Whooley questions to screen for major depression, one including all adults^180^ and one limited to prenatal women.^189^ Two- and three-item Whooley questions were included.

The systematic review examining all adult populations included 10 studies with 4,618 participants.^180^ Of those 4,618 participants, 602 had depression (13.0%). The diagnosis of depression had to be made using DSM or ICD criteria. Five of the studies recruited participants from primary care. Nine studies reported the percent of female participants, ranging from 3 to 100 percent of participants (35% overall).^180^ The pooled sensitivity to detect major depression was 0.95 (95% CI, 0.88 to 0.97) and the pooled specificity was 0.65 (95% CI, 0.56 to 0.74) (Figure 8, Appendix E Table 13).^180^ Among the five studies conducted in primary care, the pooled sensitivity was 0.96 (95% CI, 0.91 to 0.98) and the pooled specificity was 0.61 (95% CI, 0.48 to 0.73).^180^

The systematic review examining only prenatal populations included five studies with 1,402 participants (one study conducted in primary care was removed from their main analysis as an outlier and is not discussed).^189^ Of those participants, 115 were diagnosed with depression (9.6%). The diagnosis of depression was made using DSM-IV and DSM-5 criteria in four studies; one study did not report the diagnostic criteria used. The pooled sensitivity of the Whooley questions to detect major depression was 0.95 (95% CI, 0.81 to 0.99) and pooled specificity was 0.60 (95% CI, 0.44 to 0.74).^189^

##### CES-D

We identified one systematic review examining the accuracy of the CES-D.^184^ The review included 28 studies with 10,617 participants. Studies had to be conducted among participants in primary care or the general population. Eleven studies recruited only older adults and six recruited only adolescents. The diagnosis of major depression was made using DSM or ICD criteria, most commonly using the DIS, SCID, CIDI, and MINI. Of the 10,617 participants, 807 had depression (7.6%; range from individual studies, 1.8 to 37.9%).^184^

To detect major depression using the standard cutoff of ≥16, the CES-D had a pooled sensitivity of 0.87 (95% CI, 0.82 to 0.91) and a pooled specificity of 0.70 (95% CI, 0.65 to 0.75) (Figure 8, Appendix E Table 13).^184^ Higher cutoffs (≥20, ≥22) yielded lower sensitivities and higher specificities. The AUC for the CES-D to detect major depression was 0.87. The authors noted that test accuracy was lower among younger age groups, but the age covariate was not statistically significant.^184^

##### EPDS

We included one recent systematic review and IPD meta-analysis examining the test accuracy of the EPDS to screen for major depression among pregnant or post-partum persons (within 12 months of giving birth), conducted by the same group who did the IPD meta-analyses for the PHQ instruments.^182^ Like the others, this review was also limited to participants who were 18 years or older. Participants could not be previously identified as having possible depression or be receiving psychiatric assessment or care. A total of 58 studies with 15,557 participants were included. Of the included 58 studies, 25 were conducted with pregnant persons, 30 with postpartum persons, and three with both. Studies taking place in any country were eligible; three fifths (62%) took place in very high HDI countries (k=36). Among the 15,557 included participants, 2,069 were diagnosed with major depression (13.3%). All studies were required to use either a fully structured (including the MINI) or semi-structured interview to determine the diagnosis of major depression; the interview also had to take place within 2 weeks of EPDS administration. IPD meta-analyses were conducted for EPDS cutoffs ranging from ≥7 to ≥15, grouped by the reference standard used (semi-structured, fully structured excluding the MINI, or the MINI).^182^

The IPD meta-analysis determined that an EPDS cutoff of ≥11 yielded the best balance of sensitivity and specificity (Figure 8).^182^ For studies using a semi-structured reference standard (k=36, n=9,066) and an EPDS cutoff of 11, sensitivity was 0.81 (95% CI, 0.75 to 0.87) and specificity was 0.88 (95% CI, 0.85 to 0.91) (Figure 8, Appendix E Table 13). With the same reference standard and an EPDS cutoff of ≥12, which is a standard cutoff, sensitivity to detect major depression was 0.75 (95% CI, 0.67 to 0.81) and specificity was 0.92 (95% CI, 0.89 to 0.94) (Appendix E Table 13). Sensitivity and specificity estimates varied sightly with the use of the MINI and other fully structured reference standards, but generally remained in the same ranges. The AUC for all reference standards ranged from 0.890 (MINI) to 0.924 (fully structured, excluding the MINI) (Appendix E Table 13). The authors also noted that the test accuracy did not significantly change when EPDS administration occurred in the postpartum or pregnant period.^182^

### KQ3. What Are the Harms Associated With Screening for Depression in Primary Care or Comparable Settings in Adults, Including Pregnant and Postpartum Persons?

Only one depression screening study reported on harms (Table 8).^159^ This study, conducted in Hong Kong among post-partum patients, reported that there were no adverse events in either group. Across all depression screening studies included for KQ1, there was no pattern of effects indicating that screening might paradoxically worsen any outcomes the interventions were aiming to benefit (Appendix E Table 14).

### KQ4. Does Treatment of Depression (Psychotherapy or Pharmacotherapy) Result in Improved Health Outcomes in Adults, Including Pregnant and Postpartum Persons?

#### Summary

We included 39 ESRs (reported in 41 publications) of treatment for depression, 30 addressing psychological treatment (Table 15)^191–220^ and ten ESRs addressing pharmacologic treatment (Table 16).^212,^ ^221–232^ One ESR reports both psychological and pharmacotherapy treatment benefits and results are discussed under the appropriate sections.^212^ Psychological treatment improved depression outcomes (Figure 9). This was the case in both broad analyses that included a wide range of populations and specific interventions, and in analyses of some important specific populations, including older adults, perinatal populations, and primary care patients. For example, the broadest analysis, which included any type of psychological treatment compared to any kind of control condition, measuring the depression outcome immediately post-treatment (typically 2 to 6 months post-baseline), had a standardized mean difference (SMD) of −0.72 (95% CI, −0.78 to −0.67; k=385, N not reported, but estimated at approximately 33,000),^195^ suggesting a moderate to large effect size. When limited to studies in primary care patients, the effect was smaller but clearly statistically significant (SMD, −0.42 [95% CI, −0.56 to −0.29; k=59, N not reported]). Evidence also indicated that psychological treatment for depression improved other outcomes, including anxiety symptoms, hopelessness, quality of life, social functioning, parental functioning, and mental health in offspring.

Figure 9 Forest Plot of Standardized Mean Differences Between Groups in Depression Symptom Severity by Intervention Type, Population, Control Group Type, and Followup for Psychological Treatment of Depression (KQ4)

Abbreviations: BAT = Behavioral Activation Therapy; CBT = cognitive behavioral therapy; CI: confidence interval; eCBT = enhanced cognitive behavioral therapy; EUC = enhanced usual care; IPT = interpersonal therapy; NOS = not otherwise specified; NR = not reported; PC = primary care; PST = problem solving therapy; SES = socioeconomic status; SMD = standardized mean difference; UC = usual care; WL = waitlist.

This figure shows a forest plot of standardized mean differences between groups in depression symptom severity by intervention type, population, control group type, and followup for psychological treatment of depression (key question 4).

Table 15 Characteristics of Existing Systematic Reviews Included to Address the Benefits of Psychological Treatment of Depression (KQ4)

Author, Year | Cuijpers database | Quality | Outcomes | Population | Intervention | Last search date | Total # of included studies | Total N | Included study designs (Note if conducted IPD analysis)
Aherne, 2017^191^ | No | Good | Depression | Moderate-level depression | Psychological | Jan-2014 | 4 CBT (14 total) | 1,743 | RCTs, ESRs
Castro, 2020^192^ | No | Good | Depression | General population | Telemedicine | Sep-2017 | 10 | 1,392 | RCTs
Collado, 2016^193^ | No | Good | Depression | Hispanic/Latino | Psychological | Jul-2015 | 36 (22 RCT and 14 OLT) | NR | RCTs, open-label trial
Cuijpers, 2017^194^ | Yes | Good | Depression, Anxiety, QoL or functioning, Maternal or fetal, Suicide-related | General population | Psychological | NR | NR | NR | RCTs, ESRs
Cuijpers, 2018^197^ | Yes | Good | Depression | General population | Psychological | Jan-2016 | 256 | 34,921 | RCTs
Cuijpers, 2019^196^ | Yes | Good | Depression | General population | Psychological | Jan-2019 | 289 (369 comparisons) | NR | RCTs
Cuijpers, 2019^198^ | Yes | Good | Depression | General population | Psychological | Jan-2019 | 140 | 15,419 | RCTs
Cuijpers, 2020^195^ | Yes | Good | Depression | General population | Psychological | Jan-2018 | 309 (385 comparisons) | NR | RCTs
Driessen, 2015^199^ | Yes | Good | Depression | General population | Psychological | Jun-2013 | 57 | 2,103 | RCTs
Harerimana, 2019^200^ | No | Good | Depression | Older adults | E-interventions | Nov-2017 | 9 | 2,032 | RCTs, Obsrv, QuasiRCT
Harper Shehadeh, 2016^201^ | No | Good | Depression, Anxiety | Specific racial/ethnic | Self-help (or minimally guided) | Jul-2015 | 8 | NR | RCTs, nonrandomized experimental studies
Holvast, 2017^202^ | No | Good | Depression | Older adult primary care patients | Psychological | Jan-2017 | 11 (10 RCTs and 1 cohort study) | 1,543 (1,529 RCT, 14 cohort) | No restrictions
Huang, 2018^203^ | No | Good | Depression | Perinatal | CBT-specific | Mar-2017 | 20 | 3,623 | RCTs
Karyotaki, 2017^205^ | Yes | Good | Depression | General population | E-interventions | Jan-2016 | 13 | 3,876 | RCTs (IPD)
Karyotaki, 2018^204^ | Yes | Good | Depression | General population | E-interventions | Jan-2016 | 24 | 4,889 | RCTs (IPD)
Letourneau, 2017^206^ | No | Good | Depression | Perinatal | Psychological | NR | 36 | >5,000 | RCTs, QuasiRCT
Li, 2022^220^ | No | Good | Depression, Anxiety | Perinatal | CBT-specific | Apr-2020 | 77 (68 in MA) | 11,221 | RCTs, QuasiRCT
Massoudi, 2019^207^ | No | Good | Depression, Anxiety | Primary care patients | E-interventions | Jan-2018 | 14 | 4,183 | RCTs
Nair, 2018^208^ | No | Good | Depression | Perinatal | Telemedicine | Apr-18 | 10 | 1,138 | RCTs
Nieuwenhuijsen, 2020^209^ | No | Good | QoL or functioning | General population | Psychological | April-2020 | 45 | 13,669 | RCTs
Pineros-Leano, 2017^210^ | No | Good | Depression | Hispanic/Latino immigrant | CBT-specific | Jul-2016 | 11 | NR | RCTs, Obsrv, QuasiRCT
Ponting, 2020^211^ | No | Good | Depression | Perinatal Black and Hispanic/Latino | Psychological | Sep-2018 | 13 (10 RCTs) | 1,971 | RCTs, CCTs
Rojas-Garcia, 2015^212^ | No | Good | Depression | Low SES | Any behavioral delivered in healthcare setting | Apr-2013 | 11 (13 comparisons) | 2,261 | RCTs, QuasiRCT
Roman, 2020^213^ | No | Good | Depression | Perinatal | CBT-specific | 2017 | 6 | 635 | RCTs
Thomas, 2018^214^ | No | Good | Depression | Older adults | CBT-specific | Jan-2015 | 53 | 3,568 | RCTs, Nonrandomized experimental studies
Weaver, 2017^215^ | No | Good | Depression, Anxiety | Rural settings | CBT-specific | Apr-2015 | 16 | 1,193 | No restrictions
Weitz, 2018^216^ | Yes | Good | Anxiety | General population | Psychological | Jan-2016 | 51 | 5,737 | RCTs
Xiang, 2020^217^ | No | Good | Depression | Older adults | E-interventions | Nov-2017 | 9 | 1,272 | RCTs, Obsrv, CCTs
Zhang, 2019^219^ | No | Good | Depression | Primary care patients | Psychological | Apr-2017 | 65 | 10,951 | RCTs
Zhang, 2019a^218^ | No | Good | Depression | Primary care patients | CBT-specific | Nov-2018 | 57 | 10,701 | RCTs

Abbreviations: CBT = cognitive behavioral therapy; CBT-specific = cognitive behavioral therapy-specific; CCTs = controlled clinical trials; E-Interventions = electronic interventions; ESRs = existing systematic reviews; IPD = individual participant data; MA = meta-analysis; N = number of participants; NR = not reported; Obsrv = observation; OLT = open label trial; QoL = quality of life; QuasiRCT = quasi-randomized controlled trial; RCTs = randomized controlled trials; RCTs (IPD) = randomized controlled trial individual participant data; SES = socioeconomic status.

Table 16 Existing Systematic Reviews Included to Address the Benefits of Pharmacologic Treatment of Depression (KQ4)

Author, Year | Quality | Outcomes | Population | Intervention | Last search date | Total # of included studies | Total N | Included study designs (Note if conducted IPD analysis)
Arroll, 2016^221^ | Good | Depression | Primary care patients | AD | Oct-2015 | 17 | NR | RCTs
Baune, 2018^222^ | Good | QoL or functioning | General population | AD | Nov-2014 | 12 | NR | RCTs, Obsrv, CCTs
Cipriani, 2018^224^ | Good | Depression, Harms | General population | AD | Jan-2016 | 522 (814 tx groups) | 116, 477 | RCTs
Cuijpers, 2015^226^ | Good | Depression | General population | AD, SSRIs, SNRIs, Any pharm | January2014 | 53 | 4,740 | RCTs
Krause, 2019^227^ | Good | Depression, QoL or functioning, Harms | Older adults | Any pharm | Dec-2017 | 53 | 9,274 | RCTs
Lee, 2018^228^ | Fair | QoL or functioning | General population | AD | Jun-2017 | 17 | NR | RCTs
Lisinski, 2020^229^ | Fair | Depression, Harms | General population | Duloxetine | NR | 15 | 3575 | RCTs (IPD)
Rabinowitz, 2016^231^ | Fair | Depression | General population | AD | NA | 34 | 10,737 | RCTs (IPD)
Rojas-Garcia, 2015^212^ | Good | Depression | Low SES | Any pharm | Apr-2013 | 11 (13 comparisons) | 2,261 | RCTs, QuasiRCT
Viswanathan, 2021^232^ | Good | Depression, QoL or functioning, Maternal or fetal, Harms | Perinatal | Any pharm | Jun-2020 | 164 | NR | RCTs, Obsrv, CCTs

Abbreviations: AD = antidepressant; CCTs = controlled clinical trials; IPD = individual participant data; N = number of participants; NA = not applicable; NR = not reported; Obsrv = observation; pharm = pharmacotherapy; QoL = quality of life; QuasiRCT = quasi-randomized controlled trial; RCTs = randomized controlled trials; RCTs (IPD) = randomized controlled trial individual participant data; SES = socioeconomic status; SSRIs = selective serotonin reuptake inhibitors; SNRIs = serotonin and norepinephrine reuptake inhibitor; tx = treatment.

Data were limited for populations who were socially or economically disadvantaged or in specific racial or ethnic groups, however the limited evidence supported benefits of psychological treatment in these populations as well. For example, an analysis of five trials among people described as having low socioeconomic status found reduced depressive symptoms at up to 12 weeks post-baseline (SMD, −0.66 [95% CI, −0.92 - −0.41; k=5, N=424]),^212^ and a separate analysis found no differences in effect size between studies limited to race or ethnic “minority” populations vs not limited to these population.^197^

For antidepressant medications, pooled effects consistently demonstrated increased rates of remission and response to treatment, and small but statistically significant reductions in depressive symptom severity in the short term (typically 8 weeks, Figures 10–12). For example, fluoxetine, which had the largest body of evidence with 117 studies, was associated with a small reduction in symptom severity (SMD, −0.23 [95% CI, −0.28 to −0.19]), a 46 percent increase in the odds of remission (OR, 1.46 [95% CI, 1.34 to 1.60]) and a 52 percent increase in the odds of treatment response (OR, 1.52 [95% CI, 1.40 to 1.66], number of studies and individuals included in each specific analysis was not reported, nor were I^2^ values).^224^ However, little information was available on the longer-term impact of antidepressants in the synthesized literature, and information was absent or extremely limited on the benefits of pharmacologic treatment in specific a priori populations of interest.

Figure 10 Forest Plot of Group Differences in Depression Remission With Pharmacological Treatment of Depression Compared to Placebo (KQ4)

Abbreviations: CI = confidence interval; ES = effect size; NR = not reported; OR = odds ratio, PC = primary care; RR = relative risk; SSRI = selective serotonin reuptake inhibitor; TCA = tricyclic antidepressant.

This figure shows a forest plot of group differences in depression remission with pharmacological treatment of depression compared to placebo (key question 4).

Figure 11 Forest Plot of Group Differences in Depression Response With Pharmacological Treatment of Depression Compared to Placebo (KQ4)

Abbreviations: CI = confidence interval; ES = effect size; NR = not reported; OR = odds ratio, RR = relative risk.

This figure shows a forest plot of group differences in depression response with pharmacological treatment of depression compared to placebo (key question 4).

Figure 12 Forest Plot of Standardized Mean Differences Between Groups in Depression Symptom Severity for Pharmacological Treatment of Depression Compared to Placebo (KQ4)

Abbreviations: CI: confidence interval; FUP = followup; NR = not reported; OR = odds ratio, PC = primary care; RR = relative risk; SES = socioeconomic status; SMD = standardized mean difference; SSRI = selective serotonin reuptake inhibitor; TCA = tricyclic antidepressant.

This figure shows a forest plot of standardized mean differences between groups in depression symptom severity for pharmacological treatment of depression compared to placebo (key question 4).

#### Psychological Treatment of Depression

##### Study Characteristics

We examined the benefits of treatment for depression using ESRs. We included 30 reviews of psychological treatment, which covered a wide range of specific intervention approaches and outcomes (Table 15, Appendix E Table 15).^191–220^ Two of these reviews conducted meta-analyses using individual patient data,^204,^ ^205^ enabling them to examine effect modification by patient characteristics. Most other reviews conducted traditional study-level meta-analyses and provided information on effect modification by key study and intervention characteristics. Nine of the reviews utilized the Cuijpers database described in the Methods section, including up to 309 trials with control conditions in a given analysis, and approximately 33,000 participants.^194–198,^ ^204,^ ^205,^ ^216^

All of the included reviews were either limited to studies of people meeting some kind of depression criteria or reported results separately for studies that were limited to those meeting depression-related criteria. Most of the included reviews were limited to studies among adults, generally defined as 18 years and older. Some reviews focused on older adults^200,^ ^202,^ ^214,^ ^217^ (lowest age ranging from 50 to 65 years) and six reviews focused on perinatal patients.^203,^ ^206,^ ^208,^ ^211,^ ^213,^ ^220^ Other reviews focused on rural settings,^215^ participants who were socially disadvantaged,^212^ participants who were culturally and linguistically different from those for whom the intervention was originally designed,^201^ or had samples that were primarily comprised of Hispanic/Latino,^193^ Hispanic/Latino immigrant,^210^ or Black or Hispanic/Latino^211^ participants. Four ESRs focused on studies conducted among people recruited from primary care settings, in general^207,^ ^218,^ ^219^ and older adults.^202^

Most reviews included psychological interventions without restriction to specific therapeutic approaches, however we also retained reviews that were limited to CBT-based interventions,^203,^ ^210,^ ^213–215,^ ^218,^ ^220^ since this was the most widely studied therapeutic approach. Five reviews focused on electronically delivered interventions (e.g., via websites or apps),^200,^ ^204,^ ^205,^ ^207,^ ^217^ and two examined telemedicine in general^192^ and perinatal populations.^208^ We rated all included reviews as good quality. All were published in 2015 or later, searched multiple databases with what appeared to be comprehensive search strategies; had explicit and relevant selection criteria; indicated some type of standard quality appraisal of included studies, and, if applicable, used valid meta-analytic methods.

##### Results

Detailed results for all outcomes are reported in Appendix E Tables.

###### Depression Symptom Severity

Most reviews explored either continuous measures of depression symptom severity, or used the studies’ main outcome, which was typically a continuous measure of depression symptom severity but could also include some dichotomous outcomes that were converted to standardized effect sizes. Standardized effect sizes are shown in Figures 9 and 13, and Appendix E Tables 16 and 17. The broadest analysis, including any type of psychological treatment compared to any kind of control condition, with the main depression outcome measured immediately post-treatment, had a standardized mean difference (SMD) of −0.72 (95% CI, −0.78 to −0.67; k=385, N not reported, but estimated at approximately 34,000, Figure 9),^195^ suggesting a moderate to large effect size. An analysis in the same review that was limited to CBT treatment reported a very similar effect size (SMD, −0.73 [95% CI, −0.80 to −0.65]; k=205, N not reported).^195^ Interpersonal therapy (IPT), problem-solving therapy (PST), behavioral activation therapy (BAT), Life review, and “Third wave” cognitive therapies such as mindfulness-based approaches and Acceptance and Commitment therapy (ACT) all had SMDs of −0.60 or larger at post-treatment, with 19 to 30 studies in the analysis, as reported in the same ESR.^195^

Figure 13 Forest Plot of Standardized Mean Differences Between Groups in Depression Symptoms Severity by Study, Intervention, and Population Characteristics Where Effect Modification Was Assessed for Psychological Treatment of Depression (KQ4)

Abbreviations: CI = confidence interval; MDD = major depressive disorder; MH = mental health; PC = primary care; SMD = standardized mean difference; UC = usual care; WL = wait list.

This figure shows a forest plot of standardized mean differences between groups in depression symptoms severity by study, intervention, and population characteristics where effect modification was assessed for psychological treatment of depression (key question 4).

Effects in patient populations specified a priori in our Research Plan also demonstrated greater symptom reduction with psychological interventions compared to control groups. Among perinatal patients (pregnant or postpartum), CBT was associated with an effect similar to the overall effect size at post-treatment followup(SMD of −0.69 (95% CI, −0.83 to −0.55; k=54, N=5,393, Figure 9).^220^ An examination of the effect of internet-based CBT in postpartum patients showed a similar effect size (SMD, −0.55 [95% CI, −0.76 to −0.34]; k=6, N=635, Figure 9).^213^ A review focused on older adults treated with CBT reported an SMD of −0.63 at post-treatment (95% CI, −0.76 to −0.49; k=52, N=2,925, Figure 13).^214^ Psychological interventions also reduced depressive symptoms in studies of socioeconomically disadvantaged persons in the short term (SMD, −0.66 [95% CI, −0.92 to −0.41]; k=5, N=not reported), however this effect was not statistically significant at long-term followup (SMD, −0.53 [95% CI, −1.12 to 0.05]; k=4, N=not reported).^212^ Effect sizes in studies among patients recruited from primary care tended to be smaller than effect sizes reported for broad analyses, not limited to studies among primary care patients. However, effect sizes among studies of primary care patients demonstrated a statistically significant benefit in most cases. For example, the SMD for any psychological treatment among primary care patients compared to any control condition was −0.42 (95% CI, −0.56 to −0.29; k=59, N not reported).^219^ The effect was smaller for older adult primary care patients being treated with CBT at 26-week followup (SMD, −0.21 [95% CI, −0.40 to −0.03]; k=4, N=445)^202^ but was not statistically significant when pooling the post-treatment timepoints (SMD, −0.16 [95% CI, −0.34 to 0.02]; k=4, N=274).^202^ Narrative syntheses also reported generally positive effects of various psychological treatment approaches for people in rural settings and Hispanic/Latino patients, but fewer statistically significant group differences in four studies each of CBT and interpersonal therapy among Black and Hispanic/Latino perinatal patients (Appendix E Table 18).^211^

###### Depression Remission and Response

Fewer reviews reported pooled effects for depression remission^203,^ ^204^ and response to treatment^194,^ ^204,^ ^205^ (Table 17, Appendix E Table 19). Analyses of remission demonstrated a two-fold or more increase in the odds of remission, among studies focused on either guided internet-based interventions or on CBT among postpartum patients. Similarly, all three analyses examining response to treatment indicated a benefit, including at followup of more than six months (OR, 1.92 [95% CI, 1.60 to 2.31]; k=55, N not reported, I^2^=65) and more than one year (OR, 1.59 [95% CI, 1.14 to 2.21; k=11, N not reported, I^2^=55).^194^

Table 17 Meta-Analysis Results for Depression Remission and Depression Response in ESRs of Psychological Treatment of Depression (KQ4)

Author, Year | Intervention | Outcome | Population | Control | FUP, wks | k | N analyzed | Effect | ES (95% CI) | I^2^ (%)
Huang, 2018 ^203^ | CBT | Depression remission | Postpartum mothers | Any | Shortterm | 4 | 590 | OR | 6.57 (1.84 to 23.48) | 60
Huang, 2018^203^ | CBT | Depression remission | Postpartum mothers | Any | Longterm | 9 | 1,558 | OR | 2.00 (1.61 to 2.48) | 0
Karyotaki, 2018^236^ | Guided internet-based | Depression remission | All participants | Any | 5–13 | 26 | 4,867 | OR | 2.41 (2.07 to 2.79) | NR
Karyotaki, 2017^205^ | Self-guided iCBT | Depression response | All participants | Any | NR | 13 | 3,795 | Standardized regression coefficient (IPD MA) | 0.53 (NR, p<.05) | NA
Cuijpers, 2017^194^ | Psychological (any) | Depression response | All participants | Any | 52 | 11 | NR | OR | 1.59 (1.14 to 2.21) | 55
Karyotaki, 2018^236^ | Guided internet-based | Depression response | All participants | Any | 5–13 | 26 | 4,867 | OR | 2.49 (2.17 to 2.85) | NR

Abbreviations: CBT = cognitive behavioral therapy; CI = confidence interval; ES = evidence synthesis; ESRs = existing systematic reviews; FUP = followup; iCBT = internet-based cognitive behavior therapy; IPD MA = individual participant data meta-analysis; NA = not applicable; NR = not reported; OR = odds ratio.

###### Other Outcomes

Reviews reported that depression treatment improved a number of other outcomes, including anxiety symptoms, hopelessness, quality of life, social functioning, days of sickness absence, parental functioning, and mental health in offspring (Appendix E Table 20), although some of these outcomes were sparsely reported and some effects were small. Findings for work functioning, anxiety symptom severity among postpartum patients, and suicidality did not demonstrate a statistically significant benefit, but were reported in only one,^209^ two,^203^ and four^194^ trials, respectively (Appendix E Table 20).

###### Effect Modification and Findings in Specific Populations

We included effect modification analyses covering a wide range of study, intervention, and patient characteristics (Figure 13, Appendix E Tables 17 and 18). We extracted detailed results for effect modification of depression symptom severity, the most commonly reported outcome. Narrative summaries were extracted for other depression-related outcomes. Statistically significant effect modification was found for variation in study characteristics by age, the presence of medical comorbidities, perinatal status, format, sessions per week, and some control group types. Among traditional, study-level meta-analyses, effects were smaller in studies limited to:

- General and older adults, compared to students^197^
- People with medical comorbidities^197^
- Perinatal patients^197^
- Interventions delivered in “Other/mixed” format compared to individual, group, or guided self-help formats^197^
- One or fewer sessions per week^194^
- Active control group (e.g., education group) compared with usual care or wait-list controls^214^
- Pill placebo control groups^197^
- US-based specialty mental health usual care control group, compared with specialty mental health usual care in The Netherlands^198^
- UK or Netherlands-based usual primary care, compared with US-based usual primary care^198^

In most cases, however, psychological interventions still had a statistically significant benefit even when the effect was smaller than others in the stratified analyses. Reviews with study-level meta-analyses found no effect modification related to gender composition (women only vs. women and men), race/ethnicity composition (limited to a race or ethnic “minority” group vs. not limited by race or ethnicity), recruitment setting (primary care, other medical, community, or other), usual care setting when combining studies from all countries, type of control group aside from pill placebo and active controls (e.g., wait list, usual care, no treatment), depression inclusion criteria, intervention format (individual, group, or guided self-help), and number of sessions. The individual patient data meta-analyses of internet-based interventions examined a wide range of individual-level characteristics.^204,^ ^205^ These reviews found only three characteristics that were associated with effect size: higher baseline symptom severity, older age, and being native-born to country where the study took place were all associated with larger effects for guided (but not unguided) internet-based interventions.

There was indication of publication bias in this literature. One review contacted investigators of studies in an NIH grants database that had no published results and requested the unpublished results. They then compared the pooled effect with and without the results from the unpublished studies.^199^ The standardized mean difference (SMD) was reduced from −0.52 (95% CI, −0.68 to −0.37, k=20, N not reported) among published studies to −0.39 (95% CI, −0.70 to −0.08, k=26, N not reported) when the unpublished studies were included in the analysis. Additionally, a separate ESR used the Duval and Tweedie trim and fill procedure to estimate an effect adjusted for publication bias.^197^ This procedure fills in “missing” studies that are hypothesized to exist but be unpublished based on the funnel plot of the data. According to this analysis, the SMD adjusted for publication bias was estimated to be −0.50 (95% CI, −0.56 to −0.44), compared with the main analysis effect of −0.71 (95% CI, −0.77 to −0.66, k=332). Thus, psychological interventions appear to reduce depression symptom severity, even taking into account the probable presence of publication bias.

#### Pharmacologic Treatment of Depression

##### Study Characteristics

We included ten ESRs of pharmacologic treatment (Table 16, Appendix E Table 21), covering all antidepressants commonly used in the US.^212,^ ^221,^ ^222,^ ^224,^ ^226–229,^ ^231,^ ^232^ Our primary data source for general adult populations was an exhaustive systematic review with a network meta-analysis of antidepressants conducted by Cipriani and colleagues.^224^ This review included 522 trials, covering 814 different active treatment groups (N=116,477). We focused on placebo comparisons, although this review did not report the number of studies included in each specific placebo comparison. Therefore, we reported the total number of studies included in the review for each agent in our forest plots and tables. One review each covered older,^227^ perinatal,^232^ primary care,^221^ and socially or economically disadvantaged populations.^212^ Other reviews reported outcomes not addressed by the Cipriani review, including quality of life and social functioning in older adults,^227^ occupational functioning,^228^ and cognitive functioning as measured by the Digit Symbol Substitution Test.^222^ One review conducted individual patient-level analysis of the items of the Hamilton Depression Rating Scale to determine whether duloxetine has greater or lesser impact on specific symptoms.^229^ Finally, one review reported on the effect of combined pharmacologic and psychological treatment compared to placebo.^226^

We rated seven of the included reviews as good quality.^212,^ ^221,^ ^222,^ ^224,^ ^226,^ ^227,^ ^232^ The good quality reviews all were published in 2015 or later, searched multiple databases with what appeared to be comprehensive search strategies; had explicit and relevant selection criteria; indicated some type of standard appraisal of included studies, and, if applicable, used valid meta-analytic methods. The ESRs rated as fair were downgraded because they did not describe conducting risk of bias assessment for the studies included in their reviews.^228,^ ^229,^ ^231^ We included these studies, however, because they either had some risk of bias safeguard (e.g., requiring double-blind design),^228^ or conducted individual patient data meta-analysis which we judged to be less affected by typical risk of bias threats in component studies.^229,^ ^231^

Most of the reviews made efforts to search for unpublished data, typically by searching conference abstracts or requesting information from the regulatory agencies or pharmaceutical companies. For example, the Cipriani review reported manual searching of trial registries and websites of drug approval agencies for unpublished studies. In addition, they contacted all of the pharmaceutical companies marketing antidepressants to ask for supplemental unpublished information about both premarketing and post-marketing studies. Finally, they also contacted study authors and drug manufacturers to supplement incomplete reports of the original papers or provide data for unpublished studies.^224^

##### Results

Detailed results for all outcomes are reported in Appendix E Tables.

###### Depression Outcomes

The stated primary outcome of the Cipriani review was response to treatment, typically reported as a 50 percent reduction in symptom severity measures such as the HAM-D or the MADRAS. Other depression outcomes examined were standardized mean differences of continuous symptoms severity measures and remission. In broad analyses unrestricted by population, all antidepressant agents demonstrated statistically significantly greater improvements than placebo for all three depression outcomes (Figures 10–12; Appendix E Tables 22–24). At 8 week followup (or the closest available), SMDs ranged from −0.17 (95% CI, −0.26 to −0.08, 17 studies included in the ESR) to −0.50 (95% CI, −0.85 to −0.15; 1 RCT, n=63), consistent with small effects for symptom severity.^224^ The number of included trials ranged from one to an estimated 117, including non-placebo comparisons. The odds of remission were increased by a range of 23 percent to 252 percent and the increased odds of treatment response ranged from 37 percent to 213 percent.

The agent with the largest body of evidence was fluoxetine, with 117 trials (N not reported).^224^ Fluoxetine was associated with an SMD of −0.23 (95% CI, −0.28 to −0.19) for depression symptoms severity, a 46 percent increase in the odds of remission (OR, 1.46 [95% CI, 1.34 to 1.60]) and a 52 percent increase in the odds of treatment response (OR, 1.52 [95% CI, 1.40 to 1.66], number of studies and individuals included in each specific analysis was not reported, nor were I^2^ values).^224^ A review addressing combination treatment (pharmacologic and psychological) also found that depression symptoms were reduced with combination treatment (SMD, −0.46 [95% CI, −0.70 to −0.21], 6 RCTs, N not reported; I^2^, 17%).^226^

Among analyses limited to specific populations, findings were more variable and confidence intervals were generally wide, reflecting the small number of studies for most analyses. In a review of RCTs among primary care patients, SSRIs demonstrated a benefit for both symptom severity (SMD, −0.27 [95% CI, −0.38 to −0.16], number of studies, N, and I^2^ not reported) and remission (RR, 1.33 [95% CI, 1.20 to 1.48], 7 RCTs, N=1652; I^2^ not reported).^221^ In a review of trials in older adults, duloxetine both had the most evidence (4 RCTs, N=1,347) and the most consistent finding of benefit across depression outcomes, while fluoxetine was the least promising.^227^ In analyses among populations determined to have low socioeconomic status, one to three RCTs found greater improvements with paroxetine and with combination treatment compared to placebo.^212^

We found little information in the recent synthesized literature about longer-term effects. The review that was focused on interventions for depression among low socioeconomic status populations reported on long-term outcomes, which they defined as outcomes measured three or more months after the intervention was completed.^212^ This review found one such study reporting that paroxetine was associated with lower symptom severity than placebo at 6 months’ followup, 4 months after treatment had been completed (SMD, −0.39 [95% CI, −0.74 to −0.04]). This review also reported results of a meta-analysis of three studies of combination treatment. The long-term pooled effect was not statistically significant (SMD, −0.47 [95% CI, −0.97 to 0.03], I^2^=85%, N=482), although the short-term finding was statistically significant for this group of three studies (SMD, −0.68 [95% CI, −0.97 to −0.40], I^2^=56%, N=491). The review focused on older adults included one placebo-controlled trial of duloxetine that reported results longer than 12 weeks’ followup.^227^ This study reported greater symptoms reduction at long-term followup (SMD, −0.39 [95% CI, −0.64 to −0.14]) but the remission benefit was no longer statistically significant (RR, 1.57 [95% CI, 0.95 to 2.59]).^227^

###### Other Outcomes

Aside from suicide-related outcomes, which are discussed under KQ5 (harms of treatment), we found very limited information on other outcomes reported in the synthesized literature of antidepressants. One review found no improvement in cognitive function as measured by the Digit Symbol Substitution Test for citalopram, duloxetine, escitalopram, nortriptyline, or sertraline, but found a small benefit for vortioxetine relative to placebo (SMD, 0.34 [95% CI, 0.18 to 0.49], 3 RCTs, I^2^ and N not reported, Appendix E Table 25).^222^ No benefits were seen for quality of life in the review focused on older adults, but one RCT of bupropion reported improved social functioning (SMD, −0.26 [95% CI, −0.06 to −0.45]).^227^

###### Effect Modification and Findings in Specific Populations

Detailed results are reported in Appendix Tables 26 and 27. The main review by Cipriani and colleagues examined some important potential effect modifiers.^224^ They found larger effects in studies with earlier publication dates for several antidepressants, and also larger effects in smaller studies. They also found an association between baseline symptom severity and effect size, however this analysis was at high risk of ecological bias and is better addressed using individual patient data. Finally, they also found no association between effect size and industry sponsorship or with publication status (published vs. unpublished), however they reported having limited ability to detect the impact of these characteristics. An individual patient data meta-analysis examined effect modification for duloxetine.^229^ This review found a greater reduction in suicidality with duloxetine among adults age 25 and older compared to those age 18–24, relative to placebo; duloxetine demonstrated a statistically significant benefit only in adults age 25 and older. Additionally, this review found no association between degree of improvement in depression symptoms and either baseline symptom severity or severity of side effects. A separate individual patient data meta-analysis found no association between baseline symptoms severity and effect size.^231^

### KQ5. What Are the Harms of Treatment of Depression (Psychotherapy or Pharmacotherapy) in Adults, Including Pregnant and Postpartum Persons?

#### Summary

We included four ESRs addressing harms of psychological interventions (Table 18).^233–236^ We included one cohort study^237^ and 22 ESRs (in 29 publications) addressing harms of pharmacologic treatment for depression (Tables 19 and 20).^224,^ ^227,^ ^232,^ ^238–255^ Psychological interventions did not increase the risk of harm, as measured by deterioration of depressive symptoms.

Table 18 Characteristics of ESRs Addressing Harms of Psychological Treatment of Depression (KQ5)

Author, Year | Cuijpers database | Quality | Outcomes | Population | Intervention | Last search date | Total # of included studies | Total N | Included study designs (Note if conducted IPD analysis)
Cuijpers, 2018^197^ | Yes | Good | Harms | General population | Psychological | Jan-2017 | 18 (23 comparison) | 1,655 | RCTs
Ebert, 2016^234^ | Yes | Good | Harms | General population | E-interventions (guided) | Jan-2014 | 18 | 2,079 | RCTs (IPD)
Jonsson, 2016^235^ | No | Good | Harms | Older adults | Psychological | May-2016 | 14 | 927 | RCTs
Karyotaki, 2018^236^ | Yes | Good | Harms | General population | E-interventions (self-help) | Jan-2016 | 13 | 3,805 | RCTs (IPD)

Abbreviations: E-Interventions = electronic interventions; ESRs = existing systematic reviews; IPD = individual participant data; N = number of participants; RCTs = randomized controlled trials; RCTs (IPD) = randomized controlled trial individual participant data.

Table 19 Characteristics of ESRs in General Adult Populations Addressing Harms of Pharmacologic Treatment of Depression (KQ5)

Author, Year | Quality | Outcomes | Population | Intervention | Last search date | Total # of included studies | Total N | Included study designs (Note if conducted IPD analysis)
Braun, 2016^238^ | Fair | Suicide-related | General population | AD | Sep-2014; Mar-2015 | 29 | 6,934 | RCTs
Chan, 2019^239^ | Good | Harms | General population | AD | Nov-2018 | 18 | 2,119,627 | Obsrv
Cipriani, 2018^224^ | Good | Depression, Harms | General population | AD | Jan-2016 | 522 (814 tx groups) | 116,477 | RCTs
Gibbons, 2012^240^ | Fair | Suicide-related | General population, Older adults | Fluoxetine, venlafaxine | NR | 41 | 9,185 (2 deaths, 20 attempts) | RCTs (IPD)
Hengartner, 2021^241^ | Good | Suicide-related | General population | SSRIs, SNA | Jan-2020 | 27 | 1,447,480 | Obsrv
Jacobsen, 2019^242^ | Good | Harms | General population | AD | Mar-2016 | 17 | 9,475 | RCTs
Jakobsen, 2017^243^ | Good | Harms, Suicide-related | General population | SSRIs | Jan-2016 | 195 (131 in MA) | 27,422 | RCTs
Jensen, 2019^244^ | Good | Harms | General population | SSRIs | Dec-2017 | 30 (3 RCTs, 27 obs) | >845,655 | RCTs, Obsrv
Kaminski, 2020 ^245^ | Fair | Suicide-related | General population | 2nd gen AD | 2016 | 14 investigational AD programs | 40,857 | RCTs
Khanassov, 2018^246^ | Good | Harms | General population | SSRIs and SNRIs | Nov-2016 | 33 | >1.3 million | Obsrv
Kunutsor, 2018^248^ | Good | Harms | General population | AD | Apr-2018 | 8 | 960,113 (9,027 VTEs) | Obsrv
Maslej, 2017^249^ | Good | Harms | General population | AD | Jun-2014 | 16 (1 RCTs, 15 obs) | 378,400 | RCTs, Obsrv
Na, 2018^250^ | Good | Harms | General population | Bupropion, Mirtazapine | May-2017 | 7 | 128,480 | Obsrv
Naslund, 2018^251^ | Fair | Suicide-related | General population | SSRIs | NR | 28 | 8,262 | RCTs (IPD)
Trajkova, 2019^253^ | Good | Harms | General population | AD | Sep-2018 | 31 | 3,103,686 | Obsrv

Abbreviations: AD = antidepressant; CCTs = controlled clinical trials; ESRs = existing systematic reviews; IPD = individual participant data; MA = meta-analysis; N = number of participants; NR = not reported; Obsrv or obs = observation; pharm = pharmacotherapy; QoL = quality of life; QuasiRCT = quasi-randomized controlled trial; RCTs = randomized controlled trials; RCTs (IPD) = randomized controlled trial individual participant data; SNA = spherical nucleic acid; SNRIs = serotonin and norepinephrine reuptake inhibitor; SSRIs = selective serotonin reuptake inhibitors; tx = treatment; VTEs = venous thromboembolism.

Table 20 Characteristics of ESRs Limited to Perinatal or Older Adult Populations Addressing Harms of Pharmacologic Treatment of Depression (KQ5)

Author, Year | Quality | Outcomes | Population | Intervention | Last search date | Total # of included studies | Total N | Included study designs (Note if conducted IPD analysis)
Gumusoglu, 2022^255^ | Fair | Harms, maternal HTN or preeclampsia | Perinatal | SSRIs | Jun-2020 | 9 | 1,287,539 | Obsrv
KoKoAung, 2015^247^ | Good | Harms, Suicide-related | Older adults | SSRIs | Nov-2012 | 13 (8 RCTs, 5 Obs) | NR | RCTs, Obsrv, QuasiRCT
Krause, 2019^227^ | Good | Depression, QoL or functioning, Harms | Older adults | Any pharm | Dec-2017 | 53 | 9,274 | RCTs
Sobieraj, 2019^252^ | Good | Harms | Older adults | SSRIs, SNRIs, bupropion, mirtazapine, trazodone, vilazodone, vortioxetine | May-2018 | 21 (19 RCTs, 2 obs) | NR | RCTs, Obsrv, QuasiRCT
Viswanathan, 2021^232^ | Good | Depression, QoL or functioning, Maternal or fetal, Harms | Perinatal | Any pharm | Jun-2020 | 164 (10 RCTs, 121 obs in analysis, remaining unadjusted) | NR | RCTs, Obsrv, CCTs
Vlenterie, 2021^257^ | Fair | Maternal or fetal,Harms | Perinatal | AD | Jun-2016 | 27 databases | 402,375 | No restrictions
Wang, 2018^254^ | Good | Harms | Older adults | AD | December2017 | 5 (all obs) | 53,955 | RCTs, Obsrv

Abbreviations: AD = antidepressant; CCTs = controlled clinical trials; ESRs = existing systematic reviews; IPD = individual participant data; N = number of participants; NR = not reported; Obsrv or obs = observation; pharm = pharmacotherapy; QoL = quality of life; QuasiRCT = quasi-randomized controlled trial; RCTs = randomized controlled trials; SNRIs = serotonin and norepinephrine reuptake inhibitors; SSRIs = selective serotonin reuptake inhibitors.

For pharmacologic treatment, there was clear evidence that those receiving antidepressants were at a higher risk of dropout because of adverse events (Figure 14),^224^ which likely reflect the increased risk of non-serious adverse events.^243^ There was also some evidence of an increased risk of serious adverse events with SSRI use (OR, 1.39 [95% CI 1.12 to 1.72], 44 RCTs, N not reported, I^2^=0%, Figure 15).^243^ The absolute risk of serious adverse events appears to be relatively low, however, and evidence for specific serious adverse events other than suicide was very limited. There were too few suicide deaths to determine the association between antidepressant use and suicide death, but both RCT and observational evidence supported a small absolute increase in risk of suicide attempts with second generation antidepressant use among adults up to age 65 (Figure 16). For example, a review of FDA regulatory data indicated a 53 percent increase in the odds of a suicide attempt at post-treatment with the use of second-generation antidepressants (OR, 1.53 [1.09 to 2.15]; N= 41,861; 0.7% of antidepressants users had a suicide attempt vs 0.3% of placebo users.^256^ Evidence on other outcomes was limited and generally included only observational evidence.

Figure 14 Forest Plot of Group Differences in Dropout Due to Adverse Events With Pharmacological Treatment of Depression Compared to Placebo (KQ5)

Abbreviations: CI = confidence interval; NR = not reported; RR = relative risk; SMD = standardized mean difference; SSRI = selective serotonin reuptake inhibitor.

This figure shows a forest plot of group differences in dropout due to adverse events with pharmacological treatment of depression compared to placebo (key question 5)

Figure 15 Forest Plot of Group Differences in Any Serious Adverse Events With Pharmacological Treatment of Depression Compared to Placebo (KQ5)

Abbreviations: AE = adverse event; ES = effect size; CI = confidence interval; NR = not reported; OR = odds ratio; RR = relative risk; SMD = standardized mean difference; SSRI = selective serotonin reuptake inhibitor.

This figure shows a forest plot of group differences in any serious adverse events with pharmacological treatment of depression compared to placebo (key question 5).

Figure 16 Forest Plot of Group Differences in Suicide-Related Outcomes With Pharmacological Treatment of Depression Compared to Placebo (KQ5)

*The following effects are ORs rather than RRs: suicide deaths with 2nd generation antidepressants; suicide attempts with 2^nd^ generation antidepressants; suicide attempts with SSRIs for older adults; suicidal ideation with SSRIs for older adults.

Abbreviations: AD = antidepressant; COI = conflict of interest; MDD = major depressive disorder; NR = not reported; SNA = serotonergic-noradrenergic antidepressant; SSRI = selective serotonin reuptake inhibitor; RR = relative risk.

This figure shows a forest plot of group differences in suicide-related outcomes with pharmacological treatment of depression compared to placebo (key question 5).

#### Psychological Treatment of Depression

##### Study Characteristics and Results

Four ESRs reported on adverse outcomes of psychological treatment of depression, including an estimated 63 RCTs (Tables 18 and 21, Appendix E Table 28).^233–236^ Three of the ESRs included studies that had reported deterioration rates with any psychological treatment,^233^ self-guided internet-based CBT,^236^ and guided internet-based interventions.^234^ Deterioration rates were either lower with psychological interventions or did not differ statistically from control groups. In the broadest analysis, which included RCTs of any type of psychological treatment that reported deterioration rates, participants in psychological interventions had a 61 percent lower likelihood of deterioration (RR, 0.39 [95% CI, 0.27 to 0.57]; 23 RCTs, N not reported; I^2^, 0%). A separate review of psychological interventions among older adults reported that none of the 14 included trials reported safety data.^235^

Table 21 Adverse Events Reported in ESRs of Psychological Treatment of Depression (KQ5)

Author, Year | Intervention | Outcome | Population | Control | Followup | k | N analyzed | Effect | ES (95% CI) | I^2^ (%) | Narrative summary
Jonsson, 2016^235^ | Psychological (any) | Any adverse events | Older adults | Any | NR | 14 | NR | NR | NR | NR | Safety data were not reported in any included trials
Cuijpers, 2018^197^ | Psychological (any) | Deterioration rates | All participants | Any | Post-tx | 23 | NR | RR | 0.39 (0.27 to 0.57) | 0 | NR
Karyotaki, 2018^236^ | Self-guided, iCBT | Deterioration rates | All participants | Any | 6–16 | 13 | 3,795 | OR | 0.62 (0.46 to 0.83) | NR | NR
Ebert, 2016^234^ | Guided, internet-based intv | Deterioration rates | All participants | Any | 26+ | 4 | NR | RR | 1.17 (0.49 to 2.87) | 0 | NR
Ebert, 2016^234^ | Guided, internet-based intv | Deterioration rates | All participants | Any | 4–17 | 5 | NR | RR | 0.47 (0.20 to 1.42) | 0 | NR
Ebert, 2016^234^ | Guided, internet-based intv | Deterioration rates | All participants | Any | Post-tx | 21 | NR | RR | 0.47 (0.29 to 0.75) | 0 | NR

Abbreviations: CI = confidence interval; ES = evidence synthesis; ESRs = existing systematic reviews; iCBT = internet-based cognitive behavior therapy; intv = intervention; k = number of trials; N = number of participants; NR = not reported; OR = odds ratio; Post-tx = posttreatment; RR = relative risk.

#### Pharmacologic Treatment of Depression

##### Study Characteristics

We included 22 ESRs that addressed harms of antidepressant use (Tables 19 and 20, Appendix E Table 29).^224,^ ^227,^ ^232,^ ^238–255^ We estimated that these reviews collectively included approximately 522 RCTs and 175 observational studies. Three of these reviews covered perinatal patients,^232,^ ^257^ four focused on older adults,^227,^ ^247,^ ^252,^ ^254^ and the remaining included studies of adults of any age. Sixteen of the reviews were rated as good quality and six were rated fair, down-graded for lack of risk of bias assessment^238,^ ^240,^ ^245,^ ^251,^ ^257^ or for only searching one database.^255^ Eight of the reviews addressed the question of whether antidepressant use increased risk of suicide, primarily focused on SSRIs and other second generation agents. ^237,^ ^238,^ ^241,^ ^243,^ ^247,^ ^251,^ ^256^ We also included a large cohort study examining suicide risk that was published after the ESR we included that examined observation evidence for suicide-related outcomes (Table 22).^237^

Table 22 Results From Observational Studies of Suicide Attempt Risk With Pharmacologic Treatment for Depression Published After Included ESRs (KQ5)

Author, Year | Study design (Quality) | Country | Study N | Population | Outcome definition | Comparison | Medication | HR (95% CI)^*^
Valuck, 2016^237^ | Retro-spective cohort (Fair) | USA | 358,351 | General adults with incident depressive episode | Suicide attempt leading to medical encounter | No AD dispensing | SSRI | 0.85 (0.17 to 4.19)
Valuck, 2016^237^ | Retro-spective cohort (Fair) | USA | 358,351 | General adults with incident depressive episode | Suicide attempt leading to medical encounter | No AD dispensing | SNRI | 0.65 (0.14 to 3.02)
Valuck, 2016^237^ | Retro-spective cohort (Fair) | USA | 358,351 | General adults with incident depressive episode | Suicide attempt leading to medical encounter | No AD dispensing | TCA | 0.48 (0.04 to 5.65)
Valuck, 2016^237^ | Retro-spective cohort (Fair) | USA | 358,351 | General adults with incident depressive episode | Suicide attempt leading to medical encounter | No AD dispensing | Multiple AD | 2.24 (0.50 to 10.02)

* Demographic covariates included gender; region (East, Midwest, South and West); Medicaid status at time of index depression diagnosis and age at index depression diagnosis; specific and total numbers of mental health comorbidities; specific chronic and acute non-mental health comorbidities; indices of chronic comorbidity including the Chronic Disease Indicator (CDI) score and the Charlson comorbidity score; prior medication use (drug-months of exposure to both psychotropic medications and all prescription medications); use of health services; history of suicide attempt; severity of the index depression diagnosis; physician-level covariates; and a market-level covariate reflecting rates of prescribing of each drug group by generalist vs. specialist prescribers during the month that antidepressant therapy was initiated.

Abbreviations: AD = antidepressant; CI = confidence interval; ESRs = existing systematic reviews; HR = hazard ratio; N = number of participants; SNRI = serotonin and norepinephrine reuptake inhibitor; SSRI = selective serotonin reuptake inhibitors; TCA = tricyclic antidepressants; USA = United States of America.

##### Results

Detailed results are shown in Appendix E Tables.

###### Any Adverse Events, Dropout, and Serious Adverse Events

Seventeen ESRs considered non-suicidal harms of pharmacologic treatment.^224,^ ^227,^ ^232,^ ^238,^ ^239,^ ^242–250,^ ^252–254^ A broad review examining RCTs of SSRI use compared to placebo did not report an overall estimate of the risk of any adverse event, but they examined a large number of specific non-serious events.^243^ The most commonly reported events with higher rates among SSRI users were abnormal ejaculation, tremor, anorexia, nausea, somnolence, sweating, asthenia, diarrhea, constipation, insomnia, dizziness, dry mouth, libido decreased, sexual dysfunction, appetite decreased, fatigue, vomiting or upset stomach, flu syndrome, drowsiness, blurred/abnormal vision or dry eyes, nervousness, back pain, headache, dyspepsia, weight loss. These analyses included up to 78 studies per outcome (Appendix E Table 30 for narrative summary). Neither RCT nor observational cohort evidence indicated any clear difference between the presence of the composite outcome of any adverse events for antidepressant treatment compared to placebo in older adults (Figure 17, Appendix E Table 31).

Figure 17 Forest Plot of Group Differences in Any Adverse Events With Pharmacological Treatment of Depression Compared to Placebo (KQ5)

Abbreviations: CI = confidence interval; NR = not reported; RR = relative risk; SNRI = Serotonin and norepinephrine reuptake inhibitors; SSRI = selective serotonin reuptake inhibitor.

This figure shows a forest plot of group differences in any adverse events with pharmacological treatment of depression compared to placebo (key question 5).

RCT evidence indicated no pattern of increased dropout for any reason with antidepressants, compared to placebo (Figure 18, Appendix E Table 32).^224^ However, RCT evidence showed that whether assessed as a class (SSRI, or SNRI) or as a specific antidepressant, receiving antidepressant treatment increased the risk of dropout due to adverse events (Figure 14, Appendix E Table 33). Nearly every agent tested had a statistically significant increase in dropout due to adverse events among general adult populations, with ORs ranging from 1.64 (95% CI, 1.25 to 2.14, 15 RCTs, N and I^2^ not reported) for Vortioxetine to 4.44 (95% CI, 3.07 to 6.50, 20 RCTs, N and I^2^ not reported) for Clomipramine.^224^ For older adults, SSRIs as a class increased the risk of dropping out because of adverse events nearly 3-fold (RR, 2.90 [95% CI, 1.16 to 5.06]; 3 RCTs, N=887, I^2^ not reported), and SNRIs similarly increased the risk nearly two-fold (RR, 1.85 [95% CI, 1.05 to 3.27]; 3 RCTs, N=812, I^2^ not reported).^252^

Figure 18 Forest Plot of Group Differences in Dropout for Any Reason With Pharmacological Treatment of Depression Compared to Placebo (KQ5)

Abbreviations: CI = confidence interval; NR = not reported; RR = relative risk.

This figure shows a forest plot of group differences in dropout for any reason with pharmacological treatment of depression compared to placebo (key question 5).

The association of antidepressant use with any serious adverse events was less clear (Figure 15, Appendix E Table 34). The broadest review, covering RCTs in adults reporting serious adverse events of SSRI use compared to placebo, suggested a nearly 40 percent increase in odds with antidepressant use (OR, 1.39 [95% CI 1.12 to 1.72]; k=44, N=NR, I^2^ not reported).^243^ Serious adverse events were relatively rare; 239/8242 SSRI participants (2.7%) had serious adverse events, compared to 106/4956 (2.1%) of placebo participants. The authors of this review rated the strength of this evidence as very low due to high risk of bias of the included studies, which they note is likely to overestimate benefits and underestimate harms. In a separate review addressing serious adverse events in older adults, only one to two studies reported serious adverse events for any specific agent (N = 122 to 607) and findings were imprecise, with wide ranging confidence intervals crossing the null. A third review examined the impact of pharmacologic interventions in perinatal patients.^232^ Five RCTs and 70 observational studies were included, reporting on 27 potential serious adverse events, including maternal, birth, and infant/child harms. The authors judged the certainty of evidence to be insufficient or low in all instances, including for congenital and cardiac anomalies (graded insufficient), primarily because of lack of control for confounding. Their findings indicated small absolute risk differences for all adverse events.

###### Suicide Death

Evidence for the impact of antidepressant use on suicide death was limited by the small number of events (Figure 16, Appendix E Table 35). The review with the most evidence involved an analysis of FDA regulatory data of 14 antidepressants, and 41 suicide deaths altogether.^256^ In this review, there was a statistically non-significant 74% increase in risk of suicide with antidepressants (RR, 1.74 [95% CI, 0.78 to 3.90]; 0.12% [37/31781] died from suicide among those taking antidepressants, 0.04% [4/10080] with placebo). Other reviews included only seven suicide deaths (three with SSRI use, four with placebo)^243^ and eight suicide deaths (seven of eight deaths were among those taking second generation antidepressants, one with placebo).^238^ A review of cohort studies focused on older adults found only two studies examining suicide deaths.^247^ One of the two cohort studies in this review was limited to people with depression, and showed a statistically non-significant effect in the direction of benefit (RR, 0.64 [95% CI, 0.38 to 1.07], n=3,325,567 prescriptions). The other cohort study in this review, among people taking SSRIs for any indication, found an increased risk of suicide death (RR, 4.87 [95% CI, 1.99 to 11.94], n=241,754 patients).

###### Suicide Attempts

Evidence suggested a very small increased risk of suicide attempts with antidepressant use (Figure 16, Appendix E Table 35).^238,^ ^243,^ ^256^ For example, a review of FDA regulatory data found a 53 percent increase in the odds of a suicide attempt at post-treatment with the use of second generation antidepressants (OR, 1.53 [95% CI, 1.09 to 2.15], 206/31,781 [0.7%] of antidepressant users had a suicide attempt vs 28/10,080 [0.3%] of placebo users).^256^ However, given how rarely suicide attempts occur in clinical trials, this is still based on a very small number of events. Observational evidence supported the RCT-based findings. A review of cohort and case-control studies examining the impact of second generation antidepressants found a statistically significant increase in the risk of the composite outcome of any suicide death or suicide attempt (RR, 1.29 [95% CI, 1.06 to 1.57]; k=27, N and I^2^ not reported).^241^ This finding held when limited to studies with low risk of bias, studies that adjusted for covariates, and studies that declared no fCOI. The increased risk was also statistically significant when limited to people with MDD, when any indication was allowed, and among studies conducted outside of North America. However, there was a statistically significant reduction in risk among studies conducted in North America and no association found when limited to studies with a financial COI declared. In a cohort study (N=358,351) using claims data,^237^ there was no association between antidepressant dispensing and a suicide attempt leading to a medical encounter (Table 22). This study controlled for a wide range of patient-, physician-, and market-level variables. Effect sizes for SSRI, SNRI, and tricyclic antidepressants (TCA) dispensings had very wide confidence intervals but trended in the direction of benefit; however the association was in the direction of increased risk of a suicide attempt for people who had dispensings of two or more different kinds of antidepressants.^237^

One IPD MA of suicidal ideation as measured by the HAM-D suicide item found that, among adults age 25 and older, the reduction in mean suicidality ratings was larger in patients receiving SSRI from week 1 and onwards, relatively to placebo.^251^ In young adults (age 18–24 years), those given an SSRI were at higher risk for worsening of suicidal ideation (in the unadjusted analysis) or emergent suicidality during the late (weeks 3–6) but not the early phase (weeks 1–2) of treatment. A separate IPD MA confirmed a lack of harms related to suicidal ideation in general and older adult populations. Fluoxetine and venlafaxine decreased suicidal thoughts and behavior for adult and geriatric patients. They determined that the protective effect was mediated by decreases in depressive symptoms with treatment.^240^

###### Other Serious Adverse Events

ESRs also reported on specific serious adverse events, although the evidence was limited and the data were primarily from observational studies. For falls and fractures, the available evidence was insufficient to determine whether pharmacotherapy increased the risk of serious harm (Figure 19, Appendix E Table 36).^246,^ ^252^ Most analyses included only one to three RCTs and few events. The largest analysis was among observational studies and found an increased risk of fracture with antidepressant use (RR, 1.67 [95% CI, 1.56 to 1.79], 23 studies, N not reported, I^2^=88.4). Effect sizes were very similar in stratified analyses of studies that did and did not control for depression. These observational studies include a risk of confounding by unmeasured variables, such as indication for treatment.

Figure 19 Forest Plot of Group Differences in Falls or Fractures With Pharmacological Treatment of Depression Compared to Placebo (KQ5)

Abbreviations: CI = confidence interval; ES = effect size; HR = hazard ratio; MDD = major depressive disorder; NR = not reported; RR = relative risk; SNRI = Serotonin and norepinephrine reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor.

This figure shows a forest plot of group differences in falls or fractures with pharmacological treatment of depression compared to placebo (key question 5).

For cardio- or cerebro-vascular disease, four ESRs provided data, which was primarily or entirely limited to observational studies (Figure 20, Appendix E Table 37).^244,^ ^248,^ ^249,^ ^253^ While many of the findings for stroke, intracranial hemorrhage, and venous thromboembolism showed an increased risk with antidepressant use, all reviews had a risk of confounding by indication, rendering these data insufficient to determine whether pharmacotherapy increased the risk of these serious harms. Findings were also inconclusive for mortality, dementia, and bleeding risk due to the small numbers of studies and events and most evidence being from observational studies (Appendix E Tables 38 and 39).

Figure 20 Forest Plot of Group Differences in Cardiovascular-Related Outcomes With Pharmacological Treatment of Depression Compared to Placebo (KQ5)^*^ * Effects are RRs for all outcomes except those reported by Maslej, 2017, which are HRs.

Abbreviations: AD = antidepressant; CI = confidence interval; CVD = cardiovascular disease; ES = effect size; HR = hazard ratio; ICrH = intracranial hemorrhage; MDD = major depressive disorder; NR = not reported; RCT = randomized controlled trials; SNRI = Serotonin and norepinephrine reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor; TCA = tricyclic antidepressant.

This figure shows a forest plot of group differences in cardiovascular-related outcomes with pharmacological treatment of depression compared to placebo (key question 5).*

Similarly, evidence related to harms of antidepressants during pregnancy were almost entirely limited to observational evidence. An IPD meta-analysis of cohort studies found a statistically significant association between SSRI use and higher probability of preterm birth among women with depressive symptoms (OR, 1.6 [95% CI, 1.0 to 2.5]; 140/1328 (10.5) with SSRI use, 468/5652 (8.2) without SSRI, adjusted for race/ethnicity, parity, and smoking during pregnancy), but no association between either any antidepressant use or SSRI use and low birth weight, small for gestational age, or low 5-minute Apgar result (Appendix E Table 39). A review of 9 observational studies (n=1,287,539) examining the association between SSRI use and preeclampsia or gestational hypertension found an increased risk (OR, 1.43 [95% CI, 1.15 to 1.78]).^255^ They cautioned, however, that this evidence was limited by confounding and high heterogeneity, and most studies did not account for risk factors shared between mood disorders and hypertension or for underlying risk factors shared by depression and preeclampsia. Similarly, another broader review concluded that, although many studies report on adverse events, they could not rule out underlying disease severity as the cause of the association between exposures and adverse events.^232^ The authors of this review judged the certainty of evidence to draw conclusions to be insufficient or low in all instances, including congenital and cardiac anomalies (graded insufficient), primarily because of lack of control for confounding.

## Anxiety

### KQ1. Do Anxiety Screening Programs in Primary Care or Comparable Settings Result in Improved Health Outcomes in Adults, Including Pregnant and Postpartum Persons?

### KQ1a. Does Sending Anxiety Screening Test Results to Providers (With or Without Additional Care Management Supports) Result in Improved Health Outcomes?

#### Summary

We identified two RCTs (reported in 4 publications) of anxiety screening, both in general adult populations.^165,^ ^258–260^ One of these also screened for depression and several other conditions along with anxiety^165^ (Table 23). Both trials found no reduction in anxiety symptoms or general psychological symptom severity compared with usual care at 13 to 22 weeks’ followup.

Table 23 Characteristics of Anxiety Screening Studies (KQ1)

Author, Year | Quality rating | Study design (Unscreened control?) | Study N | Country | Broad population | Specific population | FUP, wks | Screening approach | Screen pos, % | Condition criteria | Benefit (KQ1) | Harm (KQ3)
Kroenke, 2018^165^ | Good | RCT (No) | 300 | USA | General adults | Primary care patients age ≥18 years screening positive for sleep, pain, anxiety, depression, or fatigue symptoms. | 13 | Screening results | 89 | Scored ≥4 (out of 10) on anxiety, depression, sleep, fatigue, or pain sx (single item each) | X
Mathias, 1994^259^ | Fair | Cluster RCT (No) | 618 | USA | General adults | Primary care patients with elevated anxiety symptoms who were currently unrecognized and untreated. | 13, 22 | Screening results | 7.7 | Unrecognized and untreated elevated anxiety symptoms on the SCL-90-R | X

Abbreviations: FUP = followup; KQ = key question; pos = positive; RCT = randomized controlled trial; SCL-90-R = Symptom Checklist-90-Revised; sx = symptoms; USA = United States of America.

#### Study Characteristics

Two studies examined the benefits of screening for anxiety (N=918), both conducted in the US (Tables 23–25, Appendix F Table 1).^165,^ ^259^ A fair-quality study published in 1994 (n=618) screened adult primary care patients and enrolled those with elevated anxiety symptoms according to the Revised Symptom Checklist-90 (SCL-90-R) whose anxiety symptoms had not been recognized by their healthcare providers.^259^ Screening results for intervention participants were given to their primary care providers in the form of patient profiles showing anxiety symptoms and functional status. Primary care providers received one-on-one training in both the use of the study-provided profiles and anxiety treatment in general, and also had phone access to study physicians for questions. The average age of participants in this study was 42.6 years, 58.6 percent were women, and 80.4 percent were White. The race and ethnicity of the remaining participants was not reported. The second study (n=300, rated good quality) published in 2018 screened adult primary care patients for symptoms of anxiety, depression, sleep, pain, or fatigue and enrolled those who scored 4 or higher (out of 10) for any of these concerns.^165^ Primary care clinicians were given a visual display of participants’ symptom profile based on sections of the Patient-reported Outcome Measurement Information System (PROMIS). In this study, the average age of participants was 49.4 years, 71.7 percent were women, 49.3 percent were Black, and 45.0 percent were White. This study was also included above, under depression screening since it screened for both of these conditions.

Table 24 Participant Characteristics of Anxiety Screening Studies (KQ1)

Author, Year | Mean age (Range), years | % Women^*^ | Education | Other SES | Race or Ethnicity | % Screen pos | BL MH status
Kroenke, 2018^165^ | 49.4 (NR) | 71.7 | High school grad: NR; College grad: 13.3 | Employed: NR; Single: NR; Other SES: Edu high school or less: 53.3% | Black: 49.3; Hispanic/Latino: NR; Asian/AA: NR; Native Am/AN: NR; White: 45.0 | 89 | t-score ≥55 on PROMIS depression subscale: 59.3%; t-score ≥55 on PROMIS anxiety subscale: 72.3%
Mathias, 1994^259^ | 42.6 (NR) | 58.6 | High school grad: NR; College grad: 31.7 | Employed: NR; Single: 20.2; Other SES: Income: 49,000: 23.9% | Black: NR; Hispanic/Latino: NR; Asian/AA: NR; Native Am/AN: NR; White: 80.4 | 7.7 | NR

* Non-binary/gender non-conforming categories were not reported in any studies.

Abbreviations: Asian/AA = Asian/Asian American; BL MH = baseline mental health; edu = education; NR = not reported; Native Am/AN = Native American/Alaska Native; pos = positive; PROMIS = Patient-Reported Outcomes Measurement Information System; SES = socioeconomic status.

Table 25 Intervention Characteristics of Anxiety Screening Studies (KQ1)

Author, Year | Target pop | Tng in Screening | Tng in Diagnosis | Tng in treatment | Generic tx guide | Generic handout | Pt-specific tx rec | Referral support | Sx monitoring | Monitoring med use | Med use counseling | PCP Role
Kroenke, 2018^165^ | General adults | | | | | | | | | | | Deliver most/all of intervention
Mathias, 1994^259^ | General adults | | X | | | | | X | | | | Deliver some of intervention

Abbreviations: Med = medication; NR = not reported; PCP = primary care provider; pop = population; Pt = patient; sx = symptoms; Tng = training; tx = treatment.

#### Results

Both of the included studies reported that the screening programs did not improve anxiety outcomes over usual care (Table 26). The older study that only screened for anxiety found no differences between groups at followup in anxiety symptom levels or in any of the SF-36 subscale scores at 5 months’ followup.^259^ The study that screened for anxiety along with depression, pain, sleep disturbance, and fatigue reported a difference in improvement of 0.83 points on a 16-point scale at 3 months’ followup (p=.47).^165^ Similarly, this study also found almost identical absolute change in the General Severity Index (p=.74), a measure of mental health symptom severity. Across all outcomes reported, group differences in change ranged from −1.5 on a 16-point scale to 0.3 on a 40-point scale.

Table 26 Results of Anxiety Screening Studies (KQ1)

Author, Year (Pop) | Outcome | Measure | Scale range | Higher score is | Analyzed | IG | FUP, wks | IG n | CG n | IG BL Mean (SD) | CG BL Mean (SD) | IG Chg Mean (SD) | CG Chg Mean (SD) | Diff in Chg (CI) | p-value | Adj^*^
Kroenke, 2018^165^ (G) | Depression symptoms | PROMIS-Depression | 4–20 | Worse | All | IG1 | 13 | 151 | 149 | 55.8 (10.4) | 56 (9.1) | -3.1 (NR) | -1.6 (NR) | -1.5 (NR) | 0.174 | NR
Mathias, 1994^259^ (G) | Anxiety symptoms | GAS | 40–81 | Worse | All | IG1 | 22 | 357 | 216 | 60.1 (5.7) | 60.8 (5.9) | -2.7 (6.4) | -3.1 (6.5) | 0.3 (-1.3 to 2) | 0.52 | Yes
Kroenke, 2018^165^ (G) | Anxiety symptoms | PROMIS-Anxiety | 4–20 | Worse | All | IG1 | 13 | 151 | 149 | 59 (10.1) | 59.2 (8.7) | -3 (NR) | -2.1 (NR) | -0.8 (NR) | 0.471 | NR
Mathias, 1994^259^ (G) | Global mental health symptoms | GSI | 40–81 | Worse | All | IG1 | 22 | 357 | 216 | 63.8 (7.6) | 64.6 (7.3) | -3.8 (8.5) | -3.7 (8.7) | -0.1 (-2.3 to 2.1) | 0.74 | Yes

* Analysis adjusted for baseline values or covariates.

Abbreviations: Adj = adjusted; BL = baseline; Chg = change; CI = confidence interval; CG = control group; Diff = difference; G = general adults; FUP = followup; GAS = Geriatric Anxiety Scale; GSI = Global Severity Index; IG = intervention group; IG1 = intervention group 1; NR = not reported; Pop = population; PROMIS = Patient-Reported Outcomes Measurement Information System; SD = standard deviation; wks = weeks.

### KQ2. Do Instruments to Screen for Anxiety Accurately Identify Adults, Including Pregnant and Postpartum Persons, With Anxiety in Primary Care or Comparable Settings?

#### Summary

We included ten primary studies (in 12 articles) that reported the test accuracy of screening for anxiety with the GAD, GAS, EPDS-anxiety subscale, or PHQ-panic disorder to detect generalized anxiety disorder, panic disorder, social anxiety disorder, or any anxiety disorder (Table 27, Figure 21).^29,^ ^261–271^ The most commonly studied instruments were the GAD-2 and GAD-7. To detect generalized anxiety disorder, the GAD-2 at a cutoff of ≥3 accurately identified 69 to 83 percent of adults (including pregnant women) with generalized anxiety disorder and 88 to 91 percent without it. The GAD-2 needed a lower cutoff to obtain similar test accuracy to detect any anxiety disorder, with a cutoff of ≥1 identifying a similar proportion of those with any anxiety disorder (70% to 90%), but at the cost identifying those without any anxiety disorder (55% to 64%). At a cutoff of ≥2, the GAD-2 accurately detected 50 to 91 percent of adults with a panic disorder and 63 to 74 percent of those without a panic disorder. At the same cutoff, the GAD-2 identified 85 percent of those with social anxiety disorder and 62 percent of those without. In general, the GAD-7 performed as well or better than the GAD-2.

Figure 21 Summary of Test Accuracy of Screening Instruments to Detect Anxiety Disorders (KQ2)

* Pooled results for fewer than 3 studies shown only for illustrative purposes.

Note: The number of participants for Generalized Anxiety Disorder and Any Anxiety Disorder, GAD-2, pregnant women are totaling with an extrapolated sample from one study.

Abbreviations: CI = Confidence interval; GAD = Generalized Anxiety Disorder.

This figure shows a summary of test accuracy of screening instruments to detect anxiety disorders (key question 2)

Table 27 Characteristics of Studies Examining the Test Accuracy of Instruments to Screen for Anxiety

Author, Year | Quality | Country | Brief population description | N analyzed | Diagnostic interview | Diagnostic criteria | Screening test | Condition
Ahn, 2019^261^ | Good | The Republic of Korea | ≥ 9 years, community | 1,157 | MINI | DSM-IV | GAD-2 | Anxiety disorder
Ahn, 2019^261^ | Good | The Republic of Korea | ≥ 9 years, community | 1,157 | MINI | DSM-IV | GAD-2 | GAD
Ahn, 2019^261^ | Good | The Republic of Korea | ≥ 9 years, community | 1,157 | MINI | DSM-IV | GAD-7 | Anxiety disorder
Ahn, 2019^261^ | Good | The Republic of Korea | ≥ 9 years, community | 1,157 | MINI | DSM-IV | GAD-7 | GAD
Austin, 2021^262^ | Fair | Australia | Women attending their first prenatal appointment | 954 | SAGE-SR | DSM-5 | GAD-2 | Anxiety disorder
Austin, 2021^262^ | Fair | Australia | Women attending their first prenatal appointment | 954 | SAGE-SR | DSM-5 | GAD-7 | Anxiety disorder
Austin, 2021^262^ | Fair | Australia | Women attending their first prenatal appointment | 954 | SAGE-SR | DSM-5 | EPDS - Anxiety Subscale | Anxiety disorder
Gould, 2014^263^ | Fair | USA | ≥65 years, community-dwelling | 110 | SCID | DSM-IV | GAS | Anxiety disorder
Kujanpaa, 2014^264^ | Fair | Finland | ≥18 years, high utilizers of health care | 150 | MINI | DSM-IV | GAD-2 | Anxiety disorder
Kujanpaa, 2014^264^ | Fair | Finland | ≥18 years, high utilizers of health care | 150 | MINI | DSM-IV | GAD-2 | GAD
Kujanpaa, 2014^264^ | Fair | Finland | ≥18 years, high utilizers of health care | 150 | MINI | DSM-IV | GAD-2 | PD
Kujanpaa, 2014^264^ | Fair | Finland | ≥18 years, high utilizers of health care | 150 | MINI | DSM-IV | GAD-7 | Anxiety disorder
Kujanpaa, 2014^264^ | Fair | Finland | ≥18 years, high utilizers of health care | 150 | MINI | DSM-IV | GAD-7 | GAD
Kujanpaa, 2014^264^ | Fair | Finland | ≥18 years, high utilizers of health care | 150 | MINI | DSM-IV | GAD-7 | PD
Makulowich, 2018^265^ | Fair | USA | ≥18 years, receiving primary care in an integrated community care clinic | 50 | MINI | DSM-IV | GAD-7 | Anxiety disorder
Matthey, 2013^266^ | Fair | Australia | Women attending their first prenatal appointment | 249 | MINI | DSM-IV | EPDS - Anxiety Subscale | Anxiety disorder
Nath, 2018^267^ | Fair | UK | Women using inner-city maternity services | 528 (sample without extrapolation) | SCID | DSM-IV | GAD-2 | Anxiety disorder
Nath, 2018^267^ | Fair | UK | Women using inner-city maternity services | 528 (sample without extrapolation) | SCID | DSM-IV | GAD-2 | GAD
Spitzer, 2006^270^ | Good | USA | Primary care patients | 965 | SCID | DSM-IV | GAD-2 | Anxiety disorder
Spitzer, 2006^270^ | Good | USA | Primary care patients | 965 | SCID | DSM-IV | GAD-2 | GAD
Spitzer, 2006^270^ | Good | USA | Primary care patients | 965 | SCID | DSM-IV | GAD-2 | PD
Spitzer, 2006^270^ | Good | USA | Primary care patients | 965 | SCID | DSM-IV | GAD-2 | SAnD
Spitzer, 2006^270^ | Good | USA | Primary care patients | 965 | SCID | DSM-IV | GAD-7 | Anxiety disorder
Spitzer, 2006^270^ | Good | USA | Primary care patients | 965 | SCID | DSM-IV | GAD-7 | GAD
Spitzer, 2006^270^ | Good | USA | Primary care patients | 965 | SCID | DSM-IV | GAD-7 | PD
Spitzer, 2006^270^ | Good | USA | Primary care patients | 965 | SCID | DSM-IV | GAD-7 | SAnD
Spitzer, 1999^269^ | Fair | USA | Primary care patients | 585 | SCID | DSM-III-R | PHQ-PD | PD
Vasiliadis, 2015^271^ | Fair | Canada | ≥65 years, community-dwelling, attending primary care | 1,715 | ESA diagnostic module | DSM-IV | GAD-7 | Anxiety disorder

Abbreviations: DSM-III-R = Diagnostic and Statistical Manual of Mental Disorders, 3^rd^ edition revised; DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, 4^th^ edition; EPDS = Edinburgh Postnatal Depression Scale; EPDS-Anxiety subscale = Edinburgh Postnatal Depression Scale - Anxiety subscale; ESA = Enquête sur la Santé des Aînés (Seniors’ Health Survey); GAD = Generalized Anxiety Disorder; GAD-2 = generalized anxiety disorder 2-item scale; GAD-7 = generalized anxiety disorder 7-item scale; GAS = Geriatric Anxiety Scale; MINI = Mini International Neuropsychiatric Interview; N = number of participants; PD = panic disorder; PHQ-PD = Patient Health Questionnaire-Panic Disorder; SAGE-SR = Series of Assessments to Guide Evaluation-Self Report; SAnD = social anxiety disorder; SCID = Structured Clinical Interview for DSM Disorders; UK = United Kingdom; USA = United States of America.

#### Study Characteristics

Ten primary studies (N=6,463) were included that provided test accuracy results for anxiety screening (Table 27).^261–267,^ ^269–271^ Included studies primarily examined the GAD-2 and GAD-7; one study reported accuracy for the EPDS anxiety subscale, one study reported accuracy for the GAS, and one for the panic disorder module of the PHQ. Four studies were conducted in the US.^263,^ ^265,^ ^269,^ ^270^ The others took place in South Korea, Finland, Australia, Canada, and the UK. Sample size ranged from 50 to 1,715; four of the studies analyzed a sample of 249 participants or less.

Two studies recruited older adults (65 years or older),^263,^ ^271^ three studies recruited patients from prenatal care,^262,^ ^266,^ ^267^ one study recruited adults who were high utilizers of primary care,^264^ and the remaining four recruited adults from primary care or the community. Mean age ranged from 29 to 75 years (k=9) (Table 28). Women were represented in higher proportions than men: 57 to 100 percent of participants were women. Race and ethnicity were reported in six studies. One study, conducted in South Korea, recruited only participants of South Korean ethnicity.^261^ A US-based study recruited participants from an integrated community care clinic and reported that 76 percent of participants were Hispanic/Latino.^265^ One study—conducted among patients using inner-city maternity services in the UK—recruited 53 percent White and 32 percent Black participants. The remaining three studies reporting race or ethnicity recruited mainly White participants (79%, 80%, and 91%).^263,^ ^269,^ ^270^ SES was variably reported; mean years of education ranged from 14.6 to 17.3 (k=2) and those with 12 or more years of education ranged from 88 to 94 percent (k=5).

Table 28 Participant Characteristics for Studies of Test Accuracy of Anxiety Screening Instrument (KQ2)

Author, Year | N analyzed | Anxiety disorder, n (%) | Mean age, years | Age range, years | % Women^*^ | Race or ethnicity, % | SES
Ahn, 2019^261^ | 1,157 | Any: 218 (18.8); GAD: 90 (7.8) | 37 | 19–85 | 67 | Korean: 100 | Mean education, years: 14.6
Austin, 2021^262^ | 954 | Any: 30 (3.1) | 34 | 20–50 | 100 | NR | University education, %: 82
Gould, 2014^263^ | 110 | Any: 10 (9.1); GAD: 2 (1.8) | 75 | 65+ | 57 | White: 90.9 | Mean education, years: 17.3
Kujanpaa, 2014^264^ | 150 | Any: 26 (17.3); GAD: 6 (4.0); PD: 10 (6.7) | 63 | 18+ | 69 | NR | Education, %; Less than comprehensive school: 10.8; Comprehensive school: 38.5; Matriculation examination: 1.4; Vocational examination: 35.1; College: 13.5; Academic degree: 0.7
Makulowich, 2018^265^ | 50 | Any: 16 (32); GAD: 8 (16) | 50 | 18+ | 70 | White: 26; Black: 8; Asian: 2; Hispanic: 76; Other: 53 | NR
Matthey, 2013^266^ | 249 | Any: 35 (14.0) | 29 | NR | 100 | NR | Education, %; Completed HS: 65.2; Tertiary: 27.6; Recruited from a low-middle SES area of Sydney
Nath, 2018^267^ | 528; (unextrapolated sample) | Any: 90 (17, weighted); GAD: 79 (15, weighted) | 32 | 14–52 | 100 | White: 53; Black: 32; Asian: 4; Other: 7 | Highest education level, %; None/school qualifications: 12; College/diploma/higher/certificate/training: 36; Degree level/postgraduate: 52; Income in pounds, %; <15,000: 18; 15–30,999: 17; 31–45,999: 15; 46–60,999: 15; >61,000: 35
Spitzer, 2006^270^ | 965 | Any: 188 (19.5); GAD: 73 (7.6); PD: 66 (6.8); SAnD: 60 (6.2) | 47 | 18–95 | 65 | White: 80; Black: 8; Hispanic: 9 | Education, %; HS or equivalent: 31; Some college: 62
Spitzer, 1999^269^ | 585 | NR | 46^†^ | 18–99^†^ | 46^†^ | White: 79; Black: 13; Hispanic: 4 | Education, %; College graduate: 25
Vasiliadis, 2015^271^ | 1,715 | Any: 251 (15.1) | NR | 65+ | 57 | NR | NR

* Non-binary/gender non-conforming categories were not reported in any studies.

† These characteristics are from 3,000 patients screened using the full PHQ, not the 585 patients who received the reference standard and used to determine the test accuracy.

Abbreviations: GAD = generalized anxiety disorder; HS = high school; N = number of participants; NR = not reported; PD = panic disorder; SAnD = social anxiety disorder; SES = socioeconomic status.

All studies used a structured or semi-structured interview within two weeks after the screener to identify generalized anxiety disorder or any anxiety disorder. The most common interviews were the MINI (k=4) and the SCID (k=4). The proportion of participants who were diagnosed with generalized anxiety disorder ranged from 1.8 percent to 16 percent, the proportion diagnosed with any anxiety disorder ranged from 3.1 percent to 32 percent, and the proportion diagnosed with panic disorder in two studies was 6.7 and 6.8 percent. The one study reporting social anxiety disorder reported a prevalence of 6.2 percent.

#### Results

##### GAD-2

Four studies reported the accuracy of the GAD-2 to detect GAD,^261,^ ^264,^ ^267,^ ^270^ one of which took place in the US among primary care patients (Table 27).^270^ Despite the GAD-2 being developed to detect generalized anxiety disorder, some of these studies also reported test accuracy of the GAD-2 to detect any anxiety disorder (k=4), panic disorder (k=2), and social anxiety disorder (k=1).

###### Generalized Anxiety Disorder

Three studies among general adult populations reported the test accuracy of the GAD-2 to detect GAD.^261,^ ^264,^ ^270^ At a cutoff of ≥2, the pooled sensitivity to detect GAD was 0.94 (95% CI, 0.90 to 0.98; I^2^=0%) and the pooled specificity was 0.68 (95% CI, 0.64 to 0.72; I^2^=94.5%). At a cutoff of ≥3, the pooled sensitivity was 0.81 (95% CI, 0.73 to 0.89; I^2^=28.8%) and the pooled specificity was 0.86 (95% CI, 0.83 to 0.90; I^2^=84.5%) (Figure 22, Appendix F Table 2).^261,^ ^264,^ ^270^

Figure 22 Test Accuracy of the GAD-2 to Detect Generalized Anxiety Disorder, by Cutoff (KQ2)

Note: Pooled results for the three general adult studies are not shown. At a cutoff of ≥2, pooled sensitivity was 0.94 (95% CI, 0.90 to 0.98; I^2^=0%) and pooled specificity was 0.68 (95% CI, 0.64 to 0.72; I^2^=94.5%). At a cutoff of ≥3, pooled sensitivity was 0.81 (95% CI, 0.73 to 0.89; I^2^=28.8%) and pooled specificity was 0.86 (95% CI, 0.83 to 0.90; I^2^=84.5%).

Abbreviations: CI = Confidence interval; GAD = Generalized Anxiety Disorder; n = number of participants.

This figure shows the test accuracy of the GAD-2 to detect generalized anxiety disorder, by cutoff (key question 2)

For the study among pregnant women (n=9,750), at a cutoff of ≥1, the sensitivity of the GAD-2 to identity GAD was 1.0 (95% CI, 0.99 to 1.0) and the specificity was 0.60 (95% CI, 0.60 to 0.61).^267^ At a cutoff of ≥3, the sensitivity to detect GAD was 0.69 (95% CI, 0.64 to 0.73) and the specificity was 0.91 (95% CI, 0.90 to 0.91) (Figure 22, Appendix F Table 2).^267^

###### Any Anxiety Disorder

The same three studies among adults reported the test accuracy of the GAD-2 to detect any anxiety disorder.^261,^ ^264,^ ^270^ At a cutoff of ≥2, the pooled sensitivity to detect any anxiety disorder was 0.76 (95% CI, 0.65 to 0.87; I^2^=85.8%) and the pooled specificity was 0.73 (95% CI, 0.69 to 0.76; I^2^=67.7%). At a cutoff of ≥3, the pooled sensitivity was 0.53 (95% CI, 0.39 to 0.66; I^2^=86.8%) and the pooled specificity was 0.90 (95% CI, 0.88 to 0.92; I^2^=48.1%) (Figure 23, Appendix F Table 3).^261,^ ^264,^ ^270^

Figure 23 Test Accuracy of the GAD-2 to Detect Any Anxiety Disorder, by Cutoff (KQ2)

Note: Pooled results for the three general adult studies are not shown. At a cutoff of ≥2, pooled sensitivity was 0.76 (95% CI, 0.65 to 0.87; I^2^=85.8%) and pooled specificity was 0.73 (95% CI, 0.69 to 0.76; I^2^=67.7%). At a cutoff of ≥3, pooled sensitivity was 0.53 (95% CI, 0.39 to 0.66; I^2^=86.8%) and pooled specificity was 0.90 (95% CI, 0.88 to 0.92; I^2^=48.1%).

Abbreviations: CI = Confidence interval; ext = extrapolated; GAD = Generalized Anxiety Disorder; n = number of participants.

This figure shows the test Accuracy of the GAD-2 to detect any anxiety disorder, by cutoff (key question 2)

For two studies among pregnant patients (n=528 [9,750 extrapolated] and n=954), at a cutoff of ≥1, the sensitivity of the GAD-2 to identity any anxiety disorder was 0.90 (95% CI, 0.74 to 0.97) and 0.70 (0.68, 0.73) and the specificity was 0.63 (95% CI, 0.59 to 0.66) and 0.64 (95% CI, 0.63 to 0.65).^262,^ ^267^ At a cutoff of ≥3, the sensitivity to detect any anxiety disorder was 0.30 (95% CI, 0.17 to 0.48) and 0.26 (95% CI, 0.24 to 0.29) and the specificity was 0.98 (95% CI, 0.96 to 0.98) and 0.91 (95% CI, 0.90 to 0.92)^262,^ ^267^ (Figure 23, Appendix F Table 3).

###### Panic Disorder

Two studies reported the test accuracy of the GAD-2 to identify panic disorder among adults.^264,^ ^270^ At a cutoff of ≥2, sensitivity ranged from 0.50 (95% CI, 0.19 to 0.81) among high utilizers of primary care to 0.91 (95% CI, 0.81 to 0.97) among primary care patients in the US. Specificity ranged from 0.74 (95% CI, 0.66 to 0.81) to 0.63 (95% CI, 0.60 to 0.66), respectively. At a cutoff of ≥3, sensitivity decreased (0.30 to 0.76) but specificity increased (0.81 to 0.89) (Figure 24, Appendix F Table 4).

Figure 24 Test Accuracy of the GAD-2 to Detect Panic Disorder, by Cutoff (KQ2)

Abbreviations: CI = confidence interval; GAD = generalized anxiety disorder.

This figure shows the test accuracy of the GAD-2 to detect panic disorder, by cutoff (key question 2)

###### Social Anxiety Disorder

One study among primary care patients in the US reported the test accuracy of the GAD-2 to detect social anxiety disorder.^270^ At a cutoff of >=2, the sensitivity was 0.85 (95% CI, 0.73 to 0.93) and the specificity was 0.62 (95% CI, 0.59 to 0.65). At a cutoff of >=3, the sensitivity was lowered to 0.70 (95% CI, 0.57 to 0.81) and the specificity increased to 0.81 (95% CI, 0.78 to 0.83) (Appendix F Table 5).^270^

##### GAD-7

Six studies reported test accuracy for the GAD-7 to detect GAD, PD, SAD, or any anxiety disorder (Table 27).^261,^ ^262,^ ^264,^ ^265,^ ^270,^ ^271^ Four of the studies recruited adults from the community or primary care,^261,^ ^264,^ ^265,^ ^270^ although one was among high utilizers of primary care.^264^ One study recruited community-dwelling older adults attending primary care^271^ and one recruited prenatal patients.^262^

###### Generalized Anxiety Disorder

To detect GAD, three studies reported test accuracy for the GAD-7 at a cutoff of ≥8, ≥9, and ≥10.^261,^ ^264,^ ^270^ At a cutoff of ≥10, the pooled sensitivity to detect GAD was 0.79 (95% CI, 0.65 to 0.94; I^2^=77.3%) and pooled specificity was 0.89 (95% CI, 0.83 to 0.94; I^2^=94.8%). Sensitivity among the three studies ranged from 0.67 to 0.89, and specificity ranged from 0.82 to 0.95. At lower cutoffs (≥8, ≥9), sensitivity increased and specificity decreased (Figure 25, Appendix F Table 2). At higher (≥10–21) cutoffs, only one to two studies reported test accuracy data at each cutoff to detect GAD. These studies followed the same trend with higher cutoffs yielding lower sensitivity and higher specificity and lower cutoffs yielding higher sensitivity and lower specificity.

Figure 25 Test Accuracy of the GAD-7 to Detect Generalized Anxiety Disorder, by Cutoff (KQ2)

Abbreviations: CI = Confidence interval; GAD = Generalized Anxiety Disorder; n = number of participants.

This figure shows the test accuracy of the GAD-7 to detect generalized anxiety disorder, by cutoff (key question 2)

###### Any Anxiety Disorder

To adequately detect any anxiety disorder, lower cutoffs of the GAD-7 were necessary. At a cutoff of ≥6, pooled sensitivity of the GAD-7 to detect any anxiety disorder from four studies conducted among adults was 0.67 (95% CI, 0.48 to 0.81; I^2^=90.5%; n=2,322) and pooled specificity was 0.81 (95% CI, 0.73 to 0.87; I^2^=91.0%) (pooled estimate not shown in a figure).^261,^ ^264,^ ^265,^ ^270^ Sensitivity ranged from 0.38 to 0.85 and specificity ranged from 0.71 to 0.91 (Figure 26, Appendix F Table 3). At a cutoff of ≥5, the pooled sensitivity to detect any anxiety disorder among adults was 0.81 (95% CI, 0.68 to 0.95; I^2^=91.4%) and the pooled specificity was 0.72 (95% CI, 0.63 to 0.81; I^2^=96.1%) (pooled estimate not shown in a figure). At lower cutoffs, sensitivity increased and specificity decreased, but no more than two studies among a general adult population were represented at each lower cutoff. Similarly, at higher (≥10–21) cutoffs, only one to two studies reported test accuracy data at each cutoff to detect any anxiety disorder. These studies followed the same trend with higher cutoffs yielding lower sensitivity and higher specificity and lower cutoffs yielding higher sensitivity and lower specificity.

Figure 26 Test Accuracy of the GAD-7 to Detect Any Anxiety Disorder, by Cutoff (KQ2)

Note: Pooled results for the four general adult studies are not shown. At a cutoff of ≥6, pooled sensitivity was 0.67 (95% CI, 0.48 to 0.81; I^2^=90.5%) and pooled specificity was 0.81 (95% CI, 0.73 to 0.87; I^2^=91.0%). At a cutoff of ≥5, pooled sensitivity was 0.81 (95% CI, 0.68 to 0.95; I^2^=91.4%) and pooled specificity was 0.72 (95% CI, 0.63 to 0.81; I^2^=96.1%) (k=3).

Abbreviations: CI = confidence interval; GAD = Generalized Anxiety Disorder; n = number of participants.

This figure shows the test accuracy of the GAD-7 to detect any anxiety disorder, by cutoff (key question 2)

The one study that examined the test accuracy of the GAD-7 to detect any anxiety disorder among older adults determined the optimal cutoff was ≥5.^271^ Sensitivity was 0.71 (95% CI, 0.65 to 0.76) and specificity was 0.57 (95% CI, 0.54 to 0.59) (Figure 26), with an AUC of 0.695 (Appendix F Table 3). While lower cutoffs yielded higher sensitivities (ranging from 0.80 to 0.92), the corresponding specificity was lowered to unacceptable levels (ranging from 0.25 to 0.46).^271^ Similarly, higher cutoffs lowered sensitivity and increased specificity (Appendix F Table 2).

For the one study that recruited pregnant women, to detect any anxiety disorder, four cutoffs of the GAD-7 were reported ranging from ≥4 to ≥7.^262^ Sensitivity ranged from a low of 0.43 (95% CI, 0.27 to 0.61) at a cutoff of ≥7 to a high of 0.80 (95% CI, 0.63 to 0.90) and a cutoff of ≥4. Corresponding specificity was 0.93 (95% CI, 0.91 to 0.94) and 0.71 (95% CI, 0.68 to 0.73), respectively.^262^

###### Panic Disorder

Two studies among adults—one among primary care patients in the US—reported the test accuracy of the GAD-7 to detect panic disorder.^264,^ ^270^ At a cutoff of ≥6 (the cutoff required to adequately detect any anxiety disorder), sensitivity to detect panic disorder ranged from 0.70 (95% CI, 0.35 to 0.93) among high utilizers of primary care to 0.88 (95% CI, 0.78 to 0.95) among primary care patients in the US and specificity ranged from 0.64 (0.60 to 0.67) to 0.79 (95% CI, 0.72 to 0.86). At a cutoff of ≥10 (the cutoff needed to detect generalized anxiety disorder), sensitivity among high utilizers of primary care was only 0.40 (95% CI, 0.12 to 0.74) and the specificity was 0.95 (95% CI, 0.90 to 0.98). Among primary care patients in the US, a cutoff of 10 yielded a sensitivity of 0.74 (95% CI, 0.62 to 0.84) and specificity of 0.81 (95% CI, 0.78, 0.83). Both studies showed an inverse relationship between sensitivity and specificity—where lower cutoffs increased sensitivity and decreased specificity—as the cutoff was adjusted (Figure 27, Appendix F Table 4).^264,^ ^270^

Figure 27 Test Accuracy of the GAD-7 to Detect Panic Disorder, by Cutoff (KQ2)

Abbreviations: CI = confidence interval; GAD = Generalized Anxiety Disorder.

This figure shows the test accuracy of the GAD-7 to detect panic disorder, by cutoff (key question 2)

###### Social Anxiety Disorder

One study among primary care patients (n=965) in the US reported the test accuracy of the GAD-7 to detect social anxiety disorder.^270^ Reported cutoffs ranged from ≥5 to ≥10. Sensitivity to detect social anxiety disorder ranged from 0.72 (95% CI, 0.59 to 0.83) at a cutoff of ≥10 to 0.88 (95% CI, 0.77 to 0.95) at a cutoff of ≥5. Specificity ranged from 0.55 (95% CI, 0.52 to 0.59) at a cutoff of ≥5 to 0.80 (95% CI, 0.77 to 0.83) at a cutoff of ≥10 (Appendix F Table 5).

##### Other Anxiety Screeners

One study reported test accuracy of the geriatric anxiety scale (GAS) to identify any anxiety disorder among 110 older adults in the US.^263^ The study reported cutoffs ranging from >9 to >16 with a cutoff of >9 identified as yielding the optimal balance of sensitivity and specificity. At a cutoff of >9, sensitivity of the GAS to detect any anxiety disorder was 0.60 (95% CI, 0.31 to 0.83) and specificity was 0.75 (95% CI, 0.66 to 0.82). Sensitivity increased and specificity decreased with increasing cutoffs (Appendix F Table 3).^263^

Two studies^262,^ ^266^ reported the accuracy of the EPDS anxiety subscale to identify any anxiety disorder among prenatal patients; one reported the sensitivity at a single cutoff only. At a cutoff of 5, sensitivity of the EPDS anxiety subscale to detect any anxiety disorder ranged from 0.54 (95% CI, 0.38 to 0.70)^266^ to 0.70 (95% CI, 0.52 to 0.83)^262^. Corresponding specificity for the single study that reported it was 0.84 (95% CI, 0.81 to 0.86).^262^ At a lower cutoff of 4, sensitivity improved slightly (0.73 [95% CI, 0.56 to 0.86]) but specificity was much lower (0.71 [95% CI, 0.68 to 0.74])^262^ (Appendix F Table 3).

One study reported the test accuracy of the panic disorder module of the PHQ to detect panic disorder among US adults in primary care.^269^ If all five items of the PHQ-PD were endorsed, the sensitivity of the PHQ-PD to detect panic disorder was 0.81 (95% CI, 0.69 to 0.93) and the specificity was 0.99 (95% CI, 0.98 to 1.0) (Appendix F Table 4).^269^

### KQ3. What Are the Harms Associated With Screening for Anxiety in Primary Care or Comparable Settings in Adults, Including Pregnant and Postpartum Persons?

Neither of the two studies of anxiety screening reported on harms, and there was no pattern of effects indicating that screening might paradoxically increase anxiety or mental health symptoms.^165,^ ^259^

### KQ4. Does Treatment of Anxiety (Psychotherapy or Pharmacotherapy) Result in Improved Health Outcomes in Adults, Including Pregnant and Postpartum Persons?

#### Summary

We included 26 RCTs (reported in 36 publications) among primary care patients^272–308^ and 18 ESRs (not limited to primary care populations) addressing treatment for anxiety (Tables 29–32).^211,^ ^215,^ ^220,^ ^232,^ ^309–322^ Among the 24 included RCTs of psychological interventions, 14 were in mixed populations of people with anxiety or depression, and tenwere limited to people with anxiety. Psychological interventions showed a relatively small but statistically significant reduction in anxiety symptom severity in primary care patients with anxiety (SMD, −0.41 [95% CI, −0.58 to −0.23]; 10 RCTs [n=2,075]; I^2^=40.2% , Table 33, Figure 28), but not among mixed populations of people with anxiety or depression (SMD, −0.18 [95% CI, −0.39 to 0.03]; 12 RCTs [n=1,868]; I^2^=66.7%). In the ESRs of psychological treatment, which included an estimated 144 RCTs and approximately 11,000 participants, treatment was associated with reduced anxiety symptoms; SMDs at post-treatment among broad adult populations were −0.80 and larger (e.g., among people with generalized anxiety disorder, SMD, −0.80 [95% CI, −0.93 to −0.67]; 31 RCTs, N and I^2^ not reported; Figure 29). Psychological treatment was also associated with improved depression symptom severity and quality of life. More limited evidence suggested a benefit in older and perinatal patients as well.

Figure 28 Forest Plot Showing the Difference Between Groups in Change From Baseline in Anxiety Symptoms, for Primary Studies of Psychological Intervention for Treatment of Anxiety in Primary Care Populations Reported in Primary RCTs (KQ4)

Abbreviations: BAI = Beck Anxiety Inventory; BSI = Brief Symptom Inventory; CBT = cognitive behavioral therapy; CG = control group; GAD = generalized anxiety disorder; GADSS = Generalized Anxiety Disorder Severity Scale; HADS-A = Hospital Anxiety and Depression Scale – Anxiety; Hamilton Anxiety Rating Scale; IG = intervention group; MBT mindfulness-based therapy; PROMIS – Anxiety = Patient-Reported Outcomes Measurement Information System – Anxiety; PST = problem solving therapy; SCL-ASS8 = Symptom Checklist – Anxiety Symptom Scale; SD = standard deviation; SMD = standardized mean difference; STAI = State Trait Anxiety Inventory.

This figure shows a forest plot showing the difference between groups in change from baseline in anxiety symptoms, for primary studies of psychological intervention for treatment of anxiety in primary care populations reported in primary RCTs (key question 4)

Figure 29 Forest Plot of Standardized Mean Differences Between Groups in Anxiety Symptom Severity for Psychological Treatment of Anxiety Compared to Controls Reported in ESRs (KQ4)

Abbreviations: CBT = cognitive behavioral therapy; CI = confidence interval; FUP = followup; GAD = generalized anxiety disorder; NR = not reported; RoB = risk of bias; PD = panic disorder; SaND = social anxiety disorder; SMD = standardized mean difference.

This figure shows a forest plot of standardized mean differences between groups in anxiety symptom severity for psychological treatment of anxiety compared to controls reported in ESRs (key question 4).

Table 29 Characteristics of Primary Research Studies of Psychological Treatment of Anxiety in Primary Care Patients (KQ4)

Author, Year | Quality rating | Study design | Study N | Country | Broad population | Specific population | Anxiety required | Disorders | Screen detected | FUP, wks | Intervention | Benefits (KQ4) | Harms (KQ5)
Burger, 2020^274^ | Fair | RCT | 282 | NLD | Perinatal | Adult pregnant individuals with at least moderate anxiety or depression symptoms | No | Anxiety disorder: 30.1; GAD: 22.9; PD: 8.2; SAnD: NR; Depressive disorder: 8.2 | Yes | g24, g36, p06, p13, p26, p52, p78 | IG1: 10–14 individual CBT sessions, delivered in person by licensed psychologists | X
Clark, 2022^305^ | Good | RCT | 201 | GBR | General adults | Adults, ages 18–65 years with SAnD | Yes | NR: NR; GAD: 20; PD: 6; SAnD: 100; MDD: 30 | Yes | 13, 52 | IG1: Up to 14 weekly, 90 min face-to-face therapy sessions plus 3 booster sessions; IG2: Personalized internet cognitive therapy program delivered over 14 weeks | X
Corpas, 2021^275^ | Fair | RCT | 105 | ESP | General adults | Adult patients with mild/moderate anxiety, depression, or somatoform symptoms meeting one of the following thresholds: GAD-7 ≥5; PHQ-15 ≥5; PHQPD ≥8; PHQ-9 ≥10 | No | Anxiety disorder: NR; GAD: 63.8; PD: 63.8; SAnD: NR; Depressive disorder: 81.9 | Yes | 8 | IG1: 8 one-hour group sessions of transdiagnostic psychotherapy over 8 weeks with psychologist | X
Fletcher, 2005^277^ | Fair | RCT | 30 | GBR | General adults | Primary care patients age ≥16 years with mild to moderate anxiety and/or depression symptoms | No | GAD: NR; PD: NR; SAnD: NR; MDD: NR | No | 6, 12 | IG1: CBT-oriented self-help manual | X
Gensichen, 2019^278^ | Fair | Cluster RCT | 419 | DEU | General adults | Adult primary care patients with PD, with or without agoraphobia | Yes | GAD: NR; PD: 100; SAnD:; MDD: NR | Yes | 26, 52 | IG1: 4 individual CBT sessions delivered in person, plus case management by general practitioners | X
Graham, 2020^280^ | Good | RCT | 146 | USA | General adults | Adult primary care patients with symptoms of anxiety or depression | No | Screen positive on GAD-7: 89.7; GAD: NR; PD: NR; SAnD: NR; Screen positive on PHQ-9: 83.6 | No | 4, 8 | IG1: 8-week app-based CBT intervention with one 30- to 45-min orientation phone call, optional 10- to 15-min call mid-treatment, and coaching support via brief text messaging | X
Kendrick, 2005^283^ | Fair | RCT | 247 | GBR | General adults | Primary care patients ages 18–65 years with anxiety or depression symptoms | No | Mixed anxiety disorder and depressive disorder, SAnD, PD, or Agoraphobia: 42.1; GAD: NR; PD: 3.6; SAnD: 8.9; Depressive disorder: 33.2 | No | 8, 26 | IG1: One 60-min introductory individual session and five 30- to 45-min individual problem-solving sessions, delivered in person by a community mental health nurse | X
King, 2000^284^ | Fair | RCT | 197 | GBR | General adults | Adult primary care patients with depression, with or without anxiety | No | Mixed depression and anxiety, PD, or SAnD: 34.7; GAD: NR; PD: 3.9; SAnD: 4.8; Depressive disorder: 62.3 | No | 17, 52 | IG1: Up to 12 50-min individual CBT sessions, delivered in person by counselors | X
Lam, 2010^285^ | Fair | RCT | 299 | HKG | Older adults | Primary care patients age ≥60 years with anxiety or depression symptoms | No | GAD: NR; PD: NR; SAnD: NR; MDD: NR | Yes | 6, 12, 26, 52 | IG1: Three 20-to 45-min individual problem-solving sessions, delivered in person by a Family Medicine trainee | X
Lang, 2006^286^ | Fair | RCT | 62 | USA | General adults | Adult primary care patients with anxiety or depression symptoms | No | GAD: 32.2; PD: 6.5; SAnD: 14.5; MDD: 67.7 | Partial (multiple recruitment streams) | 0, 4, 17, 30 | IG1: One 30- to 60-min individual problem-solving session, delivered in person by a therapist, followed by three 30-to 60-min telephone or in person sessions | X
Linden, 2005^289^ | Fair | RCT | 72 | DEU | General adults | Adult primary care patients with GAD | Yes | GAD: 100; PD: NR; SAnD: NR; MDD: NR | No | 14.5 | IG1: 25 50-min individual CBT sessions, delivered in person by therapists | X
Nordgren, 2014^290^ | Good | RCT | 100 | SWE | General adults | Adult primary care patients with any anxiety disorder, with or without co-morbid depression | Yes | GAD: 21; PD: 32; SAnD: 45; MDD: NR | No | 10 | IG1: 7 to 10 modules consisting of text-based guided CBT with therapist support via the internet | X
O’Mahen, 2022^306^ | Fair | RCT | 114 | GBR | Perinatal | Pregnant individuals experiencing prenatal anxiety | Yes | GAD-7, 7+: 100; GAD: NR; PD: NR; SAnD: NR; MDD: NR | Yes | 10, 18, 34 | IG1: Three 90-min group sessions over 10 weeks | X
Proudfoot, 2004^292^ | Fair | RCT | 274 | GBR | General adults | Adult primary care patients with any anxiety disorder, mixed anxiety or depression, or depression. | No | Diagnosis of any anxiety disorder: 66.1; GAD: NR; PD: 5.1; SAnD: 4.0 Diagnosis of depression: 85.4 | Partial (multiple recruitment streams) | 8, 13, 21, 34 | IG1: One 15-min introduction delivered in person, and 8 50-minute computer-based CBT sessions | X
Rollman, 2018^293^ | Good | RCT | 704 | USA | General adults | Adult primary care patients with at least moderate anxiety symptoms | Yes | GAD: 44.5; PD: 22.7; SAnD: NR; MDD: 84.8 | No | 13, 26, 52 | IG1: Internet support group, 8 50-min computerized CBT sessions, and up to 13 15- to 30-min telephone contacts with a care manager | X
Roy-Byrne, 2010^294^ | Good | RCT | 1004 | USA | General adults | Adult primary care patients with GAD, PD, PTSD, or social anxiety disorder | Yes | GAD: 75.3; PD: 47.3; SAnD: 40.3; MDD: 64.5 | Partial (multiple recruitment streams) | 26, 52, 78 | IG1: 6 to 8 individual CBT sessions delivered in person, either alone or with medication by clinical specialist with experience working with anxiety disorders | X
Schreuders, 2007^295^ | Fair | RCT | 175 | NLD | General adults | Adult primary care patients with anxiety or depression symptoms | No | GAD: NR; PD: NR; SAnD: NR; MDD: NR | Yes | 13 | IG1: 4 to 6 internet-based CBT sessions delivered by nurses | X
Seekles, 2011^296^ | Fair | RCT | 120 | NLD | General adults | Adult primary care patients with GAD, minor anxiety disorder, PD, social phobia, MDD or dysthymia | No | Any anxiety disorder: 92.6; GAD: NR; PD: NR; SAnD: NR; Depressive disorder: 56.5 | Yes | 8 | IG1: Stepped care program of watchful waiting for 4 weeks, one 30-min orientation session with a psychiatric nurse, 5-week guided selfhelp problem-solving therapy, and phobia-specific self-help intervention for those with phobias; optional phone or email | X
Stanley, 2009^298^ | Good | RCT | 134 | USA | Older adults | Patients age ≥60 years with GAD, with or without comorbid MDD, dysthymia or other anxiety disorder | Yes | GAD with or without comorbid depression or other anxiety disorder: 100; GAD: 100; PD: NR; SAnD: NR; Presence of coexistent diagnosis of any depression: 44.8 | No | 26, 39, 52, 65 | IG1: Up to 10 individual sessions of CBT delivered in person by a therapist, followed by 4 brief telephone booster sessions | X
Stanley, 2014^297^ | Fair | RCT | 223 | USA | Older adults | Primary care patients age ≥60 years with GAD, with or without comorbid MDD, dysthymia or other anxiety disorder | Yes | GAD with or without comorbid depression or other anxiety disorder: 100; GAD: 100; PD: NR; SAnD: NR; Depressive disorder: 38.6 | No | 26 | IG1: Up to 10 individual CBT sessions, delivered in person or by phone by PhD-level providers | X
Suchan, 2022^307^ | Fair | RCT | 63 | CAN | Perinatal | Mothers age ≥18 years with postpartum depression or anxiety | No | GAD: NR; PD: NR; SAnD: NR; MDD: NR | Partial (multiple recruitment streams) | 8, 13 | IG1: 8-wk web-based CBT lessons with weekly support from a therapist | X | X
Sundquist, 2015^299^ | Fair | RCT | 215 | SWE | General adults | Adult primary care patients with one or more anxiety disorders, depression, adjustment disorder, or severe stress reaction | No | GAD: NR; PD: NR; SAnD: NR; MDD: NR | No | 8 | IG1: Eight 2-hr mindfulness-based group therapy sessions, delivered in person | X
Torres-Platas, 2019^302^ | Fair | RCT | 61 | CAN | Older adults | Patients age ≥60 years with at least moderate anxiety or depression symptoms | No | Anxiety disorder: 57.4; GAD: NR; PD: NR; SAnD: NR; MDD: 54.1 | No | 8 | IG1: 8 2-hr mindfulness-based group sessions, delivered in person by multi-disciplinary care team | X
Vera, 2021^304^ | Good | RCT | 60 | USA (PR) | General adults | Spanish-speaking, Hispanic/Latino primary care patients with scores of at least 5.7 on the GAD-Q-IV and 56 on PSWQ. | Yes | Anxiety disorders: NR; GAD: 100; PD: NR; SAnD: NR; MDD: NR | Yes | 20, 28 | IG1: Fifteen 1.5-hr individual CBT sessions with a licensed psychologist, delivered weekly for 16 weeks | X

Abbreviations: CAN = Canada; CBT = cognitive behavioral therapy; DEU = Germany; FUP = followup; GAD = generalized anxiety disorder; GAD-7 = Generalized Anxiety Disorder 7-item scale; GBR = Great Britain; HKG = Hong Kong; IG1 = intervention group 1; KQ = key question; MDD = major depressive disorder; NLD = Netherlands; N = number of participants; NR = not reported; PD = panic disorder; PHQ = Patient Health Questionnaire; PR = Puerto Rico; PSWQ = Penn State Worry Questionnaire; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial; SAnD = social anxiety disorder; SWE = Sweden; USA = United States of America.

Table 30 Characteristics of RCTs of Pharmacologic Treatment of Anxiety in Primary Care Patients (KQs 4, 5)

Author, Year | Quality rating | Study design | Study N | Country | Target pop | Population | Anxiety required | Disorders | Screen detected | Followup, wks | Intervention | Benefits | Harms
Lader, 1998^324^ | Fair | RCT | 246 | GBR, FRA | General adults | Primary care patients with GAD and HAM-A score ≥20 | Yes | GAD: 100; PD: NR; SAnD: NR; MDD: 0 | NR | 4 | IG1: Fixed dose of buspirone, 20 mg/day over 4 weeks | | X
Lenox-Smith, 2003 | Fair | RCT | 244 | GBR | General adults | Adult primary care patients with GAD | Yes | GAD: 100; PD: NR; SAnD: NR; MDD: NR | NR | 8, 24 | IG1: 75–150 mg daily venlafaxine XL for 24 weeks | X | X
Lenze, 2009^288^ | Good | RCT | 179 | USA | Older adults | Individuals age ≥60 years with GAD | Yes | GAD: 100; PD: NR; SAnD: NR; MDD: 24.9 | Partial (multiple recruitment streams) | 12 | IG1: 12 weeks of 10 mg escitalopram; increased to 20 mg after 4 weeks if no response | X | X

Abbreviations: FRA = France; GAD = generalized anxiety disorder; GBR = Great Britain; HAM-A = Hamilton Rating Scale for Anxiety; IG1 = intervention group 1; MDD = major depressive disorder; N = number of participants; NR = not reported; PD = panic disorder; RCT = randomized controlled trial; SAnD = social anxiety disorder; USA = United States of America.

Table 31 Characteristics of ESRs of Psychological Treatment of Anxiety (KQ4)

Author, Year | Quality | Outcomes | Specific d/o | Population | Intervention | Last Search Date | Total # of Included Studies | Total N | Included Study Designs | Benefits (KQ4) | Harms (KQ5)
van Dis, 2020^321^ | Good | Anxiety | None | General population | CBT-specific | Jan-2019 | 69 Total; GAD: 14; PD: 13; SAnD: 7 | 4,118 | RCTs | X
Hofmann, 2014^317^ | Good | QoL or functioning | None | General population | CBT-specific | Feb-2013 | 59 trials (published in 44 papers) | 3,326 | NR | X
Gould, 2012^315^ | Good | Depression, Anxiety | None | Older adults | CBT-specific | Nov-2010 | 12 | NR | RCTs | X
Li, 2022^220^ | Good | Depression, Anxiety | None | Perinatal | CBT-specific | Apr-2020 | 77 (68 in MA) | 11,221 | RCTs, QuasiRCT | X
Ponting, 2020^211^ | Good | Depression | None | Perinatal Black and Hispanic/Latino | Psychological | Sep-2018 | 13 (10 RCTs) | 1,971 | RCTs, CCTs | X
Weaver, 2017^215^ | Good | Depression, Anxiety | None | Rural settings | CBT-specific | Apr-2015 | 16 | 1,193 | No restrictions | X
Cuijpers, 2016^313^ | Good | Anxiety | GAD, SAnD, PD | General population | CBT-specific | Aug-2015 | 144 Total (184 comparisons); GAD: 24; PD: 30; SAnD: 36; (Comparisons: 31 for GAD, 42 for PD, and 48 for SAnD) | 11,030 | RCTs | X
Cuijpers, 2016^313^ | Good | Depression | GAD, SAnD, PD | General population | CBT-specific | Aug-2015 | 81 total; GAD: 16; SAnD: 13; PD: 18; MDD: 34 | 5,486 | RCTs | X

Abbreviations: CBT = cognitive behavioral therapy; CBT-specific = cognitive behavioral therapy-specific; CCTs = controlled clinical trials; ESRs = existing systematic reviews; GAD = generalized anxiety disorder; IPD = individual participant data; NR = not reported; MA = meta-analysis; PD = panic disorder; QoL = quality of life; QuasiRCT = quasi-randomized controlled trial; RCTs = randomized controlled trials; SAnD = social anxiety disorder.

Table 32 Characteristics of ESRs of Pharmacologic Treatment of Anxiety (KQs 4, 5)

Author, Year | Quality | Outcomes | Specific d/o | Population | Intervention | Last Search Date | Total # of Included Studies | Total N | Included Study Designs (Note if conducted IPD analysis) | Benefits (KQ4) | Harms (KQ5)
Balasubramaniam, 2019^309^ | Good | Anxiety, Harms | None | Older adults | AD | Oct-2018 | 12 | NR | RCTs | X | X
Bighelli, 2018^310^ | Good | Anxiety, Harms | PD | General population | AD | May-2017 | 47 | 9,377 | RCTs | X | X
Breilmann, 2019^311^ | Good | Anxiety, Harms | PD | General population | BZD | May-2018 | 23 | 4,233 | RCTs | X | X
Chen, 2019^312^ | Good | Anxiety | GAD | General population | Any pharm | Sep-2017 | 91 | 15,596 | RCTs | X
Gupta, 2020^316^ | Good | Anxiety, Harms | None | Older adults | BZD | Aug-2018 | 5 | 553 | RCTs | X | X
Imai, 2014^318^ | Good | Anxiety, Harms | PD | General population | Anxiolytics | Jan-2014 | 3 | 170 | RCTs, Randomized cross-over trials | X | X
Roest, 2015^319^ | Fair | Anxiety | None | General population | 2nd-gen AD | Dec-2012 | 57 | NR | RCTs | X
Slee, 2019^320^ | Good | Anxiety, Harms | GAD | General population | Any pharm | Aug-2017 | 89 | 25,441 | RCTs | X | X
Viswanathan, 2021^232^ | Good | Depression, QoL or functioning, Maternal or fetal, Harms | None | Perinatal | Any pharm | Jun-2020 | 164 | NR | RCTs, Obsrv, CCTs | X | X
Williams, 2017^322^ | Good | Depression, Anxiety, QoL or functioning, Harms | SAnD | General population | Any pharm | Aug-2015 | 66 | 11,597 | RCTs | X | X

Abbreviations: AD = antidepressant; BZD = benzodiazepines; CCTs = controlled clinical trials; ESRs = existing systematic reviews; GAD = generalized anxiety disorder; IPD = individual participant data; NR = not reported; Obsrv = observation; PD = panic disorder; pharm = pharmacotherapy; QoL = quality of life; RCTs = randomized controlled trials; SAnD = social anxiety disorder.

Table 33 Summary of Meta-Analysis Results for Anxiety Outcomes in Primary Research Studies of Psychological Treatment of Anxiety in Primary Care Patients (KQ4)

Outcome | No. studies (n analyzed) | Type of effect | Pooled result (95% CI)^*^ | I^2^, % | Tau^2^ | Range of effects (in native units)^†^ | Median (IQR) effects^†^
Anxiety symptom severity
All studies | 22 (3,943) | SMD | −0.29 (−0.44 to −0.15) | 70.6 | 0.06 | −8.0 to 6.8 | −1.8 (−2.8 to −0.5)
Anxiety required | 10 (2,075) | SMD | −0.41 (−0.58 to −0.23) | 40.2 | 0.02 | −8.0 to 6.8 | −2.3 (−3.0 to −1.4)
Anxiety or depression | 12 (1,868) | SMD | −0.18 (−0.39 to 0.03) | 66.7 | 0.06 | −6.1 to 4.5 | −0.7 (−2.4 to 0.4)
Depression symptom severity
All studies | 22 (3,970) | SMD | −0.32 (−0.46 to −0.19) | 66.4 | 0.05 | −9.0 to 6.3 | −1.50 (−2.6 to 0.01)
Anxiety required | 9 (1,990) | SMD | −0.49 (−0.74 to −0.25) | 68.4 | 0.05 | −9.0 to 6.3 | −2.0 (−2.7 to −1.5)
Anxiety or depression | 13 (1,980) | SMD | −0.20 (−0.34 to −0.06) | 39.9 | 0.02 | −6.5 to 4.4 | −0.7 (−2.4 to 0.01)
Mental Components Score | 7 (2,104) | SMD | 0.17 (−0.03 to 0.36) | 54.4 | 0.02 | −5.4 to 9.8 | 0.4 (−1.3 to 3.5)
Physical Component Score | 5 (1,656) | SMD | 0.03 (−0.12 to 0.18) | 13.0 | 0.0 | −1.5 to 2.2 | 0.3 (−1.5 to 0.6)

* Effect based on restricted maximum likelihood model with the Knapp-Hartung adjustment for small samples.

† Range of effects for all study arms, subgroup analyses, and timepoints (i.e., not limited to records in the meta-analysis).

Abbreviations: CI = confidence interval; IQR = interquartile range; SMD = standardized mean difference.

There were only two RCTs of pharmacotherapy in primary care patients, addressing venlafaxine and escitalopram, and both showed a benefit. Broad ESRs (i.e., not limited to primary care patients) reported improved anxiety and other outcomes for people taking antidepressants and benzodiazepines compared to placebo. For example, among patients with generalized anxiety disorder, the SMD for change in anxiety symptom severity with SSRIs was −0.66 (95% CI, −0.90 to −0.43, 31 studies, N and I^2^ not reported). For antidepressants, benefits were seen for a variety of anxiety outcomes among people with generalized anxiety disorder, social anxiety disorder, and panic disorder. Limited evidence suggested that antidepressants and benzodiazepines may improve anxiety symptoms in older adults, but evidence in perinatal patients was lacking. Improvements were also seen for depression and social functioning outcomes with pharmacotherapy.

#### Psychological Treatment of Anxiety

##### Primary Study Characteristics

We included 24 RCTs (N=5,307) that examined the benefits of psychological interventions to treat anxiety (Table 29),^274,^ ^275,^ ^277,^ ^278,^ ^280,^ ^283–286,^ ^289,^ ^290,^ ^292–299,^ ^302,^ ^304–307^ including ten trials in which all participants had anxiety disorders or symptoms^278,^ ^289,^ ^290,^ ^293,^ ^294,^ ^297,^ ^298,^ ^304,^ ^305,^ ^307^ and 14 studies of participants with either anxiety or depression (i.e., some participants may not have had anxiety).^274,^ ^275,^ ^277,^ ^280,^ ^283–286,^ ^292,^ ^295,^ ^296,^ ^299,^ ^302,^ ^307^ All interventions were either specifically targeted at anxiety, or used flexible treatment approaches that are appropriate for anxiety (e.g., cognitive behavioral techniques, mindfulness, problem solving approaches). Most studies (k=16) were conducted in populations of general adults.^274,^ ^275,^ ^277,^ ^278,^ ^280,^ ^283,^ ^284,^ ^286,^ ^290,^ ^292–296,^ ^299,^ ^304,^ ^305^ The remaining studies were conducted in populations of older adults^285,^ ^297,^ ^298,^ ^302^ or perinatal populations.^274,^ ^306,^ ^307^

Seven of the trials were conducted in the US,^280,^ ^286,^ ^293,^ ^294,^ ^297,^ ^298,^ ^304^ and the remaining were conducted in the UK,^277,^ ^283,^ ^284,^ ^292,^ ^305,^ ^306^ the Netherlands,^274,^ ^295,^ ^296^ Canada,^302,^ ^307^ Sweden,^290,^ ^299^ Germany,^278,^ ^289^ Hong Kong,^285^ and Spain^275^. Most trials (k=18) recruited participants from primary care clinics or other primary care relevant settings; however, two trials recruited from other clinical settings (e.g., multispecialty medical organization, university health center),^298,^ ^302^ and two trials recruited from OB-GYN and midwifery practices.^274,^ ^306^ Thirteen of the trials used screening to identify eligible participants, either entirely^274,^ ^275,^ ^278,^ ^285,^ ^295,^ ^296,^ ^304,^ ^305,^ ^307^ or for a subset of participants.^286,^ ^292,^ ^294,^ ^307^ Only four of the trials limited to people with anxiety used screening for participant recruitment.^278,^ ^294,^ ^305,^ ^306^

Seven trials were rated as good quality,^280,^ ^290,^ ^293,^ ^294,^ ^298,^ ^304,^ ^306^ and the remaining were rated as fair quality. Common reasons for downgrading included baseline differences between treatment groups that were not statistically controlled for in analyses, excessive or differential loss to followup between groups, or inadequate methods for handling missing data.

Sociodemographic information about the included RCTs is presented in Appendix F Table 6 and summarized in Table 34. Across all studies, the mean age was 45.4 years, and 74.5 percent of participants were women. Among the six trials conducted in the US and reporting on race and ethnicity,^280,^ ^286,^ ^293,^ ^294,^ ^297,^ ^298^ the majority (68.5 percent) of participants were White, 16.3 percent were Hispanic/Latino, 15.3 percent were Black, 1.5 percent were Asian American or Pacific Islander and less than one percent were Native American or Alaska Native. In studies that reported race and ethnicity data, the percentage of White participants ranged from 56.6 to 81.8 percent. None of the studies appeared to target sub-populations with significant socioeconomic challenges (e.g., low income or homelessness).

Table 34 Summary of Participant Demographic Characteristics in Primary Studies of Psychological Treatment of Anxiety in Primary Care Patients (KQ4); Weighted Mean (Number of Studies Reporting), Unless Otherwise Indicated

Population | No. of studies (No. US-based studies) | Total N | Mean age | % Women^*^ | Race or ethnicity (US-based studies only), % | Race or ethnicity, range of % of participants among US-based studies
All | 24 (7) | 5,208 | 45.4 (24) | 74.5 (24) | Black: 15.3 (6); Asian-Amer/PI: 1.50 (3); Native Amer/AN: 0.64 (2); Hispanic/Latino: 16.3 (5); White: 68.5 (6) | Black: 8 to 32; Asian-Amer/PI: 1 to 2.2; Native Amer/AN: 0.4 to 1; Hispanic/Latino: 7 to 24; White: 56.6 to 81.8
Older | 4 (2) | 717 | 69.1 (4) | 61.9 (4) | Black: 18.2 (2); Asian-Amer/PI: 1.7 (2); Native Amer/AN: 0.4 (1); Hispanic/Latino: 9.82 (2); White: 75.6 (2) | Black: 17.9 to 18.7; Asian-Amer/PI: 1.4 to 2.2; Native Amer/AN: 0.4 to 0.4; Hispanic/Latino: 8.2 to 10.8; White: 70.2 to 78.9
Perinatal | 3 (0) | 459 | 32.2 (3) | 100 (0) | NA | NA

* Gender was not reported in studies of perinatal patients so participants are counted as women, recognizing that there may be some individuals who do not identify as women; non-binary/gender non-conforming categories were not reported in any studies.

Abbreviations: Asian-Amer/PI = Asian American/Pacific Islander; N = number of participants; Native Am/AN = Native American/Alaska Native; NR = not reported; US = United States.

Intervention characteristics of the RCTs are summarized in Table 35 and detailed in Appendix F Table 7. The most commonly utilized intervention approach was cognitive behavior therapy (CBT), with or without a support group, which was used in eighteen studies.^274,^ ^275,^ ^277,^ ^278,^ ^280,^ ^284,^ ^289,^ ^290,^ ^292–295,^ ^297,^ ^298,^ ^304–307^ Common components of CBT-based interventions included psychoeducation, goal-setting, cognitive restructuring, behavioral activation, self-monitoring, and problem solving. Few studies involved primary care providers in the delivery of the intervention. However, one study intervention (Coordinated Anxiety Learning and Management, or CALM) allowed participants to choose CBT, medication, or both and was delivered by nonexpert care managers who also assisted primary care clinicians in promoting medication adherence.^294^ Another CBT intervention had the primary care provider delivering most or all of the intervention content, which included four individual sessions delivered in person, along with printed companion materials.^278^ The most intensive CBT intervention involved up to 14 weekly 90-minute in-person manualized CBT sessions followed by 3 monthly booster sessions.^305^ The least intensive CBT intervention was a 22-session app-based intervention totaling 50 minutes of therapist phone contact over an 8-week period. The intervention was delivered via a combination of web, email, text, and phone contacts.^280^ Less commonly utilized intervention approaches included problem-solving therapy (alone or with case management),^283,^ ^285,^ ^286,^ ^296^ mindfulness-based approaches,^299,^ ^302^ or non-directive therapy.^284^ Most studies used usual care as the control condition, however some studies utilized waitlist, attention, or minimal treatment controls.

Table 35 Summary of Intervention Components in Primary Research Studies of Psychological Treatment of Anxiety in Primary Care Patients (KQ4)

Anxiety required | Author, Year | IG | Duration, wks | Therapeutic approach | Est contact hrs | Delivery | PC Team role | Control
Yes | Clark, 2022^305^ | IG1 | 14 | CBT | 25.5 | In-person | None | Waitlist
Yes | Clark, 2022^305^ | IG2 | 14 | CBT | NA | Phone, Web, Email or Text | None | Waitlist
Yes | Gensichen, 2019^278^ | IG1 | 23 | CBT | 2 | In-person, Print | Most/all | Usual care
Yes | Linden, 2005^289^ | IG1 | 14 | CBT | 5.8 | In-person | None | Waitlist
Yes | Nordgren, 2014^290^ | IG1 | 10 | CBT | NA | Web, Virtual | None | Attention Control
Yes | O’Mahen, 2022^306^ | IG1 | 10 | CBT | 4.5 | In-person | None | Usual specialty mental health care
Yes | Rollman, 2018^293^ | IG1 | 26 | CBT | 10.8 | Phone, Web, Email or Text | None | Usual care
Yes | Rollman, 2018^293^ | IG2 | 26 | CBT, Support group | 10.8 | Phone, Web, Email or Text | None | Usual care
Yes | Roy-Byrne, 2010^294^ | IG1 | 11 | CBT | NR | In-person | None | Usual care
Yes | Stanley, 2009^298^ | IG1 | 12 | CBT | 5.3 | In-person, Phone | None | Minimal
Yes | Stanley, 2014^297^ | IG1 | 26 | CBT | 5 | In-person, Phone | None | Usual care
Yes | Vera, 2021^304^ | IG1 | 16 | CBT | 22.5 | In-person | None | Usual care
No | Burger, 2020^274^ | IG1 | 33 | CBT | NR | In-person | None | Usual care
No | Corpas, 2021^275^ | IG1 | 8 | CBT | 8 | In-person | None | Usual care
No | Fletcher, 2005^277^ | IG1 | 12 | CBT | NA | Print | None | Waitlist
No | Graham, 2020^280^ | IG1 | 8 | CBT | 0.8 | Phone, Web, Email or Text | None | Waitlist
No | Kendrick, 2005^283^ | IG1 | 8 | Problem-Solving Therapy | 3.5 | In-person | None | Usual care
No | Kendrick, 2005^283^ | IG2 | 8 | NR | 3.5 | In-person | None | Usual care
No | King, 2000^284^ | IG1 | NR | CBT | 5 | In-person | None | Usual care
No | King, 2000^284^ | IG2 | NR | Non-directive | 5 | In-person | Some | Usual care
No | Lam, 2010^285^ | IG1 | 5 | Problem-Solving Therapy | 1.5 | In-person | None | Minimal
No | Lang, 2006^286^ | IG1 | NR | Problem-Solving Therapy | 3 | In-person, Phone | None | Usual care
No | Proudfoot, 2004^292^ | IG1 | 9 | CBT | 6.9 | Web | None | Usual care
No | Schreuders, 2007^295^ | IG1 | NR | CBT | 3 | Web | None | Usual care
No | Seekles, 2011^296^ | IG1 | 8 | Problem-Solving Therapy, Case Mgmt | NR | In-person, Web, Email or Text | None | Usual care
No | Suchan, 2022^307^ | IG1 | 8 | CBT | NR | Phone, Web, Email or Text | None | Usual care
No | Sundquist, 2015^299^ | IG1 | 8 | Mindful | 16 | In-person | None | Usual care
No | Torres-Platas, 2019^302^ | IG1 | 8 | Mindful | 16 | In-person | None | Usual care

Abbreviations: CBT = cognitive behavioral therapy; Est = estimated; IG = intervention group; IG1 = intervention group 1; IG2 = intervention group 2; Mgmt = management; NA = not applicable; NR = not reported; PC = primary care.

##### ESR Characteristics

In addition to trial evidence, we included eight ESRs that addressed psychological treatment of anxiety (Table 31, Appendix F Table 8).^211,^ ^215,^ ^220,^ ^313–315,^ ^317,^ ^321^ We focused on results reflecting the impact on health outcomes in general populations or in a priori populations of interest, with minimal examination of effect modification by study or intervention characteristics. Four of the reviews include studies in general adult populations,^313,^ ^314,^ ^317,^ ^321^ while the other reviews limited their focus to older adults,^315^ general perinatal population,^323^ Black and Hispanic/Latino perinatal population,^211^ and rural populations.^215^ All reviews included studies that addressed generalized anxiety disorder, panic disorder, and social anxiety disorder. Some reviews covered additional anxiety disorders as well, but we did not include results that were specific to disorders outside of our scope (e.g., OCD, PTSD). The largest review included 144 studies, of which 90 were specifically targeted at generalized anxiety disorder, panic disorder, and social anxiety disorder.^313^

#### Results (Primary and ESR Evidence)

Detailed results for all outcomes are reported in Appendix F.

##### Anxiety Outcomes

Twenty-two of the RCTs among primary care patients reported on anxiety symptoms and could be included in the meta-analysis, ranging from 8 to 30 weeks’ followup.^274,^ ^275,^ ^277,^ ^278,^ ^280,^ ^285,^ ^286,^ ^289,^ ^290,^ ^292–299,^ ^302,^ ^304–307^ The overall pooled effect size for all twenty-two studies was statistically significant, in favor of the intervention groups (SMD, −0.29 [95% CI, −0.44 to −0.15]; 22 RCTs [n=3,943]; I^2^=70.6%, Figure 28, Table 33). However, the pooled effect size for the twelve studies that included participants with or without anxiety was not statistically significant (SMD, −0.18 [95% CI, −0.39 to 0.03]; 12 RCTs [n=1,868]; I^2^=66.7%), whereas the pooled effect size for the ten studies which required participants to have anxiety was statistically significant (SMD, −0.41 [95% CI, −0.58 to −0.23]; 10 RCTs [n=2,075]; I^2^=40.2%). One RCT also reported on disorder-specific outcome measures for subgroups with specific anxiety disorder diagnoses.^294^ In all cases, disorder-specific outcomes showed statistically significant improvement at 6 and 12-month followup (Appendix F Table 9).

One of the included RCTs offered primary care patients with panic disorder, social anxiety disorder, generalized anxiety disorder, or PTSD the choice between medication, CBT, or both in comparison to usual care.^294^ First choice medications included SSRIs or SNRIs but could be augmented by another antidepressant or a benzodiazepine for non-refractory patients. While the intervention participants demonstrated greater improvements on a number of outcomes, the study did not report results separately for participants who chose medication (with or without CBT) as part of their treatment. Therefore, this study was unable to determine which specific components of the blended intervention contributed to the results.^294^

Other less commonly reported anxiety related outcomes in the RCTs included anxiety response^278,^ ^297,^ ^298^ and anxiety remission,^278,^ ^280^ variously defined. Both studies addressing remission found greater likelihood of remission for at least one outcome among those in the intervention group, but most findings for treatment response did not demonstrate a benefit (Appendix F Table 10).^278,^ ^280^

Among the ESRs, most effect sizes at the end of treatment were in the moderate to large range. For example, the broadest analyses showed clear benefits of CBT at the post-treatment assessment for generalized anxiety disorder (SMD, −0.80 [95% CI, −0.93 to −0.67]; 31 studies), social anxiety disorder (SMD, −0.88 [95% CI, −1.03 to −0.74]; 48 studies),^313^ and panic disorder (SMD, −0.81 [95% CI, −1.04 to −0.59]; 42 studies, N and I^2^ not reported, Figure 29, Appendix F Table 11). Similar benefits were seen for perinatal women. Effect sizes tended to be smaller and based on fewer studies at followup beyond the post-treatment assessment. For older adult evidence was more sparse, effect sizes had wide confidence intervals, and were frequently not statistically significant, although SMDs were all −0.20 or larger, in the direction of benefit.

##### Other Mental Health Outcomes, Quality of Life, and Functioning

Twenty-two of the RCTs among primary care patients reported on depression symptoms ranging from 8 to 30 weeks’ followup.^274,^ ^275,^ ^277,^ ^278,^ ^280,^ ^284–286,^ ^290,^ ^292–299,^ ^302,^ ^304–307^ The overall pooled effect size for all nineteen studies was statistically significant (SMD, −0.32 [95% CI, −0.46 to −0.19]; 22 RCTs [n=3,970]; I^2^=66.4%, Figure 30, Table 33, Appendix F Table 12), in favor of the intervention groups. The pooled effect was statistically significant both in the studies limited to people with anxiety (SMD, −0.49 [95% CI, −0.74 to −0.25]; 9 RCTs [n=1,990]; I^2^=68.4%) and in mixed populations with anxiety or depression (SMD, −0.20 [95% CI, −0.34 to −0.06]; 13 RCTs [n=1,980]; I^2^=39.9%; p=0.01 for the difference in effect size between studies requiring anxiety vs. those in mixed populations).

Figure 30 Forest Plot Showing the Difference Between Groups in Change From Baseline in Depression Symptoms, for Primary Studies of Psychological Intervention for Treatment of Anxiety in Primary Care Populations (KQ4)

Abbreviations: BDI = Beck Depression Inventory; BSI = Brief Symptom Inventory; CBT = cognitive behavioral therapy; CG = control group; EPDS = Edinburgh Postnatal Depression Scale; GAD = Generalized Anxiety Disorder; HADS-D = Hospital Anxiety and Depression Scale – Depression; IDS = Inventory of Depressive Symptomatology; IG = intervention group; MBT = mindfulness-based therapy; p26 = Assessment at 26 weeks postpartum; PHQ = Patient Health Questionnaire; PROMIS – Depression = Patient-Reported Outcomes Measurement Information System – Depression; PST = problem solving therapy; SCL-D6 = Symptom Checklist – Core Depression; SD = standard deviation; SMD = standardized mean difference.

This figure shows a forest plot showing the difference between groups in change from baseline in depression symptoms, for primary studies of psychological intervention for treatment of anxiety in primary care populations (key question 4).

Only one RCT among primary care patients reported depression remission outcomes; that trial included people with anxiety or depression. Graham and colleagues (2020) defined treatment remission as PHQ-9 scores less than 5 or a 50 percent reduction from baseline.^280^ The rate of recovery from depression was 59.4 percent in the app-based CBT intervention group and 31.0 percent in the wait list control group. The odds of recovery for depression were 3.25 (95% CI, 1.54 to 6.86) times greater for intervention participants compared with the control group.^280^

Ten RCTs among primary care patients reported on quality-of-life outcomes ranging from 8 to 30 weeks’ followup.^285,^ ^286,^ ^290,^ ^293–295,^ ^297,^ ^298,^ ^302,^ ^306^ Few individual study findings were statistically significant, and the pooled effect sizes were small and not statistically significant for both the Mental Health Component scale of the SF-12 or SF-36 (SMD, 0.17 [95% CI, −0.03 to 0.38]; 7 RCTs [n=2,104]; I^2^=54.4%) and the Physical Component Scale (SMD, 0.03 [95% CI, −0.12 to 0.18]; 5 RCTs [n=1,656]; I^2^=54.4; Figure 31). Other health outcomes reported included global mental health symptoms,^277,^ ^283,^ ^284,^ ^290^ general functioning,^283,^ ^284,^ ^292,^ ^294^ infant outcomes (e.g., birth weight, gestational age, and Apgar scores),^274^ and emergency room visits and hospitalizations,^293^ and parenting adjustment.^306,^ ^307^ Very few individual findings for any of these outcomes showed statistically significant group differences (Appendix F Tables 12–15).

Figure 31 Forest Plot Showing the Difference Between Groups in Change From Baseline in Quality of Life Measures, for Primary Studies of Psychological Intervention for Treatment of Anxiety in Primary Care Populations (KQ4)^*^ * For the EQ-5D, a higher score indicates a worse outcome (unlike all other QoL outcomes shown), so the effect for EQ-5D is in the direction of benefit.

Abbreviations: CBT = cognitive behavioral therapy; CG = control group; EQ-5D = EuroQol-5D; GAD = generalized anxiety disorder; QOLI = Quality of Life Inventory; MBT mindfulness-based therapy; MCS = Mental Component Score; SF = Short Form; PCS = Physical Component Score; PST = problem solving therapy.

This figure is a forest plot showing the difference between groups in change from baseline in quality of life measures, for primary studies of psychological intervention for treatment of anxiety in primary care populations.

Among the included ESRs (which were not limited to primary care patients), one reported improvement in quality of life with CBT treatment for anxiety (SMD, −0.56 [95% CI, −0.80 to −0.32, 21 RCTs, N and I^2^ not reported, Figure 32, Appendix F Table 16).^317^ Another review found that depression symptoms were improved with CBT among people with generalized anxiety disorder, panic disorder, and social anxiety disorder; these findings held up even when limited to studies rated as having a low risk of bias (Figure 32, Appendix F Table 16).^314^

Figure 32 Forest Plot of Standardized Mean Differences Between Groups in Other Outcomes for Psychological Treatment of Anxiety Compared to Controls (KQ4)^*^ * For the EQ-5D, a higher score indicates a worse outcome (unlike all other QoL outcomes shown), so the effect for EQ-5D is in the direction of benefit.

Abbreviations: CBT = cognitive behavioral therapy; GAD = generalized anxiety disorder; QoL = Quality of Life; NR = not reported; PD = panic disorder; SaND = social anxiety disorder; SMD = standardized mean difference.

This figure is a forest plot of standardized mean differences between groups in other outcomes for psychological treatment of anxiety compared to controls.

##### Effect Modification and Findings in Specific Populations

One of the primary RCTs by Rollman and colleagues (2018) reported subgroup analyses by age, gender, race (White vs. other race and ethnic groups), level of education, baseline GAD-7 and PHQ scores, and whether or not the participant lived alone.^293^ They reported better improvements in persons age 35–59 years relative to younger and older age groups on anxiety (p=.006), depression (p=.033), and global mental health (p=.01). Participants who were not White (88% of whom were Black) reported greater improvements in depression (p=.024) than White participants, and the effect was similar but not statistically significant for anxiety (p=.08). Persons who lived alone also showed greater improvements in depression (p=.008) and anxiety (p=.01). None of the other subgroup analyses resulted in statistically significant differences, although level of education approached significance (Appendix F Table 9).

We stratified forest plots of anxiety symptom severity from the primary RCTs among primary care patients by population (i.e., general adult, older adult, and perinatal), whether participants were recruited via screening, and several intervention characteristics (e.g., intervention type, modality, and total contact time) to determine other factors that may modify treatment effects. We combined all studies for these analyses, both those in which all participants had anxiety and those in mixed populations. None of these factors showed as strong an association with effect size as whether the population was limited to people with anxiety compared to mixed populations (Figure 33). However, given the limited number of studies and the many sources of variability, we have limited confidence in whether these analyses could clarify sources of effect modification. ^278,^ ^304^

Figure 33 Stratified Analyses Examining Effect Modification for Anxiety Symptom Severity in Primary Studies of Anxiety Treatment Among Primary Care Patients (KQ4)

Abbreviations: CBT = cognitive behavioral therapy; CI = confidence interval; NA = not applicable; SMD = standardized mean difference.

This figure is a forest plot of stratified analyses examining effect modification for anxiety symptom severity in primary studies of anxiety treatment among primary care patients.

#### Pharmacologic Treatment of Anxiety

##### Primary Study Characteristics

Two RCTs (N=423) among primary care patients examined the benefits of pharmacological interventions to treat anxiety (Tables 30 and 36).^287,^ ^288^ Both studies were rated as good quality. Mean age across the two studies was 57.5 and 60.0 percent of the participants were women. Only one study reported race or ethnicity data and participants were 82.5 percent White.^288^ The first trial (N=244; UK) assessed the efficacy of venlafaxine XL (an SNRI) in participants with generalized anxiety disorder (with and without co-morbid depression) over a 24-week period.^287^ Participants were recruited from primary care settings, were over 18 years old, met DSM-IV criteria for generalized anxiety disorder, and had a score of 20 or more on the HAM-A and a score of 23 or less on the MADRS. Participants were randomized to receive 75 mg of venlafaxine or matched placebo. After 2 weeks, the dose could be doubled if initial response was poor. The second trial (N=179; US) assessed the efficacy of escitalopram (an SSRI) in older adults with generalized anxiety disorder over a 12-week period.^288^ Participants were recruited from primary care and specialty medical care (e.g., arthritis, geriatric medicine) clinics, were over 60 years old, and had a primary diagnosis of generalized anxiety disorder (defined as a score of 17 or more on the HAM-A). Participants were randomized to receive 10–20 mg of escitalopram or matched placebo.

Table 36 Participant Characteristics of Primary Research Studies of Pharmacologic Treatment of Anxiety in Primary Care Patients (KQ4)

Author, Year | Mean Age (Range), years | % Women^*^ | Education | Other SES | Race or Ethnicity | BL MH status
Lenox-Smith, 2003^287^ | 47 (19–79) | 59.0 | High school grad: NR; College grad: NR | Employed: NR; Single: NR; Other SES: NR | Black: NR; Hispanic/Latino: NR; Asian/AA: NR; Native Am/AN: NR; White: NR | NR
Lenze, 2009^288^ | 71.7 (60+) | 61.3 | High school grad: NR; College grad: NR | Employed: NR; Single: NR; Other SES: Edu (yrs, mean): 13.9 | Black: NR; Hispanic/Latino: NR; Asian/AA: NR; Native Am/AN: NR; White: 82.5 | MDD: 24.9%; GAD: 100%; Exception: 14.7%; Benzodiazepine: 0%

* Gender was not reported in studies of perinatal patients so participants are counted as women, recognizing that there may be some individuals who do not identify as women; non-binary/gender non-conforming categories were not reported in any studies.

Abbreviations: Asian/AA = Asian/Asian American; BL MH = baseline mental health; Edu = education; GAD = generalized anxiety disorder; MDD = major depressive disorder; Native Am/AN = Native American/Alaska Native; NR = not reported; SES = socioeconomic status.

##### ESR Characteristics

We also included ten ESRs of pharmacologic treatment of anxiety (Table 32, Appendix F Table 17), covering antidepressants, benzodiazepines, and buspirone.^232,^ ^309–312,^ ^316,^ ^318–320,^ ^322^ Two reviews focused on trials in older adults^309,^ ^316^ and one focused on perinatal populations.^232^ Four of the reviews were not limited to a specific anxiety disorder,^232,^ ^309,^ ^316,^ ^319^ two focused on generalized anxiety disorder,^312,^ ^320^ three focused on panic disorder,^310,^ ^311,^ ^318^ and one focused on social anxiety disorder.^322^ We could not determine the total number of included studies across all included reviews, but estimate that at least 227 RCTs (N approximately 40,000) were included.

All but one^319^ of the included ESRs was rated good quality. The review rated as fair was downgraded because it lacked risk of bias assessment for included studies, however the focus of this review was on publication bias, and we felt risk of bias assessment was not central to this analysis. In this review, which addressed second generation antidepressants, the reviewers downloaded packets from the FDA website and submitted freedom of information requests for medications without packets. FDA information was compared with published studies to examine reporting bias, which was classified as study publication bias, outcome reporting bias, or spin. Four additional ESRs reported at least some efforts to include unpublished evidence.^232,^ ^311,^ ^318,^ ^322^

##### Results

Detailed results for all outcomes are reported in Appendix F.

###### Primary Study Results

Anxiety and general mental health outcomes. In the trial of venlafaxine among primary care patients, participants taking venlafaxine showed greater improvement in the primary outcome of anxiety symptoms at 24 weeks followup, compared to placebo (mean difference at followup, −2.1 [95% CI, −4.2 to 0]; p = 0.05, Appendix F Table 18).^287^ Similar findings were observed for secondary outcomes of global mental health symptom score and the Mental Health subscale of the SF-36. Group differences were not statistically significant for treatment response, remission, or depression symptoms, although all of these trended in the direction of benefit for venlafaxine.^287^

In the RCT of escitalopram, which was limited to older adults, more participants taking escitalopram met the criteria for a treatment response than those taking a placebo (OR, 1.87 [95% CI, 1.03 to 3.39]; 60% taking escitalopram compared to 45% taking a placebo, p = 0.05, Appendix F Table 18).^288^ Treatment response was defined as a clinician rating of improved or very much improved. Participants taking escitalopram also showed greater reduction in global mental health symptoms and anxiety symptoms, but the finding for anxiety symptoms was not statistically significant (p=.06).^288^

###### ESR Results

Anxiety outcomes. The continuous outcome of anxiety symptom improvement was reported on for people with generalized anxiety disorder and panic disorder in general adult populations. (Figure 34, Appendix F Table 19). For generalized anxiety disorder, SMDs in anxiety symptoms scores ranged from −0.23 for serotonin modulators (95% CI, −0.53 to 0.06; 8 RCTs, N=1801; I^2^ not reported) to −1.84 for bupropion (95% CI, −3.05 to −0.62; 1 RCT, N=11; I^2^ not applicable).^312^ All but one of the seven effects were statistically significant with most in the medium to large effect size range. The effect for SSRIs was in the medium range, with the confidence intervals indicating a clearly statistically significant effect (SMD, −0.66 [95% CI, −0.90 to −0.43; 23 RCTs, N=2142; I^2^ not reported).^312^

Figure 34 Forest Plot of Standardized Mean Differences Between Groups in Anxiety Symptom Severity for Pharmacologic Treatment of Anxiety Compared to Controls (KQ4)

Abbreviations: CI = confidence interval; GAD = generalized anxiety disorder; PD = panic disorder; SMD = standardized mean difference; SNRI = Serotonin and norepinephrine reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor.

This figure is a forest plot of standardized mean differences between groups in anxiety symptom severity for pharmacologic treatment of anxiety compared to controls.

Improvements in anxiety symptoms were also reported in three reviews addressing panic disorder, with the use of antidepressants,^310^ buspirone,^318^ and benzodiazepines.^311^ Antidepressant use was associated with improved anxiety symptoms broadly, panic symptoms, number of panic attacks, and agoraphobia symptoms.^310^ SMDs ranged from −0.33 (95% CI, −0.47 to −0.20; 12 RCTs, N=2,477; I^2^, 57%) for mean change in anxiety symptoms broadly to −0.69 (95% CI, −0.99 to −0.39; 13 RCTs, N=2,987; I^2^, 91%) for endpoint agoraphobia scores. SSRIs showed a statistically significant benefit for all of these outcomes except for one agoraphobia outcome. TCAs showed a benefit for all but one agoraphobia and one broad anxiety symptom outcome.^310^ Benzodiazepines were associated with improvements in panic symptoms and agoraphobia (range of effects: SMD, −0.35 [95% CI, −0.50 to −0.20; 13 RCTs, N=2,371; I^2^, 58% to −0.92 [95% CI, −1.22 to −0.61; 7 RCTs, N=1,489, I^2^, 77%).^311^ However, buspirone had no impact on symptoms of agoraphobia in one small RCT (SMD, −0.01 [95% CI, −0.56 to 0.53; N=52).^318^

Two reviews reported on remission, for antidepressants^310^ and benzodiazepines, both limited to studies among people with panic disorder (Appendix F Table 20).^311^ Both types of medication demonstrated a benefit at followup of up to 28 weeks. Antidepressants demonstrated a benefit; they were associated with a 17 percent lower likelihood of failure to remit (RR, 0.83 [95% CI, 0.78 to 0.88]; 24 RCTs, N=6,164; I^2^=40%; 51% taking antidepressants vs. 60% taking placebo had not remitted at post-treatment).^310^ Benzodiazepines also demonstrated a benefit; they were associated with a 61 percent higher likelihood of remission (RR, 1.61 [95% CI, 1.38 to 1.88]; 15 RCTs, N=2,907; I^2^=62%; 63% taking benzodiazepines vs. 40% taking placebo were in remission at post-treatment).^311^ Remission was not reported for any other type of anxiety disorder.

Three reviews reported on response to treatment, for people with social anxiety disorder^322^ and panic disorder (Figure 35, Appendix F Table 21).^310,^ ^311^ The largest body of evidence for social anxiety disorder was for SSRIs, which were associated with a 65 percent increase in the likelihood of treatment response. (RR, 1.65 [95% CI, 1.48 to 1.85]; 24 RCTs, N=4,984; I^2^=50%; 54% taking SSRIs vs. 32% taking placebo met study criteria for responding to treatment).^322^ For panic disorder, both antidepressants and benzodiazepines demonstrated an increased likelihood of response. Antidepressants were associated with a 28 percent reduced likelihood of failure to respond (RR, 0.72 [95% CI, 0.66 to 0.79]; 31 RCTs, N=6,500; I^2^=67%; 40% taking antidepressants, 56% taking placebo had not responded at post-treatment, not shown in the figure because it reported the inverse of all other reviews).^310^ Benzodiazepines were associated with a 65 percent increased likelihood of response (RR, 1.65 [95% CI, 1.39 to 1.96]; 16 RCTs, N=2,476; I^2^=67%; 65% taking benzodiazepines, 41% taking placebo were in remission at post-treatment).^311^ For benzodiazepines, effect sizes were of similar magnitude and statistically significant when studies were excluded from the analyses that (a) had attrition higher than 20 percent, (b) were limited to patients with comorbidities, (c) were industry-funded, and (d) were not industry funded.^311^

Figure 35 Forest Plot of Odds Ratios for Group Differences in the Odds of Treatment Response With Pharmacological Treatment of Anxiety Compared to Placebo (KQ4)

Abbreviations: CI = confidence interval; GAD = generalized anxiety disorder; MDD = major depressive disorder; PD = panic disorder; RoB = risk of bias; RR = relative risk; SaND = social anxiety disorder; SNRI = Serotonin and norepinephrine reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor.

This figures is a forest plot of odds ratios for group differences in the odds of treatment response with pharmacological treatment of anxiety compared to placebo.

Other outcomes. Reviews of RCTs among people with panic disorder and social anxiety disorder found improvements in other important outcomes (Figure 36, Appendix F Table 22). Reviews among people with panic disorder found statistically significant improvements in depression and social functioning with antidepressant^310^ and benzodiazepine^311^ use, but the effect was small and not statistically significant for quality of life with antidepressant use.^310^ For example, the standardized effect size for endpoint depression symptom score was −0.41 for antidepressants after 8 to 28 weeks (95% CI, −0.57 to −0.25; 12 RCTs, N=1,794; I^2^, 43%)^310^ and −0.70 for benzodiazepines after 3 to 15 weeks (95% CI, −1.08 to −0.32; 8 RCTs, N=968; I^2^, 78%).^311^ One RCT of buspirone did not demonstrate an impact on depression for people with panic disorder.^318^ For social anxiety disorder, SSRIs showed a benefit for depression, social functioning, family functioning, and work functioning, and benzodiazepines improved social and work functioning.^322^

Figure 36 Forest Plot of Groups in Other Outcomes for Pharmacologic Treatment of Anxiety Compared to Placebo (KQ4)

Abbreviations: CG = control group; CI = confidence interval; ES = effect size; HAMD = Hamilton Rating Scale for Depression; IG = intervention group; MD = mean difference; MDD = major depressive disorder; PD = panic disorder; QoL = quality of life; SaND = social anxiety disorder; SNRI = Serotonin and norepinephrine reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor.

This figure is a forest plot of groups in other outcomes for pharmacologic treatment of anxiety compared to placebo.

Effect modification and findings in specific populations. In addition to effect modification findings described above for specific outcomes, one review examined publication and reporting bias for second generation antidepressants, addressing any anxiety disorder.^319^ Among the 57 trials identified, the FDA interpreted 41 of the 57 trials (72%) to have positive results. However, 43 of the 45 published article conclusions (96%) were positive (P < .001). Trials that the FDA determined to be positive were five times more likely to be published compared with trials that were not positive (risk ratio, 5.20; 95% CI, 1.87 to 14.45; P < .001). The reviewers found evidence for study publication bias (P < .001), outcome reporting bias (P = .02), and spin (P = .02). The pooled effect size based on the published literature (Hedges’ g, 0.38; 95% CI, 0.33 to 0.42; P < .001) was 15% higher than the effect size based on the FDA data (Hedges’ g, 0.33; 95% CI, 0.29 to 0.38; P < .001), but this difference was not statistically significant (β = 0.04; 95% CI, −0.02 to 0.10; P = .18); the effect size adjusted for publication bias was statistically significant (Appendix F Table 23).

Two narrative systematic reviews focused on trials of older adults, and found more limited evidence that antidepressants and benzodiazepines improved anxiety symptoms among older adults (Appendix F Table 23).^309,^ ^316^ One review found seven placebo or waitlist-controlled RCTs, most limited to patients with generalized anxiety disorder, and reported that antidepressants were associated with reduced anxiety symptoms after 8 to 15 weeks of treatment.^309^ Similarly, in three of four placebo-controlled trials limited to older adults with generalized anxiety disorder, panic disorder, or any anxiety disorder, benzodiazepines were associated with decreased anxiety during the 4- to 8-week study period (p<.05).^316^ Another review that addressed pharmacologic treatment of mental health disorders in perinatal patients found no studies of pharmacologic treatment (benzodiazepines or other anxiolytics) for anxiety among perinatal patients (Appendix F Table 23).^232^

### KQ5. What Are the Harms of Treatment of Anxiety (Psychotherapy or Pharmacotherapy) in Adults, Including Pregnant and Postpartum Persons?

#### Summary

None of the RCTs or ESRs of psychological treatment reported on adverse events, but there was no pattern of effects indicating an elevated risk of harm. For the harms of pharmacologic treatment, we included three RCTs (Table 30)^287,^ ^288,^ ^324^ and eight ESRs addressing medications other than antidepressants, which were addressed above under depression (Table 32).^232,309–311,^ ^316,^ ^318,^ ^320,^ ^322^ Evidence indicated an increase in non-serious harms as measured by a higher percent of participants experiencing any adverse events or withdrawals due to adverse events if they were taking medication (vs. placebo). Serious adverse events were rare, and data were insufficient to determine whether the risk of serious harms was increased. Case-control studies found an association between benzodiazepine use and suicide death^325^ and spontaneous abortion.^326^ However, the inability to fully match cases and controls on severity of mental health symptoms and other health behaviors such as substance use limited our confidence in the causal nature of these associations.

#### Psychological Treatment of Anxiety

None of the included RCTs or ESRs of psychological treatment of anxiety reported on harms.

#### Pharmacologic Treatment of Anxiety

Three primary RCTs of medication use among primary care patients reported on adverse events (n=669, Tables 29 and 37). These included both RCTs described under KQ4 of venlafaxine^287^ and escitalopram^288^ as well as an RCT of buspirone that was not included for KQ4 because it had only 4 weeks of followup.^324^ All three medications were associated with statistically non-significant increases in the experience of any adverse effects (Table 37, Appendix F Table 24). Serious adverse effects were rare. In the trial of venlafaxine, four participants (3.3%) taking venlafaxine experienced serious adverse events compared with five (4.1%) who were taking placebo (RR, 0.79 [95% CI, 0.21 to 3.03], n=244).^287^ No participants experienced serious adverse events in the RCTs of either buspirone after 4 weeks or escitalopram after 12 weeks.^288^ Escitalopram had the greatest between-group difference in experiencing any adverse events (RR, 1.82 [95% CI, 0.94 to 3.51), N=177, 76% taking escitalpram vs 64% taking placebo). Among non-serious harms that were increased with escitalopram use were fatigue or somnolence (p<.001, 41% vs 11%) and urinary symptoms (p=.002, 9% vs 0%), but aches were higher in the placebo group (p=.05, 15% vs 6%).

Table 37 Adverse Outcomes Reported in Primary Research Studies of Pharmacologic Treatment of Anxiety in Primary Care Patients (KQ5)

Author, Year | Medication | Serious Adverse Events, N (%) | | Any Adverse Events, N (%) | | Dropout Due to Adverse Events, N (%) | | Most Common Nonserious AEs
- | - | Medication | Placebo | Medication | Placebo | Medication | Placebo | -
Lenze, 2009^288^ | Escitalopram | 0 | 0 | 65 (76) | 59 (64) | 3 (4) | 4 (4) | Fatigue or somnolence, sleep disturbance, urinary sx
Lenox-Smith, 2003^287^ | Venlafaxine XL | 4 (3.3) | 5 (4.1) | 112 (92) | 110 (90) | NR | NR | NR
Lader, 1998 324 | Buspirone | 0 | 0 | 31 (38) | 23 (28) | NR | NR | Headache, dizziness

Abbreviations: AEs = adverse events; N = number of participants; NR = not reported; sx = symptoms; XL = extended release.

Eight ESRs reported on harms or dropout for any reason (Table 38).^232,^ ^309–311,^ ^316,^ ^318,^ ^320,^ ^322^ Detailed results for all outcomes are shown in Appendix F Table 25. Dropout due to adverse events was increased with the use of antidepressants (for panic disorder),^310^ SSRIs and SNRIs (for social anxiety disorder),^322^ and benzodiazepines (for panic disorder)^311^ (Figure 37). In addition, persons with panic disorder were slightly more likely to experience any adverse events when taking antidepressants, compared to placebo (RR, 1.11 [95% CI, 1.07 to 1.15); 16 RCTs, N=4,246; I^2^, 0%).^310^ The most common non-serious harms reported by older patients with anxiety included gastrointestinal complaints, feelings of fatigue or sedation, and sleep concerns.^309^ The findings for dropout for any reason ranged from favoring pharmacotherapy to favoring placebo (Figure 38). Seven reviews addressing antidepressant use for any indication (including anxiety) were also included (Table 38), however we refer the reader to the results above under Depression (KQ5) for an examination of risks associated with antidepressant use.^244,^ ^246,^ ^248–250,^ ^253,^ ^254^

Figure 37 Forest Plot of Group Differences in Dropout Due to Adverse Events in ESRs With Pharmacological Treatment of Anxiety Compared to Placebo (KQ5)

Abbreviations: AE = adverse event; CI = confidence interval; PD = panic disorder; RR = relative risk; SaND = social anxiety disorder; SNRI = Serotonin and norepinephrine reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor.

This figure is a forest plot of group differences in dropout due to adverse events in ESRs with pharmacological treatment of anxiety compared to placebo.

Figure 38 Forest Plot of Group Differences in Dropout for Any Reason in ESRs With Pharmacological Treatment of Anxiety Compared to Placebo (KQ5)

Abbreviations: CI = confidence interval; GAD = generalized anxiety disorder; PD = panic disorder; RR = relative risk; SaND = social anxiety disorder; SNRI = Serotonin and norepinephrine reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor.

This figure is a forest plot of group differences in dropout for any reason in ESRs with pharmacological treatment of anxiety compared to placebo.

Table 38 Characteristics of ESRs Addressing Harms of Pharmacologic Treatment of Anxiety (KQ5)

Author, Year | Quality | Outcomes | Population | Intervention | Last Search Date | Total # of Included Studies | Total N | Included Study Designs (Note if Conducted IPD Analysis)
Balasubramaniam, 2019^309^ | Good | Anxiety, Harms | Older adults | AD | Oct-2018 | 12 | NR | RCTs
Bighelli, 2018^310^ | Good | Anxiety, Harms | General population | AD | May-2017 | 47 | 9,377 | RCTs
Breilmann, 2019^311^ | Good | Anxiety, Harms | General population | BZD | May-2018 | 23 | 4,233 | RCTs
Gupta, 2020^316^ | Good | Anxiety, Harms | Older adults | BZD | Aug-2018 | 5 | 553 | RCTs
Imai, 2014^318^ | Good | Anxiety Harms | General population | Anxiolytics | Jan-2014 | 3 | 170 | RCTs, Randomized cross-over trials
Jensen, 2019^244^ | Good | Harms | General population | SSRIs | Dec-2017 | 30 | >845,655 | RCTs, Obsrv
Khanassov, 2018^246^ | Good | Harms | General population | SSRIs and SNRIs | Nov-2016 | 33 | NR | Obsrv
Kunutsor, 2018^248^ | Good | Harms | General population | AD | Apr-2018 | 8 | 960,113 (9,027 VTEs) | Obsrv
Maslej, 2017^249^ | Good | Harms | General population | AD | Jun-2014 | 16 | 378,400 | RCTs, Obsrv
Na, 2018^250^ | Good | Harms | General population | Bupropion, Mirtazapine | May-2017 | 7 | NR | Obsrv
Slee, 2019^320^ | Good | Anxiety, Harms | General population | Any pharm | Aug-2017 | 89 | 25,441 | RCTs
Trajkova, 2019^253^ | Good | Harms | General population | AD | Sep-2018 | 31 | NR | Obsrv
Viswanathan, 2021^232^ | Good | Depression, Anxiety, QoL or functioning, Maternal or fetal, Harms | Perinatal | Any pharm | Jun-2020 | 164 | NR | RCTs, Obsrv, CCTs
Wang, 2018^254^ | Good | Harms | Older adults | AD | December2017 | 5 | 53,955 | RCTs, Obsrv
Williams, 2017^322^ | Good | Depression, Anxiety, QoL or functioning, Harms | General population | Any pharm | Aug-2015 | 66 | 11,597 | RCTs

Abbreviations: AD = antidepressant; BZD = benzodiazepines; CCTs = controlled clinical trials; ESRs = existing systematic reviews; IPD = individual participant data; N = number of participants; NR = not reported; Obsrv = observation; pharm = pharmacotherapy; QoL = quality of life; RCTs = randomized controlled trials; SNRIs = serotonin and norepinephrine reuptake inhibitor; SSRIs = selective serotonin reuptake inhibitors; VTE = venous thromboembolism.

For benzodiazepine use, an extensive review of pharmacologic treatment of mental health conditions during the perinatal period concluded that the strength of evidence was low for an association with spontaneous abortion and NICU admissions (Appendix F Table 26).^232^ The review also concluded that evidence was insufficient for preeclampsia, perinatal death, birthweight, Apgar score, and infant respiratory distress. They found no evidence on the association of benzodiazepine use with 19 other serious outcomes included in their review. Among older adults, a review of five studies of benzodiazepine treatment for anxiety found that mild adverse effects such as drowsiness, faintness, and light-headedness were more common with benzodiazepines than placebo.^316^ One study in this review reported a serious adverse event (severe gastralgia) in one participant taking a placebo (at 15 days) (Appendix F Table 26).

Additional harms of antidepressants are reported above under the harms of depression treatment; many of those reviews included trials of antidepressant use for any indication (including anxiety disorders). Even findings in reviews specific to people with depression likely also apply to people with anxiety, given the high level of comorbidity between these two conditions.

We identified two additional case-control studies published in our search window (Table 39) examining the association between benzodiazepine use and spontaneous abortion (n=262,070)^326^ or suicide risk (n=308);^325^ outcomes that were not addressed in the ESRs. The good-quality study of spontaneous abortion was based on a cohort of 442,066 pregnancies in the Quebec Pregnancies Cohort, a cohort drawn from the Quebec Public Prescription Drug Insurance Plan.^326^ The final sample included 26,789 patients with spontaneous abortions between gestation weeks 6 and 20, and 134,305 matched controls with pregnancies in the same calendar year and gestational age. Confounding variables pulled from medication dispensing databases, other medical records, and demographic databases included: antidepressant use, antipsychotic use, maternal age, welfare recipient status, urban dweller status, past 12 months’ healthcare utilization (inpatient, general practice, psychiatric, other specialty), past 12 months’ mental health diagnoses (mood and anxiety disorders, insomnia), folic acid exposure, and medical comorbidities (hypertension, diabetes, asthma, thyroid disorders, tobacco, alcohol or other drug dependence). This study found that benzodiazepines were associated with an 85 percent higher risk of spontaneous abortion (OR, 1.85, 95% CI, 1.61 to 2.12; 1.4% of cases had benzodiazepines dispensed vs. 0.6% of controls). They also found higher risk levels for both long- and short-acting agents, and all specific agents, as well as a dose-response effect (all p<.05). This was a well-executed study, however they could not directly measure symptom severity or other health behaviors that may be associated with mental health symptoms such as substance use, which could be independently related to spontaneous abortion.^326^

Table 39 Observational Studies of Harms of Pharmacologic Treatment of Anxiety, Excluding Antidepressant Treatment (KQ5)

Author, Year | Study design (Quality) | Country | Study N | Population | Exposure | Outcome | Matching variables | OR (95% CI)
Cato, 2019^325^ | Case-control (Fair) | SWE | 308 | General adults | Benzodiazepine (prescription) | Suicide death | Age, sex, psychiatric diagnosis, and mental health treatment in the same timeframe (1:1 matching) | 1.83 (1.06 to 3.14)^*^
Sheehy, 2019^326^ | Case-control (Good) | CAN | 262,070 | Pregnant | Benzodiazepine (dispensing) | Spontaneous abortion, gestational weeks 6–20 | Gestational age and calendar year (1:5 matching) | 1.85 (1.61 to 2.12)^†^; Statistically significant effects for both long- and short-acting agents, and all specific agents. Dose-response effect was also identified.

* Adjusted for prescription for antidepressant, anticonvulsant, lithium, psychostimulant, antipsychotics, sedatives; previous suicide attempt; previous inpatient psychiatric care; previous inpatient somatic care; age; sex; 9 mental health diagnosis categories (depressive, anxiety, aspergers/ADHD, etc.).

† Adjusted for antidepressant use, antipsychotic use, maternal age, welfare recipient, urban dweller, past 12 month healthcare utilization (inpatient, general practitioner, psychiatric, other specialty), past 12 month mental health diagnosis (mood and anxiety disorder, insomnia), folic acid exposure, medical comorbidities (hypertension, diabetes, asthma, thyroid disorders, tobacco, alcohol or other drug dependence), and other pregnancy in previous 12 months.

Abbreviations: CAN = Canada; CI = confidence interval; N = number of participants; OR = odds ratio; SWE = Sweden.

The fair-quality case-control study of suicide risk used Sweden’s national cause of death records to identify people who had died by suicide, and matched them 1-to-1 with people with mental health service use in the same timeframe by age, sex, and primary mental health diagnosis.^325^ Medication exposure was determined by a prescription database. Other potential confounders controlled for included: prescriptions for antidepressants, anticonvulsants, lithium, psychostimulants, antipsychotics and sedatives; previous suicide attempt; previous psychiatric inpatient stay; previous non-psychiatric inpatient stay; age; sex; and diagnostic group (mental and behavioral disorder due to substance use, schizophrenia and related conditions, bipolar disorder, depressive disorder, anxiety disorder, disorders of adult personality and behavior, Asperger’s/ADHD, and substance use). This study found that benzodiazepines were associated with an 83 percent higher odds of suicide death (OR, 1.83, 95% CI, 1.06 to 3.14; 42% of cases had benzodiazepines prescribed vs. 28% of controls). As with the other case-control study, this was a well-executed study but could not directly measure symptom severity or other health behaviors that may be associated with mental health symptoms that may be important confounders. In addition, this study relied on prescriptions rather than dispensing as the measure of benzodiazepine exposure, which is even further removed from medication actually taken.^325^

## Suicide Risk

### KQ1. Do Suicide Risk Screening Programs in Primary Care or Comparable Settings Result in Improved Health Outcomes in Adults, Including Pregnant and Postpartum Persons?

### KQ1a. Does Sending Suicide Risk Screening Test Results to Providers (With or Without Additional Care Management Supports) Result in Improved Health Outcomes?

#### Summary

We found one short-term RCT (n=443) that examined screening for suicide risk, which was limited to primary care patients who had screened positive for depression (Table 40).^327^ This trial reported no statistically significant group differences in suicidal ideation at 2 weeks’ followup, and only a single suicide attempt among study participants.

Table 40 Characteristics of Suicide Risk Screening Studies (KQ1)

Author, Year | Quality rating | Study Design (Unscreened Control?) | Study N | Country | Broad Population | Specific Population | FUP, wks | Screening Approach | Screen Pos, % | Condition Criteria | Benefit (KQ1) | Harm (KQ3)
Crawford, 2011^327^ | Fair | RCT (Yes) | 443 | GBR | General adults | Adults answering “Yes” to either of two depression screening items | 2 | Screening | NR | “Yes” on either of two depression screening items | X | X

Abbreviations: FUP = followup; GBR = Great Britain; KQ = key question; N = number of participants; NR = not reported; Pos = positive; RCT = randomized controlled trial.

#### Study Characteristics

One short-term RCT (n=443) was included for addressing the benefits of suicide screening, which was also included in the previous review (Tables 40–42, Appendix G Table 1).^327^ This trial included adult primary care patients who had screened positive for depression in general practices in the UK. Patients were randomized to suicide screening or to answer health and lifestyle questions, with the primary aim of determining whether suicide screening increased the likelihood of suicidal ideation. Participants who screened positive for suicide risk were given information about helplines and other sources of help and were encouraged to use those resources. The mean age was 48 years (range, 18 to 92 years) and 70 percent were women. Retention was 81 percent at the 2-week followup.

Table 41 Participant Characteristics of Suicide Risk Screening Studies (KQ1)

Author, Year | Mean Age (Range), years | % Women^*^ | Education | Other SES | Race or Ethnicity | % Screen Pos | BL MH status
Crawford, 2011^327^ | 48.5 (16–92) | 69.1 | High school grad: NR; College grad: Completed higher education, 33.0% | Employed: 47.7; Single: 56.9; Other SES: NR | Black: NR; Hispanic/Latino: NR; Asian/AA: NR; Native Am/AN: NR; White: NR | NR | “Yes” on either of 2item screening questionnaire: 100%

* Non-binary/gender non-conforming categories were not reported.

Abbreviations: Asian/AA = Asian/Asian American; BL MH = baseline mental health; Native Am/AN = Native American/Alaska Native; NR = not reported; Pos = positive; SES = socioeconomic status.

Table 42 Intervention Characteristics of Suicide Risk Screening Studies (KQ1)

Author, Year | Target Pop | Tng in Screening | Tng in Diagnosis | Tng in Treatment | Generic tx Guide | Generic Handout | PtSpecific tx Rec | Referral Support | Sx Monitoring | Monitoring Med Use | Med Use Counseling | PCP Role
Crawford, 2011^327^ | General adults | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | Not involved

Abbreviations: Med = medication; NR = not reported; PCP = primary care provider; Pop = population; Pt = patient; Rec = recommendation; sx = symptoms; Tng = training; tx = treatment.

#### Results

At 2 weeks’ followup, one control group participant had attempted suicide and there were no suicide attempts in the screening group (Table 43).^327^ There were no statistically significant differences between groups in the proportion feeling that life was not worth living (28% in the screening group vs. 24% in the control group; OR, 1.23 [95% CI, 0.76 to 1.98]), wishing they were dead (23% in both groups; OR, 1.01 [95% CI, 0.61 to 1.66]), or reporting thoughts of taking their own life (15% in the screening group vs. 11% in the control group; OR, 1.36 [95% CI, 0.72 to 2.54).^327^ Thus, although some outcomes trended in the direction of harm, confidence intervals were wide, making it inadvisable to draw conclusions about the short-term impact of suicide screening.

Table 43 Results From Suicide Risk Screening Studies (KQ1)

Author, Year (Pop) | Outcome | Measure | IG | Analyzed | FUP, wks | OR (95% CI) | IG n/N (%) | CG n/N (%) | pvalue | Adjusted
Crawford, 2011^327^ (G) | Suicide attempt | Suicide attempt | IG1 | All | 2 | 0.38 (0.02 to 9.34) | 0/164 (0.0) | 1/187 (0.5) | NR | No
Crawford, 2011^327^ (G) | Suicidal ideation | Felt life not worth living | IG1 | All | 2 | 1.23 (0.76 to 1.98) | 46/164 (28.0) | 45/187 (24.1) | NR | Yes
Crawford, 2011^327^ (G) | Suicidal ideation | Thought of taking own life | IG1 | All | 2 | 1.36 (0.72 to 2.54) | 24/164 (14.7) | 21/187 (11.3) | NR | Yes
Crawford, 2011^327^ (G) | Suicidal ideation | Wished to be dead | IG1 | All | 2 | 1.01 (0.61 to 1.66) | 38/164 (23.2) | 43/187 (22.9) | NR | Yes

Abbreviations: CI = confidence interval; CG = control group; FUP = followup; G = general adults; IG = intervention group; IG1 = intervention group 1; NR = not reported; OR = odds ratio; Pop = population.

### KQ2. Do Instruments to Screen for High Suicide Risk Accurately Identify Adults, Including Pregnant and Postpartum Persons, With High Suicide Risk in Primary Care or Comparable Settings?

#### Summary of Results

We included three studies that screened for suicidal ideation (Table 44).^328–330^ Most screening instruments reported sensitivity and specificity above 0.80 for at least one reported cutoff (Figure 39). However, there was no replication of any instrument and two of the three studies included only three^328^ and 12^330^ individuals with suicidal ideation or at very high risk according to the reference standards. The study with the most events was limited to older adults.^329^

Figure 39 Summary of Test Accuracy of Screening Tools to Detect High Risk of Suicide (KQ2)

Abbreviations: CI = Confidence interval; GDS-SI = Geriatric Depression Scale – Suicide Ideation; NA = Not applicable; SDDS-PC = Symptom Driven Diagnostic System for Primary Care.

This figure is showing a summary of test accuracy of screening tools to detect high risk of suicide.

Table 44 Characteristics of Studies Examining Test Accuracy of Suicide Risk Screening Instruments to Identify People at Increased Risk of Suicide (KQ2)

Author, Year | Quality | Country | Brief population description | N analyzed | Diagnostic interview | Screening test
Desjardins, 2016^328^ | Fair | USA | Age ≥ years from the ED with any chief complaint | 124 | Unstructured interview from a psychiatrist | Suicide Risk Assessment Tool
Heisel, 2010^329^ | Fair | USA | Age ≥65 years from primary care | 626 | SCID and Ham-D | GDS-15
Heisel, 2010^329^ | Fair | USA | Age ≥65 years from primary care | 626 | SCID and Ham-D | GDS-SI
Olfson, 1996^330^ | Fair | USA | Ages 18–70 years | 1,001 | SCID | SDDS-PC - Feeling suicidal
Olfson, 1996^330^ | Fair | USA | Ages 18–70 years | 1,001 | SCID | SDDS-PC - Thoughts of death
Olfson, 1996^330^ | Fair | USA | Ages 18–70 years | 1,001 | SCID | SDDS-PC - Wishing you were dead

Abbreviations: ED = emergency department; GDS = Geriatric Depression Scale; GDS-SI = Geriatric Depression Scale – Suicide Ideation; HAM-D = Hamilton Rating Scale for Depression; N = number of participants; SCID = Structured Clinical Interview for DSM Disorders; SDDS-PC = Symptom Driven Diagnostic System for Primary Care; USA = United States of America.

#### Study Characteristics

Three studies screening for suicidal ideation were included;^328–330^ two were included in the previous review (Table 44).^329,^ ^330^ Each study examined a different screening test, including two versions of the Geriatric Depression Scale (GDS), three separate questions about suicide from the Symptom Driven Diagnostic System for Primary Care (SDDS-PC) (feeling suicidal, thoughts of death, wishing you were dead), and an unnamed suicide risk assessment tool. All three studies were conducted in the US. Two recruited participants from primary care and the third recruited participants from the ED for any chief complaint (i.e., not limited to patients with mental health concerns). Sample sizes ranged from 124 to 1,001. Two studies recruited adults 18 years and older while one study recruited older adults (≥65 years) (Table 44). Mean age ranged from 47 to 75 years (Table 45). Women were represented in higher proportions than men: 52 to 63 percent of participants were women. Race and ethnicity were reported in only one study;^329^ 93 percent were White. SES was reported in one study with a mean of 14 years of education.^329,^ ^330^

Table 45 Participant Characteristics for Studies of Test Accuracy of Suicide Risk Screening Instruments (KQ2)

Author, Year | N | Suicide Risk, n/n (%) | Mean Age | Age Range | % Women^*^ | Race or Ethnicity, % | SES
Heisel, 2010^329^ | 626 | 69/626 (11) | 75 | 65–95 | 62 | White: 93; Black: 5; Other: 2 | Mean years of education: 14; Employment Status, %; Retired: 82; Unemployed/disability benefits: 2; Part/Full-time employment: 14; Part/Full-time student: <1
Olfson, 1996^330^ | 1,001 | 12/1,001 (1.2) | 49 | 18–70 | 63 | NR | NR
Desjardins, 2016^328^ | 124 | 3/124 (2.4) | 47 | ≥ | 50 | NR | NR

* Non-binary/gender non-conforming categories were not reported in any studies.

Abbreviations: N = number of participants; NR = not reported; SES = socioeconomic status.

Two studies used the SCID (one along with the HAM-D) to determine suicidal ideation, administered within a maximum of 4 days.^329,^ ^330^ The third used an unstructured interview from a psychiatrist administered on the day of the screening test.^328^ The proportion of participants who were identified through interviews as being at risk of suicide ranged from 1.2 percent to 11 percent.

#### Results

##### GDS-15

One study reported test accuracy for the GDS-15 to identify suicidal ideation in older adults.^329^ The authors determined a GDS-15 cutoff of ≥4 would maximize sensitivity and specificity, but the optimal cutoff for women alone was lower (≥3) and for men it was higher (≥5). At a GDS-15 cutoff of ≥4, sensitivity to detect suicidal ideation was 0.75 (95% CI, 0.64 to 0.84) and specificity was 0.82 (95% CI, 0.78 to 0.85) (Appendix G Table 2). At higher cutoffs (≥5, ≥6), sensitivity decreased and specificity increased; at lower cutoffs (≥2, ≥3) sensitivity increased and specificity decreased.^329^

##### GDS-SI

One study reported test accuracy for the GDS-SI. The GDS-SI is a 5-item subset of the GDS that addresses suicidal ideation (GDS items 3, 7, 11, 12, and 14).^329^ The authors identified a GDS-SI cutoff of ≥1 as optimal to screen for suicidal ideation, with a sensitivity of 0.80 (95% CI, 0.69 to 0.88) and a specificity of 0.80 (95% CI, 0.77 to 0.84) (Appendix G Table 2). Stratified results showed at a GDS-SI cutoff of ≥1; test performance was similar between men and women. At higher cutoffs (≥2, ≥3), sensitivity decreased and specificity increased.^329^

##### SDDS-PC

One study (n=1,001) reported the test accuracy of three questions from the SDDS-PC to screen for suicidal ideation in primary care.^330^ The sensitivity of the “feeling suicidal” symptom to identify suicidal ideation was 0.83 (95% CI, 0.62 to 1.0) and the specificity was 0.98 (95% CI, 0.97 to 0.99). The “thoughts of death” symptom resulted in a sensitivity of 1.0 (95% CI, 0.76 to 1.0) and a specificity of 0.81 (95% CI, 0.78 to 0.84). The last symptom—“wishing you were dead”—yielded a sensitivity of 0.92 (95% CI, 0.76 to 1.0) and a specificity of 0.93 (95% CI, 0.92 to 0.95) (Appendix G Table 2).^330^

##### Suicide Risk Assessment Tool

One newly identified study examined the accuracy of a new risk assessment tool.^328^ The aim of the tool was to predict the risk of committing suicide within 72 hours and to replicate a psychiatrist-recommended intervention. The risk assessment tool was replicated with a sequentially recruited ED population (n=124). Compared with an interview from a psychiatrist, the sensitivity of the tool to identify moderate or high suicide risk was 0.42 (95% CI, 0.19 to 0.68) and the specificity was 0.98 (95% CI, 0.94 to 1.0). Only 12 participants were identified as at moderate or high risk of suicide (Appendix G Table 2).^328^

### KQ3. What Are the Harms Associated With Screening for Suicide Risk in Primary Care or Comparable Settings in Adults, Including Pregnant and Postpartum Persons?

The same short-term study (n=443) that was included for KQ1 was the only evidence included for assessing the harms of suicide screening (Table 40).^327^ This study was designed to determine whether screening for suicide among people with symptoms of depression increased the risk of suicidal ideation. As described above under KQ1, two of three suicidal ideation items indicated a possible higher risk with screening, however the findings were inconclusive due to the lack of statistical significance and very wide confidence intervals (Table 43).

### KQ4. Does Treatment of High Suicide Risk (Psychotherapy or Pharmacotherapy) Result in Improved Health Outcomes in Adults, Including Pregnant and Postpartum Persons?

#### Summary of Results

We included 23 RCTs (reported in 36 articles, N=22,632) of suicide prevention among people at increased risk of suicide (Table 46).^331–366^ The impact of psychological interventions for suicide prevention on suicide deaths could not be determined due to the small number of events, however enough events were available to address suicide attempts. One large (n=18,882) good-quality multi-site trial conducted in US integrated care settings tested two suicide prevention interventions among adults with an elevated risk for suicide based on item 9 of the PHQ-9.^365^ This study found that, compared to usual care, a care management intervention had no impact on the rate of suicide attempts (HR, 1.07 [97.5% CI, 0.84 to 1.37]; p=.52) and a low-intensity online skills training intervention was associated with an increased risk of suicide attempts (HR, 1.29 [97.5% CI, 1.02 to 1.64]; p=.015) Most other studies reported five or fewer suicide attempts per study group and the pooled effect was not statistically significant (OR, 0.94 [95% CI, 0.73 to 1.22]; 12 RCTs [n=14,573]; I^2^=11.2%, including only the care management arm of the large trial; Figure 40, Table 47). Although there was a small statistically significant benefit for depression symptom severity, there was no clear improvement over usual care for suicidal ideation, self-harm, other mental outcomes, or emergency or inpatient healthcare utilization. (Table 47). Usual mental health care was the most common control group, and was in some cases enhanced or optimized, so most of the included studies could be considered comparative effectiveness studies. The study with the most favorable findings (n=598)used individually tailored depression care management for older adults who had screened positive for depression.^337^ This study reported improvements in depression outcomes for up to one year and suicidal ideation for up to eight months, but only five suicide attempts and one suicide death over two years. One study examined the impact of a pharmacologic intervention and found no differences between those taking placebo or 600 mg/day of lithium for up to one year in any suicide-related outcome, although medication adherence was low in this study.

Figure 40 Forest Plot of Proportion With a Suicide Attempt From the Suicide Prevention Trials (KQ4)

Abbreviations: BPD = bipolar disorder; CAMS = Collaborative Assessment and Management of Suicidality; CBT = cognitive behavioral therapy; CG = control group; CI = Confidence interval; DBT = dialectical behavioral therapy; GDS-SI = Geriatric Depression Scale – Suicide Ideation; IG = intervention group; NA = Not applicable; OR = odds ratio; SDDS-PC = Symptom Driven Diagnostic System for Primary Care.

This figure is a forest plot of proportion with a suicide attempt from the suicide prevention trials.

Table 46 Characteristics of Suicide Prevention Studies (KQ4)

Author, Year | Quality rating | Study design | Study N | Country | Target pop | Population | Followup, wks | Intervention | Benefits | Harms
Borschmann, 2013^336^ | Good | RCT | 88 | GBR | General adults | Adults with borderline personality disorder and selfharm in the past 12 months | 26 | IG1: One 60-min joint crisis plan meeting. | X | X
Bruce, 2004^337^ | Fair | Cluster RCT | 598 | USA | Older adults | Adults age ≥60 years with MDD or minor depressive disorder | 16, 35, 52 | IG1: Individually tailored in-person or phone-based depression care management. | X
Bush, 2017^338^ | Good | RCT | 118 | USA | General adults | Veterans in mental health treatment expressing suicidal ideation | 3, 6, 12 | IG1: App-based CBT intervention. | X
Carter, 2010^340^ | Fair | RCT | 76 | AUS | General adults | Adult women, ages 18–65 years, with borderline personality disorder and a history of selfharm | 13, 26 | IG1: Individual (number NR) and 24 group DBT sessions, and phone calls (number NR) with individual therapist. | X
Davidson, 2006^342^ | Good | RCT | 106 | GBR | General adults | Patients with borderline personality disorder and selfharm in previous 12 months | 52, 104 | IG1: Up to 30 60-min CBT sessions | X
Franklin, 2016^343^ | Fair | RCT | 163 | USA | General adults | Adults recruited from online mental health forums reporting at least one suicidal behavior within the past year | 4 | IG1: Mobile gamelike app called Therapeutic Evaluative Conditioning (TEC), designed to increase aversion to selfinjurious thoughts and behaviors and decrease aversion to the self. | X
Goodman, 2016^345^ | Fair | RCT | 91 | USA | General adults | Veterans ages 1855 years at high risk of suicide | 12, 26, 52 | IG1: 26 50- to 60min individual and 26 90-min group DBT sessions. | X
Jobes, 2017^347^ | Fair | RCT | 148 | USA | General adults | Active-duty US Army soldiers, age ≥18 years with significant suicidal ideation (≥13 on SSI-C) | 4, 13, 26, 52 | IG : ≥4 counseling sessions based on CAMS approach. | X
Katz, 2022^362^ | Fair | RCT | 519 | USA | General adults | Veterans with depression or bipolar disorder who had survived a recent suicidal event | 8.5, 52 | IG1: Lithium 600 mg/d for 1 year plus usual VA mental health care | X | X
Kovac, 2002^348^ | Fair | RCT | 121 | USA | General adults | College students age ≥18 years who screened positive for increased risk of suicide | 2, 6 | IG1: Four 20-min writing sessions over 2 weeks about thoughts and feelings associated with the most difficult time(s) in their life. | X
Linehan, 2006^349^ | Fair | RCT | 111 | USA | General adults | Women ages 1845 years with borderline personality disorder and recent self-harm | 52, 104 | IG1: 52 1-hr individual and 52 2.5-hr group DBT sessions, plus telephone consultation as needed. | X
McMain, 2017^350^ | Fair | RCT | 84 | CAN | General adults | Adults ages 18–60 years with borderline personality disorder and recent history of suicidal and/or NSSI episodes. | 10, 20, 32 | IG1: 20 2-hour DBT skills training group sessions. | X
Mühlmann, 2021^351^ | Fair | RCT | 402 | DNK | General adults | Adults age ≥18 years in Denmark with suicidal thoughts | 6, 32 | IG1: Six online selfhelp CBT modules, available over 6 weeks. | X
Pigeon, 2019^353^ | Good | RCT | 54 | USA | General adults | Veterans ages 1870 years who screened positive for suicidal ideation, insomnia, and co-occurring PTSD and/or depression. | 6 | IG1: Four individual sessions of brief CBT for insomnia with a behavioral health provider. | X
Pistorello, 2012^354^ | Fair | RCT | 63 | USA | General adults | College students experiencing suicidal ideation with a history of self-harm and characteristics of borderline personality disorder | 12, 26, 38, 52, 78 | IG1: 52 50-min individual and 52 90min DBT group sessions, additional coaching as needed. | X
Pistorello, 2021^363^ | Fair | RCT | 62 | USA | General adults | College students seeking services at a college counseling center and at risk for suicide | 13 | IG1: 4 to 8 weekly CAMS therapy sessions. | X
Priebe, 2012^355^ | Fair | RCT | 80 | GBR | General adults | Patients with borderline personality disorder and recent self-harm | 52 | IG1: 52 1-hour individual and 52 2hour DBT group sessions, telephone coaching as needed. | X
Riblet, 2022^364^ | Fair | RCT | 20 | USA | General adults | Primary care veteran patients at risk for suicide | 4, 13 | IG1: Educational materials, 1-hour phone or video educational session followed by 6 additional contacts over 3 months; focus on symptom monitoring, safety planning, treatment adherence. | X
Simon, 2022^365^ | Good | RCT | 18882 | USA | General adults | Adult outpatients who report recent frequent suicidal thoughts (PHQ-9 item 9=2–3) | 78 | IG1: Structured care management program, including a series of patient outreach contacts over 12 months.; IG2: 4-session online skills training program supported by messages from skills coach to support program engagement, offered for up to 12 months. | X
Torok, 2022^366^ | Fair | RCT | 455 | AUS | General adults | Young adults (ages 18–25 years) at risk of suicide | 6 | IG1: LifeBuoy: a brief, self-guided DBT smartphone application with 7 modules delivered over 6 weeks. | X
Van Orden, 2021^359^ | Fair | RCT | 62 | USA | Older adults | Adults, age ≥60 years, reported subjective disconnection (feeling lonely and/or like a burden) | 3, 6, 10 | IG1: Up to 10 inhome individual social activation intervention sessions over approximately 10 weeks. | X
van Spijker, 2014^358^ | Good | RCT | 236 | NLD | General adults | Adults age ≥18 years scoring between 1 and 26 on Beck Scale for Suicide Ideation (BSS) | 2, 4, 6 | IG1: 6-week online CBT educational modules with automated email followup. | X
Ward-Ciesielski, 2017^361^ | Fair | RCT | 93 | USA | General adults | Adults age ≥18 years with suicidal ideation in the past week and no mental health treatment in the past month | 1, 4, 12 | IG1: One 45- to 60min DBT session. | X

Abbreviations: AUS = Australia; CAMS = Collaborative Assessment and Management of Suicidality; CAN = Canada; CBT = cognitive behavioral therapy; DBT = dialectical behavior therapy; GBR = Great Britain; IG1 = intervention group 1; MDD = major depressive disorder; NLD = Netherlands; NR = not reported; NSSI = non-suicidal self-injury; pop = population; PHQ = Patient Health Questionnaire; PTSD = post-traumatic stress disorder; RCT = randomized controlled trial; SSI-C = Scale for Suicide Ideation-Current; USA = United States of America.

Table 47 Summary of Meta-Analysis Results for Suicide Prevention Studies (KQ4)

Outcome | No. studies (n analyzed) | Type of effect | Pooled result (95% CI)^*^ | I^2^, % | Tau^2^ | Range of effects^†^ | Median (IQR) effects^†^
% With suicide attempt | 12 (14,573) | OR | 0.94 (0.73 to 1.22) | 11.2 | 0.02 | 0.34 to 4.59 ARD: −23.6 to +8.3 percentage points | 0.94 (0.61 to 1.05) ARD: 0.0 (−2.6 to +0.5) percentage points
Suicidal ideation (continuous measures) | 12 (1,734) | SMD | −0.14 (−0.31 to 0.02) | 54.8 | 0.04 | Mean diff in change: −11.8 to +5.2 | Mean diff in change: −0.7 (−2.5 to +0.2)
Depression symptoms severity | 11 (2,177) | SMD | −0.22 (−0.33 to −0.10) | 0 | 0 | −12.8 to +2.5 | −1.8 (−3.2 to −0.3)

* Effect based on restricted maximum likelihood model with the Knapp-Hartung adjustment for small samples.

† Range of effects for all study arms, subgroup analyses, and timepoints (i.e., not limited to records in the meta-analysis).

Abbreviations: ARD = absolute risk difference; CI = confidence interval; diff = difference; IQR = interquartile range; OR = odds ratio; SMD = standardized mean difference.

#### Study Characteristics

23 RCTs (N=2,694) examined the benefits of interventions to prevent suicide among those at increased risk (Table 46),^336–338,^ ^340,^ ^342,^ ^343,^ ^345,^ ^347–351,^ ^353–355,^ ^358,^ ^359,^ ^361–366^ including one that aimed to both reduce depression and prevent suicide among older adults with a depressive disorder.^337^ Two studies were restricted to older adults,^337,^ ^359^ one was limited to young adults (ages 18–25 years),^366^ and none were limited to perinatal women. Many of the studies were restricted to specific populations, however, including persons meeting the criteria for borderline personality disorder,^336,^ ^340,^ ^342,^ ^349,^ ^350,^ ^355^ veterans,^338,^ ^345,^ ^353,^ ^362,^ ^364^ active duty members of the US Army,^347^ and college students.^348,^ ^354,^ ^363^

Fifteen of the trials were conducted in the US,^337,^ ^338,^ ^343,^ ^345,^ ^347–349,^ ^353,^ ^354,^ ^359,^ ^361–365^ and the remaining were in Australia,^340,^ ^366^ Canada,^350^ The Netherlands,^358^ Denmark,^351^ and the UK.^336,^ ^342,^ ^355^ Studies used a wide range of recruitment strategies. The most common approaches were referral from medical or mental health practitioners, however three recruited through screening in primary care clinics^337,^ ^353,^ ^359^ and one identified patients through examination of electronic medical records for PHQ-9 results, which was routinely administered at mental health visits and primary care visits for depression treatment in the participating health systems.^365^ Three studies of a mobile app recruited patients from online forums, including some that focused on mental health or suicide prevention topics.^343,^ ^351,^ ^358^ We excluded studies that recruited patients from emergency or inpatient settings who were in the midst of an acute suicidal crisis, due to limited applicability of the findings to patients who would be identified through screening in primary care settings.

Sociodemographic information about the included samples are presented in Appendix G Table 3 and summarized in Table 48. Across all studies, the mean age was 33.8 years, and 66.3 percent of participants were women. Among the twelve trials conducted in the US and reporting on race or ethnicity, the percent of participants who were Black ranged from 18 to 31.9, the percent Hispanic/Latino ranged from 3.6 to 45.1, and the percent White ranged from 14.3 to 92. The highest proportions of Asian American or Pacific Islander, and Native American participants in any study were 16.1 percent and 4.8 percent, respectively. Only two trials included a sample in which less than half of participants were White, a study of veterans age 18–55^345^ and one of college students^363^. Two studies appeared to be primarily comprised of people with significant socioeconomic challenges.^336,^ ^361^ One of these had a high proportion (54%) of participants who had experienced homelessness and 43 percent with an annual income below $10,000.^361^ In the other study, 47.7 percent were permanently disabled and only 11.4 percent were employed.^336^

Table 48 Summary of Participant Demographic Characteristics Among Studies of Suicide Prevention (KQ4); Weighted Mean (Number of Studies Reporting), Unless Otherwise Indicated

Condition | No. of studies (no. USbased studies) | Total N | Mean age | % Women^*^ | Race or ethnicity (USbased studies only) | Race or ethnicity, range of % of participants among US-based studies
Suicide | 23 (15) | 22,632 | 33.8 (21) | 66.3 (22) | Black: 4.7 (12); Asian-Amer/PI: 3.4 (9); Native Amer/AN: 0.8 (7); Hispanic/Latino: 8.7 (10); White: 74.3 (14) | Black: 1.8 to 31.9; Asian-Amer/PI: 1 to 16.1; Native Amer/AN: 0.7 to 4.8; Hispanic/Latino: 3.6 to 45.1; White: 14.3 to 92

* Gender was not reported in studies of perinatal patients so participants are counted as women, recognizing that there may be some individuals who do not identify as women; non-binary/gender non-conforming categories were not reported in any studies.

Abbreviations: Asian-Amer/PI = Asian American/Pacific Islander; N = number of participants; Native Am/AN = Native American/Alaska Native; US = United States.

One study examined the impact of a pharmacologic intervention (lithium)^362^ and the remaining examined behavioral interventions, along with usual mental health care. The most common intervention approach was dialectical behavior therapy (DBT) or programs based on DBT principles, used in seven studies (Table 49, Appendix G Table 4).^340,^ ^345,^ ^349,^ ^350,^ ^354,^ ^355,^ ^361,^ ^365,^ ^366^ The DBT studies were wide ranging in intensity and fidelity to original DBT approaches. They included some lower-intensity approaches such as a self-guided smartphone app,^366^ a brief on-line skills development program with brief messages from an interventionist,^365^ and a single 45- to 60-minute session.^361^ Higher contact interventions included weekly individual and group sessions for 6 months^345^ to 1 year.^349,^ ^354,^ ^355^ DBT includes cognitive behavioral elements and directly addresses suicidal thinking and behavior. Common elements included mindfulness, emotional regulation, distress tolerance, interpersonal effectiveness, and dialectics (i.e., understanding and tolerating two simultaneous yet opposing truths, such as acceptance of a current state or skill level and a desire to improve). Three other interventions used CBT approaches: one offered up to 30 CBT counseling sessions,^342^ one tested an app-based intervention^338^ and the third used a CBT program to improve sleep and was limited to people with suicidal ideation and insomnia.^353^ Other traditional clinical approaches included a 60-minute crisis planning meeting,^336^ depression care management,^338,^ ^365^ and the Collaborative Assessment and Management of Suicidality (CAMS) approach.^347^ Two other novel approaches that have not been widely used were an app-based intervention designed to increase aversion to self-injurious thoughts and behaviors through pairing of words and images,^343^ and a series of expressive writing exercises.^348^

Table 49 Intervention Characteristics of Suicide Prevention Studies (KQ4)

Author, Year | IG | Duration, wks | Therapeutic Approach | Est Contact Hours | Delivery | PC Team Role | Control
Borschmann, 2013^336^ | IG1 | 0.14 | Other | 1 | In-person | None | Usual care
Bruce, 2004^337^ | IG1 | NR | Care management | | In-person, Phone | Some | Usual care
Bush, 2017^338^ | IG1 | 12 | CBT | NR | Web | None | Enhanced usual care
Carter, 2010^340^ | IG1 | 26 | DBT | 24 | In-person, Phone | None | Usual care
Davidson, 2006^342^ | IG1 | 52 | CBT | 3 | In-person | None | Usual care
Franklin, 2016^343^ | IG1 | 4 | Other | NR | Virtual | None | Usual care
Goodman, 2016^345^ | IG1 | 26 | DBT | 62.8 | In-person, Phone | None | Usual care
Jobes, 2017^347^ | IG1 | 4–52 | Other | 2.5 | In-person | None | Enhanced usual specialty MH care
Katz, 2022 #41302 | IG1 | 52 | Lithium | NA | NA | Most/all | Placebo
Kovac, 2002^348^ | IG1 | 2 | Other | 1.3 | In-person | None | Minimal
Linehan, 2006^349^ | IG1 | 52 | DBT | 182 | In-person, Phone | None | Enhanced usual specialty MH care
McMain, 2017^350^ | IG1 | 20 | DBT | 41.5 | In-person | None | Waitlist
Mühlmann, 2021^351^ | IG1 | 6 | CBT | NR | Web | None | Waitlist
Pigeon, 2019^353^ | IG1 | 6 | CBT | 1 | In-person | None | Usual care
Pistorello, 2012^354^ | IG1 | 52 | DBT | 121.3 | In-person, Phone | None | Enhanced usual specialty MH care
Pistorello, 2021 #42286 | IG1 | 4–8 | CAMS | 8 | In-person | None | Usual specialty MH care
Priebe, 2012^355^ | IG1 | 52 | DBT | 156 | In-person, Phone | None | Usual care
Riblet, 2022^364^ | IG1 | 13 | Other | 2.5 | Phone, Print, Video | None | Usual specialty MH care
Simon, 2022^365^ | IG1 | 52 | Case management | NR | Phone, Email or Text | None | Usual care
Simon, 2022^365^ | IG2 | 52 | DBT | NR | Phone, Web, Email or Text | None | Usual care
Torok, 2022^366^ | IG1 | 6 | DBT | 0.6 | Smartphone/App | None | Attention Control
Van Orden, 2021^359^ | IG1 | 10 | Social-behavioral activation | 10 | In-person | None | Usual care
van Spijker, 2014^358^ | IG1 | 6 | CBT | 21 | Web | None | Usual care
Ward-Ciesielski, 2017^361^ | IG1 | 0.14 | DBT | 0.8 | In-person | None | Minimal

Abbreviations: CAMS = collaborative assessment and management of suicidality; CBT = cognitive behavioral therapy; DBT = dialectical behavior therapy; Est = estimated; IG = intervention group; IG1 = intervention group 1; MH = mental health; NR = not reported; PC = primary care.

Control groups involved usual care. For most studies, this meant usual specialty mental health care (i.e., active treatment), due to the potential serious consequences of suicidal ideation. For some studies, usual care was enhanced in some way, such as by providing training to control providers, matching the amount of contact between the control and intervention groups, or limiting the control providers to those deemed to be expert clinicians in the community.

Five studies were rated as good quality^336,^ ^338,^ ^342,^ ^353,^ ^365^ and the remaining were rated as fair quality. The most common reasons for downgrading studies from good to fair included attrition greater than 10 percent, lack of information about allocation concealment and randomization procedures, and questions about the baseline comparability of the groups (often secondary to small sample sizes).

#### Results

Detailed results for all outcomes are reported in Appendix G.

##### Suicide-Related Outcomes

Two trials reported on suicide deaths by treatment group, both at 2 years’ followup.^337,^ ^349^ One study was limited to older adults and reported one death by suicide.^337^ The other study was among patients with borderline personality disorder and reported no suicide deaths (Appendix G Table 5).^349^

Twelve trials reported suicide attempts and indicated no reduction in suicide attempts for the studied interventions.^337,^ ^342,^ ^345,^ ^347,^ ^349,^ ^351,^ ^354,^ ^358,^ ^361,^ ^362,^ ^364,^ ^365^ The interventions studied included DBT, CBT, CAMS, lithium, and care management. The best evidence on suicide attempts comes from a large (n=18,882) good-quality multi-site trial conducted in US integrated care settings.^365^ This study tested two suicide prevention interventions among adults with an elevated risk for suicide based on item 9 of the PHQ-9. This study found that, compared to usual care, a care management intervention had no impact on the rate of suicide attempts (HR, 1.07 [97.5% CI, 0.84 to 1.37]; p=.52) and an online DBT-based skills training intervention was associated with an increased risk of suicide attempts (HR, 1.29 [97.5% CI, 1.02 to 1.64]; p=.015). Estimated event rates of the primary outcome of fatal or nonfatal self harm were 3.3% for those offered care management, 3.9% for those offered skills training, and 3.1% for those receiving usual care. The skills training intervention involved minimal contact with skills coaches, who did not provide psychotherapy but sent messages through the electronic health record portal to reinforce each visit to the online program, encourage practice of specific skills, and reach out to participants without recent visits. Frequency of outreach depended on each participant’s level of involvement but was at least monthly during the initial 6 months. The results for this trial held even among extensive sensitivity analyses.

Most of the remaining studies had only one to five suicide attempts in each group; only two other trials had more than ten suicide attempts in either group.^342,^ ^349^ Both of these trials were limited to people diagnosed with borderline personality disorder, and they used CBT^342^ and DBT interventions.^349^ Of these two, a very high-intensity DBT intervention trial was the only study to find a statistically significant reduction in suicide attempts (OR, 0.34 [95% CI, 0.14 to 0.80], n=101).^349^ The intervention for this trial involved a median of 42 individual and 39 group DBT sessions. The overall pooled effect combining all twelve trials reporting this outcome (and including only the care management arm of the very large trial) was not statistically significant, with follow-up ranging from 3-months to 2-years (OR, 0.94 [95% CI, 0.73 to 1.22]; 12 RCTs [n=14,573]; I^2^=11.2%, Figure 40, Table 47).

Twelve trials reported on change in a continuous measure of suicidal ideation severity or number of days with suicidal ideation.^338,^ ^343,^ ^345,^ ^348,^ ^349,^ ^351,^ ^353,^ ^354,^ ^361,^ ^363,^ ^366^ The pooled analysis indicated no impact of the interventions on suicidal ideation beyond usual care (SMD, 0.14 [95% CI, −0.31 to 0.02]; I^2^=54.8%, 12 RCTs, N=1,734, Figure 41, Table 47, Appendix G Table 6). Point estimates ranged in both directions, and only two of the individual trials reported a statistically significant improvement at any timepoint on a continuous measure of suicidal ideation.^354,^ ^366^ The trial of older adults who screened positive for depression reported a greater reduction in the percent of participants with suicidal ideation in the care management group (29.4% at baseline to 16.5% at followup) compared to usual care (20.1% to 17.1%, p=.01 for the difference between groups).^337^

Figure 41 Forest Plot of Standardized Mean Difference in Change From Baseline of Continuous Suicidal Ideation Measures From the Suicide Prevention Trials (KQ4)

Note: “IG/CG Mn(SD)” show change from baseline in the native units of the measures reported.

Abbreviations: ASIQ = Adult Suicidal Ideation Questionnaire; BPD = bipolar disorder; BSS = Beck Scale for Suicide ideation; CBT = cognitive behavioral therapy; CG = control group; CI = Confidence interval; C-SRRS = Columbia-Suicide Severity Rating Scale; DBT = dialectical behavioral therapy; IG = intervention group; SBQ = Suicide Behaviors Questionnaire; SD = standard deviation; SMD = standardized mean difference; SSI = Scale for Suicidal Ideation.

This is a forest plot of standardized mean difference in change from baseline of continuous suicidal ideation measures from the suicide prevention trials.

##### Other Mental Health Outcomes, Quality of Life, and Functioning

The other mental health outcomes reported most widely included depression-related outcomes (remission, response,^337^ and symptom severity,^336,^ ^337,^ ^342,^ ^345,^ ^348–350,^ ^353,^ ^354,^ ^361,^ ^366^ self-harm (non-suicidal intent, or a mix of suicidal and non-suicidal intent),^336,^ ^340,^ ^350,^ ^354,^ ^355,^ ^361^ global mental health symptom severity,^336,^ ^342,^ ^347,^ ^350,^ ^355^ and anxiety symptom severity (Appendix G Tables 7 and 8).^336,^ ^342,^ ^345,^ ^361,^ ^366^

We conducted meta-analysis for depression symptom severity scores and found that suicide prevention treatment in high-risk individuals was associated with a small, statistically significant reduction in depression symptoms (SMD, −0.22 [95% CI, −0.33 to −0.10]; 11 RCTs [n=2,177]; I^2^=0%, Figure 42, Table 47). Three trials reported statistically significant reductions in depression symptoms, including the trial of a care management intervention among older adults who screened positive for depression; the intervention in this study also targeted depression.^337,^ ^353,^ ^354^ This care management study found a 3.5-point greater reduction in the HAM-D for participants in the intervention group at four months post-baseline (mean difference in change from baseline [MD], −3.5 [95% CI, −4.7 to −2.3]; n=598). The effect size diminished over time, and group differences were not statistically significant at the final followup after 18 months (p=.06). This study also reported an increased likelihood of depression remission at up to 8 months’ followup (OR, 2.1 [95% CI, 1.1 to 4.2]; n=487; 41.1% in the intervention group, 31.8% in the control group) and an increased likelihood of a clinically significant response at up to 1 year (OR, 2.0 [95% CI, 1.1 to 3.8]; n=405; 52.1% in the intervention group, 42.0 % in the control group reduced their HAM-D score by 50% or more).^337^

Figure 42 Forest Plot of Depression Symptom Severity Scores From the Suicide Prevention Trials (KQ4)

Note: “IG/CG Mn(SD)” show change from baseline in the native units of the measures reported.

Abbreviations: BDI = Beck Depression Inventory; BPD = bipolar disorder; CBT = cognitive behavioral therapy; CG = control group; CI = Confidence interval; DBT = dialectical behavioral therapy; HADS-D = Hospital Anxiety and Depression Scale – Depression; HAM-D = Hamilton Rating Scale for Depression; IG = intervention group; PHQ = Patient Health Questionnaire; SD = standard deviation; SMD = standardized mean difference; ZSDS = Zung Self-rating Depression Scale.

This figure is a forest plot of depression symptom severity scores from the suicide prevention trials.

Five trials reported self-harm, all were in trials among patients with a diagnosis of borderline personality disorder or symptoms of borderline personality disorder.^336,^ ^340,^ ^350,^ ^354,^ ^355^ The findings were mixed and inconclusive (Appendix G Table 6). Four of these trials reported the proportion of participants with episodes of self-harm but the results were inconclusive; the pooled effect had wide confidence intervals (OR, 1.21 [95% CI, 0.71 to 2.07]; 7 RCTs [n=1,009]; I^2^=27.1%). On the other hand, two trials reported reductions in the number of self-harms episodes, among those with any self-harm episodes at baseline.^350,^ ^355^ One of these reported a reduced number of suicidal and self-injurious episodes at the final, 32-week followup (1.4 in the intervention group, 2.6 in the control group over the previous 12 weeks, p<.04).^350^ The other trial reported a reduced number of days with self-harm in the previous 2 months (IRR, 0.91 [95% CI NR], p<.001).^355^ These two studies and a third that showed a reduced proportion with self-harm were high-contact trials of DBT among patients diagnosed with borderline personality disorder.^349^

Global mental health symptom severity measures generally showed very small, statistically non-significant differences in improvement favoring the intervention groups, with most group differences being one point or less on a wide variety of scales (Appendix G Table 8). Similarly, anxiety symptom severity, mental health-related quality of life, global quality of life, and social function were each reported in one to four studies, with null or mixed results.

##### Other Health Outcomes

The very large trial found no group differences in inpatient admissions with a mental health diagnosis.^365^ Two studies limited to patients with borderline personality disorder found no group differences in the proportion of patients with Accident and Emergency Department attendances or inpatient admissions (Appendix G Table 9).^336,^ ^340^

##### Effect Modification and Findings in Specific Populations

None of the trials reported on effect modification by age, gender, race, or ethnicity, nor was there sufficient evidence to explore effect size variability by study or intervention characteristics through stratified analyses or meta-regression. The very large trial found that several demographic characteristics (sex, age distribution, race and ethnicity) and clinical characteristics (location of index visit, rates of prior mental health diagnoses) varied across levels of intervention uptake more than expected by chance. However, these comparisons did not show a consistent relationship between baseline indicators of risk and specific levels or types of intervention participation.^365^

### KQ5. What Are the Harms of Treatment of High Suicide Risk (Psychotherapy or Pharmacotherapy) in Adults, Including Pregnant and Postpartum Persons?

Two of the included RCTs of suicide prevention that we examined reported on harms.^336,^ ^362^ There were no differences between groups at followup on an instrument designed to assess the perceived level of coercion experienced by service users during hospital admission.^336^ There was no pattern of effect in the studies included for KQ4 to indicate paradoxical harms of treatment. The study of lithium found a higher rate of non-serious adverse events (75.7% with lithium, 69% with placebo, p-value not reported), a slightly higher rates of serious adverse events (38.8 % with lithium, 34.1% with placebo, p-value not reported) but but no difference in withdrawals due to adverse events (1.2% with lithium, 1.5% with placebo, p-value not reported).^362^