# Chapter 1 Introduction

## Purpose

The Agency for Healthcare Research and Quality (AHRQ) has requested a review on screening and treatment for depression, anxiety disorders, and suicide risk in adults, including pregnant people. This topic includes updating the evidence for two previous USPSTF reviews, Screening for Depression in Adults^1^ and Screening for Suicide Risk in Primary Care,^2^ and a new topic of screening for anxiety disorders. This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2016 recommendation for Screening for Depression in Adults and its 2013 Screening for Suicide Risk in Primary Care, and to develop a new recommendation on screening for anxiety disorders.

## Condition Background

### Condition Definitions

#### Depression

Major Depressive Disorder (MDD) is a mood disorder characterized by persistent feelings of sadness and loss of interest in usually pleasurable activities, and may be accompanied by irritability, changes in sleeping patterns and appetite, aches and pains, restlessness, and feelings of low self-worth.^3^ The fifth edition of the Diagnostic and Statistical Manual of Mental Disorders (DSM-5) describes depression as a “common and serious medical illness that negatively affects how you feel, the way you think, and how you act.”^4^ Perinatal depression refers to major and minor depressive episodes that occur during pregnancy and the postpartum period, which is often defined as the first 12 months following delivery.^5^ In addition to the typical symptoms of depressive disorders (e.g., feeling hopeless, loss of interest in activities that used to be enjoyed, withdrawing from friends and family), other symptoms in the perinatal period may also include a persistent doubt of the ability to take care of the infant, trouble bonding with or forming an emotional attachment with the infant, and thoughts of death, suicide, self-harm or harm of the infant.^6^

#### Anxiety

Anxiety disorders are characterized by excessive and persistent fear and anxiety about everyday events, along with related behavioral and somatic complaints such as autonomic arousal, restlessness, fatigue, problems concentrating, irritability, and sleep problems.^4^ Anxiety disorders include generalized anxiety disorder, social anxiety disorder, panic disorder, agoraphobia, specific phobias, separation anxiety disorder, selective mutism, substance/medication-induced anxiety disorder, anxiety disorder due to another medical condition, and anxiety not otherwise specified.

#### Suicide Risk

Suicide is defined as an intentional act of inflicting one’s own death. Suicide attempts and ideation (thoughts of killing oneself or wishing to be dead), as well as self-harm (a broader term that includes suicide attempts as well as self-injury without intent of death) are more common than suicide deaths and often signal a precursor to suicide and a potential intervention point.^7^ However, it can be challenging to ascertain the intent of patients with self-inflicted injury. Suicide, suicide attempts, suicidal ideation, and self-harm can occur with various psychiatric diagnoses, including depressive and anxiety disorders.^7^

### Prevalence and Burden

#### Depression

Depression is a common mental disorder in the US, with substantial economic costs. In 2019, an estimated 7.8 percent of US adults (19.4 million adults) experienced at least one major depressive episode and 5.3 percent of adults (13.1 million individuals) experienced a major depressive episode with severe impairment (Table 1).^8^ The average prevalence of postpartum depressive symptoms across 31 sites was 13.2 percent in 2018,^9^ according to the Data from the Pregnancy Risk Assessment Monitoring System (PRAMS). Aggregate data from the PRAMS survey showed an increase in self-reported depression during pregnancy from 11.6 percent in 2016 to 14.8 percent in 2019.^10^A study using national survey and administrative claims data found that between 2010 and 2018, the incremental economic burden of individuals with MDD alone increased by 37.9% from $236.6 billion to $326.2 billion (2020 values).^11^

Table 1 Percent of U.S. Adults With a Major Depressive Episode in the Past Year, 2019

Category | Total (2019) | Male (2019) | Female (2019)
Total | 7.8 | 6.0 | 9.6
Age, yrs
18–25 | 15.2 | 11.1 | 19.4
26–49 | 8.9 | 6.6 | 11.1
50 or Older | 4.7 | 3.8 | 5.6
65 or Older | 3.3 | 3.0 | 3.5
Hispanic origin and race
Not Hispanic or Latino | 8.0 | NR | NR
White | 8.5 | NR | NR
Black or African American | 6.3 | NR | NR
American Indian or Alaska Native | 9.4 | NR | NR
Native Hawaiian or Pacific Islander | 3.5 | NR | NR
Asian American | 4.7 | NR | NR
Two or more races | 13.7 | NR | NR
Hispanic or Latino | 6.8 | NR | NR

Source: SAMHSA, Center for Behavioral Health Statistics and Quality, National Survey on Drug and Health, 2019.^455^

Abbreviation: NR = not reported.

Women have nearly double the risk of depression compared to men, though the mechanisms underlying this disparity are unclear. It has been hypothesized that social and economic circumstances, as well as biology (e.g., endocrine or neurobiological differences, pregnancy and postpartum changes) may contribute to this gap.^12,^ ^13^ In addition to varying by sex, prevalence rates among the general American adult population vary by age, race and ethnicity, education, geographic location, poverty level, and employment. Young adults, multiracial, and Native American/Alaska Native individuals experience higher rates of depression.^14^

Depression has a significant impact on quality of life, personal relationships, and self -care.^15^ Depression, especially untreated, is associated with increased mortality, higher risk of cardiovascular events, and may exacerbate comorbid conditions.^16–18^ Depression during pregnancy increases the risk of preterm birth and small-for-gestational age^19,^ ^20^ infants, and postpartum depression interferes with optimal parenting to promote infant bonding.^21^ A systematic review exploring neonatal risks associated with untreated prenatal depression found that pregnant women with untreated depression had an increased risk of both preterm birth and low birthweight compared with women without depression.^20^ A Canadian study found that young children exposed to maternal depression had a 17 percent higher risk of having at least one developmental vulnerability at school entry, such as difficulties in social competence (adjusted relative risk [aRR], 1.28 [95% CI, 1.20 to 1.38]), physical health and well-being (aRR, 1.28 [95% CI, 1.20 to 1.36]), and emotional maturity (aRR, 1.27 [95% CI, 1.18 to 1.37]).^22^

#### Anxiety

We found no recent estimates of the prevalence of anxiety disorders among adults in the US. In 2001–2004, an estimated 19.1 percent of adults had an anxiety disorder in the past year, according to the National Comorbidity Survey-Replication study (Table 2).^23^ The lifetime prevalence of anxiety disorders in adults in the US is 40.4 percent for women and 26.4 percent for men, according to data collected in 2001–2002.^24^ More recent data from the 2019 National Health Interview Survey focus on the presence of generalized anxiety disorder (GAD) symptoms according to the GAD-7 screening questionnaire, and found that 9.5%, 3.4%, and 2.7% of adults had experienced mild, moderate, or severe symptoms of anxiety in the past 2 weeks, respectively.^25^ According to this survey, anxiety symptoms were highest among those aged 18–29 and decreased with age, and were higher in women than in men. Asian-American adults were least likely to experience anxiety symptoms compared with Hispanic, non-Hispanic White, and non-Hispanic Black adults. Perinatal GAD has an estimated prevalence of 8.5 percent–10.5 percent during pregnancy and 4.4 percent–10.8 percent postpartum.^26^ During August 2020-February 2021, the percentage of adults with recent symptoms of an anxiety or a depressive disorder increased from 36.4 percent to 41.5 percent.^27^

Table 2 12-Month Prevalence of DSM-IV/WMH-CIDI Disorders by Sex and Cohort (n=9,282)^456^

Demographic characteristic | Any anxiety disorder, % | Panic disorder | Generalized anxiety disorder | Social phobia^*^
Total | 19.1 | 2.7 | 2.7 | 7.1
Gender
Male | 14.3 | 1.6 | 1.9 | 6.1
Female | 23.4 | 3.8 | 3.4 | 8.0
Age
18–29 | 22.3 | 2.8 | 2.0 | 9.1
30–44 | 22.7 | 3.7 | 3.5 | 8.7
45–59 | 20.6 | 3.1 | 3.4 | 6.8
60+ | 9.0 | 0.8 | 1.5 | 3.1

* Social phobia was the term used at the time of the original survey and was replaced by the term “Social Anxiety Disorder.”

Abbreviations: DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, 4^th^ edition; WMH-CIDI = World Health Organization World Mental Health Composite International Diagnostic Interview.

Anxiety disorders are associated with impaired quality of life^28^ and functioning,^29^ and substantial economic costs.^30^ One review estimated average health expenditures attributable to anxiety disorders among countries in the Organization for Economic Cooperation and Development (OECD) to be $135 billion.^31^ A meta-analysis indicated that anxiety disorders are a statistically significant, albeit weak, predictor of suicide ideation and attempts.^32^ According to the Global Burden of Disease study, anxiety disorders were the sixth leading cause of disability in high income countries in 2010.^33^ A prospective examination of data from the 2011 National Health and Aging Trends Study found that depression and anxiety symptoms in adults without disability or impairments were prospectively associated with disability and impairments in self-care and household activities 5 years later.^34,^ ^35^ A large retrospective cohort study of the impact of anxiety disorders during pregnancy found that anxiety was an independent risk factor for preterm delivery (adjusted OR 1.8, 95% CI 1.32–2.69; P < 0.001), hypertensive disorders during pregnancy (adjusted OR 1.7, 95% CI 1.08–2.69; P = 0.02) and cesarean delivery (adjusted OR 1.6, 95% CI 1.32–2.1; P < 0.001).^36^ Perinatal anxiety can potentially impact mother–infant bonding and influence neurodevelopmental outcomes in children,^26^ and offspring born to mothers with anxiety disorders during pregnancy had higher rates of neuropsychiatric-related hospitalizations (6.3 vs 3.1% P = 0.002; Kaplan-Meier log-rank test P < 0.001).^36^

#### Suicide Risk

In 2019, a total of 47,511 deaths were attributable to suicide (Table 3).^37^ Suicide was the tenth leading cause of death in adults in 2019, accounting for 45,861 deaths.^38^ In the same year, an estimated 381,295 adults visited hospital emergency department for nonfatal, self-inflicted injuries. From 2001 to 2017, there was a 31 percent increase in the number of suicide deaths in the US.^39^ Overall rates flattened and even declined^40^ in recent years; provisional suicide counts in 2020 numbered 45,855, which was 3% less than in 2019 (47,511).^41^ However, rates did not decline among Black and Hispanic persons.^42^ In 2017, suicide accounted for over 1.8 million years of potential life lost (YPLL) before the age of 85 years—nearly five percent of total YPLL in the US.^43^ Disorders that most strongly predict suicide attempts are bipolar disorder, PTSD, and MDD; the increased risk of suicide attempts for people with these disorders appears to be mediated by the increased risk of suicidal ideation with these disorders.^44^ Additionally, hopelessness is predictive of suicide and suicide attempts among those with suicidal ideation, but research has not supported impulsivity as a predictor of suicide attempts.^44^

Table 3 Annual Number and Age-Adjusted* Rate of Suicide^†^ per 100,000 Population, National Vital Statistics System, United States, 2019^37^

Demographic characteristic | Total no. (rate) | Male no. (rate) | Female no. (rate)
Total | 47,511 (13.9) | 37,256 (22.4) | 10,255 (6.0)
Age group, yrs
10–14 | 534 (2.6) | 331 (3.1) | 203 (2.0)
15–24 | 5,954 (14.0) | 4,800 (22.0) | 1,154 (5.5)
25–34 | 8,059 (17.5) | 6,533 (28.0) | 1,526 (6.8)
35–44 | 7,525 (18.1) | 5,815 (28.0) | 1,526 (6.8)
45–54 | 8,012 (19.6) | 5,856 (29.0) | 2,156 (10.4)
55–64 | 8,238 (19.4) | 6,290 (30.7) | 1,948 (8.9)
65–74 | 4,867 (15.5) | 3,882 (26.4 | 985 (5.9)
75–84 | 2,977 (18.6) | 2,567 (36.7) | 410 (4.6)
≥85 | 1,329 (20.1) | 1,171 (49.3) | 158 (3.7)
Hispanic origin and race
White | 37,428 (17.7) | 29,382 (28.1) | 8,046 (7.7)
Black or African American | 3,115 (7.5) | 2,491 (12.5) | 624 (2.9)
American Indian/Alaska Native | 546 (22.5) | 401 (33.0) | 145 (12.1)
Native Hawaiian/Pacific Islander | 90 (14.4) | 72 (22.1) | 18 (-)
Asian | 1,342 (6.7) | 950 (10.1) | 392 (3.7)
Multiracial | 527 (8.8) | 405 (14.2) | 122 (3.9)
Hispanic | 4,331 (7.3) | 3,445 (11.6) | 886 (3.0)
Unknown | 132 (-) | 110 (-) | 22 (-)

Men are more than three times more likely to die from suicide than women.^45^ The highest suicide rates for women occur between the ages of 45 and 54 years, while for men the highest rates are over age 65 years.^39^ Suicide rates vary by race. In the US, the highest age-adjusted suicide rates are among adults who are White, followed by American Indians and Alaska Natives.^45^ From 2018–2019, the overall age-adjusted rates of suicide decreased for White and American Indian or Alaska Native individuals; however, between 2014 and 2019 the age-adjusted rate increased for Black individuals by 30 percent, and Asian or Pacific Islander individuals by 16 percent.^46^ Military veterans are 1.5 times more likely to die by suicide than non-veteran adults, and that rate is even higher for female veterans.^47^ However, veterans are not more likely to report suicide attempts or suicidal ideation compared to nonveterans.^2^ A similar pattern of risk is seen for suicide attempts. A recent analysis exploring suicide risk during the years 2008–2019 indicate the following relative increased risks for suicide attempts: serious psychological distress (aOR, 7.51 [95% CI, 6.49–8.68]; P < .001), major depressive episodes (aOR, 2.90 [95% CI, 2.57–3.27]; P < .001), alcohol use disorder (aOR, 1.81 [95%CI, 1.61–2.04]; P< .001), divorced or separated (aOR, 1.65 [95% CI, 1.35–2.02]; P < .001), unemployed (aOR, 1.47 [95% CI, 1.27–1.70]; P< .001), identified as Black (aOR, 1.41 [95% CI, 1.24–1.60]; P < .001), identified as American Indian or Alaska Native, Asian, or Native Hawaiian or Other Pacific Islander (aOR, 1.56 [95% CI, 1.26–1.93]; P < .001).^48^

According to data from the National Survey on Drug Use and Health during years 2015–2019, 4.3 percent of US adults (10.6 million (annual average)) reported having suicidal thoughts during the previous year.^38^Additionally, an estimated 1.3 percent of adults (3.1 million adults) in the US made suicide plans and 0.6 percent (1.4 million) attempted suicide (Table 4).^38,^ ^49^ Female adults when compared with male adults, and younger adults (aged 18–39) compared with adults at or older than 40 were more likely than males to have suicidal thoughts, made plans to kill themselves, or attempted suicide in the past year.^38^An estimated 381,295 adults visited hospital emergency department for nonfatal, self-inflicted injuries.^38^ The cost for suicides and suicide attempts in the US in 2013 was estimated at $58.4 billion, including lost productivity costs.^50^

Table 4 Percent of U.S. Adults With Serious Thoughts of Suicide/a Suicide Attempt and in the Past Year, 2019^455^

Demographic characteristic | Aged 18+ (2019) | Aged 18–25 (2019) | Aged 26–49 (2019) | Aged 50+ (2019)
Total | 4.8 / 0.6 | 11.8 / 1.8 | 5.3 / 0.6 | 2.4 / 0.2
Gender
Male | 4.5 / 0.4 | 9.8 / 1.3 | 4.8 / 0.5 | 2.5 / 0.1
Female | 5.1 / 0.7 | 13.7 / 2.3 | 5.8 / 0.6 | 2.3 / 0.3
Hispanic origin and race
Not Hispanic or Latino | 4.8 / 0.5 | 12.3 / 2.0 | 5.4 / 0.6 | 2.4 / 0.2
White | 5.0 / 0.5 | 13.1 / 1.8 | 5.9 / 0.5 | 2.6 / 0.2
Black or African American | 4.0 / 0.8 | 10.0 / 2.4 | 4.3 / 0.9 | 1.4 / 0.1
American Indian/Alaska Native | 5.1 / 0.5 | 11.4 / 1.8 | 5.0 / 0.6 | *
Native Hawaiian/Pacific Islander | 2.3 / 0.4 | * | 0.9 / 0.1 | *
Asian | 3.6 / 0.4 | 9.1 / 2.0 | 3.5 / 0.2 | 1.6 / *
Two or more races | 6.9 / 1.5 | 15.9 / 4.5 | 6.9 / 1.2 | * / 0.1
Hispanic or Latino | 5.0 / 0.6 | 10.0 / 1.2 | 4.9 / 0.6 | 2.2 / 0.2

* = low precision.

### Etiology and Natural History

#### Depression

The causes of depression are likely multifactorial, including both biological and environmental factors.^51^ The onset of depression can occur at any age, but most frequently begins in adolescence or early adulthood.^52,^ ^53^ Experiencing trauma or adverse life events increases the likelihood of developing depression, though underlying biology may predispose persons affected by environmental stimuli, such as life events, to a greater or lesser extent.^54,^ ^55^ It is also suspected that heritability is a factor in developing depression: first-degree relatives of individuals diagnosed with depression have a two- to three-times greater risk of developing depression compared to the general population.^56^ Additionally, several twin studies and family cohorts have estimated the heritability of depression, though these studies offer only associational insights.^57^ Other risk factors for developing depression include a history of childhood sexual abuse,^58^ intimate partner violence,^59^ comorbid mental health diagnoses, substance abuse, and certain illnesses, such as stroke and cardiovascular disease events.^60^ Some medications, such as hormonal contraception and β-blockers, may also increase one’s risk of developing depression.^61,^ ^62^ Among older adults social isolation is in important risk factor for depression and other mental health concerns.^63^ Risk factors for perinatal depression include stress, lack of social support, current or past abuse, history of depression, and marital or partner dissatisfaction.^64^

In addition, structural inequities that disadvantage Black, Hispanic, and Native American families are numerous. Examples include housing policies (e.g., redlining, home loan financing), drug and criminal justice policies (e.g., treatment of crack versus power cocaine), employment policies (e.g., exclusion of agricultural and domestic workers from unemployment and retirement benefits) and disinvestment in communities with a high proportion of Black, Hispanic, and Native American residents.^65^ Challenges posed by structural inequities and by the resulting income inequalities have a damaging impact on mental health in disadvantaged communities, and have been specifically correlated with depression prevalence,^66,^ ^67^ For example, unemployment, precarious employment, low income, race/ethnicity, immigrant status, sexual orientation, and/or occupational status have all been associated with higher risk of depression.^68^ Interestingly, evidence based on the National Survey of American Life suggests that race, gender, income, and education interact as risk and protective factors for depression.^69^ This study found that white women benefit more from income, Black women benefit from education, but high income (above and beyond education, employment, and marital status) may become a risk factor for Black men.

The COVID-19 pandemic and increasing numbers of serious natural disasters affecting the US have had an important impact on mental health. A 2020 review concluded that the psychological effects of the current pandemic as well as past epidemics and natural disasters suggest numerous psychological impacts.^70^ Alcohol use, PTSD, anxiety, anger, fear of contagion, perceived risk, uncertainty, and distrust are a few of the immediate and long-term effects that are likely to result from the COVID-19 pandemic.

Depression can be a chronic condition and is characterized by periods of remission and recurrence of various lengths, though this varies individually.^71^ Severity of depression at diagnosis may influence time to remission or relapse rate after treatment, with moderate to severe depressive episodes being slower to remit.^72^ Level of functioning, comorbidities, and adherence to treatment also play a role in recovery rates.^73^ Some people do fully recover. A community survey of Canadian adults found that, among those with a history of depression, 39 percent met the study’s definition of complete mental health, which included the presence of happiness or life satisfaction and social and psychological well-being, as well as the absence of mental health disorders.^74^

#### Anxiety

Anxiety disorders often have onset during childhood and adolescence, with a median age of onset of 11 years.^75^ Prevalence of anxiety disorders tends to decrease in the middle and older adult years, and is the lowest among those age 65 to 79.^75^ The lifetime prevalence of anxiety disorders in adulthood is higher for women (40.4%) than men (26.4%).^24^ Risk factors for anxiety disorders in adults are wide-ranging and include sociodemographic factors (female sex, non-Hispanic ethnicity, African-American race, marital status of widowed or divorced, economic deprivation), psychosocial factors (stressful life events, smoking and alcohol use), and physical and mental health factors (presence of other mental health conditions, parental history of mental disorders).^76^ In addition, anxiety and depression strongly overlap. One cohort study found that 67 percent of individuals with a depressive disorder also had a current anxiety disorder, and 75 percent had a lifetime comorbid anxiety disorder.^77^ Like depression, the course of anxiety tends to be chronic,^75^ yet some people do recover. Similar to the findings for depression, 40 percent of adults with a history of generalized anxiety disorder who completed a Canadian community survey met the study’s definition of complete mental health.^78^

#### Suicide

Suicide death is very rare prior to adolescence.^39^ Regardless, it is the second-leading cause of death in age groups 10 to 34 years of age.^23^ Many young adults experience suicidal thoughts—in 2017, 10.5 percent of young adults age 18 to 25 experienced suicidal thoughts in the US, and 1.9 percent attempted suicide.^23^ A previous suicide attempt is the strongest predictor of future suicide death.^79^ Suicide and suicide behavior are complex and predictors are multifactorial, and models have been developed to attempt to describe various factors and pathways.^44,^ ^80^ A wide range of risk factors are associated with suicide, including the presence of depression, other mental health disorders, and substance abuse; family history of mental health disorders, substance abuse, or suicide; certain medical conditions; chronic pain; family violence or abuse; having firearms in the home; and recent incarceration.^81^ A study that examined the medical charts of 157 people who had died by suicide indicated that 70 percent or more had each of the following risk factors: prior suicidal ideation or suicide attempt; anxiety or agitation; sleep problems; current strain related to intimate partner, job, or finances; a mood disorder diagnosis; and had acquired the means for suicide.^82^ A separate study of 421 people who had died during pregnancy determined that, among persons who died by suicide during pregnancy, 72% had a history of depression.^83^

### Rationale for Screening

Depression and anxiety are relatively common, a source of tremendous suffering, are often unrecognized in primary care settings,^84,^ ^85^ and years-long delays in treatment initiation are the norm.^86^ If effective, routine screening could substantially increase the likelihood that patients receive treatment, potentially saving years of suffering and reducing economic burden. While suicide is rare, it is catastrophic and in many cases likely preventable.^7^ From 2008 through 2019, 34.8 percent to 45.5 percent of adults with a suicide attempt reported needing services but did not receive them, with no significant change from 2008 to 2019.^48^ Screening has the potential to substantially increase identification of patients in need of further evaluation and referral to treatment and may prevent suicide deaths.

### Screening Strategies

Screening for mental health conditions involves administration of brief questionnaires to determine whether people have been experiencing mental health symptoms. Thus, patients who screen positive are not asymptomatic but rather have symptoms that have not been detected by the healthcare clinician. Many brief screening tools have been developed that may be used to screen for depression, anxiety, or suicide risk and are appropriate for use in primary care. For all conditions, rather than assigning a diagnosis based on a positive screening test, patients who screen positive should receive a more thorough assessment to determine symptom severity, whether a mental health condition is present, the need for treatment, patient treatment history and preferences, and the most important impacts of the condition for the patient.

Potential barriers to implementation of screening include provider knowledge and comfort level with screening, provider access to effective screening instruments, and impact on care flow. In addition, a trusting relationship with a clinician who is sensitive to cultural issues and free of implicit bias is an important part of effective mental health screening and accurate diagnosis. Implicit bias may be reflected, for example, by the fact that Black adults have a higher rate of being diagnosed with schizophrenia,^87^ a phenomena that has been documented across approximately 30 years. One group of researchers found evidence to support a pattern of under-recognition of mood-related symptoms and over-emphasis of psychotic-spectrum symptoms, suggesting racial bias in the diagnosis of schizophrenia spectrum disorders that might also contribute to underdiagnosis of mood disorders.^88,^ ^89^Other evidence suggests a tendency for differences in symptom presentation across racial and ethnic groups, highlighting the need for cultural sensitivity.^90,^ ^91^ See Appendix H for a more extensive discussion of racial and ethnic differences in diagnosis and presentation.

We have identified selected tools that appear to be most widely used or recommended for use in the US (Table 5)^92–96^. Some of these tools were not specifically designed for screening, but were developed for purposes such as supporting diagnosis, assessing severity, or monitoring treatment response, but may be feasible as screening tools.

Table 5 Most Commonly Used and Recommended Depression, Anxiety, and Suicide Risk Screening Tools for Relevant Patient Populations

Condition | Instrument | No. of items (range of scores) | Typical cut-points
Depression | Patient Health Questionnaire–Depression (PHQ-9)^269,^ ^457^ (2-item version is also available)^458^ | 9; (0 to 27) | <5 = minimal; 5 to 9 = mild; 10 to 14 = moderate; 15 to 19 = moderately severe; 20 to 27 = severe
Depression | Patient Health Questionnaire–Panic Disorder (PHQ-PD)^269^ | 5; (NA, algorithm used) | NA, positive score is indicated if questions 3a–d are all answered with yes (sum score 4) in combination with four or more other items of question 4 answered with yes (sum score ≥4)
Depression | Center for Epidemiologic Studies Depression Scale (CES-D)^459,^ ^460^ | 20; (0 to 60) | ≥ 6
Depression | Edinburgh Postnatal Depression Scale (EPDS)^461^ | 10; (0 to 30) | 0 to 9 = mild distress; 10 to 12 = moderate distress; 13 = high likelihood of diagnosis
Depression | Geriatric Depression Scale, 15-item (GDS Short Form)^462^ | 15; (0 to 15) | ≥6
Anxiety | Generalized Anxiety Disorder scale (GAD), 2- and 7-item versions^29,^ ^270^ | 2; (0 to 6) | ≥3
Anxiety | Generalized Anxiety Disorder scale (GAD), 2- and 7-item versions^29,^ ^270^ | 7; (0 to 21) | 0 to 4 = minimal; 5 to 9 = mild; 10 to 14 = moderate; 15 to 21 = severe
Anxiety | EPDS-Anxiety subscale^463^ | 3; 0 to 9 | ≥6
Anxiety | Geriatric Anxiety Scale (GAS),^464^ GAS-10 | 30; (0 to 75) | NR
Anxiety | Geriatric Anxiety Scale (GAS),^464^ GAS-10 | 10; (0 to 30) | NR
Anxiety | Geriatric Anxiety Inventory (GAI),^465^ GAI-Short Form (GAI-SF)^466^ | 20; (0 to 20) | ≥11
Anxiety | Geriatric Anxiety Inventory (GAI),^465^ GAI-Short Form (GAI-SF)^466^ | 5; (0–5) | ≥3
Depression and anxiety | Patient Health Questionnaire–Anxiety-Depression Scale (PHQ-ADS)^467^ (Combination of the PHQ-9 and GAD-7) | 16; (0 to 48) | 0 to 9 = minimal; 10 to 19 = mild; 20 to 29 = moderate; 30 to 48 = severe
Suicide risk | PHQ-9 suicide item^269,^ ^457^ | 1; (0 to 1) | 1
Suicide risk | Columbia-Suicide Severity Rating Scale (C-SSRS)^468^ | 6; (NA, algorithm used) | NA, 4 levels of risk with different clinical actions
Suicide risk | SAD PERSONS Scale^469^ | 10; (0 to 10) | 0 to 4 = low; 5 to 6 = moderate; 7 to 10 = high
Suicide risk | Manchester Self-Harm Rule^470^ | 4; (NA) | Yes to any item
Suicide risk | ReACT Self-Harm Rule^471^ | 4; (NA) | Yes to any item
Suicide risk | Beck Hopelessness Scale^472^ | 20; (0 to 20) | 0 to 3 = normal; 4 to 8 = mild hopelessness; 9 to 14 = moderate hopelessness; >14 = severe hopelessness
Suicide risk | SAFE-T^473^ | NA, semi-structured assessment | Assessment of risk level (Low, Moderate, or High) based on clinical judgement, after completing proposed steps 1 through 3

Abbreviations: EPDS-Anxiety subscale = Edinburgh Postnatal Depression Scale - Anxiety subscale; NA = not applicable; NR = not reported; SAD PERSONS = Sex, Age, Depression, Previous attempt, Ethanol abuse, Rational thinking loss, Social supports lacking, Organized plan, No spouse, Sickness; SAFE-T = Suicide Assessment Five-step Evaluation and Triage.

### Treatment Approaches, First-Line Treatments

Identification of mental health conditions alone is not always sufficient to ensure effective treatment in primary care settings. Rather, successful treatment requires a number of steps, including recognition that a patient is depressed, treatment initiation (often including referral and care coordination), and completion of an adequate course of treatment.^97^

First-line treatments for all of these disorders include psychotherapy (e.g., cognitive behavioral, interpersonal, family, and acceptance and commitment therapy) and pharmacotherapy (e.g., antidepressants, see Table 6).^98–100^ Anxiety treatment may also include focused work on relaxation and desensitization, and some medications that are specific to anxiety (e.g., benzodiazepines). Interventions developed for people at high risk of suicide can include dialectical behavioral therapy, cognitive behavioral therapy for suicide prevention (CT-SP), and collaborative assessment and management of suicide risk (CAMS).^44^ Interventions for those at high risk of suicide may include suicide-specific components such as safety assessment, means restriction, and pharmacological agents that may be specifically directed at suicide risk (e.g., lithium) as well as psychological and pharmacologic treatment aimed at underlying mental health conditions. Dialectical behavior therapy is a variant of cognitive behavioral therapy that has been used in patient populations at high risk of suicide, particularly those diagnosed with Borderline Personality Disorder.^101,^ ^102^

Table 6 Pharmacotherapy Treatment

Drug class | Generic names
Selective serotonin reuptake inhibitors (SSRIs) | Citalopram, escitalopram, fluoxetine, fluvoxamine (CR), paroxetine (CR), sertraline
Selective serotoninin norephinephrine re-uptake inhibitors (SNRI) | Desvenlafaxine, duloxetine, levomilnacipran, milnacipran, venlafaxine (XR)
Atypical agents | Bupropion, mirtazapine
Serotonin modulators | nefazodone, trazodone, vilazodone, vortioxetine
Tricyclic and tetracyclic antidepressants | Amitriptyline, amoxapine, clomipramine, desipramine, doxepin, imipramine, ma protiline, nortriptyline, protriptyline, trimipramine
Azapirone | Buspirone
Neuroactive steroid gamma-aminobutyric acid (for perinatal depression only) | Brexanolone
Antimanic agents (for suicide risk only) | Lithium
Benzodiazepines (for anxiety only) | Alprazolam, chlordiazepoxide, clonazepam, clorazepate, diazepam, estazolam, flurazepam, lorazepam, midazolam, oxazepam, temazepam, triazolam, quazepam

Abbreviations: CR = controlled release; XR = extended release.

Given the high degree of overlap between depression and anxiety, transdiagnostic approaches have been developed for use with patients who have either or both conditions. This approach focuses on identifying common maladaptive psychological, cognitive, emotional, interpersonal, and behavioral processes that underpin a broad array of mental health challenges.^103^ This approach is consistent with the Research Domain Criteria (RDC) promoted by the National Institute for Mental Health that focuses on underlying mechanisms related to mental health (e.g., cognition, negative affect, arousal) rather than focusing ICD or DSM diagnosis.^104^

### Current Clinical Practice in the United States and Recent Recommendations

Despite the USPSTF recommendation to screen for depression, data from a nationally representative survey of adults ages 35 and older conducted in 2014 and 2015 indicated that only 49 percent had been screened or assessed for depression at a routine health care visit in the past year (i.e., agreed that a health care professional had asked them about their mood, “such as whether you are anxious or depressed”).^105^ Adults who were males, older than age 75 years, uninsured, Black, of Asian or Hispanic ethnicity, and who had lower educational attainment were less likely to have been screened than their counterparts in this study. Screening rates are much lower when based on medical records documentation. Data from the 2012 and 2013 National Ambulatory Medical Care Survey (NAMCS) found that only 4.2 percent of adults without known existing depression were screened for depression at primary care visits.^106^ During perinatal care visits, 79.1 percent of women reported that a health care provider asked about depression, and 87.4 percent of women reported that a provider asked about depression during postpartum visits.^9^

Depression screening rates do appear to be increasing, however, since the USPSTF initially issued its B recommendation to screen in 2009. An analysis of NAMCS data from 2005 through 2015 found that screening rates among adults without a known depression diagnosis who made an ambulatory care visit to a non-psychiatrist steadily increased from a low of 0.65 percent in 2008 (one year prior to first USPSTF recommendation to screen adults for depression) to 3.0 percent in 2015.^107^ In the absence of screening, it is estimated that only 50 percent of patients with major depression are identified.^84^ Depression is undiagnosed in pregnant women who have experienced a major depressive episodes more often than in nonpregnant women of reproductive age (66% undiagnosed vs. 59%), despite having more frequent contact with the healthcare system.^108^ According to the World Health Organization’s World Mental Health Initiative, only 35 percent of adults in the US with a depressive disorder initiated treatment in the first year of depression onset, and the median time to treatment initiation was 4.0 years.^86^

We did not find information on screening rates for anxiety and suicide risk. Anxiety disorders do not appear to be regularly screened for in most U.S. primary care settings, and under-detection appears to be common. For example, one study of primary care patients in Quebec, Canada found that only 52.5 percent of primary care patients with generalized anxiety disorder were recognized as having the disorder.^85^ Under-detection may be related to the fact that patients with anxiety disorders often present with other complaints. For example, one study found that only 13.3 percent of primary care patients with generalized anxiety disorder presented with anxiety as the chief complaint; more common complaints in these patients were somatic complaints (47.8%), pain (34.7%), and sleep disturbance (32.5%).^109^ Delays in treatment initiation appear even more pronounced than for depressive disorders: according to the World Mental Health Initiative, only 11 percent of American adults with an anxiety disorder initiated treatment within the first year of onset, and the median time to treatment initiation was 23.0 years.^86^

Suicide screening likely primarily occurs as part of depression screening, among settings that have implemented suicide screening. For example, the PHQ-9 includes an item on suicidal ideation, and an affirmative response to this item typically warrants followup that may include administration of a more extensive suicide risk assessment or instrument. It is unclear how frequently high suicide risk is detected in primary care, in the absence of routine screening. Only 36 percent of U.S. primary care providers discussed suicide in encounters with patients portraying major depression, adjustment disorder, or seeking antidepressants.^110^ Further, one study found that as many as 83 percent of individuals who died by suicide had a health care visit in the prior year, yet only 24 percent had a mental health diagnosis in the four-week period prior to death. Together, these data indicate that primary care clinicians likely have underutilized opportunities to identify patients who are at a high risk of suicide.^111^

Even though individuals may be screened for depression and diagnosed, many do not receive adequate treatment. Less than half of people who experience a mental illness will receive mental health care.^112,^ ^113^ There are systemic barriers, such as lack of connection between mental health and primary care, as well as patient hesitation to initiate treatment and non-adherence to medication and therapy.^112,^ ^114^ For example, a study of 965 primary care patients in the U.S. found that only 41 percent of patients with an anxiety disorder were receiving treatment for their disorder.^29^ We were unable to find information on treatment and referral rates for high suicide risk among patients identified in U.S.-based primary care settings.

### Recommendations of Others

Several professional organizations recommend universal screening for depression in the general adult population.^115–119^ However, the National Institute for Health and Care Excellence (NICE) recommends only that providers administer a brief, question-based screener to patients they suspect may have depression, and the Canadian Task Force on Preventive Health Care (CTFPHC) similarly recommends against routinely screening for depression in adults who are at average risk.^120,^ ^121^ The UK’s National Screening Committee state that the reasons for not recommending depression screening include concerns about false positive screens, uncertainty as to whether screening reduced depression, whether treatment of mild depression was effective, and concerns about how well depression is managed in the UK.^122^ Screening for postpartum depression is recommended by several professional organizations.^5,^ ^123,^ ^124^ The American College of Obstetricians and Gynecologists and the Center Of Perinatal Excellence also recommend anxiety screening for perinatal^124^ or postpartum^5^ women, however NICE again recommends only that clinicians be alert to the possibility of anxiety disorders rather than recommending broad routine screening.^125^ The Women’s Preventive Services Initiative (WPSI) recommends that screening for anxiety should include all female patients aged 13 years and older not currently diagnosed with anxiety disorders, including pregnant and postpartum women.^126^ Both the Department of Veterans Affairs and the Canadian Coalition for Seniors’ Mental Health recommended regular screening for suicide risk.^127–129^ The Michigan Quality Improvement Consortium recommends suicide screening only for individuals diagnosed with depressive disorders.^130^ See Table 7 for a brief description of these and other relevant guidelines.

Table 7 Other Relevant Guidelines on Screening for Depression, Anxiety, and Suicide

Condition | Organization, year | Recommendation(s)
Depression | American Academy of Family Physicians (AAFP), 2018 | The AAFP recommends screening for depression in the general adult population. Screening must be implemented with adequate systems in place to ensure accurate diagnosis, effective treatment, and appropriate followup. Pregnant women should be screened for depression at least once during the perinatal period using a validated screening instrument such as the Edinburgh Postnatal Depression Scale or the PHQ-9. Consider screening at least once during pregnancy and again 4 to 8 weeks after delivery.^115^ These recommendations are based on the 2016 USPSTF recommendation.^133^
Depression | American Academy of Pediatrics (AAP), 2019 | The AAP recommends that pediatricians screen mothers for postpartum depression at the infant’s -, 2-, and 4-month visits.^123^
Depression | American College of Physicians (ACP), 2013 | The ACP recommends clinicians screen for depression as the first step in a systematic evaluation of mood disorders in all adults. Adults who are postpartum, have a personal or family history of depression, or have comorbid medical illnesses are at increased risk. The ACP states the PHQ-2 is a widely used and efficient screening tool for depression.^474^
Depression | American College of Preventive Medicine (ACPM), 2009 | ACPM recommends universal screening for depression for all adults and that the earliest and best opportunities to identify depression are in the clinics of primary care providers.^116^
Depression | American College of Obstetricians and Gynecologists (ACOG), 2018 | ACOG recommends that all obstetrician–gynecologists and other obstetric care providers complete a full assessment of mood and emotional well-being (including screening for postpartum depression and anxiety with a validated instrument) during the comprehensive postpartum visit for each patient. If a patient is screened for depression and anxiety during pregnancy, additional screening should then occur during the comprehensive postpartum visit. There is evidence that screening alone can have clinical benefits, although initiation of treatment or referral to mental health care providers offers maximum benefit.^5^ All patients with depression should be evaluated for suicidal thinking and previous suicide attempts; this evaluation is best done by direct questioning. If a woman has specific plans or significant risk of suicide, such as prior attempts or hopelessness, a mental health specialist should be consulted immediately.^475^
Depression | American Psychiatric Association (APA), 2018 | All perinatal patients should be evaluated for depressive, anxiety, and psychotic disorders throughout the pregnancy and postpartum period. We recommend screening for depression with a validated screening tool twice during pregnancy, once in early pregnancy for pre-existing psychiatric disorders and once later in the pregnancy; we also recommend postpartum patients be screened for depression during pediatric visits throughout the first 6 months postpartum as recommended by the American Academy of Pediatrics. A systematic response to screening should be in place to ensure that psychiatric disorders are appropriately assessed, treated, and followed.^476^
Depression | Association of Women’s Health, Obstetric and Neonatal Nurses (AWHONN), 2022 | All pregnant and postpartum women should be screened for mood and anxiety disorders. Nurses are in key positions to screen women, provide education regarding perinatal mood and anxiety disorders to pregnant and postpartum women and their families, and ensure appropriate treatment referrals.^477^
Depression | Canadian Task Force on Preventive Health Care (CTFPHC), 2013 | The CTFPHC recommends against routinely screening for depression in adults who are at average risk of depression or in subgroups of the population who may be at increased risk of depression.^120^
Depression | Centre of Perinatal Excellence (COPE), 2017 | COPE endorses using the Edinburgh Postnatal Depression Scale (EPDS) to screen for a possible depressive disorder in the perinatal period and to arrange further assessment of perinatal women with an EPDS score ≥ 3. The recommended timeline for screening is as follows:^124^; ii Complete the first antenatal screening as early as practical in pregnancy and repeat screening at least once later in pregnancy.; iii Complete the first postnatal screening 6–12 weeks after birth and repeat screening at least once in the first postnatal year.; iv For a woman with an EPDS score between 10 and 12, monitor and repeat the EPDS in 2–4 weeks as her score may increase subsequently.; v Repeat the EPDS at any time in pregnancy and in the first postnatal year if clinically indicated.
Depression | Community Preventive Services Task Force (CPSTF), 2010 | The CPSTF recommends collaborative care for managing depressive disorders, which includes improving the routine screening and diagnosis of depressive disorders and increasing provider use of evidence-based protocols for proactive management of diagnosed depressive disorders. The CPSTF recommends primary providers actively screen for and diagnose depressive disorders, initiate treatment for depression, and refer patients to mental health specialists as needed.^117^
Depression | National Institute for Health and Care Excellence (NICE), 2009 | NICE encourages providers to conduct a brief, question-based screener to patients who may have depression; if patients answer “yes” to either question, providers should refer the patient to a mental health provider or conduct further screening using a validated tool, such as the PHQ-9 or HADS.^121,^ ^478^
Depression | Institute for Clinical Systems Improvement (ICSI), 2016 | ICSI endorses universal screening for suspected depression based on patient presentation, risk factors, and special populations (e.g., pregnant and postpartum persons, individuals with cognitive impairment). ICSI recommends the use of a standardized screening instrument (such as the PHQ-9) and use of DSM-5 criteria.^118^
Depression | UK National Screening Committee (NSC) | UK NSC does not recommend screening for depression in adults or in new mothers.^479^
Depression | VA/DoD, 2022 | The VA/DoD suggest that all patients not currently receiving treatment for depression be screened for depression. If screening results are positive, followup should be standard clinical practice. States that providers may use any validated instrument for appropriate populations, but the PHQ-2 is recommended within the VA and DoD. Recommends pregnant and postpartum women be screened for depression during their initial antenatal and postnatal visits; in addition, states screening to be repeated in the postpartum period at 4 to 6 weeks and 3 to 4 months after birth.PHQ-2 and PHQ-9 are the primary recommended screening and assessment tools in older populations.^119^
Anxiety | National Institute for Health and Care Excellence (NICE), 2011 | NICE encourages providers to be alert to possible anxiety disorders in patients and to consider asking the person about their feelings of anxiety and their ability to stop or control worry, using the 2-item Generalized Anxiety Disorder scale. NICE includes next steps depending on GAD-2 responses.^125^
Anxiety | Centre of Perinatal Excellence (COPE), 2017 | COPE advises providers to include anxiety screening in the broader clinical assessment of all perinatal women due to its high prevalence. As part of the clinical assessment, use anxiety items from other screening tools (e.g., EPDS items 3, 4, and 5; DASS anxiety items and K-10 items 2, 3, 5, and 6) and relevant items in structured psychosocial assessment tools (e.g., ANRQ).^124^
Anxiety | American College of Obstetricians and Gynecologists (ACOG), 2018 | ACOG recommends that all obstetrician–gynecologists and other obstetric care providers complete a full assessment of mood and emotional well-being (including screening for postpartum depression and anxiety with a validated instrument) during the comprehensive postpartum visit for each patient. If a patient is screened for depression and anxiety during pregnancy, additional screening should then occur during the comprehensive postpartum visit. There is evidence that screening alone can have clinical benefits, although initiation of treatment or referral to mental health care providers offers maximum benefit.^5^
Anxiety | American Psychiatric Association (APA), 2018 | All perinatal patients should be evaluated for depressive, anxiety, and psychotic disorders throughout the pregnancy and postpartum period. We recommend screening for depression with a validated screening tool twice during pregnancy, once in early pregnancy for pre-existing psychiatric disorders and once later in the pregnancy; we also recommend postpartum patients be screened for depression during pediatric visits throughout the first 6 months postpartum as recommended by the American Academy of Pediatrics. A systematic response to screening should be in place to ensure that psychiatric disorders are appropriately assessed, treated, and followed.^476^
Anxiety | Association of Women’s Health, Obstetric and Neonatal Nurses (AWHONN), 2022 | All pregnant and postpartum women should be screened for mood and anxiety disorders. Nurses are in key positions to screen women, provide education regarding perinatal mood and anxiety disorders to pregnant and postpartum women and their families, and ensure appropriate treatment referrals.^477^
Anxiety | Women’s Preventive Services Initiative (WPSI), 2020 | The WPSI recommends considering screening adolescents (≥ 3 years) and adult women (including pregnant and postpartum women) who have not been recently screened for anxiety. Clinical judgment should be used to determine screening frequency in those without a diagnosis of anxiety.^480^
Suicide risk | Department of Veterans Affairs and the Joint Commission, 2019 | The VA and Joint Commission both endorse universal screening to identify individuals at-risk of suicidal behavior (the PHQ-9, item 9, is recommended). They also recommend an assessment of risk factors as part of a comprehensive evaluation of suicide risk.^127,^ ^128^
Suicide risk | Canadian Coalition for Seniors’ Mental Health, 2006 | Healthcare providers should assess for suicide risk.^129^
Suicide risk | Michigan Quality Improvement Consortium, 2019 | The Michigan Quality Improvement Consortium recommends to assess risk of suicide in individuals diagnosed with a depressive disorder at each encounter addressing depression until patient is treated to remission.^130^ It also recommends education and counseling for suicide threats among parents, children, and adolescents, as well as annual screening for psychological, behavioral, depression, and suicide among those ages 10 to 21 years.^481^

Abbreviations: ANRQ = ANtenatal Risk Questionnaire; DASS = Depression Anxiety Stress Scales; DoD = Department of Defence; DSM-5 = Diagnostic and Statistical Manual of Mental Disorders, 5^th^ edition; EPDS = Edinburgh Postnatal Depression Scale; GAD-2 = generalized anxiety disorder 2-item scale; HADS = Hospital Anxiety and Depression Scale; PHQ = Patient Health Questionnaire; VA = Veterans Affairs.

In addition, Healthy People 2030^131^ has a number of objectives relevant to this review, including:

- Increase the proportion of primary care visits where adolescents and adults are screened for depression (MHMD-08)
- Increase the proportion of women who get screened for postpartum depression (MICH-D01)
- Increase the proportion of adults with depression who get treatment (MHMD-05)
- Reduce the suicide rate (MHMD-01)
- Reduce emergency department visits for nonfatal intentional self-harm injuries (IVP-19)

The National Committee for Quality Assurance has also developed a number of measures related to depression screening and care for health plans.^132^ Relevant Healthcare Effectiveness Data and Information Set (HEDIS) measures include:

- Depression Screening: The percentage of members who were screened for clinical depression using a standardized tool.
- Followup on Positive Screen: The percentage of members who screened positive for depression and received followup care within 30 days.
- Utilization of the PHQ-9 to Monitor Depression Symptoms for Adolescents and Adults: The percentage of members 12 years of age and older with a diagnosis of depression, who had an outpatient encounter with a PHQ-9 score present in their record in the same assessment period as the encounter.
- Depression Remission or Response for Adolescents and Adults: The percentage of members 12 years of age and older with a diagnosis of depression and an elevated PHQ-9 score, who had evidence of response or remission within 4–8 months of the elevated score.

### Previous USPSTF Recommendations

In 2016, the USPSTF recommended screening for depression in the general adult population, including pregnant and postpartum women.^133^ They further stated that screening should be implemented with adequate systems in place to ensure accurate diagnosis, effective treatment, and appropriate followup. (Grade B recommendation).

In addition, the USPSTF has issued two other depression-related recommendations. In 2022, the USPSTF recommended screening for major depressive disorder in adolescents aged 12 to 18 years (Grade B recommendation).^134^ They also concluded that the evidence was insufficient to recommend for or against depression screening in children age 11 and younger (I statement). In 2016, The USPSTF recommended that clinicians provide or refer pregnant and postpartum persons who are at increased risk of perinatal depression to preventive counseling interventions (Grade B recommendation).^135^

The USPSTF has never issued a recommendation on screening for anxiety disorders for adults, but in 2022 issued a recommendation to screen for anxiety disorders in young people age 8 to 18 years (Grade B recommendation).^136^

In 2014, the USPSTF concluded that the evidence was insufficient to assess the balance of benefits and harms associated with screening for suicide risk (I statement) in adolescents, adults, and older adults.^137^ They came to the same conclusion for adolescents in 2022 (I statement).^134^