# Appendix K References

1 National Institute for Health and Care Excellence. Falls in Older People: Assessing Risk and Prevention. United Kingdom: 2013.
2 Centers for Medicare & Medicaid Services. Medicaid Plan Finder. https://www.medicare.gov/plan-compare/#/?lang=en&year=2022. Accessed: 1/17/2022.
3 O’Connor EA, Whitlock EP, Beil TL, . Screening for depression in adult patients in primary care settings: a systematic evidence review. Ann Intern Med. 151(11):793–803. PMID: 19949145. 10.7326/0003-4819-151-11-200912010-00007 19949145
4 O’Connor E, Rossom RC, Henninger M, . Primary Care Screening for and Treatment of Depression in Pregnant and Postpartum Women: Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2016;315(4):388–406. PMID: 26813212. 10.1001/jama.2015.18948 26813212
5 Pocklington C, Gilbody S, Manea L, . The diagnostic accuracy of brief versions of the Geriatric Depression Scale: a systematic review and meta-analysis. Int J Geriatr Psychiatry. 2016;31(8):837–57. PMID: 26890937. 10.1002/gps.4407 26890937
6 Plummer F, Manea L, Trepel D, . Screening for anxiety disorders with the GAD-7 and GAD-2: a systematic review and diagnostic metaanalysis. Gen Hosp Psychiatry. 2016/01/01 ed2016. p. 24–31. PMID: 2671910526719105. 10.1016/j.genhosppsych.2015.11.005
7 Sinesi A, Maxwell M, O’Carroll R, . Anxiety scales used in pregnancy: systematic review. BJPsych open. 2019;5(1):e5. PMID: 30762504. 10.1192/bjo.2018.75 30762504
8 Balsamo M, Cataldi F, Carlucci L, . Assessment of anxiety in older adults: a review of self-report measures. Clin Interv Aging. 2018;13:573–93. PMID: 29670342. 10.2147/CIA.S114100 29670342
9 Cuijpers P, Cristea IA, Weitz E, . The effects of cognitive and behavioural therapies for anxiety disorders on depression: a meta-analysis. Psychol Med. 2016;46(16):3451–62. PMID: 27659840. 10.101/7/S0033291716002348 27659840
10 Slee A, Nazareth I, Bondaronek P, . Pharmacological treatments for generalised anxiety disorder: a systematic review and network meta-analysis. Lancet (London, England). 2019;393(10173):768–77. PMID: 30712879. 10.1016/S0140-6736(18)31793-8 30712879
11 Bighelli I, Castellazzi M, Cipriani A, . Antidepressants versus placebo for panic disorder in adults. Cochrane Database Syst Rev. 2018;4:CD010676. PMID: 29620793. 10.1002/14651858.CD010676.pub2 29620793
12 Imai H, Tajika A, Chen P, . Azapirones versus placebo for panic disorder in adults. Cochrane Database Syst Rev. 2014(9). PMID: CD010828. 10.1002/14651858.CD010828.pub2
13 Williams T, Hattingh CJ, Kariuki CM, . Pharmacotherapy for social anxiety disorder (SAnD). Cochrane Database Syst Rev. 2017;10:CD001206. PMID: 29048739. 10.1002/14651858.CD001206.pub3 29048739
14 O’Connor E, Gaynes B, Burda BU, . Screening for Suicide Risk in Primary Care: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD): 2013.
15 Spitzer RL, Kroenke K, Williams JB. Validation and utility of a self-report version of PRIME-MD: the PHQ primary care study. Primary Care Evaluation of Mental Disorders. Patient Health Questionnaire. Jama. 1999/11/24 ed1999. p. 1737–44. PMID: 1056864610568646. 10.1001/jama.282.18.1737
16 Yesavage JA, Brink TL, Rose TL, . Development and validation of a geriatric depression screening scale: a preliminary report. J Psychiatr Res. 1982;17(1):37–49. PMID: 7183759. 10.1016/0022-3956(82)90033-4 7183759
17 Radloff L. The CES-D scale: A self report depression scale for research in the general population. Applied Psychological Measurements. 1977;1:385–401. 10.1177/014662167700100306
18 Whooley MA, Avins AL, Miranda J, . Case-finding instruments for depression: Two questions are as good as many. Journal of general internal medicine. 1997;12(7):439–45. 10.1046/j.1525-1497.1997.00076.x 9229283
19 Cox JL, Holden JM, Sagovsky R. Detection of postnatal depression. Development of the 10-item Edinburgh Postnatal Depression Scale. Br J Psychiatry. 1987;150:782–6. PMID: 3651732. 10.1192/bjp.150.6.782 3651732
20 Spitzer RL, Kroenke K, Williams JB, . A brief measure for assessing generalized anxiety disorder: the GAD-7. Arch Intern Med. 2006;166(10):1092–7. PMID: 16717171. 10.1001/archinte.166.10.1092 16717171
21 Segal DL, June A, Payne M, . Development and initial validation of a self-report assessment tool for anxiety among older adults: the Geriatric Anxiety Scale. J Anxiety Disord. 2010;24(7):709–14. PMID: 20558032. 10.1016/j.janxdis.2010.05.002 20558032
22 Olfson M, Weissman MM, Leon AC, . Suicidal ideation in primary care. Journal of general internal medicine. 1996;11(8):447–53. PMID: 8872781. 10.1007/BF02599038 8872781
23 Desjardins I, Cats-Baril W, Maruti S, . Suicide Risk Assessment in Hospitals: An Expert System-Based Triage Tool. Journal of Clinical Psychiatry. 2016;77(7):e874–82. PMID: 27314465. 10.4088/JCP.15m09881 27314465
24 Wells G, Shea B, O’Connell D, . The Newcastle–Ottawa Scale (NOS) for Assessing the Quality of Non-Randomized Studies in Meta-Analysis. 2000; Accessed 10/26/2021 from https://www.ohri.ca/programs/clinical_epidemiology/oxford.asp
25 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville (MD): Agency for Healthcare Research and Quality (US); 2021.
26 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529–36. PMID: 22007046. 10.7326/0003-4819-155-8-201110180-00009 22007046
27 Bergus GR, Hartz AJ, Noyes R, Jr., . The limited effect of screening for depressive symptoms with the PHQ-9 in rural family practices. J Rural Health. 2005;21(4):303–9. PMID: 16294652. 10.1111/j.1748-0361.2005.tb00099.x 16294652
28 Bijl D, van Marwijk HWJ, Ader HJ, . A randomised controlled trial to improve the recognition, diagnosis and treatment of major depression in elderly people in general practice - primary and secondary outcomes of the West Friesland Study. Diemen: College Voor Zortgverskeringen; 2003.
29 Callahan CM, Hendrie HC, Dittus RS, . Improving treatment of late life depression in primary care: a randomized clinical trial. J Am Geriatr Soc. 1994;42(8):839–46. PMID: 8046193. 10.1111/j.1532-5415.1994.tb06555.x 8046193
30 Glavin K, Smith L, Sorum R, . Redesigned community postpartum care to prevent and treat postpartum depression in women--a one-year follow-up study. J Clin Nurs. 2010;19(21–22):3051–62. PMID: 20726926. 10.1111/j.1365-2702.2010.03332.x 20726926
31 Jarjoura D, Polen A, Baum E, . Effectiveness of screening and treatment for depression in ambulatory indigent patients. Journal of general internal medicine. 2004;19(1):78–84. PMID: 14748864. 10.1111/j.1525-1497.2004.21249.x 14748864
32 Kroenke K, Talib TL, Stump TE, . Incorporating PROMIS Symptom Measures into Primary Care Practice-a Randomized Clinical Trial. Journal of general internal medicine. 2018;33(8):1245–52. PMID: 29623512. 10.1007/s11606-018-4391-0 29623512
33 Leung SS, Leung C, Lam TH, . Outcome of a postnatal depression screening programme using the Edinburgh Postnatal Depression Scale: a randomized controlled trial. J Public Health (Oxf). 2011;33(2):292–301. PMID: 20884642. 10.1093/pubmed/fdq075 20884642
34 MacArthur C, Winter HR, Bick DE, . Effects of redesigned community postnatal care on womens’ health 4 months after birth: a cluster randomised controlled trial. Lancet (London, England). 2002;359(9304):378–85. PMID: 11844507. 10.1016/s0140-6736(02)07596-7 11844507
35 Morrell CJ, Slade P, Warner R, . Clinical effectiveness of health visitor training in psychologically informed approaches for depression in postnatal women: pragmatic cluster randomised trial in primary care. BMJ (Clinical research ed). 2009;338:a3045. PMID: 19147636. 10.1136/bmj.a3045 19147636
36 Rost K, Nutting P, Smith J, . Improving depression outcomes in community primary care practice: a randomized trial of the quEST intervention. Quality Enhancement by Strategic Teaming. Journal of general internal medicine. 2001;16(3):143–9. PMID: 11318908. 10.1111/j.1525-1497.2001.00537.x 11318908
37 van der Weele GM, de Waal MW, van den Hout WB, . Effects of a stepped-care intervention programme among older subjects who screened positive for depressive symptoms in general practice: the PROMODE randomised controlled trial. Age Ageing. 2012;41(4):482–8. PMID: 22427507. 10.1093/ageing/afs027 22427507
38 van der Zee-van den Berg AI, Boere-Boonekamp MM, Groothuis-Oudshoorn CG, . Post-up study: Postpartum depression screening in well-child care and maternal outcomes. Pediatrics. 2017;140(4):1–8. PMID: 28882876. 10.1542/peds.2017-0110 28882876
39 Wells KB, Sherbourne C, Schoenbaum M, . Impact of disseminating quality improvement programs for depression in managed primary care: A randomized controlled trial. JAMA. 2000;283(2):212–20. PMID: 10634337. 10.1001/jama.283.2.212 10634337
40 Whooley M, Stone B. Randomized trial of case-finding for depression in elderly primary care patients. Journal of general internal medicine. 2000;15(5):293–300. PMID: 10840264. 10.1046/j.1525-1497.2000.04319.x 10840264
41 Wickberg B, Tjus T, Hwang P. Using the EPDS in routine antenatal care in Sweden: a naturalistic study. J Reprod Infant Psychol. 2005;23(1):33–41. 10.1080/02646830512331330956
42 Williams J, CD M, Kroenke K. Case-finding for depression in primary care: A randomized trial. The American journal of medicine. 1999;106(1):36–43. PMID: 10320115. 10.1016/s0002-9343(98)00371-4 10320115
43 Yawn BP, Dietrich AJ, Wollan P, . TRIPPD: a practice-based network effectiveness study of postpartum depression screening and management. Annals of family medicine. 2012;10(4):320–9. PMID: 22778120. 10.1370/afm.1418 22778120
44 van Marwijk HW, Wallace P, de Bock GH, . Evaluation of the feasibility, reliability and diagnostic value of shortened versions of the geriatric depression scale. The British journal of general practice : the journal of the Royal College of General Practitioners. 1995;45(393):195–9. PMID: 7612321.7612321
45 Eriksen S, Bjorklof GH, Helvik AS, . The validity of the hospital anxiety and depression scale and the geriatric depression scale-5 in home-dwelling old adults in Norway. Journal of affective disorders. 2019;256:380–5. PMID: 31212233. 10.1016/j.jad.2019.05.049 31212233
46 Izal M, Montorio I, Nuevo R, . Optimising the diagnostic performance of the Geriatric Depression Scale. Psychiatry Res. 2010;178(1):142–6. PMID: 20452060. 10.1016/j.psychres.2009.02.018 20452060
47 Broekman BF, Niti M, Nyunt MS, . Validation of a brief seven-item response bias-free geriatric depression scale. Am J Geriatr Psychiatry. 2011;19(6):589–96. PMID: 21606902. 10.1097/JGP.0b013e3181f61ec9 21606902
48 Marc LG, Raue PJ, Bruce ML. Screening performance of the 15-item geriatric depression scale in a diverse elderly home care population. Am J Geriatr Psychiatry. 2008;16(11):914–21. PMID: 18978252. 10.1097/JGP.0b013e318186bd67 18978252
49 Alves Apostolo JL, Bobrowicz-Campos EM, Carvalho dos Reis IA, . Exploring the screening capacity of the European Portuguese version of the 15-item Geriatric Depression Scale. Revista de Psicopatologia y Psicologia Clinica. 2018;23(2):99–107. 10.5944/rppc.vol.23.num.2.2018.21050
50 Jung YE, Kim MD, Bahk WM, . Validation of the Korean Version of the Depression in Old Age Scale and Comparison with Other Depression Screening Questionnaires Used in Elderly Patients in Medical Settings. Clin. 2019;17(3):369–76. PMID: 31352703. 10.9758/cpn.2019.17.3.369 31352703
51 Pellas J, Damberg M. Accuracy in detecting major depressive episodes in older adults using the Swedish versions of the GDS-15 and PHQ-9. Ups J Med Sci. 2021;126. PMID: 34754407. 10.48101/ujms.v126.7848 34754407
52 Rait G, Burns A, Baldwin R, . Screening for depression in African-Caribbean elders. Fam Pract. 1999;16(6):591–5. PMID: 10625132. 10.1093/fampra/16.6.591 10625132
53 Davison TE, McCabe MP, Mellor D. An examination of the “gold standard” diagnosis of major depression in aged-care settings. Am J Geriatr Psychiatry. 2009;17(5):359–67. PMID: 19390293. 10.1097/JGP.0b013e318190b901 19390293
54 Licht-Strunk E, van der Kooij KG, van Schaik DJ, . Prevalence of depression in older patients consulting their general practitioner in The Netherlands. Int J Geriatr Psychiatry. 2005;20(11):1013–9. PMID: 16250082. 10.1002/gps.1391 16250082
55 Blank K, Gruman C, Robison JT. Case-finding for depression in elderly people: balancing ease of administration with validity in varied treatment settings. J Gerontol A Biol Sci Med Sci. 2004;59(4):378–84. PMID: 15071082. 10.1093/gerona/59.4.m378 15071082
56 Shin C, Park MH, Lee SH, . Usefulness of the 15-item geriatric depression scale (GDS-15) for classifying minor and major depressive disorders among community-dwelling elders. Journal of affective disorders. 2019;259:370–5. PMID: 31470180. 10.1016/j.jad.2019.08.053 31470180
57 Stefan AM, Baban A. The Romanian version of the Geriatric Depression Scale: Reliability and validity. Cognition, Brain, Behavior: An Interdisciplinary Journal. 2017;21(3):175–87. 10.24193/cbb.2017.21.10
58 Negeri ZF, Levis B, Sun Y, . Accuracy of the Patient Health Questionnaire-9 for screening to detect major depression: updated systematic review and individual participant data meta-analysis. BMJ (Clinical research ed). 2021;375:n2183. PMID: 34610915. 10.1136/bmj.n2183 34610915
59 Wang L, Kroenke K, Stump TE, . Screening for perinatal depression with the Patient Health Questionnaire depression scale (PHQ-9): A systematic review and meta-analysis. General hospital psychiatry. 2021;68:74–82. PMID: 33360526. 10.1016/j.genhosppsych.2020.12.007 33360526
60 He C, Levis B, Riehm KE, . The Accuracy of the Patient Health Questionnaire-9 Algorithm for Screening to Detect Major Depression: An Individual Participant Data Meta-Analysis. Psychother Psychosom. 2020;89(1):25–37. PMID: 31593971. 10.1159/000502294 31593971
61 Wu Y, Levis B, Riehm KE, . Equivalency of the diagnostic accuracy of the PHQ-8 and PHQ-9: a systematic review and individual participant data meta-analysis. Psychol Med. 2019:1–13. PMID: 3129818031298180. 10.1017/S0033291719001314
62 Harel D, Levis B, Sun Y, . External validation of a shortened screening tool using individual participant data meta-analysis: A case study of the Patient Health Questionnaire-Dep-4. Methods. 2022;204:300–11. PMID: 34780986. 10.1016/j.ymeth.2021.11.005 34780986
63 Levis B, Sun Y, He C, . Accuracy of the PHQ-2 Alone and in Combination With the PHQ-9 for Screening to Detect Major Depression: Systematic Review and Meta-analysis. JAMA. 2020;323(22):2290–300. PMID: 32515813. 10.1001/jama.2020.6504 32515813
64 Bosanquet K, Bailey D, Gilbody S, . Diagnostic accuracy of the Whooley questions for the identification of depression: a diagnostic meta-analysis. BMJ Open. 2015;5(12):e008913. PMID: 26656018. 10.1136/bmjopen-2015-008913 26656018
65 Smith RD, Shing JSY, Lin J, . Meta-analysis of diagnostic properties of the Whooley questions to identify depression in perinatal women. Journal of affective disorders. 2022;315:148–55. PMID: 35931230. 10.1016/j.jad.2022.07.026 35931230
66 Vilagut G, Forero CG, Barbaglia G, . Screening for Depression in the General Population with the Center for Epidemiologic Studies Depression (CES-D): A Systematic Review with Meta-Analysis. PLoS ONE [Electronic Resource]. 2016;11(5):e0155431. PMID: 27182821. 10.1371/journal.pone.0155431 27182821
67 Levis B, Negeri Z, Sun Y, . Accuracy of the Edinburgh Postnatal Depression Sscale (EPDS) for Screening to Detect Major Depression among Pregnant and Postpartum Women: Systematic Review and Meta-analysis of Individual Participant Data. BMJ (Clinical research ed). 2020;371:m4022. PMID: 33177069. 10.1136/bmj.m4022 33177069
68 Aherne D, Fitzgerald A, Aherne C, . Evidence for the treatment of moderate depression: a systematic review. Ir J Psychol Med. 2017;34(3):197–204. PMID: 30115148. 10.1017/ipm.2017.10 30115148
69 Castro A, Gili M, Ricci-Cabello I, . Effectiveness and adherence of telephone-administered psychotherapy for depression: A systematic review and meta-analysis. Journal of affective disorders. 2020;260:514–26. PMID: 31539688. 10.1016/j.jad.2019.09.023 31539688
70 Collado A, Lim AC, MacPherson L. A systematic review of depression psychotherapies among Latinos. Clin Psychol Rev. 2016;45:193–209. PMID: 27113679. 10.1016/j.cpr.2016.04.001 27113679
71 Cuijpers P. Four decades of outcome research on psychotherapies for adult depression: An overview of a series of meta-analyses. Canadian Psychology/Psychologie canadienne. 2017;58(1):7–19. 10.1037/cap0000096
72 Cuijpers P, Karyotaki E, Reijnders M, . Who benefits from psychotherapies for adult depression? A meta-analytic update of the evidence. Cognitive Behav Ther. 2018;47(2):91–106. PMID: 29345530. 10.1080/16506073.2017.1420098 29345530
73 Cuijpers P, Karyotaki E, Reijnders M, . Was Eysenck right after all? A reassessment of the effects of psychotherapy for adult depression. Epidemiol Psychiatr Sci. 2019;28(1):21–30. PMID: 29486804. 10.1017/s2045796018000057 29486804
74 Cuijpers P, Quero S, Papola D, . Care-as-usual control groups across different settings in randomized trials on psychotherapy for adult depression: a meta-analysis. Psychol Med. 2019:1–11. PMID: 3184303131843031. 10.1017/S0033291719003581
75 Cuijpers P, Karyotaki E, de Wit L, . The effects of fifteen evidence-supported therapies for adult depression: A meta-analytic review. Psychother. 2020;30(3):279–93. PMID: 31394976. 10.1080/10503307.2019.1649732 31394976
76 Driessen E, Hollon SD, Bockting CL, . Does Publication Bias Inflate the Apparent Efficacy of Psychological Treatment for Major Depressive Disorder? A Systematic Review and Meta-Analysis of US National Institutes of Health-Funded Trials. PLoS ONE [Electronic Resource]. 2015;10(9):e0137864. PMID: 26422604. 10.1371/journal.pone.0137864 26422604
77 Harerimana B, Forchuk C, O’Regan T. The use of technology for mental healthcare delivery among older adults with depressive symptoms: A systematic literature review. Int J Ment Health Nurs. 2019;28(3):657–70. PMID: 30666762. 10.1111/inm.12571 30666762
78 Harper Shehadeh M, Heim E, Chowdhary N, . Cultural Adaptation of Minimally Guided Interventions for Common Mental Disorders: A Systematic Review and Meta-Analysis. JMIR Ment Health. 2016;3(3):e44. PMID: 27670598. 10.2196/mental.5776 27670598
79 Holvast F, Massoudi B, Oude Voshaar RC, . Non-pharmacological treatment for depressed older patients in primary care: A systematic review and meta-analysis. PLoS ONE [Electronic Resource]. 2017;12(9):e0184666. PMID: 28938015. 10.1371/journal.pone.0184666 28938015
80 Huang L, Zhao Y, Qiang C, . Is cognitive behavioral therapy a better choice for women with postnatal depression? A systematic review and meta-analysis. PLoS ONE [Electronic Resource]. 2018;13(10):e0205243. PMID: 30321198. 10.1371/journal.pone.0205243 30321198
81 Karyotaki E, Riper H, Twisk J, . Efficacy of Self-guided Internet-Based Cognitive Behavioral Therapy in the Treatment of Depressive Symptoms: A Meta-analysis of Individual Participant Data. JAMA Psychiatry. 2017;74(4):351–9. PMID: 28241179. 10.1001/jamapsychiatry.2017.0044 28241179
82 Karyotaki E, Ebert DD, Donkin L, . Do guided internet-based interventions result in clinically relevant changes for patients with depression? An individual participant data meta-analysis. Clin Psychol Rev. 2018;63:80–92. PMID: 29940401. 10.1016/j.cpr.2018.06.007 29940401
83 Letourneau NL, Dennis CL, Cosic N, . The effect of perinatal depression treatment for mothers on parenting and child development: A systematic review. Depress Anxiety. 2017;34(10):928–66. PMID: 28962068. 10.1002/da.22687 28962068
84 Li X, Laplante DP, Paquin V, . Effectiveness of cognitive behavioral therapy for perinatal maternal depression, anxiety and stress: A systematic review and meta-analysis of randomized controlled trials. Clin Psychol Rev. 2022;92:102129. PMID: 35123346. 10.1016/j.cpr.2022.102129 35123346
85 Massoudi B, Holvast F, Bockting CLH, . The effectiveness and cost-effectiveness of e-health interventions for depression and anxiety in primary care: A systematic review and meta-analysis. Journal of affective disorders. 2019;245:728–43. PMID: 30447572. 10.1016/j.jad.2018.11.050 30447572
86 Nair U, Armfield NR, Chatfield MD, . The effectiveness of telemedicine interventions to address maternal depression: A systematic review and meta-analysis. Journal of Telemedicine & Telecare. 2018;24(10):639–50. PMID: 30343660. 10.1177/1357633X18794332 30343660
87 Nieuwenhuijsen K, Verbeek JH, Neumeyer-Gromen A, . Interventions to improve return to work in depressed people. Cochrane Database Syst Rev. 2020;10:CD006237. PMID: 33052607. 10.1002/14651858.CD006237.pub4 33052607
88 Pineros-Leano M, Liechty JM, Piedra LM. Latino immigrants, depressive symptoms, and cognitive behavioral therapy: A systematic review. Journal of affective disorders. 2017;208:567–76. PMID: 27810273. 10.1016/j.jad.2016.10.025 27810273
89 Ponting C, Mahrer NE, Zelcer H, . Psychological interventions for depression and anxiety in pregnant Latina and Black women in the United States: A systematic review. Clinical Psychology & Psychotherapy. 2020;27(2):249–65. PMID: 31960525. 10.1002/cpp.2424 31960525
90 Rojas-Garcia A, Ruiz-Perez I, Rodriguez-Barranco M, . Healthcare interventions for depression in low socioeconomic status populations: A systematic review and meta-analysis. Clin Psychol Rev. 2015;38:65–78. PMID: 25797906. 10.1016/j.cpr.2015.03.001 25797906
91 Roman M, Constantin T, Bostan CM. The efficiency of online cognitive-behavioral therapy for postpartum depressive symptomatology: a systematic review and meta-analysis. Women Health. 2020;60(1):99–112. PMID: 31057080. 10.1080/03630242.2019.1610824 31057080
92 Thomas WJ, Hauson AO, Lambert JE, . A meta-analysis of the effectiveness of cognitive-behavioural therapies for late-life depression. Canadian Journal of Counselling and Psychotherapy. 2018;52(1):78–117.
93 Weaver A, Himle JA. Cognitive-behavioral therapy for depression and anxiety disorders in rural settings: A review of the literature. Journal of Rural Mental Health. 2017;41(3):189–221. 10.1037/rmh0000075
94 Weitz E, Kleiboer A, van Straten A, . The effects of psychotherapy for depression on anxiety symptoms: a meta-analysis. Psychol Med. 2018;48(13):2140–52. PMID: 29361995. 10.1017/s0033291717003622 29361995
95 Xiang X, Wu S, Zuverink A, . Internet-delivered cognitive behavioral therapies for late-life depressive symptoms: a systematic review and meta-analysis. Aging Ment Health. 2019:1–11. PMID: 3091389830913898. 10.1080/13607863.2019.1590309
96 Zhang A, Franklin C, Jing S, . The effectiveness of four empirically supported psychotherapies for primary care depression and anxiety: A systematic review and meta-analysis. Journal of affective disorders. 2019;245:1168–86. PMID: 30699860. 10.1016/j.jad.2018.12.008 30699860
97 Zhang A, Borhneimer LA, Weaver A, . Cognitive behavioral therapy for primary care depression and anxiety: a secondary meta-analytic review using robust variance estimation in meta-regression. J Behav Med. 2019;42(6):1117–41. PMID: 31004323. 10.1007/s10865-019-00046-z 31004323
98 Jonsson U, Bertilsson G, Allard P, . Psychological Treatment of Depression in People Aged 65 Years and Over: A Systematic Review of Efficacy, Safety, and Cost-Effectiveness. PLoS ONE [Electronic Resource]. 2016;11(8):e0160859. PMID: 27537217. 10.1371/journal.pone.0160859 27537217
99 Arroll B, Chin WY, Martis W, . Antidepressants for treatment of depression in primary care: a systematic review and meta-analysis. J Prim Health Care. 2016;8(4):325–34. PMID: 29530157. 10.1071/HC16008 29530157
100 Baune BT, Brignone M, Larsen KG. A Network Meta-Analysis Comparing Effects of Various Antidepressant Classes on the Digit Symbol Substitution Test (DSST) as a Measure of Cognitive Dysfunction in Patients with Major Depressive Disorder. Int J Neuropsychopharmcol. 2018;21(2):97–107. PMID: 29053849. 10.1093/ijnp/pyx070 29053849
101 Cipriani A, Furukawa TA, Salanti G, . Comparative efficacy and acceptability of 21 antidepressant drugs for the acute treatment of adults with major depressive disorder: a systematic review and network meta-analysis. Lancet (London, England). 2018;391(10128):1357–66. PMID: 29477251. 10.1016/S0140-6736(17)32802-7 29477251
102 Cuijpers P, de Wit L, Weitz E, . The combination of psychotherapy and pharmacotherapy in the treatment of adult depression: A comprehensive meta-analysis. Journal of Evidence-Based Psychotherapies. 2015;15(2):147–68.
103 Krause M, Gutsmiedl K, Bighelli I, . Efficacy and tolerability of pharmacological and non-pharmacological interventions in older patients with major depressive disorder: A systematic review, pairwise and network meta-analysis. Eur Neuropsychopharmacol. 2019;29(9):1003–22. PMID: 31327506. 10.1016/j.euroneuro.2019.07.130 31327506
104 Lee Y, Rosenblat JD, Lee J, . Efficacy of antidepressants on measures of workplace functioning in major depressive disorder: A systematic review. Journal of affective disorders. 2018;227:406–15. PMID: 29154157. 10.1016/j.jad.2017.11.003 29154157
105 Lisinski A, Hieronymus F, Naslund J, . Item-based analysis of the effects of duloxetine in depression: A patient-level post hoc study. Neuropsychopharmacology. 2020;45(3):553–60. PMID: 31521062. 10.1038/s41386-019-0523-4 31521062
106 Rabinowitz J, Werbeloff N, Mandel FS, . Initial depression severity and response to antidepressants v. placebo: patient-level data analysis from 34 randomised controlled trials. Br J Psychiatry. 2016;209(5):427–8. PMID: 27198482. 10.1192/bjp.bp.115.173906 27198482
107 Viswanathan M, Middleton JC, Stuebe AM, . Maternal, Fetal, and Child Outcomes of Mental Health Treatments in Women: A Meta-Analysis of Perinatal Pharmacotherapy. Psychiatric Research and Clinical Practice. 2021;3(3):123–40. 10.1176/appi.prcp.20210001 36101835
108 Naslund J, Hieronymus F, Lisinski A, . Effects of selective serotonin reuptake inhibitors on rating-scale-assessed suicidality in adults with depression. The British Journal of Psychiatry. 2018;212(3):148–54. 10.1192/bjp.2017.24 29436321
109 Jakobsen JC, Katakam KK, Schou A, . Selective serotonin reuptake inhibitors versus placebo in patients with major depressive disorder. A systematic review with meta-analysis and Trial Sequential Analysis. BMC Psychiatry. 2017;17(1):58. PMID: 28178949. 10.1186/s12888-016-1173-2 28178949
110 Hengartner MP, Amendola S, Kaminski JA, . Suicide risk with selective serotonin reuptake inhibitors and other new-generation antidepressants in adults: a systematic review and meta-analysis of observational studies. J Epidemiol Community Health. 2021. PMID: 3368596433685964. 10.1136/jech-2020-214611
111 Jacobsen PL. Antidepressant-associated sexual dysfunction in patients with depression: A meta-analysis of sexual functioning data collected via prospective questionnaires. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2019;80(8-B(E)):No Pagination Specified.
112 Cuijpers P, Reijnders M, Karyotaki E, . Negative effects of psychotherapies for adult depression: A meta-analysis of deterioration rates. Journal of affective disorders. 2018;239:138–45. PMID: 30005327. 10.1016/j.jad.2018.05.050 30005327
113 Ebert DD, Donkin L, Andersson G, . Does Internet-based guided-self-help for depression cause harm? An individual participant data meta-analysis on deterioration rates and its moderators in randomized controlled trials. Psychol Med. 2016;46(13):2679–93. PMID: 27649340. 10.1017/S0033291716001562 27649340
114 Karyotaki E, Kemmeren L, Riper H, . Is self-guided internet-based cognitive behavioural therapy (iCBT) harmful? An individual participant data meta-analysis. Psychol Med. 2018;48(15):2456–66. PMID: 29540243. 10.1017/s0033291718000648 29540243
115 Braun C, Bschor T, Franklin J, . Suicides and Suicide Attempts during Long-Term Treatment with Antidepressants: A Meta-Analysis of 29 Placebo-Controlled Studies Including 6,934 Patients with Major Depressive Disorder. Psychother Psychosom. 2016;85(3):171–9. PMID: 27043848. 10.1159/000442293 27043848
116 Chan JYC, Yiu KKL, Kwok TCY, . Depression and Antidepressants as Potential Risk Factors in Dementia: A Systematic Review and Meta-analysis of 18 Longitudinal Studies. J Am Med Dir Assoc. 2019;20(3):279–86.e1. PMID: 30711460. 10.1016/j.jamda.2018.12.004 30711460
117 Gibbons RD, Brown CH, Hur K, . Suicidal thoughts and behavior with antidepressant treatment: reanalysis of the randomized placebo-controlled studies of fluoxetine and venlafaxine. Archives of general psychiatry. 2012;69(6):580–7. PMID: 22309973. 10.1001/archgenpsychiatry.2011.2048 22309973
118 Gumusoglu SB, Schickling BM, Vignato JA, . Selective serotonin reuptake inhibitors and preeclampsia: A quality assessment and meta-analysis. Pregnancy Hypertens. 2022;30:36–43. PMID: 35963154. 10.1016/j.preghy.2022.08.001 35963154
119 Jensen MP, Ziff OJ, Banerjee G, . The impact of selective serotonin reuptake inhibitors on the risk of intracranial haemorrhage: A systematic review and meta-analysis. European Stroke Journal. 2019;4(2):144–52. PMID: 31259262. 10.1177/2396987319827211 31259262
120 Kaminski JA, Bschor T. Antidepressants and suicidality: A re-analysis of the re-analysis. Journal of affective disorders. 2020;266:95–9. PMID: 32056952. 10.1016/j.jad.2020.01.107 32056952
121 Khanassov V, Hu J, Reeves D, . Selective serotonin reuptake inhibitor and selective serotonin and norepinephrine reuptake inhibitor use and risk of fractures in adults: A systematic review and meta-analysis. Int J Geriatr Psychiatry. 2018;33(12):1688–708. PMID: 30247774. 10.1002/gps.4974 30247774
122 KoKoAung E, Cavenett S, McArthur A, . The association between suicidality and treatment with selective serotonin reuptake inhibitors in older people with major depression: a systematic review. JBI Database System Rev Implement Rep. 2015;13(3):174–205. PMID: 26447056. 10.11124/jbisrir-2015-2272 26447056
123 Kunutsor SK, Seidu S, Khunti K. Depression, antidepressant use, and risk of venous thromboembolism: systematic review and meta-analysis of published observational evidence. Ann Med. 2018;50(6):529–37. PMID: 30001640. 10.1080/07853890.2018.1500703 30001640
124 Maslej MM, Bolker BM, Russell MJ, . The Mortality and Myocardial Effects of Antidepressants Are Moderated by Preexisting Cardiovascular Disease: A Meta-Analysis. Psychother Psychosom. 2017;86(5):268–82. PMID: 28903117. 10.1159/000477940 28903117
125 Na KS, Jung HY, Cho SJ, . Can we recommend mirtazapine and bupropion for patients at risk for bleeding?: A systematic review and meta-analysis. Journal of affective disorders. 2018;225:221–6. PMID: 28841484. 10.1016/j.jad.2017.08.002 28841484
126 Sobieraj DM, Martinez BK, Hernandez AV, . Adverse Effects of Pharmacologic Treatments of Major Depression in Older Adults. J Am Geriatr Soc. 2019;67(8):1571–81. PMID: 31140587. 10.1111/jgs.15966 31140587
127 Trajkova S, d’Errico A, Soffietti R, . Use of Antidepressants and Risk of Incident Stroke: A Systematic Review and Meta-Analysis. Neuroepidemiology. 2019;53(3–4):142–51. PMID: 31216542. 10.1159/000500686 31216542
128 Vlenterie R, van Gelder M, Anderson HR, . Associations Between Maternal Depression, Antidepressant Use During Pregnancy, and Adverse Pregnancy Outcomes: An Individual Participant Data Meta-analysis. Obstetrics and gynecology. 2021;138(4):633–46. PMID: 34623076. 10.1097/AOG.0000000000004538 34623076
129 Wang YC, Tai PA, Poly TN, . Increased Risk of Dementia in Patients with Antidepressants: A Meta-Analysis of Observational Studies. Behav. 2018;2018:5315098. PMID: 30123386. 10.1155/2018/5315098 30123386
130 Balasubramaniam M, Joshi P, Alag P, . Antidepressants for anxiety disorders in late-life: A systematic review. Ann Clin Psychiatry. 2019;31(4):277–91. PMID: 31369663.31369663
131 Mathias SD, Fifer SK, Mazonson PD, . Necessary but not sufficient: the effect of screening and feedback on outcomes of primary care patients with untreated anxiety. Journal of general internal medicine. 1994;9(11):606–15. PMID: 7853069. 10.1007/BF02600303 7853069
132 Nath S, Ryan EG, Trevillion K, . Prevalence and identification of anxiety disorders in pregnancy: the diagnostic accuracy of the two-item Generalised Anxiety Disorder scale (GAD-2). BMJ Open. 2018;8(9):e023766. PMID: 30185582. 10.1136/bmjopen-2018-023766 30185582
133 Ahn JK, Kim Y, Choi KH. The Psychometric Properties and Clinical Utility of the Korean Version of GAD-7 and GAD-2. Front Psychiatr. 2019;10:127. PMID: 30936840. 10.3389/fpsyt.2019.00127 30936840
134 Kujanpaa T, Ylisaukko-Oja T, Jokelainen J, . Prevalence of anxiety disorders among Finnish primary care high utilizers and validation of Finnish translation of GAD-7 and GAD-2 screening tools. Scand J Prim Health Care. 2014;32(2):78–83. PMID: 24920316. 10.3109/02813432.2014.920597 24920316
135 Austin MV, Mule V, Hadzi-Pavlovic D, . Screening for anxiety disorders in third trimester pregnancy: a comparison of four brief measures. Arch Women Ment Health. 2021;05:05. PMID: 34350480. 10.1007/s00737-021-01166-9 34350480
136 Makulowich AA. Identification of patients with anxiety symptoms in an integrated community care clinic among a predominantly Latino patient population. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2019;80(1-B(E)):No Pagination Specified.
137 Vasiliadis HM, Chudzinski V, Gontijo-Guerra S, . Screening instruments for a population of older adults: The 10-item Kessler Psychological Distress Scale (K10) and the 7-item Generalized Anxiety Disorder Scale (GAD-7). Psychiatry Res. 2015;228(1):89–94. PMID: 25956759. 10.1016/j.psychres.2015.04.019 25956759
138 Gould CE, Segal DL, Yochim BP, . Measuring anxiety in late life: a psychometric examination of the geriatric anxiety inventory and geriatric anxiety scale. Journal of Anxiety Disorders. 2014;28(8):804–11. PMID: 25271176. 10.1016/j.janxdis.2014.08.001 25271176
139 Matthey S, Valenti B, Souter K, . Comparison of four self-report measures and a generic mood question to screen for anxiety during pregnancy in English-speaking women. Journal of affective disorders. 2013;148(2–3):347–51. PMID: 23380518. 10.1016/j.jad.2012.12.022 23380518
140 Burger H, Verbeek T, Aris-Meijer JL, . Effects of psychological treatment of mental health problems in pregnant women to protect their offspring: randomised controlled trial. Br J Psychiatry. 2020;216(4):182–8. PMID: 31806071. 10.1192/bjp.2019.260 31806071
141 Clark DM, Wild J, Warnock-Parkes E, . More than doubling the clinical benefit of each hour of therapist time: a randomised controlled trial of internet cognitive therapy for social anxiety disorder. Psychol Med. 2022:1–11. PMID: 3583572635835726. 10.1017/S0033291722002008
142 Corpas J, Moriana JA, Vencesla JF, . Effectiveness of brief group transdiagnostic therapy for emotional disorders in primary care: A randomized controlled trial identifying predictors of outcome. Psychother. 2021:1–14. PMID: 3426964034269640. 10.1080/10503307.2021.1952331
143 Fletcher J, Lovell K, Bower P, . Process and Outcome of a Non-Guided Self-Help Manual for Anxiety and Depression in Primary Care: A Pilot Study. Behav. 2005;33(3):319–31. 10.1017/S1352465805002079
144 Gensichen J, Hiller TS, Breitbart J, . Panic Disorder in Primary Care. Dtsch. 2019;116(10):159–66. PMID: 30995952. 10.3238/arztebl.2019.0159 30995952
145 Graham AK, Greene CJ, Kwasny MJ, . Coached Mobile App Platform for the Treatment of Depression and Anxiety Among Primary Care Patients: A Randomized Clinical Trial. JAMA Psychiatry. 2020;20:20. PMID: 32432695. 10.1001/jamapsychiatry.2020.1011 32432695
146 Kendrick T, Simons L, Mynors-Wallis L, . A trial of problem-solving by community mental health nurses for anxiety, depression and life difficulties among general practice patients. The CPN-GP study. Health Technol Assess. 2005;9(37):1–104, iii. PMID: 16153354. 10.3310/hta9370 16153354
147 King M, Sibbald B, Ward E, . Randomised controlled trial of non-directive counselling, cognitive-behaviour therapy and usual general practitioner care in the management of depression as well as mixed anxiety and depression in primary care. Health Technol Assess. 2000;4(19):1–83. PMID: 11086269.11086269
148 Lam CLK, Fong DYT, Chin WY, . Brief problem-solving treatment in primary care (PST-PC) was not more effective than placebo for elderly patients screened positive of psychological problems. Int J Geriatr Psychiatry. 2010;25(10):968. 10.1002/gps.2435 20033901
149 Lang AJ, Norman GJ, Casmar PV. A randomized trial of a brief mental health intervention for primary care patients. J Consult Clin Psychol. 2006;74(6):1173–9. PMID: 17154746. 10.1037/0022-006x.74.6.1173 17154746
150 Linden M, Zubraegel D, Baer T, . Efficacy of cognitive behaviour therapy in generalized anxiety disorders. Results of a controlled clinical trial (Berlin CBT-GAD Study). Psychother Psychosom. 2005;74(1):36–42. PMID: 15627855. 10.1159/000082025 15627855
151 Nordgren LB, Hedman E, Etienne J, . Effectiveness and cost-effectiveness of individually tailored Internet-delivered cognitive behavior therapy for anxiety disorders in a primary care population: a randomized controlled trial. Behav Res Ther. 2014;59:1–11. PMID: 24933451. 10.1016/j.brat.2014.05.007 24933451
152 O’Mahen HA, Ramchandani PG, King DX, . Adapting and testing a brief intervention to reduce maternal anxiety during pregnancy (ACORN): report of a feasibility randomized controlled trial. BMC Psychiatry. 2022;22(1):129. PMID: 35177019. 10.1186/s12888-022-03737-1 35177019
153 Proudfoot J, Ryden C, Everitt B, . Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry. 2004;185:46–54. PMID: 15231555. 10.1192/bjp.185.1.46 15231555
154 Rollman BL, Herbeck Belnap B, Abebe KZ, . Effectiveness of Online Collaborative Care for Treating Mood and Anxiety Disorders in Primary Care: A Randomized Clinical Trial. JAMA Psychiatry. 2018;75(1):56–64. PMID: 29117275. 10.1001/jamapsychiatry.2017.3379 29117275
155 Roy-Byrne P, Craske MG, Sullivan G, . Delivery of evidence-based treatment for multiple anxiety disorders in primary care: a randomized controlled trial. JAMA. 2010;303(19):1921–8. PMID: 20483968. 10.1001/jama.2010.608 20483968
156 Schreuders B, van Marwijk H, Smit J, . Primary care patients with mental health problems: outcome of a randomised clinical trial. British Journal of General Practice. 2007;57(544):886–91. PMID: 17976289. 10.3399/096016407782317829 17976289
157 Seekles W, van Straten A, Beekman A, . Effectiveness of guided self-help for depression and anxiety disorders in primary care: a pragmatic randomized controlled trial. Psychiatry Res. 2011;187(1–2):113–20. PMID: 21145112. 10.1016/j.psychres.2010.11.015 21145112
158 Stanley MA, Wilson NL, Novy DM, . Cognitive behavior therapy for generalized anxiety disorder among older adults in primary care: a randomized clinical trial. Jama. 2009;301(14):1460–7. PMID: 19351943. 10.1001/jama.2009.458 19351943
159 Stanley MA, Wilson NL, Amspoker AB, . Lay providers can deliver effective cognitive behavior therapy for older adults with generalized anxiety disorder: a randomized trial. Depress Anxiety. 2014;31(5):391–401. PMID: 24577847. 10.1002/da.22239 24577847
160 Suchan V, Peynenburg V, Thiessen D, . Transdiagnostic Internet-Delivered Cognitive Behavioral Therapy for Symptoms of Postpartum Anxiety and Depression: Feasibility Randomized Controlled Trial. JMIR Form Res. 2022;6(9):e37216. PMID: 36066958. 10.2196/37216 36066958
161 Sundquist J, Lilja Å, Palmér K, . Mindfulness group therapy in primary care patients with depression, anxiety and stress and adjustment disorders: randomised controlled trial. Br J Psychiatry. 2015;206(2):128–35. PMID: 25431430. 10.1192/bjp.bp.114.150243 25431430
162 Torres-Platas SG, Escobar S, Belliveau C, . Mindfulness-Based Cognitive Therapy Intervention for the Treatment of Late-Life Depression and Anxiety Symptoms in Primary Care: A Randomized Controlled Trial. Psychother Psychosom. 2019;88(4):254–6. PMID: 31288245. 10.1159/000501214 31288245
163 Vera M, Oben A, Juarbe D, . Randomized pilot trial of cognitive-behavioral therapy and acceptance-based behavioral therapy in the treatment of Spanish-speaking Latino primary care patients with generalized anxiety disorder. Journal of Behavioral and Cognitive Therapy. 2021;31(2):91–103. PMID: 35813157. 10.1016/j.jbct.2020.11.007 35813157
164 Cuijpers P, Cristea IA, Karyotaki E, . How effective are cognitive behavior therapies for major depression and anxiety disorders? A meta-analytic update of the evidence. World psychiatry : official journal of the World Psychiatric Association (WPA). 2016;15(3):245–58. PMID: 27717254. 10.1002/wps.20346 27717254
165 Gould RL, Coulson MC, Howard RJ. Efficacy of cognitive behavioral therapy for anxiety disorders in older people: a meta-analysis and meta-regression of randomized controlled trials. J Am Geriatr Soc. 2012;60(2):218–29. PMID: 22283717. 10.1111/j.1532-5415.2011.03824.x 22283717
166 Hofmann SG, Wu JQ, Boettcher H. Effect of cognitive-behavioral therapy for anxiety disorders on quality of life: a meta-analysis. J Consult Clin Psychol. 2014;82(3):375–91. PMID: 24447006. 10.1037/a0035491 24447006
167 van Dis EAM, van Veen SC, Hagenaars MA, . Long-term Outcomes of Cognitive Behavioral Therapy for Anxiety-Related Disorders: A Systematic Review and Meta-analysis. JAMA Psychiatry. 2020;77(3):265–73. PMID: 31758858. 10.1001/jamapsychiatry.2019.3986 31758858
168 Breilmann J, Girlanda F, Guaiana G, . Benzodiazepines versus placebo for panic disorder in adults. Cochrane Database Syst Rev. 2019;3:CD010677. PMID: 30921478. 10.1002/14651858.CD010677.pub2 30921478
169 Chen TR, Huang HC, Hsu JH, . Pharmacological and psychological interventions for generalized anxiety disorder in adults: A network meta-analysis. J Psychiatr Res. 2019;118:73–83. PMID: 31494377. 10.1016/j.jpsychires.2019.08.014 31494377
170 Gupta A, Bhattacharya G, Farheen SA, . Systematic review of benzodiazepines for anxiety disorders in late life. Ann Clin Psychiatry. 2020;32(2):114–27. PMID: 32343283.32343283
171 Roest AM, de Jonge P, Williams CD, . Reporting Bias in Clinical Trials Investigating the Efficacy of Second-Generation Antidepressants in the Treatment of Anxiety Disorders: A Report of 2 Meta-analyses. JAMA Psychiatry. 2015;72(5):500–10. PMID: 25806940. 10.1001/jamapsychiatry.2015.15 10.1001/jamapsychiatry.2015.15 25806940
172 Lenox-Smith AJ, Reynolds A. A double-blind, randomised, placebo controlled study of venlafaxine XL in patients with generalised anxiety disorder in primary care. Br J Gen Pract. 2003;53(495):772–7. PMID: 14601352.14601352
173 Lenze EJ, Rollman BL, Shear MK, . Escitalopram for older adults with generalized anxiety disorder: a randomized controlled trial. Jama. 2009;301(3):295–303. PMID: 19155456. 10.1001/jama.2008.977 19155456
174 Lader M, Scotto JC. A multicentre double-blind comparison of hydroxyzine, buspirone and placebo in patients with generalized anxiety disorder. Psychopharmacology (Berl). 1998;139(4):402–6. PMID: 9809861. 10.1007/s002130050731 9809861
175 Crawford MJ, Thana L, Methuen C, . Impact of screening for risk of suicide: randomised controlled trial. Br J Psychiatry. 2011;198:379–84. PMID: 21525521. 10.1192/bjp.bp.110.083592 21525521
176 Heisel MJ, Duberstein PR, Lyness JM, . Screening for suicide ideation among older primary care patients. Journal of the American Board of Family Medicine : JABFM. 2010;23(2):260–9. PMID: 20207936. 10.3122/jabfm.2010.02.080163 20207936
177 Borschmann R, Barrett B, Hellier JM, . Joint crisis plans for people with borderline personality disorder: feasibility and outcomes in a randomised controlled trial. Br J Psychiatry. 2013;202(5):357–64. PMID: 23637110. 10.1192/bjp.bp.112.117762 23637110
178 Bruce ML, Ten Have TR, Reynolds CF, III, . Reducing suicidal ideation and depressive symptoms in depressed older primary care patients: a randomized controlled trial. JAMA. 2004;291(9):1081–91. PMID: 14996777. 10.1001/jama.291.9.1081 14996777
179 Bush NE, Smolenski DJ, Denneson LM, . A Virtual Hope Box: Randomized Controlled Trial of a Smartphone App for Emotional Regulation and Coping With Distress. Psychiatr Serv. 2017;68(4):330–6. PMID: 27842473. 10.1176/appi.ps.201600283 27842473
180 Carter GL, Willcox CH, Lewin TJ, . Hunter DBT project: randomized controlled trial of dialectical behaviour therapy in women with borderline personality disorder. Aust N Z J Psychiatry. 2010;44(2):162–73. PMID: 20113305. 10.3109/00048670903393621 20113305
181 Davidson K, Norrie J, Tyrer P, . The effectiveness of cognitive behavior therapy for borderline personality disorder: results from the borderline personality disorder study of cognitive therapy (BOSCOT) trial. J Pers Disord. 2006;20(5):450–65. PMID: 17032158. 10.1521/pedi.2006.20.5.450 17032158
182 Franklin JC, Fox KR, Franklin CR, . A brief mobile app reduces nonsuicidal and suicidal self-injury: Evidence from three randomized controlled trials. J Consult Clin Psychol. 2016;84(6):544–57. PMID: 27018530. 10.1037/ccp0000093 27018530
183 Goodman M, Banthin D, Blair NJ, . A Randomized Trial of Dialectical Behavior Therapy in High-Risk Suicidal Veterans. Journal of Clinical Psychiatry. 2016;77(12):e1591–e600. PMID: 27780335. 10.4088/JCP.15m10235 27780335
184 Jobes D, Comtois K, Gutierrez P, . A Randomized Controlled Trial of the Collaborative Assessment and Management of Suicidality versus Enhanced Care as Usual With Suicidal Soldiers. Psychiatry (new york). 2017;80(4):339–56. PMID: CN-01466006. 10.1080/00332747.2017.1354607
185 Katz IR, Rogers MP, Lew R, . Lithium Treatment in the Prevention of Repeat Suicide-Related Outcomes in Veterans With Major Depression or Bipolar Disorder: A Randomized Clinical Trial. JAMA Psychiatry. 2022;79(1):24–32. PMID: 34787653. 10.1001/jamapsychiatry.2021.3170 34787653
186 Kovac SH, Range LM. Does writing about suicidal thoughts and feelings reduce them? Suicide & life-threatening behavior. 2002;32(4):428–40. PMID: 12501967. 10.1521/suli.32.4.428.22335 12501967
187 Linehan MM, Comtois KA, Murray AM, . Two-year randomized controlled trial and follow-up of dialectical behavior therapy vs therapy by experts for suicidal behaviors and borderline personality disorder. Archives of general psychiatry. 2006;63(7):757–66. PMID: 16818865. 10.1001/archpsyc.63.7.757 16818865
188 McMain SF, Guimond T, Barnhart R, . A randomized trial of brief dialectical behaviour therapy skills training in suicidal patients suffering from borderline disorder. Acta Psychiatr Scand. 2017;135(2):138–48. PMID: 27858962. 10.1111/acps.12664 27858962
189 Muhlmann C, Madsen T, Hjorthoj C, . Effectiveness of an Internet-Based Self-help Therapy Program for Suicidal Ideation With Follow-up at 6 Months: Results of a Randomized Controlled Trial. Journal of Clinical Psychiatry. 2021;82(5):31. PMID: 34464522. 10.4088/JCP.20m13803 34464522
190 Pigeon WR, Funderburk JS, Cross W, . Brief CBT for insomnia delivered in primary care to patients endorsing suicidal ideation: a proof-of-concept randomized clinical trial. Transl Behav Med. 2019;9(6):1169–77. PMID: 31271210. 10.1093/tbm/ibz108 31271210
191 Pistorello J, Fruzzetti AE, Maclane C, . Dialectical behavior therapy (DBT) applied to college students: a randomized clinical trial. J Consult Clin Psychol. 2012;80(6):982–94. PMID: 22730955. 10.1037/a0029096 22730955
192 Pistorello J, Jobes DA, Gallop R, . A Randomized Controlled Trial of the Collaborative Assessment and Management of Suicidality (CAMS) Versus Treatment as Usual (TAU) for Suicidal College Students. Arch. 2021;25(4):765–89. PMID: 32275480. 10.1080/13811118.2020.1749742 32275480
193 Priebe S, Bhatti N, Barnicot K, . Effectiveness and cost-effectiveness of dialectical behaviour therapy for self-harming patients with personality disorder: a pragmatic randomised controlled trial. Psychother Psychosom. 2012;81(6):356–65. PMID: 22964561. 10.1159/000338897 22964561
194 Riblet NB, Kenneally L, Stevens S, . A virtual, pilot randomized trial of a brief intervention to prevent suicide in an integrated healthcare setting. General hospital psychiatry. 2022;75:68–74. PMID: 35202942. 10.1016/j.genhosppsych.2022.02.002 35202942
195 Simon GE, Shortreed SM, Rossom RC, . Effect of Offering Care Management or Online Dialectical Behavior Therapy Skills Training vs Usual Care on Self-harm Among Adult Outpatients With Suicidal Ideation: A Randomized Clinical Trial. JAMA. 2022;327(7):630–8. PMID: 35166800. 10.1001/jama.2022.0423 35166800
196 Torok M, Han J, McGillivray L, . The effect of a therapeutic smartphone application on suicidal ideation in young adults: Findings from a randomized controlled trial in Australia. PLoS Med. 2022;19(5):e1003978. PMID: 35639672. 10.1371/journal.pmed.1003978 35639672
197 Van Orden KA, Arean PA, Conwell Y. A Pilot Randomized Trial of Engage Psychotherapy to Increase Social Connection and Reduce Suicide Risk in Later Life. Am J Geriatr Psychiatry. 2021;29(8):789–800. PMID: 33952416. 10.1016/j.jagp.2021.03.009 33952416
198 van Spijker B, van Straten A, Kerkhof A. Effectiveness of online self-help for suicidal thoughts: results of a randomised controlled trial. PloS one. 2014;9(2):e90118. PMID: 24587233. 10.1371/journal.pone.0090118 24587233
199 Ward-Ciesielski EF, Tidik JA, Edwards AJ, . Comparing brief interventions for suicidal individuals not engaged in treatment: A randomized clinical trial. Journal of affective disorders. 2017;222:153–61. PMID: 28709022. 10.1016/j.jad.2017.07.011 28709022
200 Alves-Bradford JM, Trinh NH, Bath E, . Mental Health Equity in the Twenty-First Century: Setting the Stage. Psychiatr Clin North Am. 2020;43(3):415–28. PMID: 32773071 10.1016/j.psc.2020.05.001 32773071
201 Bailey ZD, Krieger N, Agénor M, . Structural racism and health inequities in the USA: evidence and interventions. Lancet (London, England). 2017;389(10077):1453–63. PMID: 28402827 10.1016/s0140-6736(17)30569-x 28402827
202 Wildeman C, Wang EA. Mass incarceration, public health, and widening inequality in the USA. Lancet (London, England). 2017;389(10077):1464–74. PMID: 28402828 10.1016/s0140-6736(17)30259-3 28402828
203 McIntosh K, Moss E, Nunn R, . Examining the Black-white wealth gap. Up Front. WA, DC: The Brookings Institution; 2020.
204 Himmelstein G, Himmelstein KEW. Inequality Set in Concrete: Physical Resources Available for Care at Hospitals Serving People of Color and Other U.S. Hospitals. Int J Health Serv. 2020;50(4):363–70. PMID: 32611234 10.1177/0020731420937632 32611234
205 Muramatsu N. County-level income inequality and depression among older Americans. Health Serv Res. 2003;38(6 Pt 2):1863–83. PMID: 14727801 10.1111/j.1475-6773.2003.00206.x 14727801
206 Messias E, Eaton WW, Grooms AN. Economic grand rounds: Income inequality and depression prevalence across the United States: an ecological study. Psychiatr Serv. 2011;62(7):710–2. PMID: 21724781 10.1176/ps.62.7.pss6207_0710 21724781
207 Nandi A, Galea S, Ahern J, . What explains the association between neighborhood-level income inequality and the risk of fatal overdose in New York City? Soc Sci Med. 2006;63(3):662–74. PMID: 16597478 10.1016/j.socscimed.2006.02.001 16597478
208 Pickett KE, Wilkinson RG. Child wellbeing and income inequality in rich societies: ecological cross sectional study. BMJ (Clinical research ed). 2007;335(7629):1080. PMID: 18024483 10.1136/bmj.39377.580162.55 18024483
209 Galea S, Tracy M, Hoggatt KJ, . Estimated deaths attributable to social factors in the United States. Am J Public Health. 2011;101(8):1456–65. PMID: 21680937 10.2105/ajph.2010.300086 21680937
210 Purtle J. COVID-19 and mental health equity in the United States. Soc Psychiatry Psychiatr Epidemiol. 2020;55(8):969–71. PMID: 32556376 10.1007/s00127-020-01896-8 32556376
211 Bailey RK, Mokonogho J, Kumar A. Racial and ethnic differences in depression: current perspectives. Neuropsychiatr Dis Treat. 2019/03/14 ed2019. p. 603–9. PMID: 3086308130863081. 10.2147/ndt.S128584
212 Williams DR, Lawrence JA, Davis BA, . Understanding how discrimination can affect health. Health Serv Res. 2019;54 Suppl 2(Suppl 2):1374–88. PMID: 31663121 10.1111/1475-6773.13222 31663121
213 National Public Radio, The Robert Wood Johnson Foundation, Harvard T.H. Chan School of Public Health. Discrimination in America: Final Summary. 2018.
214 Sorkin DH, Murphy M, Nguyen H, . Barriers to Mental Health Care for an Ethnically and Racially Diverse Sample of Older Adults. J Am Geriatr Soc. 2016;64(10):2138–43. PMID: 27565017 10.1111/jgs.14420 27565017
215 Shepard Payne J. Influence of Race and Symptom Expression on Clinicians’ Depressive Disorder Identification in African American Men. Journal of the Society for Social Work and Research. 2012;3(3):162–77. 10.5243/jsswr.2012.11
216 Flores MW, Moyer M, Rodgers CRR, . Major Depressive Episode Severity Among Adults from Marginalized Racial and Ethnic Backgrounds in the US. JAMA Psychiatry. 2021. PMID: 3449528234495282. 10.1001/jamapsychiatry.2021.2485
217 Hahm HC, Cook BL, Ault-Brutus A, . Intersection of race-ethnicity and gender in depression care: screening, access, and minimally adequate treatment. Psychiatr Serv. 2015;66(3):258–64. PMID: 25727113. 10.1176/appi.ps.201400116 25727113
218 Kato E, Borsky AE, Zuvekas SH, . Missed Opportunities for Depression Screening and Treatment in the United States. Journal of the American Board of Family Medicine : JABFM. 2018;31(3):389–97. PMID: 29743222. 10.3122/jabfm.2018.03.170406 29743222
219 Patel JS, Oh Y, Rand KL, . Measurement invariance of the patient health questionnaire-9 (PHQ-9) depression screener in U.S. adults across sex, race/ethnicity, and education level: NHANES 2005-2016. Depress Anxiety. 2019;36(9):813–23. PMID: 31356710. 10.1002/da.22940 31356710
220 Harry ML, Waring SC. The measurement invariance of the Patient Health Questionnaire-9 for American Indian adults. Journal of affective disorders. 2019;254:59–68. PMID: 31108281. 10.1016/j.jad.2019.05.017 31108281
221 Huang FY, Chung H, Kroenke K, . Using the Patient Health Questionnaire-9 to measure depression among racially and ethnically diverse primary care patients. Journal of general internal medicine. 2006;21(6):547–52. PMID: 16808734. 10.1111/j.1525-1497.2006.00409.x 16808734
222 Kim G, Decoster J, Huang CH, . Race/ethnicity and the factor structure of the Center for Epidemiologic Studies Depression Scale: a meta-analysis. Cultur Divers Ethnic Minor Psychol. 2011;17(4):381–96. PMID: 21988578. 10.1037/a0025434 21988578
223 Moazen-Zadeh E, Assari S. Depressive Symptoms Predict Major Depressive Disorder after 15 Years among Whites but Not Blacks. Front Public Health. 2016;4:13. PMID: 26925396. 10.3389/fpubh.2016.00013 26925396
224 Kim G, DeCoster J, Huang CH, . A meta-analysis of the factor structure of the Geriatric Depression Scale (GDS): the effects of language. Int Psychogeriatr. 2013;25(1):71–81. PMID: 22929164. 10.1017/s1041610212001421 22929164
225 Di Florio A, Putnam K, Altemus M, . The impact of education, country, race and ethnicity on the self-report of postpartum depression using the Edinburgh Postnatal Depression Scale. Psychol Med. 2017;47(5):787–99. PMID: 27866476. 10.1017/s0033291716002087 27866476
226 Parkerson HA, Thibodeau MA, Brandt CP, . Cultural-based biases of the GAD-7. Journal of Anxiety Disorders. 2015;31:38–42. 10.1016/j.janxdis.2015.01.005 25725310
227 Stockdale SE, Lagomasino IT, Siddique J, . Racial and ethnic disparities in detection and treatment of depression and anxiety among psychiatric and primary health care visits, 1995-2005. Med Care. 2008;46(7):668–77. PMID: 18580385 10.1097/MLR.0b013e3181789496 18580385
228 Coyne JC, Marcus SC. Health disparities in care for depression possibly obscured by the clinical significance criterion. Am J Psychiatry. 2006;163(9):1577–9. PMID: 16946183. 10.1176/ajp.2006.163.9.1577 16946183
229 Breslau J, Javaras KN, Blacker D, . Differential item functioning between ethnic groups in the epidemiological assessment of depression. J Nerv Ment Dis. 2008;196(4):297–306. PMID: 18414124. 10.1097/NMD.0b013e31816a490e 18414124
230 Olbert CM, Nagendra A, Buck B. Meta-analysis of Black vs. White racial disparity in schizophrenia diagnosis in the United States: Do structured assessments attenuate racial disparities? J Abnorm Psychol. 2018;127(1):104–15. PMID: 29094963. 10.1037/abn0000309 29094963
231 Strakowski SM, Keck PE, Jr., Arnold LM, . Ethnicity and diagnosis in patients with affective disorders. The Journal of clinical psychiatry. 2003;64(7):747–54. PMID: 12934973. 10.4088/jcp.v64n0702 12934973
232 Strakowski SM, Hawkins JM, Keck PE, Jr., . The effects of race and information variance on disagreement between psychiatric emergency service and research diagnoses in first-episode psychosis. The Journal of clinical psychiatry. 1997;58(10):457–63; quiz 64-5. PMID: 9375599. 10.4088/jcp.v58n1010a 9375599
233 Eack SM, Bahorik AL, Newhill CE, . Interviewer-perceived honesty as a mediator of racial disparities in the diagnosis of schizophrenia. Psychiatr Serv. 2012;63(9):875–80. PMID: 22751938. 10.1176/appi.ps.201100388 22751938
234 Londono Tobon A, Flores JM, Taylor JH, . Racial Implicit Associations in Psychiatric Diagnosis, Treatment, and Compliance Expectations. Acad Psychiatry. 2021;45(1):23–33. PMID: 33438155. 10.1007/s40596-020-01370-2 33438155
235 Coker TR, Elliott MN, Toomey SL, . Racial and Ethnic Disparities in ADHD Diagnosis and Treatment. Pediatrics. 2016;138(3). PMID: 27553219. 10.1542/peds.2016-0407 27553219
236 Substance Abuse and Mental Health Services Administration. Racial/Ethnic Differences in Mental Health Service Use among Adults. Rockville, MD: 2015.
237 Hines AL, Cooper LA, Shi L. Racial and ethnic differences in mental healthcare utilization consistent with potentially effective care: The role of patient preferences. General hospital psychiatry. 2017;46:14–9. PMID: 28622809. 10.1016/j.genhosppsych.2017.02.002 28622809
238 Coleman KJ, Stewart C, Waitzfelder BE, . Racial-Ethnic Differences in Psychiatric Diagnoses and Treatment Across 11 Health Care Systems in the Mental Health Research Network. Psychiatr Serv. 2016;67(7):749–57. PMID: 27079987. 10.1176/appi.ps.201500217 27079987
239 Cook BL, Trinh NH, Li Z, . Trends in Racial-Ethnic Disparities in Access to Mental Health Care, 2004-2012. Psychiatr Serv. 2017;68(1):9–16. PMID: 27476805. 10.1176/appi.ps.201500453 27476805
240 Bishop TF, Press MJ, Keyhani S, . Acceptance of insurance by psychiatrists and the implications for access to mental health care. JAMA Psychiatry. 2014;71(2):176–81. PMID: 24337499. 10.1001/jamapsychiatry.2013.2862 24337499
241 Fortuna LR, Alegria M, Gao S. Retention in depression treatment among ethnic and racial minority groups in the United States. Depress Anxiety. 2010;27(5):485–94. PMID: 20336808. 10.1002/da.20685 20336808
242 Jonassaint CR, Belnap BH, Huang Y, . Racial Differences in the Effectiveness of Internet-Delivered Mental Health Care. Journal of general internal medicine. 2020;35(2):490–7. PMID: 31745855. 10.1007/s11606-019-05542-1 31745855
243 Rathod S, Gega L, Degnan A, . The current status of culturally adapted mental health interventions: a practice-focused review of meta-analyses. Neuropsychiatr Dis Treat. 2018;14:165–78. PMID: 29379289. 10.2147/ndt.S138430 29379289
244 Arundell L-L, Barnett P, Buckman JEJ, . The effectiveness of adapted psychological interventions for people from ethnic minority groups: A systematic review and conceptual typology. Clin Psychol Rev. 2021;88:102063. 10.1016/j.cpr.2021.102063 34265501
245 Alegría M, Alvarez K, Ishikawa RZ, . Removing Obstacles To Eliminating Racial And Ethnic Disparities In Behavioral Health Care. Health Aff (Millwood). 2016;35(6):991–9. PMID: 27269014. 10.1377/hlthaff.2016.0029 27269014
246 American Psychological Association. Health Care Reform: Disparities in Mental Health Status and Mental Health Care. WA, DC: American Psychological Association; 2021.