# Appendix J Ongoing Studies

Appendix J Table 1 Ongoing Screening Trials for Depression, Anxiety, or High Suicide Risk Depression,

Condition | Trial | Trial number | Location | N | Duration (years) | Intervention | Relevant endpoints | Estimated completion date
Depression | General Practitioner (GP) education and screening feedback for improving depression outcomes among primary care patients | ACTRN12618001139268 | Australia | 1992 | 1 year | General Practitioner education and screening feedback vs. no education and screening feedback | Proportion of patients scoring 10 or more on the Patient Health Questionnaire (PHQ-9), delivery of mental health services, supply of prescribed psychotropic medications | Dec 2021; Protocol published (https://doi.org/10.1136/bmjopen-2019-032057)
Depression | GET.FEEDBACK.GP | NCT03988985 | Germany | 1074 | 6 months | Patient and GP-targeted feedback vs. GP-targeted feedback only vs. no feedback | Depression severity, depression treatment, qualityadjusted life years, anxiety | Sep 2022; Protocol published (https://doi.org/10.1136/bmjopen-2019-035973)
Depression | The Efficacy of Automated Feedback After Internet-based Depression Screening (DISCOVER) | NCT04633096 | Germany | 1074 | 6 months | Tailored feedback vs. standardized feedback vs. no feedback | Depression severity, health-related quality of life, anxiety, depression diagnosis, AEs | Sep 2022; Protocol published (https://doi.org/10.1136/bmjopen-2019-035973)
Depression | Depression Screening in Black Churches | NCT04524767 | US | 600 | 3 and 6 months | Screening, brief intervention, and referral to treatment vs. referral as usual or edu brochures | Changes in depression severity, depressive symptoms, and QoL | May 2025
Depression/Anxiety | Perinatal Identification, Referral and Integrated Management for Improving Depression: The PIRIMID Study | ACTRN12619001433190 | Australia | 1650 | 6 months | Integrated electronic screening and clinical decision support system vs. usual care | Treatment uptake, anxiety and stress symptoms, health-related quality of life | Oct 2021; No results available
Depression/Anxiety | Improving mental health screening for Aboriginal and Torres Strait Islander pregnant women and mothers of young children | ACTRN12619000580178 | Australia | 1246 | 1 year | Screening with the Kimberley Mum’s Mood Scale (KMMS) vs. reference standard assessment | Sensitivity of the KMMS for screening for perinatal anxiety and depression, health system responses to identified risk; pattern of change in KMMS risk | Nov 2021; Protocol Published (https://doi.org/10.1186/s12889-019-7845-3)
Depression/Anxiety | New Moms Mood Tracking & Wellbeing | NCT05056454 | US | 200 | 26 weeks | Screening and Treatment of Anxiety and Depression (STAND) vs. TAU | Depression score reduction (EPDS-9), Sheehan disability scale results | June 2023
Suicide | A System of Safety (SOS) | NCT03104504 | United States | 31000 | 4.5 years | CQI initiative implementation vs. preinitiative implementation (primary focus on ED, inpatient units; involvement of primary care at last phase of study) | Standardized suicide risk screening, safety planning, means restriction counseling, suicide risk identification, suicide outcomes | June 2023
Suicide | Adaptive Implementation Intervention for VA Suicide Risk Identification Strategy | NCT04243330 | United States | 140 | 1 year | Audit and feedback vs. audit and feedback + external facilitation vs. implementation as usual | Columbia Suicide Severity Rating Scale Screener, comprehensive Suicide risk evaluation uptake, safety planning uptake | Apr 2023; Protocol published (https://doi.org/10.1186/s13012-020-01019-6)
| Effectiveness and Implementation of eScreening in Post 9/11 Transition Programs | NCT04506164 | United States | 45 | NR | eScreening compared to screening as usual | Change in rate of referral to care; rate of screening completion; rate of comprehensive suicide risk evaluation | Dec 2023

Abbreviations: AE = adverse event; CQI = continuous quality improvement; ED = emergency department; edu = education; EPDS = Edinburgh Postnatal Depression Scale; GP = general practitioner; QoL = quality of life; TAU = treatment as usual.