# Appendix I Additional Details on CQ2

Appendix I Additional Details on Contextual Question 2: Diagnosis, Referral, and Treatment Outcomes Reported by Studies of Depression, Anxiety, or Suicide Risk Screening Studies

Author, year (Study name); Quality | Group | Pop | Outcome | Notes | FUP | IG n | CG n | IG; BL | CG; BL | IG mean chg; (SD) or n/N (%) | CG mean chg; (SD) or n/N (%) | Effect type | Betweengroup difference, p-value
Whooley, 2000^40^; Fair | All | Older adults | Provider dx depression | Depression diagnosed by a physician | 104 | 162 | 169 | NR (NR) | NR (NR) | 56/162; (35.0) | 58/169; (34.0) | OR | 1.00 (0.60 to 1.60), 0.96
Callahan, 1994^29^; Fair | All | Older adults | Provider dx depression | Depression diagnosis in medical record | 26 | 76 | 60 | NR; (NR) | NR; (NR) | 25/76; (32.3) | 7/60; (12.1) | calc OR | 3.41 (1.25 to 9.36), 0.002
Leung, 2011^33^; Good | All | Perinatal | Provider dx depression | Probable depression recognized | p26 | 231 | 231 | NR; (NR) | NR; (NR) | 67/231; (29.0) | 14/231; (6.0) | calc OR | 6.33 (3.44 to 11.66), ≤0.05
Williams, 1999^42^; Fair | Depression dx at BL | General adults | Provider dx depression | Diagnosed by physician | 13 | 77 | 38 | NR; (NR) | NR; (NR) | 30/77; (39.0) | 11/38; (29.0) | calc OR | 1.57 (0.68 to 3.62), NSD
Williams, 1999^42^; Fair | MDD dx at BL | General adults | Provider dx depression | Diagnosed by physician | 13 | 49 | 20 | NR; (NR) | NR; (NR) | 22/49; (45.0) | 5/20; (24.0) | calc OR | 2.44 (0.77 to 7.78), <0.02
Yawn, 2012^43^; Fair | EPDS ≥10 at BL | Perinatal | Provider dx depression | According to PHQ-9 scores and clinician assessment (Clinician NS) | p52 | 322 | 233 | NR; (NR) | NR; (NR) | 194/322; (66.0) | 78/233; (41.0) | calc OR | 3.01 (2.12 to 4.28), 0.0001
Bergus, 2005^27^; Fair | All | General adults | Advised counseling | - | 10 | 24 | 27 | NR; (NR) | NR; (NR) | 5/24; (22.0) | 3/27; (12.0) | calc OR | 2.11 (0.45 to 9.95), 0.32
Bergus, 2005^27^; Fair | PHQ-9 ≥10 at BL | General adults | Advised counseling | - | 10 | 10 | 11 | NR; (NR) | NR; (NR) | 1/10; (10.0) | 0/11; (0.0) | calc OR | 3.63 (0.13 to 99.85), 0.28
Bergus, 2005^27^; Fair | PHQ-9 ≥10 at BL | General adults | Advised counseling | - | 10 | 14 | 16 | NR; (NR) | NR; (NR) | 4/14; (29.0) | 3/16; (20.0) | calc OR | 1.73 (0.31 to 9.57), 0.59
Wickberg, 2005^41^; Fair | EPDS≥12 at BL | Perinatal | Referral to mental health | Study used cut-off level of 11/12 for EPDS | p10 | 34 | 31 | NR; (NR) | NR; (NR) | 13/34; (38.2) | 5/31; (16.1) | calc OR | 3.22 (0.99 to 10.49), NSD
Rost, 2001^36^; Good | In treatment at BL | General adults | Referral to mental health | Referral for psychotherapy | 26 | | | NR; (NR) | NR; (NR) | NR; (51.8) | NR; (45.0) | OR | 1.31 (NR), 0.32
Rost, 2001^36^; Good | New treatment episode | General adults | Referral to mental health | Referral for psychotherapy | 26 | 97 | 92 | NR; (NR) | NR; (NR) | 22/97; (22.7) | 13/92; (14.1) | OR | 1.83 (NR), 0.21
Leung, 2011^33^; Good | All | Perinatal | Tx: counseling | Received counseling session | p26 | 231 | 231 | NR; (NR) | NR; (NR) | 55/231; (23.8) | 11/231; (4.8) | calc OR | 6.25 (3.18 to 12.30), ≤0.05
Yawn, 2012^43^; Fair | EPDS ≥10 at BL | Perinatal | Tx: counseling | Tx of women with postpartum depression diagnosis | p52 | 322 | 233 | NR; (NR) | NR; (NR) | 54/322; (20.0) | 20/233; (11.0) | calc OR | 2.15 (1.25 to 3.70), 0.02
Wells, 2000^39^; Fair | All | General adults | Any specialty counseling | - | 26 | 770 | 386 | NR; (NR) | NR; (NR) | 294/770; (38.2) | 99/386; (25.6) | calc OR | 1.79 (1.37 to 2.35), <0.001
Wells, 2000^39^; Fair | All | General adults | Any specialty counseling | - | 52 | 752 | 374 | NR; (NR) | NR; (NR) | 205/752; (27.3) | 78/374; (20.9) | calc OR | 1.42 (1.06 to 1.91), 0.03
Whooley, 2000^40^; Fair | All | Older adults | Prescription for antidepressants | - | 104 | 162 | 169 | NR; (NR) | NR; (NR) | 59/162; (36.0) | 72/169; (43.0) | OR | 0.80 (0.50 to 1.20), 0.3
Whooley, 2000^40^; Fair | GDS ≥11 at BL | Older adults | Prescription for antidepressants | - | 104 | 24 | 36 | NR; (NR) | NR; (NR) | 12/24; (50.0) | 17/36; (47.0) | OR | 1.10 (0.40 to 3.10), 0.8
Morrell, 2009^35^; Fair | All | Perinatal | Antidepressant prescriptions | - | p26 | 1237 | 495 | NR; (NR) | NR; (NR) | FUP= 0(NR) | FUP= .1(NR) | MeanDiff | −0.10 (−0.10 to 0.00), NR
Morrell, 2009^35^; Fair | EPDS ≥12 at p06 | Perinatal | Antidepressant prescriptions | - | p26 | 195 | 78 | NR; (NR) | NR; (NR) | FUP= .3(NR) | FUP= .5(NR) | MeanDiff | −0.20 (−0.50 to 0.10), NSD
Bergus, 2005^27^; Fair | All | General adults | Tx: medication | Newly prescribed AD | 10 | 24 | 27 | NR; (NR) | NR; (NR) | 10/24; (42.0) | 8/27; (30.0) | calc OR | 1.70 (0.53 to 5.40), 0.34
Bergus, 2005^27^; Fair | PHQ-9 ≥10 at BL | General adults | Tx: medication | Newly prescribed AD | 10 | 14 | 16 | NR; (NR) | NR; (NR) | 6/14; (43.0) | 7/16; (44.0) | calc OR | 0.96 (0.23 to 4.10), 0.96
Bergus, 2005^27^; Fair | PHQ-9 ≥10 at BL | General adults | Tx: medication | Newly prescribed AD | 10 | 10 | 11 | NR; (NR) | NR; (NR) | 4/10; (40.0) | 1/11; (9.0) | calc OR | 6.67 (0.60 to 74.51), 0.10
Callahan, 1994^29^; Fair | All | Older adults | Tx: medication | Newly prescribed AD | 26 | 76 | 60 | NR; (NR) | NR; (NR) | 20/76; (26.0) | 5/60; (8.0) | calc OR | 3.91 (1.21 to 12.62), 0.01
Wells, 2000^39^; Fair | All | General adults | Any appropriate antidepressant meds | - | 26 | 771 | 380 | NR; (NR) | NR; (NR) | 268/771; (34.7) | 95/380; (25.1) | calc OR | 1.60 (1.21 to 2.11), 0.001
Wells, 2000^39^; Fair | All | General adults | Any appropriate antidepressant meds | - | 52 | 753 | 371 | NR; (NR) | NR; (NR) | 233/753; (31.0) | 89/371; (24.0) | calc OR | 1.42 (1.07 to 1.89), 0.01
Jarjoura, 2004^31^; Fair | All | General adults | Tx: medication | - | 52 | 33 | 28 | NR; (NR) | NR; (NR) | 21/33; (64.0) | 4/28; (15.0) | calc OR | 10.50 (2.94 to 37.54), ≤0.05
Yawn, 2012^43^; Fair | EPDS ≥10 at BL | Perinatal | Tx: medication | Tx of women with postpartum depression diagnosis | p52 | 322 | 233 | NR; (NR) | NR; (NR) | 169/322; (56.0) | 67/233; (35.0) | calc OR | 2.74 (1.91 to 3.92), <0.0001
Rost, 2001^36^; Good | In treatment at BL | General adults | Tx: medication | Received any pharmacotherapy | 26 | | | NR; (NR) | NR; (NR) | NR; (NR) | NR; (NR) | | NR, NSD
Rost, 2001^36^; Good | New treatment episode | General adults | Tx: medication | Received any pharmacotherapy | 26 | 97 | 92 | NR; (NR) | NR; (NR) | 67/97; (69.1) | 26/92; (28.3) | calc OR | 5.67 (3.03 to 10.60), NSD
Jarjoura, 2004^31^; Fair | All | General adults | Tx: medication or counseling | - | 52 | 33 | 28 | NR; (NR) | NR; (NR) | 23/33; (70.0) | 4/28; (15.0) | calc OR | 13.80 (3.79 to 50.28), ≤0.05
Williams, 1999^42^; Fair | MDD dx at BL | General adults | Tx: medication or counseling | - | 13 | 49 | 20 | NR; (NR) | NR; (NR) | 27/49; (55.0) | 6/20; (28.0) | calc OR | 2.86 (0.94 to 8.69), 0.005
Yawn, 2012^43^; Fair | EPDS ≥10 at BL | Perinatal | Tx: medication plus counseling | Tx of women with postpartum depression diagnosis | p52 | 322 | 233 | NR; (NR) | NR; (NR) | 176/322; (60.0) | 70/233; (37.0) | calc OR | 2.81 (1.97 to 4.01), <0.0001
Bergus, 2005^27^; Fair | All | General adults | Tx: newly prescribed ADs or advised couns | - | 10 | 24 | 27 | NR; (NR) | NR; (NR) | 11/24; (46.0) | 9/27; (33.0) | calc OR | 1.69 (0.54 to 5.26), 0.36
Bergus, 2005^27^; Fair | PHQ-9 ≥10 at BL | General adults | Tx: newly prescribed ADs or advised couns | - | 10 | 14 | 16 | NR; (NR) | NR; (NR) | 7/14; (50.0) | 8/16; (50.0) | calc OR | 1.00 (0.24 to 4.20), 1.0
Bergus, 2005^27^; Fair | PHQ-9 ≥10 at BL | General adults | Tx: newly prescribed ADs or advised couns | - | 10 | 10 | 11 | NR; (NR) | NR; (NR) | 4/10; (40.0) | 1/11; (9.0) | calc OR | 6.67 (0.60 to 74.51), 0.10
Wells, 2000^39^; Fair | All | General adults | Overall appropriate care | - | 26 | 772 | 380 | NR; (NR) | NR; (NR) | 393/772; (50.9) | 151/380; (39.7) | calc OR | 1.57 (1.23 to 2.02), <0.001
Wells, 2000^39^; Fair | All | General adults | Overall appropriate care | - | 52 | 720 | 305 | NR; (NR) | NR; (NR) | 426/720; (59.2) | 153/305; (50.1) | calc OR | 1.44 (1.10 to 1.88), 0.006
Callahan, 1994^29^; Fair | All | Older adults | Adequate treatment course | Remained on antidepressant for 6 mo | 26 | 76 | 60 | NR; (NR) | NR; (NR) | 25/76; (33.0) | 11/60; (19.0) | calc OR | 2.11 (0.86 to 5.20), 0.04
Rost, 2001^36^; Good | In treatment at BL | General adults | Adequate treatmentpsychotherapy | ≥8 session MH specialty care visits over 6 mo | 26 | | | NR; (NR) | NR; (NR) | NR; (31.3) | NR; (19.1) | OR | 1.93 (NR), 0.05
Rost, 2001^36^; Good | New treatment episode | General adults | Adequate treatmentpsychotherapy | ≥8 session MH specialty care visits over 6 mo | 26 | 97 | 92 | NR; (NR) | NR; (NR) | 3/97; (3.1) | 1/92; (1.1) | OR | 3.48 (NR), 0.33
Rost, 2001^36^; Good | In treatment at BL | General adults | Adequate treatmentpharmacotherapy | Guideline concordant pharmacotherapy (≥3 mo at ≥minimum dose) | 26 | | | NR; (NR) | NR; (NR) | NR; (NR) | NR; (NR) | | NR, NSD
Rost, 2001^36^; Good | New treatment episode | General adults | Adequate treatmentpharmacotherapy | Guideline concordant pharmacotherapy (≥3 mo at ≥minimum dose) | 26 | 97 | 92 | NR; (NR) | NR; (NR) | 35/97; (36.1) | 9/92; (9.8) | OR | 5.13 (NR), <0.001

Abbreviations: AD = antidepressant; BL = baseline; CG = control group; cal = calculated; chg = change; couns = counseling; dx = diagnosis; EPDS = Edinburgh Postnatal Depression Scale; FUP = followup; GDS = Geriatric Depression Scale; IG = intervention group; MDD = major depressive disorder; MeanDiff = mean difference; MH = mental health; NR = not reported; NS = not significant; NSD = no significant difference; OR = odds ratio; PHQ = Patient Health Questionnaire; SD = standard deviation Tx =treatment.