# Appendix G Additional Evidence for Suicide Risk

Appendix G Table 1 Intervention Description of Suicide Risk Screening Studies (KQ1)

Appendix G Table 2 Test Accuracy of Screening Instruments to Identify Suicidal Ideation

Appendix G Table 3 Detailed Participant Characteristics Among Studies of Suicide Prevention Treatment (KQ4)

Appendix G Table 4 Detailed Intervention Characteristics Among Studies of Suicide Prevention Treatment (KQ4)

Appendix G Table 5 Results for Suicide Deaths, Suicide Attempts, and All-Cause Mortality Among Studies of Suicide Prevention Treatment (KQ4)

Appendix G Table 6 Results for Suicidal Ideation and Other Continuous Suicide-Related Measures Among Studies of Suicide Prevention Treatment (KQ4)

Appendix G Table 7 Results for Depression Measures Among Studies of Suicide Prevention Treatment (KQ4)

Appendix G Table 8 Results for Other Mental Health Outcomes Among Studies of Suicide Prevention Treatment (KQ4)

Appendix G Table 9 Results for Other Health Outcomes Among Studies of Suicide Prevention Treatment (KQ4)