# Appendix F Additional Evidence for Anxiety

Appendix F Table 1 Intervention Description of Anxiety Screening Studies (KQ1)

Appendix F Table 2 Test Accuracy of Screening Instruments to Detect Generalized Anxiety Disorder (KQ2)

Appendix F Table 3 Test Accuracy of Screening Instruments to Detect Any Anxiety Disorder (KQ2)

Appendix F Table 4 Test Accuracy of Screening Instruments to Detect Panic Disorder (KQ2)

Appendix F Table 5 Test Accuracy of Screening Instruments to Detect Social Anxiety Disorder (KQ2)

Appendix F Table 6 Detailed Participant Characteristics for Primary Research Studies of Psychological Treatment of Anxiety in Primary Care Populations (KQ4)

Appendix F Table 7 Detailed Intervention Characteristics for Primary Research Studies of Psychological Treatment of Anxiety in Primary Care Populations

Appendix F Table 8 Detailed Inclusion and Exclusion Criteria of Existing Systematic Reviews Addressing Benefits of Psychological Treatment of Anxiety (KQ4)

Appendix F Table 9 Anxiety Symptom Severity Results for Primary Research Studies of Psychological Treatment of Anxiety in Primary Care Populations (KQ4)

Appendix F Table 10 Anxiety Symptom Remission and Response Results for Primary Research Studies of Psychological Treatment of Anxiety in Primary Care Populations (KQ4)

Appendix F Table 11 Results for Anxiety Symptoms Severity From ESRs of Psychological Treatment of Anxiety Compared to Controls (KQ4)

Appendix F Table 12 Other Mental Health Outcome Results for Primary Research Studies of Psychological Treatment of Anxiety in Primary Care Populations (KQ4)

Appendix F Table 13 Quality of Life Outcome Results for Primary Research Studies of Psychological Treatment of Anxiety in Primary Care Populations (KQ4)

Appendix F Table 14 Functioning Outcome Results for Primary Research Studies of Psychological Treatment of Anxiety in Primary Care Populations (KQ4)

Appendix F Table 15 Other Health Outcome Results for Primary Research Studies of Psychological Treatment of Anxiety in Primary Care Populations (KQ4)

Appendix F Table 16 Results for Other Outcomes From ESRs of Psychological Treatment of Anxiety Compared to Controls (KQ4)

Appendix F Table 17 Detailed Inclusion and Exclusion Criteria of Existing Systematic Reviews Addressing Benefits of Pharmacologic Treatment of Anxiety (KQ4)

Appendix F Table 18 Anxiety Outcome Results for Primary Research Studies of Pharmacologic Treatment of Anxiety in Primary Care Populations (KQ4)

Appendix F Table 19 Results for Anxiety Symptoms Severity From ESRs of Pharmacologic Treatment of Anxiety Compared to Controls (KQ4)

Appendix F Table 20 Results for Anxiety Remission From ESRs of Pharmacologic Treatment of Anxiety Compared to Controls (KQ4)

Appendix F Table 21 Results for Anxiety Response to Treatment From ESRs of Pharmacologic Treatment of Anxiety Compared to Controls (KQ4)

Appendix F Table 22 Results for Other Outcomes From ESRs of Pharmacologic Treatment of Anxiety Compared to Controls (KQ4)

Appendix F Table 23 Results From Narrative Syntheses of Pharmacological Treatment of Anxiety (KQ4)

Appendix F Table 24 Results for Adverse Events From Primary Studies of Pharmacologic Treatment of Anxiety Compared to Placebo (KQ5)

Appendix F Table 25 Results for Adverse Events From ESRs of Pharmacologic Treatment of Anxiety Compared to Placebo (KQ5)

Appendix F Table 26 Results of Narrative Syntheses From ESRs of Pharmacologic Treatment of Anxiety (KQ5)