# Appendix E Additional Evidence for Depression

Appendix E Table 1 Participant Characteristics of Depression Screening Studies (KQ1)

Appendix E Table 2 Intervention Description of Depression Screening Studies (KQ1)

Appendix E Table 3 Depression Prevalence Results for Studies of Depression Screening (KQ1)

Appendix E Table 4 Depression Remission Results for Studies of Depression Screening (KQ1)

Appendix E Table 5 Depression Response Results for Studies of Depression Screening (KQ1)

Appendix E Table 6 Depression Symptom Severity Results for Studies of Depression Screening (KQ1)

Appendix E Table 7 Other Continuous Measures of Mental Health Results for Studies of Depression Screening (K1)

Appendix E Table 8 Quality of Life and Functioning Outcomes for Studies of Depression Screening (KQ1)

Appendix E Table 9 Functioning Outcomes Results for Studies of Depression Screening (KQ1)

Appendix E Table 10 Other Health Outcomes for Studies of Depression Screening (KQ1), Dichotomous Measures

Appendix E Table 11 Other Health Outcomes for Studies of Depression Screening (KQ1), Continuous Measures

Appendix E Table 12 Test Accuracy of the Geriatric Depression Scale to Detect MDD or Depression (KQ2)

Appendix E Table 13 Test Accuracy of Screening Tests for Major Depression Reported in ESRs (KQ2)

Appendix E Table 14 Adverse Events for Studies of Depression Screening (KQ3)

Appendix E Table 15 Detailed Inclusion and Exclusion Criteria of Existing Systematic Reviews Addressing Benefits of Psychological Treatment of Depression (KQ4)

Appendix E Table 16 Results for Depression Symptoms Severity From ESRs of Psychological Treatment for Depression (KQ4)

Appendix E Table 17 Results of Analyses From ESRs Examining Effect Modification of Depression Symptom Severity for Psychological Treatment of Depression (KQ4)

Appendix E Table 18 Results From Narrative Syntheses From ESRs of Psychological Treatment of Depression (KQ4)

Appendix E Table 19 Results for Remission and Response to Treatment From ESRs of Psychological Treatment for Depression (KQ4)

Appendix E Table 20 Pooled Standardized Mean Differences Between Groups for Health Outcomes Other Than Depression in ESRs of Psychological Treatment of Depression (KQ4)

Appendix E Table 21 Detailed Inclusion and Exclusion Criteria of Existing Systematic Reviews Addressing Benefits of Pharmacologic Treatment of Depression (KQ4)

Appendix E Table 22 Results for Depression Symptoms Severity From ESRs for Pharmacologic Treatment of Depression Compared to Placebo (KQ4)

Appendix E Table 23 Results for Depression Remission From ESRs for Pharmacologic Treatment of Depression Compared to Placebo (KQ4)

Appendix E Table 24 Results for Response to Depression Treatment From ESRs for Pharmacologic Treatment of Depression Compared to Placebo (KQ4)

Appendix E Table 25 Results for Other Outcomes From ESRs for Pharmacologic Treatment of Depression Compared to Placebo (KQ4)

Appendix E Table 26 Results of Effect Modification Analyses From ESRs of Pharmacologic Treatment of Depression (KQ4)

Appendix E Table 27 Results of Narrative Syntheses From ESRs of Pharmacologic Treatment of Depression (KQ4)

Appendix E Table 28 Detailed Inclusion and Exclusion Criteria of Existing Systematic Reviews Addressing Benefits of Psychological Treatment of Depression (KQ5)

Appendix E Table 29 Detailed Inclusion and Exclusion Criteria of Existing Systematic Reviews Addressing Harms of Pharmacologic Treatment of Depression (KQ5)

Appendix E Table 30 Results of Narrative Syntheses From ESRs of Pharmacologic Treatment of Depression (KQ5)

Appendix E Table 31 Results for Any Adverse Events From ESRs for Pharmacologic Treatment of Depression Compared to Placebo (KQ5)

Appendix E Table 32 Results for Dropout for Any Reason From ESRs for Pharmacologic Treatment of Depression Compared to Placebo (KQ5)

Appendix E Table 33 Results for Dropout Due to Adverse Events From ESRs for Pharmacologic Treatment of Depression Compared to Placebo (KQ5)

Appendix E Table 34 Results for Any Serious Adverse Events From ESRs for Pharmacologic Treatment of Depression Compared to Placebo (KQ5)

Appendix E Table 35 Results for Suicide-Related Outcomes From ESRs for Pharmacologic Treatment of Depression Compared to Placebo (KQ5)

Appendix E Table 36 Results for Falls and Fractures From ESRs for Pharmacologic Treatment of Depression Compared to Placebo (KQ5)

Appendix E Table 37 Results for CVD-Related Outcomes From ESRs for Pharmacologic Treatment of Depression Compared to Placebo (KQ5)

Appendix E Table 38 Results for Mortality From ESRs for Pharmacologic Treatment of Depression Compared to Placebo (KQ5)

Appendix E Table 39 Results for Other Adverse Events From ESRs for Pharmacologic Treatment of Depression Compared to Placebo (KQ5)