# Appendix D Excluded Studies List

Reason for Exclusion^*^
E1. Aim
E1a. Not an included condition
E2. Setting
E2a. Not conducted in very high HDI country
E3. Study design
E3a. Original research covered by an ESR
E3b. Development sample only (KQ2)
E4. Comparator
E5. Outcomes (no relevant outcomes)
E6. Outcome assessment timing
E7. Population
E7a. Primarily limited to an excluded population
E7b. Not limited to a primary care population but otherwise meets inclusion criteria
E8. Intervention
E9a. Not an included screening instrument (but addressed a target condition)
E9b. Not a relevant screening instrument (addressed an excluded condition)
E10a. ESR superseded by another ESR
E11. Poor quality
E12. Non-English
E13. Unable to locate article
E14. Abstract only or study ongoing, no outcomes published
E15. Interval between screener and ref std > 2 weeks

* Assigned at full-text phase

Abbreviations: E = exclude

## KQs 1 and 3 Excluded Studies

1 Ahmad, F, Lou, W, . Preconsult interactive computer-assisted client assessment survey for common mental disorders in a community health centre: a randomized controlled trial. CMAJ open. 5(1): E190–E197. 2017. PMID: 28401134. 10.9778/cmajo.20160118 KQ1E5, KQ3E528401134
2 Almeida, OP, Pirkis, J, . A randomized trial to reduce the prevalence of depression and self-harm behavior in older primary care patients. Ann Fam Med. 10(4): 347–356. 2012. PMID: 22778123. KQ1E1, KQ3E122778123
3 Anding, J, Rohrle, B, . Early Detection of Postpartum Depressive Symptoms in Mothers and Fathers and Its Relation to Midwives’ Evaluation and Service Provision: A Community-Based Study. Frontiers in Pediatrics. 3: 62. 2015. PMID: 26217649. 10.3389/fped.2015.00062 KQ1E1, KQ3E126217649
4 Bender, TheodoreW, Fitzpatrick, Skye, . Does it hurt to ask? An analysis of iatrogenic risk during suicide risk assessment. Neurol Psychol Brain Res. 33: 73–81. 2019. KQ1E2, KQ3E2
5 Bender, TW. Screening for Suicide in an Adult Population: An Analysis of Iatrogenic Risk. Psychology. Doctor of Philosophy. 2012. KQ1E2, KQ3E2
6 Boudreaux, ED, Camargo, CA, . Improving Suicide Risk Screening and Detection in the Emergency Department. Am J Prev Med. 50(4): 445–453. 2016. PMID: 26654691. 10.1016/j.amepre.2015.09.029 KQ1E5, KQ3E526654691
7 Byatt, N, Brenckle, L, . Improving perinatal depression care in obstetric settings: pRogram in Support of Moms (PRISM). Arch Womens Ment Health. 22(5): 702. 2019. KQ1E14, KQ3E14
8 de Beurs, DP, Ghoncheh, R, . Psychological Distress Because of Asking about Suicidal Thoughts: A Randomized Controlled Trial among Students. Archives of Suicide Research. 20(2): 153–9. 2016. PMID: 25751130. 10.1080/13811118.2015.1004475 KQ1E2, KQ3E225751130
9 Edward, KL, Giandinoto, JA, . Self-screening using the Edinburgh post natal depression scale for mothers and fathers to initiate early help seeking behaviours. Arch Psychiatr Nurs. 33(4): 421–427. 2019. PMID: 31280789. 10.1016/j.apnu.2019.05.007 KQ1E11, KQ3E1131280789
10 Fletcher, S, Spittal, MJ, . Clinical efficacy of a Decision Support Tool (Link-me) to guide intensity of mental health care in primary practice: a pragmatic stratified randomised controlled trial. The Lancet. Psychiatry. 8(3): 202–214. 2021. 10.1016/S2215-0366(20)30517-4 KQ1E4, KQ3E433571453
11 Gidding, LG, Spigt, M, . PsyScan e-tool to support diagnosis and management of psychological problems in general practice: a randomised controlled trial. Br J Gen Pract. 68(666): e18–e27. 2018. PMID: 29255109. 10.3399/bjgp17X694109 KQ1E7, KQ3E729255109
12 Gould, MS, Marrocco, FA, . Evaluating iatrogenic risk of youth suicide screening programs: a randomized controlled trial. JAMA. 293(13): 1635–1643. 2005. PMID: 15811983. KQ1E7a, KQ3E7a15811983
13 Gould, MS, Marrocco, FA, . Service use by at-risk youths after school-based suicide screening. J Am Acad Child Adolesc Psychiatry. 48(12): 1193–1201. 2009. PMID: 19858758. KQ1E7a, KQ3E7a19858758
14 Harris, KM, Goh, MT. Is suicide assessment harmful to participants? Findings from a randomized controlled trial. Int J Ment Health Nurs. 26(2): 181–190. 2017. 10.1111/inm.12223 KQ1E2, KQ3E227083774
15 Kigozi, J, Jowett, S, . Cost-Utility Analysis of Routine Anxiety and Depression Screening in Patients Consulting for Osteoarthritis: Results From a Clinical, Randomized Controlled Trial. Arthritis Care Res (Hoboken). 70(12): 1787–1794. 2018. PMID: 29609205. 10.1002/acr.23568 KQ1E7a, KQ3E7a29609205
16 King, CA, Eisenberg, D, . Online suicide risk screening and intervention with college students: a pilot randomized controlled trial. J Consult Clin Psychol. 83(3): 630–6. 2015. KQ1E2, KQ3E225688811
17 Kleinveld, JH, Timmermans, DR, . Does prenatal screening influence anxiety levels of pregnant women? A longitudinal randomised controlled trial. Prenat Diagn. 26(4): 354–61. 2006. PMID: 16511902. KQ1E1, KQ3E116511902
18 Law, Mary Kate, Furr, Michael R, . Does assessing suicidality frequently and repeatedly cause harm? A randomized control study. Psychol Assess. 27(4): 1171–1181. 2015. 10.1037/pas0000118 KQ1E8, KQ3E825894705
19 Mathias, CW, Michael Furr, R, . What’s the harm in asking about suicidal ideation?. Suicide Life Threat Behav. 42(3): 341–51. 2012. 10.1111/j.1943-278X.2012.0095.x KQ1E7a, KQ3E7a22548324
20 Meyers, MA, Groh, CJ, . Depression screening and treatment in uninsured urban patients. Journal of the American Board of Family Medicine: JABFM. 27(4): 520–9. 2014. PMID: 25002006. 10.3122/jabfm.2014.04.130254 KQ1E4, KQ3E425002006
21 Ono, Y, Sakai, A, . Effectiveness of a multimodal community intervention program to prevent suicide and suicide attempts: a quasi-experimental study. PLoS ONE [Electronic Resource]. 8(10): e74902. 2013. PMID: 24130673. 10.1371/journal.pone.0074902 KQ1E8, KQ3E824130673
22 Oyama, H, Sakashita, T. Community-based screening intervention for depression affects suicide rates among middle-aged Japanese adults. Psychol Med. 47(8): 1500–1509. 2017. KQ1E8, KQ3E828193313
23 Oyama, H, Sakashita, T. Differences in specific depressive symptoms among community-dwelling middle-aged Japanese adults before and after a universal screening intervention. Soc Psychiatry Psychiatr Epidemiol. 49(2): 251–8. 2014. KQ1E8, KQ3E823824236
24 Oyama, H, Sakashita, T. Effects of universal screening for depression among middle-aged adults in a community with a high suicide rate. J Nerv Ment Dis. 202(4): 280–6. 2014. KQ1E8, KQ3E824647214
25 Oyama, H, Sakashita, T, . A community-based survey and screening for depression in the elderly: the short-term effect on suicide risk in Japan. Crisis. 31(2): 100–8. 2010. PMID: 20418216. 10.1027/0227-5910/a000007 KQ1E8, KQ3E820418216
26 Oyama, H, Sakashita, T. Long-Term Effects of a Screening Intervention for Depression on Suicide Rates among Japanese Community-Dwelling Older Adults. American Journal of Geriatric Psychiatry. 24(4): 287–96. 2016. PMID: 26796924. 10.1016/j.jagp.2015.10.008 KQ1E8, KQ3E826796924
27 Picardi, A, Lega, I, . A randomised controlled trial of the effectiveness of a program for early detection and treatment of depression in primary care. J Affect Disord. 198: 96–101. 2016. KQ1E1, KQ3E127015158
28 Robinson, J, Pan, YuenH, . Does screening high school students for psychological distress, deliberate self-harm, or suicidal ideation cause distress--and is it acceptable? An Australian-based study. Crisis. 32: 254–263. 2011. KQ1E7a, KQ3E7a21940259
29 Rona, Rj, Burdett, H, . Post-deployment screening for mental disorders and tailored advice about help-seeking in the UK military: a cluster randomised controlled trial. Lancet. (no pagination). 2017. KQ1E7, KQ3E7
30 Silverstone, PH, Rittenbach, K, . Depression Outcomes in Adults Attending Family Practice Were Not Improved by Screening, Stepped-Care, or Online CBT during a 12-Week Study when Compared to Controls in a Randomized Trial. Frontiers in psychiatry Frontiers Research Foundation. 8: 32. 2017. PMID: 28373846. 10.3389/fpsyt.2017.00032 KQ1E11, KQ3E1128373846
31 Smith, Phillip, Poindexter, Erin, . The Effect of Participating in Suicide Research: Does Participating in a Research Protocol on Suicide and Psychiatric Symptoms Increase Suicide Ideation and Attempts?. Suicide Life Threat Behav. 40(6): 535–543. 2010. 10.1521/suli.2010.40.6.535 KQ1E8, KQ3E821198322
32 Staeheli, M, Aseltine, RH, . Using mHealth technologies to improve the identification of behavioral health problems in urban primary care settings. SAGE Open Medicine. 5: 2050312117712656. 2017. PMID: 28634539. 10.1177/2050312117712656 KQ1E5, KQ3E528634539
33 Swavely, D, O’Gurek, DT, . Primary Care Practice Redesign: Challenges in Improving Behavioral Health Care for a Vulnerable Patient Population. American Journal of Medical Quality. 35(2): 101–109. 2020. PMID: 31226884. 10.1177/1062860619855136 KQ1E3, KQ3E331226884
34 Thomas, HV, Lewis, G, . Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 54(508): 832–7. 2004. PMID: 15527609. KQ1E8, KQ3E815527609
35 Thombs, BD, Markham, S, . Does depression screening in primary care improve mental health outcomes?. BMJ. 374: n1661. 2021. 10.1136/bmj.n1661 KQ1E3, KQ3E334281908
36 van Dijk, DJ, Crone M R, van Empelen, . Favourable outcomes of a preventive screening and counselling programme for older people in underprivileged areas in the Netherlands: The PRIMUS project. Preventive Medicine Reports. 6: 258–264. 2017. PMID: 28409087. 10.1016/j.pmedr.2017.03.013 KQ1E5, KQ3E528409087
37 Yelin, Edward, Mathias, SusanD, . The impact on employment of an intervention to increase recognition of previously untreated anxiety among primary care physicians. Soc Sci Med. 42(7): 1069–1075. 1996. KQ1E4, KQ3E48730912
38 Zhao, Y, Munro-Kramer, ML, . Effects of antenatal depression screening and intervention among Chinese high-risk pregnant women with medically defined complications: a randomized controlled trial. Early Interv Psychiatry. 13(5): 1090–1098. 2018. KQ1E2a, KQ3E2a30160373
39 Zhao, Y, Munro-Kramer, ML, . Effects of antenatal depression screening and intervention among Chinese high-risk pregnant women with medically defined complications: A randomized controlled trial. Early Interv Psychiatry. 13(5): 1090–1098. 2019. KQ1E2a, KQ3E2a30160373

## KQ 2 Excluded Studies

1 Abas, MA, Phillips, C, . Culturally sensitive validation of screening questionnaires for depression in older African-Caribbean people living in south London. Br J Psychiatry. 173: 249–54. 1998. KQ2E119926102
2 Adouard, F, Glangeaud-Freudenthal, NM, . Validation of the Edinburgh postnatal depression scale (EPDS) in a sample of women with high-risk pregnancies in France. Arch Womens Ment Health. 8(2): 89–95. 2005. KQ2E315883653
3 Alghadir, A, Manzar, MD, . Psychometric Properties of the Generalized Anxiety Disorder Scale Among Saudi University Male Students. Neuropsychiatr Dis Treat. 16: 1427–1432. 2020. 10.2147/NDT.S246526 KQ2E332606696
4 Allen, AmandaN, Kilgus, StephenP, . Surveillance of internalizing behaviors: A reliability and validity generalization study of universal screening evidence. School Mental Health: A Multidisciplinary Research and Practice Journal. 11(2): 194–209. 2019. KQ2E7
5 Allen, MH, Abar, BW, . Screening for suicidal ideation and attempts among emergency department medical patients: instrument and results from the Psychiatric Emergency Research Collaboration. Suicide Life Threat Behav. 43(3): 313–23. 2013. KQ2E523413776
6 Alvarado, R, Jadresic, E, . First validation of a Spanish-translated version of the Edinburgh postnatal depression scale (EPDS) for use in pregnant women. A Chilean study. Arch Womens Ment Health. 18(4): 607–612. 2015. KQ2E325300676
7 Arthur, A, Jagger, C, . Using an annual over-75 health check to screen for depression: validation of the short Geriatric Depression Scale (GDS15) within general practice. Int J Geriatr Psychiatry. 14(6): 431–9. 1999. KQ2E1510398352
8 Bae, JN, Cho, MJ. Development of the Korean version of the Geriatric Depression Scale and its short form among elderly psychiatric patients. J Psychosom Res. 57(3): 297–305. 2004. KQ2E715507257
9 Ballester, L, Alayo, I, . Accuracy of online survey assessment of mental disorders and suicidal thoughts and behaviors in Spanish university students. Results of the WHO World Mental Health- International College Student initiative. PLoS ONE [Electronic Resource]. 14(9): e0221529. 2019. KQ2E1531487306
10 Balsamo, M, Cataldi, F, . Assessment of late-life depression via self-report measures: a review. Clin Interv Aging. 13: 2021–2044. 2018. KQ2E10a30410319
11 Bantjes, J, Kagee, A, . The Utility of the Hopkins Symptom Checklist as a Trans-Diagnostic Screening Instrument for Common Mental Disorders Among Persons Seeking HIV Testing. AIDS Behav. 24(2): 629–636. 2020. KQ2E2a31041626
12 Barzilay, S, Yaseen, ZS, . Determinants and Predictive Value of Clinician Assessment of Short-Term Suicide Risk. Suicide Life Threat Behav. 49(2): 614–626. 2019. KQ2E229665120
13 Batterham, PJ, Sunderland, M, . Psychometric Properties of 7- and 30-Day Versions of the PROMIS Emotional Distress Item Banks in an Australian Adult Sample. Assessment. 26(2): 249–259. 2019. KQ2E1128052687
14 Beck, CT, Gable, RK. Comparative analysis of the performance of the Postpartum Depression Screening Scale with two other depression instruments. Nurs Res. 50(4): 242–250. 2001. KQ2E311480533
15 Beck, CT, Gable, RK. Further validation of the Postpartum Depression Screening Scale. Nurs Res. 50(3): 155–164. 2001. KQ2E311393637
16 Belk, RA, Pilling, M, . The theoretical and practical determination of clinical cut-offs for the British Sign Language versions of PHQ-9 and GAD-7. BMC Psychiatry. 16(1): 372. 2016. KQ2E427809821
17 Benvenuti, P, Ferrara, M, . The Edinburgh Postnatal Depression Scale: validation for an Italian sample. J Affect Disord. 53(2): 137–141. 1999. KQ2E2a10360408
18 Bertens, AS, Moonen, JE, . Validity of the three apathy items of the Geriatric Depression Scale (GDS-3A) in measuring apathy in older persons. Int J Geriatr Psychiatry. 32(4): 421–428. 2017. KQ2E127060966
19 Bijl, Dick, van Marwijk, HarmWJ, . Test-Characteristics of the GDS-15 in Screening for Major Depression in Elderly Patients in General Practice. Clin Gerontol. 29(1): 1–9. 2006. KQ2E11
20 Blackwell, TerryL, McDermott, AmberN. Review of Patient health questionnaire-9 (PHQ-9). Rehabil Couns Bull. 57(4): 246–248. 2014. KQ2E3
21 Brouwers, EP, van Baar, AL, . Does the Edinburgh Postnatal Depression Scale measure anxiety? J Psychosom Res. 51(5): 659–63. 2001. KQ2E511728506
22 Brucker, K, Duggan, C, . Assessing Risk of Future Suicidality in Emergency Department Patients. Acad Emerg Med. 26(4): 376–383. 2019. KQ2E130375082
23 Bryan, CJ, Allen, MH, . Improving Suicide Risk Screening to Identify the Highest Risk Patients: Results From the PRImary Care Screening Methods (PRISM) Study. Ann Fam Med. 19(6): 492–498. 2021. PMID: 34750123. 10.1370/afm.2729 KQ2E634750123
24 Bryan, CraigJ, May, AlexisM, . Psychometric evaluation of the Suicide Cognitions Scale-Revised (SCS-R). Military Psychology. 34(3): 269–279. 2022. 10.1080/08995605.2021.1897498 KQ2E7
25 Bryan, CraigJ. A preliminary validation study of two ultra-brief measures of suicide risk: The Suicide and Perceived Burdensomeness Visual Analog Scales. Suicide Life Threat Behav. 49(2): 343–352. 2019. 10.1111/sltb.12447 KQ2E729512832
26 Bunevicius, A, Kusminskas, L, . Screening for antenatal depression with the Edinburgh Depression Scale. J Psychosom Obstet Gynaecol. 30(4): 238–243. 2009. KQ2E319845492
27 Bunevicius, A, Kusminskas, L, . Validation of the Lithuanian version of the Edinburgh Postnatal Depression Scale. Medicina (Kaunas). 45(7): 544–548. 2009. KQ2E319667749
28 Butnoriene, J, Steibliene, V, . Does presence of metabolic syndrome impact anxiety and depressive disorder screening results in middle aged and elderly individuals? A population based study. BMC Psychiatry. 18(1): 5. 2018. KQ2E9a29310620
29 Byrd-Bredbenner, C, Eck, K, . Psychometric Properties of the Generalized Anxiety Disorder-7 and Generalized Anxiety Disorder-Mini in United States University Students. Front Psychol. 11: 550533. 2020. 10.3389/fpsyg.2020.550533 KQ2E433071867
30 Byrne, GJ, Pachana, NA, . Psychometric properties and health correlates of the Geriatric Anxiety Inventory in Australian community-residing older women. Aging Ment Health. 14(3): 247–54. 2010. KQ2E520425643
31 Calear, AL, Batterham, PJ, . Development and Validation of Static and Adaptive Screeners to Assess Suicidal Thoughts and Behavior. Suicide Life Threat Behav. 50(1): 189–200. 2020. KQ2E531343755
32 Campos, RuiC, Holden, RonaldR. Portuguese version of the Suicidal Behaviors Questionnaire-Revised: Validation data and the establishment of a cut-score for screening purposes. European Journal of Psychological Assessment. 35(2): 190–195. 2019. KQ2E4
33 Cano-Vindel, A, Munoz-Navarro, R, . A computerized version of the Patient Health Questionnaire-4 as an ultra-brief screening tool to detect emotional disorders in primary care. J Affect Disord. 234: 247–255. 2018. KQ2E729549826
34 Carlucci, L, Balestrieri, M, . Psychometric properties and diagnostic accuracy of the short form of the geriatric anxiety scale (GAS-10). BMC Geriatr. 21(1): 401. 2021. 10.1186/s12877-021-02350-3 KQ2E434193082
35 Carpiniello, B, Pariante, CM, . Validation of the Edinburgh Postnatal Depression Scale in Italy. J Psychosom Obstet Gynaecol. 18(4): 280–285. 1997. KQ2E39443138
36 Chan, EC, Wallace, K, . Internal consistency and concurrent validity of self-report components of a new instrument for the assessment of suicidality, the Suicide Ideation and Behavior Assessment Tool (SIBAT). Psychiatry Res. 304: 114128. 2021. PMID: 34343876. 10.1016/j.psychres.2021.114128 KQ2E534343876
37 Chen, H, Bautista, D, . Screening for postnatal depression in Chinese-speaking women using the Hong Kong translated version of the Edinburgh Postnatal Depression Scale. Asia Pac Psychiatry. 5(2): E64–E72. 2013. KQ2E323857814
38 Chorwe-Sungani, G, Chipps, J. A systematic review of screening instruments for depression for use in antenatal services in low resource settings. BMC Psychiatry. 17(1): 112. 2017. KQ2E2a28340609
39 Christensen, H, Batterham, PJ, . A population study comparing screening performance of prototypes for depression and anxiety with standard scales. BMC Med Res Methodol. 11: 154. 2011. KQ2E1122103584
40 Chu, J, Hoeflein, B, . A Shortened Screener Version of the Cultural Assessment of Risk for Suicide. Archives of Suicide Research. 22(4): 679–687. 2017. KQ2E429281563
41 Chung, Yeunjoo, Jeglic, ElizabethL. Detecting suicide risk among college students: A test of the predictive validity of the modified emotional Stroop task. Suicide Life Threat Behav. 47(4): 398–409. 2017. KQ2E9b27658610
42 Chung, Yeunjoo. Use of the modified emotional stroop task to detect suicide risk in college students. Dissertation Abstracts International: Section B: The Sciences and Engineering. 76: No Pagination Specified. 2016. KQ2E9b
43 Clarke, PJ. Validation of two postpartum depression screening scales with a sample of First Nations and Metis women. Can J Nurs Res. 40: 113–125. 2008. KQ2E318459275
44 Cosco, TD, Lachance, CC, . Latent structure of the Centre for Epidemiologic Studies Depression Scale (CES-D) in older adult populations: a systematic review. Aging Ment Health. 24(5): 700–704. 2020. KQ2E530661386
45 Costa, MV, Diniz, MF, . Accuracy of three depression screening scales to diagnose major depressive episodes in older adults without neurocognitive disorders. Revista Brasileira de Psiquiatria. 38(2): 154–6. 2016. KQ2E327304758
46 Cox, JL, Chapman, G, . Validation of the Edinburgh Postnatal Depression Scale (EPDS) in non-postnatal women. J Affect Disord. 39(3): 185–189. 1996. KQ2E38856422
47 Cox, JL, Murray, D, . A controlled study of the onset, duration and prevalence of postnatal depression. Br J Psychiatry. 163: 27–31. 1993. KQ2E38353695
48 Daly-Cano, Meada. Refining the edinburgh postpartum depression screening: Is there a distinct role for anxiety?. Dissertation Abstracts International: Section B: The Sciences and Engineering. 80(8-B(E)): No Pagination Specified. 2019. KQ2E13
49 D’Ath, Penny, Katona, Philippa, . Screening, Detection and Management of Depression in Elderly Primary Care Attenders. I: The Acceptability and Performance of the 15 Item Geriatric Depression Scale (GDS15) and the Development of Short Versions. Fam Pract. 11: 260–6. 1994. KQ2E117843514
50 de Craen, AJ, Heeren, TJ, . Accuracy of the 15-item geriatric depression scale (GDS-15) in a community sample of the oldest old. Int J Geriatr Psychiatry. 18(1): 63–6. 2003. KQ2E7a12497557
51 de Graaff, AM, Cuijpers, P, . A systematic review and meta-analysis of diagnostic test accuracy studies of self-report screening instruments for common mental disorders in Arabic-speaking adults. Global Mental Health. 8: e43. 2021. PMID: 34966543. 10.1017/gmh.2021.39 KQ2E2a34966543
52 Delgado-Gomez, D, Baca-Garcia, E, . Computerized Adaptive Test vs. decision trees: Development of a support decision system to identify suicidal behavior. J Affect Disord. 206: 204–209. 2016. KQ2E327475891
53 Dias, Fldc, Teixeira, AL, . Accuracy of the 15-item Geriatric Depression Scale (GDS-15) in a community-dwelling oldest-old sample: the Pieta Study. Trends in Psychiatry & Psychotherapy. 39(4): 276–279. 2017. KQ2E2a29267511
54 Dokuzlar, O, Soysal, P, . The evaluation and design of a short depression screening tool in Turkish older adults. Int Psychogeriatr. 30(10): 1541–1548. 2018. KQ2E1129560848
55 Donker, T, van Straten, A, . Quick and easy self-rating of Generalized Anxiety Disorder: validity of the Dutch web-based GAD-7, GAD-2 and GAD-SI. Psychiatry Res. 188(1): 58–64. 2011. KQ2E721339006
56 Durmaz, B, Soysal, P, . Validity and reliability of geriatric depression scale-15 (short form) in Turkish older adults. Northern Clinics of Istanbul. 5(3): 216–220. 2018. KQ2E1130688929
57 Eberhard-Gran, M, Slinning, K, . Screening for postnatal depression--a summary of current knowledge. Tidsskr Nor Laegeforen. 134(3): 297–301. 2014. KQ2E324518477
58 El-Den, S, Chen, TF, . The psychometric properties of depression screening tools in primary healthcare settings: A systematic review. J Affect Disord. 225: 503–522. 2018. KQ2E10a28866295
59 Elliott, SA, Leverton, TJ, . Promoting mental health after childbirth: a controlled trial of primary prevention of postnatal depression. Br J Clin Psychol. 39 (Pt 3): 223–241. 2000. KQ2E311033746
60 Fairbrother, N, Corbyn, B, . Screening for perinatal anxiety disorders: Room to grow. J Affect Disord. 250: 363–370. 2019. KQ2E1530877859
61 Farabaugh, Amy, Nyer, Maren, . Screening for suicide risk in the college population. Journal of Rational-Emotive & Cognitive-Behavior Therapy. 33(1): 78–94. 2015. KQ2E4
62 Felice, E, Saliba, J, . Validation of the Maltese version of the Edinburgh Postnatal Depression Scale. Arch Womens Ment Health. 9: 75–80. 2006. KQ2E316172837
63 Ferrari, S, Signorelli, MS, . Never too late to be anxious: validation of the Geriatric Anxiety Inventory, Italian version. Clin Ter. 168(2): e120–e127. 2017. KQ2E228383623
64 García-Campayo, J, Zamorano, E, . Cultural adaptation into Spanish of the generalized anxiety disorder-7 (GAD-7) scale as a screening tool. Health Qual Life Outcomes. 8: 8. 2010. KQ2E320089179
65 García-Campayo, J, Zamorano, E, . The assessment of generalized anxiety disorder: psychometric validation of the Spanish version of the self-administered GAD-2 scale in daily medical practice. Health Qual Life Outcomes. 10: 114. 2012. KQ2E322992432
66 Garcia-Esteve, L, Ascaso, C, . Validation of the Edinburgh Postnatal Depression Scale (EPDS) in Spanish mothers. J Affect Disord. 75(1): 71–76. 2003. KQ2E312781353
67 Gatti, A, Gottschling, J, . An investigation of the psychometric properties of the Geriatric Anxiety Scale (GAS) in an Italian sample of community-dwelling older adults. Aging Ment Health. 22(9): 1170–1178. 2018. KQ2E428675312
68 Gauvin, G, Bardon, C, . Psychometric validation of the French version of the Suicidal Ideation Attributes Scale (SIDAS-FR). Death Stud. 46(10): 2404–2412. 2022. 10.1080/07481187.2021.1951395 KQ2E434282700
69 Gjerdingen, D, Crow, S, . Postpartum depression screening at well-child visits: validity of a 2-question screen and the PHQ-9. Ann Fam Med. 7: 63–70. 2009. KQ2E319139451
70 Gjerdingen, D, McGovern, P, . Problems with a diagnostic depression interview in a postpartum depression trial. J Am Board Fam Med. 24: 187–193. 2011. KQ2E321383219
71 Gokcekuyu, BM, Akin, S, . Validation of the five-item version of the Geriatric Depression Scale (GDS-5) in a Turkish elderly population. Psychogeriatrics: The Official Journal of the Japanese Psychogeriatric Society. 22(3): 382–390. 2022. PMID: 35332628. 10.1111/psyg.12827 KQ2E435332628
72 Gottfried, E, Bodell, L, . The clinical utility of the MMPI-2-RF Suicidal/Death Ideation Scale. Psychol Assess. 26(4): 1205–11. 2014. KQ2E725068910
73 Graham, AK, Minc, A, . Validation of the Computerized Adaptive Test for Mental Health in Primary Care. Ann Fam Med. 17(1): 23–30. 2019. KQ2E530670391
74 Grossberg, GT, Beck, D, . Rapid Depression Assessment in Geriatric Patients. Clin Geriatr Med. 33(3): 383–391. 2017. KQ2E328689570
75 Guedeney, N, Fermanian, J. Validation study of the French version of the Edinburgh Postnatal Depression Scale (EPDS): new results about use and psychometric properties. Eur Psychiatry. 13(2): 83–89. 1998. KQ2E319698604
76 Guerin, JM, Copersino, ML, . Clinical utility of the 15-item geriatric depression scale (GDS-15) for use with young and middle-aged adults. J Affect Disord. 241: 59–62. 2018. KQ2E730096593
77 Harris, B, Huckle, P, . The use of rating scales to identify post-natal depression. Br J Psychiatry. 154: 813–817. 1989. KQ2E32597888
78 Heck, JL. Screening for Postpartum Depression in American Indian/Alaska Native Women: A Comparison of Two Instruments. Am Indian Alsk Native Ment Health Res. 25(2): 74–102. 2018. KQ2E2a29889949
79 Heisel, MJ, Flett, GL. Screening for suicide risk among older adults: assessing preliminary psychometric properties of the Brief Geriatric Suicide Ideation Scale (BGSIS) and the GSIS-Screen. Aging Ment Health. 26(2): 392–406. 2022. 10.1080/13607863.2020.1857690 KQ2E433327729
80 Henderson, LeighC, Antony, MartinM, . Psychometric properties of the Generalized Anxiety Disorder Inventory in a Canadian sample. J Psychopharmacol. 28(5): 440–448. 2014. KQ2E124621984
81 Herizchi, S, Barzegar, H, . Reliability and validity of Azeri Turkish version of geriatric depression scale. Health Promotion Perspectives. 10(1): 74–79. 2020. KQ2E2a32104660
82 Herr, NR, Williams, JW, . Does this patient have generalized anxiety or panic disorder? The Rational Clinical Examination systematic review. JAMA. 312(1): 78–84. 2014. KQ2E325058220
83 Hirschtritt, ME, Kroenke, K. Screening for Depression. JAMA. 318(8): 745–746. 2017. KQ2E328829850
84 Holi, MM, Pelkonen, M, . Detecting suicidality among adolescent outpatients: evaluation of trained clinicians’ suicidality assessment against a structured diagnostic assessment made by trained raters. BMC Psychiatry. 8: 97. 2008. KQ2E719116040
85 Howard, LM, Ryan, EG, . Accuracy of the Whooley questions and the Edinburgh Postnatal Depression Scale in identifying depression and other mental disorders in early pregnancy. Br J Psychiatry. 212(1): 50–56. 2018. KQ2E329433610
86 Hoyt, T, Repke, D, . Development of a Leader Tool for Assessing and Mitigating Suicide Risk Factors. Mil Med. 185(Suppl 1): 334–341. 2020. KQ2E7a
87 Ibrahim, N, Che Din, N, . Psychometric Properties and the Cut-Off Point of the English Version of the Yatt Suicide Attitude Scale. Inquiry. 59: 469580221096276. 2022. PMID: 35485917. 10.1177/00469580221096276 KQ2E435485917
88 Jin, H, Wu, S. Text Messaging as a Screening Tool for Depression and Related Conditions in Underserved, Predominantly Minority Safety Net Primary Care Patients: Validity Study. J Med Internet Res. 22(3): e17282. 2020. KQ2E732213473
89 Johansson, S, Lovheim, H, . A clinically feasible short version of the 15-item geriatric depression scale extracted using item response theory in a sample of adults aged 85 years and older. Aging Ment Health. 26(2): 431–437. 2022. 10.1080/13607863.2021.1881759 KQ2E3b33554652
90 Karam, GE, Khandakji, MN, . Validation of geriatric depression and anxiety rating scales into Arabic. Alzheimer’s & Dementia : Diagnosis, Assessment & Disease Monitoring. 10: 791–795. 2018. KQ2E2a
91 Khoury, R, Chakkamparambil, B, . Diagnostic Accuracy of the SLU AMSAD Scale for Depression in Older Adults Without Dementia. J Am Med Dir Assoc. 21(5): 665–668. 2020. KQ2E231704225
92 Kiely, KM, Butterworth, P. Validation of four measures of mental health against depression and generalized anxiety in a community based sample. Psychiatry Res. 225(3): 291–8. 2015. KQ2E1125578983
93 Kim, S, Lee, HK, . Assessment of suicidal risk using Minnesota multiphasic personality inventory-2 restructured form. BMC Psychiatry. 20(1): 81. 2020. PMID: 32102658. 10.1186/s12888-020-02495-2 KQ2E332102658
94 Kim, S, Lee, HK, . Which PHQ-9 Items Can Effectively Screen for Suicide? Machine Learning Approaches. International Journal of Environmental Research & Public Health [Electronic Resource]. 18(7): 24. 2021. 10.3390/ijerph18073339 KQ2E11
95 Kim, S, Lee, K. Screening for Depression in Mobile Devices Using Patient Health Questionnaire-9 (PHQ-9) Data: A Diagnostic Meta-Analysis via Machine Learning Methods. Neuropsychiatr Dis Treat. 17: 3415–3430. 2021. PMID: 34848962. 10.2147/NDT.S339412 KQ2E434848962
96 Kotz, J, Marriott, R, . The EPDS and Australian Indigenous women: A systematic review of the literature. Women & Birth: Journal of the Australian College of Midwives. 03: 03. 2020. KQ2E10a
97 Kozinszky, Z, Dudas, RB. Validation studies of the Edinburgh Postnatal Depression Scale for the antenatal period. J Affect Disord. 176: 95–105. 2015. KQ2E10a25704562
98 Kroenke, K, Wu, J, . Patient Health Questionnaire Anxiety and Depression Scale: Initial Validation in Three Clinical Trials. Psychosom Med. 78(6): 716–27. 2016. KQ2E727187854
99 Lee, DT, Yip, AS, . Screening for postnatal depression: are specific instruments mandatory? J Affect Disord. 63(1-3): 233–238. 2001. KQ2E311246101
100 Lee, HJ, Lee, DH, . Development and Validation of the Self-Rating Suicide Risk Screening Questionnaire. Omega - Journal of Death & Dying. 302228221119029. 2022. PMID: 3596877335968773. 10.1177/00302228221119029 KQ2E3
101 Lee, Seong Chan, Kim, Won Hyung, . The Use of the Korean Version of Short Form Geriatric Depression Scale (SGDS-K) in the Community Dwelling Elderly in Korea. Journal of Korean Geriatric Psychiatry. 17(1): 37–43. 2013. KQ2E13
102 Lee, SH, Tsai, YF, . Development and psychometric testing of the triggers of Suicidal Ideation Inventory for assessing older outpatients in primary care settings. Int J Geriatr Psychiatry. 32(10): 1114–1121. 2017. KQ2E3b27572427
103 Leverton, TJ, Elliott, SA. Is the EPDS a magic wand? 1. A comparison of the Edinburgh Postnatal Depression Scale and health visitor report as predictors of diagnosis on the Present State Examination. J Reprod Infant Psychol. 18(4): 279–296. 2000. KQ2E3
104 Levis, B, Benedetti, A, . Accuracy of Patient Health Questionnaire-9 (PHQ-9) for screening to detect major depression: individual participant data meta-analysis. BMJ. 365: l1476. 2019. KQ2E10a30967483
105 Levis, B, Benedetti, A, . Patient Health Questionnaire-9 scores do not accurately estimate depression prevalence: individual participant data meta-analysis. J Clin Epidemiol. 122: 115–128.e1. 2020. KQ2E532105798
106 Levis, B, Benedetti, A, . Selective Cutoff Reporting in Studies of Diagnostic Test Accuracy: A Comparison of Conventional and Individual-Patient-Data Meta-Analyses of the Patient Health Questionnaire-9 Depression Screening Tool. Am J Epidemiol. 185(10): 954–964. 2017. KQ2E10a28419203
107 Levis, B, McMillan, D, . Comparison of major depression diagnostic classification probability using the SCID, CIDI, and MINI diagnostic interviews among women in pregnancy or postpartum: An individual participant data meta-analysis. Int J Methods Psychiatr Res. 28(4): e1803. 2019. KQ2E1
108 Limon, FJ, Lamson, AL, . Screening for Depression in Latino Immigrants: A Systematic Review of Depression Screening Instruments Translated into Spanish. Journal of Immigrant & Minority Health. 18(4): 787–798. 2016. KQ2E2a26660481
109 Limon, FranciscoJ. Screening Latino farmworkers for depression in primary care. Dissertation Abstracts International: Section B: The Sciences and Engineering. 78(2-B(E)): No Pagination Specified. 2017. KQ2E3
110 Loyal, D, Sutter, AL, . Screening Beyond Postpartum Depression: Occluded Anxiety Component in the EPDS (EPDS-3A) in French Mothers. Matern Child Health J. 24(3): 369–377. 2020. 10.1007/s10995-020-02885-8 KQ2E431974900
111 Lozupone, M, D’Urso, F, . The diagnostic accuracy of late-life depression is influenced by subjective memory complaints and educational level in an older population in Southern Italy. Psychiatry Res. 308: 114346. 2022. PMID: 34953202. 10.1016/j.psychres.2021.114346 KQ2E1134953202
112 Ludman, EJ, Simon, GE, . Reevaluating Sensitivity of Self-Reported Suicidal Ideation. J Clin Psychiatry. 79(3). 2018. KQ2E1
113 Lyness, JM, Noel, TK, . Screening for depression in elderly primary care patients. A comparison of the Center for Epidemiologic Studies-Depression Scale and the Geriatric Depression Scale. Arch Intern Med. 157(4): 449–54. 1997. KQ2E159046897
114 Lyoo, YC, Ju, S, . The patient health questionnaire-15 and its abbreviated version as screening tools for depression in Korean college and graduate students. Compr Psychiatry. 55(3): 743–8. 2014. KQ2E324342054
115 Manea, L, Gilbody, S, . A diagnostic meta-analysis of the Patient Health Questionnaire-9 (PHQ-9) algorithm scoring method as a screen for depression. Gen Hosp Psychiatry. 37(1): 67–75. 2015. KQ2E10a25439733
116 Manea, L, Gilbody, S, . Identifying depression with the PHQ-2: A diagnostic meta-analysis. J Affect Disord. 203: 382–395. 2016. KQ2E10a27371907
117 Mann, R, Adamson, J, . Diagnostic accuracy of case-finding questions to identify perinatal depression. CMAJ. 184: E424–E430. 2012. KQ2E9a22451686
118 Martinez-Borba, V, Suso-Ribera, C, . The Use of Information and Communication Technologies in Perinatal Depression Screening: A Systematic Review. Cyberpsychol Behav Soc Netw. 30: 30. 2018. KQ2E1
119 McBride, HillaryL, Wiens, RachelM, . The Edinburgh Postnatal Depression Scale (EPDS): A review of the reported validity evidence. Validity and validation in social, behavioral, and health sciences. 157–174. 2014. KQ2E3
120 McCusker, PJ. The Clinical Utility of PHQ-9 Item 9 for Suicide Prediction. Psychiatr Serv. 67(9): 1042. 2016. KQ2E3
121 Meuldijk, D, Giltay, EJ, . A Validation Study of the Web Screening Questionnaire (WSQ) Compared With the Mini-International Neuropsychiatric Interview-Plus (MINI-Plus). JMIR Mental Health. 4(3): e35. 2017. KQ2E9a28851674
122 Miller, Peter, Newby, David, . The performance and accuracy of depression screening tools capable of self-administration in primary care: A systematic review and meta-analysis. The European Journal of Psychiatry. 35(1): 1–18. 2021. 10.1016/j.ejpsy.2020.10.002 KQ2E10a
123 Mitchell, AJ, Yadegarfar, M, . Case finding and screening clinical utility of the Patient Health Questionnaire (PHQ-9 and PHQ-2) for depression in primary care: a diagnostic meta-analysis of 40 studies. B J Psych Open. 2(2): 127–138. 2016. KQ2E10a
124 Moore, MT, Anderson, NL, . Using the GAD-Q-IV to identify generalized anxiety disorder in psychiatric treatment seeking and primary care medical samples. J Anxiety Disord. 28(1): 25–30. 2014. KQ2E1524334213
125 Moriarty, AS, Gilbody, S, . Screening and case finding for major depressive disorder using the Patient Health Questionnaire (PHQ-9): a meta-analysis. Gen Hosp Psychiatry. 37(6): 567–76. 2015. KQ2E10a26195347
126 Morrell CJ, Slade P, Warner R, Paley G, . Clinical effectiveness of health visitor training in psychologically informed approaches for depression in postnatal women: pragmatic cluster randomised trial in primary care. BMJ. 338: a3045. 2009. KQ2E319147636
127 Morrell, CJ, Warner, R, . Psychological interventions for postnatal depression: cluster randomised trial and economic evaluation. The PONDER trial. Health Technol Assess. 13(30): 1–176. 2009. KQ2E3
128 Mullinax, S, Chalmers, CE, . Suicide screening scales may not adequately predict disposition of suicidal patients from the emergency department. Am J Emerg Med. 36(10): 1779–1783. 2018. KQ2E729530359
129 Mulvaney-Day, N, Marshall, T, . Screening for Behavioral Health Conditions in Primary Care Settings: A Systematic Review of the Literature. J Gen Intern Med. 33(3): 335–346. 2018. KQ2E10a28948432
130 Munoz-Navarro, R, Cano-Vindel, A, . Screening for generalized anxiety disorder in Spanish primary care centers with the GAD-7. Psychiatry Res. 256: 312–317. 2017. KQ2E728666201
131 Munoz-Navarro, R, Cano-Vindel, A, . The PHQ-PD as a Screening Tool for Panic Disorder in the Primary Care Setting in Spain. PLoS ONE [Electronic Resource]. 11(8): e0161145. 2016. KQ2E727525977
132 Murray, D, Cox, JL. Screening for depression during pregnancy with the Edinburgh Depression Scale (EPDS). J Reprod Infant Psychol. 8: 99–107. 1990. KQ2E3
133 Na, PJ, Yaramala, SR, . The PHQ-9 Item 9 based screening for suicide risk: a validation study of the Patient Health Questionnaire (PHQ)-9 Item 9 with the Columbia Suicide Severity Rating Scale (C-SSRS). J Affect Disord. 232: 34–40. 2018. KQ2E429477096
134 Nabbe, P, Le Reste, JY, . Which DSM validated tools for diagnosing depression are usable in primary care research? A systematic literature review. European Psychiatry: the Journal of the Association of European Psychiatrists. 39: 99–105. 2017. KQ2E10a27992813
135 Neal, RM, Baldwin, RC. Screening for anxiety and depression in elderly medical outpatients. Age Ageing. 23(6): 461–4. 1994. KQ2E119231938
136 Nelson, HD, Cantor, A, . Screening for Anxiety in Adolescent and Adult Women: A Systematic Review for the Women’s Preventive Services Initiative. Ann Intern Med. 09: 09. 2020. KQ2E3
137 O’Connor, E, Gaynes, BN, . Screening for and treatment of suicide risk relevant to primary care: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 158(10): 741–54. 2013. KQ2E323609101
138 O’Connor, E, Rossom, RC, . Screening for Depression in Adults: An Updated Systematic Evidence Review for the U.S. Preventive Services Task Force. Agency for Healthcare Research and Quality (US). 2016. KQ2E10a
139 O’Connor, L, Larkin, C, . Development and pilot study of simple suicide risk rulers for use in the emergency department. Gen Hosp Psychiatry. 63: 97–102. 2020. KQ2E430121140
140 Owora, AH, Carabin, H, . Diagnostic performance of major depression disorder case-finding instruments used among mothers of young children in the United States: A systematic review. J Affect Disord. 201: 185–93. 2016. KQ2E10a27240311
141 Owora, AH, Carabin, H, . Summary diagnostic validity of commonly used maternal major depression disorder case finding instruments in the United States: A meta-analysis. J Affect Disord. 205: 335–343. 2016. KQ2E10a27566453
142 Pachana, NA, Byrne, GJ, . Development and validation of the Geriatric Anxiety Inventory. Int Psychogeriatr. 19(1): 103–14. 2007. KQ2E716805925
143 Pal, Sutanaya, Oswal, RajatM, . Recognition of major depressive disorder and its correlates among adult male patients in primary care. Archives of Psychiatry and Psychotherapy. 20(3): 55–62. 2018. KQ2E2a
144 Park, SH, Kim, JI. Predictive validity of the Edinburgh postnatal depression scale and other tools for screening depression in pregnant and postpartum women: a systematic review and meta-analysis. Arch Gynecol Obstet. 13: 13. 2022. PMID: 35416478. 10.1007/s00404-022-06525-0 KQ2E10a35416478
145 Pettersson, A, Bostrom, KB, . Which instruments to support diagnosis of depression have sufficient accuracy? A systematic review. Nord J Psychiatry. 69(7): 497–508. 2015. KQ2E10a25736983
146 Pierson, ME, Prenoveau, JM, . Psychometric properties of the Generalized Anxiety Disorder Questionnaire - IV (GAD-Q-IV) in postpartum mothers. Psychol Assess. 29(11): 1391–1399. 2017. KQ2E1128221055
147 Podlogar, MC, Gutierrez, PM, . Optimizing the Beck Scale for Suicide Ideation: An Item Response Theory Approach Among U.S. Military Personnel. Assessment. 10731911221092420. 2022. PMID: 3557507035575070. 10.1177/10731911221092420 KQ2E7
148 Pranckeviciene, A, Saudargiene, A, . Validation of the patient health questionnaire-9 and the generalized anxiety disorder-7 in Lithuanian student sample. PLoS ONE [Electronic Resource]. 17(1): e0263027. 2022. PMID: 35085349. 10.1371/journal.pone.0263027 KQ2E635085349
149 Ribeiro, O, Paul, C, . Portuguese version of the Geriatric Anxiety Inventory: transcultural adaptation and psychometric validation. Aging Ment Health. 15(6): 742–8. 2011. KQ2E321656405
150 Rice, DB, Kloda, LA, . Are MEDLINE searches sufficient for systematic reviews and meta-analyses of the diagnostic accuracy of depression screening tools? A review of meta-analyses. J Psychosom Res. 87: 7–13. 2016. KQ2E527411746
151 Rice, DB, Shrier, I, . Methodological quality of meta-analyses of the diagnostic accuracy of depression screening tools. J Psychosom Res. 84: 84–92. 2016. KQ2E327095164
152 Rice, SM, Ogrodniczuk, JS, . Validity of the Male Depression Risk Scale in a representative Canadian sample: sensitivity and specificity in identifying men with recent suicide attempt. J Ment Health. 28(2): 132–140. 2019. KQ2E429271280
153 Rogers, R, Hartigan, SE, . Identifying Mental Disorders in Primary Care: Diagnostic Accuracy of the Connected Mind Fast Check (CMFC) Electronic Screen. J Clin Psychol Med Settings. 28(4): 882–896. 2021. PMID: 34609692. 10.1007/s10880-021-09820-1 KQ2E1134609692
154 Rost K, Nutting P, Smith J, Werner J, . Improving depression outcomes in community primary care practice: a randomized trial of the quEST intervention. Quality Enhancement by Strategic Teaming. J Gen Intern Med. 16(3): 143–149. 2001. KQ2E311318908
155 Rost K, Nutting P, Smith JL, Elliott CE, . Managing depression as a chronic disease: a randomised trial of ongoing treatment in primary care. BMJ. 325(7370): 934. 2002. KQ2E312399343
156 Rost K, Nutting PA, Smith J, Werner JJ. Designing and implementing a primary care intervention trial to improve the quality and outcome of care for major depression. Gen Hosp Psychiatry. 22(2): 66–77. 2000. KQ2E310822094
157 Rucker, G, Steinhauser, S, . RE: “Selective Cutoff Reporting in Studies of Diagnostic Test Accuracy: A Comparison of Conventional and Individual-Patient-Data Meta-Analyses of the Patient Health Questionnaire - 9 Depression Screening Tool”. Am J Epidemiol. 186(7): 894. 2017. KQ2E328978197
158 Rudd, MD, Bryan, CJ. The Brief Suicide Cognitions Scale: Development and Clinical Application. Frontiers in psychiatry Frontiers Research Foundation. 12: 737393. 2021. PMID: 34594254. 10.3389/fpsyt.2021.737393 KQ2E434594254
159 Rutter, LA, Brown, TA. Psychometric Properties of the Generalized Anxiety Disorder Scale-7 (GAD-7) in Outpatients with Anxiety and Mood Disorders. J Psychopathol Behav Assess. 39(1): 140–146. 2017. KQ2E228260835
160 Sahni, A, Agius, M. The Use of the PHQ9 self-rating scale to assess depression within Primary Care. Psychiatr Danub. 29(Suppl 3): 615–618. 2017. KQ2E328953840
161 Sambrook Smith, M, Cairns, L, . Validated tools to identify common mental disorders in the perinatal period: A systematic review of systematic reviews. J Affect Disord. 298(Part A): 634–643. 2022. 10.1016/j.jad.2021.11.011 KQ2E334763033
162 Sedgwick, P, Joekes, K. Evaluating the performance of a screening test for depression in primary care. BMJ. 350: h1801. 2015. KQ2E325858900
163 Segal, DL, June, A, . Development and initial validation of a self-report assessment tool for anxiety among older adults: the Geriatric Anxiety Scale. J Anxiety Disord. 24(7): 709–14. 2010. KQ2E420558032
164 Seo, JW, Kwon, SM. Preliminary Validation of a Korean Version of the Acquired Capability for Suicide Scale-Fearlessness About Death. Suicide Life Threat Behav. 48(3): 305–314. 2018. KQ2E428591462
165 Serrani Azcurra, D. Psychometric validation of the Columbia-Suicide Severity rating scale in Spanish-speaking adolescents. Colomb Med. 48(4): 174–182. 2017. KQ2E4
166 Shrestha, S, Ramos, K, . Psychometric properties of worry and anxiety measures in a sample of african american and caucasian older adults. Aging Ment Health. 24(2): 315–321. 2020. KQ2E730810345
167 Siau, CS, Wee, LH, . Cross-Cultural Adaptation and Validation of the Attitudes Toward Suicide Questionnaire Among Healthcare personnel in Malaysia. Inquiry. 54: 46958017707295. 2017. KQ2E1
168 Sidik, Sherina Mohd, Arroll, Bruce, . Validation of the GAD-7 (Malay version) among women attending a primary care clinic in Malaysia. J Prim Health Care. 4(1): 5–11, A1. 2012. KQ2E1122377544
169 Simon, GE, Rutter, CM, . Does response on the PHQ-9 Depression Questionnaire predict subsequent suicide attempt or suicide death? Psychiatr Serv. 64(12): 1195–202. 2013. KQ2E124036589
170 Simpson, W, Glazer, M, . Comparative efficacy of the generalized anxiety disorder 7-item scale and the Edinburgh Postnatal Depression Scale as screening tools for generalized anxiety disorder in pregnancy and the postpartum period. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 59(8): 434–40. 2014. KQ2E725161068
171 Smith, EK, Gopalan, P, . Postpartum Depression Screening: A Review for Psychiatrists. Harv Rev Psychiatry. 24(3): 173–87. 2016. KQ2E10a27148910
172 Smith, MV, Gotman, N, . Do the PHQ-8 and the PHQ-2 accurately screen for depressive disorders in a sample of pregnant women? Gen Hosp. Psychiatry. 32: 544–548. 2010. KQ2E3
173 Sousa, TV, Viveiros, V, . Reliability and validity of the Portuguese version of the Generalized Anxiety Disorder (GAD-7) scale. Health Qual Life Outcomes. 13: 50. 2015. KQ2E525908249
174 Spangenberg, L, Glaesmer, H, . Psychometric properties of the German version of the suicide cognitions scale in two clinical samples. Psychiatry Res. 274: 254–262. 2019. KQ2E730822742
175 Staples, LG, Dear, BF, . Psychometric properties and clinical utility of brief measures of depression, anxiety, and general distress: The PHQ-2, GAD-2, and K-6. Gen Hosp Psychiatry. 56: 13–18. 2019. KQ2E730508772
176 Sugishita, K, Sugishita, M, . A Validity and Reliability Study of the Japanese Version of the Geriatric Depression Scale 15 (GDS-15-J). Clin Gerontol. 40(4): 233–240. 2017. KQ2E228452641
177 Swalm, D, Brooks, J, . Using the Edinburgh postnatal depression scale to screen for perinatal anxiety. Arch Womens Ment Health. 13(6): 515–22. 2010. KQ2E420574749
178 Tandon, SD, Cluxton-Keller, F, . A comparison of three screening tools to identify perinatal depression among low-income African American women. J Affect Disord. 136(1-2): 155–162. 2012. KQ2E321864914
179 Teng, HW, Hsu, CS, . Screening postpartum depression with the Taiwanese version of the Edinburgh Postnatal Depression scale. Compr Psychiatry. 46(4): 261–265. 2005. KQ2E316175756
180 Thombs, BD, Rice, DB. Sample sizes and precision of estimates of sensitivity and specificity from primary studies on the diagnostic accuracy of depression screening tools: a survey of recently published studies. Int J Methods Psychiatr Res. 25(2): 145–52. 2016. KQ2E127060912
181 Thompson, EA, Eggert, LL. Using the suicide risk screen to identify suicidal adolescents among potential high school dropouts. J Am Acad Child Adolesc Psychiatry. 38: 1506–1514. 1999. KQ2E710596250
182 Tomasula, Jessica, L. Identifying the missing piece of suicide prevention: Formative risk assessment. Dissertation Abstracts International: Section B: The Sciences and Engineering. 76(2-B(E)): No Pagination Specified. 2015. KQ2E4
183 Toreki, A, Ando, B, . The Edinburgh Postnatal Depression Scale: translation and antepartum validation for a Hungarian sample. Midwifery. 29(4): 308–315. 2013. KQ2E322417756
184 Toreki, A, Ando, B, . Validation of the Edinburgh Postnatal Depression Scale as a screening tool for postpartum depression in a clinical sample in Hungary. Midwifery. 30(8): 911–918. 2014. KQ2E324742635
185 Trent, LindsayR. Diagnostic accuracy of self-report instruments in a non-clinical sample: A Receiver and Operating Characteristics (roc) analysis. Dissertation Abstracts International: Section B: The Sciences and Engineering. 76(2-B(E)): No Pagination Specified. 2015. KQ2E9a
186 Ukatu, N, Clare, CA, . Postpartum Depression Screening Tools: A Review. Psychosomatics. 59(3): 211–219. 2018. KQ2E10a29396166
187 van Ballegooijen, W, Riper, H, . Validation of online psychometric instruments for common mental health disorders: a systematic review. BMC Psychiatry. 16: 45. 2016. KQ2E526915661
188 van der Weele GM, de Waal MW, van den Hout WB, de Craen AJ, . Effects of a stepped-care intervention programme among older subjects who screened positive for depressive symptoms in general practice: the PROMODE randomised controlled trial. Age Ageing. 41(4): 482–488. 2012. KQ2E322427507
189 van der Weele GM, de Waal MW, van den Hout WB, van der Mast RC, . Yield and costs of direct and stepped screening for depressive symptoms in subjects aged 75 years and over in general practice. Int J Geriatr Psychiatry. 26: 229–238. 2011. KQ2E320665554
190 van der Zee-van den Berg, AI, Boere-Boonekamp, MM, . The Edinburgh Postpartum Depression Scale: Stable structure but subscale of limited value to detect anxiety. PLoS ONE [Electronic Resource]. 14(9): e0221894. 2019. KQ2E531498818
191 van Spijker, BA, Batterham, PJ, . The suicidal ideation attributes scale (SIDAS): Community-based validation study of a new scale for the measurement of suicidal ideation. Suicide Life Threat Behav. 44(4): 408–19. 2014. KQ2E424612048
192 von Glischinski, M, Teismann, T, . Depressive Symptom Inventory Suicidality Subscale: Optimal Cut Points for Clinical and Non-Clinical Samples. Clin Psychol Psychother. 23(6): 543–549. 2016. KQ2E426857479
193 Vuorilehto, M, Valtonen, HM, . Method of assessment determines prevalence of suicidal ideation among patients with depression. European Psychiatry: the Journal of the Association of European Psychiatrists. 29(6): 338–44. 2014. KQ2E124176645
194 Walker, LO, Gao, J, . Postpartum Psychosocial and Behavioral Health: A Systematic Review of Self-Administered Scales Validated for Postpartum Women in the United States. Womens Health Issues. 25(5): 586–600. 2015. KQ2E10a26169216
195 Watson, LC, Pignone, MP. Screening accuracy for late-life depression in primary care: a systematic review. J Fam Pract. 52(12): 956–64. 2003. KQ2E10a14653982
196 Whooley, MA. Screening for Depression--A Tale of Two Questions. JAMA Intern Med. 176(4): 436–8. 2016. KQ2E326814016
197 Wild, B, Eckl, A, . Assessing generalized anxiety disorder in elderly people using the GAD-7 and GAD-2 scales: results of a validation study. American Journal of Geriatric Psychiatry. 22(10): 1029–38. 2014. KQ2E15
198 Willi, J, Ehlert, U. Assessment of perimenopausal depression: A review. J Affect Disord. 249: 216–222. 2019. KQ2E530776662
199 Williams, Nerys. Questionnaire review: PHQ-9. Occup Med (Chic Ill). 64(2): 139–140. 2014. KQ2E3
200 Williams, Nerys. The GAD-7 Questionnaire. Occup Med (Chic Ill). 64(3): 224. 2014. KQ2E3
201 Willis, BH, Hyde, CJ. What is the test’s accuracy in my practice population? Tailored meta-analysis provides a plausible estimate. J Clin Epidemiol. 68(8): 847–54. 2015. KQ2E125479685
202 Wilson, R, Agius, M. Is there good evidence that the two Questions in PHQ-2 are useful questions to use in order to screen for depression? Psychiatr Danub. 29(Suppl 3): 232–235. 2017. KQ2E328953768
203 Wongpakaran, N, Wongpakaran, T, . Core Symptom Index (CSI): testing for bifactor model and differential item functioning. Int Psychogeriatr. 31(12): 1769–1779. 2019. KQ2E2a30915932
204 Wu, CY, Lee, JI, . Predictive validity of a five-item symptom checklist to screen psychiatric morbidity and suicide ideation in general population and psychiatric settings. Journal of the Formosan Medical Association. 115(6): 395–403. 2016. KQ2E426141706
205 Wunner, C, Stemmler, M, . Screening for depression in old age : A comparison of the geriatric depression scale and the depression in old age scale. Z Gerontol Geriatr. 05: 05. 2021. 10.1007/s00391-021-01949-w KQ2E7a
206 Yamashita, H, Yoshida, K, . Postnatal depression in Japanese women. Detecting the early onset of postnatal depression by closely monitoring the postpartum mood. J Affect Disord. 58(2): 145–154. 2000. KQ2E310781704
207 Yochim, BP, Mueller, AE, . Psychometric Properties of the Geriatric Anxiety Scale: Comparison to the Beck Anxiety Inventory and Geriatric Anxiety Inventory. Clin Gerontol. 34(21-33). 2011. KQ2E4
208 Yoon, S, Park, K, . The ultra brief checklist for suicidality. J Affect Disord. 276(): 279–286. 2020. 10.1016/j.jad.2020.07.037 KQ2E7a32697710

## KQs 4-5 Excluded Studies

1 Ahern, E, Kinsella, S, . Clinical efficacy and economic evaluation of online cognitive behavioral therapy for major depressive disorder: a systematic review and meta-analysis. Expert Rev Pharmacoecon Outcomes Res. 18(1): 25–41. 2018. KQ4E10a, KQ5E10a29145746
2 Ahmadi, R, Ahmadizadeh, R, . Transdiagnostic versus construct-specific cognitive behavioural therapy for emotional disorders in patients with high anxiety sensitivity: a double-blind randomised clinical trial. Behaviour change. 2021. 10.1017/bec.2021.6 KQ4E2a, KQ5E2a
3 Akarsu, NE, Prince, MJ, . Depression in carers of people with dementia from a minority ethnic background: Systematic review and meta-analysis of randomised controlled trials of psychosocial interventions. Int J Geriatr Psychiatry. 34(6): 790–806. 2019. KQ4E7, KQ5E730714226
4 Alberti, S, Chiesa, A, . Insomnia and somnolence associated with second-generation antidepressants during the treatment of major depression: a meta-analysis. J Clin Psychopharmacol. 35(3): 296–303. 2015. PMID: 25874915. 10.1097/JCP.0000000000000329 KQ4E5, KQ5E525874915
5 Allain, N, Leven, C, . Manic switches induced by antidepressants: an umbrella review comparing randomized controlled trials and observational studies. Acta Psychiatr Scand. 135(2): 106–116. 2017. PMID: 27878807. 10.1111/acps.12672 KQ4E7, KQ5E727878807
6 Allard, R, Marshall, M, . Intensive follow-up does not decrease the risk of repeat suicide attempts. Suicide Life Threat Behav. 22(3): 303–314. 1992. PMID: 1440744. KQ4E2b, KQ5E2b1440744
7 Allen, AR, Newby, JM, . Internet cognitive-behavioural treatment for panic disorder: randomised controlled trial and evidence of effectiveness in primary care. B J Psych Open. 2(2): 154–162. 2016. PMID: 27703768. KQ4E11, KQ5E1127703768
8 Allgulander, C, Mangano, R, . Efficacy of Venlafaxine ER in patients with social anxiety disorder: a double-blind, placebo-controlled, parallel-group comparison with paroxetine. Hum Psychopharmacol. 19(6): 387–96. 2004. KQ4E7b, KQ5E7b15303242
9 Allgulander, C, Dahl, AA, . Efficacy of sertraline in a 12-week trial for generalized anxiety disorder. Am J Psychiatry. 161(9): 1642–9. 2004. PMID: 15337655. 10.1176/appi.ajp.161.9.1642 KQ4E7b, KQ5E7b15337655
10 Allgulander, C, Hackett, D, . Venlafaxine extended release (ER) in the treatment of generalised anxiety disorder: twenty-four-week placebo-controlled dose-ranging study. Br J Psychiatry. 179: 15–22. 2001. PMID: 11435263. 10.1192/bjp.179.1.15 KQ4E7b, KQ5E7b11435263
11 Almeida, OP, Pirkis, J, . A randomized trial to reduce the prevalence of depression and self-harm behavior in older primary care patients. Ann Fam Med. 10(4): 347–356. 2012. PMID: 22778123. KQ4E8, KQ5E822778123
12 Alves, Stephanie, Martins, Alexandra, . Preventing and treating women’s postpartum depression: A qualitative systematic review on partner-inclusive interventions. J Child Fam Stud. 27(1): 1–25. 2018. KQ4E10a, KQ5E5
13 Amiri, NP, Ahmadi, A, . The Effect of Dialectic Behavioral Counseling on Depression, Anxiety, and Postpartum Hematocrit Level. Revista Brasileira de Ginecologia e Obstetricia. 43(4): 275–282. 2021. 10.1055/s-0041-1728780 KQ4E2a, KQ5E2a33979888
14 Ammerman, RT, Altaye, M, . Depression improvement and parenting in low-income mothers in home visiting. Arch Womens Ment Health. 18(3): 555–63. 2015. PMID: 25369906. KQ4E3a, KQ5E3a25369906
15 Ammerman, RT, Peugh, JL, . Child maltreatment history and response to CBT treatment in depressed mothers participating in home visiting. J Interpers Violence. 31(5): 774–91. 2016. PMID: 25395221. KQ4E3a, KQ5E3a25395221
16 Ammerman, RT, Putnam, FW, . A clinical trial of in-home CBT for depressed mothers in home visitation. Behav Ther. 44(3): 359–372. 2013. PMID: 23768664. KQ4E3a, KQ5E3a23768664
17 Ammerman, RT, Putnam, FW, . Treatment of depressed mothers in home visiting: impact on psychological distress and social functioning. Child Abuse Negl. 37(8): 544–554. 2013. PMID: 23623623. KQ4E3a, KQ5E3a23623623
18 Andersch, S, Rosenberg, NK, . Efficacy and safety of alprazolam, imipramine and placebo in treating panic disorder. A Scandinavian multicenter study. Acta Psychiatr Scand Suppl. 365: 18–27. 1991. KQ4E7b, KQ5E7b1862730
19 Andersen, JT, Andersen, NL, . Exposure to selective serotonin reuptake inhibitors in early pregnancy and the risk of miscarriage. Obstet Gynecol. 124(4): 655–661. 2014. PMID: 25198261. KQ4E3, KQ5E3a25198261
20 Andersen, P, Toner, P, . Effectiveness of Transdiagnostic Cognitive Behaviour Therapy for Anxiety and Depression in Adults: A Systematic Review and Meta-analysis. Behav Cogn Psychother. 44(6): 673–690. 2016. KQ4E10a, KQ5E10a27301967
21 Anderson, KN, Lind, JN, . Maternal Use of Specific Antidepressant Medications During Early Pregnancy and the Risk of Selected Birth Defects. JAMA Psychiatry. 77(12): 1246–1255. 2020. PMID: 32777011. 10.1001/jamapsychiatry.2020.2453 KQ4E3, KQ5E3a32777011
22 Andersson, G, Rozental, A, . Long-term effects of internet-supported cognitive behaviour therapy. Expert Rev Neurother. 18(1): 21–28. 2018. KQ4E10a, KQ5E529094622
23 Andersson, G, Carlbring, P, . Internet Interventions for Adults with Anxiety and Mood Disorders: A Narrative Umbrella Review of Recent Meta-Analyses. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 64(7): 465–470. 2019. PMID: 31096757. 10.1177/0706743719839381 KQ4E10a, KQ5E531096757
24 Andersson, G, Carlbring, P, . Response and Remission Rates in Internet-Based Cognitive Behavior Therapy: An Individual Patient Data Meta-Analysis. Frontiers in psychiatry Frontiers Research Foundation. 10: 749. 2019. PMID: 31708813. 10.3389/fpsyt.2019.00749 KQ4E10a, KQ5E10a31708813
25 Anding, J, Rohrle, B, . Early Detection of Postpartum Depressive Symptoms in Mothers and Fathers and Its Relation to Midwives’ Evaluation and Service Provision: A Community-Based Study. Frontiers in Pediatrics. 3: 62. 2015. PMID: 26217649. 10.3389/fped.2015.00062 KQ4E8, KQ5E826217649
26 Andrade, C. Antidepressant Exposure During Pregnancy and Risk of Autism in the Offspring, 1: Meta-Review of Meta-Analyses. J Clin Psychiatry. 78(8): e1047–e1051. 2017. PMID: 28994903. 10.4088/JCP.17f11903 KQ4E5, KQ5E10a28994903
27 Andreasson, K, Krogh, J, . Effectiveness of Dialectical Behavior Therapy Versus Collaborative Assessment and Management of Suicidality Treatment for Reduction of Self-Harm in Adults with Borderline Personality Traits and Disorder-a Randomized Observer-Blinded Clinical Trial. Depress Anxiety. 33(6): 520–30. 2016. KQ4E4a, KQ5E4a26854478
28 Andreoli, A, Burnand, Y, . Disappointed Love and Suicide: A Randomized Controlled Trial of “Abandonment Psychotherapy” Among Borderline Patients. J Pers Disord. 30(2): 271–87. 2016. KQ4E2b, KQ5E2b26111250
29 Andrews, G, Basu, A, . Computer therapy for the anxiety and depression disorders is effective, acceptable and practical health care: An updated meta-analysis. J Anxiety Disord. 55: 70–78. 2018. PMID: 29422409. 10.1016/j.janxdis.2018.01.001 KQ4E8, KQ5E829422409
30 Andrisano, C, Chiesa, A, . Newer antidepressants and panic disorder: a meta-analysis. Int Clin Psychopharmacol. 28(1): 33–45. 2013. PMID: 23111544. 10.1097/YIC.0b013e32835a5d2e KQ4E10a, KQ5E10a23111544
31 Apolinario-Hagen, J. Internet-Delivered Psychological Treatment Options for Panic Disorder: A Review on Their Efficacy and Acceptability. Psychiatry Investig. 16(1): 37–49. 2019. PMID: 30122031. 10.30773/pi.2018.06.26 KQ4E10a, KQ5E530122031
32 Apostolo, J, Queiros, P, . The effectiveness of nonpharmacological interventions in older adults with depressive disorders: a systematic review. JBI Database of Systematic Reviews and Implementation Reports. 13(6): 220–78. 2015. KQ4E10a, KQ5E10a26455753
33 Apostolo, J, Bobrowicz-Campos, E, . The effectiveness of non-pharmacological interventions in older adults with depressive disorders: A systematic review. Int J Nurs Stud. 58: 59–70. 2016. PMID: 27087298. 10.1016/j.ijnurstu.2016.02.006 KQ4E10a, KQ5E10a27087298
34 Appleby, L, Warner, R, . A controlled study of fluoxetine and cognitive-behavioural counselling in the treatment of postnatal depression. BMJ. 314(7085): 932–936. 1997. PMID: 9099116. KQ4E3a, KQ5E3a9099116
35 Araujo, JSA, Delgado, IF, . Antenatal exposure to antidepressant drugs and the risk of neurodevelopmental and psychiatric disorders: a systematic review. Cad Saude Publica. 36(2): e00026619. 2020. PMID: 32022173. 10.1590/0102-311X00026619 KQ4E5, KQ5E10a32022173
36 Arensman, E, McAuliffe, C, . Findings of the POPMACT study. Psychol Med. 34(6): 1143–1144. 2004. PMID: 15554583. KQ4E2b, KQ5E2b15554583
37 Asnis, GM, Hameedi, FA, . Fluvoxamine in the treatment of panic disorder: a multi-center, double-blind, placebo-controlled study in outpatients. Psychiatry Res. 103(1): 1–14. 2001. KQ4E7b, KQ5E7b11472786
38 Asnis, GregoryM, Henderson, MargaretA. Levomilnacipran for the treatment of major depressive disorder: A review. Neuropsychiatric Disease and Treatment 11. 2015. KQ4E10a, KQ5E10a
39 Bai, Z, Luo, S, . Acceptance and Commitment Therapy (ACT) to reduce depression: A systematic review and meta-analysis. J Affect Disord. 260: 728–737. 2020. KQ4E10a, KQ5E531563072
40 Bala, A, Nguyen, HMT, . Post-SSRI Sexual Dysfunction: A Literature Review. Sexual Medicine Reviews. 6(1): 29–34. 2018. KQ4E1, KQ5E10a28778697
41 Baldessarini, RJ, Lau, WK, . Duration of initial antidepressant treatment and subsequent relapse of major depression. J Clin Psychopharmacol. 35(1): 75–6. 2015. PMID: 25502491. 10.1097/JCP.0000000000000263 KQ4E11, KQ5E1125502491
42 Baldwin, D, Woods, R, . Efficacy of drug treatments for generalised anxiety disorder: systematic review and meta-analysis. BMJ. 342: d1199. 2011. PMID: 21398351. 10.1136/bmj.d1199 KQ4E10a, KQ5E10a21398351
43 Baldwin, DS, Asakura, S, . Efficacy of escitalopram in the treatment of social anxiety disorder: A meta-analysis versus placebo. Eur Neuropsychopharmacol. 26(6): 1062–9. 2016. PMID: 26971233. 10.1016/j.euroneuro.2016.02.013 KQ4E10a, KQ5E526971233
44 Baldwin, DS, Florea, I, . A meta-analysis of the efficacy of vortioxetine in patients with major depressive disorder (MDD) and high levels of anxiety symptoms. J Affect Disord. 206: 140–150. 2016. PMID: 27474960. 10.1016/j.jad.2016.07.015 KQ4E10a, KQ5E10a27474960
45 Ban, L, Gibson, J, . Maternal depression, antidepressant prescriptions, and congenital anomaly risk in offspring: a population-based cohort study. BJOG. 121(12): 1471–1481. 2014. PMID: 24612301. KQ4E3, KQ5E3a24612301
46 Bandelow, B, Reitt, M, . Efficacy of treatments for anxiety disorders: a meta-analysis. Int Clin Psychopharmacol. 30(4): 183–92. 2015. KQ4E10a, KQ5E525932596
47 Bandelow, B, Sagebiel, A, . Enduring effects of psychological treatments for anxiety disorders: meta-analysis of follow-up studies. Br J Psychiatry. 212(6): 333–338. 2018. PMID: 29706139. 10.1192/bjp.2018.49 KQ4E5, KQ5E529706139
48 Bannan, Noreen. Group-based problem-solving therapy in self-poisoning females: A pilot study. Couns Psychother Res. 10(3): 201–213. 2010. PMID: None. KQ4E2b, KQ5E2b
49 Barbato, A, D’Avanzo, B, . Couple therapy for depression. Cochrane Database of Systematic Reviews. 6(): CD004188. 2018. PMID: 29882960. 10.1002/14651858.CD004188.pub3 KQ4E10a, KQ5E10a29882960
50 Barkowski, S, Schwartze, D, . Efficacy of group psychotherapy for anxiety disorders: A systematic review and meta-analysis. Psychotherapy Research. 1–18. 2020. KQ4E10a, KQ5E5
51 Barkowski, S, Schwartze, D, . Efficacy of group psychotherapy for social anxiety disorder: A meta-analysis of randomized-controlled trials. J Anxiety Disord. 39: 44–64. 2016. PMID: 26953823. 10.1016/j.janxdis.2016.02.005 KQ4E10a, KQ5E10a26953823
52 Barlow, DH, Farchione, TJ, . The Unified Protocol for Transdiagnostic Treatment of Emotional Disorders Compared With Diagnosis-Specific Protocols for Anxiety Disorders: A Randomized Clinical Trial. JAMA Psychiatry. 74(9): 875–884. 2017. PMID: 28768327. 10.1001/jamapsychiatry.2017.2164 KQ4E7b, KQ5E7b28768327
53 Barnes, AJ. Attachment-based family therapy reduces suicidal ideation in adolescents. Evid Based Ment Health. 14(1): 8–8. 2011. KQ4E7a, KQ5E7a21266605
54 Barth, J, Munder, T, . Comparative Efficacy of Seven Psychotherapeutic Interventions for Patients with Depression: A Network Meta-Analysis. Focus (Madison). 14(2): 229–243. 2016. KQ4E10a, KQ5E5
55 Barth, M, Kriston, L, . Efficacy of selective serotonin reuptake inhibitors and adverse events: meta-regression and mediation analysis of placebo-controlled trials. Br J Psychiatry. 208(2): 114–9. 2016. PMID: 26834168. 10.1192/bjp.bp.114.150136 KQ4E10a, KQ5E10a26834168
56 Basu, A, Andrews, G, . Computer therapy for the anxiety and depression disorders is effective, acceptable and practical healthcare: an updated meta-analysis. Aust N Z J Psychiatry. 51(1): 117. 2017. 10.1177/0004867417702054 KQ4E14, KQ5E1427920065
57 Bateman, A, Fonagy, P. Effectiveness of partial hospitalization in the treatment of borderline personality disorder: a randomized controlled trial. Am J Psychiatry. 156(10): 1563–1569. 1999. PMID: 10518167. KQ4E11, KQ5E1110518167
58 Bateman, A, Fonagy, P. Treatment of borderline personality disorder with psychoanalytically oriented partial hospitalization: an 18-month follow-up. Am J Psychiatry. 158(1): 36–42. 2001. PMID: 11136631. KQ4E11, KQ5E1111136631
59 Batterham, PJ, van Spijker, BAJ, . Consistency of trajectories of suicidal ideation and depression symptoms: Evidence from a randomized controlled trial. Depress Anxiety. 36(4): 321–329. 2019. KQ4E11, KQ5E1130466148
60 Batterham, PJ, Calear, AL, . A Brief Intervention to Increase Uptake and Adherence of an Internet-Based Program for Depression and Anxiety (Enhancing Engagement With Psychosocial Interventions): Randomized Controlled Trial. J Med Internet Res. 23(7): e23029. 2021. 10.2196/23029 KQ4E8, KQ5E834313595
61 Batterham, PJ, Calear, AL, . FitMindKit: Randomised controlled trial of an automatically tailored online program for mood, anxiety, substance use and suicidality. Internet Interv. 12: 91–99. 2018. 10.1016/j.invent.2017.08.002 KQ4E11, KQ5E1130135773
62 Baumgartner, K, Doering, M, . Vilazodone poisoning: a systematic review. Clinical Toxicology: The Official Journal of the American Academy of Clinical Toxicology & European Association of Poisons Centres & Clinical Toxicologists. 58(5): 360–367. 2020. KQ4E5, KQ5E10a31777303
63 Bautista, ChandraL, Ralston, AlluraL, . Peer coach support in internet-based cognitive behavioral therapy for college students with social anxiety disorder: Efficacy and acceptability. Cogent Psychology. 9(1). 2022. 10.1080/23311908.2022.2040160 KQ4E7b, KQ5E7b
64 Beautrais, AL, Gibb, SJ, . Postcard intervention for repeat self-harm: randomised controlled trial. Br J Psychiatry. 197(1): 55–60. 2010. PMID: 20592434. KQ4E2b, KQ5E2b20592434
65 Behenck, ADS, Wesner, AC, . Anxiety Sensitivity and Panic Disorder: Evaluation of the Impact of Cognitive-Behavioral Group Therapy. Issues Ment Health Nurs. 42(2): 112–118. 2021. 10.1080/01612840.2020.1780527 KQ4E2a, KQ5E2a32643490
66 Beijers, C, Verbeek, T, . Cognitive behavioral therapy for treatment of antenatal anxiety and depressive symptoms: a randomized controlled trial. Arch Womens Ment Health. 18(2): 373. 2015. 10.1007/s00737-014-0488-6 KQ4E14, KQ5E14
67 Bellantuono, Cesario, Vargas, Marianna, . The safety of serotonin-noradrenaline reuptake inhibitors (SNRIs) in pregnancy and breastfeeding: A comprehensive review. Human Psychopharmacology: Clinical and Experimental. 30(3): 143–151. 2015. KQ4E5, KQ5E10a25784291
68 Belliveau, C, Nagy, C, . Effects of Mindfulness-Based Cognitive Therapy on Peripheral Markers of Stress and Inflammation in Older-Adults With Depression and Anxiety: A Parallel Analysis of a Randomized Controlled Trial. Frontiers in psychiatry Frontiers Research Foundation. 12: 804269. 2021. PMID: 35002817. 10.3389/fpsyt.2021.804269 KQ4E5, KQ5E535002817
69 Bennett, CharlesB, Ruggero, CamiloJ, . eHealth to redress psychotherapy access barriers both new and old: A review of reviews and meta-analyses. J Psychother Integr. 30(2): 188–207. 2020. KQ4E11, KQ5E11
70 Bennewith, O, Stocks, N, . General practice based intervention to prevent repeat episodes of deliberate self harm: cluster randomised controlled trial. BMJ. 324(7348): 1254–1257. 2002. PMID: 12028981. KQ4E8, KQ5E812028981
71 Benraad, CE, Kamerman-Celie, F, . Geriatric characteristics in randomised controlled trials on antidepressant drugs for older adults: a systematic review. Int J Geriatr Psychiatry. 31(9): 990–1003. 2016. KQ4E10a, KQ5E10a26924120
72 Bereza, BG, Machado, M, . Evidence-based review of clinical outcomes of guideline-recommended pharmacotherapies for generalized anxiety disorder. Can J Psychiatry. 57(8): 470–8. 2012. PMID: 22854029. 10.1177/070674371205700805 KQ4E10a, KQ5E10a22854029
73 Berger, T, Urech, A, . Effects of a transdiagnostic unguided Internet intervention (‘velibra’) for anxiety disorders in primary care: results of a randomized controlled trial. Psychol Med. 47(1): 67–80. 2017. KQ4E7b, KQ5E7b27655039
74 Bergstrom, Jan. Internet-based treatment for depression and panic disorder: From development to deployment. Dissertation Abstracts International: Section B: The Sciences and Engineering. 83(2-B): No Pagination Specified. 2022. KQ4E7b, KQ5E7b
75 Berryhill, MB, Halli-Tierney, A, . Videoconferencing psychological therapy and anxiety: a systematic review. Fam Pract. 36(1): 53–63. 2019. PMID: 30188992. 10.1093/fampra/cmy072 KQ4E8, KQ5E830188992
76 Betz, ME, Knoepke, CE, . An Interactive Web-Based Lethal Means Safety Decision Aid for Suicidal Adults (Lock to Live): Pilot Randomized Controlled Trial. J Med Internet Res. 22(1): e16253. 2020. KQ4E2b, KQ5E2b32012056
77 Beyazyüz, M, Albayrak, Y, . Relationship between SSRIs and Metabolic Syndrome Abnormalities in Patients with Generalized Anxiety Disorder: A Prospective Study. Psychiatry Investig. 10(2): 148–54. 2013. PMID: 23798963. 10.4306/pi.2013.10.2.148 KQ4E3, KQ5E523798963
78 Beyer, C, Cappetta, K, . Meta-analysis: Risk of hyperhidrosis with second-generation antidepressants. Depress Anxiety. 34(12): 1134–1146. 2017. KQ4E5, KQ5E10a28881483
79 Biffi, A, Cantarutti, A, . Use of antidepressants during pregnancy and neonatal outcomes: An umbrella review of meta-analyses of observational studies. J Psychiatr Res. 124: 99–108. 2020. KQ4E5, KQ5E10a32135392
80 Bighelli, I, Borghesani, A, . Is the efficacy of antidepressants in panic disorder mediated by adverse events? A mediational analysis. PLoS ONE [Electronic Resource]. 12(6): e0178617. 2017. PMID: 28575031. 10.1371/journal.pone.0178617 KQ4E10a, KQ5E528575031
81 Blanck, P, Perleth, S, . Effects of mindfulness exercises as stand-alone intervention on symptoms of anxiety and depression: Systematic review and meta-analysis. Behav Res Ther. 102: 25–35. 2018. KQ4E10a, KQ5E10a29291584
82 Blomhoff, S, Haug, TT, . Randomised controlled general practice trial of sertraline, exposure therapy and combined treatment in generalised social phobia. Br J Psychiatry. 179: 23–30. 2001. 10.1192/bjp.179.1.23 KQ4E11, KQ5E1111435264
83 Boettcher, Johanna, Magnusson, Kristoffer, . Adding a smartphone app to internet-based self-help for social anxiety: A randomized controlled trial. Comput Human Behav. 87: 98–108. 2018. KQ4E2, KQ5E2
84 Boffa, JosephW, III. Development of a novel intervention for intrusive suicidal thoughts informed by cognitive behavioral models of anxiety. Dissertation Abstracts International: Section B: The Sciences and Engineering. 82(4-B): No Pagination Specified. 2021. KQ4E7b, KQ5E7b
85 Bose, A, Korotzer, A, . Randomized placebo-controlled trial of escitalopram and venlafaxine XR in the treatment of generalized anxiety disorder. Depress Anxiety. 25(10): 854–61. 2008. KQ4E7b, KQ5E7b18050245
86 Boumparis, N, Karyotaki, E, . The effect of psychotherapeutic interventions on positive and negative affect in depression: A systematic review and meta-analysis. J Affect Disord. 202: 153–62. 2016. KQ4E10a, KQ5E527262637
87 Bradwejn, J, Ahokas, A, . Venlafaxine extended-release capsules in panic disorder: flexible-dose, double-blind, placebo-controlled study. Br J Psychiatry. 187: 352–9. 2005. PMID: 16199795. 10.1192/bjp.187.4.352 KQ4E7b, KQ5E7b16199795
88 Brenes, GA, Danhauer, SC, . Telephone-Delivered Cognitive Behavioral Therapy and Telephone-Delivered Nondirective Supportive Therapy for Rural Older Adults With Generalized Anxiety Disorder: A Randomized Clinical Trial. JAMA Psychiatry. 72(10): 1012–20. 2015. PMID: 26244854. 10.1001/jamapsychiatry.2015.1154 KQ4E7b, KQ5E7b26244854
89 Broglia, E, Millings, A, . Counseling With Guided Use of a Mobile Well-Being App for Students Experiencing Anxiety or Depression: Clinical Outcomes of a Feasibility Trial Embedded in a Student Counseling Service. JMIR MHealth and UHealth. 7(8): e14318. 2019. KQ4E4a, KQ5E4a31418424
90 Broocks, A, Bandelow, B, . Comparison of aerobic exercise, clomipramine, and placebo in the treatment of panic disorder. Am J Psychiatry. 155(5): 603–9. 1998. PMID: 9585709. 10.1176/ajp.155.5.603 KQ4E7b, KQ5E7b9585709
91 Brown, GK, Ten, HaveT, . Cognitive therapy for the prevention of suicide attempts: a randomized controlled trial. JAMA. 294(5): 563–570. 2005. PMID: 16077050. KQ4E2b, KQ5E2b16077050
92 Brown, L, Ospina, JP, . The Effects of Positive Psychological Interventions on Medical Patients’ Anxiety: A Meta-analysis. Psychosom Med. 81(7): 595–602. 2019. KQ4E10a, KQ5E531232915
93 Brunnauer, Alexander, Laux, Cerd. Driving under the influence of antidepressants: A systematic review and update of the evidence of experimental and controlled clinical studies. Pharmacopsychiatry. 50(5): 173–181. 2017. KQ4E5, KQ5E528718182
94 Bruno, Antonio, Morabito, Paolo, . The role of levomilnacipran in the management of major depressive disorder: A comprehensive review. Curr Neuropharmacol. 14(2): 191–199. 2016. 10.2174/1570159X14666151117122458 KQ4E10a, KQ5E10a26572745
95 Bryan, CJ, Mintz, J, . Effect of crisis response planning vs. contracts for safety on suicide risk in U.S. Army Soldiers: A randomized clinical trial. J Affect Disord. 212: 64–72. 2017. KQ4E2b, KQ5E2b28142085
96 Bryan, CJ, Peterson, AL, . Differential Effects of Brief CBT Versus Treatment as Usual on Posttreatment Suicide Attempts Among Groups of Suicidal Patients. Psychiatr Serv. 69(6): 703–709. 2018. KQ4E2b, KQ5E2b29493409
97 Bryan, CJ, Wood, DS, . Mechanisms of Action Contributing to Reductions in Suicide Attempts Following Brief Cognitive Behavioral Therapy for Military Personnel: A Test of the Interpersonal-Psychological Theory of Suicide. Archives of Suicide Research. 22(2): 241–253. 2018. KQ4E2b, KQ5E2b28422576
98 Burnand, Yvonne, Andreoli, Antonio, . “Abandonment psychotherapy” for suicidal patients with borderline personality disorder: Long-term outcome. Psychother Psychosom. 86(5): 311–313. 2017. KQ4E2b, KQ5E2b28903102
99 Cameron, DH, Rapoport, MJ. Antidepressants and Driving in Older Adults: A Systematic Review. Canadian Journal on Aging. 35(Suppl 1): 7–14. 2016. PMID: 27091414. 10.1017/S0714980816000064 KQ4E11, KQ5E1127091414
100 Canfield, ShannonM. Improving perinatal mental health: A pilot study of the online mothers and babies course with couples. Dissertation Abstracts International: Section B: The Sciences and Engineering. 83(8-B): No Pagination Specified. 2022. KQ4E7b, KQ5E7b
101 Canuso, C, Singh, J, . Persevere: a study of esketamine for the reduction of the symptoms of major depressive disorder, including suicidal ideation, in subjects assessed to be at imminent risk for suicide. Biol Psychiatry. 81(10): S31. 2017. KQ4E14, KQ5E14
102 Canuso, C, Fu, Dj, . Esketamine nasal spray for rapid reduction of depressive symptoms in adult patients with major depressive disorder at imminent risk for suicide: results from the phase 3 program. Neuropsychopharmacology. 44: 454–455. 2019. 10.1038/s41386-019-0547-9 KQ4E14, KQ5E14
103 Canuso, C, Singh, Jb, . Efficacy and safety of intranasal esketamine for the rapid reduction of symptoms of major depressive disorder, including suicidal ideation, in patients assessed to be at imminent risk for suicide: a proof-ofconcept study. Neuropsychopharmacology. 41: S370–s371. 2016. 10.1038/npp.2016.241 KQ4E14, KQ5E14
104 Canuso, CM, Singh, JB, . Efficacy and Safety of Intranasal Esketamine for the Rapid Reduction of Symptoms of Depression and Suicidality in Patients at Imminent Risk for Suicide: Results of a Double-Blind, Randomized, Placebo-Controlled Study. Am J Psychiatry. 175(7): 620–630. 2018. PMID: 29656663. 10.1176/appi.ajp.2018.17060720 KQ4E2b, KQ5E2b29656663
105 Cao, B, Zhu, J, . Pharmacological interventions targeting anhedonia in patients with major depressive disorder: A systematic review. Prog Neuropsychopharmacol Biol Psychiatry. 92: 109–117. 2019. KQ4E10a, KQ5E10a30611836
106 Cappetta, K, Beyer, C, . Meta-analysis: Risk of dry mouth with second generation antidepressants. Prog Neuropsychopharmacol Biol Psychiatry. 84(Pt A): 282–293. 2018. KQ4E10a, KQ5E10a29274375
107 Carbone, GA, Zarfati, A, . Online psychological counselling during lockdown reduces anxiety symptoms and negative affect: Insights from Italian framework. Clin Psychol Psychother. 05: 05. 2021. 10.1002/cpp.2608 KQ4E7b, KQ5E7b
108 Carl, E, Stein, AT, . Virtual reality exposure therapy for anxiety and related disorders: A meta-analysis of randomized controlled trials. J Anxiety Disord. 61: 27–36. 2019. KQ4E10a, KQ5E10a30287083
109 Carl, E, Witcraft, SM, . Psychological and pharmacological treatments for generalized anxiety disorder (GAD): a meta-analysis of randomized controlled trials. Cogn Behav Ther. 49(1): 1–21. 2020. KQ4E10a, KQ5E530760112
110 Carl, JR, Miller, CB, . Efficacy of digital cognitive behavioral therapy for moderate-to-severe symptoms of generalized anxiety disorder: A randomized controlled trial. Depress Anxiety. 37(12): 1168–1178. 2020. 10.1002/da.23079 KQ4E7b, KQ5E7b32725848
111 Carli, Vladimir. Preventing suicidality through online tools: The SUPREME Project. Understanding suicide: From diagnosis to personalized treatment. 281–289. 2016. KQ4E7a, KQ5E7a
112 Carlyle, D, Green, R, . A Randomized-Controlled Trial of Mentalization-Based Treatment Compared With Structured Case Management for Borderline Personality Disorder in a Mainstream Public Health Service. Front Psychiatry. 11: 2020. 10.3389/fpsyt.2020.561916 KQ4E4, KQ5E5
113 Carpenter, JK, Andrews, LA, . Cognitive behavioral therapy for anxiety and related disorders: A meta-analysis of randomized placebo-controlled trials. Depress Anxiety. 35(6): 502–514. 2018. PMID: 29451967. 10.1002/da.22728 KQ4E4, KQ5E429451967
114 Carrasco, JL, Kornstein, SG, . An integrated analysis of the efficacy and safety of desvenlafaxine in the treatment of major depressive disorder. Int Clin Psychopharmacol. 31(3): 134–46. 2016. KQ4E10a, KQ5E10a26895080
115 Carter, GL, Clover, K, . Postcards from the EDge project: randomised controlled trial of an intervention using postcards to reduce repetition of hospital treated deliberate self poisoning. BMJ. 331(7520): 805. 2005. PMID: 16183654. KQ4E2b, KQ5E2b16183654
116 Carter, GL, Clover, K, . Postcards from the EDge: 24-month outcomes of a randomised controlled trial for hospital-treated self-poisoning. Br J Psychiatry. 191: 548–553. 2007. PMID: 18055960. KQ4E2b, KQ5E2b18055960
117 Carter, GL, Clover, K, . Postcards from the EDge: 5-year outcomes of a randomised controlled trial for hospital-treated self-poisoning. Br J Psychiatry. 202(5): 372–80. 2013. PMID: 23520223. 10.1192/bjp.bp.112.112664 KQ4E2b, KQ5E2b23520223
118 Carvalho, AF, Sharma, MS, . The Safety, Tolerability and Risks Associated with the Use of Newer Generation Antidepressant Drugs: A Critical Review of the Literature. Psychother Psychosom. 85(5): 270–88. 2016. PMID: 27508501. 10.1159/000447034 KQ4E5, KQ5E10a27508501
119 Castelpietra, G, Bortolussi, L, . Discontinuation of antidepressants in suicides findings from the Friuli Venezia Giulia Region, Italy, 2005-2014. Basic Clin Pharmacol Toxicol. 124(3): 312–320. 2019. PMID: 30281896. 10.1111/bcpt.13140 KQ4E3, KQ5E130281896
120 Castelpietra, G, Gobbato, M, . Antidepressant use in suicides: a case-control study from the Friuli Venezia Giulia Region, Italy, 2005-2014. Eur J Clin Pharmacol. 73(7): 883–890. 2017. PMID: 28342066. 10.1007/s00228-017-2236-0 KQ4E3, KQ5E3a28342066
121 Caye, A, Pilz, LK, . The impact of selective serotonin reuptake inhibitors on the thyroid function among patients with major depressive disorder: A systematic review and meta-analysis. Eur Neuropsychopharmacol. 33: 139–145. 2020. PMID: 32046933. 10.1016/j.euroneuro.2020.01.011 KQ4E5, KQ5E532046933
122 Cebria, AI, Parra, I, . Effectiveness of a telephone management programme for patients discharged from an emergency department after a suicide attempt: controlled study in a Spanish population. J Affect Disord. 147(1–3): 269–76. 2013. KQ4E2b, KQ5E2b23219058
123 Cebria, AI, Perez-Bonaventura, I, . Telephone Management Program for Patients Discharged From an Emergency Department After a Suicide Attempt: A 5-Year Follow-Up Study in a Spanish Population. Crisis: Journal of Crisis Intervention & Suicide. 36(5): 345–52. 2015. KQ4E2b, KQ5E2b
124 Cedereke, M, Monti, K, . Telephone contact with patients in the year after a suicide attempt: does it affect treatment attendance and outcome? A randomised controlled study. Eur Psychiatry. 17(2): 82–91. 2002. PMID: 11973116. KQ4E8, KQ5E811973116
125 Chady, I, Wadih, N, . Non-Antidepressant Pharmacologic Long-Term Treatment of Panic Disorder. Curr Clin Pharmacol. 10(2): 112–115. 2015. KQ4E10a, KQ5E523438727
126 Chai, Y, Luo, H, . Antidepressant use and risk of self-harm among people aged 40 years or older: A population-based cohort and self-controlled case series study. The Lancet Regional Health. Western Pacific. 27: 100557. 2022. PMID: 35971451. 10.1016/j.lanwpc.2022.100557 KQ4E3, KQ5E435971451
127 Chan, ATY, Sun, GYY, . The effectiveness of group-based behavioral activation in the treatment of depression: An updated meta-analysis of randomized controlled trial. J Affect Disord. 208: 345–354. 2017. PMID: 27810717. 10.1016/j.jad.2016.08.026 KQ4E10a, KQ5E10a27810717
128 Chanen, AM, Jackson, HJ, .. Early intervention for adolescents with borderline personality disorder using cognitive analytic therapy: randomised controlled trial.[Erratum appears in Br J Psychiatry. 2009 Feb;194(2):191]. Br J Psychiatry. 193(6): 477–484. 2008. PMID: 19043151. KQ4E7a, KQ5E7a19043151
129 Chang, Q, Ma, XY, . Antidepressant Use in Depressed Women During Pregnancy and the Risk of Preterm Birth: A Systematic Review and Meta-Analysis of 23 Cohort Studies. Front Pharmacol. 11: 659. 2020. PMID: 32508635. 10.3389/fphar.2020.00659 KQ4E5, KQ5E10a32508635
130 Chau, SW, Tse, CY, . Attentional Bias Modification Training for Patients with Generalised Anxiety Disorder: a Randomised Controlled Study. East Asian Archives of Psychiatry. 29(1): 3–9. 2019. PMID: 31237250. KQ4E7b, KQ5E7b31237250
131 Chen, C, Shan, W. Pharmacological and non-pharmacological treatments for major depressive disorder in adults: A systematic review and network meta-analysis. Psychiatry Res. 281: 112595. 2019. PMID: 31627074. 10.1016/j.psychres.2019.112595 KQ4E10a, KQ5E10a31627074
132 Chen, KW, Berger, CC, . Meditative therapies for reducing anxiety: a systematic review and meta-analysis of randomized controlled trials. Depress Anxiety. 29(7): 545–62. 2012. KQ4E5, KQ5E10a22700446
133 Chen, LW, Chen, MY, . Amitriptyline and Sexual Function: A Systematic Review Updated for Sexual Health Practice. American Journal of Mens Health. 12(2): 370–379. 2018. PMID: 29019272. 10.1177/1557988317734519 KQ4E5, KQ5E10a29019272
134 Chen, WJ, Ho, CK, . Employing crisis postcards with case management in Kaohsiung, Taiwan: 6-month outcomes of a randomised controlled trial for suicide attempters. BMC Psychiatry. 13: 191. 2013. PMID: 23865947. 10.1186/1471-244X-13-191 KQ4E4, KQ5E423865947
135 Chen, YJ, Li, XX, . Non-pharmacological interventions for older adults with depressive symptoms: a network meta-analysis of 35 randomized controlled trials. Aging Ment Health. 25(5): 773–786. 2021. KQ4E10a, KQ5E10a31880174
136 Christensen, MC, Florea, I, . Efficacy of vortioxetine on the physical symptoms of major depressive disorder. J Psychopharmacol. 32(10): 1086–1097. 2018. PMID: 30047820. 10.1177/0269881118788826 KQ4E10a, KQ5E10a30047820
137 Christensen, MC, Schmidt, S, . Effectiveness of vortioxetine in patients with major depressive disorder comorbid with generalized anxiety disorder: Results of the RECONNECT study. J Psychopharmacol. 36(5): 566–577. 2022. PMID: 35499104. 10.1177/02698811221090627 KQ4E7b, KQ5E7b35499104
138 Citrome, L. Vortioxetine for major depressive disorder: a systematic review of the efficacy and safety profile for this newly approved antidepressant - what is the number needed to treat, number needed to harm and likelihood to be helped or harmed?. Int J Clin Pract. 68(1): 60–82. 2014. PMID: 24165478. 10.1111/ijcp.12350 KQ4E10a, KQ5E10a24165478
139 Clarke, Tom, Baker, Paul, . Self-harm in adults: A randomised controlled trial of nurse-led case management versus routine care only. J Ment Health. 11(2): 167–176. 2002. PMID: None. KQ4E2b, KQ5E2b
140 Clayton, AH, Hwang, E, . Effects of 50 and 100 mg desvenlafaxine versus placebo on sexual function in patients with major depressive disorder: a meta-analysis. Int Clin Psychopharmacol. 30(6): 307–15. 2015. KQ4E5, KQ5E526230270
141 Clond, M. Emotional Freedom Techniques for Anxiety: A Systematic Review With Meta-analysis. J Nerv Ment Dis. 204(5): 388–95. 2016. KQ4E10a, KQ5E526894319
142 Cluxton-Keller, F, Bruce, ML. Clinical effectiveness of family therapeutic interventions in the prevention and treatment of perinatal depression: A systematic review and meta-analysis. PLoS ONE [Electronic Resource]. 13(6): e0198730. 2018. PMID: 29902211. 10.1371/journal.pone.0198730 KQ4E10a, KQ5E10a29902211
143 Collado-Navarro, C, Navarro-Gil, M, . Effectiveness of mindfulness-based stress reduction and attachment-based compassion therapy for the treatment of depressive, anxious, and adjustment disorders in mental health settings: A randomized controlled trial. Depress Anxiety. 38(11): 1138–1151. 2021. PMID: 34288280. 10.1002/da.23198 KQ4E7b, KQ5E7b34288280
144 Collings, S, Jenkin, G, . Preventing suicidal behaviours with a multilevel intervention: a cluster randomised controlled trial. BMC Public Health. 18(1): 140. 2018. PMID: 29338723. 10.1186/s12889-018-5032-6 KQ4E8, KQ5E829338723
145 Collins, RN, Kishita, N. The Effectiveness of Mindfulness- and Acceptance-Based Interventions for Informal Caregivers of People With Dementia: A Meta-Analysis. Gerontologist. 59(4): e363–e379. 2019. PMID: 29635303. 10.1093/geront/gny024 KQ4E7, KQ5E729635303
146 Collins, S, Byrne, M, . Evaluation of a computerized cognitive behavioural therapy programme, MindWise (2.0), for adults with mild-to-moderate depression and anxiety. Br J Clin Psychol. 57(2): 255–269. 2018. PMID: 29197102. 10.1111/bjc.12165 KQ4E3, KQ5E329197102
147 Comtois, KA, Jobes, DA, . Collaborative assessment and management of suicidality (CAMS): feasibility trial for next-day appointment services. Depress Anxiety. 28(11): 963–972. 2011. PMID: 21948348. KQ4E2b, KQ5E2b21948348
148 Connolly, KR, Thase, ME. Vortioxetine: a New Treatment for Major Depressive Disorder. Expert Opin Pharmacother. 17(3): 421–31. 2016. KQ4E10a, KQ5E10a26679430
149 Cools, O, Hebbrecht, K, . Pharmacotherapy and nutritional supplements for seasonal affective disorders: a systematic review. Expert Opin Pharmacother. 19(11): 1221–1233. 2018. KQ4E10a, KQ5E10a30048159
150 Cooper, PJ, Murray, L, . Controlled trial of the short- and long-term effect of psychological treatment of post-partum depression. I. Impact on maternal mood. Br J Psychiatry. 182: 412–419. 2003. PMID: 12724244. KQ4E3a, KQ5E3a12724244
151 Coto-Lesmes, R, Fernandez-Rodriguez, C, . Acceptance and Commitment Therapy in group format for anxiety and depression. A systematic review. J Affect Disord. 263: 107–120. 2020. KQ4E10a, KQ5E531818766
152 Coughtrey, AE, Pistrang, N. The effectiveness of telephone-delivered psychological therapies for depression and anxiety: A systematic review. J Telemed Telecare. 24(2): 65–74. 2018. PMID: 28038505. 10.1177/1357633X16686547 KQ4E10a, KQ5E528038505
153 Craske, MG, Rose, RD, . Computer-assisted delivery of cognitive behavioral therapy for anxiety disorders in primary-care settings. Depress Anxiety. 26(3): 235–42. 2009. PMID: 19212970. 10.1002/da.20542 KQ4E5, KQ5E519212970
154 Crawford, MJ, Csipke, E, . The effect of referral for brief intervention for alcohol misuse on repetition of deliberate self-harm: an exploratory randomized controlled trial. Psychol Med. 40(11): 1821–1828. 2010. PMID: 20047702. KQ4E2b, KQ5E2b20047702
155 Cremers, G, Taylor, E, . Effectiveness and Acceptability of Low-intensity Psychological Interventions on the Well-being of Older Adults: A Systematic Review. Clin Gerontol. 45(2): 214–234. 2022. KQ4E5, KQ5E10a31507251
156 Cristancho, P, O’Connor, B, . Treatment Emergent Suicidal Ideation in depressed older adults. Int J Geriatr Psychiatry. 32(6): 596–604. 2017. PMID: 27162147. 10.1002/gps.4498 KQ4E3, KQ5E327162147
157 Cristea, IA, Huibers, MJ, . The effects of cognitive behavior therapy for adult depression on dysfunctional thinking: A meta-analysis. Clin Psychol Rev. 42: 62–71. 2015. KQ4E10a, KQ5E10a26319193
158 Cristea, IA, Stefan, S, . The effects of cognitive behavioral therapy are not systematically falling: A revision of Johnsen and Friborg (2015). Psychol Bull. 143(3): 326–340. 2017. KQ4E10a, KQ5E10a28230413
159 Cristea, IA, Kok, RN, . Efficacy of cognitive bias modification interventions in anxiety and depression: meta-analysis. Br J Psychiatry. 206(1): 7–16. 2015. PMID: 25561486. 10.1192/bjp.bp.114.146761 KQ4E10a, KQ5E525561486
160 Crowe, SimonF, Stranks, ElizabethK. The residual medium and long-term cognitive effects of benzodiazepine use: An updated meta-analysis. Archives of Clinical Neuropsychology. 33(7): 901–911. 2018. 10.1093/arclin/acx120 KQ4E5, KQ5E529244060
161 Cuijpers, P, Gentili, C, . Relative effects of cognitive and behavioral therapies on generalized anxiety disorder, social anxiety disorder and panic disorder: A meta-analysis. J Anxiety Disord. 43: 79–89. 2016. KQ4E5, KQ5E527637075
162 Cuijpers, P, Turner, EH, . Comparison of psychotherapies for adult depression to pill placebo control groups: a meta-analysis. Psychol Med. 44(4): 685–95. 2014. KQ4E10a, KQ5E10a23552610
163 Cuijpers, P, van Straten, A, . Is psychotherapy for depression equally effective in younger and older adults? A meta-regression analysis. Int Psychogeriatr. 21(1): 16–24. 2009. KQ4E10a, KQ5E10a19040783
164 Cuijpers, P, van Straten, A, . The effects of psychotherapy for adult depression are overestimated: a meta-analysis of study quality and effect size. Psychol Med. 40(2): 211–23. 2010. KQ4E10a, KQ5E10a19490745
165 Cuijpers, P, Weitz, E, . Gender as predictor and moderator of outcome in cognitive behavior therapy and pharmacotherapy for adult depression: an “individual patient data” meta-analysis. Depress Anxiety. 31(11): 941–51. 2014. KQ4E4, KQ5E425407584
166 Cuijpers, P, Weitz, E, . The effects of psychological treatment of maternal depression on children and parental functioning: a meta-analysis. Eur Child Adolesc Psychiatry. 24(2): 237–45. 2015. KQ4E10a, KQ5E10a25522839
167 Cuijpers, P, Berking, M, . A meta-analysis of cognitive-behavioural therapy for adult depression, alone and in comparison with other treatments. Can J Psychiatry. 58(7): 376–85. 2013. PMID: 23870719. 10.1177/070674371305800702 KQ4E10a, KQ5E10a23870719
168 Cuijpers, P, Cristea, IA, . Component studies of psychological treatments of adult depression: A systematic review and meta-analysis. Psychother Res. 29(1): 15–29. 2019. PMID: 29115185. 10.1080/10503307.2017.1395922 KQ4E4, KQ5E429115185
169 Cuijpers, P, Cristea, IA, . Psychological Treatment of Depression in College Students: A Meta-Analysis. Depress Anxiety. 33(5): 400–14. 2016. PMID: 26682536. 10.1002/da.22461 KQ4E10a, KQ5E10a26682536
170 Cuijpers, P, de Beurs, DP, . The effects of psychotherapy for adult depression on suicidality and hopelessness: a systematic review and meta-analysis. J Affect Disord. 144(3): 183–90. 2013. PMID: 22832172. 10.1016/j.jad.2012.06.025 KQ4E10a, KQ5E10a22832172
171 Cuijpers, P, de Wit, L, . Problem-solving therapy for adult depression: An updated meta-analysis. European Psychiatry: the Journal of the Association of European Psychiatrists. 48: 27–37. 2018. PMID: 29331596. 10.1016/j.eurpsy.2017.11.006 KQ4E10a, KQ5E529331596
172 Cuijpers, P, Donker, T, . Interpersonal Psychotherapy for Mental Health Problems: A Comprehensive Meta-Analysis. Am J Psychiatry. 173(7): 680–7. 2016. PMID: 27032627. 10.1176/appi.ajp.2015.15091141 KQ4E10a, KQ5E10a27032627
173 Cuijpers, P, Driessen, E, . The efficacy of non-directive supportive therapy for adult depression: a meta-analysis. Clin Psychol Rev. 32(4): 280–91. 2012. PMID: 22466509. 10.1016/j.cpr.2012.01.003 KQ4E10a, KQ5E10a22466509
174 Cuijpers, P, Geraedts, AS, . Interpersonal psychotherapy for depression: a meta-analysis. Am J Psychiatry. 168(6): 581–92. 2011. PMID: 21362740. 10.1176/appi.ajp.2010.10101411 KQ4E10a, KQ5E10a21362740
175 Cuijpers, P, Huibers, M, . How much psychotherapy is needed to treat depression? A metaregression analysis. J Affect Disord. 149(1–3): 1–13. 2013. PMID: 23528438. 10.1016/j.jad.2013.02.030 KQ4E10a, KQ5E10a23528438
176 Cuijpers, P, Karyotaki, E, . Managing depression in older age: psychological interventions. Maturitas. 79(2): 160–9. 2014. PMID: 24973043. 10.1016/j.maturitas.2014.05.027 KQ4E10a, KQ5E10a24973043
177 Cuijpers, P, Karyotaki, E, . Psychotherapy for Depression Across Different Age Groups: A Systematic Review and Meta-analysis. JAMA Psychiatry. 77(7): 694–702. 2020. PMID: 32186668. 10.1001/jamapsychiatry.2020.0164 KQ4E10a, KQ5E532186668
178 Cuijpers, P, Karyotaki, E, . The effects of psychotherapies for major depression in adults on remission, recovery and improvement: a meta-analysis. J Affect Disord. 159: 118–26. 2014. PMID: 24679399. 10.1016/j.jad.2014.02.026 KQ4E5, KQ5E524679399
179 Cuijpers, P, Noma, H, . Effectiveness and Acceptability of Cognitive Behavior Therapy Delivery Formats in Adults With Depression: A Network Meta-analysis. JAMA Psychiatry. 76(7): 700–707. 2019. PMID: 30994877. 10.1001/jamapsychiatry.2019.0268 KQ4E10a, KQ5E10a30994877
180 Cuijpers, P, Quero, S, . Psychological Treatment of Depression in Primary Care: Recent Developments. Curr Psychiatry Rep. 21(12): 129. 2019. PMID: 31760505. 10.1007/s11920-019-1117-x KQ4E10a, KQ5E531760505
181 Cuijpers, P, Sijbrandij, M, . Psychological treatment of generalized anxiety disorder: a meta-analysis. Clin Psychol Rev. 34(2): 130–40. 2014. PMID: 24487344. 10.1016/j.cpr.2014.01.002 KQ4E10a, KQ5E10a24487344
182 Cunningham, JEA, Shapiro, CM. Cognitive Behavioural Therapy for Insomnia (CBT-I) to treat depression: A systematic review. J Psychosom Res. 106: 1–12. 2018. KQ4E10a, KQ5E10a29455893
183 Curley, LJM, Duffy, FF, . Suicide Behavior Results From the U.S. Army’s Suicide Prevention Leadership Tool Study: The Behavioral Health Readiness and Suicide Risk Reduction Review (R4). Mil Med. 21: 21. 2022. PMID: 35726499. 10.1093/milmed/usac169 KQ4E7b, KQ5E7b35726499
184 Currier, GW, Fisher, SG, . Mobile crisis team intervention to enhance linkage of discharged suicidal emergency department patients to outpatient psychiatric services: a randomized controlled trial. Acad Emerg Med. 17(1): 36–43. 2010. PMID: 20015106. KQ4E2b, KQ5E2b20015106
185 Curth, NK, Brinck-Claussen, UO, . Collaborative care for depression and anxiety disorders: results and lessons learned from the Danish cluster-randomized Collabri trials. BMC Fam Pract. 21(1): 234. 2020. 10.1186/s12875-020-01299-3 KQ4E8, KQ5E833203365
186 Curtiss, J, Andrews, L, . A meta-analysis of pharmacotherapy for social anxiety disorder: an examination of efficacy, moderators, and mediators. Expert Opin Pharmacother. 18(3): 243–251. 2017. KQ4E10a, KQ5E528110555
187 Cutler, NR, Sramek, JJ, . A double-blind, placebo-controlled study comparing the efficacy and safety of ipsapirone versus lorazepam in patients with generalized anxiety disorder: a prospective multicenter trial. J Clin Psychopharmacol. 13(6): 429–37. 1993. KQ4E7b, KQ5E7b7907097
188 Dafei, M, Mojahed, S, . The effect of cognitive-behavioral counseling of pregnant women with the presence of a spouse on stress, anxiety, and postpartum depression. J Educ Health Promot. 10: 131. 2021. 10.4103/jehp.jehp_926_20 KQ4E2a, KQ5E2a34222506
189 Danborg, PB, Valdersdorf, M, . Long-term harms from previous use of selective serotonin reuptake inhibitors: A systematic review. International Journal of Risk & Safety in Medicine. 30(2): 59–71. 2019. PMID: 30714974. 10.3233/JRS-180046 KQ4E5, KQ5E10a30714974
190 Davidson, JR, DuPont, RL, . Efficacy, safety, and tolerability of venlafaxine extended release and buspirone in outpatients with generalized anxiety disorder. J Clin Psychiatry. 60(8): 528–35. 1999. PMID: 10485635. 10.4088/jcp.v60n0805 KQ4E7b, KQ5E7b10485635
191 Davidson, K, Scott, J, . Therapist competence and clinical outcome in the Prevention of Parasuicide by Manual Assisted Cognitive Behaviour Therapy trial: the POPMACT study. Psychol Med. 34(5): 855–863. 2004. PMID: 15500306. KQ4E2b, KQ5E2b15500306
192 De Jaegere, E, van Landschoot, R, . The online treatment of suicidal ideation: A randomised controlled trial of an unguided web-based intervention. Behav Res Ther. 119: 103406. 2019. KQ4E11, KQ5E1131176889
193 de Vries, YA, de Jonge, P, . Influence of baseline severity on antidepressant efficacy for anxiety disorders: meta-analysis and meta-regression. Br J Psychiatry. 208(6): 515–21. 2016. PMID: 26989093. 10.1192/bjp.bp.115.173450 KQ4E11, KQ5E1126989093
194 de Vries, YA, Roest, AM, . Bias in the reporting of harms in clinical trials of second-generation antidepressants for depression and anxiety: A meta-analysis. Eur Neuropsychopharmacol. 26(11): 1752–1759. 2016. PMID: 27659240. 10.1016/j.euroneuro.2016.09.370 KQ4E5, KQ5E127659240
195 Delgadillo, J, McMillan, D, . Cost-effectiveness of feedback-informed psychological treatment: Evidence from the IAPT-FIT trial. Behav Res Ther. 142(): 103873. 2021. PMID: 33945983. 10.1016/j.brat.2021.103873 KQ4E4a, KQ5E4a33945983
196 Di Simplicio, M, Appiah-Kusi, E, . Imaginator: A Proof-of-Concept Feasibility Trial of a Brief Imagery-Based Psychological Intervention for Young People Who Self-Harm. Suicide Life Threat Behav. e12620. 2020. PMID: 3205713132057131. 10.1111/sltb.12620 KQ4E11, KQ5E11
197 Diamond, GS, Wintersteen, MB, . Attachment-based family therapy for adolescents with suicidal ideation: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 49: 122–131. 2010. KQ4E7a, KQ5E7a20215934
198 Dindo, L, Fiedorowicz, JG, . A randomized controlled trial for symptoms of anxiety and depression: Effects of a 1-day acceptance and commitment training workshop. Annals of Clinical Psychiatry. 33(4): 258–269. 2021. PMID: 34672928. 10.12788/acp.0046 KQ4E7b, KQ5E7b34672928
199 Dodds, TJ. Prescribed Benzodiazepines and Suicide Risk: A Review of the Literature. Prim Care Companion CNS Disord. 19(2): 02. 2017. PMID: 28257172. 10.4088/PCC.16r02037 KQ4E11, KQ5E1128257172
200 Dol, J, Richardson, B, . Impact of mobile health interventions during the perinatal period on maternal psychosocial outcomes: a systematic review. JBI Database Of Systematic Reviews And Implementation Reports. 18(1): 30–55. 2020. KQ4E10a, KQ5E10a
201 Domany, Y, Shelton, RC, . Ketamine for acute suicidal ideation. An emergency department intervention: A randomized, double-blind, placebo-controlled, proof-of-concept trial. Depress Anxiety. 37(3): 224–233. 2020. KQ4E2b, KQ5E2b31733088
202 Domhardt, M, Geslein, H, . Internet- and mobile-based interventions for anxiety disorders: A meta-analytic review of intervention components. Depress Anxiety. 36(3): 213–224. 2019. KQ4E8, KQ5E830450811
203 Donaldson, D, Spirito, A, . Treatment for adolescents following a suicide attempt: results of a pilot trial. J Am Acad Child Adolesc Psychiatry. 44(2): 113–120. 2005. PMID: 15689724. KQ4E7a, KQ5E7a15689724
204 Dong, C, Tang, W, . Psychological nursing intervention combined with family care for elderly patients with generalized anxiety disorder. Acta medica mediterranea. 37(4): 2145–2149. 2021. 10.19193/0393-6384_2021_4_335 KQ4E2a, KQ5E2a
205 Dong, L, Xu, L, . Model-based comparing efficacy of fluoxetine between elderly and non-elderly participants with major depressive disorder. J Affect Disord. 229: 224–230. 2018. PMID: 29324370. 10.1016/j.jad.2017.12.103 KQ4E10a, KQ5E529324370
206 Driessen, E, Hegelmaier, LM, . The efficacy of short-term psychodynamic psychotherapy for depression: A meta-analysis update. Clin Psychol Rev. 42: 1–15. 2015. KQ4E10a, KQ5E10a26281018
207 Duan-Porter, W, Goldstein, K, . Mapping the Evidence: Sex Effects in High-Impact Conditions for Women Veterans – Depression, Diabetes, and Chronic Pain. Department of Veterans Affairs. 09: 09. 2015. KQ4E10a, KQ5E5
208 Duan-Porter, W, Goldstein, KM, . Reporting of Sex Effects by Systematic Reviews on Interventions for Depression, Diabetes, and Chronic Pain. Ann Intern Med. 165(3): 184–93. 2016. PMID: 27111355. 10.7326/M15-2877 KQ4E10a, KQ5E527111355
209 Ducasse, D, Jaussent, I, . Acceptance and Commitment Therapy for the Management of Suicidal Patients: A Randomized Controlled Trial. Psychother Psychosom. 87(4): 211–222. 2018. KQ4E2b, KQ5E2b29874680
210 Ducasse, D, Rene, E, . Acceptance and commitment therapy for management of suicidal patients: a pilot study. Psychother Psychosom. 83(6): 374–6. 2014. KQ4E3, KQ5E325323551
211 Dugas, Mj, Sexton, Ka, . Behavioral Experiments for Intolerance of Uncertainty: a Randomized Clinical Trial for Adults With Generalized Anxiety Disorder. Behav Ther. 53(6): 1147–1160. 2022. 10.1016/j.beth.2022.05.003 KQ4E7b, KQ5E7a36229113
212 Durgam, S, Ruth, A, . Post hoc analyses of anxiety measures in adult patients with generalized anxiety disorder treated with vilazodone. J Pharm Pract. 28(3): 326. 2015. 10.1177/0897190015582204 KQ4E10a, KQ5E10a
213 Ebenfeld, L, Lehr, D, . Evaluating a Hybrid Web-Based Training Program for Panic Disorder and Agoraphobia: Randomized Controlled Trial. J Med Internet Res. 23(3): e20829. 2021. 10.2196/20829 KQ4E7b, KQ5E7b33661121
214 Ebert, DavidD, Van Daele, Tom, . Internet- and mobile-based psychological interventions: Applications, efficacy, and potential for improving mental health: A report of the EFPA E-Health Taskforce. Eur Psychol. 23(2): 167–187. 2018. KQ4E10a, KQ5E5
215 Eckersley, MJ, Sepehripour, AH, . Do selective serotonin reuptake inhibitors increase the risk of bleeding or mortality following coronary artery bypass graft surgery? A meta-analysis of observational studies. Perfusion. 33(6): 415–422. 2018. PMID: 29569518. 10.1177/0267659118765933 KQ4E7, KQ5E729569518
216 Edwards, Anna Rosenberg. Psychotherapy and pharmacotherapy for social anxiety disorder: A comprehensive meta-analysis. Dissertation Abstracts International: Section B: The Sciences and Engineering. 72(4-B): 2433. 2011. KQ4E10a, KQ5E5
217 Egan, SJ, McEvoy, P, . Unguided low intensity cognitive behaviour therapy for anxiety and depression during the COVID-19 pandemic: A randomised trial. Behav Res Ther. 144: 103902. 2021. 10.1016/j.brat.2021.103902 KQ4E6, KQ5E534174706
218 Eggert, LL, Thompson, EA, . Preliminary effects of brief school-based prevention approaches for reducing youth suicide--risk behaviors, depression, and drug involvement. J Child Adolesc Psychiatr Nurs. 15: 48–64. 2002. KQ4E7a, KQ5E7a12083753
219 Eke, AC, Saccone, G, . Selective serotonin reuptake inhibitor (SSRI) use during pregnancy and risk of preterm birth: a systematic review and meta-analysis. BJOG: An International Journal of Obstetrics & Gynaecology. 123(12): 1900–1907. 2016. PMID: 27239775. 10.1111/1471-0528.14144 KQ4E5, KQ5E10a27239775
220 Erickson, DH, Janeck, AS, . A cognitive-behavioral group for patients with various anxiety disorders. Psychiatr Serv. 58(9): 1205–11. 2007. KQ4E7b, KQ5E7b17766567
221 Escobar, KerenM, Gorey, KevinM. Cognitive behavioral interventions for depression among Hispanic people: Promising meta-analytic evidence for deep cultural adaptations. Soc Work Ment Health. 16(6): 746–758. 2018. KQ4E10a, KQ5E5
222 escobar, S. Group Mindfulness Meditation Based Cognitive Therapy Intervention for the Treatment of Late-Life Depression and Anxiety Symptoms: A Randomized Controlled Trial. American journal of geriatric psychiatry. 27(3): S168. 2019. 10.1016/j.jagp.2019.01.121 KQ4E14, KQ5E14
223 Esposito-Smythers, C, Walsh, B, . Working with the suicidal client who also abuses substances. Cognit Behavir Pract. 19: 245–255. 2012. KQ4E7a, KQ5E7a
224 Esposito-Smythers, C, Spirito, A, . Treatment of co-occurring substance abuse and suicidality among adolescents: a randomized trial. J Consult Clin Psychol. 79(6): 728–739. 2011. PMID: 22004303. KQ4E7a, KQ5E7a22004303
225 Evans, K, Morrell, CJ, . Systematic review and meta-analysis of non-pharmacological interventions to reduce the symptoms of mild to moderate anxiety in pregnant women. J Adv Nurs. 74(2): 289–309. 2018. PMID: 28921612. 10.1111/jan.13456 KQ4E10a, KQ5E528921612
226 Evans, K, Tyrer, P, . Manual-assisted cognitive-behaviour therapy (MACT): a randomized controlled trial of a brief intervention with bibliotherapy in the treatment of recurrent deliberate self-harm. Psychol Med. 29(1): 19–25. 1999. PMID: 10077290. KQ4E2b, KQ5E2b10077290
227 Evans, VC, Alamian, G, . The Effects of Newer Antidepressants on Occupational Impairment in Major Depressive Disorder: A Systematic Review and Meta-Analysis of Randomized Controlled Trials. CNS Drugs. 30(5): 405–17. 2016. PMID: 27113464. 10.1007/s40263-016-0334-7 KQ4E11, KQ5E1127113464
228 Ezenwaji, CO, Aloh, HE, . Managing social anxiety among undergraduate adult education and extra-mural studies students: An intervention study. Medicine (Baltimore). 100(42): e27596. 2021. PMID: 34678909. 10.1097/MD.0000000000027596 KQ4E2a, KQ5E2a34678909
229 Farah, WH, Alsawas, M, . Non-pharmacological treatment of depression: a systematic review and evidence map. Evidence Based Medicine. 21(6): 214–221. 2016. KQ4E10a, KQ5E10a27836921
230 Farrer, L, Gulliver, A, . Technology-based interventions for mental health in tertiary students: systematic review. J Med Internet Res. 15(5): e101. 2013. KQ4E10a, KQ5E523711740
231 Fava, GA, Benasi, G, . Withdrawal Symptoms after Serotonin-Noradrenaline Reuptake Inhibitor Discontinuation: Systematic Review. Psychother Psychosom. 87(4): 195–203. 2018. PMID: 30016772. 10.1159/000491524 KQ4E11, KQ5E1130016772
232 Feigenbaum, JD, Fonagy, P, . A real-world study of the effectiveness of DBT in the UK National Health Service. Br J Clin Psychol. 51(2): 121–41. 2012. 10.1111/j.2044-8260.2011.02017.x KQ4E7a, KQ5E7a22574799
233 De Feijo, Mello M. Effectiveness of alprazolam in the treatment of panic disorder: a systematic review. Rev Bras Med. 63(11): 606–610. 2006. KQ4E10a, KQ5E10a
234 Fenger, M, Lindschou, J, . Internet-based therapy with FearFighter for anxiety disorders: a randomised clinical trial. Nord J Psychiatry. 74(7): 518–524. 2020. KQ4E7b, KQ5E7b32401099
235 Fereidouni, Zhila, Behnammoghadam, Mohammad, . The Effect of Eye Movement Desensitization and Reprocessing (EMDR) on the severity of suicidal thoughts in patients with major depressive disorder: A randomized controlled trial. Neuropsychiatric Disease and Treatment 15: 2459–2466. 2019. 10.2147/NDT.S210757 KQ4E2a, KQ5E2a31695382
236 Fiedorowicz, JG, Dindo, L, . One-day acceptance and commitment therapy (ACT) workshop improves anxiety but not vascular function or inflammation in adults with moderate to high anxiety levels in a randomized controlled trial. Gen Hosp Psychiatry. 73: 64–70. 2021. PMID: 34619441. 10.1016/j.genhosppsych.2021.09.009 KQ4E7b, KQ5E7b34619441
237 Field, T. Prenatal Depression Risk Factors, Developmental Effects and Interventions: A Review. Journal Of Pregnancy And Child Health. 4(1). 2017. KQ4E10a, KQ5E5
238 Firth, J, Torous, J, . Can smartphone mental health interventions reduce symptoms of anxiety? A meta-analysis of randomized controlled trials. J Affect Disord. 218: 15–22. 2017. PMID: 28456072. 10.1016/j.jad.2017.04.046 KQ4E10a, KQ5E10a28456072
239 Firth, J, Torous, J, . The efficacy of smartphone-based mental health interventions for depressive symptoms: a meta-analysis of randomized controlled trials. World Psychiatry. 16(3): 287–298. 2017. PMID: 28941113. 10.1002/wps.20472 KQ4E10a, KQ5E528941113
240 Fish, J, Brimson, J, . Mindfulness Interventions Delivered by Technology Without Facilitator Involvement: What Research Exists and What Are the Clinical Outcomes?. Mindfulness (N Y). 7(5): 1011–1023. 2016. PMID: 27642370. KQ4E10a, KQ5E527642370
241 Fisher, J, Tran, T, . Gender-informed psycho-educational programme to promote respectful relationships and reduce postpartum common mental disorders among primiparous women: long-term follow-up of participants in a community-based cluster randomised controlled trial. Global Mental Health. 5: e30. 2018. PMID: 30455965. 10.1017/gmh.2018.20 KQ4E8, KQ5E830455965
242 Fitton, CA, Steiner, MFC, . In utero exposure to antidepressant medication and neonatal and child outcomes: a systematic review. Acta Psychiatr Scand. 141(1): 21–33. 2020. KQ4E5, KQ5E10a31648376
243 Fitzpatrick, Kathleen Kara, Witte, TracyK, . Randomized controlled trial of a brief problem-orientation intervention for suicidal ideation. Behav Ther. 36(4): 323–333. 2005. PMID: None. KQ4E2, KQ5E2
244 Fletcher, S, Spittal, MJ, . Clinical efficacy of a Decision Support Tool (Link-me) to guide intensity of mental health care in primary practice: a pragmatic stratified randomised controlled trial. The Lancet. Psychiatry. 8(3): 202–214. 2021. 10.1016/S2215-0366(20)30517-4 KQ4E8, KQ5E833571453
245 Flint, J, Cuijpers, P, . Is there an excess of significant findings in published studies of psychotherapy for depression?. Psychol Med. 45(2): 439–46. 2015. PMID: 25062429. 10.1017/S0033291714001421 KQ4E10a, KQ5E525062429
246 Florea, I, Loft, H, . The effect of vortioxetine on overall patient functioning in patients with major depressive disorder. Brain Behav. 7(3): e00622. 2017. PMID: 28293465. 10.1002/brb3.622 KQ4E10a, KQ5E10a28293465
247 Fodor, LA, Georgescu, R, . Efficacy of cognitive bias modification interventions in anxiety and depressive disorders: a systematic review and network meta-analysis. The Lancet. Psychiatry. 7(6): 506–514. 2020. KQ4E10a, KQ5E532445689
248 Fodor, LA, Cotet, CD, . The effectiveness of virtual reality based interventions for symptoms of anxiety and depression: A meta-analysis. Sci Rep. 8(1): 10323. 2018. PMID: 29985400. 10.1038/s41598-018-28113-6 KQ4E10a, KQ5E10a29985400
249 Fonagy, P. The effectiveness of psychodynamic psychotherapies: An update. World Psychiatry. 14(2): 137–50. 2015. PMID: 26043322. 10.1002/wps.20235 KQ4E10a, KQ5E526043322
250 Forkmann, T, Brakemeier, EL, . The Effects of Mindfulness-Based Cognitive Therapy and Cognitive Behavioral Analysis System of Psychotherapy added to Treatment as Usual on suicidal ideation in chronic depression: Results of a randomized-clinical trial. J Affect Disord. 200: 51–7. 2016. KQ4E3a, KQ5E3a27128357
251 Forkmann, T, Wichers, M, . Effects of mindfulness-based cognitive therapy on self-reported suicidal ideation: results from a randomised controlled trial in patients with residual depressive symptoms. Compr Psychiatry. 55(8): 1883–90. 2014. PMID: 25218397. 10.1016/j.comppsych.2014.08.043 KQ4E3a, KQ5E3a25218397
252 Forneris, CA, Nussbaumer-Streit, B, . Psychological therapies for preventing seasonal affective disorder. Cochrane Database of Systematic Reviews. 5: CD011270. 2019. PMID: 31124141. 10.1002/14651858.CD011270.pub3 KQ4E7, KQ5E731124141
253 Francis, SEB, Shawyer, F, . Group Mindfulness-Integrated Cognitive Behavior Therapy (MiCBT) Reduces Depression and Anxiety and Improves Flourishing in a Transdiagnostic Primary Care Sample Compared to Treatment-as-Usual: A Randomized Controlled Trial. Frontiers in psychiatry Frontiers Research Foundation. 13: 815170. 2022. PMID: 35711582. 10.3389/fpsyt.2022.815170 KQ4E7, KQ5E735711582
254 Freeman, MP, Szpunar, MJ, . Pregnancy outcomes after first-trimester exposure to buspirone: prospective longitudinal outcomes from the MGH National Pregnancy Registry for Psychiatric Medications. Arch Womens Ment Health. 25(5): 923–928. 2022. PMID: 35840767. 10.1007/s00737-022-01250-8 KQ4E3, KQ5E435840767
255 Fu, DJ, Ionescu, DF, . Esketamine Nasal Spray for Rapid Reduction of Major Depressive Disorder Symptoms in Patients Who Have Active Suicidal Ideation With Intent: Double-Blind, Randomized Study (ASPIRE I). J Clin Psychiatry. 81(3): 12. 2020. KQ4E2b, KQ5E2b
256 Fu, Dj, Canuso, Cm, . P.323 Esketamine nasal spray for rapid reduction of major depressive disorder symptoms in patients at imminent risk for suicide: aspire-1 study. Eur Neuropsychopharmacol. 29: S231–s232. 2019. 10.1016/j.euroneuro.2019.09.343 KQ4E14, KQ5E14
257 Fu, J, Chen, Y. The efficacy and safety of 5 mg/d Vortioxetine compared to placebo for major depressive disorder: A meta-analysis. Psychopharmacology (Berl). 232(1): 7–16. 2015. KQ4E10a, KQ5E10a24871704
258 Fu, J, Peng, L, . The efficacy and safety of multiple doses of vortioxetine for generalized anxiety disorder: a meta-analysis. Neuropsychiatr Dis Treat. 12: 951–9. 2016. PMID: 27143896. 10.2147/NDT.S104050 KQ4E10a, KQ5E10a27143896
259 Furukawa, TA, Maruo, K, . Initial severity of major depression and efficacy of new generation antidepressants: individual participant data meta-analysis. Acta Psychiatr Scand. 137(6): 450–458. 2018. KQ4E10a, KQ5E10a29611870
260 Furukawa, TA, Salanti, G, . No benefit from flexible titration above minimum licensed dose in prescribing antidepressants for major depression: systematic review. Acta Psychiatr Scand. 141(5): 401–409. 2020. KQ4E10a, KQ5E10a31891415
261 Furukawa, TA, Salanti, G, . No benefit from flexible titration above minimum licensed dose in prescribing antidepressants for major depression: systematic review. Acta Psychiatr Scand. 141(5): 401–409. 2020. KQ4E10a, KQ5E10a31891415
262 Furukawa, TA, Weitz, ES, . Initial severity of depression and efficacy of cognitive-behavioural therapy: individual-participant data meta-analysis of pill-placebo-controlled trials. Br J Psychiatry. 210(3): 190–196. 2017. PMID: 28104735. 10.1192/bjp.bp.116.187773 KQ4E10a, KQ5E528104735
263 Gabilondo, A, Aristegi, E, . Prevention of Suicidal Behavior with Telemedicine in Patients with a Recent Suicide Attempt: Is a 6-month Intervention Long Enough?. Suicide Life Threat Behav. 50(1): 211–219. 2020. PMID: 31343761. 10.1111/sltb.12576 KQ4E2b, KQ5E2b31343761
264 Gartlehner, G, Wagner, G, . Pharmacological and non-pharmacological treatments for major depressive disorder: review of systematic reviews. BMJ Open. 7(6): e014912. 2017. PMID: 28615268. 10.1136/bmjopen-2016-014912 KQ4E10a, KQ5E528615268
265 Gautam, M, Kaur, M, . Levomilnacipran: More of the Same?. Prim Care Companion CNS Disord. 21(5): 05. 2019. KQ4E10a, KQ5E10a
266 Gebara, MA, Lipsey, KL, . Cause or Effect? Selective Serotonin Reuptake Inhibitors and Falls in Older Adults: A Systematic Review. American Journal of Geriatric Psychiatry. 23(10): 1016–28. 2015. PMID: 25586602. 10.1016/j.jagp.2014.11.004 KQ4E5, KQ5E10a25586602
267 Gebhardt, S, Heinzel-Gutenbrunner, M, . Pain Relief in Depressive Disorders: A Meta-Analysis of the Effects of Antidepressants. J Clin Psychopharmacol. 36(6): 658–668. 2016. PMID: 27753729. KQ4E5, KQ5E527753729
268 Gelenberg, AJ, Lydiard, RB, . Efficacy of venlafaxine extended-release capsules in nondepressed outpatients with generalized anxiety disorder: A 6-month randomized controlled trial. Jama. 283(23): 3082–8. 2000. PMID: 10865302. 10.1001/jama.283.23.3082 KQ4E7b, KQ5E7b10865302
269 Gentile, S, Fusco, ML. Placental and fetal effects of antenatal exposure to antidepressants or untreated maternal depression. Journal of Maternal-Fetal & Neonatal Medicine. 30(10): 1189–1199. 2017. KQ4E10a, KQ5E10a27379818
270 Gentile, S. Early pregnancy exposure to selective serotonin reuptake inhibitors, risks of major structural malformations, and hypothesized teratogenic mechanisms. Expert Opin Drug Metab Toxicol. 11(10): 1585–97. 2015. KQ4E5, KQ5E10a26135630
271 Ghahramanlou-Holloway, M, Bhar, SS, . Changes in problem-solving appraisal after cognitive therapy for the prevention of suicide. Psychol Med. 42: 1185–1193. 2012. PMID: 22008384. KQ4E2b, KQ5E2b22008384
272 Gidding, LG, Spigt, M, . PsyScan e-tool to support diagnosis and management of psychological problems in general practice: a randomised controlled trial. Br J Gen Pract. 68(666): e18–e27. 2018. PMID: 29255109. 10.3399/bjgp17X694109 KQ4E8, KQ5E829255109
273 Gjerdingen, D, Crow, S, . Stepped care treatment of postpartum depression: impact on treatment, health, and work outcomes. J Am Board Fam Med. 22(5): 473–482. 2009. PMID: 19734392. KQ4E3a, KQ5E3a19734392
274 Goldberg, SB, Tucker, RP, . Mindfulness-based cognitive therapy for the treatment of current depressive symptoms: a meta-analysis. Cogn Behav Ther. 48(6): 445–462. 2019. PMID: 30732534. 10.1080/16506073.2018.1556330 KQ4E10a, KQ5E10a30732534
275 Goldney, RD. Immediate post intervention effects of two brief youth suicide prevention interventions. Suicide Life Threat Behav. 32(4): 454–456. 2002. PMID: 12501969. KQ4E7a, KQ5E7a12501969
276 Gomez, AF, Barthel, AL, . Comparing the efficacy of benzodiazepines and serotonergic anti-depressants for adults with generalized anxiety disorder: a meta-analytic review. Expert Opin Pharmacother. 19(8): 883–894. 2018. PMID: 29806492. 10.1080/14656566.2018.1472767 KQ4E10a, KQ5E529806492
277 Goncalves, DC, Byrne, GJ. Interventions for generalized anxiety disorder in older adults: systematic review and meta-analysis. J Anxiety Disord. 26(1): 1–11. 2012. PMID: 21907538. 10.1016/j.janxdis.2011.08.010 KQ4E10a, KQ5E10a21907538
278 Goodman, JH, Prager, J, . Perinatal Dyadic Psychotherapy for postpartum depression: a randomized controlled pilot trial. Arch Womens Ment Health. 18(3): 493–506. 2014. PMID: 25522664. KQ4E3a, KQ5E3a25522664
279 Gotink, RA, Chu, P, . Standardised mindfulness-based interventions in healthcare: an overview of systematic reviews and meta-analyses of RCTs. PLoS ONE [Electronic Resource]. 10(4): e0124344. 2015. PMID: 25881019. 10.1371/journal.pone.0124344 KQ4E10a, KQ5E525881019
280 Gould, Ce, Kok, Bc, . Video-Delivered Relaxation Intervention Reduces Late-Life Anxiety: a Pilot Randomized Controlled Trial. American journal of geriatric psychiatry. 27(5): 514–525. 2019. 10.1016/j.jagp.2018.12.018 KQ4E7b, KQ5E7b
281 Gould, CE, Kok, BC, . Video-Delivered Relaxation Intervention Reduces Late-Life Anxiety: A Pilot Randomized Controlled Trial. American Journal of Geriatric Psychiatry. 27(5): 514–525. 2019. 10.1016/j.jagp.2018.12.018 KQ4E7b, KQ5E7b
282 Gramaglia, C, Gambaro, E, . Increased Risk of Metabolic Syndrome in Antidepressants Users: A Mini Review. Frontiers in psychiatry Frontiers Research Foundation. 9: 621. 2018. PMID: 30546325. 10.3389/fpsyt.2018.00621 KQ4E5, KQ5E530546325
283 Gratz, KL, Tull, MT, . Randomized controlled trial and uncontrolled 9-month follow-up of an adjunctive emotion regulation group therapy for deliberate self-harm among women with borderline personality disorder. Psychol Med. 44(10): 2099–112. 2014. KQ4E1a, KQ5E1a23985088
284 Green, JM, Wood, AJ, . Group therapy for adolescents with repeated self harm: randomised controlled trial with economic evaluation. BMJ. 342: d682. 2011. PMID: 21459975. KQ4E7a, KQ5E7a21459975
285 Green, SM, Donegan, E, . Cognitive Behavior Therapy for Women With Generalized Anxiety Disorder in the Perinatal Period: Impact on Problematic Behaviors. Behav Ther. 52(4): 907–916. 2021. 10.1016/j.beth.2020.11.004 KQ4E7b, KQ5E7b34134830
286 Green, SM, Donegan, E, . Cognitive behavioral therapy for perinatal anxiety: A randomized controlled trial. Aust N Z J Psychiatry. 54(4): 423–432. 2020. PMID: 31957479. 10.1177/0004867419898528 KQ4E7b, KQ5E7b31957479
287 Greenfield, B, Larson, C, . A rapid-response outpatient model for reducing hospitalization rates among suicidal adolescents. Psychiatr Serv. 53: 1574–1579. 2002. KQ4E7a, KQ5E7a12461218
288 Gregory, Virgil Lee, Jr. Cognitive-behavioral therapy for anxious symptoms in persons of African descent: A meta-analysis. J Soc Serv Res. 45(1): 87–101. 2019. KQ4E7, KQ5E5
289 Gregory, VirgilL, Jr. Cognitive-behavioral therapy for depressive symptoms in persons of African descent: A meta-analysis. J Soc Serv Res. 42(1): 113–129. 2016. KQ4E7, KQ5E7
290 Grigoriadis, S, Graves, L, . Benzodiazepine Use During Pregnancy Alone or in Combination With an Antidepressant and Congenital Malformations: Systematic Review and Meta-Analysis. J Clin Psychiatry. 80(4): 09. 2019. KQ4E5, KQ5E10a
291 Grimholt, TineK, Jacobsen, Dag, . Effect of Systematic Follow-Up by General Practitioners after Deliberate Self-Poisoning: A Randomised Controlled Trial. PLoS One. 10(12): e0143934. 2015. 10.1371/journal.pone.0143934 KQ4E2b, KQ5E2b26629812
292 Guan, HB, Wei, Y, . Prenatal Selective Serotonin Reuptake Inhibitor Use and Associated Risk for Gestational Hypertension and Preeclampsia: A Meta-Analysis of Cohort Studies. Journal of Women’s Health. 27(6): 791–800. 2018. PMID: 29489446. 10.1089/jwh.2017.6642 KQ4E5, KQ5E10a29489446
293 Guthrie, E, Kapur, N, . Predictors of outcome following brief psychodynamic-interpersonal therapy for deliberate self-poisoning. Aust N Z J Psychiatry. 37(5): 532–536. 2003. PMID: 14511080. KQ4E2b, KQ5E2b14511080
294 Guthrie, E, Kapur, N, . Randomised controlled trial of brief psychological intervention after deliberate self poisoning. BMJ. 323(7305): 135–138. 2001. PMID: 11463679. KQ4E2b, KQ5E2b11463679
295 Gutierrez, PM, Johnson, L, . Pilot study of the Collaborative Assessment and Management of Suicidality-Group. Suicide Life Threat Behav. 52(2): 244–255. 2022. PMID: 34780099. 10.1111/sltb.12817 KQ4E11, KQ5E1134780099
296 Gysin-Maillart, A, Schwab, S, . A Novel Brief Therapy for Patients Who Attempt Suicide: A 24-months Follow-Up Randomized Controlled Study of the Attempted Suicide Short Intervention Program (ASSIP). PLoS Medicine / Public Library of Science. 13(3): e1001968. 2016. PMID: 26930055. 10.1371/journal.pmed.1001968 KQ4E2b, KQ5E2b26930055
297 Gysin-Maillart, A, Soravia, L, . Attempted suicide short intervention program influences coping among patients with a history of attempted suicide. J Affect Disord. 264: 393–399. 2020. 10.1016/j.jad.2019.11.059 KQ4E2b, KQ5E2b31759660
298 Hacker, T, Stone, P, . Acceptance and commitment therapy - Do we know enough? Cumulative and sequential meta-analyses of randomized controlled trials. J Affect Disord. 190: 551–565. 2016. KQ4E10a, KQ5E526571105
299 Hackett, D, Haudiquet, V, . A method for controlling for a high placebo response rate in a comparison of venlafaxine XR and diazepam in the short-term treatment of patients with generalised anxiety disorder. Eur Psychiatry. 18(4): 182–7. 2003. KQ4E7b, KQ5E7b12814852
300 Hadjistavropoulos, HD, Peynenburg, V, . A randomized factorial trial of internet-delivered cognitive behavioural therapy: An 8-week program with or without extended support and booster lesson. Internet Interventions. 27: 100499. 2022. PMID: 35198410. 10.1016/j.invent.2022.100499 KQ4E4, KQ5E435198410
301 Hall, J, Kellett, S, . Efficacy of Cognitive Behavioral Therapy for Generalized Anxiety Disorder in Older Adults: Systematic Review, Meta-Analysis, and Meta-Regression. American Journal of Geriatric Psychiatry. 24(11): 1063–1073. 2016. PMID: 27687212. 10.1016/j.jagp.2016.06.006 KQ4E10a, KQ5E10a27687212
302 Hamilton, J, Saxon, D, . A randomized, controlled pilot study of cognitive analytic therapy for stressed pregnant women with underlying anxiety and depression in a routine health service setting. Clin Psychol Psychother. 28(2): 394–408. 2021. 10.1002/cpp.2520 KQ4E11, KQ5E1132997871
303 Harada, E, Tokuoka, H, . Is duloxetine’s effect on painful physical symptoms in depression an indirect result of improvement of depressive symptoms? Pooled analyses of three randomized controlled trials. Pain. 157(3): 577–84. 2016. PMID: 26882344. 10.1097/j.pain.0000000000000406 KQ4E5, KQ5E526882344
304 Harada, Eiji, Schacht, Alexander, . Efficacy comparison of duloxetine and SSRIs at doses approved in Japan. Neuropsychiatric Disease and Treatment 11: 115–23. 2015. KQ4E10a, KQ5E525624763
305 Harnod, T, Wang, YC, . Association between use of short-acting benzodiazepines and migraine occurrence: a nationwide population-based case-control study. Curr Med Res Opin. 33(3): 511–517. 2017. KQ4E3, KQ5E727893291
306 Hassanian, MoghaddamH, Sarjami, S, . Postcards in Persia: randomised controlled trial to reduce suicidal behaviours 12 months after hospital-treated self-poisoning. Br J Psychiatry. 198: 309–316. 2011. PMID: 21343332. KQ4E2a, KQ5E2a21343332
307 Hatcher, S, Sharon, C, . Problem-solving therapy for people who present to hospital with self-harm: Zelen randomised controlled trial. Br J Psychiatry. 199: 310–316. 2011. PMID: 21816868. KQ4E2b, KQ5E2b21816868
308 Hatcher, S, Sharon, C, . The ACCESS study: Zelen randomised controlled trial of a package of care for people presenting to hospital after self-harm. Br J Psychiatry. 206(3): 229–36. 2015. PMID: 25614531. 10.1192/bjp.bp.113.135780 KQ4E2b, KQ5E2b25614531
309 Hawton, K, McKeown, S, . Evaluation of out-patient counselling compared with general practitioner care following overdoses. Psychol Med. 17(3): 751–761. 1987. PMID: 2819914. KQ4E2b, KQ5E2b2819914
310 Hayes, RM, Wu, P, .. Maternal antidepressant use and adverse outcomes: a cohort study of 228,876 pregnancies.[Erratum appears in Am J Obstet Gynecol. 2013 Apr;208(4):326]. Am J Obstet Gynecol. 207(1): 49–49. 2012. PMID: 22727349. KQ4E3, KQ5E3a22727349
311 Hazell, PL, Martin, G, . Group therapy for repeated deliberate self-harm in adolescents: failure of replication of a randomized trial. J Am Acad Child Adolesc Psychiatry. 48: 662–670. 2009. KQ4E7a, KQ5E7a19454922
312 He, H, Xiang, Y, . Comparative efficacy and acceptability of first-line drugs for the acute treatment of generalized anxiety disorder in adults: A network meta-analysis. J Psychiatr Res. 118: 21–30. 2019. KQ4E10a, KQ5E10a31473564
313 He, H, Wang, W, . Efficacy and tolerability of different doses of three new antidepressants for treating major depressive disorder: A PRISMA-compliant meta-analysis. J Psychiatr Res. 96: 247–259. 2018. PMID: 29127931. 10.1016/j.jpsychires.2017.10.018 KQ4E10a, KQ5E10a29127931
314 Health Quality, Ontario. Internet-Delivered Cognitive Behavioural Therapy for Major Depression and Anxiety Disorders: A Health Technology Assessment. Ont Health Technol Assess Ser. 19(6): 1–199. 2019. KQ4E10a, KQ5E10a
315 Health Quality, Ontario. Psychotherapy for Major Depressive Disorder and Generalized Anxiety Disorder: A Health Technology Assessment. Ont Health Technol Assess Ser. 17(15): 1–167. 2017. KQ4E10a, KQ5E5
316 Healy, D, Le Noury, J, . Links between serotonin reuptake inhibition during pregnancy and neurodevelopmental delay/spectrum disorders: A systematic review of epidemiological and physiological evidence. International Journal of Risk & Safety in Medicine. 28(3): 125–41. 2016. PMID: 27662278. 10.3233/JRS-160726 KQ4E5, KQ5E10a27662278
317 Heeren, A, Mogoase, C, . Attention bias modification for social anxiety: A systematic review and meta-analysis. Clin Psychol Rev. 40: 76–90. 2015. KQ4E10a, KQ5E526080314
318 Heh, SS, Fu, YY. Effectiveness of informational support in reducing the severity of postnatal depression in Taiwan. J Adv Nurs. 42(1): 30–36. 2003. PMID: 12641809. KQ4E3a, KQ5E3a12641809
319 Heinz, MV, Price, GD, . Association of Selective Serotonin Reuptake Inhibitor Use With Abnormal Physical Movement Patterns as Detected Using a Piezoelectric Accelerometer and Deep Learning in a Nationally Representative Sample of Noninstitutionalized Persons in the US. JAMA Network Open. 5(4): e225403. 2022. PMID: 35389502. 10.1001/jamanetworkopen.2022.5403 KQ4E5, KQ5E535389502
320 Heller, HM, Hoogendoorn, AW, . The Effectiveness of a Guided Internet-Based Tool for the Treatment of Depression and Anxiety in Pregnancy (MamaKits Online): Randomized Controlled Trial. J Med Internet Res. 22(3): e15172. 2020. KQ4E7b, KQ5E7b32202505
321 Heller, Hm, Hoogendoorn, Aw, . The effectiveness of a guided Internet-based tool for the treatment of depression and anxiety in pregnancy (Mamakits online): randomized controlled trial. J Med Internet Res. 22(3). 2020. 10.2196/15172 KQ4E7b, KQ5E7b
322 Heller, HM, Ravelli, ACJ, . Increased postpartum haemorrhage, the possible relation with serotonergic and other psychopharmacological drugs: a matched cohort study. BMC Pregnancy Childbirth. 17(1): 166. 2017. PMID: 28577352. 10.1186/s12884-017-1334-4 KQ4E3, KQ5E3a28577352
323 Hellerstein, DJ, Flaxer, J. Vilazodone for the treatment of major depressive disorder: an evidence-based review of its place in therapy. Core Evid. 10: 49–62. 2015. PMID: 25945081. 10.2147/CE.S54075 KQ4E10a, KQ5E10a25945081
324 Hengartner, MP, Jakobsen, JC, . Efficacy of new-generation antidepressants assessed with the Montgomery-Asberg Depression Rating Scale, the gold standard clinician rating scale: A meta-analysis of randomised placebo-controlled trials. PLoS ONE [Electronic Resource]. 15(2): e0229381. 2020. PMID: 32101579. 10.1371/journal.pone.0229381 KQ4E10a, KQ5E532101579
325 Henssler, J, Kurschus, M, . Long-Term Acute-Phase Treatment With Antidepressants, 8 Weeks and Beyond: A Systematic Review and Meta-Analysis of Randomized, Placebo-Controlled Trials. J Clin Psychiatry. 79(1). 2018. PMID: 28068463. 10.4088/JCP.15r10545 KQ4E10a, KQ5E10a28068463
326 Hieronymus, F, Lisinski, A, . Multiple possible inaccuracies cast doubt on a recent report suggesting selective serotonin reuptake inhibitors to be toxic and ineffective. Acta Neuropsychiatr. 30(5): 244–250. 2018. PMID: 28718394. 10.1017/neu.2017.23 KQ4E5, KQ5E10a28718394
327 Hill, LL, Lauzon, VL, . Depression, antidepressants and driving safety. Injury Epidemiology. 4(1): 10. 2017. PMID: 28367591. 10.1186/s40621-017-0107-x KQ4E11, KQ5E1128367591
328 Hirsch, CR, Krahe, C, . Internet-delivered interpretation training reduces worry and anxiety in individuals with generalized anxiety disorder: A randomized controlled experiment. J Consult Clin Psychol. 89(7): 575–589. 2021. PMID: 34383532. 10.1037/ccp0000660 KQ4E7b, KQ5E7b34383532
329 Hoermann, S, McCabe, KL, . Application of Synchronous Text-Based Dialogue Systems in Mental Health Interventions: Systematic Review. J Med Internet Res. 19(8): e267. 2017. PMID: 28784594. 10.2196/jmir.7023 KQ4E10a, KQ5E528784594
330 Hofmann, SG, Curtiss, J, . Effect of treatments for depression on quality of life: a meta-analysis. Cogn Behav Ther. 46(4): 265–286. 2017. PMID: 28440699. 10.1080/16506073.2017.1304445 KQ4E10a, KQ5E528440699
331 Hofmann, SG, Wu, JQ, . Effect of pharmacotherapy for anxiety disorders on quality of life: a meta-analysis. Qual Life Res. 23(4): 1141–53. 2014. PMID: 24241771. 10.1007/s11136-013-0573-8 KQ4E10a, KQ5E10a24241771
332 Hogberg, GN, Bremberg, SG. Antidepressant medication might increase the risk of self-harm injuries: findings in 17 OECD countries. Eur J Public Health. 29(2): 365–367. 2019. KQ4E3, KQ5E530590506
333 Holden, JM, Sagovsky, R, . Counselling in a general practice setting: controlled study of health visitor intervention in treatment of postnatal depression. BMJ. 298(6668): 223–226. 1989. PMID: 2493868. KQ4E3a, KQ5E3a2493868
334 Holdsworth, Nicholas, Paxton, Roger, . Parallel evaluations of new guidance materials for anxiety and depression in primary care. J Ment Health. 5(2): 195–208. 1996. PMID: 9606206380. 10.1080/09638239650037081 KQ4E4, KQ5E5
335 Honey, KL, Bennett, P, . A brief psycho-educational group intervention for postnatal depression. Br J Clin Psychol. 41(Pt 4): 405–409. 2002. PMID: 12437794. KQ4E3a, KQ5E3a12437794
336 Hooley, JillM, Fox, KathrynR, . Novel online daily diary interventions for non-suicidal self-injury: A randomized controlled trial. Communicating with, about, and through self-harm: Scarred discourse. (): 37–56. 2021. KQ4E1, KQ5E1
337 Hooven, C, Walsh, E, . Promoting CARE: Including parents in youth suicide prevention. Fam Community Health. 35(3): 225–235. 2012. PMID: 22617413. KQ4E7a, KQ5E7a22617413
338 Hopkinson, MD, Reavell, J, . Cognitive Behavioral Therapy for Depression, Anxiety, and Stress in Caregivers of Dementia Patients: A Systematic Review and Meta-Analysis. Gerontologist. 59(4): e343–e362. 2019. PMID: 29529290. 10.1093/geront/gnx217 KQ4E7, KQ5E729529290
339 Horowitz, JA, Bell, M, . Promoting responsiveness between mothers with depressive symptoms and their infants. J Nurs Scholarsh. 33(4): 323–329. 2001. PMID: 11775301. KQ4E3a, KQ5E3a11775301
340 Huang, AX, Delucchi, K, . A systematic review and meta-analysis of psychotherapy for late-life depression. American Journal of Geriatric Psychiatry. 23(3): 261–73. 2015. PMID: 24856580. 10.1016/j.jagp.2014.04.003 KQ4E10a, KQ5E524856580
341 Huang, J, Nigatu, YT, . Interventions for common mental health problems among university and college students: A systematic review and meta-analysis of randomized controlled trials. J Psychiatr Res. 107: 1–10. 2018. KQ4E10a, KQ5E10a30300732
342 Huang, Qunlian, Zhong, Xiaoyan, . Efficacy and safety of multiple doses of levomilnacipran extended-release for the treatment of major depressive disorder. Neuropsychiatric Disease and Treatment 12: 2707–2714. 2016. KQ4E10a, KQ5E10a27822042
343 Huang, R, Yang, D, . The short- and long-term effectiveness of mother-infant psychotherapy on postpartum depression: A systematic review and meta-analysis. J Affect Disord. 260: 670–679. 2020. KQ4E10a, KQ5E531550613
344 Huguet, A, Miller, A, . A systematic review and meta-analysis on the efficacy of Internet-delivered behavioral activation. J Affect Disord. 235: 27–38. 2018. KQ4E10a, KQ5E10a29649708
345 Huguet, A, Rao, S, . A Systematic Review of Cognitive Behavioral Therapy and Behavioral Activation Apps for Depression. PLoS ONE [Electronic Resource]. 11(5): e0154248. 2016. PMID: 27135410. 10.1371/journal.pone.0154248 KQ4E10a, KQ5E527135410
346 Huybrechts, KF, Palmsten, K, . Antidepressant use in pregnancy and the risk of cardiac defects. N Engl J Med. 370(25): 2397–2407. 2014. PMID: 24941178. KQ4E3, KQ5E3a24941178
347 Ilgen, Ma, Price, Am, . Encouraging the use of the Veterans Crisis Line among high-risk Veterans: a randomized trial of a Crisis Line Facilitation intervention. J Psychiatr Res. 154: 159–166. 2022. 10.1016/j.jpsychires.2022.07.047 KQ4E2b, KQ5E2b35940001
348 Ionescu, Df, Canuso, Cm, . P.607 Esketamine nasal spray for rapid reduction of major depressive disorder symptoms in patients at imminent risk for suicide: ASPIRE-2 study. Eur Neuropsychopharmacol. 29: S414–s415. 2019. 10.1016/j.euroneuro.2019.09.591 KQ4E14, KQ5E14
349 Ionescu, DF, Fu, DJ, . Esketamine Nasal Spray for Rapid Reduction of Depressive Symptoms in Patients With Major Depressive Disorder Who Have Active Suicide Ideation With Intent: Results of a Phase 3, Double-Blind, Randomized Study (ASPIRE II). International Journal of Neuropsychopharmacology. 24(1): 22–31. 2021. 10.1093/ijnp/pyaa068 KQ4E2b, KQ5E2b32861217
350 Jacobsen, PL, Mahableshwarkar, AR, . Treatment-emergent sexual dysfunction in randomized trials of vortioxetine for major depressive disorder or generalized anxiety disorder: a pooled analysis. CNS Spectr. 21(5): 367–378. 2016. PMID: 26575433. KQ4E5, KQ5E10a26575433
351 Jakobsen, JC, Gluud, C, . Should antidepressants be used for major depressive disorder?. BMJ Evidence based Medicine. 25(4): 130. 2019. PMID: 31554608. 10.1136/bmjebm-2019-111238 KQ4E11, KQ5E1131554608
352 Jakubovski, E, Johnson, JA, . Systematic review and meta-analysis: Dose-response curve of SSRIs and SNRIs in anxiety disorders. Depress Anxiety. 36(3): 198–212. 2019. KQ4E11, KQ5E1130479005
353 Jakubovski, E, Varigonda, AL, . Systematic Review and Meta-Analysis: Dose-Response Relationship of Selective Serotonin Reuptake Inhibitors in Major Depressive Disorder. Am J Psychiatry. 173(2): 174–83. 2016. PMID: 26552940. 10.1176/appi.ajp.2015.15030331 KQ4E11, KQ5E1126552940
354 Jarde, A, Morais, M, . Does non-pharmacological therapy for antenatal depression reduce risks for the infant?. Arch Womens Ment Health. 19(3): 549–552. 2016. KQ4E4, KQ5E426395260
355 Jayasekara, R, Procter, N, . Cognitive behavioural therapy for older adults with depression: a review. J Ment Health. 24(3): 168–71. 2015. KQ4E10a, KQ5E525358075
356 Jayasinghe, N, Finkelstein-Fox, L, . Systematic Review of the Clinical Application of Exposure Techniques to Community-Dwelling Older Adults with Anxiety. Clin Gerontol. 40(3): 141–158. 2017. PMID: 28452667. 10.1080/07317115.2017.1291546 KQ4E10a, KQ5E528452667
357 Jensen, HM, Gron, R, . The effects of maternal depression and use of antidepressants during pregnancy on risk of a child small for gestational age. Psychopharmacology (Berl). 228(2): 199–205. 2013. PMID: 23455598. KQ4E3, KQ5E3a23455598
358 Ji, JL, Baee, S, . Multi-session online interpretation bias training for anxiety in a community sample. Behav Res Ther. 142: 103864. 2021. PMID: 33966880. 10.1016/j.brat.2021.103864 KQ4E7b, KQ5E7b33966880
359 Jia, Y, Wang, X, . Relaxation Therapy for Depression: An Updated Meta-analysis. J Nerv Ment Dis. 208(4): 319–328. 2020. KQ4E10a, KQ5E532221187
360 Jia, Y, Li, M, . Morita therapy for depression in adults: A systematic review and meta-analysis. Psychiatry Res. 269: 763–771. 2018. PMID: 30380592. 10.1016/j.psychres.2018.08.108 KQ4E10a, KQ5E10a30380592
361 Johnsen, TJ, Friborg, O. The effects of cognitive behavioral therapy as an anti-depressive treatment is falling: A meta-analysis. Psychol Bull. 141(4): 747–68. 2015. KQ4E10a, KQ5E10a25961373
362 Johnsen, TomJ, Thimm, JensC. A meta-analysis of group cognitive–behavioral therapy as an antidepressive treatment: Are we getting better?. Canadian Psychology/Psychologie canadienne. 59(1): 15–30. 2018. KQ4E10a, KQ5E10a
363 Johnson, LL, O’Connor, SS, . Evaluation of Structured Assessment and Mediating Factors of Suicide-Focused Group Therapy for Veterans Recently Discharged from Inpatient Psychiatry. Archives of Suicide Research. 23(1): 15–33. 2019. KQ4E2b, KQ5E2b29220609
364 Jones, Shannon Leigh. An efficacy trial of therapist-assisted internet-delivered cognitive-behaviour therapy for older adults with generalized anxiety. Dissertation Abstracts International: Section B: The Sciences and Engineering. 82(7-B): No Pagination Specified. 2021. KQ4E7b, KQ5E7b
365 Joseph, KS, Sheehy, O, . Can drug effects explain the recent temporal increase in atonic postpartum haemorrhage? Paediatr Perinat Epidemiol. 29(3): 220–31. 2015. PMID: 25847112. 10.1111/ppe.12190 KQ4E3, KQ5E3a25847112
366 Josephine, K, Josefine, L, . Internet- and mobile-based depression interventions for people with diagnosed depression: A systematic review and meta-analysis. J Affect Disord. 223: 28–40. 2017. KQ4E10a, KQ5E528715726
367 Jou, Joan. Personality traits as predictors of treatment response in a randomized controlled trial of cognitive behavioral therapy for social anxiety disorder. Dissertation Abstracts International: Section B: The Sciences and Engineering. 79(1-B(E)): No Pagination Specified. 2018. KQ4E1, KQ5E1
368 Kamenov, K, Twomey, C, . The efficacy of psychotherapy, pharmacotherapy and their combination on functioning and quality of life in depression: a meta-analysis. Psychol Med. 47(3): 414–425. 2017. PMID: 27780478. 10.1017/S0033291716002774 KQ4E10a, KQ5E10a27780478
369 Kampmann, IL, Emmelkamp, PM, . Meta-analysis of technology-assisted interventions for social anxiety disorder. J Anxiety Disord. 42: 71–84. 2016. PMID: 27376634. 10.1016/j.janxdis.2016.06.007 KQ4E10a, KQ5E10a27376634
370 Kapur, N, Gunnell, D, . Messages from Manchester: pilot randomised controlled trial following self-harm. Br J Psychiatry. 203(1): 73–4. 2013. PMID: 23818535. 10.1192/bjp.bp.113.126425 KQ4E2b, KQ5E2b23818535
371 Karyotaki, E, Smit, Y, . The Long-Term Efficacy of Acute-Phase Psychotherapy for Depression: A Meta-Analysis of Randomized Trials. Depress Anxiety. 33(5): 370–83. 2016. KQ4E10a, KQ5E527000501
372 Kasper, S, Herman, B, . Efficacy of pregabalin and venlafaxine-XR in generalized anxiety disorder: results of a double-blind, placebo-controlled 8-week trial. Int Clin Psychopharmacol. 24(2): 87–96. 2009. KQ4E7b, KQ5E7b21456104
373 Kayrouz, R, Dear, BF, . Meta-analysis of the efficacy and acceptability of cognitive-behavioural therapy for Arab adult populations experiencing anxiety, depression or post-traumatic stress disorder. Cogn Behav Ther. 47(5): 412–430. 2018. KQ4E10a, KQ5E10a29714106
374 Kelson, J, Rollin, A, . Internet-Delivered Acceptance and Commitment Therapy for Anxiety Treatment: Systematic Review. J Med Internet Res. 21(1): e12530. 2019. KQ4E10a, KQ5E10a30694201
375 Kemp, JoshuaJ. Examining dropout rates during cognitive and exposure-based treatments for anxiety: A meta-analytic approach. Dissertation Abstracts International: Section B: The Sciences and Engineering. 78(3-B(E)): No Pagination Specified. 2017. KQ4E5, KQ5E10a
376 Kessler, RC, Chalker, SA, . A Preliminary Precision Treatment Rule for Remission of Suicide Ideation. Suicide Life Threat Behav. 50(2): 558–572. 2020. 10.1111/sltb.12609 KQ4E5, KQ5E531814153
377 Khoo, AL, Zhou, HJ, . Network Meta-Analysis and Cost-Effectiveness Analysis of New Generation Antidepressants. CNS Drugs. 29(8): 695–712. 2015. PMID: 26293743. 10.1007/s40263-015-0267-6 KQ4E10a, KQ5E10a26293743
378 Kilbourne, AM, Li, D, . Pilot randomized trial of a cross-diagnosis collaborative care program for patients with mood disorders. Depress Anxiety. 30(2): 116–22. 2013. KQ4E3a, KQ5E3a23077119
379 Kim, HS, Kim, EJ. Effects of Relaxation Therapy on Anxiety Disorders: A Systematic Review and Meta-analysis. Arch Psychiatr Nurs. 32(2): 278–284. 2018. PMID: 29579524. 10.1016/j.apnu.2017.11.015 KQ4E10a, KQ5E10a29579524
380 King, CA, Klaus, N, . The Youth-Nominated Support Team-Version II for suicidal adolescents: A randomized controlled intervention trial. J Consult Clin Psychol. 77(5): 880–893. 2009. PMID: 19803568. KQ4E7a, KQ5E7a19803568
381 Kirkham, JG, Choi, N, . Meta-analysis of problem solving therapy for the treatment of major depressive disorder in older adults. Int J Geriatr Psychiatry. 31(5): 526–35. 2016. KQ4E10a, KQ5E526437368
382 Kishi, T, Sakuma, K, . Vortioxetine vs placebo in major depressive disorder: A systematic review and meta-analysis of double-blind, randomized, placebo-controlled, phase 3 trials in Japan. Psychiatry Clin Neurosci. 74(5): 330–332. 2020. KQ4E10a, KQ5E532175646
383 Kishita, N, Hammond, L, . Which interventions work for dementia family carers? An updated systematic review of randomized controlled trials of carer interventions. Int Psychogeriatr. 30(11): 1679–1696. 2018. KQ4E7, KQ5E730017008
384 Kishita, N, Laidlaw, K. Cognitive behaviour therapy for generalized anxiety disorder: Is CBT equally efficacious in adults of working age and older adults?. Clin Psychol Rev. 52: 124–136. 2017. KQ4E10a, KQ5E528119196
385 Kishita, N, Takei, Y, . A meta-analysis of third wave mindfulness-based cognitive behavioral therapies for older people. Int J Geriatr Psychiatry. 32(12): 1352–1361. 2017. KQ4E10a, KQ5E527862293
386 Kjaersgaard, MI, Parner, ET, . Prenatal antidepressant exposure and risk of spontaneous abortion - a population-based study. PLoS One. 8(8): e72095. 2013. PMID: 24015208. KQ4E3, KQ5E3a24015208
387 Kladnitski, N, Smith, J, . Transdiagnostic internet-delivered CBT and mindfulness-based treatment for depression and anxiety: A randomised controlled trial. Internet Interventions. 20: 100310. 2020. 10.1016/j.invent.2020.100310 KQ4E7b, KQ5E7b32140427
388 Klainin-Yobas, P, Oo, WN, . Effects of relaxation interventions on depression and anxiety among older adults: a systematic review. Aging Ment Health. 19(12): 1043–55. 2015. KQ4E10a, KQ5E525574576
389 Kleiboer, Annet, Donker, Tara, . A randomized controlled trial on the role of support in internet-based problem solving therapy for depression and anxiety. Behav Res Ther. 72: 63–71. 2015. KQ4E7b, KQ5E7b26188373
390 Koesters, M, Ostuzzi, G, . Vortioxetine for depression in adults. Cochrane Database of Systematic Reviews. 7: CD011520. 2017. PMID: 28677828. 10.1002/14651858.CD011520.pub2 KQ4E10a, KQ5E10a28677828
391 Kolovos, S, Kleiboer, A, . Effect of psychotherapy for depression on quality of life: meta-analysis. Br J Psychiatry. 209(6): 460–468. 2016. PMID: 27539296. 10.1192/bjp.bp.115.175059 KQ4E10a, KQ5E10a27539296
392 Koponen, H, Allgulander, C, . Efficacy of duloxetine for the treatment of generalized anxiety disorder: implications for primary care physicians. Prim Care Companion J Clin Psychiatry. 9(2): 100–7. 2007. PMID: 17607331. 10.4088/pcc.v09n0203 KQ4E7b, KQ5E7b17607331
393 Koszycki, D, Guérin, E, . Randomized trial of cognitive behaviour group therapy and a mindfulness-based intervention for social anxiety disorder: preliminary findings. Clin Psychol Psychother. 28(1): 200–218. 2021. 10.1002/cpp.2502 KQ4E4, KQ5E432818325
394 Kozinszky, Z, Dudas, RB, . Can a brief antepartum preventive group intervention help reduce postpartum depressive symptomatology?. Psychother Psychosom. 81(2): 98–107. 2012. PMID: 22261988. KQ4E3a, KQ5E3a22261988
395 Kronstein, PD, Ishida, E, . Summary of findings from the FDA regulatory science forum on measuring sexual dysfunction in depression trials. J Clin Psychiatry. 76(8): 1050–9. 2015. PMID: 26335083. 10.4088/JCP.14r09699 KQ4E10a, KQ5E10a26335083
396 Kumar, V, Sattar, Y, . The Effectiveness of Internet-Based Cognitive Behavioral Therapy in Treatment of Psychiatric Disorders. Cureus. 9(8): e1626. 2017. PMID: 29098136. 10.7759/cureus.1626 KQ4E10a, KQ5E529098136
397 Kuo, JR, Zeifman, RJ, . The moderating effects of anger suppression and anger expression on cognitive behavioral group therapy and mindfulness-based stress reduction among individuals with social anxiety disorder. J Affect Disord. 285: 127–135. 2021. 10.1016/j.jad.2021.02.022 KQ4E7b, KQ5E7b33647580
398 Lahoz, T, Hvid, M, . Preventing repetition of attempted suicide-III. The Amager Project, 5-year follow-up of a randomized controlled trial. Nord J Psychiatry. 70(7): 547–53. 2016. KQ4E2b, KQ5E2b27187267
399 Lamb, T, Pachana, NA, . Update of Recent Literature on Remotely Delivered Psychotherapy Interventions for Anxiety and Depression. Telemedicine Journal & E-Health. 25(8): 671–677. 2019. PMID: 30300082. 10.1089/tmj.2018.0079 KQ4E10a, KQ5E530300082
400 Lang, ArielJ. Brief intervention for co-occurring anxiety and depression in primary care: A pilot study. Int J Psychiatry Med. 33(2): 141–154. 2003. 10.2190/4FM9-T915-L7E3-EFMX KQ4E6, KQ5E512968827
401 Laoutidis, ZG, Kioulos, KT. Desvenlafaxine for the acute treatment of depression: a systematic review and meta-analysis. Pharmacopsychiatry. 48(6): 187–99. 2015. PMID: 26205685. 10.1055/s-0035-1555879 KQ4E10a, KQ5E10a26205685
402 Lassen, D, Ennis, ZN, . First-Trimester Pregnancy Exposure to Venlafaxine or Duloxetine and Risk of Major Congenital Malformations: A Systematic Review. Basic Clin Pharmacol Toxicol. 118(1): 32–6. 2016. PMID: 26435496. 10.1111/bcpt.12497 KQ4E5, KQ5E10a26435496
403 Lattie, EG, Adkins, EC, . Digital Mental Health Interventions for Depression, Anxiety, and Enhancement of Psychological Well-Being Among College Students: Systematic Review. J Med Internet Res. 21(7): e12869. 2019. KQ4E10a, KQ5E10a31333198
404 Lau, Y, Htun, TP, . Therapist-Supported Internet-Based Cognitive Behavior Therapy for Stress, Anxiety, and Depressive Symptoms Among Postpartum Women: A Systematic Review and Meta-Analysis. J Med Internet Res. 19(4): e138. 2017. KQ4E10a, KQ5E528455276
405 Laurenzi, CA, Gordon, S, . Psychosocial interventions targeting mental health in pregnant adolescents and adolescent parents: a systematic review. Reprod Health. 17(1): 65. 2020. PMID: 32410710. 10.1186/s12978-020-00913-y KQ4E7, KQ5E732410710
406 Lauterbach, E, Felber, W, . Adjunctive lithium treatment in the prevention of suicidal behaviour in depressive disorders: a randomised, placebo-controlled, 1-year trial. Acta Psychiatr Scand. 118(6): 469–479. 2008. PMID: 18808400. KQ4E2b, KQ5E2b18808400
407 Lee, EW, Denison, FC, . Web-based interventions for prevention and treatment of perinatal mood disorders: a systematic review. BMC Pregnancy Childbirth. 16: 38. 2016. PMID: 26928898. 10.1186/s12884-016-0831-1 KQ4E10a, KQ5E10a26928898
408 Lee, M, Ryoo, JH, . Effective interventions for depressive symptoms among caregivers of people with dementia: A systematic review and meta-analysis. Dementia. 19(7): 2368–2398. 2020. PMID: 30638044. 10.1177/1471301218822640 KQ4E10a, KQ5E530638044
409 Leger, J, Letourneau, N. New mothers and postpartum depression: a narrative review of peer support intervention studies. Health Soc Care Community. 23(4): 337–48. 2015. PMID: 25346377. 10.1111/hsc.12125 KQ4E10a, KQ5E525346377
410 Lenz, A, Hall, Joseph, . Meta-analysis of group mindfulness-based cognitive therapy for decreasing symptoms of acute depression. Journal for Specialists in Group Work. 41(1): 44–70. 2016. KQ4E10a, KQ5E5
411 Lepola, U, Bergtholdt, B, . Controlled-release paroxetine in the treatment of patients with social anxiety disorder. J Clin Psychiatry. 65(2): 222–9. 2004. KQ4E7b, KQ5E7b15003077
412 Lepola, UM, Wade, AG, . A controlled, prospective, 1-year trial of citalopram in the treatment of panic disorder. J Clin Psychiatry. 59(10): 528–34. 1998. KQ4E7b, KQ5E7b9818634
413 Lever Taylor, B, Cavanagh, K, . The Effectiveness of Mindfulness-Based Interventions in the Perinatal Period: A Systematic Review and Meta-Analysis. PLoS ONE [Electronic Resource]. 11(5): e0155720. 2016. PMID: 27182732. 10.1371/journal.pone.0155720 KQ4E10a, KQ5E527182732
414 Li, G, Wang, X, . The efficacy and safety of 10 mg vortioxetine in the treatment of major depressive disorder: a meta-analysis of randomized controlled trials. Neuropsychiatr Dis Treat. 12: 523–31. 2016. PMID: 27013879. 10.2147/NDT.S103173 KQ4E5, KQ5E10a27013879
415 Li, SYH, Bressington, D. The effects of mindfulness-based stress reduction on depression, anxiety, and stress in older adults: A systematic review and meta-analysis. Int J Ment Health Nurs. 28(3): 635–656. 2019. KQ4E10a, KQ5E10a30656813
416 Li, W, Li, W, . Appraisal of the methodological quality and summary of the findings of systematic reviews on the relationship between SSRIs and suicidality. Shanghai Jingshen Yixue. 26(5): 248–58. 2014. PMID: 25477718. 10.11919/j.issn.1002-0829.214080 KQ4E5, KQ5E10a25477718
417 Li, X, Hou, Y, . Efficacy and tolerability of paroxetine in adults with social anxiety disorder: A meta-analysis of randomized controlled trials. Medicine (Baltimore). 99(14): e19573. 2020. PMID: 32243377. 10.1097/MD.0000000000019573 KQ4E10a, KQ5E10a32243377
418 Li, X, Zhu, L, . Efficacy and tolerability of short-term duloxetine treatment in adults with generalized anxiety disorder: A meta-analysis. PLoS ONE [Electronic Resource]. 13(3): e0194501. 2018. PMID: 29558528. 10.1371/journal.pone.0194501 KQ4E10a, KQ5E10a29558528
419 Li, X, Zhu, L, . Short-term efficacy and tolerability of venlafaxine extended release in adults with generalized anxiety disorder without depression: A meta-analysis. PLoS ONE [Electronic Resource]. 12(10): e0185865. 2017. PMID: 28982121. 10.1371/journal.pone.0185865 KQ4E10a, KQ5E10a28982121
420 Liebowitz, MR, Asnis, G, . A double-blind, placebo-controlled, parallel-group, flexible-dose study of venlafaxine extended release capsules in adult outpatients with panic disorder. J Clin Psychiatry. 70(4): 550–61. 2009. KQ4E7b, KQ5E7b19358784
421 Liebowitz, MR, Careri, J, . Vortioxetine versus placebo in major depressive disorder comorbid with social anxiety disorder. Depress Anxiety. 34(12): 1164–1172. 2017. KQ4E7b, KQ5E7b29166552
422 Liebowitz, MR, Mangano, RM, . A randomized controlled trial of venlafaxine extended release in generalized social anxiety disorder. J Clin Psychiatry. 66(2): 238–47. 2005. KQ4E7b, KQ5E7b15705011
423 Liebowitz, MR, Gelenberg, AJ, . Venlafaxine extended release vs placebo and paroxetine in social anxiety disorder. Arch Gen Psychiatry. 62(2): 190–8. 2005. PMID: 15699296. 10.1001/archpsyc.62.2.190 KQ4E7b, KQ5E7b15699296
424 Lin, PZ, Xue, JM, . Effectiveness of self-help psychological interventions for treating and preventing postpartum depression: a meta-analysis. Arch Womens Ment Health. 21(5): 491–503. 2018. KQ4E10a, KQ5E10a29616334
425 Lin, YC, Liu, SI, . Brief Cognitive-based Psychosocial Intervention and Case Management for Suicide Attempters Discharged from the Emergency Department in Taipei, Taiwan: A Randomized Controlled Study. Suicide & Life Threatening Behavior. 50(3): 688–705. 2020. PMID: 32067261. 10.1111/sltb.12626 KQ4E2b, KQ5E2b32067261
426 Linardon, J, Cuijpers, P, . The efficacy of app-supported smartphone interventions for mental health problems: a meta-analysis of randomized controlled trials. World Psychiatry. 18(3): 325–336. 2019. PMID: 31496095. 10.1002/wps.20673 KQ4E7, KQ5E731496095
427 Linde, K, Kriston, L, . Efficacy and acceptability of pharmacological treatments for depressive disorders in primary care: systematic review and network meta-analysis. Ann Fam Med. 13(1): 69–79. 2015. PMID: 25583895. 10.1370/afm.1687 KQ4E10a, KQ5E10a25583895
428 Linde, K, Rucker, G, . Comparative effectiveness of psychological treatments for depressive disorders in primary care: network meta-analysis. BMC Fam Pract. 16: 103. 2015. PMID: 26286590. 10.1186/s12875-015-0314-x KQ4E10a, KQ5E10a26286590
429 Linde, K, Sigterman, K, . Effectiveness of psychological treatments for depressive disorders in primary care: systematic review and meta-analysis. Ann Fam Med. 13(1): 56–68. 2015. PMID: 25583894. 10.1370/afm.1719 KQ4E10a, KQ5E525583894
430 Lindegaard, T, Seaton, F, . Internet-based cognitive behavioural therapy for depression and anxiety among Arabic-speaking individuals in Sweden: a pilot randomized controlled trial. Cogn Behav Ther. 50(1): 47–66. 2021. 10.1080/16506073.2020.1771414 KQ4E7b, KQ5E7b32603632
431 Linehan, MM, Armstrong, HE, . Cognitive-behavioral treatment of chronically parasuicidal borderline patients. Mindfulness: Clinical applications of mindfulness and acceptance: Specific interventions for psychiatric, behavioural, and physical health conditions. III (pp. 90–102). xii, 648. 2017. KQ4E14, KQ5E14
432 Linehan, MM, Armstrong, HE, . Cognitive-behavioral treatment of chronically parasuicidal borderline patients. Arch Gen Psychiatry. 48(12): 1060–1064. 1991. PMID: 1845222. KQ4E11, KQ5E111845222
433 Linetzky, M, Pergamin-Hight, L, . Quantitative evaluation of the clinical efficacy of attention bias modification treatment for anxiety disorders. Depress Anxiety. 32(6): 383–91. 2015. KQ4E10a, KQ5E525708991
434 Liu, Haining, Li, Xianwen, . Effects of cognitive bias modification on social anxiety: A meta-analysis. PLoS ONE 12(4). 2017. KQ4E10a, KQ5E5
435 Liu, X, Li, X, . Efficacy and tolerability of fluvoxamine in adults with social anxiety disorder: A meta-analysis. Medicine (Baltimore). 97(28): e11547. 2018. PMID: 29995828. 10.1097/MD.0000000000011547 KQ4E10a, KQ5E10a29995828
436 Lo, HermanH, Ng, Siu Man, . Evaluating compassion-mindfulness therapy for recurrent anxiety and depression: A randomized control trial. Res Soc Work Pract. 25(6): 715–725. 2015. KQ4E7, KQ5E7
437 Locher, C, Kossowsky, J, . Moderation of antidepressant and placebo outcomes by baseline severity in late-life depression: A systematic review and meta-analysis. J Affect Disord. 181: 50–60. 2015. PMID: 25917293. 10.1016/j.jad.2015.03.062 KQ4E10a, KQ5E10a25917293
438 Londborg, PD, Wolkow, R, . Sertraline in the treatment of panic disorder. A multi-site, double-blind, placebo-controlled, fixed-dose investigation. Br J Psychiatry. 173: 54–60. 1998. KQ4E7b, KQ5E7b9850204
439 Loo Gee, B, Griffiths, KM, . Effectiveness of mobile technologies delivering Ecological Momentary Interventions for stress and anxiety: a systematic review. Journal of the American Medical Informatics Association. 23(1): 221–9. 2016. PMID: 25997643. 10.1093/jamia/ocv043 KQ4E10a, KQ5E525997643
440 Lopez-Lopez, JA, Davies, SR, . The process and delivery of CBT for depression in adults: a systematic review and network meta-analysis. Psychol Med. 49(12): 1937–1947. 2019. PMID: 31179960. 10.1017/S003329171900120X KQ4E10a, KQ5E531179960
441 Loughnan, S. Regaining MUMentum: findings from two randomized controlled trials evaluating brief internet cognitive behavioral therapy for perinatal distress, anxiety, and depression. Arch Womens Ment Health. 22(5): 682. 2019. KQ4E7b, KQ5E7b
442 Loughnan, SA, Butler, C, . A randomised controlled trial of ‘MUMentum postnatal’: Internet-delivered cognitive behavioural therapy for anxiety and depression in postpartum women. Behav Res Ther. 116: 94–103. 2019. KQ4E14, KQ5E1430877878
443 Loughnan, SA, Joubert, AE, . Internet-delivered psychological interventions for clinical anxiety and depression in perinatal women: a systematic review and meta-analysis. Arch Womens Ment Health. 22(6): 737–750. 2019. KQ4E10a, KQ5E10a31101993
444 Loughnan, SA, Sie, A, . A randomized controlled trial of ‘MUMentum Pregnancy’: Internet-delivered cognitive behavioral therapy program for antenatal anxiety and depression. J Affect Disord. 243: 381–390. 2019. KQ4E7b, KQ5E7b30266030
445 Loughnan, SA, Wallace, M, . A systematic review of psychological treatments for clinical anxiety during the perinatal period. Arch Womens Ment Health. 21(5): 481–490. 2018. KQ4E10a, KQ5E10a29368048
446 Louik, C, Kerr, S, . First-trimester exposure to bupropion and risk of cardiac malformations. Pharmacoepidemiol Drug Saf. 23(10): 1066–1075. 2014. PMID: 24920293. KQ4E3, KQ5E3a24920293
447 Lowndes, TA, Egan, SJ, . Efficacy of brief guided self-help cognitive behavioral treatment for perfectionism in reducing perinatal depression and anxiety: a randomized controlled trial. Cogn Behav Ther. 48(2): 106–120. 2019. KQ4E7b, KQ5E7b30003839
448 Lucock, M, Kirby, R, . A pragmatic randomized controlled trial of a guided self-help intervention versus a waiting list control in a routine primary care mental health service. Br J Clin Psychol. 50(3): 298–309. 2011. KQ4E11, KQ5E1121810108
449 Luo, Y, Chaimani, A, . Visualizing the evolution of evidence: Cumulative network meta-analyses of new generation antidepressants in the last 40 years. Res Synth Methods. 12(1): 74–85. 2021. PMID: 32352639. 10.1002/jrsm.1413 KQ4E10a, KQ5E10a32352639
450 Lupattelli, Angela, Spigset, Olav, . Risk of vaginal bleeding and postpartum hemorrhage after use of antidepressants in pregnancy: A study from the Norwegian Mother and Child Cohort Study. J Clin Psychopharmacol. 34(1): 143–148. 2014. PMID: 24135843. KQ4E3, KQ5E3a24135843
451 Maguire, PN, Clark, GI, . The efficacy of cognitive behavior therapy for the treatment of perinatal anxiety symptoms: A preliminary meta-analysis. J Anxiety Disord. 60: 26–34. 2018. KQ4E10a, KQ5E530388545
452 Mahableshwarkar, A, Jacobsen, P, . The Safety and tolerability profile of vortioxetine in the treatment of patients with major depressive disorder aged 65 years and older. American journal of geriatric psychiatry. 22(3 suppl. 1): S143–s144. 2014. KQ4E14, KQ5E14
453 Mahableshwarkar, AR, Affinito, J, . Suicidal ideation and behavior in adults with major depressive disorder treated with vortioxetine: post hoc pooled analyses of randomized, placebo-controlled, short-term and open-label, long-term extension trials. CNS Spectr. 25(3): 352–362. 2020. PMID: 31199210. 10.1017/S109285291900097X KQ4E5, KQ5E10a31199210
454 Mahmoodi, M, Bakhtiyari, M, . The comparison between CBT focused on perfectionism and CBT focused on emotion regulation for individuals with depression and anxiety disorders and dysfunctional perfectionism: a randomized controlled trial. Behav Cogn Psychother. 1–18. 2020. 10.1017/S1352465820000909 KQ4E2a, KQ5E2a
455 Maksimowski, Michael, Qayyum, Zheala. Initial severity and antidepressant benefits: A meta-analysis of data submitted to the food and drug administration. 50 studies every psychiatrist should know. 167–172. 2018. KQ4E10a, KQ5E5
456 Mallery, L, MacLeod, T, . Systematic review and meta-analysis of second-generation antidepressants for the treatment of older adults with depression: questionable benefit and considerations for frailty. BMC Geriatr. 19(1): 306. 2019. PMID: 31718566. 10.1186/s12877-019-1327-4 KQ4E10a, KQ5E10a31718566
457 Maples-Keller, JL, Bunnell, BE, . The Use of Virtual Reality Technology in the Treatment of Anxiety and Other Psychiatric Disorders. Harv Rev Psychiatry. 25(3): 103–113. 2017. PMID: 28475502. 10.1097/HRP.0000000000000138 KQ4E10a, KQ5E528475502
458 Marasinghe, RB, Edirippulige, S, . Effect of mobile phone-based psychotherapy in suicide prevention: a randomized controlled trial in Sri Lanka. J Telemed Telecare. 18(3): 151–5. 2012. PMID: 22362830. KQ4E2b, KQ5E2b22362830
459 Marchesi, C, Ossola, P, . Clinical management of perinatal anxiety disorders: A systematic review. J Affect Disord. 190: 543–550. 2016. PMID: 26571104. 10.1016/j.jad.2015.11.004 KQ4E10a, KQ5E10a26571104
460 Maslej, MM, Furukawa, TA, . Individual Differences in Response to Antidepressants: A Meta-analysis of Placebo-Controlled Randomized Clinical Trials. JAMA Psychiatry. 78(5): 490–497. 2021. PMID: 33595620. 10.1001/jamapsychiatry.2020.4564 KQ4E5, KQ5E533595620
461 Maslej, MM, Furukawa, TA, . Individual Differences in Response to Antidepressants: A Meta-analysis of Placebo-Controlled Randomized Clinical Trials. JAMA Psychiatry. 77(6): 607–617. 2020. PMID: 32074273. 10.1001/jamapsychiatry.2019.4815 KQ4E13, KQ5E1332074273
462 Mathiasen, K, Riper, H, . Internet-based CBT for social phobia and panic disorder in a specialised anxiety clinic in routine care: Results of a pilot randomised controlled trial. Internet Interventions. 4: 92–98. 2016. PMID: 30135794. 10.1016/j.invent.2016.03.001 KQ4E11, KQ5E1130135794
463 Mayo-Wilson, E, Montgomery, P. Media-delivered cognitive behavioural therapy and behavioural therapy (self-help) for anxiety disorders in adults. Cochrane Database of Systematic Reviews. (9). 2013. 10.1002/14651858.CD005330.pub4 KQ4E8, KQ5E8
464 McAuliffe, C, McLeavey, BC, . Group problem-solving skills training for self-harm: randomised controlled trial. Br J Psychiatry. 204: 383–90. 2014. PMID: 24434070. 10.1192/bjp.bp.111.101816 KQ4E2b, KQ5E2b24434070
465 McCall, WV, Benca, RM, . Reducing Suicidal Ideation Through Insomnia Treatment (REST-IT): A Randomized Clinical Trial. Am J Psychiatry. 176(11): 957–965. 2019. PMID: 31537089. 10.1176/appi.ajp.2019.19030267 KQ4E4, KQ5E431537089
466 McDonagh, M, Matthews, A, . Treatment of depression during pregnancy and the postpartum period: A Systematic Review and Meta-Analysis. Obstetrics & Gynecology 124(3):p 526–534. 10.1097/AOG.0000000000000410. 2014. KQ4E5, KQ5E10a25004304
467 McFarquhar, T, Luyten, P, . Changes in interpersonal problems in the psychotherapeutic treatment of depression as measured by the Inventory of Interpersonal Problems: A systematic review and meta-analysis. J Affect Disord. 226: 108–123. 2018. KQ4E10a, KQ5E528968563
468 McGregor, M, Coghlan, M, . The effect of physician-based cognitive behavioural therapy among pregnant women with depressive symptomatology: a pilot quasi-experimental trial. Early Interv Psychiatry. 8(4): 348–357. 2013. PMID: 23855406. KQ4E3, KQ5E3a23855406
469 McIntyre, RS, Harrison, J, . The Effects of Vortioxetine on Cognitive Function in Patients with Major Depressive Disorder: A Meta-Analysis of Three Randomized Controlled Trials. International Journal of Neuropsychopharmacology. 19(10): 15. 2016. PMID: 27312740. 10.1093/ijnp/pyw055 KQ4E10a, KQ5E10a27312740
470 Meeker, AS, Herink, MC, . The safety and efficacy of vortioxetine for acute treatment of major depressive disorder: a systematic review and meta-analysis. Syst Rev. 4: 21. 2015. PMID: 25874839. 10.1186/s13643-015-0001-y KQ4E10a, KQ5E10a25874839
471 Meltzer-Brody, S, Colquhoun, H, . Efficacy of Brexanolone Injection in Subjects With Postpartum Depression With and Without Baseline Antidepressant Therapy: insights From an Integrated Analysis of Three Pivotal Trials. Biol Psychiatry. 85(10): S241. 2019. 10.1016/j.biopsych.2019.03.610 KQ4E14, KQ5E14
472 Menon, V, Rajan, TM, . Psychotherapeutic Applications of Mobile Phone-based Technologies: A Systematic Review of Current Research and Trends. Indian J Psychol Med. 39(1): 4–11. 2017. PMID: 28250552. 10.4103/0253-7176.198956 KQ4E10a, KQ5E10a28250552
473 Messiah, A, Notredame, CE, . Combining green cards, telephone calls and postcards into an intervention algorithm to reduce suicide reattempt (AlgoS): P-hoc analyses of an inconclusive randomized controlled trial. PLoS ONE [Electronic Resource]. 14(2): e0210778. 2019. PMID: 30707710. 10.1371/journal.pone.0210778 KQ4E2b, KQ5E2b30707710
474 Meuldijk, D, Carlier, IV, . The clinical effectiveness of concise cognitive behavioral therapy with or without pharmacotherapy for depressive and anxiety disorders; a pragmatic randomized controlled equivalence trial in clinical practice. Contemp Clin Trials. 47: 131–8. 2016. PMID: 26762883. 10.1016/j.cct.2015.12.021 KQ4E4a, KQ5E4a26762883
475 Meyers, MA, Groh, CJ, . Depression screening and treatment in uninsured urban patients. Journal of the American Board of Family Medicine: JABFM. 27(4): 520–9. 2014. PMID: 25002006. 10.3122/jabfm.2014.04.130254 KQ4E3a, KQ5E3a25002006
476 Mezzacappa, A, Lasica, PA, . Risk for Autism Spectrum Disorders According to Period of Prenatal Antidepressant Exposure: A Systematic Review and Meta-analysis. JAMA Pediatr. 171(6): 555–563. 2017. PMID: 28418571. 10.1001/jamapediatrics.2017.0124 KQ4E5, KQ5E10a28418571
477 Michel, K, Valach, L, . A Novel Therapy for People Who Attempt Suicide and Why We Need New Models of Suicide. International Journal of Environmental Research & Public Health [Electronic Resource]. 14(3): 01. 2017. PMID: 28257071. 10.3390/ijerph14030243 KQ4E2b, KQ5E2b28257071
478 Milgrom, J, Holt, CJ, . Treating postnatal depressive symptoms in primary care: a randomised controlled trial of GP management, with and without adjunctive counselling. BMC Psychiatry. 11: 95. 2011. PMID: 21615968. KQ4E3a, KQ5E3a21615968
479 Milgrom, J, Negri, LM, . A randomized controlled trial of psychological interventions for postnatal depression. Br J Clin Psychol. 44(Pt 4): 529–542. 2005. PMID: 16368032. KQ4E3a, KQ5E3a16368032
480 Miller, M, Pate, V, . Antidepressant class, age, and the risk of deliberate self-harm: a propensity score matched cohort study of SSRI and SNRI users in the USA. CNS Drugs. 28(1): 79–88. 2014. PMID: 24146116. 10.1007/s40263-013-0120-8 KQ4E3, KQ5E424146116
481 Miller, M, Swanson, SA, . Antidepressant dose, age, and the risk of deliberate self-harm. JAMA Intern Med. 174(6): 899–909. 2014. PMID: 24782035. 10.1001/jamainternmed.2014.1053 KQ4E3, KQ5E424782035
482 Milner, A, Aitken, Z, . The relationship between an electronic mental health stigma campaign and suicidal thoughts and behaviours: a two-arm randomized controlled trial in the Australian construction industry. Health Promot Int. 35(3): 478–485. 2020. PMID: 31081030. 10.1093/heapro/daz034 KQ4E7b, KQ5E7b31081030
483 Mitchell, J, Goodman, J. Comparative effects of antidepressant medications and untreated major depression on pregnancy outcomes: a systematic review. Arch Womens Ment Health. 21(5): 505–516. 2018. KQ4E5, KQ5E10a29644439
484 Mohlman, J, Gorenstein, EE, . Standard and enhanced cognitive-behavior therapy for late-life generalized anxiety disorder: two pilot investigations. Am J Geriatr Psychiatry. 11(1): 24–32. 2003. KQ4E7b, KQ5E7b12527537
485 Molyneaux, Emma, Howard, LouiseM, . Antidepressant treatment for postnatal depression. Issues Ment Health Nurs. 38(2): 188–190. 2017. KQ4E10a, KQ5E10a27362508
486 Moore, LucyM, Carr, Alan, . Does group CBT for depression do what it says on the tin? A systemic review and meta-analysis of group CBT for depressed adults (2000-2016). Journal of Contemporary Psychotherapy: On the Cutting Edge of Modern Developments in Psychotherapy. 47(3): 141–152. 2017. KQ4E10a, KQ5E5
487 Morthorst, B, Krogh, J, . Effect of assertive outreach after suicide attempt in the AID (assertive intervention for deliberate self harm) trial: randomised controlled trial. BMJ. 345: e4972. 2012. PMID: 22915730. 10.1136/bmj.e4972 KQ4E2b, KQ5E2b22915730
488 Morvaridi, Maryam, Mashhadi, Ali, . The effectiveness of group emotional schema therapy on emotional regulation and social anxiety symptoms. Int J Cogn Ther. 12(1): 16–24. 2019. 10.1007/s41811-018-0037-6 KQ4E2a, KQ5E2a
489 Mosca, D, Zhang, M, . Efficacy of Desvenlafaxine Compared With Placebo in Major Depressive Disorder Patients by Age Group and Severity of Depression at Baseline. J Clin Psychopharmacol. 37(2): 182–192. 2017. PMID: 28146000. 10.1097/JCP.0000000000000674 KQ4E10a, KQ5E10a28146000
490 Motter, JN, Pimontel, MA, . Computerized cognitive training and functional recovery in major depressive disorder: A meta-analysis. J Affect Disord. 189: 184–91. 2016. PMID: 26437233. 10.1016/j.jad.2015.09.022 KQ4E10a, KQ5E10a26437233
491 Motto, JA, Bostrom, AG. A randomized controlled trial of postcrisis suicide prevention. Psychiatr Serv. 52(6): 828–833. 2001. PMID: 11376235. KQ4E8, KQ5E811376235
492 Mouaffak, F, Marchand, A, . OSTA program: A French follow up intervention program for suicide prevention. Psychiatry Res. 230(3): 913–8. 2015. KQ4E2b, KQ5E2b26607432
493 Mullin, A, Dear, Bf, . The UniWellbeing course: a randomised controlled trial of a transdiagnostic internet-delivered cognitive behavioural therapy (CBT) programme for university students with symptoms of anxiety and depression. Internet interventions. 2(2): 128–136. 2015. 10.1016/j.invent.2015.02.002 KQ4E7, KQ5E7
494 Munk-Olsen, T, Liu, X, . Maternal and infant outcomes associated with lithium use in pregnancy: an international collaborative meta-analysis of six cohort studies. The Lancet Psychiatry. 5(8): 644–652. 2018. PMID: 29929874. 10.1016/S2215-0366(18)30180-9 KQ4E5, KQ5E10a29929874
495 Murray, L, Cooper, PJ, . Controlled trial of the short- and long-term effect of psychological treatment of post-partum depression: 2. Impact on the mother-child relationship and child outcome. Br J Psychiatry. 182: 420–427. 2003. PMID: 12724245. KQ4E3a, KQ5E3a12724245
496 Murrough, Jw. Ketamine for the rapid treatment of suicidal ideation: new findings from a randomized controlled trial. Biol Psychiatry. 79(9): 37s. 2016. 10.1016/j.biopsych.2016.03.1748 KQ4E14, KQ5E14
497 Muscatello, MRA, Zoccali, RA, . Duloxetine in Psychiatric Disorders: Expansions Beyond Major Depression and Generalized Anxiety Disorder. Frontiers in psychiatry Frontiers Research Foundation. 10: 772. 2019. PMID: 31749717. 10.3389/fpsyt.2019.00772 KQ4E10a, KQ5E10a31749717
498 Muzik, Maria, Hamilton, SusanE. Use of antidepressants during pregnancy? What to consider when weighing treatment with antidepressants against untreated depression. Matern Child Health J. 20(11): 2268–2279. 2016. KQ4E5, KQ5E10a27461022
499 Naglich, AC, Brown, ES, . Systematic review of preclinical, clinical, and post-marketing evidence of bupropion misuse potential. Am J Drug Alcohol Abuse. 45(4): 341–354. 2019. KQ4E7, KQ5E730601027
500 Nair, NP, Bakish, D, . Comparison of fluvoxamine, imipramine, and placebo in the treatment of outpatients with panic disorder. Anxiety. 2(4): 192–8. 1996. KQ4E7b, KQ5E7b9160622
501 Nash, A, Turkoz, I, . Esketamine nasal spray for rapid reduction of symptoms of major depressive disorder in adult patients at imminent risk for suicide: a post-hoc analysis of north American subjects. Neuropsychopharmacology. 44: 127. 2019. 10.1038/s41386-019-0545-y KQ4E14, KQ5E14
502 Naslund, J, Hieronymus, F, . Incidence of early anxiety aggravation in trials of selective serotonin reuptake inhibitors in depression. Acta Psychiatr Scand. 136(4): 343–351. 2017. KQ4E10a, KQ5E10a28859218
503 Naslund, J, Hieronymus, F, . Net effect of serotonin reuptake inhibitors on suicidality in depression is beneficial rather than harmful already during the first week of treatment. Eur Neuropsychopharmacol. 27: S869–s870. 2017. KQ4E14, KQ5E14
504 Negt, P, Brakemeier, EL, . The treatment of chronic depression with cognitive behavioral analysis system of psychotherapy: a systematic review and meta-analysis of randomized-controlled clinical trials. Brain Behav. 6(8): e00486. 2016. PMID: 27247856. 10.1002/brb3.486 KQ4E10a, KQ5E10a27247856
505 Nelms, JA, Castel, L. A Systematic Review and Meta-Analysis of Randomized and Nonrandomized Trials of Clinical Emotional Freedom Techniques (EFT) for the Treatment of Depression. Explore: The Journal of Science & Healing. 12(6): 416–426. 2016. PMID: 27843054. 10.1016/j.explore.2016.08.001 KQ4E8, KQ5E827843054
506 Newby, JM, Mackenzie, A, . Internet cognitive behavioural therapy for mixed anxiety and depression: a randomized controlled trial and evidence of effectiveness in primary care. Psychol Med. 43(12): 2635–48. 2013. KQ4E7b, KQ5E7b23419552
507 Newby, JM, McKinnon, A, . Systematic review and meta-analysis of transdiagnostic psychological treatments for anxiety and depressive disorders in adulthood. Clin Psychol Rev. 40: 91–110. 2015. PMID: 26094079. 10.1016/j.cpr.2015.06.002 KQ4E10a, KQ5E10a26094079
508 Newby, JM, Twomey, C, . Transdiagnostic computerised cognitive behavioural therapy for depression and anxiety: A systematic review and meta-analysis. J Affect Disord. 199: 30–41. 2016. PMID: 27060430. 10.1016/j.jad.2016.03.018 KQ4E10a, KQ5E10a27060430
509 Nezafati, MH, Eshraghi, A, . Selective serotonin reuptake inhibitors and cardiovascular events: A systematic review. Journal of Research in Medical Sciences. 21: 66. 2016. KQ4E10a, KQ5E10a27904611
510 Nezafati, MH, Vojdanparast, M, . Antidepressants and cardiovascular adverse events: A narrative review. ARYA Atheroscler. 11(5): 295–304. 2015. PMID: 26715935. KQ4E11, KQ5E1126715935
511 Nicolini, H, Bakish, D, . Improvement of psychic and somatic symptoms in adult patients with generalized anxiety disorder: examination from a duloxetine, venlafaxine extended-release and placebo-controlled trial. Psychol Med. 39(2): 267–76. 2009. PMID: 18485261. 10.1017/s0033291708003401 KQ4E7b, KQ5E7b18485261
512 Nillni, YI, Mehralizade, A, . Treatment of depression, anxiety, and trauma-related disorders during the perinatal period: A systematic review. Clin Psychol Rev. 66: 136–148. 2018. PMID: 29935979. 10.1016/j.cpr.2018.06.004 KQ4E10a, KQ5E10a29935979
513 Nomikos, GG, Tomori, D, . Efficacy, safety, and tolerability of vortioxetine for the treatment of major depressive disorder in patients aged 55 years or older. CNS Spectr. 22(4): 348–362. 2017. PMID: 27869048. 10.1017/S1092852916000626 KQ4E10a, KQ5E10a27869048
514 Normann, N, Morina, N. The Efficacy of Metacognitive Therapy: A Systematic Review and Meta-Analysis. Front Psychol. 9: 2211. 2018. PMID: 30487770. 10.3389/fpsyg.2018.02211 KQ4E10a, KQ5E530487770
515 Norton, AR, Abbott, MJ, . A systematic review of mindfulness and acceptance-based treatments for social anxiety disorder. J Clin Psychol. 71(4): 283–301. 2015. PMID: 25529254. 10.1002/jclp.22144 KQ4E10a, KQ5E525529254
516 Norton, PJ, Provencher, MD, . Impact of group transdiagnostic cognitive-behavior therapy for anxiety disorders on comorbid diagnoses: Results from a pragmatic randomized clinical trial in primary care. Depress Anxiety. 18: 18. 2021. 10.1002/da.23184 KQ4E7b, KQ5E5
517 O’Connor, E, Rossom, RC, . Primary Care Screening for and Treatment of Depression in Pregnant and Postpartum Women: Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 315(4): 388–406. 2016. PMID: 26813212. 10.1001/jama.2015.18948 KQ4E10a, KQ5E10a26813212
518 O’Connor, RC, Smillie, S, . SAFETEL: a pilot randomised controlled trial to assess the feasibility and acceptability of a safety planning and telephone follow-up intervention to reduce suicidal behaviour. Pilot & Feasibility Studies. 8(1): 156. 2022. PMID: 35897119. 10.1186/s40814-022-01081-5 KQ4E2b, KQ5E2b35897119
519 O’Connor, Rory C, Ferguson, Eamonn, . A brief psychological intervention to reduce repetition of self-harm in patients admitted to hospital following a suicide attempt: A randomised controlled trial. The Lancet Psychiatry. 4(6): 451–460. 2017. KQ4E2b, KQ5E2b28434871
520 O’Connor, SS, Comtois, KA, . The development and implementation of a brief intervention for medically admitted suicide attempt survivors. Gen Hosp Psychiatry. 37(5): 427–33. 2015. PMID: 25983187. 10.1016/j.genhosppsych.2015.05.001 KQ4E2b, KQ5E2b25983187
521 O’Connor, SS, Johnson, LL, . Three-year follow-up of suicide prevention-focused group therapy for veterans. Psychol Serv. 30: 30. 2021. PMID: 34968124. 10.1037/ser0000451 KQ4E3, KQ5E334968124
522 O’Day, EB, Butler, RM, . Reductions in social anxiety during treatment predict lower levels of loneliness during follow-up among individuals with social anxiety disorder. J Anxiety Disord. 78: 102362. 2021. 10.1016/j.janxdis.2021.102362 KQ4E7b, KQ5E7b33486385
523 Olivares-Olivares, PabloJ, Olivares, Jose, . Community versus Clinical Cognitive-Behavioral Intervention in Young-Adult Spanish Population with Generalized Social Phobia. Terapia Psicologica. 34(1): 23–30. 2016. KQ4E2, KQ5E2
524 Olthuis, JV, Watt, MC, . Therapist-supported Internet cognitive behavioural therapy for anxiety disorders in adults. Cochrane Database of Systematic Reviews. (3): CD011565. 2015. PMID: 2574218625742186. 10.1002/14651858.CD011565 KQ4E10a, KQ5E5
525 Olthuis, JV, Watt, MC, . Therapist-supported Internet cognitive behavioural therapy for anxiety disorders in adults. Cochrane Database Syst Rev. 3: CD011565. 2016. PMID: 26968204. 10.1002/14651858.CD011565.pub2 KQ4E8, KQ5E826968204
526 O’Mahen, H, Himle, JA, . A pilot randomized controlled trial of cognitive behavioral therapy for perinatal depression adapted for women with low incomes. Depress Anxiety. 30(7): 679–687. 2013. PMID: 23319454. KQ4E3a, KQ5E3a23319454
527 Ono, Y, Sakai, A, . Effectiveness of a multimodal community intervention program to prevent suicide and suicide attempts: a quasi-experimental study. PLoS ONE [Electronic Resource]. 8(10): e74902. 2013. PMID: 24130673. 10.1371/journal.pone.0074902 KQ4E8, KQ5E824130673
528 Orgeta, V, Brede, J, . Behavioural activation for depression in older people: systematic review and meta-analysis. Br J Psychiatry. 211(5): 274–279. 2017. PMID: 28982660. 10.1192/bjp.bp.117.205021 KQ4E10a, KQ5E528982660
529 Orsolini, L, Tomasetti, C, . Current and Future Perspectives on the Major Depressive Disorder: Focus on the New Multimodal Antidepressant Vortioxetine. CNS Neurol Disord Drug Targets. 16(1): 65–92. 2017. KQ4E10a, KQ5E10a27781949
530 Orsolini, L, Tomasetti, C, . New advances in the treatment of generalized anxiety disorder: the multimodal antidepressant vortioxetine. Expert Rev Neurother. 16(5): 483–95. 2016. KQ4E5, KQ5E10a27050932
531 Oser, M, Wallace, ML, . Guided Digital Cognitive Behavioral Program for Anxiety in Primary Care: Propensity-Matched Controlled Trial. JMIR Mental Health. 6(4): e11981. 2019. KQ4E3, KQ5E330946022
532 Osma, J, Navarro Haro, MV, . Unified Protocol in a Group Format for Improving Specific Symptoms of Emotional Disorders in the Spanish Public Health System. Psicothema. 34(1): 25–34. 2022. PMID: 35048892. 10.7334/psicothema2021.246 KQ4E7b, KQ5E7b35048892
533 O’Toole, MiaS, Arendt, MikkelB, . Testing an app-assisted treatment for suicide prevention in a randomized controlled trial: Effects on suicide risk and depression. Behav Ther. 50(2): 421–429. 2019. 10.1016/j.beth.2018.07.007 KQ4E11, KQ5E1130824256
534 O’Toole, Ms, Arendt, Mb, . Testing an App-Assisted Treatment for Suicide Prevention in a Randomized Controlled Trial: effects on Suicide Risk and Depression. Behav Ther. 50(2): 421–429. 2019. 10.1016/j.beth.2018.07.007 KQ4E11, KQ5E1130824256
535 Ougrin, D. Adding group psychotherapy to routine care does not improve outcomes in adolescents who repeatedly self-harm. Evid Based Ment Health. 14(3): 84. 2011. KQ4E7a, KQ5E7a21764883
536 Owens, D, Wright-Hughes, A, . Problem-solving therapy rather than treatment as usual for adults after self-harm: a pragmatic, feasibility, randomised controlled trial (the MIDSHIPS trial). Pilot & Feasibility Studies. 6: 119. 2020. 10.1186/s40814-020-00668-0 KQ4E2b, KQ5E2b32832098
537 Owens, D, Wright-Hughes, A, . Problem-solving therapy rather than treatment as usual for adults after self-harm: a pragmatic, feasibility, randomised controlled trial (the MIDSHIPS trial). Pilot and feasibility studies. 6(1). 2020. 10.1186/s40814-020-00668-0 KQ4E2b, KQ5E2b
538 Oyama, H, Sakashita, T. Differences in specific depressive symptoms among community-dwelling middle-aged Japanese adults before and after a universal screening intervention. Soc Psychiatry Psychiatr Epidemiol. 49(2): 251–8. 2014. KQ4E8, KQ5E823824236
539 Oyama, H, Sakashita, T. Effects of universal screening for depression among middle-aged adults in a community with a high suicide rate. J Nerv Ment Dis. 202(4): 280–6. 2014. KQ4E8, KQ5E824647214
540 Oyama, H, Sakashita, T, . A community-based survey and screening for depression in the elderly: the short-term effect on suicide risk in Japan. Crisis. 31(2): 100–8. 2010. PMID: 20418216. 10.1027/0227-5910/a000007 KQ4E8, KQ5E820418216
541 Oyama, H, Sakashita, T. Long-Term Effects of a Screening Intervention for Depression on Suicide Rates among Japanese Community-Dwelling Older Adults. American Journal of Geriatric Psychiatry. 24(4): 287–96. 2016. PMID: 26796924. 10.1016/j.jagp.2015.10.008 KQ4E8, KQ5E826796924
542 Pae, CU, Wang, SM, . Vortioxetine: a meta-analysis of 12 short-term, randomized, placebo-controlled clinical trials for the treatment of major depressive disorder. J Psychiatry Neurosci. 40(3): 174–86. 2015. KQ4E10a, KQ5E10a25350320
543 Pae, CU, Wang, SM, . Vortioxetine, a multimodal antidepressant for generalized anxiety disorder: a systematic review and meta-analysis. J Psychiatr Res. 64: 88–98. 2015. PMID: 25851751. 10.1016/j.jpsychires.2015.02.017 KQ4E10a, KQ5E10a25851751
544 Palacios, JE, Enrique, A, . Durability of treatment effects following internet-delivered cognitive behavioural therapy for depression and anxiety delivered within a routine care setting. Clin Psychol Psychother. 29(5): 1768–1777. 2022. PMID: 35466486. 10.1002/cpp.2743 KQ4E5, KQ5E535466486
545 Palmsten, K, Hernandez-Diaz, S, . Use of antidepressants near delivery and risk of postpartum hemorrhage: cohort study of low income women in the United States. BMJ. 347: f4877. 2013. PMID: 23965506. KQ4E3, KQ5E3a23965506
546 Palmsten, K, Huybrechts, KF, . Antidepressant use and risk for preeclampsia. Epidemiology. 24(5): 682–691. 2013. PMID: 23873072. KQ4E3, KQ5E3a23873072
547 Palmsten, K, Huybrechts, KF, . Harnessing the Medicaid Analytic eXtract (MAX) to evaluate medications in pregnancy: design considerations. PLoS One. 8(6): e67405. 2013. PMID: 23840692. KQ4E3, KQ5E3a23840692
548 Papakostas, GI, Martinson, MA, . Demographic variables, design characteristics, and effect sizes of randomized, placebo-controlled, monotherapy trials of major depressive disorder and bipolar depression. J Clin Psychiatry. 77(5): e619–24. 2016. PMID: 27249092. 10.4088/JCP.14r09767 KQ4E10a, KQ5E10a27249092
549 Parker, Zachary J, Waller, Glenn, . The role of exposure in treatment of anxiety disorders: A meta-analysis. International Journal of Psychology & Psychological Therapy. 18(1): 111–141. 2018. KQ4E5, KQ5E5
550 Pasarelu, CR, Andersson, G, . Internet-delivered transdiagnostic and tailored cognitive behavioral therapy for anxiety and depression: a systematic review and meta-analysis of randomized controlled trials. Cogn Behav Ther. 46(1): 1–28. 2017. KQ4E10a, KQ5E10a27712544
551 Patel, K, Allen, S, . Bupropion: a systematic review and meta-analysis of effectiveness as an antidepressant. Ther Adv Psychopharmacol. 6(2): 99–144. 2016. PMID: 27141292. 10.1177/2045125316629071 KQ4E10a, KQ5E527141292
552 Penate, W, Fumero, A. A meta-review of Internet computer-based psychological treatments for anxiety disorders. J Telemed Telecare. 22(1): 3–11. 2016. PMID: 26026188. 10.1177/1357633X15586491 KQ4E10a, KQ5E10a26026188
553 Picardi, A, Lega, I, . A randomised controlled trial of the effectiveness of a program for early detection and treatment of depression in primary care. J Affect Disord. 198: 96–101. 2016. KQ4E3a, KQ5E3a27015158
554 Pistorello, Jacqueline, Jobes, David A, . Developing adaptive treatment strategies to address suicidal risk in college students: A pilot Sequential, Multiple Assignment, Randomized Trial (SMART). Archives of Suicide Research. 22(4): 644–664. 2018. KQ4E5, KQ5E5
555 Polen, KN, Rasmussen, SA, . Association between reported venlafaxine use in early pregnancy and birth defects, national birth defects prevention study, 1997-2007. Birth Defects Res. 97(1): 28–35. 2013. PMID: 23281074. KQ4E3, KQ5E3a23281074
556 Pollack, M, Mangano, R, . A randomized controlled trial of venlafaxine ER and paroxetine in the treatment of outpatients with panic disorder. Psychopharmacology (Berl). 194(2): 233–42. 2007. PMID: 17589833. 10.1007/s00213-007-0821-0 KQ4E7b, KQ5E7b17589833
557 Pollack, MH, Lepola, U, . A double-blind study of the efficacy of venlafaxine extended-release, paroxetine, and placebo in the treatment of panic disorder. Depress Anxiety. 24(1): 1–14. 2007. PMID: 16894619. 10.1002/da.20218 KQ4E7b, KQ5E7b16894619
558 Pollack, MH, Otto, MW, . Sertraline in the treatment of panic disorder: a flexible-dose multicenter trial. Arch Gen Psychiatry. 55(11): 1010–6. 1998. PMID: 9819070. 10.1001/archpsyc.55.11.1010 KQ4E7b, KQ5E7b9819070
559 Pollack, MH, Zaninelli, R, . Paroxetine in the treatment of generalized anxiety disorder: results of a placebo-controlled, flexible-dosage trial. J Clin Psychiatry. 62(5): 350–7. 2001. PMID: 11411817. 10.4088/jcp.v62n0508 KQ4E7b, KQ5E7b11411817
560 Pollok, Justyna, van Agteren, Joseph, . Evaluation of existing experimental evidence for treatment of depression in indigenous populations: A systematic review. Aust J Psychol. 70(4): 305–317. 2018. KQ4E7a, KQ5E7a
561 Pompoli, A, Furukawa, TA, . Dismantling cognitive-behaviour therapy for panic disorder: a systematic review and component network meta-analysis. Psychol Med. 48(12): 1945–1953. 2018. PMID: 29368665. 10.1017/S0033291717003919 KQ4E5, KQ5E529368665
562 Pompoli, A, Furukawa, TA, . Psychological therapies for panic disorder with or without agoraphobia in adults: a network meta-analysis. Cochrane Database of Systematic Reviews. 4: CD011004. 2016. PMID: 27071857. 10.1002/14651858.CD011004.pub2 KQ4E10a, KQ5E10a27071857
563 Powell, J, Williams, V, . Effectiveness and cost-effectiveness of a self-guided internet intervention for social anxiety symptoms in a general population sample: randomized controlled trial. J Med Internet Res. 22(1). 2020. 10.2196/16804 KQ4E7b, KQ5E7b
564 Powell, JG, Garland, S, . Brexanolone (Zulresso): Finally, an FDA-Approved Treatment for Postpartum Depression. Annals of Pharmacotherapy. 54(2): 157–163. 2020. PMID: 31476884. 10.1177/1060028019873320 KQ4E10a, KQ5E10a31476884
565 Power, KG, Jerrom, DWA, . A Controlled Comparison of Cognitive—Behaviour Therapy, Diazepam and Placebo in the Management of Generalized Anxiety. Behavioural Psychotherapy. 17(1): 1–14. 1989. KQ4E11, KQ5E11
566 Power, MJ, Freeman, C. A randomized controlled trial of IPT versus CBT in primary care: with some cautionary notes about handling missing values in clinical trials. Clin Psychol Psychother. 19(2): 159–69. 2012. PMID: 22337508. 10.1002/cpp.1781 KQ4E7a, KQ5E7a22337508
567 Prado, CE, Watt, S, . A meta-analysis of the effects of antidepressants on cognitive functioning in depressed and non-depressed samples. Neuropsychol Rev. 28(1): 32–72. 2018. KQ4E7, KQ5E729446012
568 Prendergast, J, Austin, MP. Early childhood nurse-delivered cognitive behavioural counselling for post-natal depression. Australas Psychiatry. 9(3): 255–259. 2001. PMID: None. KQ4E3a, KQ5E3a
569 Pruckner, N, Holthoff-Detto, V. Antidepressant pharmacotherapy in old-age depression-a review and clinical approach. Eur J Clin Pharmacol. 73(6): 661–667. 2017. KQ4E10a, KQ5E10a28280892
570 Qin, B, Huang, G, . Vortioxetine treatment for generalised anxiety disorder: a meta-analysis of anxiety, quality of life and safety outcomes. BMJ Open. 9(11): e033161. 2019. PMID: 31784448. 10.1136/bmjopen-2019-033161 KQ4E10a, KQ5E10a31784448
571 Quagliato, LA, Freire, RC, . Risks and benefits of medications for panic disorder: a comparison of SSRIs and benzodiazepines. Expert Opin Drug Saf. 17(3): 315–324. 2018. KQ4E10a, KQ5E10a29357714
572 Quagliato, LA, Cosci, F, . Selective serotonin reuptake inhibitors and benzodiazepines in panic disorder: A meta-analysis of common side effects in acute treatment. J Psychopharmacol. 33(11): 1340–1351. 2019. PMID: 31304840. 10.1177/0269881119859372 KQ4E5, KQ5E10a31304840
573 Rahmani, F, Abbass, A, . Challenging the role of challenge in intensive short-term dynamic psychotherapy for social anxiety disorder: A randomized controlled trial. J Clin Psychol. 76(12): 2123–2132. 2020. 10.1002/jclp.22993 KQ4E2a, KQ5E2a32567708
574 Ram, D, Gandotra, S. Antidepressants, anxiolytics, and hypnotics in pregnancy and lactation. Indian J Psychiatry. 57(Suppl 2): S354–71. 2015. PMID: 26330654. 10.4103/0019-5545.161504 KQ4E5, KQ5E10a26330654
575 Randell, BP, Eggert, LL, . Immediate post intervention effects of two brief youth suicide prevention interventions. Suicide Life Threat. Behav. 31: 41–61. 2001. KQ4E7a, KQ5E7a11326768
576 Rees, ClareS, Maclaine, Ellen. A systematic review of videoconference-delivered psychological treatment for anxiety disorders. Aust Psychol. 50(4): 259–264. 2015. KQ4E10a, KQ5E5
577 Reinholt, N, Krogh, J. Efficacy of transdiagnostic cognitive behaviour therapy for anxiety disorders: a systematic review and meta-analysis of published outcome studies. Cogn Behav Ther. 43(3): 171–84. 2014. KQ4E10a, KQ5E10a24646219
578 Renner, F, Cuijpers, P, . The effect of psychotherapy for depression on improvements in social functioning: a meta-analysis. Psychol Med. 44(14): 2913–26. 2014. KQ4E10a, KQ5E10a24472135
579 Rezaeifard, Akbar, Mazraeh, Nasrollah, . The effect of group-based emotional schema therapy on anxiety sensitivity and anxiety severity in outpatient females with generalized anxiety disorder. Journal of Evidence-Based Psychotherapies. 22(1): 39–54. 2022. 10.24193/jebp.2022.1.3 KQ4E2a, KQ5E2a
580 Richards, Ann, Barkham, Michael, . PHASE: a randomised, controlled trial of supervised self-help cognitive behavioural therapy in primary care. Br J Gen Pract. 53(495): 764–770. 2003. PMID: 14601351. KQ4E11, KQ5E1114601351
581 Richards, D, Enrique, A, . A pragmatic randomized waitlist-controlled effectiveness and cost-effectiveness trial of digital interventions for depression and anxiety. Npj Digital Medicine. 3: 85. 2020. 10.1038/s41746-020-0293-8 KQ4E7b, KQ5E7b32566763
582 Richards, D, Timulak, L, . Effectiveness of an internet-delivered intervention for generalized anxiety disorder in routine care: A randomised controlled trial in a student population. Internet Interventions. 6: 80–88. 2016. PMID: 30135817. 10.1016/j.invent.2016.10.003 KQ4E7b, KQ5E7b30135817
583 Rickels, K, Gallop, R, . The Course of Adverse Events in Venlafaxine XR Treatment in Generalized Anxiety Disorder. J Clin Psychopharmacol. 39(3): 258–260. 2019. KQ4E3, KQ5E330932946
584 Rickels, K, Mangano, R, . A double-blind, placebo-controlled study of a flexible dose of venlafaxine ER in adult outpatients with generalized social anxiety disorder. J Clin Psychopharmacol. 24(5): 488–96. 2004. KQ4E7b, KQ5E7b15349004
585 Rickels, K, Pollack, MH, . Efficacy of extended-release venlafaxine in nondepressed outpatients with generalized anxiety disorder. Am J Psychiatry. 157(6): 968–74. 2000. PMID: 10831478. 10.1176/appi.ajp.157.6.968 KQ4E7b, KQ5E7b10831478
586 Rickels, K, Zaninelli, R, . Paroxetine treatment of generalized anxiety disorder: a double-blind, placebo-controlled study. Am J Psychiatry. 160(4): 749–56. 2003. PMID: 12668365. 10.1176/appi.ajp.160.4.749 KQ4E7b, KQ5E7b12668365
587 Roberge, EM, Bryan, CJ, . Variables associated with reductions in insomnia severity among acutely suicidal patients receiving brief cognitive behavioral therapy for suicide prevention. J Affect Disord. 252: 230–236. 2019. KQ4E2b, KQ5E2b30986738
588 Roberge, P, Provencher, MD, . Group transdiagnostic cognitive-behavior therapy for anxiety disorders: a pragmatic randomized clinical trial. Psychol Med. 52(13): 1–11. 2020. 10.1017/S0033291720004316 KQ4E7b, KQ5E5
589 Robinson, J, Hetrick, S, . Study protocol: the development of a randomised controlled trial testing a postcard intervention designed to reduce suicide risk among young help-seekers. BMC Psychiatry. 9: 59. 2009. PMID: 19775469. KQ4E7a, KQ5E7a19775469
590 Robinson, J, Yuen, HP, . Can receipt of a regular postcard reduce suicide-related behaviour in young help seekers? A randomized controlled trial. Early Interv Psychiatry. 6(2): 145–152. 2012. PMID: 22260366. KQ4E7a, KQ5E7a22260366
591 Rodriguez-Pulido, F, Castillo, G, . Treatment of Depression in Primary Care with Computerized Psychological Therapies: Systematic Reviews. J Med Syst. 44(3): 67. 2020. KQ4E4, KQ5E432060635
592 Rogers, J, Sicouri, G. A Single-Session Online Cognitive Bias Modification of Interpretations Modified for Adults With Anxiety and Depressive Symptoms. Behav Ther. 53(5): 967–980. 2022. PMID: 35987552. 10.1016/j.beth.2022.04.006 KQ4E7b, KQ5E7b35987552
593 Rollman, Bl, Belnap, Bh, . Online treatments for mood and anxiety disorders in primary care: a randomized controlled trial. J Gen Intern Med. 31(2): S316–s317. 2016. KQ4E14, KQ5E14
594 Romijn, G, Batelaan, N, . Internet-Delivered Cognitive Behavioral Therapy for Anxiety Disorders in Open Community Versus Clinical Service Recruitment: Meta-Analysis. J Med Internet Res. 21(4): e11706. 2019. KQ4E8, KQ5E830994462
595 Roopan, S, Larsen, ER. Use of antidepressants in patients with depression and comorbid diabetes mellitus: a systematic review. Acta Neuropsychiatr. 29(3): 127–139. 2017. KQ4E5, KQ5E527776567
596 Roose, SP, Rutherford, BR. Selective Serotonin Reuptake Inhibitors and Operative Bleeding Risk: A Review of the Literature. J Clin Psychopharmacol. 36(6): 704–709. 2016. PMID: 27684291. KQ4E11, KQ5E1127684291
597 Rosenblat, JD, Kakar, R, . The Cognitive Effects of Antidepressants in Major Depressive Disorder: A Systematic Review and Meta-Analysis of Randomized Clinical Trials. International Journal of Neuropsychopharmacology. 19(2): 25. 2015. PMID: 26209859. 10.1093/ijnp/pyv082 KQ4E10a, KQ5E10a26209859
598 Rudd, MD, Bryan, CJ, . Brief cognitive-behavioral therapy effects on post-treatment suicide attempts in a military sample: results of a randomized clinical trial with 2-year follow-up. Am J Psychiatry. 172(5): 441–9. 2015. PMID: 25677353. 10.1176/appi.ajp.2014.14070843 KQ4E2b, KQ5E2b25677353
599 Rudd, MD, Rajab, MH, . Effectiveness of an outpatient intervention targeting suicidal young adults: preliminary results. J Consult Clin Psychol. 64(1): 179–190. 1996. PMID: 8907098. KQ4E2b, KQ5E2b8907098
600 Ruiz, FJ, Pena-Vargas, A, . Efficacy of a two-session repetitive negative thinking-focused acceptance and commitment therapy (ACT) protocol for depression and generalized anxiety disorder: A randomized waitlist control trial. Psychotherapy: Theory, Research, Practice, Training. 57(3): 444–456. 2020. 10.1037/pst0000273 KQ4E7b, KQ5E7b
601 Rutherford, BR, Bailey, VS, . Influence of Study Design on Treatment Response in Anxiety Disorder Clinical Trials. Depress Anxiety. 32(12): 944–57. 2015. KQ4E11, KQ5E1126437267
602 Rutherford, BR, Tandler, J, . Clinic visits in late-life depression trials: effects on signal detection and therapeutic outcome. American Journal of Geriatric Psychiatry. 22(12): 1452–61. 2014. PMID: 24200597. 10.1016/j.jagp.2013.09.003 KQ4E10a, KQ5E524200597
603 Ryberg, W, Zahl, P-H, . Managing suicidality within specialized care: a randomized controlled trial. J Affect Disord. 249: 112–120. 2019. KQ4E2b, KQ5E2b30771641
604 Rynn, M, Russell, J, . Efficacy and safety of duloxetine in the treatment of generalized anxiety disorder: a flexible-dose, progressive-titration, placebo-controlled trial. Depress Anxiety. 25(3): 182–9. 2008. KQ4E7b, KQ5E7b17311303
605 Sadeghi, R, Mokhber, N, . A systematic review and meta-analysis on controlled treatment trials of metacognitive therapy for anxiety disorders. Journal of Research in Medical Sciences. 20(9): 901–9. 2015. KQ4E10a, KQ5E526759579
606 Safer, Dj. Raising the minimum effective dose of serotonin reuptake inhibitor antidepressants. J Clin Psychopharmacol. 36(5): 483–491. 2016. KQ4E10a, KQ5E10a27518478
607 Safer, DJ. Raising the Minimum Effective Dose of Serotonin Reuptake Inhibitor Antidepressants: Adverse Drug Events. J Clin Psychopharmacol. 36(5): 483–91. 2016. KQ4E1, KQ5E127518478
608 Sakiris, Nathan, Berle, David. A systematic review and meta-analysis of the Unified Protocol as a transdiagnostic emotion regulation based intervention. Clinical Psychology Review. 72: 101751. 2019. KQ4E10a, KQ5E531271848
609 Salagre, E, Grande, I, . Vortioxetine: A new alternative for the treatment of major depressive disorder. Rev Psiquiatr Salud Ment. 11(1): 48–59. 2018. KQ4E10a, KQ5E10a
610 Salagre, E, Sole, B, . Treatment of neurocognitive symptoms in unipolar depression: A systematic review and future perspectives. J Affect Disord. 221(): 205–221. 2017. PMID: 28651185. 10.1016/j.jad.2017.06.034 KQ4E5, KQ5E528651185
611 Salisbury, AL, O’Grady, KE, . The Roles of Maternal Depression, Serotonin Reuptake Inhibitor Treatment, and Concomitant Benzodiazepine Use on Infant Neurobehavioral Functioning Over the First Postnatal Month. Am J Psychiatry. 173(2): 147–57. 2016. PMID: 26514656. 10.1176/appi.ajp.2015.14080989 KQ4E3, KQ5E10a26514656
612 Salisbury-Afshar, E. Adverse Events of Pharmacologic Treatments of Major Depression in Older Adults. Am Fam Physician. 101(3): 179–181. 2020. KQ4E3, KQ5E332003957
613 Salza, A, Giusti, L, . Cognitive behavioral therapy (CBT) anxiety management and reasoning bias modification in young adults with anxiety disorders: a real-world study of a therapist-assisted computerized (TACCBT) program Vs. “person-to-person” group CBT. Internet interventions. 19: 100305. 2020. 10.1016/j.invent.2020.100305 KQ4E7b, KQ5E7b32055452
614 Samaraweera, S, Sivayogan, S, . RCT of cognitive behaviour therapy in active suicidal ideation - as feasibility study in Sri Lanka. Eur J Psychiatry. 21(3): 175–178. 2007. PMID: None. KQ4E2a, KQ5E2a
615 Sampaio, FMC, Araujo, O, . A randomized controlled trial of a nursing psychotherapeutic intervention for anxiety in adult psychiatric outpatients. J Adv Nurs. 74(5): 1114–1126. 2018. PMID: 29288510. 10.1111/jan.13520 KQ4E7b, KQ5E7b29288510
616 Sanaeinasab, H, Saffari, M, . A spiritual intervention to reduce stress, anxiety and depression in pregnant women: Randomized controlled trial. Health Care Women Int. 42(12): 1340–1357. 2021. 10.1080/07399332.2020.1836643 KQ4E2a, KQ5E2a33180001
617 Santoft, F, Axelsson, E, . Cognitive behaviour therapy for depression in primary care: systematic review and meta-analysis. Psychol Med. 49(8): 1266–1274. 2019. KQ4E10a, KQ5E10a30688184
618 Sayal, K, Roe, J, . Feasibility of a randomised controlled trial of remotely delivered problem-solving cognitive behaviour therapy versus usual care for young people with depression and repeat self-harm: lessons learnt (e-DASH). BMC Psychiatry. 19(1): 42. 2019. PMID: 30678674. 10.1186/s12888-018-2005-3 KQ4E11, KQ5E1130678674
619 Schmidt, NB, Norr, AM, . A randomized clinical trial targeting anxiety sensitivity for patients with suicidal ideation. J Consult Clin Psychol. 85(6): 596–610. 2017. KQ4E5, KQ5E528287798
620 Schwartze, Dominique, Barkowski, Sarah, . Efficacy of group psychotherapy for panic disorder: Meta-analysis of randomized, controlled trials. Group Dynamics: Theory, Research, and Practice. 21(2): 77–93. 2017. KQ4E10a, KQ5E5
621 Schweiger, JU, Schweiger, U, . The Use of Antidepressive Agents and Bone Mineral Density in Women: A Meta-Analysis. International Journal of Environmental Research & Public Health [Electronic Resource]. 15(7): 30. 2018. PMID: 29966324. 10.3390/ijerph15071373 KQ4E11, KQ5E1129966324
622 Seekles, W, Cuijpers, P, . Psychological treatment of anxiety in primary care: a meta-analysis. Psychol Med. 43(2): 351–61. 2013. KQ4E3, KQ5E322717105
623 Seeley, JR, Manitsas, T, . Feasibility study of a peer-facilitated low intensity cognitive-behavioral intervention for mild to moderate depression and anxiety in older adults. Aging Ment Health. 21(9): 968–974. 2017. KQ4E7a, KQ5E7a27220057
624 Segre, LS, Brock, RL, . Depression treatment for impoverished mothers by point-of-care providers: a randomized controlled trial. J Consult Clin Psychol. 83(2): 314–324. 2014. PMID: 25486371. KQ4E3a, KQ5E3a25486371
625 Senanayake, B, Wickramasinghe, SI, . Effectiveness of text messaging interventions for the management of depression: A systematic review and meta-analysis. J Telemed Telecare. 25(9): 513–523. 2019. PMID: 31631764. 10.1177/1357633X19875852 KQ4E10a, KQ5E531631764
626 Sharma, T, Guski, LS, . Drop-out rates in placebo-controlled trials of antidepressant drugs: A systematic review and meta-analysis based on clinical study reports. International Journal of Risk & Safety in Medicine. 30(4): 217–232. 2019. KQ4E5, KQ5E10a31561390
627 Sharma, T, Guski, LS, . Suicidality and aggression during antidepressant treatment: systematic review and meta-analyses based on clinical study reports. BMJ. 352: i65. 2016. PMID: 26819231. 10.1136/bmj.i65 KQ4E5, KQ5E10a26819231
628 Sharp, DM, Power, KG, . A comparison of the efficacy and acceptability of group versus individual cognitive behaviour therapy in the treatment of panic disorder and agoraphobia in primary care. Clin Psychol Psychother. 11(2): 73–82. 2004. KQ4E11, KQ5E11
629 Sharp, DM, Power, KG, . Global measures of outcome in a controlled comparison of pharmacological and psychological treatment of panic disorder and agoraphobia in primary care. Br J Gen Pract. 47(416): 150–155. 1997. PMID: 9167318. KQ4E11, KQ5E59167318
630 Sharp, DonaldM, Power, KevinG, . Fluvoxamine, placebo, and cognitive behaviour therapy used alone and in combination in the treatment of panic disorder and agoraphobia. J Anxiety Disord. 10(4): 219–242. 1996. 10.1016/0887-6185(96)00008-4 KQ4E11, KQ5E11
631 Sheehan, DV, Nakagome, K, . Restoring function in major depressive disorder: A systematic review. J Affect Disord. 215: 299–313. 2017. KQ4E11, KQ5E1128364701
632 Shepardson, RL, Buchholz, LJ, . Psychological interventions for anxiety in adult primary care patients: A review and recommendations for future research. J Anxiety Disord. 54: 71–86. 2018. PMID: 29427898. 10.1016/j.janxdis.2017.12.004 KQ4E3, KQ5E329427898
633 Shi, L, Wang, J, . Efficacy and tolerability of vilazodone for major depressive disorder: evidence from phase III/IV randomized controlled trials. Drug Des Devel Ther. 10: 3899–3907. 2016. PMID: 27932864. KQ4E10a, KQ5E10a27932864
634 Shi, Z, MacBeth, A. The Effectiveness of Mindfulness-Based Interventions on Maternal Perinatal Mental Health Outcomes: a Systematic Review. Mindfulness (N Y). 8(4): 823–847. 2017. PMID: 28757900. 10.1007/s12671-016-0673-y KQ4E10a, KQ5E528757900
635 Shim, IH, Bahk, WM, . Pharmacological Treatment of Major Depressive Episodes with Mixed Features: A Systematic Review. Clinical Psychopharmacology & Neuroscience. 16(4): 376–382. 2018. PMID: 30466209. 10.9758/cpn.2018.16.4.376 KQ4E10a, KQ5E10a30466209
636 Shinfuku, M, Kishimoto, T, . Effectiveness and safety of long-term benzodiazepine use in anxiety disorders: a systematic review and meta-analysis. Int Clin Psychopharmacol. 34(5): 211–221. 2019. KQ4E10a, KQ5E10a31274696
637 Shulman, B, Dueck, R, . Feasibility of a mindfulness-based cognitive therapy group intervention as an adjunctive treatment for postpartum depression and anxiety. J Affect Disord. 235: 61–67. 2018. KQ4E7b, KQ5E7b29653295
638 Silverstone, PH, Rittenbach, K, . Depression Outcomes in Adults Attending Family Practice Were Not Improved by Screening, Stepped-Care, or Online CBT during a 12-Week Study when Compared to Controls in a Randomized Trial. Frontiers in psychiatry Frontiers Research Foundation. 8: 32. 2017. PMID: 28373846. 10.3389/fpsyt.2017.00032 KQ4E11, KQ5E1128373846
639 Simmonds-Buckley, M, Kellett, S, . Acceptability and Efficacy of Group Behavioral Activation for Depression Among Adults: A Meta-Analysis. Behav Ther. 50(5): 864–885. 2019. PMID: 31422844. 10.1016/j.beth.2019.01.003 KQ4E10a, KQ5E10a31422844
640 Sinyor, M, Cheung, CP, . Antidepressant-placebo differences for specific adverse events in major depressive disorder: A systematic review. J Affect Disord. 267: 185–190. 2020. KQ4E5, KQ5E10a32217218
641 Slee, N, Garnefski, N, . Cognitive-behavioural intervention for self-harm: randomised controlled trial. Br J Psychiatry. 192(3): 202–211. 2008. PMID: 18310581. KQ4E2b, KQ5E2b18310581
642 Slee, N, Spinhoven, P, . Emotion regulation as mediator of treatment outcome in therapy for deliberate self-harm. Clin Psychol Psychother. 15(4): 205–216. 2008. PMID: 19115441. KQ4E2b, KQ5E2b19115441
643 Slesnick, Natasha, Zhang, Jing, . Cognitive therapy for suicide prevention: A randomized pilot with suicidal youth experiencing homelessness. Cognit Ther Res. 44(2): 402–411. 2020. KQ4E2, KQ5E2
644 Smit, M, Dolman, KM, . Mirtazapine in pregnancy and lactation - A systematic review. Eur Neuropsychopharmacol. 26(1): 126–135. 2016. PMID: 26631373. 10.1016/j.euroneuro.2015.06.014 KQ4E5, KQ5E10a26631373
645 Sockol, LE. A systematic review and meta-analysis of interpersonal psychotherapy for perinatal women. J Affect Disord. 232: 316–328. 2018. KQ4E10a, KQ5E10a29501991
646 Sockol, LE. A systematic review of the efficacy of cognitive behavioral therapy for treating and preventing perinatal depression. J Affect Disord. 177: 7–21. 2015. KQ4E10a, KQ5E525743368
647 Sole, B, Jimenez, E, . Cognition as a target in major depression: new developments. Eur Neuropsychopharmacol. 25(2): 231–47. 2015. PMID: 25640673. 10.1016/j.euroneuro.2014.12.004 KQ4E10a, KQ5E10a25640673
648 Soleimani, L, Dewilde, K, . Effects of ketamine on suicidal ideation in patients with mood and anxiety spectrum disorders: a randomized controlled pilot study. Neuropsychopharmacology. 39: S386–s387. 2014. 10.1038/npp.2014.281 KQ4E14, KQ5E14
649 Soler, J, Pascual, JC, . Dialectical behaviour therapy skills training compared to standard group therapy in borderline personality disorder: a 3-month randomised controlled clinical trial. Behav Res Ther. 47(5): 353–8. 2009. 10.1016/j.brat.2009.01.013 KQ4E7a, KQ5E7a19246029
650 Springer, KS, Levy, HC, . Remission in CBT for adult anxiety disorders: A meta-analysis. Clin Psychol Rev. 61: 1–8. 2018. KQ4E10a, KQ5E529576326
651 Stahl, SM, Gergel, I, . Escitalopram in the treatment of panic disorder: a randomized, double-blind, placebo-controlled trial. J Clin Psychiatry. 64(11): 1322–7. 2003. KQ4E7b, KQ5E7b14658946
652 Stahl, ST, Rodakowski, J, . Systematic review of dyadic and family-oriented interventions for late-life depression. Int J Geriatr Psychiatry. 31(9): 963–73. 2016. PMID: 26799782. 10.1002/gps.4434 KQ4E10a, KQ5E526799782
653 Stamou, G, Garcia-Palacios, A, . Cognitive-Behavioural therapy and interpersonal psychotherapy for the treatment of post-natal depression: a narrative review. BMC psychology. 6(1): 28. 2018. PMID: 29914574. 10.1186/s40359-018-0240-5 KQ4E10a, KQ5E529914574
654 Stangier, U, Schramm, E, . Cognitive therapy vs interpersonal psychotherapy in social anxiety disorder: a randomized controlled trial. Arch Gen Psychiatry. 68(7): 692–700. 2011. PMID: 21727253. 10.1001/archgenpsychiatry.2011.67 KQ4E4, KQ5E421727253
655 Stanley, MelindaA, Hopko, DerekR, . Cognitive–Behavior Therapy for Late-Life Generalized Anxiety Disorder in Primary Care: Preliminary Findings. The American Journal of Geriatric Psychiatry. 11(1): 92–96. 2003. KQ4E11, KQ5E1112527544
656 Staples, LG, Fogliati, VJ, . Internet-delivered treatment for older adults with anxiety and depression: implementation of the Wellbeing Plus Course in routine clinical care and comparison with research trial outcomes. BJPsych Open. 2(5): 307–313. 2016. PMID: 27703794. KQ4E4, KQ5E427703794
657 Stech, EP, Lim, J, . Internet-delivered cognitive behavioral therapy for panic disorder with or without agoraphobia: a systematic review and meta-analysis. Cogn Behav Ther. 49(4): 270–293. 2020. KQ4E10a, KQ5E531303121
658 Stefanopoulou, E, Lewis, D, . Digitally Delivered Psychological Interventions for Anxiety Disorders: a Comprehensive Review. Psychiatr Q. 90(1): 197–215. 2019. KQ4E10a, KQ5E530488330
659 Stein, AT, Carl, E, . Looking beyond depression: a meta-analysis of the effect of behavioral activation on depression, anxiety, and activation. Psychol Med. 51(9): 1491–1504. 2021. KQ4E10a, KQ5E532138802
660 Stein, Dj, Ahokas, A, . Efficacy and safety of agomelatine (10 or 25 mg/day) in non-depressed out-patients with generalized anxiety disorder: a 12-week, double-blind, placebo-controlled study. European neuropsychopharmacology. 27(5): 526–537. 2017. 10.1016/j.euroneuro.2017.02.007 KQ4E8, KQ5E828298261
661 Stein, DJ, Westenberg, HG, . Fluvoxamine CR in the long-term treatment of social anxiety disorder: the 12- to 24-week extension phase of a multicentre, randomized, placebo-controlled trial. Int J Neuropsychopharmacol. 6(4): 317–23. 2003. PMID: 14604447. 10.1017/s146114570300364x KQ4E7b, KQ5E7b14604447
662 Stella, F, Loureiro, JC, . Safety Limits of Antidepressant Use Plus Combinations: Focus on Cardiovascular Function. Curr Drug Metab. 19(8): 641–652. 2018. KQ4E11, KQ5E1129283067
663 Stephens, S, Ford, E, . Effectiveness of Psychological Interventions for Postnatal Depression in Primary Care: A Meta-Analysis. Ann Fam Med. 14(5): 463–72. 2016. PMID: 27621164. 10.1370/afm.1967 KQ4E10a, KQ5E10a27621164
664 Strauss, C, Cavanagh, K, . Mindfulness-based interventions for people diagnosed with a current episode of an anxiety or depressive disorder: a meta-analysis of randomised controlled trials. PLoS ONE [Electronic Resource]. 9(4): e96110. 2014. PMID: 24763812. 10.1371/journal.pone.0096110 KQ4E10a, KQ5E524763812
665 Stubner, Susanne, Grohmann, Renate, . Suicidal ideation and suicidal behavior as rare adverse events of antidepressant medication: Current report from the AMSP multicenter drug safety surveillance project. International Journal of Neuropsychopharmacology. 21(9): 814–821. 2018. 10.1093/ijnp/pyy048 KQ4E5, KQ5E329939264
666 Sukhato, K, Lotrakul, M, . Efficacy of home-based non-pharmacological interventions for treating depression: a systematic review and network meta-analysis of randomised controlled trials. BMJ Open. 7(7): e014499. 2017. PMID: 28706086. 10.1136/bmjopen-2016-014499 KQ4E10a, KQ5E528706086
667 Sullivan, S, Spears, Ap, . Supporting older veterans with suicidal symptomology and their caregivers with a novel treatment. American journal of geriatric psychiatry. 27(3): S174–s175. 2019. 10.1016/j.jagp.2019.01.129 KQ4E14, KQ5E14
668 Svensson, M, Nilsson, T, . The Effect of Patient’s Choice of Cognitive Behavioural or Psychodynamic Therapy on Outcomes for Panic Disorder: A Doubly Randomised Controlled Preference Trial. Psychother Psychosom. 90(2): 107–118. 2021. 10.1159/000511469 KQ4E7b, KQ5E7b33227785
669 Szanto, K, Kalmar, S, . A suicide prevention program in a region with a very high suicide rate. Arch Gen Psychiatry. 64(8): 914–920. 2007. PMID: 17679636. KQ4E8, KQ5E817679636
670 Sztein, DM, Koransky, CE, . Efficacy of cognitive behavioural therapy delivered over the Internet for depressive symptoms: A systematic review and meta-analysis. J Telemed Telecare. 24(8): 527–539. 2018. PMID: 28696153. 10.1177/1357633X17717402 KQ4E10a, KQ5E528696153
671 Tachibana, Yoshiyuki, Koizumi, Noriaki, . An integrated community mental healthcare program to reduce suicidal ideation and improve maternal mental health during the postnatal period: The findings from the Nagano trial. BMC Psychiatry. 20(1): 389. 2020. 10.1186/s12888-020-02765-z KQ4E3, KQ5E532727420
672 Taha, F, Zhang, H, . Effects of a culturally informed intervention on abused, suicidal African American women. Cultur Divers Ethnic Minor Psychol. 21(4): 560–70. 2015. KQ4E11, KQ5E1125403027
673 Tang, TC, Jou, SH, . Randomized study of school-based intensive interpersonal psychotherapy for depressed adolescents with suicidal risk and parasuicide behaviors. Psychiatry Clin Neurosci. 63(4): 463–470. 2009. KQ4E7a, KQ5E7a19531111
674 Tata, N, Esmaeilpour, K, . The Effect of Beck’s Cognitive Therapy On Anxiety and Fear of Childbirth: a Randomized Controlled Trial. Journal of midwifery & reproductive health. 10(2): 1–12. 2022. 10.22038/JMRH.2022.62495.1775 KQ4E2a, KQ5E2a
675 Tavares, LR, Barbosa, MR. Efficacy of group psychotherapy for geriatric depression: A systematic review. Arch Gerontol Geriatr. 78: 71–80. 2018. PMID: 29933137. 10.1016/j.archger.2018.06.001 KQ4E10a, KQ5E10a29933137
676 Telang, S, Walton, C, . Meta-analysis: Second generation antidepressants and headache. J Affect Disord. 236: 60–68. 2018. PMID: 29715610. 10.1016/j.jad.2018.04.047 KQ4E10a, KQ5E10a29715610
677 Tepper, M, Whitehead, J, . Cognitive therapy and preventing suicide attempts. JAMA. 294(22): 2847–2848. 2005. PMID: 16352790. KQ4E2b, KQ5E2b16352790
678 Terides, MD, Dear, BF, . Increased skills usage statistically mediates symptom reduction in self-guided internet-delivered cognitive-behavioural therapy for depression and anxiety: a randomised controlled trial. Cogn Behav Ther. 47(1): 43–61. 2018. KQ4E7b, KQ5E7b28724338
679 Tham, A, Jonsson, U, . Efficacy and tolerability of antidepressants in people aged 65 years or older with major depressive disorder - A systematic review and a meta-analysis. J Affect Disord. 205: 1–12. 2016. PMID: 27389296. 10.1016/j.jad.2016.06.013 KQ4E10a, KQ5E10a27389296
680 Thase, M, Asami, Y, . A meta-analysis of the efficacy of venlafaxine extended release 75-225 mg/day for the treatment of major depressive disorder. Curr Med Res Opin. 33(2): 317–326. 2017. KQ4E10a, KQ5E10a27794623
681 Thase, ME, Fayyad, R, . Effects of desvenlafaxine on blood pressure in patients treated for major depressive disorder: a pooled analysis. Curr Med Res Opin. 31(4): 809–20. 2015. KQ4E11, KQ5E1125758058
682 Thase, ME, Edwards, J, . Effects of vilazodone on suicidal ideation and behavior in adults with major depressive disorder or generalized anxiety disorder: post-hoc analysis of randomized, double-blind, placebo-controlled trials. Int Clin Psychopharmacol. 32(5): 281–288. 2017. PMID: 28538024. 10.1097/YIC.0000000000000180 KQ4E10a, KQ5E528538024
683 Thase, ME, Mahableshwarkar, AR, . A meta-analysis of randomized, placebo-controlled trials of vortioxetine for the treatment of major depressive disorder in adults. Eur Neuropsychopharmacol. 26(6): 979–93. 2016. PMID: 27139079. 10.1016/j.euroneuro.2016.03.007 KQ4E10a, KQ5E10a27139079
684 Thew, GR, Kwok, APL, . Internet-delivered cognitive therapy for social anxiety disorder in Hong Kong: A randomized controlled trial. Internet Interventions. 28: 100539. 2022. PMID: 35493437. 10.1016/j.invent.2022.100539 KQ4E7b, KQ5E7b35493437
685 Thimm, JC, Johnsen, TJ. Time trends in the effects of mindfulness-based cognitive therapy for depression: A meta-analysis. Scand J Psychol. 61(4): 582–591. 2020. PMID: 32319124. 10.1111/sjop.12642 KQ4E10a, KQ5E532319124
686 Thomas, HV, Lewis, G, . Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract. 54(508): 832–7. 2004. PMID: 15527609. KQ4E8, KQ5E815527609
687 Thomas, William Joshua Frazier. Effectiveness of cognitive-behavioral therapies for late-life depression: Research synthesis and meta-analysis. Dissertation Abstracts International: Section B: The Sciences and Engineering. 76(1-B(E)): No Pagination Specified. 2015. KQ4E10a, KQ5E5
688 Thombre Kulkarni, M, Holzman, C, . Pregnancy hypertension and its associations with pre-pregnancy depression, anxiety, antidepressants, and anxiolytics. Pregnancy Hypertens. 16: 67–74. 2019. KQ4E3, KQ5E3a31056161
689 Thompson, EA, Eggert, LL, . Evaluation of indicated suicide risk prevention approaches for potential high school dropouts. Am J Public Health. 91(5): 742–752. 2001. PMID: 11344882. KQ4E7a, KQ5E7a11344882
690 Thorlund, K, Druyts, E, . Comparative efficacy and safety of selective serotonin reuptake inhibitors and serotonin-norepinephrine reuptake inhibitors in older adults: a network meta-analysis. J Am Geriatr Soc. 63(5): 1002–9. 2015. PMID: 25945410. 10.1111/jgs.13395 KQ4E11, KQ5E1125945410
691 Tribe, RH, Sendt, KV, . A systematic review of psychosocial interventions for adult refugees and asylum seekers. J Ment Health. 28(6): 662–676. 2019. KQ4E10a, KQ5E10a28485636
692 Trivedi, Daksha. Cochrane Review Summary: Interventions to improve return to work in depressed people. Prim Health Care Res Dev. 19(2): 107–109. 2018. 10.1017/S1463423617000482 KQ4E10a, KQ5E528789717
693 Tuerk, PW, Keller, SM, . Treatment for Anxiety and Depression via Clinical Videoconferencing: Evidence Base and Barriers to Expanded Access in Practice. Focus (Madison). 16(4): 363–369. 2018. KQ4E10a, KQ5E5
694 Tunvirachaisakul, C, Gould, RL, . Predictors of treatment outcome in depression in later life: A systematic review and meta-analysis. J Affect Disord. 227: 164–182. 2018. KQ4E10a, KQ5E529100149
695 Twohig, MP, Levin, ME. Acceptance and Commitment Therapy as a Treatment for Anxiety and Depression: A Review. Psychiatr Clin North Am. 40(4): 751–770. 2017. KQ4E10a, KQ5E529080598
696 Twomey, C, O’Reilly, G, . Effectiveness of an individually-tailored computerised CBT programme (Deprexis) for depression: A meta-analysis. Psychiatry Res. 256: 371–377. 2017. KQ4E10a, KQ5E528686935
697 Twomey, C, O’Reilly, G, . Effectiveness of a tailored, integrative Internet intervention (deprexis) for depression: Updated meta-analysis. PLoS ONE [Electronic Resource]. 15(1): e0228100. 2020. PMID: 31999743. 10.1371/journal.pone.0228100 KQ4E10a, KQ5E10a31999743
698 Twomey, C, O’Reilly, G, . Effectiveness of cognitive behavioural therapy for anxiety and depression in primary care: a meta-analysis. Fam Pract. 32(1): 3–15. 2015. PMID: 25248976. 10.1093/fampra/cmu060 KQ4E10a, KQ5E10a25248976
699 Twomey, C, O’Reilly, G. Effectiveness of a freely available computerised cognitive behavioural therapy programme (MoodGYM) for depression: Meta-analysis. Aust N Z J Psychiatry. 51(3): 260–269. 2017. PMID: 27384752. 10.1177/0004867416656258 KQ4E8, KQ5E527384752
700 Tyrer, P, Jones, V, . Service variation in baseline variables and prediction of risk in a randomised controlled trial of psychological treatment in repeated parasuicide: the POPMACT Study. Int J Soc Psychiatry. 49(1): 58–69. 2003. PMID: 12793516. KQ4E2b, KQ5E2b12793516
701 Tyrer, P, Thompson, S, . Randomized controlled trial of brief cognitive behaviour therapy versus treatment as usual in recurrent deliberate self-harm: the POPMACT study. Psychol Med. 33(6): 969–976. 2003. PMID: 12946081. KQ4E2b, KQ5E2b12946081
702 Tyrer, P, Tom, B, . Differential effects of manual assisted cognitive behavior therapy in the treatment of recurrent deliberate self-harm and personality disturbance: the POPMACT study. J Pers. Disord. 18(1): 102–116. 2004. PMID: 15061347. KQ4E2b, KQ5E2b15061347
703 Uguz, F. Is There Any Association Between Use of Antidepressants and Preeclampsia or Gestational Hypertension?: A Systematic Review of Current Studies. J Clin Psychopharmacol. 37(1): 72–77. 2017. KQ4E5, KQ5E10a27941417
704 Uguz, Faruk. Maternal antidepressant use during pregnancy and the risk of attention-deficit/hyperactivity disorder in children: A systematic review of the current literature. J Clin Psychopharmacol. 38(3): 254–259. 2018. KQ4E5, KQ5E10a29596147
705 Unlu Ince, B, Riper, H, . The effects of psychotherapy on depression among racial-ethnic minority groups: a metaregression analysis. Psychiatr Serv. 65(5): 612–7. 2014. PMID: 24535615. 10.1176/appi.ps.201300165 KQ4E10a, KQ5E10a24535615
706 Vaidyam, AN, Wisniewski, H, . Chatbots and Conversational Agents in Mental Health: A Review of the Psychiatric Landscape. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 64(7): 456–464. 2019. PMID: 30897957. 10.1177/0706743719828977 KQ4E10a, KQ5E530897957
707 Vaiva, G, Berrouiguet, S, . Combining Postcards, Crisis Cards, and Telephone Contact Into a Decision-Making Algorithm to Reduce Suicide Reattempt: A Randomized Clinical Trial of a Personalized Brief Contact Intervention. J Clin Psychiatry. 79(6): 25. 2018. KQ4E2b, KQ5E2b
708 Vaiva, G, Ducrocq, F, . Effect of telephone contact on further suicide attempts in patients discharged from an emergency department: randomised controlled study. BMJ. 332(7552): 1241–1245. 2006. PMID: 16735333. KQ4E8, KQ5E816735333
709 Valenstein, M, Kim, HM, . Antidepressant agents and suicide death among US Department of Veterans Affairs patients in depression treatment. J Clin Psychopharmacol. 32(3): 346–53. 2012. PMID: 22544011. 10.1097/JCP.0b013e3182539f11 KQ4E3, KQ5E422544011
710 Valerio, MP, Szmulewicz, AG, . A quantitative review on outcome-to-antidepressants in melancholic unipolar depression. Psychiatry Res. 265: 100–110. 2018. PMID: 29702301. 10.1016/j.psychres.2018.03.088 KQ4E10a, KQ5E10a29702301
711 Vallury, KD, Jones, M, . Computerized Cognitive Behavior Therapy for Anxiety and Depression in Rural Areas: A Systematic Review. J Med Internet Res. 17(6): e139. 2015. PMID: 26048193. 10.2196/jmir.4145 KQ4E10a, KQ5E10a26048193
712 Van Ameringen, M, Mancini, C, . Nefazodone in the treatment of generalized social phobia: a randomized, placebo-controlled trial. J Clin Psychiatry. 68(2): 288–95. 2007. KQ4E7b, KQ5E7b17335328
713 Van Ameringen, MA, Lane, RM, . Sertraline treatment of generalized social phobia: a 20-week, double-blind, placebo-controlled study. Am J Psychiatry. 158(2): 275–81. 2001. PMID: 11156811. 10.1176/appi.ajp.158.2.275 KQ4E7b, KQ5E7b11156811
714 van Boeijen, CA, van Oppen, P, . Treatment of anxiety disorders in primary care practice: a randomised controlled trial. Br J Gen Pract. 55(519): 763–9. 2005. PMID: 16212851. KQ4E4a, KQ5E4a16212851
715 Van Den Bosch, LM, Koeter, MW, . Sustained efficacy of dialectical behaviour therapy for borderline personality disorder. Behav Res Ther. 43(9): 1231–1241. 2005. PMID: 16005708. KQ4E7, KQ5E716005708
716 van der Heiden, C, Muris, P, . Randomized controlled trial on the effectiveness of metacognitive therapy and intolerance-of-uncertainty therapy for generalized anxiety disorder. Behav Res Ther. 50(2): 100–9. 2012. PMID: 22222208. 10.1016/j.brat.2011.12.005 KQ4E7b, KQ5E7b22222208
717 Van Heeringen, C, Jannes, S, . The management of non-compliance with referral to out-patient after-care among attempted suicide patients: a controlled intervention study. Psychol Med. 25(5): 963–970. 1995. PMID: 8588015. KQ4E8, KQ5E88588015
718 van Rangelrooij, K, Solans-Buxeda, R, . Effectiveness of a 4-week sophrology program for primary care patients with moderate to high anxiety levels: a randomised controlled trial. Actas Esp Psiquiatr. 48(5): 200–208. 2020. KQ4E6, KQ5E633210278
719 Van Ravesteyn, LM, Kamperman, AM, . Group-based multicomponent treatment to reduce depressive symptoms in women with co-morbid psychiatric and psychosocial problems during pregnancy: A randomized controlled trial. J Affect Disord. 226: 36–44. 2018. KQ4E4a, KQ5E4a28950157
720 van Ravesteyn, LM, Lambregtse-van den Berg, MP, . Interventions to treat mental disorders during pregnancy: A systematic review and multiple treatment meta-analysis. PLoS ONE [Electronic Resource]. 12(3): e0173397. 2017. PMID: 28358808. 10.1371/journal.pone.0173397 KQ4E10a, KQ5E528358808
721 van Spijker, BA, Werner-Seidler, A, . Effectiveness of a Web-Based Self-Help Program for Suicidal Thinking in an Australian Community Sample: Randomized Controlled Trial. J Med Internet Res. 20(2): e15. 2018. 10.2196/jmir.8595 KQ4E11, KQ5E1129444769
722 Varker, T, Brand, RM, . Efficacy of synchronous telepsychology interventions for people with anxiety, depression, posttraumatic stress disorder, and adjustment disorder: A rapid evidence assessment. Psychol Serv. 16(4): 621–635. 2019. KQ4E10a, KQ5E10a29809025
723 Vega, ML, Newport, GC, . Implementation of Advanced Methods for Reproductive Pharmacovigilance in Autism: A Meta-Analysis of the Effects of Prenatal Antidepressant Exposure. Am J Psychiatry. 177(6): 506–517. 2020. PMID: 32375539. 10.1176/appi.ajp.2020.18070766 KQ4E5, KQ5E10a32375539
724 Verbeek, T, Ci, Lh, . Psychological treatment of antenatal depression and anxiety: effects on obstetric outcomes. Arch Womens Ment Health. 18(2): 284-. 2015. KQ4E14, KQ5E14
725 Verheul, R, Van Den Bosch, LM, . Dialectical behaviour therapy for women with borderline personality disorder: 12-month, randomised clinical trial in The Netherlands. Br J Psychiatry. 182: 135–140. 2003. PMID: 12562741. KQ4E7a, KQ5E7a12562741
726 Vu, AnnaMarie Huong. Randomized controlled trial of Pacifica, a CBT and mindfulness-based app for stress, depression, and anxiety management with health monitoring. Dissertation Abstracts International: Section B: The Sciences and Engineering. 82(4-B): No Pagination Specified. 2021. KQ4E7b, KQ5E7b
727 Wade, AG. Use of the internet to assist in the treatment of depression and anxiety: a systematic review. Prim Care Companion J Clin Psychiatry. 12(4). 2010. KQ4E10a, KQ5E5
728 Wadephul, F, Jones, C, . The Impact of Antenatal Psychological Group Interventions on Psychological Well-Being: A Systematic Review of the Qualitative and Quantitative Evidence. Healthcare. 4(2): 08. 2016. PMID: 27417620. 10.3390/healthcare4020032 KQ4E10a, KQ5E527417620
729 Wagner, G, Schultes, MT, . Efficacy and safety of levomilnacipran, vilazodone and vortioxetine compared with other second-generation antidepressants for major depressive disorder in adults: A systematic review and network meta-analysis. J Affect Disord. 228: 1–12. 2018. PMID: 29197738. 10.1016/j.jad.2017.11.056 KQ4E10a, KQ5E10a29197738
730 Wang, YY, Li, XH, . Mindfulness-based interventions for major depressive disorder: A comprehensive meta-analysis of randomized controlled trials. J Affect Disord. 229: 429–436. 2018. KQ4E10a, KQ5E529331704
731 Ward-Ciesielski, Erin Faye. Brief interventions for suicidal individuals not engaged in treatment. Dissertation Abstracts International: Section B: The Sciences and Engineering. 77(2-B(E)): No Pagination Specified. 2016. KQ4E2, KQ5E2
732 Watts, SE, Turnell, A, . Treatment-as-usual (TAU) is anything but usual: a meta-analysis of CBT versus TAU for anxiety and depression. J Affect Disord. 175: 152–67. 2015. KQ4E10a, KQ5E525618002
733 Weisberg, RB, Gonsalves, MA, . Development of a cognitive bias modification intervention for anxiety disorders in primary care. Br J Clin Psychol. 61(Suppl 1): 73–92. 2022. 10.1111/bjc.12281 KQ4E8, KQ5E833629751
734 Weisel, KK, Fuhrmann, LM, . Standalone smartphone apps for mental health-a systematic review and meta-analysis. Npj Digital Medicine. 2: 118. 2019. PMID: 31815193. 10.1038/s41746-019-0188-8 KQ4E10a, KQ5E531815193
735 Weisel, KK, Zarski, AC, . User Experience and Effects of an Individually Tailored Transdiagnostic Internet-Based and Mobile-Supported Intervention for Anxiety Disorders: Mixed-Methods Study. J Med Internet Res. 22(9): e16450. 2020. 10.2196/16450 KQ4E3, KQ5E332936085
736 Weitz, E, Hollon, SD, . Do depression treatments reduce suicidal ideation? The effects of CBT, IPT, pharmacotherapy, and placebo on suicidality. J Affect Disord. 167: 98–103. 2014. KQ4E3a, KQ5E3a24953481
737 Wells, MJ, Owen, JJ, . Computer-Assisted Cognitive-Behavior Therapy for Depression in Primary Care: Systematic Review and Meta-Analysis. Prim Care Companion CNS Disord. 20(2): 01. 2018. KQ4E10a, KQ5E5
738 Welu, TC. A follow-up program for suicide attempters: evaluation of effectiveness. Suicide Life Threat. Behav. 7(1): 17–20. 1977. PMID: 206990. KQ4E2b, KQ5E2b206990
739 Westen, D, Morrison, K. A multidimensional meta-analysis of treatments for depression, panic, and generalized anxiety disorder: an empirical examination of the status of empirically supported therapies. J Consult Clin Psychol. 69(6): 875–99. 2001. KQ4E10a, KQ5E511777114
740 Whiston, A, Bockting, CLH, . Towards personalising treatment: a systematic review and meta-analysis of face-to-face efficacy moderators of cognitive-behavioral therapy and interpersonal psychotherapy for major depressive disorder. Psychol Med. 49(16): 2657–2668. 2019. KQ4E10a, KQ5E531615583
741 Wickberg, B, Hwang, CP. Counselling of postnatal depression: A controlled study on a population based Swedish sample. J Affect Disorder. 39: 209–216. 1996. PMID: 8856425. KQ4E3a, KQ5E3a8856425
742 Wiklund, I, Mohlkert, P, . Evaluation of a brief cognitive intervention in patients with signs of postnatal depression: a randomized controlled trial. Acta Obstet Gynecol Scand. 89(8): 1100–1104. 2010. PMID: 20636249. KQ4E3a, KQ5E3a20636249
743 Wilks, CR, Zieve, GG, . Are Trials of Computerized Therapy Generalizable? A Multidimensional Meta-analysis. Telemedicine Journal & E-Health. 22(5): 450–7. 2016. PMID: 26461235. 10.1089/tmj.2015.0129 KQ4E10a, KQ5E526461235
744 Williams, Coleen Ruth. Long-term effectiveness of CBT for anxiety disorders: A meta-analytic review. Dissertation Abstracts International: Section B: The Sciences and Engineering. 77(3-B(E)): No Pagination Specified. 2016. KQ4E10a, KQ5E5
745 Williams, T, McCaul, M, . Pharmacological treatments for social anxiety disorder in adults: a systematic review and network meta-analysis. Acta Neuropsychiatr. 32(4): 169–176. 2020. KQ4E10a, KQ5E10a32039743
746 Williamson, MK, Pirkis, J, . Recruiting and retaining GPs and patients in intervention studies: the DEPS-GP project as a case study. BMC Med Res Methodol. 7: 42. 2007. PMID: 17875219. KQ4E8, KQ5E817875219
747 Wilson, H, Mannix, S, . The impact of medication on health-related quality of life in patients with generalized anxiety disorder. CNS Drugs. 29(1): 29–40. 2015. PMID: 25516469. 10.1007/s40263-014-0217-8 KQ4E10a, KQ5E525516469
748 Witt, K. The use of emergency department-based psychological interventions to reduce repetition of self-harm behaviour. The Lancet. Psychiatry. 4(6): 428–429. 2017. KQ4E14, KQ5E1428434872
749 Womersley, Kate, Ripullone, Katherine, . What are the risks associated with different selective serotonin re-uptake inhibitors (SSRIs) to treat depression and anxiety in pregnancy? An evaluation of current evidence. Psychiatr Danub. 29(Suppl 3): 629–644. 2017. KQ4E5, KQ5E10a28953843
750 Wong, SY, Tang, WK, . Mindfulness-based cognitive therapy for generalised anxiety disorder and health service utilisation among Chinese patients in primary care: a randomised, controlled trial. Hong Kong Medical Journal. 22 Suppl 6(6): 35–36. 2016. KQ4E14, KQ5E14
751 Wong, SY, Yip, BH, . Mindfulness-based cognitive therapy v. group psychoeducation for people with generalised anxiety disorder: randomised controlled trial. Br J Psychiatry. 209(1): 68–75. 2016. PMID: 26846612. 10.1192/bjp.bp.115.166124 KQ4E7b, KQ5E7b26846612
752 Wood, A, Trainor, G, . Randomized trial of group therapy for repeated deliberate self-harm in adolescents. J Am Acad Child Adolesc Psychiatry. 40(11): 1246–1253. 2001. PMID: 11699797. KQ4E7a, KQ5E7a11699797
753 Wright, JH, Mishkind, M, . Computer-Assisted Cognitive-Behavior Therapy and Mobile Apps for Depression and Anxiety. Curr Psychiatry Rep. 21(7): 62. 2019. KQ4E10a, KQ5E10a31250242
754 Wright, JH, Owen, JJ, . Computer-Assisted Cognitive-Behavior Therapy for Depression: A Systematic Review and Meta-Analysis. J Clin Psychiatry. 80(2): 19. 2019. KQ4E10a, KQ5E10a
755 Wu, CK, Tseng, PT, . Antidepressants during and after Menopausal Transition: A Systematic Review and Meta-Analysis. Sci Rep. 10(1): 8026. 2020. PMID: 32415128. 10.1038/s41598-020-64910-8 KQ4E10a, KQ5E10a32415128
756 Yang, X, Liu, D, . Effectiveness of Zhong-Yong thinking based dialectical behavior therapy group skills training versus supportive group therapy for lowering suicidal risks in Chinese young adults: A randomized controlled trial with a 6-month follow-up. Brain Behav. e01621. 2020. PMID: 3230435332304353. 10.1002/brb3.1621 KQ4E2a, KQ5E2a
757 Yazdanimehr, R, Omidi, A, . The Effect of Mindfulness-integrated Cognitive Behavior Therapy on Depression and Anxiety among Pregnant Women: a Randomized Clinical Trial. Journal of Caring Sciences. 5(3): 195–204. 2016. PMID: 27752485. KQ4E2a, KQ5E2a27752485
758 Yazdy, MM, Mitchell, AA, . Use of selective serotonin-reuptake inhibitors during pregnancy and the risk of clubfoot. Epidemiology. 25(6): 859–865. 2014. PMID: 25171134. KQ4E3, KQ5E3a25171134
759 Ye, YY, Zhang, YF, . Internet-Based Cognitive Behavioral Therapy for Insomnia (ICBT-i) Improves Comorbid Anxiety and Depression-A Meta-Analysis of Randomized Controlled Trials. PLoS ONE [Electronic Resource]. 10(11): e0142258. 2015. PMID: 26581107. 10.1371/journal.pone.0142258 KQ4E10a, KQ5E526581107
760 Yee, A, Ng, CG, . Vortioxetine Treatment for Anxiety Disorder: A Meta-Analysis Study. Curr Drug Targets. 19(12): 1412–1423. 2018. KQ4E10a, KQ5E10a29149828
761 Youash, S, Sharma, V. Depression, Antidepressants and Hypertensive Disorders of Pregnancy: A Systematic Review. Curr Drug Saf. 14(2): 102–108. 2019. KQ4E5, KQ5E10a30666916
762 Yulish, NE, Goldberg, SB, . The importance of problem-focused treatments: A meta-analysis of anxiety treatments. Psychotherapy: Theory, Research, Practice, Training. 54(4): 321–338. 2017. KQ4E10a, KQ5E5
763 Yunitri, Ninik, Kao, Ching-Chiu, . The effectiveness of eye movement desensitization and reprocessing toward anxiety disorder: A meta-analysis of randomized controlled trials. J Psychiatr Res. 123: 102–113. 2020. KQ4E10a, KQ5E532058073
764 Zainal, NH, Chan, WW, . Pilot randomized trial of self-guided virtual reality exposure therapy for social anxiety disorder. Behav Res Ther. 147: 103984. 2021. PMID: 34740099. 10.1016/j.brat.2021.103984 KQ4E7b, KQ5E7b34740099
765 Zareifopoulos, N, Dylja, I. Efficacy and tolerability of vilazodone for the acute treatment of generalized anxiety disorder: A meta-analysis. Asian J Psychiatr. 26: 115–122. 2017. PMID: 28483071. 10.1016/j.ajp.2017.01.016 KQ4E10a, KQ5E10a28483071
766 Zhang, A, Franklin, C, . The effectiveness of strength-based, solution-focused brief therapy in medical settings: a systematic review and meta-analysis of randomized controlled trials. J Behav Med. 41(2): 139–151. 2018. KQ4E10a, KQ5E10a28975531
767 Zhang, A, Park, S, . The Effectiveness of Problem-Solving Therapy for Primary Care Patients’ Depressive and/or Anxiety Disorders: A Systematic Review and Meta-Analysis. Journal of the American Board of Family Medicine: JABFM. 31(1): 139–150. 2018. PMID: 29330248. 10.3122/jabfm.2018.01.170270 KQ4E10a, KQ5E10a29330248
768 Zhang, B, Wang, C, . Short-Term Efficacy and Tolerability of Paroxetine Versus Placebo for Panic Disorder: A Meta-Analysis of Randomized Controlled Trials. Front Pharmacol. 11(): 275. 2020. PMID: 32296330. 10.3389/fphar.2020.00275 KQ4E10a, KQ5E10a32296330
769 Zhang, XF, Wu, L, . Evaluation of the efficacy and safety of vilazodone for treating major depressive disorder. Neuropsychiatr Dis Treat. 11: 1957–65. 2015. PMID: 26345981. 10.2147/NDT.S87968 KQ4E10a, KQ5E10a26345981
770 Zhang, Y, Huang, G, . Duloxetine in treating generalized anxiety disorder in adults: A meta-analysis of published randomized, double-blind, placebo-controlled trials. Asia Pac Psychiatry. 8(3): 215–25. 2016. KQ4E10a, KQ5E10a26238298
771 Zhao, X, Liu, Q, . A meta-analysis of selective serotonin reuptake inhibitors (SSRIs) use during prenatal depression and risk of low birth weight and small for gestational age. J Affect Disord. 241: 563–570. 2018. KQ4E5, KQ5E10a30153640
772 Zheng, J, Wang, Z, . The efficacy and safety of 10 mg/day vortioxetine compared to placebo for adult major depressive disorder: a meta-analysis. Afr Health Sci. 19(1): 1716–1726. 2019. PMID: 31149002. 10.4314/ahs.v19i1.48 KQ4E10a, KQ5E10a31149002
773 Zheng, W, Cai, DB, . Brexanolone for postpartum depression: A meta-analysis of randomized controlled studies. Psychiatry Res. 279: 83–89. 2019. PMID: 31323375. 10.1016/j.psychres.2019.07.006 KQ4E10a, KQ5E10a31323375
774 Zhong, Z, Wang, L, . A meta-analysis of effects of selective serotonin reuptake inhibitors on blood pressure in depression treatment: outcomes from placebo and serotonin and noradrenaline reuptake inhibitor controlled trials. Neuropsychiatr Dis Treat. 13: 2781–2796. 2017. PMID: 29158677. 10.2147/NDT.S141832 KQ4E5, KQ5E10a29158677
775 Zou, Y, Li, H, . Efficacy of psychological pain theory-based cognitive therapy in suicidal patients with major depressive disorder: a pilot study. Psychiatry Res. 249: 23–29. 2017. KQ4E2a, KQ5E2a28063394