# Appendix C Included Studies Lists

## Appendix C List 1 Included evidence for Depression, by Key Question (KQ)

### Ancillary publication(s) indented under primary article

#### KQs 1 and 3: Included studies for screening benefits and harms, by author

- Bergus GR, Hartz AJ, Noyes R, Jr., . The limited effect of screening for depressive symptoms with the PHQ-9 in rural family practices. J Rural Health. 2005;21(4):303–9. PMID: 16294652. 10.1111/j.1748-0361.2005.tb00099.x 16294652
- Bijl D, van Marwijk HWJ, Ader HJ, . A randomised controlled trial to improve the recognition, diagnosis and treatment of major depression in elderly people in general practice - primary and secondary outcomes of the West Friesland Study. Diemen: College Voor Zortgverskeringen; 2003.
  - Bosmans J, de Bruijne M, van Hout H, . Cost-effectiveness of a diseaes management program for major depression in elderly primary care patients. Journal of general internal medicine. 2006;21(10):1020–6. PMID: 16836625. 10.1111/j.1525-1497.2006.00555.x 16836625
- Callahan CM, Hendrie HC, Dittus RS, . Improving treatment of late life depression in primary care: a randomized clinical trial. J Am Geriatr Soc. 1994;42(8):839–46. PMID: 8046193. 10.1111/j.1532-5415.1994.tb06555.x 8046193
- Glavin K, Smith L, Sorum R, . Redesigned community postpartum care to prevent and treat postpartum depression in women-a one-year follow-up study. J Clin Nurs. 2010;19(21-22):3051–62. PMID: 20726926. 10.1111/j.1365-2702.2010.03332.x 20726926
  - Glavin K, Smith L, Sorum R, . Supportive counselling by public health nurses for women with postpartum depression. J Adv Nurs. 2010;66(6):1317–27. PMID: 20384641. 10.1111/j.1365-2648.2010.05263.x 20384641
- Jarjoura D, Polen A, Baum E, . Effectiveness of screening and treatment for depression in ambulatory indigent patients. Journal of general internal medicine. 2004;19(1):78–84. PMID: 14748864. 10.1111/j.1525-1497.2004.21249.x 14748864
- Kroenke K, Talib TL, Stump TE, . Incorporating PROMIS Symptom Measures into Primary Care Practice-a Randomized Clinical Trial. Journal of general internal medicine. 2018;33(8):1245–52. PMID: 29623512. 10.1007/s11606-018-4391-0 29623512
- Leung SS, Leung C, Lam TH, . Outcome of a postnatal depression screening programme using the Edinburgh Postnatal Depression Scale: a randomized controlled trial. J Public Health (Oxf). 2011;33(2):292–301. PMID: 20884642. https://doi.org/10.1093/pubmed/fdq075 20884642
- MacArthur C, Winter HR, Bick DE, . Effects of redesigned community postnatal care on womens’ health 4 months after birth: a cluster randomised controlled trial. Lancet (London, England). 2002;359(9304):378–85. PMID: 11844507. 10.1016/s0140-6736(02)07596-7 11844507
- Morrell CJ, Slade P, Warner R, . Clinical effectiveness of health visitor training in psychologically informed approaches for depression in postnatal women: pragmatic cluster randomised trial in primary care. BMJ (Clinical research ed). 2009;338:a3045. PMID: 19147636. 10.1136/bmj.a3045 19147636
  - Morrell CJ, Warner R, Slade P, . Psychological interventions for postnatal depression: cluster randomised trial and economic evaluation. The PONDER trial. Health Technol Assess. 2009;13(30):1–176. PMID: 19555590. 10.3310/hta13300 19555590
- Rost K, Nutting P, Smith J, . Improving depression outcomes in community primary care practice: a randomized trial of the quEST intervention. Quality Enhancement by Strategic Teaming. Journal of general internal medicine. 2001;16(3):143–9. PMID: 11318908. https://doi.org/10.1111/j.1525-1497.2001.00537.x 11318908
  - Rost K, Nutting P, Smith JL, . Managing depression as a chronic disease: a randomised trial of ongoing treatment in primary care. BMJ (Clinical research ed). 2002;325(7370):934. PMID: 12399343. https://doi.org/10.1136/bmj.325.7370.934 12399343
  - Rost K, Nutting PA, Smith J, . Designing and implementing a primary care intervention trial to improve the quality and outcome of care for major depression. General hospital psychiatry. 2000;22(2):66–77. PMID: 10822094. 10.1016/s0163-8343(00)00059-1 10822094
- van der Weele GM, de Waal MW, van den Hout WB, . Effects of a stepped-care intervention programme among older subjects who screened positive for depressive symptoms in general practice: the PROMODE randomised controlled trial. Age Ageing. 2012;41(4):482–8. PMID: 22427507. 10.1093/ageing/afs027 22427507
- van der Zee-van den Berg AI, Boere-Boonekamp MM, Groothuis-Oudshoorn CG, . Post-up study: Postpartum depression screening in well-child care and maternal outcomes. Pediatrics. 2017;140(4):1–8. PMID: 28882876. 10.1542/peds.2017-0110 28882876
  - van der Weele GM, de Waal MW, van den Hout WB, . Yield and costs of direct and stepped screening for depressive symptoms in subjects aged 75 years and over in general practice. Int J Geriatr Psychiatry. 2011;26(3):229–38. PMID: 20665554. https://doi.org/10.1002/gps.2518 20665554
- Wells KB, Sherbourne C, Schoenbaum M, . Impact of disseminating quality improvement programs for depression in managed primary care: A randomized controlled trial. JAMA. 2000;283(2):212–20. PMID: 10634337. https://doi.org/10.1001/jama.283.2.212 10634337
  - Sherbourne CD, Wells KB, Duan N, . Long-term effectiveness of disseminating quality improvement for depression in primary care. Archives of general psychiatry. 2001;58(7):696–703. PMID: 11448378. 10.1001/archpsyc.58.7.696 11448378
  - Wells K, Sherbourne C, Schoenbaum M, . Five-year impact of quality improvement for depression: Results of a group-level randomized controlled trial. Archives of general psychiatry. 2004;61(4):378–86. PMID: 15066896. 10.1001/archpsyc.61.4.378 15066896
- Whooley M, Stone B. Randomized trial of case-finding for depression in elderly primary care patients. Journal of general internal medicine. 2000;15(5):293–300. PMID: 10840264. 10.1046/j.1525-1497.2000.04319.x 10840264
- Wickberg B, Tjus T, Hwang P. Using the EPDS in routine antenatal care in Sweden: a naturalistic study. J Reprod Infant Psychol. 2005;23(1):33–41. https://doi.org/10.1080/02646830512331330956
- Williams J, CD M, Kroenke K. Case-finding for depression in primary care: A randomized trial. The American journal of medicine. 1999;106(1):36–43. PMID: 10320115. https://doi.org/10.1016/s0002-9343(98)00371-4 10320115
- Yawn BP, Dietrich AJ, Wollan P, . TRIPPD: a practice-based network effectiveness study of postpartum depression screening and management. Annals of family medicine. 2012;10(4):320–9. PMID: 22778120. https://doi.org/10.1370/afm.1418 22778120
  - Yawn BP, Bertram S, Kurland M, . Repeated depression screening during the first postpartum year. Annals of family medicine. 2015;13(3):228–34. PMID: 25964400. 10.1370/afm.1777 25964400

#### KQ 2: Included studies for test accuracy, by study design

##### Primary research studies

- Alves Apostolo JL, Bobrowicz-Campos EM, Carvalho dos Reis IA, . Exploring the screening capacity of the European Portuguese version of the 15-item Geriatric Depression Scale. Revista de Psicopatologia y Psicologia Clinica. 2018;23(2):99–107. 10.5944/rppc.vol.23.num.2.2018.21050
- Blank K, Gruman C, Robison JT. Case-finding for depression in elderly people: balancing ease of administration with validity in varied treatment settings. J Gerontol A Biol Sci Med Sci. 2004;59(4):378–84. PMID: 15071082. https://doi.org/10.1093/gerona/59.4.m378 15071082
- Broekman BF, Niti M, Nyunt MS, . Validation of a brief seven-item response bias-free geriatric depression scale. Am J Geriatr Psychiatry. 2011;19(6):589–96. PMID: 21606902. 10.1097/JGP.0b013e3181f61ec9 21606902
- Davison TE, McCabe MP, Mellor D. An examination of the “gold standard” diagnosis of major depression in aged-care settings. Am J Geriatr Psychiatry. 2009;17(5):359–67. PMID: 19390293. 10.1097/JGP.0b013e318190b901 19390293
- Eriksen S, Bjorklof GH, Helvik AS, . The validity of the hospital anxiety and depression scale and the geriatric depression scale-5 in home-dwelling old adults in Norway. Journal of affective disorders. 2019;256:380–5. PMID: 31212233. 10.1016/j.jad.2019.05.049 31212233
- Izal M, Montorio I, Nuevo R, . Optimising the diagnostic performance of the Geriatric Depression Scale. Psychiatry Res. 2010;178(1):142–6. PMID: 20452060. 10.1016/j.psychres.2009.02.018 20452060
- Jung YE, Kim MD, Bahk WM, . Validation of the Korean Version of the Depression in Old Age Scale and Comparison with Other Depression Screening Questionnaires Used in Elderly Patients in Medical Settings. Clin. 2019;17(3):369–76. PMID: 31352703. 10.9758/cpn.2019.17.3.369 31352703
- Licht-Strunk E, van der Kooij KG, van Schaik DJ, . Prevalence of depression in older patients consulting their general practitioner in The Netherlands. Int J Geriatr Psychiatry. 2005;20(11):1013–9. PMID: 16250082. https://doi.org/10.1002/gps.1391 16250082
- Marc LG, Raue PJ, Bruce ML. Screening performance of the 15-item geriatric depression scale in a diverse elderly home care population. Am J Geriatr Psychiatry. 2008;16(11):914–21. PMID: 18978252. 10.1097/JGP.0b013e318186bd67 18978252
- Pellas J, Damberg M. Accuracy in detecting major depressive episodes in older adults using the Swedish versions of the GDS-15 and PHQ-9. Ups J Med Sci. 2021;126. PMID: 34754407. 10.48101/ujms.v126.7848 34754407
- Rait G, Burns A, Baldwin R, . Screening for depression in African-Caribbean elders. Fam Pract. 1999;16(6):591–5. PMID: 10625132. 10.1093/fampra/16.6.591 10625132
- Shin C, Park MH, Lee SH, . Usefulness of the 15-item geriatric depression scale (GDS-15) for classifying minor and major depressive disorders among community-dwelling elders. Journal of affective disorders. 2019;259:370–5. PMID: 31470180. 10.1016/j.jad.2019.08.053 31470180
- Stefan AM, Baban A. The Romanian version of the Geriatric Depression Scale: Reliability and validity. Cognition, Brain, Behavior: An Interdisciplinary Journal. 2017;21(3):175–87. 10.24193/cbb.2017.21.10
- van Marwijk HW, Wallace P, de Bock GH, . Evaluation of the feasibility, reliability and diagnostic value of shortened versions of the geriatric depression scale. The British journal of general practice : the journal of the Royal College of General Practitioners. 1995;45(393):195–9. PMID: 7612321.7612321

##### ESRs

- Bosanquet K, Bailey D, Gilbody S, . Diagnostic accuracy of the Whooley questions for the identification of depression: a diagnostic meta-analysis. BMJ Open. 2015;5(12):e008913. PMID: 26656018. 10.1136/bmjopen-2015-008913 26656018
- Harel D, Levis B, Sun Y, . External validation of a shortened screening tool using individual participant data meta-analysis: A case study of the Patient Health Questionnaire-Dep-4. Methods. 2022;204:300–11. PMID: 34780986. 10.1016/j.ymeth.2021.11.005 34780986
- He C, Levis B, Riehm KE, . The Accuracy of the Patient Health Questionnaire-9 Algorithm for Screening to Detect Major Depression: An Individual Participant Data Meta-Analysis. Psychother Psychosom. 2020;89(1):25–37. PMID: 31593971. 10.1159/000502294 31593971
- Levis B, Negeri Z, Sun Y, . Accuracy of the Edinburgh Postnatal Depression Sscale (EPDS) for Screening to Detect Major Depression among Pregnant and Postpartum Women: Systematic Review and Meta-analysis of Individual Participant Data. BMJ (Clinical research ed). 2020;371:m4022. PMID: 33177069. 10.1136/bmj.m4022 33177069
- Levis B, Sun Y, He C, . Accuracy of the PHQ-2 Alone and in Combination With the PHQ-9 for Screening to Detect Major Depression: Systematic Review and Meta-analysis. JAMA. 2020;323(22):2290–300. PMID: 32515813. 10.1001/jama.2020.6504 32515813
- Negeri ZF, Levis B, Sun Y, . Accuracy of the Patient Health Questionnaire-9 for screening to detect major depression: updated systematic review and individual participant data meta-analysis. BMJ (Clinical research ed). 2021;375:n2183. PMID: 34610915. 10.1136/bmj.n2183 34610915
- Smith RD, Shing JSY, Lin J, . Meta-analysis of diagnostic properties of the Whooley questions to identify depression in perinatal women. Journal of affective disorders. 2022;315:148–55. PMID: 35931230. 10.1016/j.jad.2022.07.026 35931230
- Vilagut G, Forero CG, Barbaglia G, . Screening for Depression in the General Population with the Center for Epidemiologic Studies Depression (CES-D): A Systematic Review with Meta-Analysis. PLoS ONE [Electronic Resource]. 2016;11(5):e0155431. PMID: 27182821. 10.1371/journal.pone.0155431 27182821
- Wang, L., Kroenke, K., Stump, T. E., & Monahan, P. O. (2021). Screening for perinatal depression with the Patient Health Questionnaire depression scale (PHQ-9): A systematic review and meta-analysis. Gen Hosp Psychiatry, 68, 74–82. PMID: 3336052633360526. https://dx.doi.org/10.1016/j.genhosppsych.2020.12.007.
- Wu Y, Levis B, Riehm KE, . Equivalency of the diagnostic accuracy of the PHQ-8 and PHQ-9: a systematic review and individual participant data meta-analysis. Psychol Med. 2019:1–13. PMID: 3129818031298180. 10.1017/S0033291719001314

#### KQs 4-5: Included ESRs for treatment benefits and harms, by intervention type

##### Psychological interventions

- Aherne D, Fitzgerald A, Aherne C, . Evidence for the treatment of moderate depression: a systematic review. Ir J Psychol Med. 2017;34(3):197–204. PMID: 30115148. 10.1017/ipm.2017.10 30115148
- Castro A, Gili M, Ricci-Cabello I, . Effectiveness and adherence of telephone-administered psychotherapy for depression: A systematic review and meta-analysis. Journal of affective disorders. 2020;260:514–26. PMID: 31539688. 10.1016/j.jad.2019.09.023 31539688
- Collado A, Lim AC, MacPherson L. A systematic review of depression psychotherapies among Latinos. Clin Psychol Rev. 2016;45:193–209. PMID: 27113679. 10.1016/j.cpr.2016.04.001 27113679
- Cuijpers P. Four decades of outcome research on psychotherapies for adult depression: An overview of a series of meta-analyses. Canadian Psychology/Psychologie canadienne. 2017;58(1):7–19. 10.1037/cap0000096
- Cuijpers P, Karyotaki E, de Wit L, . The effects of fifteen evidence-supported therapies for adult depression: A meta-analytic review. Psychother. 2020;30(3):279–93. PMID: 31394976. 10.1080/10503307.2019.1649732 31394976
- Cuijpers P, Karyotaki E, Reijnders M, . Was Eysenck right after all? A reassessment of the effects of psychotherapy for adult depression. Epidemiol Psychiatr Sci. 2019;28(1):21–30. PMID: 29486804. 10.1017/s2045796018000057 29486804
- Cuijpers P, Karyotaki E, Reijnders M, . Who benefits from psychotherapies for adult depression? A meta-analytic update of the evidence. Cognitive Behav Ther. 2018;47(2):91–106. PMID: 29345530. 10.1080/16506073.2017.1420098 29345530
- Cuijpers P, Quero S, Papola D, . Care-as-usual control groups across different settings in randomized trials on psychotherapy for adult depression: a meta-analysis. Psychol Med. 2019:1–11. PMID: 3184303131843031. 10.1017/S0033291719003581
- Cuijpers P, Reijnders M, Karyotaki E, . Negative effects of psychotherapies for adult depression: A meta-analysis of deterioration rates. Journal of affective disorders. 2018;239:138–45. PMID: 30005327. 10.1016/j.jad.2018.05.050 30005327
- Driessen E, Hollon SD, Bockting CL, . Does Publication Bias Inflate the Apparent Efficacy of Psychological Treatment for Major Depressive Disorder? A Systematic Review and Meta-Analysis of US National Institutes of Health-Funded Trials. PLoS ONE [Electronic Resource]. 2015;10(9):e0137864. PMID: 26422604. 10.1371/journal.pone.0137864 26422604
- Ebert DD, Donkin L, Andersson G, . Does Internet-based guided-self-help for depression cause harm? An individual participant data meta-analysis on deterioration rates and its moderators in randomized controlled trials. Psychol Med. 2016;46(13):2679–93. PMID: 27649340. 10.1017/S0033291716001562 27649340
- Harerimana B, Forchuk C, O’Regan T. The use of technology for mental healthcare delivery among older adults with depressive symptoms: A systematic literature review. Int J Ment Health Nurs. 2019;28(3):657–70. PMID: 30666762. 10.1111/inm.12571 30666762
- Harper Shehadeh M, Heim E, Chowdhary N, . Cultural Adaptation of Minimally Guided Interventions for Common Mental Disorders: A Systematic Review and Meta-Analysis. JMIR Ment Health. 2016;3(3):e44. PMID: 27670598. 10.2196/mental.5776 27670598
- Holvast F, Massoudi B, Oude Voshaar RC, . Non-pharmacological treatment for depressed older patients in primary care: A systematic review and meta-analysis. PLoS ONE [Electronic Resource]. 2017;12(9):e0184666. PMID: 28938015. 10.1371/journal.pone.0184666 28938015
- Huang L, Zhao Y, Qiang C, . Is cognitive behavioral therapy a better choice for women with postnatal depression? A systematic review and meta-analysis. PLoS ONE [Electronic Resource]. 2018;13(10):e0205243. PMID: 30321198. 10.1371/journal.pone.0205243 30321198
- Jonsson U, Bertilsson G, Allard P, . Psychological Treatment of Depression in People Aged 65 Years and Over: A Systematic Review of Efficacy, Safety, and Cost-Effectiveness. PLoS ONE [Electronic Resource]. 2016;11(8):e0160859. PMID: 27537217. 10.1371/journal.pone.0160859 27537217
- Karyotaki E, Kemmeren L, Riper H, . Is self-guided internet-based cognitive behavioural therapy (iCBT) harmful? An individual participant data meta-analysis. Psychol Med. 2018;48(15):2456–66. PMID: 29540243. 10.1017/s0033291718000648 29540243
- Karyotaki E, Ebert DD, Donkin L, . Do guided internet-based interventions result in clinically relevant changes for patients with depression? An individual participant data meta-analysis. Clin Psychol Rev. 2018;63:80–92. PMID: 29940401. 10.1016/j.cpr.2018.06.007 29940401
- Karyotaki E, Riper H, Twisk J, . Efficacy of Self-guided Internet-Based Cognitive Behavioral Therapy in the Treatment of Depressive Symptoms: A Meta-analysis of Individual Participant Data. JAMA Psychiatry. 2017;74(4):351–9. PMID: 28241179. 10.1001/jamapsychiatry.2017.0044 28241179
- Letourneau NL, Dennis CL, Cosic N, . The effect of perinatal depression treatment for mothers on parenting and child development: A systematic review. Depress Anxiety. 2017;34(10):928–66. PMID: 28962068. https://dx.doi.org/10.1002/da.22687 28962068
- Li X, Laplante DP, Paquin V, . Effectiveness of cognitive behavioral therapy for perinatal maternal depression, anxiety and stress: A systematic review and meta-analysis of randomized controlled trials. Clin Psychol Rev. 2022;92:102129. PMID: 35123346. 10.1016/j.cpr.2022.102129 35123346
- Massoudi B, Holvast F, Bockting CLH, . The effectiveness and cost-effectiveness of e-health interventions for depression and anxiety in primary care: A systematic review and meta-analysis. Journal of affective disorders. 2019;245:728–43. PMID: 30447572. 10.1016/j.jad.2018.11.050 30447572
- Nair U, Armfield NR, Chatfield MD, . The effectiveness of telemedicine interventions to address maternal depression: A systematic review and meta-analysis. Journal of Telemedicine & Telecare. 2018;24(10):639–50. PMID: 30343660. https://dx.doi.org/10.1177/1357633X18794332 30343660
- Nieuwenhuijsen K, Verbeek JH, Neumeyer-Gromen A, . Interventions to improve return to work in depressed people. Cochrane Database Syst Rev. 2020;10:CD006237. PMID: 33052607. 10.1002/14651858.CD006237.pub4 33052607
- Pineros-Leano M, Liechty JM, Piedra LM. Latino immigrants, depressive symptoms, and cognitive behavioral therapy: A systematic review. Journal of affective disorders. 2017;208:567–76. PMID: 27810273. 10.1016/j.jad.2016.10.025 27810273
- Ponting C, Mahrer NE, Zelcer H, . Psychological interventions for depression and anxiety in pregnant Latina and Black women in the United States: A systematic review. Clinical Psychology & Psychotherapy. 2020;27(2):249–65. PMID: 31960525. 10.1002/cpp.2424 31960525
- Rojas-Garcia A, Ruiz-Perez I, Rodriguez-Barranco M, . Healthcare interventions for depression in low socioeconomic status populations: A systematic review and meta-analysis. Clin Psychol Rev. 2015;38:65–78. PMID: 25797906. 10.1016/j.cpr.2015.03.001 25797906

#### Also included under depression pharmacologic interventions

- Roman M, Constantin T, Bostan CM. The efficiency of online cognitive-behavioral therapy for postpartum depressive symptomatology: a systematic review and meta-analysis. Women Health. 2020;60(1):99–112. PMID: 31057080. 10.1080/03630242.2019.1610824 31057080
- Thomas WJ, Hauson AO, Lambert JE, . A meta-analysis of the effectiveness of cognitive-behavioural therapies for late-life depression. Canadian Journal of Counselling and Psychotherapy. 2018;52(1):78–117.
- Weaver A, Himle JA. Cognitive-behavioral therapy for depression and anxiety disorders in rural settings: A review of the literature. Journal of Rural Mental Health. 2017;41(3):189–221. 10.1037/rmh0000075
- Weitz E, Kleiboer A, van Straten A, . The effects of psychotherapy for depression on anxiety symptoms: a meta-analysis. Psychol Med. 2018;48(13):2140–52. PMID: 29361995. 10.1017/s0033291717003622 29361995
- Xiang X, Wu S, Zuverink A, . Internet-delivered cognitive behavioral therapies for late-life depressive symptoms: a systematic review and meta-analysis. Aging Ment Health. 2019:1–11. PMID: 3091389830913898. 10.1080/13607863.2019.1590309
- Zhang A, Borhneimer LA, Weaver A, . Cognitive behavioral therapy for primary care depression and anxiety: a secondary meta-analytic review using robust variance estimation in meta-regression. J Behav Med. 2019;42(6):1117–41. PMID: 31004323. 10.1007/s10865-019-00046-z 31004323
- Zhang A, Franklin C, Jing S, . The effectiveness of four empirically supported psychotherapies for primary care depression and anxiety: A systematic review and meta-analysis. Journal of affective disorders. 2019;245:1168–86. PMID: 30699860. 10.1016/j.jad.2018.12.008 30699860

##### Pharmacologic interventions

- Arroll B, Chin WY, Martis W, . Antidepressants for treatment of depression in primary care: a systematic review and meta-analysis. J Prim Health Care. 2016;8(4):325–34. PMID: 29530157. 10.1071/HC16008 29530157
- Baune BT, Brignone M, Larsen KG. A Network Meta-Analysis Comparing Effects of Various Antidepressant Classes on the Digit Symbol Substitution Test (DSST) as a Measure of Cognitive Dysfunction in Patients with Major Depressive Disorder. Int J Neuropsychopharmcol. 2018;21(2):97–107. PMID: 29053849. 10.1093/ijnp/pyx070 29053849
- Braun C, Bschor T, Franklin J, . Suicides and Suicide Attempts during Long-Term Treatment with Antidepressants: A Meta-Analysis of 29 Placebo-Controlled Studies Including 6,934 Patients with Major Depressive Disorder. Psychother Psychosom. 2016;85(3):171–9. PMID: 27043848. 10.1159/000442293 27043848
- Chan JYC, Yiu KKL, Kwok TCY, . Depression and Antidepressants as Potential Risk Factors in Dementia: A Systematic Review and Meta-analysis of 18 Longitudinal Studies. J Am Med Dir Assoc. 2019;20(3):279–86.e1. PMID: 30711460. 10.1016/j.jamda.2018.12.004 30711460
- Cipriani A, Furukawa TA, Salanti G, . Comparative efficacy and acceptability of 21 antidepressant drugs for the acute treatment of adults with major depressive disorder: a systematic review and network meta-analysis. Lancet (London, England). 2018;391(10128):1357–66. PMID: 29477251. 10.1016/S0140-6736(17)32802-7 29477251
  - Boesen K, Paludan-Muller AS, Munkholm K. Network meta-analysis of antidepressants. The Lancet. 2018;392(10152):1011. 10.1016/S0140-6736%2818%2931783-5
  - Cipriani A, Furukawa TA, Salanti G, . Comparative Efficacy and Acceptability of 21 Antidepressant Drugs for the Acute Treatment of Adults With Major Depressive Disorder: A Systematic Review and Network Meta-Analysis. Focus. 2018;16(4):420–9. PMID: 32021580. 10.1176/appi.focus.16407 32021580
  - Munkholm K, Paludan-Muller AS, Boesen K. Considering the methodological limitations in the evidence base of antidepressants for depression: a reanalysis of a network meta-analysis. BMJ Open. 2019;9(6):e024886. PMID: 31248914. 10.1136/bmjopen-2018-024886 31248914
- Cuijpers P, de Wit L, Weitz E, . The combination of psychotherapy and pharmacotherapy in the treatment of adult depression: A comprehensive meta-analysis. Journal of Evidence-Based Psychotherapies. 2015;15(2):147–68.
- Gibbons RD, Brown CH, Hur K, . Suicidal thoughts and behavior with antidepressant treatment: reanalysis of the randomized placebo-controlled studies of fluoxetine and venlafaxine. Archives of general psychiatry. 2012;69(6):580–7. PMID: 22309973. 10.1001/archgenpsychiatry.2011.2048 22309973
  - Gibbons RD, Hur K, Brown CH, . Benefits From Antidepressants: Synthesis of 6-Week Patient-Level Outcomes From Double-blind Placebo-Controlled Randomized Trials of Fluoxetine and Venlafaxine. Archives of general psychiatry. 2012;69(6):572–9. 10.1001/archgenpsychiatry.2011.2044 22393205
- Gumusoglu SB, Schickling BM, Vignato JA, . Selective serotonin reuptake inhibitors and preeclampsia: A quality assessment and meta-analysis. Pregnancy Hypertens. 2022;30:36–43. PMID: 35963154. 10.1016/j.preghy.2022.08.001 35963154
- Hengartner MP, Amendola S, Kaminski JA, . Suicide risk with selective serotonin reuptake inhibitors and other new-generation antidepressants in adults: a systematic review and meta-analysis of observational studies. J Epidemiol Community Health. 2021. PMID: 3368596433685964. 10.1136/jech-2020-214611
- Jacobsen PL. Antidepressant-associated sexual dysfunction in patients with depression: A meta-analysis of sexual functioning data collected via prospective questionnaires. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2019;80(8-B(E)):No Pagination Specified.
- Jakobsen JC, Katakam KK, Schou A, . Selective serotonin reuptake inhibitors versus placebo in patients with major depressive disorder. A systematic review with meta-analysis and Trial Sequential Analysis. BMC Psychiatry. 2017;17(1):58. PMID: 28178949. 10.1186/s12888-016-1173-2 28178949
  - Katakam KK, Sethi NJ, Jakobsen JC, . Great boast, small roast on effects of selective serotonin reuptake inhibitors: response to a critique of our systematic review. Acta Neuropsychiatr. 2018;30(5):251–65. PMID: 29465026. 10.1017/neu.2017.38 29465026
- Jensen MP, Ziff OJ, Banerjee G, . The impact of selective serotonin reuptake inhibitors on the risk of intracranial haemorrhage: A systematic review and meta-analysis. European Stroke Journal. 2019;4(2):144–52. PMID: 31259262. 10.1177/2396987319827211 31259262
- Kaminski JA, Bschor T. Antidepressants and suicidality: A re-analysis of the re-analysis. Journal of affective disorders. 2020;266:95–9. PMID: 32056952. 10.1016/j.jad.2020.01.107 32056952
  - Khan A, Fahl Mar K, Gokul S, . Decreased suicide rates in recent antidepressant clinical trials. Psychopharmacology (Berl). 2018;235(5):1455–62. PMID: 29480436. 10.1007/s00213-018-4856-1 29480436
  - Hengartner MP, Ploderl M. Newer-Generation Antidepressants and Suicide Risk in Randomized Controlled Trials: A Re-Analysis of the FDA Database. Psychother Psychosom. 2019;88(4):247–8. PMID: 31234169. 10.1159/000501215 31234169
- Khanassov V, Hu J, Reeves D, . Selective serotonin reuptake inhibitor and selective serotonin and norepinephrine reuptake inhibitor use and risk of fractures in adults: A systematic review and meta-analysis. Int J Geriatr Psychiatry. 2018;33(12):1688–708. PMID: 30247774. 10.1002/gps.4974 30247774
- KoKoAung E, Cavenett S, McArthur A, . The association between suicidality and treatment with selective serotonin reuptake inhibitors in older people with major depression: a systematic review. JBI Database System Rev Implement Rep. 2015;13(3):174–205. PMID: 26447056. 10.11124/jbisrir-2015-2272 26447056
- Krause M, Gutsmiedl K, Bighelli I, . Efficacy and tolerability of pharmacological and nonpharmacological interventions in older patients with major depressive disorder: A systematic review, pairwise and network meta-analysis. Eur Neuropsychopharmacol. 2019;29(9):1003–22. PMID: 31327506. 10.1016/j.euroneuro.2019.07.130 31327506
- Kunutsor SK, Seidu S, Khunti K. Depression, antidepressant use, and risk of venous thromboembolism: systematic review and meta-analysis of published observational evidence. Ann Med. 2018;50(6):529–37. PMID: 30001640. 10.1080/07853890.2018.1500703 30001640
- Lee Y, Rosenblat JD, Lee J, . Efficacy of antidepressants on measures of workplace functioning in major depressive disorder: A systematic review. Journal of affective disorders. 2018;227:406–15. PMID: 29154157. 10.1016/j.jad.2017.11.003 29154157
- Lisinski A, Hieronymus F, Naslund J, . Item-based analysis of the effects of duloxetine in depression: A patient-level post hoc study. Neuropsychopharmacology. 2020;45(3):553–60. 10.1038/s41386-019-0523-4 31521062
- Maslej MM, Bolker BM, Russell MJ, . The Mortality and Myocardial Effects of Antidepressants Are Moderated by Preexisting Cardiovascular Disease: A Meta-Analysis. Psychother Psychosom. 2017;86(5):268–82. PMID: 28903117. 10.1159/000477940 28903117
- Na KS, Jung HY, Cho SJ, . Can we recommend mirtazapine and bupropion for patients at risk for bleeding?: A systematic review and meta-analysis. Journal of affective disorders. 2018;225:221–6. PMID: 28841484. 10.1016/j.jad.2017.08.002 28841484
- Naslund J, Hieronymus F, Lisinski A, . Effects of selective serotonin reuptake inhibitors on ratingscale-assessed suicidality in adults with depression. The British Journal of Psychiatry. 2018;212(3):148–54. 10.1192/bjp.2017.24 29436321
- Rabinowitz J, Werbeloff N, Mandel FS, . Initial depression severity and response to antidepressants v. placebo: patient-level data analysis from 34 randomised controlled trials. Br J Psychiatry. 2016;209(5):427–8. PMID: 27198482. 10.1192/bjp.bp.115.173906 27198482
- Rojas-Garcia A, Ruiz-Perez I, Rodriguez-Barranco M, . Healthcare interventions for depression in low socioeconomic status populations: A systematic review and meta-analysis. Clin Psychol Rev. 2015;38:65–78. PMID: 25797906. 10.1016/j.cpr.2015.03.001 25797906

#### Also included under depression psychological interventions

- Sobieraj DM, Martinez BK, Hernandez AV, . Adverse Effects of Pharmacologic Treatments of Major Depression in Older Adults. J Am Geriatr Soc. 2019;67(8):1571–81. PMID: 31140587. 10.1111/jgs.15966 31140587
  - Sobieraj DM, Baker WL, Martinez BK, . Adverse Effects of Pharmacologic Treatments of Major Depression in Older Adults. Agency for Healthcare Research and Quality (US). 2019:03. PMID: 3096461630964616.
- Trajkova S, d’Errico A, Soffietti R, . Use of Antidepressants and Risk of Incident Stroke: A Systematic Review and Meta-Analysis. Neuroepidemiology. 2019;53(3-4):142–51. PMID: 31216542. 10.1159/000500686 31216542
- Valuck RJ, Libby AM, Anderson HD, . Comparison of antidepressant classes and the risk and time course of suicide attempts in adults: propensity matched, retrospective cohort study. Br J Psychiatry. 2016;208(3):271–9. PMID: 26635328. 10.1192/bjp.bp.114.150839 26635328

### Cohort study

- Vlenterie R, van Gelder M, Anderson HR, . Associations Between Maternal Depression, Antidepressant Use During Pregnancy, and Adverse Pregnancy Outcomes: An Individual Participant Data Meta-analysis. Obstetrics and gynecology. 2021;138(4):633–46. PMID: 34623076. 10.1097/AOG.0000000000004538 34623076
- Viswanathan M, Middleton JC, Stuebe AM, . Maternal, Fetal, and Child Outcomes of Mental Health Treatments in Women: A Meta-Analysis of Perinatal Pharmacotherapy. Psychiatric Research and Clinical Practice. 2021;3(3):123–40. 10.1176/appi.prcp.20210001 36101835
- Wang YC, Tai PA, Poly TN, . Increased Risk of Dementia in Patients with Antidepressants: A Meta-Analysis of Observational Studies. Behav. 2018;2018:5315098. PMID: 30123386. 10.1155/2018/5315098 30123386

## Appendix C List 2 Included evidence for anxiety, by KQ

### Ancillary publication(s) indented under primary article

#### KQs 1 and 3: Included studies for screening benefits and harms, by author

- Mathias SD, Fifer SK, Mazonson PD, . Necessary but not sufficient: the effect of screening and feedback on outcomes of primary care patients with untreated anxiety. Journal of general internal medicine. 1994;9(11):606–15. PMID: 7853069. 10.1007/BF02600303 7853069
  - Fifer S, Mathias S, Patrick D, . Untreated anxiety among adult primary care patients in a Health Maintenance Organization. Archives of general psychiatry. 1994;51(9):740–50.8080351
  - Yelin E, Mathias SD, Buesching DP, . The impact on unemployment of an intervention to increase recognition of previously untreated anxiety among primary care physicians. Soc Sci Med. 1996;42(7):1069–75. PMID: 8730912. 10.1016/0277-9536(95)00297-9 8730912
- Kroenke K, Talib TL, Stump TE, . Incorporating PROMIS Symptom Measures into Primary Care Practice-a Randomized Clinical Trial. Journal of general internal medicine. 2018;33(8):1245–52. PMID: 29623512. 10.1007/s11606-018-4391-0 29623512

#### KQ 2: Included studies for test accuracy, by author

- Ahn JK, Kim Y, Choi KH. The Psychometric Properties and Clinical Utility of the Korean Version of GAD-7 and GAD-2. Front Psychiatr. 2019;10:127. PMID: 30936840. 10.3389/fpsyt.2019.00127 30936840
- Austin MV, Mule V, Hadzi-Pavlovic D, . Screening for anxiety disorders in third trimester pregnancy: a comparison of four brief measures. Arch Women Ment Health. 2021;05:05. PMID: 34350480. 10.1007/s00737-021-01166-9 34350480
- Gould CE, Segal DL, Yochim BP, . Measuring anxiety in late life: a psychometric examination of the geriatric anxiety inventory and geriatric anxiety scale. Journal of Anxiety Disorders. 2014;28(8):804–11. PMID: 25271176. 10.1016/j.janxdis.2014.08.001 25271176
- Kujanpaa T, Ylisaukko-Oja T, Jokelainen J, . Prevalence of anxiety disorders among Finnish primary care high utilizers and validation of Finnish translation of GAD-7 and GAD-2 screening tools. Scand J Prim Health Care. 2014;32(2):78–83. PMID: 24920316. 10.3109/02813432.2014.920597 24920316
- Makulowich AA. Identification of patients with anxiety symptoms in an integrated community care clinic among a predominantly Latino patient population. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2019;80(1-B(E)):No Pagination Specified.
- Matthey S, Valenti B, Souter K, . Comparison of four self-report measures and a generic mood question to screen for anxiety during pregnancy in English-speaking women. Journal of affective disorders. 2013;148(2-3):347–51. PMID: 23380518. 10.1016/j.jad.2012.12.022 23380518
- Nath S, Ryan EG, Trevillion K, . Prevalence and identification of anxiety disorders in pregnancy: the diagnostic accuracy of the two-item Generalised Anxiety Disorder scale (GAD-2). BMJ Open. 2018;8(9):e023766. PMID: 30185582. 10.1136/bmjopen-2018-023766 30185582
- Spitzer RL, Kroenke K, Williams JB. Validation and utility of a self-report version of PRIME-MD: the PHQ primary care study. Primary Care Evaluation of Mental Disorders. Patient Health Questionnaire. Jama. 1999/11/24 ed1999. p. 1737–44. PMID: 1056864610568646. 10.1001/jama.282.18.1737
- Spitzer RL, Kroenke K, Williams JB, . A brief measure for assessing generalized anxiety disorder: the GAD-7. Arch Intern Med. 2006;166(10):1092–7. PMID: 16717171. 10.1001/archinte.166.10.1092 16717171
  - Kroenke K, Spitzer RL, Williams JB, . Anxiety disorders in primary care: prevalence, impairment, comorbidity, and detection. Ann Intern Med. 2007;146(5):317–25. PMID: 17339617. 10.7326/0003-4819-146-5-200703060-00004 17339617
- Vasiliadis HM, Chudzinski V, Gontijo-Guerra S, . Screening instruments for a population of older adults: The 10-item Kessler Psychological Distress Scale (K10) and the 7-item Generalized Anxiety Disorder Scale (GAD-7). Psychiatry Res. 2015;228(1):89–94. PMID: 25956759. 10.1016/j.psychres.2015.04.019 25956759
  - Preville M, Boyer R, Grenier S, . The epidemiology of psychiatric disorders in Quebec’s older adult population. Can J Psychiatry. 2008;53(12):822–32. PMID: 19087480. 10.1177/070674370805301208 19087480

#### KQs 4-5: Included studies for treatment benefits and harms, by study design

##### Anxiety Primary studies

###### Psychological interventions

- Burger H, Verbeek T, Aris-Meijer JL, . Effects of psychological treatment of mental health problems in pregnant women to protect their offspring: randomised controlled trial. Br J Psychiatry. 2020;216(4):182–8. PMID: 31806071. 10.1192/bjp.2019.260 31806071
- Clark DM, Wild J, Warnock-Parkes E, . More than doubling the clinical benefit of each hour of therapist time: a randomised controlled trial of internet cognitive therapy for social anxiety disorder. Psychol Med. 2022:1–11. PMID: 3583572635835726. 10.1017/S0033291722002008
- Corpas J, Moriana JA, Vencesla JF, . Effectiveness of brief group transdiagnostic therapy for emotional disorders in primary care: A randomized controlled trial identifying predictors of outcome. Psychother. 2021:1–14. PMID: 3426964034269640. 10.1080/10503307.2021.1952331
- Fletcher J, Lovell K, Bower P, . Process and Outcome of a Non-Guided Self-Help Manual for Anxiety and Depression in Primary Care: A Pilot Study. Behav. 2005;33(3):319–31. 10.1017/S1352465805002079
- Gensichen J, Hiller TS, Breitbart J, . Panic Disorder in Primary Care. Dtsch. 2019;116(10):159–66. PMID: 30995952. 10.3238/arztebl.2019.0159 30995952
  - Brettschneider C, Gensichen J, Hiller TS, . Cost-effectiveness of Practice Team-Supported Exposure Training for Panic Disorder and Agoraphobia in Primary Care: a Cluster-Randomized Trial. Journal of general internal medicine. 2020;35(4):1120–6. PMID: 31965532. 10.1007/s11606-020-05658-9 31965532
- Graham AK, Greene CJ, Kwasny MJ, . Coached Mobile App Platform for the Treatment of Depression and Anxiety Among Primary Care Patients: A Randomized Clinical Trial. JAMA Psychiatry. 2020;20:20. PMID: 32432695. 10.1001/jamapsychiatry.2020.1011 32432695
- Kendrick T, Simons L, Mynors-Wallis L, . A trial of problem-solving by community mental health nurses for anxiety, depression and life difficulties among general practice patients. The CPN-GP study. Health Technol Assess. 2005;9(37):1–104, iii. PMID: 16153354. 10.3310/hta9370 16153354
- King M, Sibbald B, Ward E, . Randomised controlled trial of non-directive counselling, cognitive-behaviour therapy and usual general practitioner care in the management of depression as well as mixed anxiety and depression in primary care. Health Technol Assess. 2000;4(19):1–83. PMID: 11086269.11086269
- Lam CLK, Fong DYT, Chin WY, . Brief problem-solving treatment in primary care (PST-PC) was not more effective than placebo for elderly patients screened positive of psychological problems. Int J Geriatr Psychiatry. 2010;25(10):968. 10.1002/gps.2435 20033901
- Lang AJ, Norman GJ, Casmar PV. A randomized trial of a brief mental health intervention for primary care patients. J Consult Clin Psychol. 2006;74(6):1173–9. PMID: 17154746. 10.1037/0022-006x.74.6.1173 17154746
- Linden M, Zubraegel D, Baer T, . Efficacy of cognitive behaviour therapy in generalized anxiety disorders. Results of a controlled clinical trial (Berlin CBT-GAD Study). Psychother Psychosom. 2005;74(1):36–42. PMID: 15627855. 10.1159/000082025 15627855
- Nordgren LB, Hedman E, Etienne J, . Effectiveness and cost-effectiveness of individually tailored Internet-delivered cognitive behavior therapy for anxiety disorders in a primary care population: a randomized controlled trial. Behav Res Ther. 2014;59:1–11. PMID: 24933451. 10.1016/j.brat.2014.05.007 24933451
- O’Mahen HA, Ramchandani PG, King DX, . Adapting and testing a brief intervention to reduce maternal anxiety during pregnancy (ACORN): report of a feasibility randomized controlled trial. BMC Psychiatry. 2022;22(1):129. PMID: 35177019. 10.1186/s12888-022-03737-1 35177019
- Proudfoot J, Ryden C, Everitt B, . Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. Br J Psychiatry. 2004;185:46–54. PMID: 15231555. 10.1192/bjp.185.1.46 15231555
  - Proudfoot J, Goldberg D, Mann A, . Computerized, interactive, multimedia cognitivebehavioural program for anxiety and depression in general practice. Psychol Med. 2003;33(2):217–27. PMID: 12622301. https://dx.doi.org/10.1017/s0033291702007225 12622301
- Rollman BL, Herbeck Belnap B, Abebe KZ, . Effectiveness of Online Collaborative Care for Treating Mood and Anxiety Disorders in Primary Care: A Randomized Clinical Trial. JAMA Psychiatry. 2018;75(1):56–64. PMID: 29117275. 10.1001/jamapsychiatry.2017.3379 29117275
  - Geramita EM, Herbeck Belnap B, Abebe KZ, . The Association Between Increased Levels of Patient Engagement With an Internet Support Group and Improved Mental Health Outcomes at 6-Month Follow-Up: Post-Hoc Analyses From a Randomized Controlled Trial. J Med Internet Res. 2018;20(7):e10402. PMID: 30021711. 10.2196/10402 30021711
  - Jonassaint CR, Belnap BH, Huang Y, . Racial Differences in the Effectiveness of Internet-Delivered Mental Health Care. Journal of general internal medicine. 2020;35(2):490–7. PMID: 31745855. 10.1007/s11606-019-05542-1 31745855
  - Jonassaint CR, Gibbs P, Belnap BH, . Engagement and outcomes for a computerised cognitive-behavioural therapy intervention for anxiety and depression in African Americans. BJPsych open. 2017;3(1):1–5. PMID: 28058109. 10.1192/bjpo.bp.116.003657 28058109
- Roy-Byrne P, Craske MG, Sullivan G, . Delivery of evidence-based treatment for multiple anxiety disorders in primary care: a randomized controlled trial. JAMA. 2010;303(19):1921–8. PMID: 20483968. 10.1001/jama.2010.608 20483968
  - Brown LA, Krull JL, Roy-Byrne P, . An examination of the bidirectional relationship between functioning and symptom levels in patients with anxiety disorders in the CALM study. Psychol Med. 2015;45(3):647–61. PMID: 25272965. 10.1017/S0033291714002062 25272965
  - Craske MG, Stein MB, Sullivan G, . Disorder-specific impact of coordinated anxiety learning and management treatment for anxiety disorders in primary care. Archives of general psychiatry. 2011;68(4):378–88. PMID: 21464362. 10.1001/archgenpsychiatry.2011.25 21464362
  - Wolitzky-Taylor K, Brown LA, Roy-Byrne P, . The impact of alcohol use severity on anxiety treatment outcomes in a large effectiveness trial in primary care. Journal of Anxiety Disorders. 2015;30:88–93. PMID: 25615523. 10.1016/j.janxdis.2014.12.011 25615523
- Schreuders B, van Marwijk H, Smit J, . Primary care patients with mental health problems: outcome of a randomised clinical trial. British Journal of General Practice. 2007;57(544):886–91. PMID: 17976289. 10.3399/096016407782317829 17976289
- Seekles W, van Straten A, Beekman A, . Effectiveness of guided self-help for depression and anxiety disorders in primary care: a pragmatic randomized controlled trial. Psychiatry Res. 2011;187(1-2):113–20. PMID: 21145112. 10.1016/j.psychres.2010.11.015 21145112
- Stanley MA, Wilson NL, Amspoker AB, . Lay providers can deliver effective cognitive behavior therapy for older adults with generalized anxiety disorder: a randomized trial. Depress Anxiety. 2014;31(5):391–401. PMID: 24577847. 10.1002/da.22239 24577847
- Stanley MA, Wilson NL, Novy DM, . Cognitive behavior therapy for generalized anxiety disorder among older adults in primary care: a randomized clinical trial. Jama. 2009;301(14):1460–7. PMID: 19351943. 10.1001/jama.2009.458 19351943
- Suchan V, Peynenburg V, Thiessen D, . Transdiagnostic Internet-Delivered Cognitive Behavioral Therapy for Symptoms of Postpartum Anxiety and Depression: Feasibility Randomized Controlled Trial. JMIR Form Res. 2022;6(9):e37216. PMID: 36066958. 10.2196/37216 36066958
  - Suchan VAM. Examining the acceptability and effectiveness of transdiagnostic, internet-delivered cognitive behaviour therapy for symptoms of postpartum anxiety and depression: A randomized controlled trial. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2022;83(10-B):No Pagination Specified.
- Sundquist J, Lilja Å, Palmér K, . Mindfulness group therapy in primary care patients with depression, anxiety and stress and adjustment disorders: randomised controlled trial. Br J Psychiatry. 2015;206(2):128–35. PMID: 25431430. 10.1192/bjp.bp.114.150243 25431430
  - Sundquist J, Palmer K, Johansson LM, . The effect of mindfulness group therapy on a broad range of psychiatric symptoms: A randomised controlled trial in primary health care. Eur Psychiatry. 2017;43:19–27. PMID: 28365464. http://doi.org/10.1016/j.eurpsy.2017.01.328 28365464
  - Sundquist J, Palmér K, Memon AA, . Long-term improvements after mindfulness-based group therapy of depression, anxiety and stress and adjustment disorders: a randomized controlled trial. Early intervention in psychiatry. 2018. 10.1111/eip.12715
- Torres-Platas SG, Escobar S, Belliveau C, . Mindfulness-Based Cognitive Therapy Intervention for the Treatment of Late-Life Depression and Anxiety Symptoms in Primary Care: A Randomized Controlled Trial. Psychother Psychosom. 2019;88(4):254–6. PMID: 31288245. 10.1159/000501214 31288245

###### Pharmacological interventions/exposure

- Cato V, Hollandare F, Nordenskjold A, . Association between benzodiazepines and suicide risk: a matched case-control study. BMC Psychiatry. 2019;19(1):317. PMID: 31655565. 10.1186/s12888-019-2312-3 31655565
- Lader M, Scotto JC. A multicentre double-blind comparison of hydroxyzine, buspirone and placebo in patients with generalized anxiety disorder. Psychopharmacology (Berl). 1998;139(4):402–6. PMID: 9809861. 10.1007/s002130050731 9809861
- Lenox-Smith AJ, Reynolds A. A double-blind, randomised, placebo controlled study of venlafaxine XL in patients with generalised anxiety disorder in primary care. Br J Gen Pract. 2003;53(495):772–7. PMID: 14601352.14601352
- Lenze EJ, Rollman BL, Shear MK, . Escitalopram for older adults with generalized anxiety disorder: a randomized controlled trial. Jama. 2009;301(3):295–303. PMID: 19155456. 10.1001/jama.2008.977 19155456
- Sheehy O, Zhao JP, Berard A. Association Between Incident Exposure to Benzodiazepines in Early Pregnancy and Risk of Spontaneous Abortion. JAMA Psychiatry. 2019;15:15. PMID: 31090881. 10.1001/jamapsychiatry.2019.0963 31090881
- Vera M, Oben A, Juarbe D, . Randomized pilot trial of cognitive-behavioral therapy and acceptance-based behavioral therapy in the treatment of Spanish-speaking Latino primary care patients with generalized anxiety disorder. Journal of Behavioral and Cognitive Therapy. 2021;31(2):91–103. 10.1016/j.jbct.2020.11.007 35813157

##### Anxiety ESRs

###### Psychological interventions

- Cuijpers P, Cristea IA, Karyotaki E, . How effective are cognitive behavior therapies for major depression and anxiety disorders? A meta-analytic update of the evidence. World psychiatry : official journal of the World Psychiatric Association (WPA). 2016;15(3):245–58. PMID: 27717254. 10.1002/wps.20346 27717254
- Cuijpers P, Cristea IA, Weitz E, . The effects of cognitive and behavioural therapies for anxiety disorders on depression: a meta-analysis. Psychol Med. 2016;46(16):3451–62. PMID: 27659840. 10.1017/S0033291716002348 27659840
- Gould RL, Coulson MC, Howard RJ. Efficacy of cognitive behavioral therapy for anxiety disorders in older people: a meta-analysis and meta-regression of randomized controlled trials. J Am Geriatr Soc. 2012;60(2):218–29. PMID: 22283717. 10.1111/j.1532-5415.2011.03824.x 22283717
- Hofmann SG, Wu JQ, Boettcher H. Effect of cognitive-behavioral therapy for anxiety disorders on quality of life: a meta-analysis. J Consult Clin Psychol. 2014;82(3):375–91. PMID: 24447006. 10.1037/a0035491 24447006
- Li X, Laplante DP, Paquin V, . Effectiveness of cognitive behavioral therapy for perinatal maternal depression, anxiety and stress: A systematic review and meta-analysis of randomized controlled trials. Clin Psychol Rev. 2022;92:102129. PMID: 35123346. 10.1016/j.cpr.2022.102129 35123346
- van Dis EAM, van Veen SC, Hagenaars MA, . Long-term Outcomes of Cognitive Behavioral Therapy for Anxiety-Related Disorders: A Systematic Review and Meta-analysis. JAMA Psychiatry. 2020;77(3):265–73. PMID: 31758858. 10.1001/jamapsychiatry.2019.3986 31758858
- Ponting C, Mahrer NE, Zelcer H, . Psychological interventions for depression and anxiety in pregnant Latina and Black women in the United States: A systematic review. Clinical Psychology & Psychotherapy. 2020;27(2):249–65. PMID: 31960525. 10.1002/cpp.2424 31960525
- Weaver A, Himle JA. Cognitive-behavioral therapy for depression and anxiety disorders in rural settings: A review of the literature. Journal of Rural Mental Health. 2017;41(3):189–221. PMID: 31004323. 10.1037/rmh0000075 31004323

###### Pharmacological interventions

- Imai H, Tajika A, Chen P, . Azapirones versus placebo for panic disorder in adults. Cochrane Database Syst Rev. 2014(9). 10.1002/14651858.CD010828.pub2
- Roest AM, de Jonge P, Williams CD, . Reporting Bias in Clinical Trials Investigating the Efficacy of Second-Generation Antidepressants in the Treatment of Anxiety Disorders: A Report of 2 Meta-analyses. JAMA Psychiatry. 2015;72(5):500–10. PMID: 25806940. 10.1001/jamapsychiatry.2015.15 25806940
- Slee A, Nazareth I, Bondaronek P, . Pharmacological treatments for generalised anxiety disorder: a systematic review and network meta-analysis. Lancet (London, England). 2019;393(10173):768–77. PMID: 30712879. 10.1016/S0140-6736(18)31793-8 30712879
- Williams T, Hattingh CJ, Kariuki CM, . Pharmacotherapy for social anxiety disorder (SAnD). Cochrane Database Syst Rev. 2017;10:CD001206. PMID: 29048739. 10.1002/14651858.CD001206.pub3 29048739
- Viswanathan M. Maternal, Fetal, and Child Outcomes of Mental Health Treatments in Women: A Meta-Analysis of Perinatal Pharmacotherapy. 2021.

## Appendix C List 3 Included evidence for suicide risk, by KQ

### Ancillary publication(s) indented under primary article

#### KQs 1 and 3: Included studies for screening benefits and harms

- Crawford MJ, Thana L, Methuen C, . Impact of screening for risk of suicide: randomised controlled trial. Br J Psychiatry. 2011;198:379–84. PMID: 21525521. 10.1192/bjp.bp.110.083592 21525521

#### KQ 2: Included studies for test accuracy, by study design

- Desjardins I, Cats-Baril W, Maruti S, . Suicide Risk Assessment in Hospitals: An Expert System-Based Triage Tool. Journal of Clinical Psychiatry. 2016;77(7):e874–82. PMID: 27314465. 10.4088/JCP.15m09881 27314465
- Heisel MJ, Duberstein PR, Lyness JM, . Screening for suicide ideation among older primary care patients. Journal of the American Board of Family Medicine : JABFM. 2010;23(2):260–9. PMID: 20207936. https://doi.org/10.3122/jabfm.2010.02.080163 20207936
- Olfson M, Weissman MM, Leon AC, . Suicidal ideation in primary care. Journal of general internal medicine. 1996;11(8):447–53. PMID: 8872781. https://doi.org/10.1007/bf02599038 8872781

#### KQs 4-5: Included studies for treatment benefits and harms, by author

- Borschmann R, Barrett B, Hellier JM, . Joint crisis plans for people with borderline personality disorder: feasibility and outcomes in a randomised controlled trial. Br J Psychiatry. 2013;202(5):357–64. PMID: 23637110. 10.1192/bjp.bp.112.117762 23637110
- Bruce ML, Ten Have TR, Reynolds CF, III, . Reducing suicidal ideation and depressive symptoms in depressed older primary care patients: a randomized controlled trial. JAMA. 2004;291(9):1081–91. PMID: 14996777. https://doi.org/10.1001/jama.291.9.1081 14996777
  - Alexopoulos GS, Reynolds CF, III, Bruce ML, . Reducing suicidal ideation and depression in older primary care patients: 24-month outcomes of the PROSPECT study. Am J Psychiatry. 2009;166(8):882–90. PMID: 19528195. 10.1176/appi.ajp.2009.08121779 19528195
  - Bao Y, Alexopoulos GS, Casalino LP, . Collaborative depression care management and disparities in depression treatment and outcomes. Archives of General Psychiatry2011. p. 627–36. PMID: 2164657921646579. 10.1001/archgenpsychiatry.2011.55
  - Bogner HR, Joo JH, Hwang S, . Does a Depression Management Program Decrease Mortality in Older Adults with Specific Medical Conditions in Primary Care? An Exploratory Analysis. J Am Geriatr Soc. 2016;64(1):126–31. PMID: 26782861. 10.1111/jgs.13711 26782861
  - Bogner HR, Morales KH, Post EP, . Diabetes, depression, and death: a randomized controlled trial of a depression treatment program for older adults based in primary care (PROSPECT). Diabetes Care. 2007;30(12):3005–10. PMID: 17717284. https://doi.org/10.2337/dc07-0974 17717284
  - Byers AL, Bruce ML, Raue P. Suicidal ideation in non-depressed elderly primary care patients: The PROSPECT Study. Am J Geriatr Psychiatry. 2009;17:A86.
  - Coyne JC, Koppel J, Colenda CC, . Interventions for treatment of depression in primary care. JAMA. 2004;291(23):2814–6. PMID: 15199023. https://doi.org/10.1001/jama.291.23.2814-a 15199023
  - Gallo JJ, Bogner HR, Morales KH, . The effect of a primary care practice-based depression intervention on mortality in older adults: a randomized trial. Ann Intern Med. 2007;146(10):689–98. PMID: 17502629. https://doi.org/10.7326/0003-4819-146-10-200705150-00002 17502629
  - Thombs BD, Ziegelstein RC. Diabetes, depression, and death: a randomized controlled trial of a depression treatment program for older adults based in primary care (PROSPECT): response to Bogner et al. Diabetes Care. 2008;31(6):e54–e. PMID: 18509141. https://doi.org/10.2337/dc08-0446 18509141
- Bush NE, Smolenski DJ, Denneson LM, . A Virtual Hope Box: Randomized Controlled Trial of a Smartphone App for Emotional Regulation and Coping With Distress. Psychiatr Serv. 2017;68(4):330–6. 10.1176/appi.ps.201600283 27842473
- Carter GL, Willcox CH, Lewin TJ, . Hunter DBT project: randomized controlled trial of dialectical behaviour therapy in women with borderline personality disorder. Aust N Z J Psychiatry. 2010;44(2):162–73. PMID: 20113305. https://doi.org/10.3109/00048670903393621 20113305
- Davidson K, Norrie J, Tyrer P, . The effectiveness of cognitive behavior therapy for borderline personality disorder: results from the borderline personality disorder study of cognitive therapy (BOSCOT) trial. J Pers Disord. 2006;20(5):450–65. PMID: 17032158. 10.1521/pedi.2006.20.5.450 17032158
- Franklin JC, Fox KR, Franklin CR, . A brief mobile app reduces nonsuicidal and suicidal self-injury: Evidence from three randomized controlled trials. J Consult Clin Psychol. 2016;84(6):544–57. 10.1037/ccp0000093 27018530
- Goodman M, Banthin D, Blair NJ, . A Randomized Trial of Dialectical Behavior Therapy in High-Risk Suicidal Veterans. Journal of Clinical Psychiatry. 2016;77(12):e1591–e600. PMID: 27780335. 10.4088/JCP.15m10235 27780335
- Jobes D, Comtois K, Gutierrez P, . A Randomized Controlled Trial of the Collaborative Assessment and Management of Suicidality versus Enhanced Care as Usual With Suicidal Soldiers. Psychiatry (new york). 2017;80(4):339–56. 10.1080/00332747.2017.1354607
- Katz IR, Rogers MP, Lew R, . Lithium Treatment in the Prevention of Repeat Suicide-Related Outcomes in Veterans With Major Depression or Bipolar Disorder: A Randomized Clinical Trial. JAMA Psychiatry. 2022;79(1):24–32. PMID: 34787653. 10.1001/jamapsychiatry.2021.3170 34787653
- Kovac SH, Range LM. Does writing about suicidal thoughts and feelings reduce them? Suicide & life-threatening behavior. 2002;32(4):428–40. PMID: 12501967. https://doi.org/10.1521/suli.32.4.428.22335 12501967
- Linehan MM, Comtois KA, Murray AM, . Two-year randomized controlled trial and follow-up of dialectical behavior therapy vs therapy by experts for suicidal behaviors and borderline personality disorder. Archives of general psychiatry. 2006;63(7):757–66. PMID: 16818865. 10.1001/archpsyc.63.7.757 16818865
  - Harned MS, Jackson SC, Comtois KA, . Dialectical behavior therapy as a precursor to PTSD treatment for suicidal and/or self-injuring women with borderline personality disorder. Journal of Traumatic Stress2010. p. 421–9. PMID: 2064856420648564. https://doi.org/10.1002/jts.20553
  - Reynolds SK, Lindenboim N, Comtois KA, . Risky assessments: participant suicidality and distress associated with research assessments in a treatment study of suicidal behavior. Suicide Life Threat Behav. 2006;36(1):19–34. PMID: 16676622. 10.1521/suli.2006.36.1.19 16676622
- McMain SF, Guimond T, Barnhart R, . A randomized trial of brief dialectical behaviour therapy skills training in suicidal patients suffering from borderline disorder. Acta Psychiatr Scand. 2017;135(2):138–48. PMID: 27858962. 10.1111/acps.12664 27858962
- Muhlmann C, Madsen T, Hjorthoj C, . Effectiveness of an Internet-Based Self-help Therapy Program for Suicidal Ideation With Follow-up at 6 Months: Results of a Randomized Controlled Trial. Journal of Clinical Psychiatry. 2021;82(5):31. PMID: 34464522. 10.4088/JCP.20m13803 34464522
- Pigeon WR, Funderburk JS, Cross W, . Brief CBT for insomnia delivered in primary care to patients endorsing suicidal ideation: a proof-of-concept randomized clinical trial. Transl Behav Med. 2019;9(6):1169–77. PMID: 31271210. https://dx.doi.org/10.1093/tbm/ibz108 31271210
- Pistorello J, Fruzzetti AE, Maclane C, . Dialectical behavior therapy (DBT) applied to college students: a randomized clinical trial. J Consult Clin Psychol. 2012;80(6):982–94. PMID: 22730955. 10.1037/a0029096 22730955
- Pistorello J, Jobes DA, Gallop R, . A Randomized Controlled Trial of the Collaborative Assessment and Management of Suicidality (CAMS) Versus Treatment as Usual (TAU) for Suicidal College Students. Arch. 2021;25(4):765–89. PMID: 32275480. 10.1080/13811118.2020.1749742 32275480
- Priebe S, Bhatti N, Barnicot K, . Effectiveness and cost-effectiveness of dialectical behaviour therapy for self-harming patients with personality disorder: a pragmatic randomised controlled trial. Psychother Psychosom. 2012;81(6):356–65. PMID: 22964561. 10.1159/000338897 22964561
  - Barnicot K, Savill M, Bhatti N, . A pragmatic randomised controlled trial of dialectical behaviour therapy: effects on hospitalisation and post-treatment follow-up. Psychother Psychosom. 2014;83(3):192–3. PMID: 24752222. 10.1159/000357365 24752222
- Riblet NB, Kenneally L, Stevens S, . A virtual, pilot randomized trial of a brief intervention to prevent suicide in an integrated healthcare setting. General hospital psychiatry. 2022;75:68–74. PMID: 35202942. 10.1016/j.genhosppsych.2022.02.002 35202942
- Simon GE, Shortreed SM, Rossom RC, . Effect of Offering Care Management or Online Dialectical Behavior Therapy Skills Training vs Usual Care on Self-harm Among Adult Outpatients With Suicidal Ideation: A Randomized Clinical Trial. JAMA. 2022;327(7):630–8. PMID: 35166800. 10.1001/jama.2022.0423 35166800
- Torok M, Han J, McGillivray L, . The effect of a therapeutic smartphone application on suicidal ideation in young adults: Findings from a randomized controlled trial in Australia. PLoS Med. 2022;19(5):e1003978. PMID: 35639672. 10.1371/journal.pmed.1003978 35639672
- van Orden KA, Arean PA, Conwell Y. A Pilot Randomized Trial of Engage Psychotherapy to Increase Social Connection and Reduce Suicide Risk in Later Life. Am J Geriatr Psychiatry. 2021;29(8):789–800. PMID: 33952416. 10.1016/j.jagp.2021.03.009 33952416
- van Spijker B, van Straten A, Kerkhof A. Effectiveness of online self-help for suicidal thoughts: results of a randomised controlled trial. PloS one. 2014;9(2):e90118. PMID: 24587233. 10.1371/journal.pone.0090118 24587233
- Ward-Ciesielski EF, Tidik JA, Edwards AJ, . Comparing brief interventions for suicidal individuals not engaged in treatment: A randomized clinical trial. Journal of affective disorders. 2017;222:153–61. PMID: 28709022. 10.1016/j.jad.2017.07.011 28709022
  - Ward-Ciesielski EF. An open pilot feasibility study of a brief dialectical behavior therapy skillsbased intervention for suicidal individuals. Suicide & life-threatening behavior. 2013;43(3):32435. PMID: 23409778. 10.1111/sltb.12019 23409778