# Appendix B Literature Flow

Appendix B Figure 1 Literature Flow Diagram

*Studies may appear in more than one Key Question.

This figure is a flow chart that summarizes the search and selection of articles for the review. There were 22,920 citations identified through literature databases. An additional 398 citations were identified from outside sources such as reference lists and suggestions from peer reviewers, 179 citations were from the most recent (2013 and 2016) USPSTF reviews. After duplicates were removed, 23,497 unique citations were screened at the title/abstract stage. The full-text of 1,237 citations were examined for inclusion for one or more of the Key Questions. The following number of studies were included for Key Question 1 (k=19), Key Question 2 (k=37), Key Question 3 (k=2), Key Question 4 (k=102), and Key Question 5 (k=44). Reasons for excluding the other articles are available in Appendix D.