# Appendix A Detailed Methods

## Search Strategy

Original search – Date delivered: 6/12/20

Bridge 1 – Date delivered: 9/24/21

Bridge 2 – Date delivered: 9/7/22

## Screening, psychotherapy, and pharmacotherapy trials

Sources Searched: database and platform
MEDLINE via Ovid
Cochrane Central Register of Controlled Clinical Trials via Wiley
PsycInfo via Ovid

## Screening instruments

Sources Searched: database and platform
MEDLINE via Ovid
Cochrane Central Register of Controlled Clinical Trials via Wiley
PsycInfo via Ovid

Key:

/ = MeSH subject heading

$ = truncation

ti = word in title

ab = word in abstract

pt = publication type

* = truncation

kw = keyword

adj = adjacent

md = methods

po = population

## Medline

### Medline Screening, psychotherapy and pharmacotherapy trials bridge search 2

Ovid MEDLINE(R) ALL <1946 to September 06, 2022>

- 1 Depression/ 143555
- 2 Depressive Disorder/ 74755
- 3 Depressive Disorder, Major/ 36338
- 4 Dysthymic Disorder/ 1171
- 5 depressive disorder, treatment-resistant/ 1972
- 6 Depression, Postpartum/ 6992
- 7 (depress$ or dysthym$).ti. 173632
- 8 (depress$ adj3 disorder$).ti,ab. 65779
- 9 (depress$ or dysthym$).ti,ab. 529334
- 10 limit 9 to (“in data review” or in process or publisher or “pubmed not medline”) 62055
- 11 or/1–8,10 345293
- 12 limit 11 to (english language and yr="2014 -Current”) 148910
- 13 anxiety disorders/ 39511
- 14 panic disorder/ 7225
- 15 phobic disorders/ 11124
- 16 Phobia, Social/ 1103
- 17 (anxiet$ or overanxious or anxious$ or phobia$ or phobic or panic).ti. 75260
- 18 ((anxiet$ or overanxious or anxious$ or phobia$ or phobic or panic) adj3 disorder$).ti,ab. 52620
- 19 or/13–18 120836
- 20 limit 19 to (english language and yr="1990 -Current”) 99331
- 21 suicide/ 43725
- 22 suicidal ideation/ 11272
- 23 suicide, attempted/ 22198
- 24 Suicide, Completed/ 267
- 25 Self-Injurious Behavior/ 9385
- 26 (suicid$ or parasuicid$ or self harm$ or Self Injur$).ti. 55339
- 27 or/21–26 82736
- 28 limit 27 to (english language and yr="2012 -Current”) 33920
- 29 12 or 20 or 28 251944
- 30 Mass screening/ 114430
- 31 (screen$ or casefinding or case finding or “trained to identify” or “trained in identifying”).ti,ab. or (diagnos$ or detect$ or identif$).ti. 2196135
- 32 30 or 31 2221747
- 33 (clinical trial or adaptive clinical trial or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or randomized controlled trial or equivalence trial or pragmatic clinical trial or Meta-Analysis).pt. 1091511
- 34 clinical trials as topic/ or adaptive clinical trials as topic/ or clinical trials, phase iii as topic/ or clinical trials, phase iv as topic/ or controlled clinical trials as topic/ or non-randomized controlled trials as topic/ or randomized controlled trials as topic/ or equivalence trials as topic/ or intention to treat analysis/ or pragmatic clinical trials as topic/ or meta-analysis as topic/ 383613
- 35 control groups/ or double-blind method/ or single-blind method/ or random allocation/ or placebos/ 323068
- 36 (randomized or randomised or placebo or randomly or phase iii or phase 3).ti,ab. 1162933
- 37 (RCT or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$).ti,ab. 427756
- 38 ((control$ or clinical) adj3 (study or studies or trial$ or group$)).ti,ab. 1769266
- 39 (Nonrandom$ or non random$ or non-random$ or quasi-random$ or quasirandom$).ti,ab. 50919
- 40 ((open label or open-label) adj5 (study or studies or trial$)).ti,ab. 42031 41 ((equivalence or superiority or non-inferiority or noninferiority) adj3 (study or studies or trial$)).ti,ab. 10434
- 42 (pragmatic study or pragmatic studies).ti,ab. 533
- 43 ((pragmatic or practical) adj3 trial$).ti,ab. 5285
- 44 ((quasiexperimental or quasi-experimental) adj3 (study or studies or trial$ or design)).ti,ab. 15227
- 45 (metaanaly$ or meta analy$).ti,ab. 245180
- 46 or/33–45 3159250
- 47 29 and 32 and 46 5479
- 48 remove duplicates from 47 5446
- 49 limit 19 to (english language and yr="2015 -Current”) 48642
- 50 limit 27 to (english language and yr="2012 -Current”) 33920
- 51 49 or 50 81404
- 52 46 and 51 16250
- 53 exp Psychotherapy/ 213730
- 54 Counseling/ 38907
- 55 Directive Counseling/ 2429
- 56 Problem Solving/ 26484
- 57 psychoanalysis/ 9853
- 58 motivational interviewing/ 2437
- 59 psychotherap$.ti,ab. 46623
- 60 (psychological adj5 (therap$ or treatment$ or intervention$)).ti,ab. 27190
- 61 (psychosocial adj5 (therap$ or treatment$ or intervention$)).ti,ab. 15790
- 62 (behavi$ adj5 (therap$ or treatment$ or intervention$)).ti,ab. 93177
- 63 (cognitive adj5 (therap$ or treatment$ or intervention$)).ti,ab. 50022
- 64 (psychodynamic adj5 (therap$ or treatment$ or intervention$)).ti,ab. 1775
- 65 (nondirective adj5 (therap$ or treatment$ or intervention$)).ti,ab. 126
- 66 (non directive adj5 (therap$ or treatment$ or intervention$)).ti,ab. 100
- 67 interpersonal therap$.ti,ab. 421
- 68 interpersonal psychotherap$.ti,ab. 977
- 69 interpersonal intervention$.ti,ab. 51
- 70 supportive therap$.ti,ab. 5261
- 71 group therap$.ti,ab. 5145
- 72 counsel$.ti,ab. 126423
- 73 psychoeducat$.ti,ab. 6423
- 74 (problem solving treatment or problem solving therapy).ti,ab. 621
- 75 motivational interview$.ti,ab. 4975
- 76 psychoanal$.ti,ab. 14387
- 77 family therapy.ti,ab. 3413
- 78 ((limit or limits or limiting or limited or restrict$ or barrier$) adj3 (access$ or mean$ or method or methods or availab$ or suicid$)).ti,ab. 102632
- 79 ((limit or limits or limiting or limited or restrict$ or barrier$ or safety) and (prevent$ or jumping or hanging or charcoal burning or poisoning or drowning or pesticide$ or firearm$ or gunshot or overdose$)).ti,ab. 273376
- 80 (Postcard or letter or telephone or writing or educational intervention or visited or home visit or outreach program$).ti,ab. 238110
- 81 27 and (78 or 79 or 80) 4218
- 82 cbt.ti,ab. 13189
- 83 limit 82 to (“in data review” or in process or publisher or “pubmed not medline”) 2164
- 84 or/53–77,81,83 511835
- 85 52 and 84 5245
- 86 remove duplicates from 85 5221
- 87 Antidepressive Agents/ or Antidepressive Agents, Second-Generation/ 54293
- 88 (anti-depress$ or antidepress$ or pharmacotherap$).ti,ab. 113418
- 89 Serotonin Uptake Inhibitors/ 20763
- 90 (serotonin reuptake or serotonin re-uptake or serotonin uptake or ssri$).ti,ab. 21258
- 91 (serotonergic adj (drug$ or agent$ or medicat$)).ti,ab. 1294
- 92 Citalopram/ or (citalopram or celexa or escitalopram or Lexapro).ti,ab. 8466
- 93 Fluoxetine/ or (fluoxetine or fluoxetin or Prozac).ti,ab. 15196
- 94 fluvoxamine/ or fluvoxamin$.ti,ab. 3193
- 95 Paroxetine/ or (paroxetine or paxil or seroxat).ti,ab. 6685
- 96 Sertraline/ or (sertraline or Zoloft).ti,ab. 5744
- 97 “Serotonin and Noradrenaline Reuptake Inhibitors"/ 481
- 98 (serotonin norepinephrine reuptake inhibitor$ or “selective serotonin and noradrenaline reuptake inhibitor$” or serotonin noradrenaline uptake inhibitor$ or “selective serotonin and noradrenaline uptake inhibitor$” or SNRI$ or SSNRI$).ti,ab. 2329 99 Duloxetine Hydrochloride/ or (duloxetine or Cymbalta).ti,ab. 3075
- 100 Desvenlafaxine Succinate/ or desvenlafaxine.ti,ab. 503
- 101 milnacipran/ or levomilnacipran/ or (milnacipran or levomilnacipran or Fetzima).ti,ab. 796
- 102 Venlafaxine Hydrochloride/ or (venlafaxine or Effexor).ti,ab. 4798
- 103 (serotonin modulator or serotonin stimulator).ti,ab. 13
- 104 (Nefazodone or serzone or dutonin or nefadar or CYP3A4).ti,ab. 11247
- 105 trazodone/ or (Trazodon$ or desyrel).ti,ab. 2263
- 106 vilazodone hydrochloride/ or Vilazodone.ti,ab. 243
- 107 vortioxetine/ or Vortioxetine.ti,ab. 577
- 108 Bupropion/ or (bupropion or Wellbutrin or amfebutamone or zyban).ti,ab. 5374
- 109 Mirtazapine/ or (mirtazapine or esmirtazapine or Remeron).ti,ab. 2611
- 110 Antidepressive Agents, Tricyclic/ 10520
- 111 Imipramine/ or (imipramine or Tofranil).ti,ab. 13440
- 112 amitriptyline/ or (amitriptyline or Elavil).ti,ab. 9717
- 113 nortriptyline/ or (nortriptyline or Pamelor or Aventyl).ti,ab. 3217
- 114 protriptyline/ or (protriptyline or Vivactil).ti,ab. 416
- 115 clomipramine/ or (clomipramine or Anafranil).ti,ab. 4120
- 116 desipramine/ or (desipramine or Norpramin).ti,ab. 7934
- 117 trimipramine/ or (trimipramine or Surmontil).ti,ab. 550
- 118 Doxepin/ or (doxepin or Sinequan).ti,ab.1500
- 119 Amoxapine/ or amoxapine.ti,ab. 478
- 120 Maprotiline/ or (Maprotiline or Ludiomil).ti,ab. 1325
- 121 Buspirone/ or (buspirone or buspar).ti,ab. 3071
- 122 Pregnanolone/ or (brexanolone or Allopregnanolone or Zulresso).ti,ab. 2570
- 123 Lithium/ or exp Lithium Compounds/ or Lithium$.ti,ab. 66681
- 124 Anti-anxiety agents/ 19342
- 125 (Anti-anxiet$ or antianxiety$ or anxiolytic or anti-panic or antipanic).ti,ab. 15790
- 126 benzodiazepines/ or benzodiazepinones/ or benzodiazepin$.ti,ab. 50954
- 127 alprazolam/ or (Alprazolam or Xanax).ti,ab. 2858
- 128 bromazepam/ or (bromazepam or lexotan or lexotanil).ti,ab. 617
- 129 chlordiazepoxide/ or (Chlordiazepoxide or Librium or Chlozepid or Elenium).ti,ab. 4839
- 130 clobazam/ or (Clobazam or Onfi or Frisium).ti,ab. 1146
- 131 clonazepam/ or (Clonazepam or Antelepsin or Rivotril).ti,ab. 4823
- 132 clorazepate dipotassium/ or (Clorazepate or Chlorazepate or Tranxene or Tranxilium or Tranex or Belseren or 4306-CB or 4306CB).ti,ab. 551
- 133 diazepam/ or (Diazepam or Valium or Faustan or Seduxen or Sibazon or Stesolid or Apaurin).ti,ab. 26433
- 134 estazolam/ or (Estazolam or Tasedan or D-40TA or D40TA).ti,ab. 286
- 135 flurazepam/ or (Flurazepam or Dalmane or Dalmadorm).ti,ab. 1190
- 136 (Halazepam or paxipam or Alapryl or Pacinone).ti,ab. 56
- 137 lorazepam/ or (Lorazepam or Ativan or Sinestron or WY-4036 or WY4036).ti,ab. 5006
- 138 oxazepam/ or (Oxazepam or Serax or Tazepam or Adumbran).ti,ab. 2019
- 139 temazepam/ or (temazepam or Restoril or Norkotral).ti,ab. 1146
- 140 or/87–139 338222
- 141 52 and 140 1897
- 142 remove duplicates from 141 1893
- 143 48 or 86 or 142 11486
- 144 143 not ((exp infant/ or child/ or adolescence/) not (exp adult/ or exp aged/ or middle aged/)) 10273
- 145 144 not (animals/ not humans/) 9992
- 146 (202109* or 202110* or 202111* or 202112* or 2022*).dt,da,ez. 2113883
- 147 145 and 146 2064

## Screening instruments

### Medline screening instruments bridge search 2

Ovid MEDLINE(R) ALL <1946 to September 06, 2022>

- 1 Depression/ 143555
- 2 Depressive Disorder/ 74755
- 3 Depressive Disorder, Major/ 36338
- 4 Dysthymic Disorder/ 1171
- 5 depressive disorder, treatment-resistant/ 1972
- 6 Depression, Postpartum/ 6992
- 7 (depress$ or dysthym$).ti. 173632
- 8 (depress$ adj3 disorder$).ti,ab. 65779
- 9 (depress$ or dysthym$).ti,ab. 529334
- 10 limit 9 to (“in data review” or in process or publisher or “pubmed not medline”) 62055
- 11 or/1–8,10 345293
- 12 limit 11 to (english language and yr="2014 -Current”) 148910
- 13 anxiety disorders/ 39511
- 14 panic disorder/ 7225
- 15 phobic disorders/ 11124
- 16 Phobia, Social/ 1103
- 17 (anxiet$ or overanxious or anxious$ or phobia$ or phobic or panic).ti. 75260
- 18 ((anxiet$ or overanxious or anxious$ or phobia$ or phobic or panic) adj3 disorder$).ti,ab. 52620
- 19 or/13–18 120836
- 20 limit 19 to (english language and yr="2014 -Current”) 53086
- 21 suicide/ 43725
- 22 suicidal ideation/ 11272
- 23 suicide, attempted/ 22198
- 24 Suicide, Completed/ 267
- 25 Self-Injurious Behavior/ 9385
- 26 (suicid$ or parasuicid$ or self harm$ or Self Injur$).ti. 55339
- 27 or/21–26 82736
- 28 limit 27 to (english language and yr="2012 -Current”) 33920
- 29 12 or 20 or 28 205922
- 30 *Mass Screening/is, mt [Instrumentation, Methods] 20438
- 31 *"Surveys and Questionnaires"/ 49921
- 32 *Interview/ 0
- 33 *Psychiatric Status Rating Scales/ 11043
- 34 *Self Report/ 7566
- 35 screen$.ti. 203799
- 36 casefinding.ti,ab. 88
- 37 case finding.ti,ab. 5567
- 38 self report$.ti. 21338
- 39 (suicid$ adj3 (scale$ or inventor$ or questionnaire$ or survey$ or index$ or checklist$ or interview$ or screen$ or self report)).ti,ab. 4367
- 40 ((depress$ or anxiety) adj3 (scale$ or inventor$ or questionnaire$ or survey$ or index$ or checklist$ or interview$ or screen$ or self report)).ti. 6967
- 41 limit 40 to (“in data review” or in process or publisher or “pubmed not medline”) 847
- 42 Patient Health Questionnaire/ 865
- 43 Patient Health Questionnaire.ti,ab. 8756
- 44 (PHQ-2 or PHQ-9 or PHQ-ADS).ti,ab. 5970
- 45 Primary Care Evaluation of Mental Disorders.ti,ab. 254
- 46 PRIME-MD.ti,ab. 329
- 47 (Center and Epidemiologic and Depression and Scale).ti,ab. 3885
- 48 (CES-D or CESD$).ti,ab. 5160
- 49 (“Edinburgh Postpartum Depression Scale” or “Edinburgh Postnatal Depression Scale”).ti,ab. 3242
- 50 EPDS.ti,ab. 2468
- 51 (Geriatric Depression adj2 Scale$).ti,ab. 4532
- 52 GDS-15.ti,ab. 629
- 53 Generali?ed Anxiety Disorder Scale.ti,ab. 617
- 54 (GAD-2 or GAD-7).ti,ab. 2630
- 55 Geriatric Anxiety Inventory.ti,ab. 103
- 56 GAI-SF.ti,ab. 17
- 57 Geriatric Anxiety Scale.ti,ab. 36
- 58 (GAS-LTC or GAS-10).ti,ab. 60
- 59 ((Harkavy$ or Asnis$) and suicid$).ti,ab. 3
- 60 suicide probability.ti,ab. 104
- 61 suicide status form.ti,ab. 18
- 62 (paykel$ and suicid$).ti,ab. 49
- 63 (self harm adj3 questionnaire$).ti,ab. 66
- 64 (self harm adj3 scale$).ti,ab. 53
- 65 (self harm adj3 survey$).ti,ab. 20
- 66 (self harm adj3 inventory).ti,ab. 116
- 67 (manchester and self harm).ti,ab. 54
- 68 suicide assessment.ti,ab. 245
- 69 (beck depression and suicid$).ti,ab. 801
- 70 (hamilton rating and suicid$).ti,ab. 199
- 71 (symptom driven diagnos$ and suicid$).ti,ab. 4
- 72 or/30–39,41–71 324077
- 73 “Sensitivity and Specificity"/ 365816
- 74 “Predictive Value of Tests"/ 221405
- 75 ROC Curve/ 69467
- 76 Receiver operat$.ti,ab. 114465
- 77 ROC curve$.ti,ab. 48646
- 78 sensitivit$.ti,ab. 945331
- 79 specificit$.ti,ab. 555143
- 80 (predictive value or “can be detected”).ti,ab. 142885
- 81 accuracy.ti,ab. 501574
- 82 False Negative Reactions/ 18295
- 83 False Positive Reactions/ 28576
- 84 Diagnostic Errors/ 39422
- 85 “Reproducibility of Results"/ 449213
- 86 Reference Values/ 163523
- 87 Reference Standards/ 45425
- 88 Observer Variation/ 44726
- 89 Psychometrics/ 85781
- 90 Psychometric$.ti,ab. 56362
- 91 false positive$.ti,ab. 65800
- 92 false negative$.ti,ab. 37195
- 93 miss rate$.ti,ab. 623
- 94 error rate$.ti,ab. 16961
- 95 or/73–94 2635868
- 96 29 and 72 and 95 4669
- 97 29 and 72 23139
- 98 limit 97 to (systematic reviews pre 2019 or systematic reviews) 680
- 99 96 or 98 5087
- 100 99 not ((exp infant/ or child/ or adolescence/) not (exp adult/ or exp aged/ or middle aged/)) 4654
- 101 (202109* or 202110* or 202111* or 202112* or 2022*).dt,da,ez. 2113883
- 102 100 and 101 778

## Cochrane Central Register of Controlled Clinical Trials (CENTRAL)

### SADS screening and therapy

#### Cochrane screening and therapy bridge 2

- Date Run: 07/09/2022 21:03:46
- ID Search Hits
- #1 (depress* or dysthym*):ti or (depress* near/3 disorder*):ti,ab with Publication Year from 2014 to present, in Trials 17204
- #2 (anxiet* or overanxious or anxious* or phobia* or phobic or panic):ti or ((anxiet* or overanxious or anxious* or phobia* or phobic or panic) near/3 (disorder*)):ti,ab with Publication Year from 1990 to present, in Trials 20865
- #3 (suicid* or parasuicid* or self NEXT harm* or Self NEXT Injur*):ti,ab with Publication Year from 2012 to present, in Trials 5006
- #4 #1 or #2 or #3 38134
- #5 (screen* or casefinding or “case finding” or “trained to identify” or “trained in identifying”):ti,ab or (diagnos* or detect* or identif*):ti 111737
- #6 #4 and #5 3775
- #7 (anxiet* or overanxious or anxious* or phobia* or phobic or panic):ti or ((anxiet* or overanxious or anxious* or phobia* or phobic or panic) near/3 (disorder*)):ti,ab with Publication Year from 2015 to present, in Trials 11103
- #8 (suicid* or parasuicid* or self NEXT harm* or Self NEXT Injur*):ti,ab with Publication Year from 2012 to present, in Trials 5006
- #9 #7 or #8 15744
- #10 psychotherap*:ti,ab 8591
- #11 ((psychological or psychosocial or behavi* or cognitive or psychodynamic or nondirective) near/5 (therap* or treatment* or intervention*)):ti,ab 61677
- #12 (non directive near/5 (therap* or treatment* or intervention*)):ti,ab 85
- #13 interpersonal NEXT therap*:ti,ab 190
- #14 interpersonal NEXT psychotherap*:ti,ab 673
- #15 interpersonal NEXT intervention*:ti,ab 6
- #16 supportive NEXT therap*:ti,ab 1015
- #17 group NEXT therap*:ti,ab 2530
- #18 counsel*:ti,ab 23574
- #19 psychoeducat*:ti,ab 5184
- #20 (“problem solving treatment” or “problem solving therapy”):ti,ab 635
- #21 Motivational NEXT interview*:ti,ab 4261
- #22 psychoanal*:ti,ab 234
- #23 family NEXT therapy:ti,ab 559
- #24((limit or limits or limiting or limited or restrict* or barrier*) near/3 (access* or mean* or method or methods or availab* or suicid*)):ti,ab 8306
- #25 ((limit or limits or limiting or limited or restrict* or barrier* or safety) and (prevent* or jumping or hanging or “charcoal burning” or poisoning or drowning or pesticide* or firearm* or gunshot or overdose*)):ti,ab 38549
- #26 (Postcard or letter or telephone or writing or “educational intervention” or visited or “home visit” or outreach NEAR program*):ti,ab 40554
- #27 cbt:ti,ab 9693
- #28 1-#27 165493
- #29 #9 and #28 6184
- #30 (anti-depress* or antidepress* or pharmacotherap*):ti,ab 20614
- #31 (“serotonin reuptake” or “serotonin re-uptake” or “serotonin uptake” or ssri*):ti,ab 4722
- #32 (serotonergic near/1 (drug* or agent* or medicat*)):ti,ab 175
- #33 (citalopram or celexa or escitalopram or Lexapro or fluoxetine or fluoxetin or Prozac or fluvoxamin* or paroxetine or paxil or seroxat or sertraline or Zoloft):ti,ab 10640
- #34 (“serotonin norepinephrine reuptake” or “selective serotonin and noradrenaline reuptake” or “serotonin noradrenaline uptake” or “selective serotonin and noradrenaline uptake” or SNRI* or SSNRI*):ti,ab 622
- #35 (duloxetine OR Cymbalta or desvenlafaxine or milnacipran OR levomilnacipran OR Fetzima or venlafaxine OR Effexor or “serotonin modulator” or “serotonin stimulator” or Nefazodone or serzone or dutonin or nefadar or CYP3A4 or Trazodon* or desyrel or Vilazodone or Vortioxetine or bupropion OR Wellbutrin OR amfebutamone OR zyban or mirtazapine OR esmirtazapine OR Remeron):ti,ab 8013
- #36 (imipramine or Tofranil or amitriptyline or Elavil or nortriptyline or Pamelor or Aventyl or protriptyline or Vivactil or clomipramine or Anafranil or desipramine or Norpramin or trimipramine or Surmontil or doxepin or Sinequan or amoxapine or Maprotiline or Ludiomil or buspirone or buspar or brexanolone or Allopregnanolone or Zulresso or Lithium*):ti,ab 9915
- #37 (Anti-anxiet* or antianxiety* or anxiolytic or anti-panic or antipanic):ti,ab 2796
- #38 (benzodiazepin* or Alprazolam or Xanax or bromazepam or lexotan or lexotanil or Chlordiazepoxide or Librium or Chlozepid or Elenium or Clobazam or Onfi or Frisium or Clonazepam or Antelepsin or Rivotril or Clorazepate or Chlorazepate or Tranxene or Tranxilium or Tranex or Belseren or Diazepam or Valium or Faustan or Seduxen or Sibazon or Stesolid or Apaurin or Estazolam or Tasedan or D-40TA or D40TA or Flurazepam or Dalmane or Dalmadorm or Halazepam or paxipam or Alapryl or Pacinone or Lorazepam or Ativan or Sinestron or WY-4036 or WY4036 or Oxazepam or Serax or Tazepam or Adumbran or temazepam or Restoril or Norkotral):ti,ab 10961
- #39 ^2-#38^ 50914
- #40 #9 and #39 2114
- #41 #6 or #29 or #40 10206
- #42 #41 NOT (pubmed):an with Cochrane Library publication date from Sep 2021 to present 1257

### SADS screening instruments

#### Cochrane screening instruments original bridge 2

- Date Run: 07/09/2022 21:11:26
- ID Search Hits
- #1 (depress* or dysthym*):ti or (depress* near/3 disorder*):ti,ab with Publication Year from 2014 to present, in Trials 17204
- #2 (anxiet* or overanxious or anxious* or phobia* or phobic or panic):ti or ((anxiet* or overanxious or anxious* or phobia* or phobic or panic) near/3 (disorder*)):ti,ab with Publication Year from 2014 to present, in Trials 12039
- #3 (suicid* or parasuicid* or self NEXT harm* or Self NEXT Injur*):ti,ab with Publication Year from 2012 to present, in Trials 5006
- #4 #1 or #2 or #3 29347
- #5 (screen* or self NEXT report*):ti 13054
- #6 (casefinding or case NEXT finding):ti,ab 407
- #7 (suicid* near/3 (scale* or inventor* or questionnaire* or survey* or index* or checklist* or interview* or screen* or self report)):ti,ab 1595
- #8 ((depress* or anxiety) near/3 (scale* or inventor* or questionnaire* or survey* or index* or checklist* or interview* or screen* or self report)):ti 986
- #9 (“Patient Health Questionnaire” or PHQ-2 OR PHQ-9 or PHQ-ADS):ti,ab 3620
- #10 (“Primary Care Evaluation of Mental Disorders” or PRIME-MD):ti,ab 57
- #11 (Center and Epidemiologic and Depression and Scale):ti,ab 657
- #12 (CES-D or CESD*):ti,ab 1180
- #13 (“Edinburgh Postpartum Depression Scale” or “Edinburgh Postnatal Depression Scale” or EPDS):ti,ab 920
- #14 (Geriatric Depression near/2 Scale*):ti,ab 1493
- #15 GDS-15:ti,ab 186
- #16 Generali?ed NEXT “Anxiety Disorder Scale":ti,ab 181
- #17 (GAD-2 or GAD-7):ti,ab 1316
- #18 “Geriatric Anxiety Inventory":ti,ab 62
- #19 GAI-SF:ti,ab 3
- #20 “Geriatric Anxiety Scale":ti,ab 16
- #21 (GAS-LTC or GAS-10 ):ti,ab 8
- #22 (Harkavy* or Asnis*):ti,ab 192
- #23 “suicide probability":ti,ab 6
- #24 “suicide status form":ti,ab 3
- #25 paykel*:ti,ab 247
- #26 (“self harm” near/3 questionnaire*):ti,ab 12
- #27 (“self harm” near/3 scale*):ti,ab 16
- #28 (“self harm” near/3 survey*):ti,ab 1
- #29 (“self harm” near/3 inventory):ti,ab 35
- #30 (manchester and “self harm”):ti,ab 12
- #31 “suicide assessment":ti,ab 41
- #32 (“beck depression” and suicid*):ti,ab 273
- #33 (“hamilton rating” and suicid*):ti,ab 142
- #34 ((“symptom driven” NEXT diagnos*) and suicid*):ti,ab 0
- #35 3-#34 23796
- #36 #4 and #35 5100
- #37 #36 NOT (pubmed):an with Cochrane Library publication date from Sep 2021 to present 687

## PsycInfo

### Screening, psychotherapy, and pharmacotherapy trials original search

#### PsycInfo screening, psychotherapy, and pharmacotherapy trials bridge 2

APA PsycInfo <1806 to August Week 5 2022>

- 1 exp major depression/ 150508
- 2 (depress$ or dysthym$).ti. or (depress$ adj3 disorder$).ti,ab. or dysthym$.ti,ab. 155080
- 3 1 or 2 195745
- 4 limit 3 to (english language and yr="2014 -Current”) 68470
- 5 Anxiety Disorders/ or Generalized Anxiety Disorder/ or Panic Disorder/ or Social Anxiety/ 34650
- 6 (anxiet$ or overanxious or anxious$ or phobia$ or phobic or panic).ti. 75038
- 7 ((anxiet$ or overanxious or anxious$ or phobia$ or phobic or panic) adj3 disorder$).ti,ab. 52653
- 8 or/5–7 105293
- 9 limit 8 to (english language and yr="1990 -Current”) 81444
- 10 Suicide/ or Attempted Suicide/ or Suicidality/ or Suicidal Ideation/ or exp Self-Injurious Behavior/ 49241
- 11 (suicid$ or parasuicid$ or self harm$ or Self Injur$).ti. 44620
- 12 10 or 11 54464
- 13 limit 12 to (english language and yr="2012 -Current”) 22539
- 14 4 or 9 or 13 156401
- 15 screening/ 10014
- 16 (screen$ or casefinding or case finding or “trained to identify” or “trained in identifying”).ti,ab. or (diagnos$ or detect$ or identif$).ti. 208017
- 17 15 or 16 208754
- 18 exp clinical trials/ 13333
- 19 clinical trial.md. 34531
- 20 Experiment Controls/ or Random Sampling/ or Placebo/ 8113
- 21 (randomized or randomised or placebo or randomly or phase iii or phase 3 or RCT or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$ or Nonrandom$ or non random$ or non-random$ or quasi-random$ or quasirandom$ or pragmatic study or pragmatic studies or metaanaly$ or meta analy$).ti,ab. 270583
- 22 ((control$ or clinical) adj3 (study or studies or trial$ or group$)).ti,ab. 245364
- 23 ((open label or open-label) adj5 (study or studies or trial$)).ti,ab. 5015
- 24 ((equivalence or superiority or non-inferiority or noninferiority) adj3 (study or studies or trial$)).ti,ab. 1111
- 25 ((pragmatic or practical) adj3 trial$).ti,ab. 989
- 26 ((quasiexperimental or quasi-experimental) adj3 (study or studies or trial$ or design)).ti,ab. 10966
- 27 or/18–26 435297
- 28 14 and 17 and 27 2575
- 29 limit 8 to (english language and yr="2015 -Current”) 29679
- 30 limit 12 to (english language and yr="2012 -Current”) 22539
- 31 29 or 30 51529
- 32 27 and 31 9317
- 33 exp Psychotherapy/ or Counseling/ or Psychotherapeutic Counseling/ or Cognitive Therapy/ or Anxiety Management/ or Behavior Therapy/ 258989
- 34 (psychotherap$ or interpersonal therap$ or interpersonal psychotherap$ or interpersonal intervention$ or supportive therap$ or group therap$ or counsel$ or psychoeducat$ or problem solving treatment or problem solving therapy or motivational interview$ or psychoanal$ or family therapy).ti,ab. 317821
- 35 ((psychological or psychosocial or behavi$ or cognitive or psychodynamic or nondirective or non directive) adj5 (therap$ or treatment$ or intervention$)).ti,ab. 158735
- 36 cbt.ti. 1841
- 37 ((limit or limits or limiting or limited or restrict$ or barrier$) adj3 (access$ or mean$ or method or methods or availab$ or suicid$)).ti,ab. 20075
- 38 ((limit or limits or limiting or limited or restrict$ or barrier$ or safety) and (prevent$ or jumping or hanging or charcoal burning or poisoning or drowning or pesticide$ or firearm$ or gunshot or overdose$)).ti,ab. 41207
- 39 (Postcard or letter or telephone or writing or educational intervention or visited or home visit or outreach program$).ti,ab. 117163
- 40 12 and (37 or 38 or 39) 3509
- 41 or/33–36,40 520490
- 42 32 and 41 3178
- 43 Antidepressant Drugs/ or Serotonin Reuptake Inhibitors/ or Citalopram/ or Fluoxetine/ or Fluvoxamine/ or Paroxetine/ or Serotonin Norepinephrine Reuptake Inhibitors/ or Venlafaxine/ or Trazodone/ or Bupropion/ or Tricyclic Antidepressant Drugs/ or Imipramine/ or Amitriptyline/ or Nortriptyline/ or Chlorimipramine/ or Desipramine/ or Doxepin/ or Maprotiline/ or Buspirone/ or Lithium/ or Lithium Carbonate/ or Minor Tranquilizers/ or Alprazolam/ or Chlordiazepoxide/ or Clonazepam/ or Diazepam/ or Lorazepam/ or Oxazepam/ or Benzodiazepines/ or Flurazepam/ 52622
- 44 (anti-depress$ or antidepress$ or pharmacotherap$ or serotonin reuptake or serotonin reuptake or serotonin uptake or ssri$ or citalopram or celexa or escitalopram or Lexapro or fluoxetine or fluoxetin or Prozac or fluvoxamin$ or paroxetine or paxil or seroxat or sertraline or Zoloft or serotonin norepinephrine reuptake inhibitor$ or “selective serotonin and noradrenaline reuptake inhibitor$” or serotonin noradrenaline uptake inhibitor$ or “selective serotonin and noradrenaline uptake inhibitor$” or SNRI$ or SSNRI$ or duloxetine or Cymbalta or desvenlafaxine or milnacipran or levomilnaipran or Fetzima or venlafaxine or Effexor or serotonin modulator or serotonin stimulator or Nefazodone or serzone or dutonin or nefadar or CYP3A4 or Trazodon$ or desyrel or Vilazodone or Vortioxetine or bupropion or Wellbutrin or amfebutamone or zyban or mirtazapine or esmirtazapine or Remeron or imipramine or Tofranil or amitriptyline or Elavil or nortriptyline or Pamelor or Aventyl or protriptyline or Vivactil or clomipramine or Anafranil or desipramine or Norpramin or trimipramine or Surmontil or doxepin or Sinequan or amoxapine or Maprotiline or Ludiomil or buspirone or buspar or brexanolone or Allopregnanolone or Zulresso or Lithium$ or Anti-anxiet$ or antianxiety$ or anxiolytic or anti-panic or antipanic or benzodiazepin$ or Alprazolam or Xanax or bromazepam or lexotan or lexotanil or Chlordiazepoxide or Librium or Chlozepid or Elenium or Clobazam or Onfi or Frisium or Clonazepam or Antelepsin or Rivotril or Clorazepate or Chlorazepate or Tranxene or Tranxilium or Tranex or Belseren or 4306-CB or 4306CB or Diazepam or Valium or Faustan or Seduxen or Sibazon or Stesolid or Apaurin or Estazolam or Tasedan or D-40TA or D40TA or Flurazepam or Dalmane or Dalmadorm or Halazepam or paxipam or Alapryl or Pacinone or Lorazepam or Ativan or Sinestron or WY-4036 or WY4036 or Oxazepam or Serax or Tazepam or Adumbran or temazepam or Restoril or Norkotral).ti,ab. 102376
- 45 (serotonergic adj (drug$ or agent$ or medicat$)).ti,ab. 686
- 46 43 or 44 or 45 104848
- 47 32 and 46 999
- 48 28 or 42 or 47 6129
- 49 48 not (Animal not Human).po. 6015
- 50 limit 49 to (childhood <birth to 12 years> or adolescence <13 to 17 years>) 1215
- 51 limit 49 to adulthood <18+ years> 3762
- 52 50 not 51 661
- 53 49 not 52 5354
- 54 (202109* or 202110* or 202111* or 202112* or 2022*).ch. 155080
- 55 (202109* or 202110* or 202111* or 202112* or 2022*).up. 189520
- 56 54 or 55 320754
- 57 53 and 56 938

## Screening instruments

### PsycInfo screening instruments bridge search 2

APA PsycInfo <1806 to August Week 5 2022>

- 1 exp major depression/ 150508
- 2 (depress$ or dysthym$).ti. or (depress$ adj3 disorder$).ti,ab. or dysthym$.ti,ab. 155080
- 3 1 or 2 195745
- 4 limit 3 to (english language and yr="2014 -Current”) 68470
- 5 Anxiety Disorders/ or Generalized Anxiety Disorder/ or Panic Disorder/ or Social Anxiety/ 34650
- 6 (anxiet$ or overanxious or anxious$ or phobia$ or phobic or panic).ti. 75038
- 7 ((anxiet$ or overanxious or anxious$ or phobia$ or phobic or panic) adj3 disorder$).ti,ab. 52653
- 8 or/5–7 105293
- 9 limit 8 to (english language and yr="2014 -Current”) 33716
- 10 Suicide/ or Attempted Suicide/ or Suicidality/ or Suicidal Ideation/ or exp Self-Injurious Behavior/ 49241
- 11 (suicid$ or parasuicid$ or self harm$ or Self Injur$).ti. 44620
- 12 10 or 11 54464
- 13 limit 12 to (english language and yr="2012 -Current”) 22539
- 14 4 or 9 or 13 108823
- 15 Screening Tests/ or Psychological Screening Inventory/ or Questionnaires/ or Surveys/ or Self-Report/ 63478
- 16 (screen$ or self report$).ti. 36565
- 17 (casefinding or case finding).ti,ab. 755
- 18 (suicid$ adj3 (scale$ or inventor$ or questionnaire$ or survey$ or index$ or checklist$ or interview$ or screen$ or self report)).ti,ab. 4523
- 19 ((depress$ or anxiety) adj3 (scale$ or inventor$ or questionnaire$ or survey$ or index$ or checklist$ or interview$ or screen$ or self report)).ti. 6724
- 20 (Patient Health Questionnaire or PHQ-2 or PHQ-9 or PHQ-ADS).ti,ab. 5071
- 21 (“Primary Care Evaluation of Mental Disorders” or PRIME-MD).ti,ab. 300
- 22 ((Center and Epidemiologic and Depression and Scale) or CES-D or CESD$).ti,ab. 5172
- 23 (“Edinburgh Postpartum Depression Scale” or “Edinburgh Postnatal Depression Scale” or EPDS).ti,ab. 2206
- 24 ((Geriatric Depression adj2 Scale$) or GDS-15).ti,ab. 3050
- 25 (Generali?ed Anxiety Disorder Scale or GAD-2 or GAD-7).ti,ab. 1234
- 26 (Geriatric Anxiety Inventory or GAI-SF).ti,ab. 102
- 27 (Geriatric Anxiety Scale or GAS-LTC or GAS-10).ti,ab. 35
- 28 ((Harkavy$ or Asnis$) and suicid$).ti,ab. 19
- 29 (suicide probability or suicide status form or suicide assessment).ti,ab. 603
- 30 (paykel$ and suicid$).ti,ab. 37
- 31 (self harm adj3 (questionnaire$ or scale$ or survey$ or inventory or Manchester)).ti,ab. 257
- 32 (beck depression and suicid$).ti,ab. 955
- 33 (hamilton rating and suicid$).ti,ab. 244
- 34 (symptom driven diagnos$ and suicid$).ti,ab. 3
- 35 or/15–34 110547
- 36 Test Sensitivity/ or Test Interpretation/ or Test Specificity/ or Predictive Validity/ or Interrater Reliability/ or Test Sensitivity/ or Test Reliability/ or Psychometrics/ or Error of Measurement/ or Measurement Invariance/ or Test Validity/ 135394
- 37 (Receiver operat$ or ROC curve$ or sensitivit$ or specificit$ or predictive value or “can be detected” or accuracy or Psychometric$ or false positive$ or false negative$ or miss rate$ or error rate$).ti,ab. 282467
- 38 36 or 37 365478
- 39 14 and 35 and 38 3139
- 40 (((comprehensive* or integrative or systematic*) adj3 (bibliographic* or review* or literature)) or (meta-analy* or metaanaly* or “research synthesis” or ((information or data) adj3 synthesis) or (data adj2 extract*))).ti,ab. or ((review adj5 (rationale or evidence)).ti,ab. and “Literature Review".md.) or (cinahl or (cochrane adj3 trial*) or embase or medline or psyclit or pubmed or scopus or “sociological abstracts” or “web of science”).ab. or (“systematic review” or “meta analysis”).md. 115132
- 41 14 and 35 and 40 414
- 42 39 or 41 3391
- 43 42 not (Animal not Human).po. 3389
- 44 limit 43 to (childhood <birth to 12 years> or adolescence <13 to 17 years>) 757
- 45 limit 43 to adulthood <18+ years> 2603
- 46 44 not 45 315
- 47 43 not 46 3074
- 48 (202109* or 202110* or 202111* or 202112* or 2022*).ch,up. 320754
- 49 47 and 48 607

Appendix A Table 1 Search Start Dates, by Condition and Key Question

Disorder | KQ1/KQ3 | KQ2 | KQ4/5: Psychotherapy | KQ4/5: Pharmacotherapy
Depression | Primary studies; Search start date: January 2014; Rationale: Bridge from previous review^4^ | ESRs (PHQ, PRIME-MD, CESD, EPDS):; Search start date: January 2015; Rationale: Abundant ESRs published in past 5 years, earlier systematic reviews likely superseded by more recent reviews; Primary studies (GDS):; Search start date: January 2014; Rationale: Bridge from Pocklighton 2016^5^ (searched thru Apr-2014) | ESRs:; Search start date: January 2015; Rationale: Abundant ESRs published in past 5 years, earlier systematic reviews likely superseded by more recent reviews | ESRs:; Search start date: January 2015; Rationale: Abundant ESRs published in past 5 years, earlier systematic reviews likely superseded by more recent reviews
Anxiety | Search start date: 1990; Rationale: First SSRI approved was fluoxetine in 1987, others in early 1990s. Assume no use for anxiety <1990. Very few trials of CBT prior to 1990. Anxiety Disorders Association of America founded in 1990 (believe this was first modern era anxiety-related advocacy group) | Primary studies (GAD-2/7, EPDS-Anx, GAD, GAI):; Search start date: January 2014; Rationale: Bridging from other reviews; - GAD-7/2: Bridge from Plummer 2016^6^ (searched thru Mar-2014); - EPDS-anxiety subscale: Bridge from Sinesi 2019^7^ (searched thru Feb-2017); - GAS: Bridge from Balsamo 2018^8^ (search dates not provided, most recently published study 2015) | Primary studies:; Search start date: January 2015; Rationale: Bridge from Cuijpers 2016^9^ (searched thru Aug-2015) | Primary studies:; Search start date: January 2015; Rationale: Bridge from:; - Slee 2019^10^ (searched thru Jul-2017); - Bighelli, 2018^11^ (searched thru May-2018); - Imai 2014^12^ (Searched thru Jan-2014); - Williams 2017^13^ (searched thru Aug-2017)
High suicide risk | Primary studies:; Search start date: January 2012; Rationale: Bridge from previous review^14^ (searched thru July 2012) | Primary studies:; Search start date: January 2012; Rationale: Bridge from previous review^14^ (searched thru July 2012) | Primary studies:; Search start date: January 2012; Rationale: Bridge from previous review^14^ (searched thru July 2012) | Primary studies:; Search start date: January 2012; Rationale: Bridge from previous review^14^ (searched thru July 2012)

Abbreviations: CBT = cognitive behavioral therapy; CESD = Center for Epidemiologic Studies Depression Scale; EPDS = Edinburgh Postnatal Depression Scale; ESR = existing systematic review; GAD = General Anxiety Disorder Scale; GAI = Geriatric Anxiety Inventory; GAS = Geriatric Anxiety Scale; GDS = Geriatric Depression Scale; KQ = key question; PHQ = Patient Health Questionnaire; PRIME-MD = Primary Care Evaluation of Mental Disorders; SSRI = selective serotonin reuptake inhibitors.

Appendix A Table 2 Inclusion and Exclusion Criteria

| Include | Exclude
Condition definitions | - Major depressive disorder (including depression with peripartum onset or other specifiers).; - Anxiety disorders addressed in this review will include generalized anxiety disorder, social anxiety disorder, panic disorder, and anxiety not otherwise specified.; - Suicidal ideation includes suicidal thoughts or plan for suicide.; - Included studies may address these conditions individually or in combination. | Other mental health disorders (e.g., obsessive-compulsive disorder, posttraumatic stress disorder, psychotic disorders, bipolar disorder, cyclothymia, adjustment disorder with depressed mood, and other depressive disorders [persistent depressive disorder/dysthymia, disruptive mood dysregulation disorder, premenstrual dysphoric disorder, substance/medication-induced depressive disorder, depressive disorder due to another medical condition], and other anxiety disorders [agoraphobia, specific phobias, separation anxiety disorder, selective mutism, substance/medication-induced anxiety disorder, anxiety disorder due to another medical condition]).
Population | KQs 1–3: Adults (age ≥19 years), including pregnant and postpartum persons. Trials may include:; - Unselected primary care population.; - Primary care patients without known depression or anxiety disorders or high risk of suicide.; - Other comparable broad-based population recruited from a health care setting.; KQs 4, 5:; - Adults (age ≥19 years), including pregnant and postpartum persons, with depressive disorders, anxiety disorders, or high risk of suicide, or with elevated symptoms of depression or anxiety. Sample must include an estimated 50% or more of participants with an included disorder but may also include some participants with related (e.g., other depressive or anxiety disorders) or subsyndromal conditions (e.g., elevated symptoms but not meeting full criteria).; - For anxiety and depression, evidence will be limited to studies that recruit primary care patients (or comparable broad-based health care recruitment), although treatment can take place in any outpatient setting, including primary care or specialty care (such as mental health). If evidence in primary care–recruited patients is limited for any condition-by-treatment approach combination, evidence will be extended to patients recruited from other settings.; All KQs: A priori subpopulations of interest include pregnant and postpartum persons, individuals identified through population-based screening in primary care or comparable community settings, and subgroups based on age, sex or gender, race or ethnicity, sexual orientation, and socioeconomic status. | - Children and adolescents (age ≤18 years). Trials in which >50% of the population are age ≤18 years will be excluded.; - Studies limited to populations that are not broadly generalizable to primary care (e.g., persons with specific comorbid mental health conditions such as depression and substance use disorder); persons with other mood disorders (e.g., bipolar disorder, persistent depressive disorder/dysthymia); persons with concomitant medical conditions (e.g., cancer, traumatic brain injury, coronary artery disease, or post-cardiovascular disease event); persons with developmental disorders; persons with physical disabilities; persons in the midst of a suicidal crisis, identified through their presentation for health care services related to self-harm in acute-care settings (i.e., in the emergency department or inpatient setting); persons in residential, institutional, or inpatient settings.; - Studies of physician-assisted suicide in patients who are terminally ill.
Interventions | KQs 1, 3: Screening interventions with or without additional provider or patient-facing elements such as referral support, treatment guidelines, symptoms monitoring, and standardized treatment. Screening tools must be brief standardized instruments designed to identify persons with depression, anxiety, and/or high risk of suicide (i.e., recent or current suicidal ideation or behavior); self-report, clinician-administered, or electronically delivered (<5 minutes for clinician-administered instruments, <15 minutes for self-administered instruments).; KQ 2: Limited to the most widely recommended or used screening tools:; - For depression: Patient Health Questionnaire (PHQ), 2- and 9-item versions; Center for Epidemiologic Studies Depression Scale (CES-D); Edinburgh Postpartum Depression Scale (EPDS) for perinatal persons; Geriatric Depression Scale (GDS) for older adults.; - For anxiety: Generalized Anxiety Disorder scale (GAD), in any form; PHQ Anxiety scale; EPDS-Anxiety subscale, for perinatal persons; Geriatric Anxiety Inventory (GAI) and Geriatric Anxiety Scale (GAS) for older adults.; - For anxiety and depression: PHQ-ADS (combines the PHQ and GAD).; For suicide screening: Any brief tools.; KQs 4, 5: Intervention to address depression, anxiety, and/or risk of suicide, including; - Counseling (e.g., psychotherapy, psychoeducation, means restriction); - First-line pharmacotherapy agents (selective serotonin reuptake inhibitors [SSRIs], selective serotonin norepinephrine reuptake inhibitors [SNRIs], serotonin modulators (e.g., vortioxetine, vilazodone, nefazodone), atypical agents (e.g., bupropion, mirtazapine), tricyclic antidepressants, buspirone, brexanolone (for postpartum depression only), lithium (for suicide risk only), benzodiazepines (for anxiety only).; - Interventions must be conducted in primary care, referable from primary care, or feasible for implementation in a health care setting. | KQ 2: Other screening instruments.; KQs 4, 5:; - Relapse prevention among persons with a history of mood disorders, other treatment modalities (e.g., exercise, light therapy, transcranial magnetic nerve stimulation, electroshock treatment, St. John’s wort, social marketing, policy, system-level interventions, or adjunctive agents to enhance the effects of antidepressants) except as optional adjunctive components to first-line approaches.; - Intervention involving components that could not be replicated in most health care settings, including environmental components (media message, public signage) or that intervenes on groups in closed (pre-existing) social networks (e.g., in worksites, churches, clubs/teams), or involves potential notification or use of authority figures (e.g., military commanders, workplace supervisors).; - Pharmacotherapeutic agents that are not approved by the U.S. Food and Drug Administration for depression or anxiety or are no longer commonly used for anxiety or depression (e.g., monoamine oxidase inhibitors [including reversible monoamine oxidase A inhibitors for anxiety]).
Comparators | KQs 1, 3 (Screening):; - Usual care/no screening.; - Screening with no feedback of results to providers.; KQ 2 (Diagnostic accuracy):; - Reference standard (structured or semistructured diagnostic interview or a nonbrief [>5 minutes] unstructured interview with mental health clinician) within 2 weeks of screening in populations that include a full spectrum of patient severity for the given setting (i.e., studies cannot limit the patient pool to only nondepressed and known/highly likely depressed patients). Reference conditions include major depressive disorder, generalized anxiety disorder, social anxiety disorder, suicidal ideation, or any combination of the above.; KQs 4, 5 (Counseling):; - Usual care/no intervention.; - Waitlist.; - Attention control.; - Minimal intervention (e.g., usual care limited to no more than 15 minutes of information).; KQs 4, 5 (Pharmacotherapy):; - Placebo (including placebo along with counseling, when compared with the active agent plus the same counseling intervention).; - All those listed under “Counseling” above. | Active intervention (i.e., comparative effectiveness).
Outcomes | KQs 1, 4:; - Depression or anxiety symptoms, remission or diagnosis, or response.; - Suicide deaths, self-harm (i.e., suicide attempts), or suicidal ideation.; - All-cause mortality.; - Quality of life.; - Functioning (including vocational).; - Change in health status (e.g., improvement in comorbid conditions or reduction in physical complaints).; - Pregnancy outcomes (e.g., preterm birth); - Child/infant outcomes (continuation of breastfeeding, achievement of recognized developmental milestones, reduced abuse or neglect).; - Emergency department visits or inpatient stays.; - Hopelessness.; KQ 2: Sensitivity, specificity, or data to calculate one or both.; KQs 3, 5:; - Treatment avoidance.; - Deterioration in patient-provider relationship.; - Labeling stigma, and negative consequences of false positive and false negative test results.; - Inappropriate or unnecessary treatment.; - Other harms reported by screening and treatment trials.; - Paradoxical worsening of mental health symptoms.; KQ 5 (Pharmacotherapy only):; - Serious adverse effects.; - Withdrawals due to adverse effects.; - Suicidality.; - Serotonin syndrome.; - Cardiac effects.; - Seizures (bupropion only).; - Dependence (benzodiazepines only).; - Thyroid or renal toxicity (lithium only).; - For pregnant persons only: fetal/infant harms (neonatal death, major malformations, small for gestational age/low birth weight, preeclampsia). | KQs 1, 4: Rate of identification of persons with depression, anxiety, or high risk of suicide (e.g., trials of clinician training to identify persons at high risk of suicide that report no patient outcomes).
Outcome assessment timing | KQs 1, 3–5: ≥6 weeks after baseline, except for suicide death or self-harm (no minimum followup).; KQ 5 (Harms of pharmacotherapy): No minimum followup.; KQ 2: Maximum of 2 weeks between screening and reference standard.
Setting | KQs 1–3:; - Primary care settings (e.g., internal medicine, family medicine, obstetrics/gynecology, pediatrics [for postpartum screening], family planning, military health clinics, university-based health clinics) or comparable (e.g., identification through health plan administrative databases).; - ED setting, if screening is universal rather than targeted to persons presenting with mental health concerns; KQs 4, 5:; - Intervention may be implemented in outpatient health care (primary or specialty, including mental health).; - Participants must be recruited from a primary care or comparable broad health care setting. If evidence in these patients is limited, evidence in patients recruited from other low-acuity outpatient settings will be used (e.g., mental health, virtual, or community settings). | KQs 1–3:; - Community settings.; - Mental health clinics (unless recruitment is through primary care screening).; - Inpatient settings, residential care facilities, assisted living facilities, adult foster care, or intermediate care facilities (e.g., nursing homes, rehabilitation facilities, subacute care facilities).; - Correctional facilities.; - Schools (other than school-based health clinics).; KQs 4, 5:; - Correctional facilities.; - Schools (other than school-based health clinics).; - Worksites.; - Inpatient/residential facilities (unless identified through primary care-based screening for suicide).; - Emergency departments (unless identified through primary care-based screening for suicide).
Study design | KQs 1, 3: Randomized, controlled trials; controlled clinical trials; KQ 2: Systematic reviews and studies of diagnostic accuracy reporting sensitivity and specificity (or comparable statistics) compared with an independently assessed gold standard (structured or semistructured diagnostic interview or a nonbrief [>5 minutes] unstructured interview with mental health clinician) within 2 weeks of screening in populations that include a full spectrum of patient severity for the given setting (i.e., studies cannot limit the patient pool to only nondepressed and known/highly likely depressed patients).; KQ 4:; - Systematic reviews of controlled trials of interventions for depression, comparing active agents with control groups.; - Randomized, controlled trials of anxiety interventions in primary care populations.; - Systematic reviews of controlled trials of anxiety interventions, comparing active agents with control groups, if primary literature in primary care populations is insufficient.; - Randomized, controlled trials of suicide prevention interventions.; KQ 5:; - Randomized, controlled trials of anxiety and suicide prevention interventions in primary care populations.; - Systematic reviews of controlled trials comparing active agents with control groups; - Systematic reviews of comparative cohort and case-control observational studies; - (Harms of pharmacotherapy only): large comparative cohort and case-control observational studies published after identified systematic reviews that include observational studies. | All KQs: All other study designs.; KQ 2: If unable to limit to existing systematic reviews, case-control studies will be used (i.e., studies that limit the study sample to only participants with and without known mental health symptoms).
Study geography | Reviews and primary studies that primarily take place in countries categorized as “Very High” on the 2018 Human Development Index (as defined by the United Nations Development Programme) (published 2019). | Reviews in which >50% of included studies take place in countries not categorized as “Very High” on the Human Development Index.
Publication language | English | Any language other than English
Publication year | 1980 or later | Prior to 1980
Quality rating | Fair- or good-quality studies | Poor-quality studies

Abbreviations: ED = emergency department; KQ = key question.

Appendix A Table 3 Depression Screening Instruments: PHQ^15^

Prompt: Over the last 2 weeks, how often have you been bothered by any of the following?

Questions | | PHQ-9 | PHQ-8 | PHQ-4 | PHQ-2
1. | Little interest or pleasure in doing things | X | X | X | X
2. | Feeling down, depressed, or hopeless | X | X | X | X
3. | Trouble falling or staying asleep, or sleeping too much | X | X
4. | Feeling tired or having little energy | X | X
5. | Poor appetite or overeating | X | X
6. | Feeling bad about yourself – or that you are a failure or have let yourself or your family down | X | X | X
7. | Trouble concentrating on things, such as reading the newspaper or watching television | X | X
8. | Moving or speaking so slowly that other people could have noticed? Or the opposite – being so fidgety or restless that you have been moving around a lot more than usual | X | X | X
9. | Thoughts that you would be better off dead or of hurting yourself in some way | X

Score for each question: 0 (not at all), 1 (several days, 2 (more than half the days), 3 (nearly every day)

Abbreviation: PHQ = Patient Health Questionnaire.

Appendix A Table 4 Depression and Suicide Risk Screening Instruments: GDS^16^

Prompt: Select the answer that describes for you felt over the past week.

Questions | | GDS-30 | GDS-15 | GDS-10 | GDS-SI
1. | Are you basically satisfied with life? (Reverse) | X | X | X
2. | Have you dropped many of your activities and interests? | X | X | X
3. | Do you feel that your life is empty? | X | X | X | X
4. | Do you often get bored? | X | X
5. | Are you hopeful about the future? (Reverse) | X
6. | Are you bothered by thoughts you can’t get out of your head? | X
7. | Are you in good spirits most of the time? (Reverse) | X | X
8. | Are you afraid that something bad is going to happen? | X | X | X
9. | Do you feel happy most of the time? (Reverse) | X | X | X | X
10. | Do you often feel helpless? | X | X | X
11. | Do you often get restless and fidgety? | X
12. | Do you prefer to stay at home rather than go out and do things? | X | X
13. | Do you frequently worry about the future? | X
14. | Do you feel you have more problems with memory than most? | X | X | X
15. | Do you think it is wonderful to be alive now? (Reverse) | X | X | | X
16. | Do you feel downhearted and blue? | X
17. | Do you feel pretty worthless the way you are now? | X | | | X
18. | Do you worry a lot about the past? | X | X
19. | Do you find life very exciting? (Reverse) | X
20. | Is it hard to get started on new projects? | X
21. | Do you feel full of energy? (Reverse) | X | X | X
22. | Do you feel that your situation is hopeless? | X | X | X | X
23. | Do you think most people are better off than you are? (Reverse) | X | X | X
24. | Do you frequently get upset over little things? (Yes, 1) | X
25. | Do you frequently feel like crying? (Yes, 1) | X
26. | Do you have trouble concentrating? (Yes, 1) | X
27. | Do you enjoy getting up in the mornings? (Reverse) | X
28. | Do you prefer to avoid social gatherings? (Yes, 1) | X
29. | Is it easy for you to make decisions? (Reverse) | X
30. | Is your mind as clear as it used to be? (Reverse) | X

Score for each question: 1 (Yes), 0 (No); unless reverse scoring is noted.

Abbreviations: GDS = Geriatric Depression Scale; GDS-SI = Geriatric Depression Scale – Suicide Ideation.

Appendix A Table 5 Depression Screening Instruments: CES-D^17^

Prompt: Tell me how often have felt this way during the past week.

Questions
1. | I was bothered by things that usually don’t bother me
2. | I did not feel like eating; my appetite was poor
3. | I felt that I could not shake off the blues even with help from my family or friends
4. | I felt I was just as good as other people
5. | I had trouble keeping my mind on what I was doing
6. | I felt depressed
7. | I felt that everything I did was an effort
8. | I felt hopeful about the future
9. | I thought my life had been a failure
10. | I felt fearful
11. | My sleep was restless
12. | I was happy
13. | I talked less than usual
14. | I felt lonely
15. | People were unfriendly
16. | I enjoyed life
17. | I had crying spells
18. | I felt sad
19. | I felt that people dislike me
20. | I could not get “going

Score for each question: 0 (rare or none of the time, <1 day), 1 (some or a little of the time, 1–2 days), 2 (occasionally or a moderate amount of time, 3–4 days), 3 (most or all of the time, 5–7 days)

Abbreviation: CES-D = Center for Epidemiologic Studies Depression Scale.

Appendix A Table 6 Depression Screening Instruments: Whooley^18^

Prompt: Over the past month:

Questions
1. | Have you been bothered by feeling down, depressed, or hopeless?
2. | Have you been bothered by having little interest or pleasure in doing things?

Scoring: Yes to one or both indicates a positive test

Appendix A Table 7 Depression Screening Instruments: EPDS^19^

Prompt: Please select the answer that comes closest to how you have felt in the past 7 days, not just how you feel today.

Questions | | EPDS | EPDS-Anxiety | Scoring
1. | I have been able to laugh and see the funny side of things | X | | 0 (As much as I always could); 1 (Not quite so much now); 2 (Definitely not so much now); 3 (Not at all)
2. | I have looked forward with enjoyment to things | X | | 0 (As much as I ever did); 1 (Rather less than I used to); 2 (Definitely less than I used to); 3 (Hardly at all)
3. | I have blamed myself unnecessarily when things went wrong | X | X | 3 (Yes, most of the time); 2 (Yes, some of the time); 1 (Not very often); 0 (No, never)
4. | I have been anxious or worried for no good reason | X | X | 0 (No, not at all); 1 (Hardly ever); 2 (Yes, sometimes); 3 (Yes, very often)
5. | I have felt scared or panicky for no very good reason | X | X | 3 (Yes, quite a lot); 2 (Yes, sometimes); 1 (No, not much); 0 (No, not at all)
6. | Things have been getting on top of me | X | | 3 (Yes, most of the time I haven’t been able to cope at all); 2 (Yes, sometimes I haven’t been coping as well as usual); 1 (No, most of the time I have coped quite well); 0 (No, I have been coping as well as ever)
7. | I have been so unhappy that I have had difficulty sleeping | X | | 3 (Yes, most of the time); 2 (Yes, sometimes); 1 (Not very often); 0 (No, not at all)
8. | I have felt sad or miserable | X | | 3 (Yes, most of the time); 2 (Yes, quite often); 1 (Not very often); 0 (No, not at all)
9. | I have been so unhappy that I have been crying | X | | 3 (Yes, most of the time); 2 (Yes, quite often); 1 (Only occasionally); 0 (No, never)
10. | The thought of harming myself has occurred to me | X | | 3 (Yes, quite often); 2 (Sometimes); 1 (Hardly ever); 0 (Never)

Abbreviation: EPDS = Edinburgh Postnatal Depression Scale.

Appendix A Table 8 Depression Screening Instruments: GAD^20^

Prompt: How often have you been bothered by the following over the past 2 weeks?

Questions | | GAD-7 | GAD-2
1. | Feeling nervous, anxious, or on edge | X | X
2. | Not being able to stop or control worrying | X | X
3. | Worrying too much about different things | X
4. | Trouble relaxing | X
5. | Being so restless that it’s hard to sit still | X
6. | Becoming easily annoyed or irritable | X
7. | Feeling afraid as if something awful might happen | X

Scoring: 3 (nearly every day), 2 (more than half the days), 1 (several days), 0 (not at all)

Abbreviation: GAD = Generalized Anxiety Disorder Scale.

Appendix A Table 9 Anxiety Screening Instruments: PHQ-Panic Disorder^15^

Questions
1. | In the last 4 weeks, have you had an anxiety attack—suddenly feeling fear or panic?
2. | Has this ever happened before?
3. | Do some of these attacks come suddenly out of the blue—that is, in situations where you don’t expect to be nervous or uncomfortable?
4. | Do these attacks bother you a lot or are you worried about having another attack?
5. | During your last bad anxiety attack, did you have symptoms like shortness of breath, sweating, or your heart racing, pounding, or skipping?

Scoring: Yes (1 point) or No (0 points)

Abbreviation: PHQ = Patient Health Questionnaire.

Appendix A Table 10 Anxiety Screening Instruments: GAS^21^

Questions
1. | My heart raced or beat strongly.
2. | My breath was short.
3. | I had an upset stomach.
4. | I felt like things were not real or like I was outside of myself.
5. | I felt like I was losing control.
6. | I was afraid of being judged by others.
7. | I was afraid of being humiliated or embarrassed.
8. | I had difficulty falling asleep.
9. | I had difficulty staying asleep.
10. | I was irritable.
11. | I had outbursts of anger.
12. | I had difficulty concentrating.
13. | I was easily startled or upset.
14. | I was less interested in doing something I typically enjoy.
15. | I felt detached or isolated from others.
16. | I felt like I was in a daze.
17. | I had a hard time sitting still.
18. | I worried too much.
19. | I could not control my worry.
20. | I felt restless, keyed up, or on edge.
21. | I felt tired.
22. | My muscles were tense.
23. | I had back pain, neck pain, or muscle cramps.
24. | I felt like I had no control over my life.
25. | I felt like something terrible was going to happen to me.

Scoring: From 0 (not at all) to 3 (all of the time)

NOTE: Development and initial validation of a self-report assessment tool for anxiety among older adults: The Geriatric Anxiety Scale. Daniel L. Segal, Andrea June, Matthew Payne, Frederick L. Coolidge and Brian Yochim. Journal of Anxiety Disorders, 2010-10-01, Volume 24, Issue 7, Pages 709–714.

Abbreviation: GAS = Geriatric Anxiety Scale.

Appendix A Table 11 Suicide Risk Screening Instruments: SDDS-PC^22^

Questions
1. | Thoughts of death
2. | Wishing you were dead
3. | Feeling suicidal

Abbreviation: SDDS-PC = Symptom Driven Diagnostic System for Primary Care.

Appendix A Table 12 Suicide Risk Screening Instruments: Suicide Risk Assessment Tool^23^

Questions | | Scoring
1. | How much pain are you in? | 5-point scale: 1 (no pain)-5 (worst pain ever)
2. | How are you coping? | Not well/so, so/well
3. | How upset are you? | A lot/a little/Not at all
4. | How would you rate your wish to live? | None (0)/Weak (1)/Moderate to strong (2)
5. | How would you rate your wish to die? | None (0)/Weak (1)/Moderate to strong (2)
6. | Have you been considering suicide in the last month? | Yes/No
7. | Have you had a recent loss? (e.g., job loss/change, relationship change, divorce, change of custody of children, death of a loved one, death of a pet, loss of home, forced to move, bankrupty, dismissal from school, legal troubles, etc.) | Yes/No
8. | Have you recently abused substances? (e.g., alcohol, sedatives or tranquilizers, stimulants, pain killers, marijuana or hashish, cocaine, club drugs, hallucinogens, opioids, inhalants or solvents, other drugs, etc.) | Yes/No
9. | Have you ever attempted to commit suicide? | Yes/No
10. | Have you ever been diagnosed with depression or panic, anxiety, or bipolar disorders? | Yes/No
11. | Have you ever had a previous inpatient psychiatric hospitalization? | Yes/No

Appendix A Table 13 Study-Design Quality Rating Criteria

Study Design | Adapted Quality Criteria
Cohort studies,^*^ adapted from Newcastle-Ottawa Scale^24^ | Bias arising in randomization process or due to confounding; - Balance in baseline characteristics; - No baseline confounding; - No time-varying confounding; Bias in selecting participants into the study; - No evidence of biased selection of sample; - Start of followup and start of intervention coincide; Bias due to departures form intended interventions; - Participant intervention status is clearly and explicitly defined and measured; - Classification of intervention status is unaffected by knowledge of the outcome or risk of the outcome; Bias in classifying interventions; - Fidelity to intervention protocol; - Participants were analyzed as originally allocated; Bias from missing data; - Outcome data are reasonably complete and comparable between groups; - Confounding variables that are controlled for in analysis are reasonably complete; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; No evidence that the measures, analyses, or subgroup analyses are selectively reported
Randomized clinical trials,^*^ adapted from U.S. Preventive Services Task Force Manual^25^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; No evidence that the measures, analyses, or subgroup analyses are selectively reported
Diagnostic accuracy, QUADAS-2^26^ | Patient Selection; - Was a consecutive or random sample of patients enrolled; - Did the study avoid inappropriate exclusions; - Risk of bias: could the selection of patients have introduced bias; Index Test; - Were the index test results interpreted without knowledge of the reference standard results; - If a threshold was used, was it pre-specified or was a range of values presented; - Risk of bias: Could the conduct or interpretation of the index test have introduced bias; Reference Standard; - Is the reference standard likely to correctly classify the target condition; - Were the reference standard results interpreted without knowledge of the index test; - Were staff trained in the use of the reference standard; - Was fidelity of the reference standard monitored or reported; - Risk of bias: Could the reference standard, its conduct, or its interpretation have introduced bias; Flow and Timing; - Was there an appropriate interval between the index test and reference standard; - Did all patients receive a reference standard; - Did all patients receive the same reference standard; - Were all patients included in the analysis; - Risk of bias: Could the patient flow have introduced bias
Systematic reviews,^†^ adapted from U.S. Preventive Services Task Force Manual^25^ | Recency and relevance.; Comprehensiveness of sources considered, and search strategy used; - Was the Search strategy reported; - Were there concerning omissions in the search strategy; - Was the search derived from known database with acceptable search strategy; Standardized appraisal of included studies and risk of bias/quality of individual studies; - Were the inclusion criteria explicitly stated; - Were the inclusion criteria appropriate for the review questions; - Were standardized RoB or quality criteria used in the assessment of individual studies; Validity of conclusions; - Were synthesis methods transparent and nonproblematic; - Were conclusions supported by the evidence

* Good-quality studies generally meet all quality criteria. Fair-quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor-quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.

† Overall confidence in the results of each review was rated according to published guidance: a rating of “high” reflects that the review had zero or one noncritical weakness; “moderate” indicates the review was judged to have more than one noncritical weakness; “low” means the review was judged to have one critical flaw with or without noncritical weaknesses or multiple noncritical weaknesses; and “critically low” signifies that more than one critical flaw was present.