# References

1 Grossman DC, Curry SJ, Owens DK, . Hormone therapy for the primary prevention of chronic conditions in postmenopausal women: US Preventive Services Task Force recommendation statement. JAMA. 2017 Dec 12;318(22):2224–33. doi: 10.1001/jama.2017.18261. PMID: 29234814.29234814
2 Col NF, Fairfield KM, Ewan-Whyte C, . In the clinic. menopause. Ann Intern Med. 2009 Apr 7;150(7):ITC4-1–15; quiz ITC4-6. PMID: 19349628.19349628
3 Harlow SD, Gass M, Hall JE, . Executive summary of the Stages of Reproductive Aging Workshop + 10: addressing the unfinished agenda of staging reproductive aging. Menopause. 2012 Apr;19(4):387–95. doi: 10.1097/gme.0b013e31824d8f40. PMID: 22343510.22343510
4 Kaunitz AM, Manson JE. Management of menopausal symptoms. Obstet Gynecol. 2015 Oct;126(4):859–76. doi: 10.1097/AOG.0000000000001058 [doi]. PMID: 26348174.26348174
5 Centers for Disease Control and Prevention. About chronic diseases. Centers for Disease Control and Prevention; 2021. https://www.cdc.gov/chronicdisease/about/index.htm. Accessed July 27, 2021.
6 Grady D, Rubin SM, Petitti DB, . Hormone therapy to prevent disease and prolong life in postmenopausal women. Ann Intern Med. 1992 Dec 15;117(12):1016–37. PMID: 1443971.1443971
7 Stampfer MJ, Colditz GA. Estrogen replacement therapy and coronary heart disease: a quantitative assessment of the epidemiologic evidence. Prev Med. 1991 Jan;20(1):47–63. PMID: 1826173.1826173
8 Hu FB, Grodstein F, Hennekens CH, . Age at natural menopause and risk of cardiovascular disease. Arch Intern Med. 1999 May 24;159(10):1061–6. PMID: 10335682.10335682
9 Mondul AM, Rodriguez C, Jacobs EJ, . Age at natural menopause and cause-specific mortality. Am J Epidemiol. 2005 Dec 1;162(11):1089–97. doi: 10.1093/aje/kwi324. PMID: 16221806.16221806
10 Derby CA, Crawford SL, Pasternak RC, . Lipid changes during the menopause transition in relation to age and weight: the Study of Women’s Health Across the Nation. Am J Epidemiol. 2009 Jun 1;169(11):1352–61. doi: 10.1093/aje/kwp043. PMID: 19357323.19357323
11 Stampfer MJ, Colditz GA, Willett WC, . Postmenopausal estrogen therapy and cardiovascular disease. ten-year follow-up from the nurses’ health study. N Engl J Med. 1991 Sep 12;325(11):756–62. doi: 10.1056/NEJM199109123251102. PMID: 1870648.1870648
12 Grodstein F, Stampfer MJ, Colditz GA, . Postmenopausal hormone therapy and mortality. N Engl J Med. 1997 Jun 19;336(25):1769–75. doi: 10.1056/nejm199706193362501. PMID: 9187066.9187066
13 Yaffe K, Sawaya G, Lieberburg I, . Estrogen therapy in postmenopausal women: effects on cognitive function and dementia. JAMA. 1998 Mar 4;279(9):688–95. doi: 10.1001/jama.279.9.688. PMID: 9496988.9496988
14 Guidelines for counseling postmenopausal women about preventive hormone therapy. American College of Physicians. Ann Intern Med. 1992 Dec 15;117(12):1038–41. doi: 10.7326/0003-4819-117-12-1038. PMID: 1443972.1443972
15 McKinlay SM. The normal menopause transition: an overview. Maturitas. 1996 Mar;23(2):137–45. PMID: 8735352.8735352
16 Nelson LM. Clinical practice. primary ovarian insufficiency. N Engl J Med. 2009 Feb 5;360(6):606–14. doi: 10.1056/NEJMcp0808697. PMID: 19196677.19196677
17 Pinkerton JV, Stovall DW. Reproductive aging, menopause, and health outcomes. Ann N Y Acad Sci. 2010 Aug;1204:169–78. doi: 10.1111/j.1749-6632.2010.05526.x. PMID: 20738288.20738288
18 Avis NE, Crawford SL, Greendale G, . Duration of menopausal vasomotor symptoms over the menopause transition. JAMA. 2015 Apr;175(4):531–9. doi: 10.1001/jamainternmed.2014.8063. PMID: 25686030.25686030
19 Social Security Administration. Acturarial life table. Period life table, 2010. Washington, DC: Social Security Administration; n.d. http://www.ssa.gov/oact/STATS/table4c6.html. Accessed April 24, 2015.
20 El Khoudary SR, Aggarwal B, Beckie TM, . Menopause transition and cardiovascular disease risk: implications for timing of early prevention: a scientific statement from the American Heart Association. Circulation. 2020 Dec 22;142(25):e506–e32. doi: 10.1161/cir.0000000000000912. PMID: 33251828.33251828
21 Matthews KA, Crawford SL, Chae CU, . Are changes in cardiovascular disease risk factors in midlife women due to chronological aging or to the menopausal transition? J Am Coll Cardiol. 2009 Dec 15;54(25):2366–73. doi: 10.1016/j.jacc.2009.10.009. PMID: 20082925.20082925
22 Thurston RC, Karvonen-Gutierrez CA, Derby CA, . Menopause versus chronologic aging: their roles in women’s health. Menopause. 2018 Aug;25(8):849–54. doi: 10.1097/gme.0000000000001143. PMID: 30045364.30045364
23 El Khoudary SR, Wildman RP, Matthews K, . Progression rates of carotid intima-media thickness and adventitial diameter during the menopausal transition. Menopause. 2013 Jan;20(1):8–14. doi: 10.1097/gme.0b013e3182611787. PMID: 22990755.22990755
24 Samargandy S, Matthews KA, Brooks MM, . Arterial stiffness accelerates within 1 year of the final menstrual period: the SWAN Heart Study. Arterioscler Thromb Vasc Biol. 2020 Apr;40(4):1001–8. doi: 10.1161/atvbaha.119.313622. PMID: 31969013.31969013
25 Muka T, Oliver-Williams C, Kunutsor S, . Association of age at onset of menopause and time since onset of menopause with cardiovascular outcomes, intermediate vascular traits, and all-cause mortality: a systematic review and meta-analysis. JAMA Cardiol. 2016 Oct 1;1(7):767–76. doi: 10.1001/jamacardio.2016.2415. PMID: 27627190.27627190
26 Lobo RA. Surgical menopause and cardiovascular risks. Menopause. 2007 May–Jun;14(3 Pt 2):562–6. doi: 10.1097/gme.0b013e318038d333. PMID: 17476145.17476145
27 US Food and Drug Administration. Menopause: medicines to help you. FDA Office of Women’s Health, US Food and Drug Administration; 2019. https://www.fda.gov/consumers/free-publications-women/menopause-medicines-help-you. Accessed August 30, 2021.
28 US Food and Drug Administration. Menopause & hormones: common questions. 2019. https://www.fda.gov/media/130242/download. Accessed August 30, 2021.
29 Boardman Henry MP, Hartley L, Eisinga A, . Hormone therapy for preventing cardiovascular disease in post-menopausal women. Cochrane Database Syst Rev. 2015(3)doi: 10.1002/14651858.CD002229.pub4. PMID: CD002229.
30 Mohammed K, Abu Dabrh AM, Benkhadra K, . Oral vs transdermal estrogen therapy and vascular events: a systematic review and meta-analysis. J Clin Endocrinol Metab. 2015 Nov;100(11):4012–20. doi: 10.1210/jc.2015-2237 [doi]. PMID: 26544651.26544651
31 Vinogradova Y, Coupland C, Hippisley-Cox J. Use of hormone replacement therapy and risk of venous thromboembolism: nested case-control studies using the QResearch and CPRD databases. BMJ. 2019 Jan 9;364:k4810. doi: 10.1136/bmj.k4810. PMID: 30626577.30626577
32 Effects of estrogen or estrogen/progestin regimens on heart disease risk factors in postmenopausal women. The Postmenopausal Estrogen/Progestin Interventions (PEPI) Trial. The Writing Group for the PEPI Trial. JAMA. 1995 Jan 18;273(3):199–208. PMID: 7807658.7807658
33 Grant MD, Marbella A, Wang AT, . Menopausal symptoms: comparative effectiveness of therapies. Comparative Effectiveness Review No. 147. (Prepared by Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-2007-10058-I.). AHRQ Publication No. 15-EHC005-EF. Rockville, MD: Agency for Healthcare Research and Quality; March 2015. www.effectivehealthcare.ahrq.gov/reports/final.cfm
34 Lukes A. Evolving issues in the clinical and managed care settings on the management of menopause following the women’s health initiative. J Manag Care Pharm. 2008 Apr;14(3 Suppl):7–13. PMID: 18439061.18439061
35 Brett KM, Chong Y. Hormone replacement therapy: knowledge and use in the United States. Hyattsville, MD: National Center for Health Statistics; 2001.
36 Rossouw JE, Anderson GL, Prentice RL, . Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results from the Women’s Health Initiative randomized controlled trial. JAMA. 2002 Jul 17;288(3):321–33. PMID: 12117397.12117397
37 Anderson GL, Limacher M, Assaf AR, . Effects of conjugated equine estrogen in postmenopausal women with hysterectomy: the Women’s Health Initiative randomized controlled trial. JAMA. 2004 Apr 14;291(14):1701–12. PMID: 15082697.15082697
38 Sprague BL, Trentham-Dietz A, Cronin KA. A sustained decline in postmenopausal hormone use: results from the National Health and Nutrition Examination Survey, 1999-2010. Obstet Gynecol. 2012 Sep;120(3):595–603. doi: 10.1097/AOG.0b013e318265df42. PMID: 22914469.22914469
39 Crawford SL, Crandall CJ, Derby CA, . Menopausal hormone therapy trends before versus after 2002: impact of the Women’s Health Initiative Study Results. Menopause. 2018 Dec 21;26(6):588–97. doi: 10.1097/gme.0000000000001282. PMID: 30586004.30586004
40 Pinkerton JV, Santoro N. Compounded bioidentical hormone therapy: identifying use trends and knowledge gaps among US women. Menopause. 2015 Sep;22(9):926–36. doi: 10.1097/GME.0000000000000420 [doi]. PMID: 25692877.25692877
41 Stuenkel CA, Manson JE. Compounded bioidentical hormone therapy: does the regulatory double standard harm women? JAMA Intern Med. 2017 Dec 1;177(12):1719–20. doi: 10.1001/jamainternmed.2017.5141. PMID: 29052690.29052690
42 American College of Obstetricians and Gynecologists. ACOG Committee Opinion No. 565: hormone therapy and heart disease. Obstet Gynecol. 2013 Jun;121(6):1407–10. doi: 10.1097/01.AOG.0000431053.33593.2d. PMID: 23812486.23812486
43 Cobin RH, Goodman NF. American Association of Clinical Endocrinologists and American College of Endocrinology position statement on menopause-2017 update. Endocr Pract. 2017 Jul;23(7):869–80. doi: 10.4158/ep171828.PS. PMID: 28703650.28703650
44 Shifren JL, Gass ML. The North American Menopause Society recommendations for clinical care of midlife women. Menopause. 2014 Oct;21(10):1038–62. doi: 10.1097/gme.0000000000000319. PMID: 25225714.25225714
45 Whitmer RA, Quesenberry CP, Zhou J, . Timing of hormone therapy and dementia: the critical window theory revisited. Ann Neurol. 2011 Jan;69(1):163–9. doi: 10.1002/ana.22239. PMID: 21280086.21280086
46 Hodis HN, Mack WJ, Henderson VW, . Vascular effects of early versus late postmenopausal treatment with estradiol. N Engl J Med. 2016 Mar 31;374(13):1221–31. doi: 10.1056/NEJMoa1505241. PMID: 27028912.27028912
47 Williams JK, Anthony MS, Honore EK, . Regression of atherosclerosis in female monkeys. Arterioscler Thromb Vasc Biol. 1995 Jul;15(7):827–36. PMID: 7600113.7600113
48 Stampfer MJ, Willett WC, Colditz GA, . A prospective study of postmenopausal estrogen therapy and coronary heart disease. N Engl J Med. 1985 Oct 24;313(17):1044–9. doi: 10.1056/NEJM198510243131703. PMID: 4047106.4047106
49 Grodstein F, Manson JE, Colditz GA, . A prospective, observational study of postmenopausal hormone therapy and primary prevention of cardiovascular disease. Ann Intern Med. 2000 Dec 19;133(12):933–41. PMID: 11119394.11119394
50 Salpeter SR, Walsh JM, Greyber E, . Mortality associated with hormone replacement therapy in younger and older women: a meta-analysis. J Gen Intern Med. 2004 Jul;19(7):791–804. doi: 10.1111/j.1525-1497.2004.30281.x. PMID: 15209595.15209595
51 Rocca WA, Grossardt BR, Shuster LT. Oophorectomy, estrogen, and dementia: a 2014 update. Mol Cell Endocrinol. 2014 May 25;389(1–2):7–12. doi: 10.1016/j.mce.2014.01.020. PMID: 24508665.24508665
52 Rossouw JE, Prentice RL, Manson JE, . Postmenopausal hormone therapy and risk of cardiovascular disease by age and years since menopause.[Erratum appears in JAMA. 2008 Mar 26;299(12):1426]. JAMA. 2007 Apr 4;297(13):1465–77. doi: 10.1001/jama.297.13.1465. PMID: 17405972.17405972
53 Harman SM, Black DM, Naftolin F, . Arterial imaging outcomes and cardiovascular risk factors in recently menopausal women: a randomized trial. Ann Intern Med. 2014 Aug 19;161(4):249–60. doi: 10.7326/m14-0353. PMID: 25069991.25069991
54 Marjoribanks J, Farquhar C, Roberts H, . Long-term hormone therapy for perimenopausal and postmenopausal women. Cochrane Database Syst Rev. 2017 Jan 17;1(1):Cd004143. doi: 10.1002/14651858.CD004143.pub5. PMID: 28093732.28093732
55 Yang Z, Hu Y, Zhang J, . Estradiol therapy and breast cancer risk in perimenopausal and postmenopausal women: a systematic review and meta-analysis. Gynecol Endocrinol. 2017 Feb;33(2):87–92. doi: 10.1080/09513590.2016.1248932. PMID: 27898258.27898258
56 Sjögren LL, Mørch LS, Løkkegaard E. Hormone replacement therapy and the risk of endometrial cancer: a systematic review. Maturitas. 2016 Sep;91:25–35. doi: 10.1016/j.maturitas.2016.05.013. PMID: 27451318.27451318
57 Kim S, Ko Y, Lee HJ, . Menopausal hormone therapy and the risk of breast cancer by histological type and race: a meta-analysis of randomized controlled trials and cohort studies. Breast Cancer Res Treat. 2018 Aug;170(3):667–75. doi: 10.1007/s10549-018-4782-2. PMID: 29713854.29713854
58 Collaborative Group on Hormonal Factors in Breast Cancer. Type and timing of menopausal hormone therapy and breast cancer risk: individual participant meta-analysis of the worldwide epidemiological evidence. Lancet. 2019 Sep 28;394(10204):1159–68. doi: 10.1016/s0140-6736(19)31709-x. PMID: 31474332.31474332
59 Liu Y, Ma L, Yang X, . Menopausal hormone replacement therapy and the risk of ovarian cancer: a meta-analysis. Front Endocrinol (Lausanne). 2019;10:801. doi: 10.3389/fendo.2019.00801. PMID: 31849838.31849838
60 Nudy M, Chinchilli VM, Foy AJ. A systematic review and meta-regression analysis to examine the ‘timing hypothesis’ of hormone replacement therapy on mortality, coronary heart disease, and stroke. Int J Cardiol Heart Vasc. 2019 Mar;22:123–31. doi: 10.1016/j.ijcha.2019.01.001. PMID: 30705938.30705938
61 Nelson HD, Walker M, Zakher B, . Menopausal hormone therapy for the primary prevention of chronic conditions: systematic review to update the 2002 and 2005 U.S. Preventive Services Task Force recommendations. Evidence Synthesis No. 93. AHRQ Pub. No. 12-05168-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; May 2012.
62 Gartlehner G, Patel SV, Feltner C, . Hormone therapy for the primary prevention of chronic conditions in postmenopausal women: evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2017 Dec 12;318(22):2234–49. doi: 10.1001/jama.2017.16952. PMID: 29234813.29234813
63 Cherry N, Gilmour K, Hannaford P, . Oestrogen therapy for prevention of reinfarction in postmenopausal women: a randomised placebo controlled trial. Lancet. 2002 Dec 21–28;360(9350):2001–8. doi: 10.1016/s0140-6736(02)12001-0. PMID: 12504395.12504395
64 United Nations Development Programme. Human Development Index (HDI) ranking. In: Human Development Report 2020: The Next Frontier: Human Development and the Anthropocene. New York City, NY: United Nations Development Programme; 2020. https://hdr.undp.org/en/content/latest-human-development-index-ranking. Accessed July 9, 2021.
65 Harris RP, Helfand M, Woolf SH, . Current methods of the third US Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21–35. PMID: 11306229.11306229
66 West SL, Gartlehner G, Mansfield AJ, . Comparative Effectiveness Review Methods: Clinical Heterogeneity. Agency for Healthcare Research and Quality. AHRQ Publication No. 10-EHC070-EF. Rockville, MD: Quality AfHRa; 2010 Sep. PMID: 2143333721433337. http://effectivehealthcare.ahrq.gov/
67 Manson JE, Chlebowski RT, Stefanick ML, . Menopausal hormone therapy and health outcomes during the intervention and extended poststopping phases of the Women’s Health Initiative randomized trials. JAMA. 2013 Oct 2;310(13):1353–68. doi: 10.1001/jama.2013.278040. PMID: 24084921.24084921
68 Higgins JP, Thompson SG, Deeks JJ, . Measuring inconsistency in meta-analyses. BMJ. 2003 Sep 6;327(7414):557–60. doi: 10.1136/bmj.327.7414.557. PMID: 12958120.12958120
69 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002 Jun 15;21(11):1539–58. doi: 10.1002/sim.1186. PMID: 12111919.12111919
70 Higgins JPT, Green S, eds. Cochrane handbook for systematic reviews of interventions version 5.1.0 [updated March 2011]. London: The Cochrane Collaboration; 2011.
71 Rucker G, Schwarzer G, Carpenter JR, . Undue reliance on I(2) in assessing heterogeneity may mislead. BMC Med Res Methodol. 2008;8:79. doi: 10.1186/1471-2288-8-79. PMID: 19036172.19036172
72 Berkman ND, Lohr KN, Ansari MT, . Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2015 Nov;68(11):1312–24. doi: 10.1016/j.jclinepi.2014.11.023. PMID: 25721570.25721570
73 Guyatt GH, Oxman AD, Vist G, . GRADE guidelines: 4. Rating the quality of evidence--study limitations (risk of bias). J Clin Epidemiol. 2011 Apr;64(4):407–15. doi: 10.1016/j.jclinepi.2010.07.017. PMID: 21247734.21247734
74 Guyatt GH, Oxman AD, Kunz R, . GRADE guidelines: 7. Rating the quality of evidence--inconsistency. J Clin Epidemiol. 2011 Dec;64(12):1294–302. doi: 10.1016/j.jclinepi.2011.03.017. PMID: 21803546.21803546
75 Guyatt GH, Oxman AD, Kunz R, . GRADE guidelines: 6. Rating the quality of evidence--imprecision. J Clin Epidemiol. 2011 Dec;64(12):1283–93. doi: 10.1016/j.jclinepi.2011.01.012. PMID: 21839614.21839614
76 Guyatt GH, Oxman AD, Kunz R, . GRADE guidelines: 8. Rating the quality of evidence--indirectness. J Clin Epidemiol. 2011 Dec;64(12):1303–10. doi: 10.1016/j.jclinepi.2011.04.014. PMID: 21802903.21802903
77 Balshem H, Helfand M, Schunemann HJ, . GRADE guidelines: 3. Rating the quality of evidence. J Clin Epidemiol. 2011 Apr;64(4):401–6. doi: 10.1016/j.jclinepi.2010.07.015. PMID: 21208779.21208779
78 Guyatt GH, Oxman AD, Sultan S, . GRADE guidelines: 9. Rating up the quality of evidence. J Clin Epidemiol. 2011 Dec;64(12):1311–6. doi: 10.1016/j.jclinepi.2011.06.004. PMID: 21802902.21802902
79 Hsia J, Criqui MH, Herrington DM, . Conjugated equine estrogens and peripheral arterial disease risk: the Women’s Health Initiative. Am Heart J. 2006 Jul;152(1):170–6. doi: 10.1016/j.ahj.2005.09.005. PMID: 16824852.16824852
80 Hsia J, Criqui MH, Rodabough RJ, . Estrogen plus progestin and the risk of peripheral aerterial disease. Circulation. 2004;109(5):620–26. doi: 10.1161/01.CIR.0000115309.63979.92. PMID: 14769684.14769684
81 Perez MV, Wang PJ, Larson JC, . Effects of postmenopausal hormone therapy on incident atrial fibrillation: the Women’s Health Initiative randomized controlled trials. Circ Arrhythm Electrophysiol. 2012 Dec;5(6):1108–16. doi: 10.1161/circep.112.972224. PMID: 23169946.23169946
82 Bumbu A, Bianca P, Tit DM, . The effects of soy isoflavones and hormonal replacing therapy on the incidence and evolution of postmenopausal female urinary incontinence. Farmacia. 2016;64(3):419–22.
83 Mosekilde L, Beck-Nielsen H, Sorensen OH, . Hormonal replacement therapy reduces forearm fracture incidence in recent postmenopausal women - results of the Danish Osteoporosis Prevention Study. Maturitas. 2000 Oct 31;36(3):181–93. PMID: 11063900.11063900
84 Clarke SC, Kelleher J, Lloyd-Jones H, . A study of hormone replacement therapy in postmenopausal women with ischaemic heart disease: the Papworth HRT atherosclerosis study. BJOG. 2002 Sep;109(9):1056–62. PMID: 12269682.12269682
85 Notelovitz M, John VA, Good WR. Effectiveness of Alora estradiol matrix transdermal delivery system in improving lumbar bone mineral density in healthy, postmenopausal women. Menopause. 2002 Sep–Oct;9(5):343–53. PMID: 12218723.12218723
86 Pefanco MA, Kenny AM, Kaplan RF, . The effect of 3-year treatment with 0.25 mg/day of micronized 17beta-estradiol on cognitive function in older postmenopausal women. J Am Geriatr Soc. 2007 Mar;55(3):426–31. doi: 10.1111/j.1532-5415.2007.01085.x. PMID: 17341247.17341247
87 Chlebowski RT, Anderson GL, Aragaki AK, . Association of menopausal hormone therapy with breast cancer incidence and mortality during long-term follow-up of the women’s health initiative randomized clinical trials. JAMA. 2020 Jul 28;324(4):369–80. doi: 10.1001/jama.2020.9482. PMID: 32721007.32721007
88 Manson JE, Aragaki AK, Rossouw JE, . Menopausal hormone therapy and long-term all-cause and cause-specific mortality: the Women’s Health Initiative randomized trials. JAMA. 2017 Sep 12;318(10):927–38. doi: 10.1001/jama.2013.278040. PMID: 28898378.28898378
89 Manson JE, Aragaki AK, Bassuk SS, . Menopausal estrogen-alone therapy and health outcomes in women with and without bilateral oophorectomy: a randomized trial. Ann Intern Med. 2019 Sep 17;171(6):406–14. doi: 10.7326/m19-0274. PMID: 31499528.31499528
90 Chlebowski RT, Anderson GL, Aragaki AK, . Breast cancer and menopausal hormone therapy by race/ethnicity and body mass index. J Natl Cancer Inst. 2016 Feb;108(2)doi: 10.1093/jnci/djv327. PMID: 26546117.26546117
91 Prentice RL, Aragaki AK, Chlebowski RT, . Randomized trial evaluation of benefits and risks of menopausal hormone therapy among women aged 50-59. Am J Epidemiol. 2020 Oct 7doi: 10.1093/aje/kwaa210. PMID: 33025002.33025002
92 Henderson VW, St John JA, Hodis HN, . Cognitive effects of estradiol after menopause: a randomized trial of the timing hypothesis. Neurology. 2016 Aug 16;87(7):699–708. doi: 10.1212/wnl.0000000000002980. PMID: 27421538.27421538
93 Espeland MA, Rapp SR, Manson JE, . Long-term effects on cognitive trajectories of postmenopausal hormone therapy in two age groups. J Gerontol A Biol Sci Med Sci. 2017 Jun 1;72(6):838–45. doi: 10.1093/gerona/glw156. PMID: 27506836.27506836
94 Chlebowski RT, Anderson GL, Sarto GE, . Continuous combined estrogen plus progestin and endometrial cancer: the Women’s Health Initiative randomized trial. J Natl Cancer Inst. 2016 Mar;108(3)doi: 10.1093/jnci/djv350. PMID: 26668177.26668177
95 Chlebowski RT, Barrington W, Aragaki AK, . Estrogen alone and health outcomes in black women by African ancestry: a secondary analyses of a randomized controlled trial. Menopause. 2017 Feb;24(2):133–41. doi: 10.1097/gme.0000000000000733. PMID: 27749739.27749739
96 Kato I, Chlebowski RT, Hou L, . Menopausal estrogen therapy and non-Hodgkin’s lymphoma: a post-hoc analysis of Women’s Health Initiative randomized clinical trial. Int J Cancer. 2016 Feb 1;138(3):604–11. doi: 10.1002/ijc.29819. PMID: 26365326.26365326
97 Watts NB, Cauley JA, Jackson RD, . No increase in fractures after stopping hormone therapy: results from the Women’s Health Initiative. J Clin Endocrinol Metab. 2017 Jan 1;102(1):302–8. doi: 10.1210/jc.2016-3270. PMID: 27820659.27820659
98 Chlebowski RT, Wakelee H, Pettinger M, . Estrogen plus progestin and lung cancer: follow-up of the Women’s Health Initiative randomized trial. Clin Lung Cancer. 2016 Jan;17(1):10–7.e1. doi: 10.1016/j.cllc.2015.09.004. PMID: 26577506.26577506
99 Liu L, Klein L, Eaton C, . Menopausal hormone therapy and risks of first hospitalized heart failure and its subtypes during the intervention and extended postintervention follow-up of the Women’s Health Initiative randomized trials. J Card Fail. 2020 Jan;26(1):2–12. doi: 10.1016/j.cardfail.2019.09.006. PMID: 31536806.31536806
100 Kantarci K, Tosakulwong N, Lesnick TG, . Effects of hormone therapy on brain structure. Neurology. 2016;87(9):887–96. doi: 10.1212/WNL.0000000000002970.27473135
101 Prentice RL, Aragaki AK, Chlebowski RT, . Dual outcome intention-to-treat analyses in the Women’s Health Initiative randomized controlled hormone therapy trials. Am J Epidemiol. 2020doi: 10.1093/aje/kwaa033. PMID: CN-02122748.
102 Mørch LS, Kjaer SK, Keiding N, . The influence of hormone therapies on type I and II endometrial cancer: a nationwide cohort study. Int J Cancer. 2016 Mar 15;138(6):1506–15. doi: 10.1002/ijc.29878. PMID: 26421912.26421912
103 Park SY, Wilkens LR, Kolonel LN, . Inverse associations of dietary fiber and menopausal hormone therapy with colorectal cancer risk in the Multiethnic Cohort Study. Int J Cancer. 2016 Sep 15;139(6):1241–50. doi: 10.1002/ijc.30172. PMID: 27137137.27137137
104 Bethea TN, Palmer JR, Adams-Campbell LL, . A prospective study of reproductive factors and exogenous hormone use in relation to ovarian cancer risk among Black women. Cancer Causes Control. 2017 May;28(5):385–91. doi: 10.1007/s10552-016-0840-4. PMID: 28025764.28025764
105 Waters DD, Alderman EL, Hsia J, . Effects of hormone replacement therapy and antioxidant vitamin supplements on coronary atherosclerosis in postmenopausal women: a randomized controlled trial. JAMA. 2002 Nov 20;288(19):2432–40. PMID: 12435256.12435256
106 Gallagher JC, Fowler SE, Detter JR, . Combination treatment with estrogen and calcitriol in the prevention of age-related bone loss. J Clin Endocrinol Metab. 2001 Aug;86(8):3618–28. doi: 10.1210/jcem.86.8.7703. PMID: 11502787.11502787
107 Greenspan SL, Resnick NM, Parker RA. The effect of hormone replacement on physical performance in community-dwelling elderly women. Am J Med. 2005 Nov;118(11):1232–9. doi: 10.1016/j.amjmed.2005.03.004. PMID: 16271907.16271907
108 LaCroix AZ, Chlebowski RT, Manson JE, . Health outcomes after stopping conjugated equine estrogens among postmenopausal women with prior hysterectomy: a randomized controlled trial. JAMA. 2011 Apr 6;305(13):1305–14. doi: 10.1001/jama.2011.382. PMID: 21467283.21467283
109 Anderson GL, Chlebowski RT, Aragaki AK, . Conjugated equine oestrogen and breast cancer incidence and mortality in postmenopausal women with hysterectomy: extended follow-up of the Women’s Health Initiative randomised placebo-controlled trial. Lancet Oncol. 2012 May;13(5):476–86. doi: 10.1016/s1470-2045(12)70075-x. PMID: 22401913.22401913
110 Prentice RL, Manson JE, Langer RD, . Benefits and risks of postmenopausal hormone therapy when it is initiated soon after menopause. Am J Epidemiol. 2009 Jul 1;170(1):12–23. doi: 10.1093/aje/kwp115. PMID: 19468079.19468079
111 Chlebowski RT, Rohan TE, Manson JE, . Breast cancer after use of estrogen plus progestin and estrogen alone: analyses of data from 2 women’s health initiative randomized clinical trials. JAMA Oncol. 2015 Jun;1(3):296–305. doi: 10.1001/jamaoncol.2015.0494. PMID: 26181174.26181174
112 Hodis HN, Mack WJ, Lobo RA, . Estrogen in the prevention of atherosclerosis. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 2001 Dec 4;135(11):939–53. PMID: 11730394.11730394
113 Herrington DM, Reboussin DM, Brosnihan KB, . Effects of estrogen replacement on the progression of coronary-artery atherosclerosis. N Engl J Med. 2000 Aug 24;343(8):522–9. doi: 10.1056/nejm200008243430801. PMID: 10954759.10954759
114 Ritenbaugh C, Stanford JL, Wu L, . Conjugated equine estrogens and colorectal cancer incidence and survival: the Women’s Health Initiative randomized clinical trial. Cancer Epidemiol Biomarkers Prev. 2008 Oct;17(10):2609–18. doi: 10.1158/1055-9965.EPI-08-0385. PMID: 18829444.18829444
115 Johnson SR, Ettinger B, Macer JL, . Uterine and vaginal effects of unopposed ultralow-dose transdermal estradiol. Obstet Gynecol. 2005;105(4):779–87. doi: 10.1097/01.AOG.0000157116.23249.52. PMID: 15802405.15802405
116 Chlebowski RT, Anderson GL, Manson JE, . Lung cancer among postmenopausal women treated with estrogen alone in the women’s health initiative randomized trial. J Natl Cancer Inst. 2010 Sep 22;102(18):1413–21. doi: 10.1093/jnci/djq285. PMID: 20709992.20709992
117 Hsia J, Langer RD, Manson JE, . Conjugated equine estrogens and coronary heart disease: the Women’s Health Initiative. Arch Intern Med. 2006 Feb 13;166(3):357–65. doi: 10.1001/archinte.166.3.357. PMID: 16476878.16476878
118 Resnick SM, Coker LH, Maki PM, . The Women’s Health Initiative Study of Cognitive Aging (WHISCA): a randomized clinical trial of the effects of hormone therapy on age-associated cognitive decline. Clin Trials. 2004;1(5):440–50. doi: 10.1191/1740774504cn040oa. PMID: 16279282.16279282
119 Shumaker SA, Legault C, Kuller L, . Conjugated equine estrogens and incidence of probable dementia and mild cognitive impairment in postmenopausal women: Women’s Health Initiative Memory Study. JAMA. 2004 Jun 23;291(24):2947–58. doi: 10.1001/jama.291.24.2947. PMID: 15213206.15213206
120 Resnick SM, Espeland MA, An Y, . Effects of conjugated equine estrogens on cognition and affect in postmenopausal women with prior hysterectomy. J Clin Endocrinol Metab. 2009 Nov;94(11):4152–61. doi: 10.1210/jc.2009-1340. PMID: 19850684.19850684
121 Espeland MA, Rapp SR, Shumaker SA, . Conjugated equine estrogens and global cognitive function in postmenopausal women: Women’s Health Initiative Memory Study. JAMA. 2004 Jun 23;291(24):2959–68. doi: 10.1001/jama.291.24.2959. PMID: 15213207.15213207
122 Espeland MA, Brunner RL, Hogan PE, . Long-term effects of conjugated equine estrogen therapies on domain-specific cognitive function: results from the Women’s Health Initiative study of cognitive aging extension. J Am Geriatr Soc. 2010 Jul;58(7):1263–71. doi: 10.1111/j.1532-5415.2010.02953.x. PMID: 20649689.20649689
123 Espeland MA, Shumaker SA, Leng I, . Long-term effects on cognitive function of postmenopausal hormone therapy prescribed to women aged 50 to 55 years. JAMA Intern Med. 2013 Aug 12;173(15):1429–36. doi: 10.1001/jamainternmed.2013.7727. PMID: 23797469.23797469
124 Yaffe K, Vittinghoff E, Ensrud KE, . Effects of ultra-low-dose transdermal estradiol on cognition and health-related quality of life. Arch Neurol. 2006 Jul;63(7):945–50. doi: 10.1001/archneur.63.7.945. PMID: 16831962.16831962
125 Bonds DE, Lasser N, Qi L, . The effect of conjugated equine oestrogen on diabetes incidence: the Women’s Health Initiative randomised trial. Diabetologia. 2006 Mar;49(3):459–68. doi: 10.1007/s00125-005-0096-0. PMID: 16440209.16440209
126 Anderson GL, Judd HL, Kaunitz AM, . Effects of estrogen plus progestin on gynecologic cancers and associated diagnostic procedures: the Women’s Health Initiative randomized trial. JAMA. 2003 Oct 1;290(13):1739–48. PMID: 14519708.14519708
127 Cirillo DJ, Wallace RB, Rodabough RJ, . Effect of estrogen therapy on gallbladder disease. JAMA. 2005;293:330–9. doi: 10.1001/jama.293.3.330. PMID: 15657326.15657326
128 Hendrix SL, Wassertheil-Smoller S, Johnson KC, . Effects of conjugated equine estrogen on stroke in the Women’s Health Initiative. Circulation. 2006 May 23;113(20):2425–34. doi: 10.1161/CIRCULATIONAHA.105.594077. PMID: 16702472.16702472
129 Waetjen LE, Brown JS, Vittinghoff E, . The effect of ultralow-dose transdermal estradiol on urinary incontinence in postmenopausal women. Obstet Gynecol. 2005 Nov;106:946–52. doi: 10.1097/01.AOG.0000182576.48290.6d. PMID: 16260511.16260511
130 Hendrix SL, Cochrane BB, Nygaard IE, . Effects of estrogen with and without progestin on urinary incontinence. JAMA. 2005 Feb 23;293(8):935–48. doi: 10.1001/jama.293.8.935. PMID: 15728164.15728164
131 Curb JD, Prentice RL, Bray PF, . Venous thrombosis and conjugated equine estrogen in women without a uterus. Arch Intern Med. 2006 Apr 10;166(7):772–80. doi: 10.1001/archinte.166.7.772. PMID: 16606815.16606815
132 Heiss G, Wallace R, Anderson GL, . Health risks and benefits 3 years after stopping randomized treatment with estrogen and progestin. JAMA. 2008 Mar 5;299(9):1036–45. doi: 10.1001/jama.299.9.1036. PMID: 18319414.18319414
133 Chlebowski RT, Hendrix SL, Langer RD, . Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women’s Health Initiative Randomized Trial. JAMA. 2003 Jun 25;289(24):3243–53. doi: 10.1001/jama.289.24.3243. PMID: 12824205.12824205
134 Chlebowski RT, Anderson GL, Gass M, . Estrogen plus progestin and breast cancer incidence and mortality in postmenopausal women. JAMA. 2010 Oct 20;304(15):1684–92. doi: 10.1001/jama.2010.1500. PMID: 20959578.20959578
135 Gramling R, Eaton CB, Rothman KJ, . Hormone replacement therapy, family history, and breast cancer risk among postmenopausal women. Epidemiology. 2009 Sep;20(5):752–6. doi: 10.1097/EDE.0b013e3181a71279. PMID: 19451819.19451819
136 Hulley S, Furberg C, Barrett-Connor E, . Noncardiovascular disease outcomes during 6.8 years of hormone therapy: Heart and Estrogen/progestin Replacement Study follow-up (HERS II). JAMA. 2002 Jul 3;288(1):58–66. doi: 10.1001/jama.288.1.58. PMID: 12090863.12090863
137 Veerus P, Hovi SL, Fischer K, . Results from the Estonian postmenopausal hormone therapy trial [ISRCTN35338757]. Maturitas. 2006 Sep 20;55(2):162–73. doi: 10.1016/j.maturitas.2006.01.012. PMID: 16504428.16504428
138 Vickers MR, MacLennan AH, Lawton B, . Main morbidities recorded in the women’s international study of long duration oestrogen after menopause (WISDOM): a randomised controlled trial of hormone replacement therapy in postmenopausal women. BMJ. 2007 Aug 4;335(7613):239. doi: 10.1136/bmj.39266.425069.AD. PMID: 17626056.17626056
139 Vickers MR, Martin J, Meade TW, . The Women’s international study of long-duration oestrogen after menopause (WISDOM): a randomised controlled trial. BMC Womens Health. 2007 Feb 26;7(2):2. doi: 10.1186/1472-6874-7-2. PMID: 17324282.17324282
140 Chlebowski RT, Wactawski-Wende J, Ritenbaugh C, . Estrogen plus progestin and colorectal cancer in postmenopausal women. N Engl J Med. 2004 Mar 4;350(10):991–1004. doi: 10.1056/NEJMoa032071. PMID: 14999111.14999111
141 Tierney MC, Oh P, Moineddin R, . A randomized double-blind trial of the effects of hormone therapy on delayed verbal recall in older women. Psychoneuroendocrinology. 2009 Aug;34(7):1065–74. doi: 10.1016/j.psyneuen.2009.02.009. PMID: 19297102.19297102
142 Chlebowski RT, Schwartz AG, Wakelee H, . Oestrogen plus progestin and lung cancer in postmenopausal women (Women’s Health Initiative trial): a post-hoc analysis of a randomised controlled trial. Lancet. 2009 Oct 10;374(9697):1243–51. doi: 10.1016/S0140-6736(09)61526-9. PMID: 19767090.19767090
143 Shumaker SA, Legault C, Rapp SR, . Estrogen plus progestin and the incidence of dementia and mild cognitive impairment in postmenopausal women: the Women’s Health Initiative Memory Study: a randomized controlled trial. JAMA. 2003 May 28;289(20):2651–62. doi: 10.1001/jama.289.20.2651. PMID: 12771112.12771112
144 Resnick SM, Maki PM, Rapp SR, . Effects of combination estrogen plus progestin hormone treatment on cognition and affect. J Clin Endocrinol Metab. 2006 May;91(5):1802–10. doi: 10.1210/jc.2005-2097. PMID: 16522699.16522699
145 Grady D, Yaffe K, Kristof M, . Effect of postmenopausal hormone therapy on cognitive function: the Heart and Estrogen/progestin Replacement Study. Am J Med. 2002 Nov;113(7):543–8. doi: 10.1016/s0002-9343(02)01270-6. PMID: 12459399.12459399
146 Gleason CE, Dowling NM, Wharton W, . Effects of hormone therapy on cognition and mood in recently postmenopausal women: findings from the Randomized, Controlled KEEPS-Cognitive and Affective Study. PLoS Med. 2015 Jun;12(6):e1001833. doi: 10.1371/journal.pmed.1001833. PMID: 26035291.26035291
147 Rapp SR, Espeland MA, Shumaker SA, . Effect of estrogen plus progestin on global cognitive function in postmenopausal women: the Women’s Health Initiative Memory Study: a randomized controlled trial. JAMA. 2003 May 28;289(20):2663–72. doi: 10.1001/jama.289.20.2663. PMID: 12771113.12771113
148 Kanaya AM, Herrington D, Vittinghoff E, . Glycemic effects of postmenopausal hormone therapy: the Heart and Estrogen/progestin Replacement Study: a randomized, double-blind, placebo-controlled trial. Ann Intern Med. 2003 Jan 7;138(1):1–9. doi: 10.7326/0003-4819-138-1-200301070-00005. PMID: 12513038.12513038
149 Margolis KL, Bonds DE, Rodabough RJ, . Effect of oestrogen plus progestin on the incidence of diabetes in postmenopausal women: results from the Women’s Health Initiative Hormone Trial. Diabetologia. 2004 Jul;47(7):1175–87. doi: 10.1007/s00125-004-1448-x. PMID: 15252707.15252707
150 Cauley JA, Robbins J, Chen Z, . Effects of estrogen plus progestin on risk of fracture and bone mineral density: the Women’s Health Initiative randomized trial. JAMA. 2003 Oct 1;290(13):1729–38. doi: 10.1001/jama.290.13.1729. PMID: 14519707.14519707
151 Wassertheil-Smoller S, Hendrix SL, Limacher M, . Effect of estrogen plus progestin on stroke in postmenopausal women: the Women’s Health Initiative: a randomized trial. JAMA. 2003 May 28;289(20):2673–84. doi: 10.1001/jama.289.20.2673. PMID: 12771114.12771114
152 Steinauer JE, Waetjen LE, Vittinghoff E, . Postmenopausal hormone therapy: does it cause incontinence? Obstet Gynecol. 2005 Nov;106(5 suppl 1):940–5. doi: 10.1097/01.AOG.0000180394.08406.15. PMID: 16260510.16260510
153 Cushman M, Kuller LH, Prentice R, . Estrogen plus progestin and risk of venous thrombosis. JAMA. 2004 Oct 6;292(13):1573–80. doi: 10.1001/jama.292.13.1573. PMID: 15467059.15467059
154 Schierbeck LL, Rejnmark L, Tofteng CL, . Effect of hormone replacement therapy on cardiovascular events in recently postmenopausal women: randomised trial. BMJ. 2012;345:e6409. doi: 10.1136/bmj.e6409. PMID: 23048011.23048011
155 Beral V, Gaitskell K, Hermon C, . Menopausal hormone use and ovarian cancer risk: individual participant meta-analysis of 52 epidemiological studies. Lancet. 2015 May 9;385(9980):1835–42. doi: 10.1016/S0140-6736(14)61687-1. PMID: 25684585.25684585
156 American Academy of Family Physicians. Hormone replacement therapy: Clinical Preventive Service recommendation. Leawood, KS: American Academy of Family Physicians; 2018. https://www.aafp.org/afp/2018/0415/od1.html. Accessed December 8, 2020.
157 American College of Obstetricians and Gynecologists (ACOG). Hormone therapy and heart disease. Number 565 (Replaces No. 420, November 2008). Washington, DC: ACOG; 2020. https://www.acog.org/en/Clinical/Clinical%20Guidance/Committee%20Opinion/Articles/2013/06/Hormone%20Therapy%20and%20Heart%20Disease. Accessed December 8, 2020.
158 American Family Physician. ACOG releases practice bulletin on osteoporosis. Am Fam Physician. 2013 August 15;88(4):269–75.23944732
159 Mosca L, Benjamin EJ, Berra K, . Effectiveness-based guidelines for the prevention of cardiovascular disease in women - 2011 update: a guideline from the American Heart Association. Circulation. 2011;123(11):1243–62. PMID: 21325087.21325087
160 Bushnell C, McCullough LD, Awad IA, . Guidelines for the prevention of stroke in women: a statement for healthcare professionals from the American Heart Association/American Stroke Association. Stroke. 2014 May;45(5):1545–88. doi: 10.1161/01.str.0000442009.06663.48. PMID: 24503673.24503673
161 American Association of Clinical Endocrinologists. AACE/ACE position statement on menopause© 2017. Jacksonville, FL: American Association of Clinical Endocrinologists; n.d. https://pro.aace.com/disease-state-resources/reproductive-and-gonad/position-and-consensus-statements/aaceace-position-0. Accessed December 15, 2020.
162 Goodman NF, Cobin RH, Ginzburg SB, . American Association of Clinical Endocrinologists medical guidelines for clinical practice for the diagnosis and treatment of menopause. Endocr Pract. 2011 Nov–Dec;17 Suppl 6:1–25. PMID: 22193047.22193047
163 American College of Physicians. ACP clinical practice guidelines. Philadelphia: American College of Physicians; 2015. http://www.acponline.org/clinical_information/guidelines/guidelines/. Accessed April 13, 2015.
164 Qaseem A, Forciea MA, McLean RM, . Treatment of low bone density or osteoporosis to prevent fractures in men and women: a clinical practice guideline update from the American College of Physicians. Ann Intern Med. 2017 Jun 6;166(11):818–39. doi: 10.7326/m15-1361. PMID: 28492856.28492856
165 Hill DA, Hill SR. Counseling patients about hormone therapy and alternatives for menopausal symptoms. Am Fam Physician. 2010 Oct 1;82(7):801–7. PMID: 20879703.20879703
166 Reid R, Abramson BL, Blake J, . Managing menopause. J Obstet Gynaecol Can. 2014 Sep;36(9):830–3. doi: 10.1016/s1701-2163(15)30487-4. PMID: 25222364.25222364
167 Grady D, Applegate W, Bush T, . Heart and Estrogen/progestin Replacement Study (HERS): design, methods, and baseline characteristics. Control Clin Trials. 1998 Aug;19(4):314–35. doi: 10.1016/s0197-2456(98)00010-5. PMID: 9683309.9683309
168 Hulley S, Grady D, Bush T, . Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. Heart and Estrogen/progestin Replacement Study (HERS) Research Group. JAMA. 1998 Aug;280(7):605–13. doi: 10.1001/jama.280.7.605. PMID: 9718051.9718051
169 Ettinger B, Ensrud KE, Wallace R, . Effects of ultralow-dose transdermal estradiol on bone mineral density: a randomized clinical trial. Obstet Gynecol. 2004 Sep;104(3):443–51. doi: 10.1097/01.AOG.0000137833.43248.79. PMID: 15339752.15339752
170 Brunner RL, Gass M, Aragaki A, . Effects of conjugated equine estrogen on health-related quality of life in postmenopausal women with hysterectomy: results from the Women’s Health Initiative Randomized Clinical Trial. Arch Intern Med. 2005 Sep 26;165(17):1976–86. doi: 10.1001/archinte.165.17.1976. PMID: 16186467.16186467
171 Canonico M, Plu-Bureau G, O’Sullivan MJ, . Age at menopause, reproductive history, and venous thromboembolism risk among postmenopausal women: the Women’s Health Initiative Hormone Therapy clinical trials. Menopause. 2014 Mar;21(3):214–20. doi: 10.1097/GME.0b013e31829752e0. PMID: 23760439.23760439
172 Hays J, Ockene JK, Brunner RL, . Effects of estrogen plus progestin on health-related quality of life. N Engl J Med. 2003 May 8;348(19):1839–54. doi: 10.1056/NEJMoa030311. PMID: 12642637.12642637
173 Hendrix SL. The Women’s Health Initiative estrogen plus progestin trial: the study and how it changes our practice. J Am Osteopath Assoc. 2003 Feb;103(2 suppl 2):S3–S5. PMID: 12625631.12625631
174 Manson JE, Hsia J, Johnson KC, . Estrogen plus progestin and the risk of coronary heart disease. N Engl J Med. 2003 Aug 7;349(6):523–34. doi: 10.1056/NEJMoa030808. PMID: 12904517.12904517
175 Tang JY, Spaunhurst KM, Chlebowski RT, . Menopausal hormone therapy and risks of melanoma and nonmelanoma skin cancers: Women’s Health Initiative randomized trials. J Natl Cancer Inst. 2011 Oct 5;103(19):1469–75. doi: 10.1093/jnci/djr333. PMID: 21878677.21878677
176 Toh S, Hernandez-Diaz S, Logan R, . Coronary heart disease in postmenopausal recipients of estrogen plus progestin therapy: does the increased risk ever disappear? a randomized trial. Ann Intern Med. 2010 Feb 16;152(4):211–7. doi: 10.7326/0003-4819-152-4-201002160-00005. PMID: 20157135.20157135
177 Culhane NS. Estrogen plus progestin may increase incidence of dementia. J Fam Pract. 2003 Oct;52(10):754–5. PMID: 14529594.14529594
178 LaCroix AZ, Joffe H, Cohen LS, . The MsFLASH research network: Latest findings. Menopause. 2013;20(12):1315.
179 Rimoin LP, Kwatra SG, Yosipovitch G. Female-specific pruritus from childhood to postmenopause: clinical features, hormonal factors, and treatment considerations. Dermatol Ther. 2013 Mar–Apr;26(2):157–67. doi: 10.1111/dth.12034. PMID: 23551372.23551372
180 Chlebowski RT, Anderson GL. Menopausal hormone therapy and cancer: changing clinical observations of target site specificity. Steroids. 2014 Nov;90:53–9. doi: 10.1016/j.steroids.2014.06.001. PMID: 24910928.24910928
181 Symer MM, Wong NZ, Abelson JS, . Hormone replacement therapy and colorectal cancer incidence and mortality in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. Clin Colorectal Cancer. 2018 Jun;17(2):e281–e8. doi: 10.1016/j.clcc.2018.01.003. PMID: 29398422.29398422
182 Shufelt C, Bairey Merz CN, Pettinger MB, . Estrogen-alone therapy and invasive breast cancer incidence by dose, formulation, and route of delivery: findings from the WHI observational study. Menopause. 2018 Sep;25(9):985–91. doi: 10.1097/gme.0000000000001115. PMID: 29738414.29738414
183 Crandall CJ, Hovey KM, Andrews C, . Comparison of clinical outcomes among users of oral and transdermal estrogen therapy in the Women’s Health Initiative Observational Study. Menopause. 2017 Oct;24(10):1145–53. doi: 10.1097/gme.0000000000000899. PMID: 28697036.28697036
184 Shah SA, Tibble H, Pillinger R, . Hormone replacement therapy and asthma onset in menopausal women: national cohort study. J Allergy Clin Immunol. 2020 Dec 3doi: 10.1016/j.jaci.2020.11.024. PMID: 33279576.33279576
185 Jalava-Broman J, Mäkinen J, Sillanmäki L, . Characteristics associated with initiation of hormone replacement therapy among Finnish women: A register-linkage study. Maturitas. 2016 Jul;89:73–8. doi: 10.1016/j.maturitas.2016.04.011. PMID: 27180163.27180163