# Acknowledgments

The authors acknowledge the following individuals for their contributions to this project and appreciate their considerable support, commitment, and contributions: Howard Tracer, MD, AHRQ Medical Officer; current and former members of the U.S. Preventive Services Task Force; expert reviewers Cynthia Farquhar, MD, MPH, The University of Auckland; JoAnn Manson, MD, MPH, Brigham and Women’s Hospital; Susan Reed, MD, MPH, University of Washington School of Medicine; and Raja Sayegh, MD, Boston University School of Medicine; federal partner reviewers from the Centers for Disease Control and Prevention and National Institutes of Health; Carol Woodell, BSPH, EPC Program Manager; Megan Van Noord, MSIS, librarian; Sharon Barrell, MA, editor; and Loraine Monroe and Teyonna Downing, publications specialists.