# Chapter 4 Discussion

This chapter begins with a summary of review findings for each KQ regarding the use of hormone therapy for primary prevention of chronic disease. Following those sections, we present limitations of the evidence and the review and end with conclusions.

## Summary of Review Findings

### Benefits and Harms of Hormone Therapy (KQs 1 and 2)

Twenty trials and three observational studies (reported in 85 publications) comparing the effects of estrogen only or estrogen plus progestogen with placebo for preventing chronic conditions in persons experiencing menopause met our eligibility criteria. Tables 7 and 8 summarize findings, SOE, and applicability for various outcomes for both KQs 1 and 2. From the previous review, the SOE grade for probable dementia was changed to low in light of the low number of outcomes (<100) and lack of additional evidence identified in the update compared to other outcomes. The SOE grade for all-cause mortality was changed to high because a calculation of an absolute risk difference indicated a precise estimate.

Table 7 Summary of Evidence: Estrogen-Only Trials

No. of Studies/Study Designs; No. of Participants | Summary of Findings by Outcome | Consistency and Precision | Limitations | Strength of Evidence^*^ | Applicability
4 RCTs;^32,^ ^37,^ ^67,^ ^87,^ ^88,^ ^108–110,^ ^112,^ ^113^ during the intervention phase, 239 events in 10,739 women contributed to effect estimate (based on 1 RCT^67^); During cumulative followup, number of events that contributed to effect estimate NR (based on 1 RCT^88^) | Invasive breast cancer; Intervention followup of 7.2 years Nonsignificant lower risk with HT (HR, 0.79 [95% CI, 0.61 to 1.02]); During cumulative followup of 20.7 years, statistically significantly lower risk with HT (HR, 0.78 [95% CI, 0.65 to 0.93]) | Consistent; imprecise | Fair quality; 3 studies followed participants for a relatively short duration; (2–3 years) | Moderate for benefit | Generally healthy postmenopausal women age ≥50 years
1 RCT;^88^ during cumulative followup, 63 events in 10,739 women contributed to effect estimate (based on 1 RCT)^88^; During cumulative followup, 63 events in 10,739 women contributed to effect estimate | Breast cancer mortality; Intervention followup of 7.2 years, similar risk (HR, 0.45 [95% CI, 0.14 to 1.46]); Significantly lower risk with HT during cumulative followup of 17.7 years (HR, 0.55 [95% CI, 0.33 to 0.92]) and 20.7 years (HR, 0.60 [95% CI, 0.37 to 0.97]) | NA; imprecise | Fair quality; evidence is limited to a single study | Low for benefit | Generally healthy postmenopausal women age ≥50 years
1 RCT;^67,^ ^91,^ ^114^ during intervention period, 123 events in 10,739 women contributed to effect estimate; During cumulative followup, 123 events in 9,786 women contributed to effect estimate | Colorectal cancer; Intervention followup of 7.2 years, no significant risk increase/reduction with HT (HR, 1.15 [95% CI, 0.81 to 1.64]); During cumulative followup (13.0 years), similarly, no significant risk increase/reduction with HT (HR, 1.13 [95% CI, 0.85 to 1.51]) | NA; imprecise | Fair quality; none | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^88^ during intervention period, 33 events in 10,739 women contributed to effect estimate; During cumulative followup, 87 events in 10,739 women contributed to effect estimate | Colorectal cancer mortality; No significant risk increase or reduction at followup of 7.2 years (HR, 0.98 [95% CI, 0.50 to 1.95]) or cumulative followup of 17.7 years (HR, 1.21 [95% CI, 0.79 to 1.84]) | NA; imprecise | Fair quality; estimates based on a single study | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^67,^ ^116^ during the intervention phase, 123 events in 10,739 women contributed to effect estimate; During cumulative followup, 223 events in 9,786 women contributed to effect estimate | Lung cancer; Intervention followup of 7.2 years, no significant risk increase/reduction with HT (HR, 1.05 [95% CI, 0.74 to 1.49]); During cumulative followup (13.0 years), no significant risk increase/reduction with HT (HR, 0.98 [95% CI, 0.75 to 1.27]) | NA; imprecise | Fair quality; none | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^116^ during intervention period, 67 events in 10,379 women contributed to effect estimate | Lung cancer mortality; Intervention followup of 7.9 years, no significant risk increase with HT (HR, 1.07 [95% CI, 0.66 to 1.72]) | NA; imprecise | Fair quality; estimates based on a single study; short duration followup for a mortality outcome | Insufficient | Generally healthy postmenopausal women age ≥50 years
1 RCT;^96^ 160 events in 10,685 women contributed to effect estimate | Non-Hodgkin’s lymphoma; Cumulative followup of 12.9 years, no significant risk increase/reduction with HT (HR, 1.02 [95% CI, 0.74 to 1.39]) | NA; imprecise | Fair quality; none | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^88^ during cumulative followup, 863 events in 10,739 women contributed to effect estimate; During cumulative followup, 863 events in 10,739 women contributed to effect estimate | Total cancer mortality; Intervention followup of 7.2 years, no significant risk reduction/increase with HT (HR, 0.96 [95% CI, 0.75 to 1.22]); Cumulative followup of 17.7 years, no significant risk reduction/increase with HT (HR, 0.99 [95% CI, 0.86 to 1.13]) | NA; imprecise | Fair quality; evidence is limited to a single study | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
4 RCTs;^32,^ ^112,^ ^113,^ ^117^; 422 events in 11,310 women contributed to meta-analysis (based on 3 RCTs^32,^ ^112,^ ^117^); During cumulative followup, 1,071 events in 7,645 women contributed to effect estimate (based on 1 RCT^101^) | Coronary heart disease; Intervention followup of 2 to 7.2 years in meta-analysis, no significant risk reduction/increase with HT (RR, 0.95 [95% CI, 0.79 to 1.14]); Cumulative followup of 19.4 years, no significant risk reduction/increase with HT (HR, 0.97 [95% CI, 0.86 to 1.09]) | Consistent; precise | Fair quality; none | High for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^88^ 517 events in 10,739 women contributed to effect estimate; During cumulative followup, 517 events in 7,645 women contributed to effect estimate | Coronary heart disease mortality; Intervention followup of 7.2 years, no significant risk reduction/increase with HT (HR, 1.02 [95% CI, 0.72 to 1.43]); Cumulative followup of 17.7 years, no significant risk reduction/increase with HT (HR, 0.89 [95% CI, 0.75 to 1.05]) | NA; precise | Fair quality; evidence is limited to a single study | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^79^; 144 events in 10,739 women contributed to effect estimate | Peripheral arterial disease; Intervention followup of 7.1 years, no significant risk reduction/increase with HT (HR, 1.35 [95% CI, 0.97 to 1.88]) | NA; imprecise | Fair quality; evidence is limited to a single study | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^119,^ ^121^; During the intervention phase, 47 events in 2,947 women contributed to effect estimate | Probable dementia; Intervention followup of 5.2 years, no significant risk increase/reduction with HT (HR, 1.49 [95% CI, 0.83 to 2.66]) | NA; imprecise | Fair quality; none | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT^88^; During intervention period, 11 events in 10,739 women contributed to effect estimate; During cumulative followup, 302 events in 10,739 women contributed to effect estimate | Alzheimer’s disease or other dementia mortality; Intervention followup of 7.2 years, no significant risk increase/reduction with HT (HR, 0.90 [95% CI, 0.27 to 2.95]); Cumulative followup of 17.7 years, significantly lower risk with HT (HR, 0.74 [95% CI, 0.59 to 0.94]) | NA; imprecise for intervention phase, precise for cumulative phase | Fair quality; few events and short-term followup for mortality outcome (intervention phase only) | Low for benefit | Generally healthy postmenopausal women age ≥50 years
1 RCT;^67,^ ^125^; During the intervention phase, 976 events in 9,917 women contributed to effect estimate; During cumulative followup, 1,605 events in 9,917 women contributed to effect estimate | Diabetes; Intervention followup of 7.1 years, risk reduction with HT (HR, 0.86 [95% CI, 0.76 to 0.98]); Cumulative followup of 13.0 years, no significant risk increase/reduction with HT (HR, 0.94 [95% CI, 0.85 to 1.04]) | NA; precise | Fair quality; diabetes is self-reported | Moderate for benefit | Generally healthy postmenopausal women age ≥50 years
2 RCTs;^67,^ ^97,^ ^108,^ ^113,^ ^126^; During the intervention phase, 1,311 events in 10,739 women contributed to effect estimate (based on 1 RCT^67^); During postintervention followup, 699 events in 5,053 women contributed to effect estimate (based on 1 RCT^97^) | Fractures; Intervention followup of 7.2 years, significant risk reduction with HT (HR, 0.72 [95% CI, 0.64 to 0.80]); Postintervention followup of 4.3 years, significant risk reduction with HT (HR, 0.85 [95% CI, 0.73 to 0.98]) | Consistent; precise | Fair quality; none | High for benefit | Generally healthy postmenopausal women age ≥50 years
2 RCTs;^32,^ ^67^; 773 events in 8,376 women contributed to effect estimate (based on 1 RCT^67^) | Gallbladder disease; Intervention followup of 7.1 years, significant risk increase with HT (HR, 1.55 [95% CI, 1.34 to 1.79]) | Consistent; precise | Fair quality; gallbladder disease is self-reported | Moderate for harm | Generally healthy postmenopausal women age ≥50 years
3 RCTs;^108,^ ^112,^ ^113^; 298 events in 10,739 women contributed to effect estimate (based on 1 RCT^67^); During cumulative followup 791 events in 10,739 women contributed to effect estimate (based on 1 RCT^101^) | Stroke; Intervention followup of 7.2 years, significant increase with HT (HR, 1.35 [95% CI, 1.07 to 1.70]); Cumulative followup of 19.4 years, no significant risk reduction/increase with HT (HR, 1.06 [95% CI, 0.92 to 1.22]) | Consistent; precise | Fair quality; 3 studies followed participants for a relatively short duration (2–3 years) | Moderate for harm | Generally healthy postmenopausal women age ≥50 years
1 RCT;^88^; 258 events in 10,739 women contributed to effect estimate; During cumulative followup, 258 events in 10,739 women contributed to effect estimate | Stroke mortality ^88^; Intervention followup of 7.2 years, no significant risk reduction/increase with HT (HR, 1.00 [95% CI, 0.57 to 1.78]); Cumulative followup of 17.7 years, no significant risk reduction/increase with HT (HR, 0.98 [95% CI, 0.77 to 1.26]) | NA; imprecise | Fair quality; evidence is limited to a single study | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
2 RCTs;^67,^ ^129^; 1,272 events in 6,767 women contributed to effect size (based on 1 RCT^67^); During postintervention followup, 1,456 events in 5,644 women contributed to effect estimate (based on 1 RCT^67^) | Urinary incontinence; Intervention followup of 1 year, significant risk increase with HT (HR, 1.61 [95% CI, 1.46 to 1.79]); Postintervention followup of 6.6 years, significant risk increase with HT (HR, 1.24 [95% CI, 1.13 to 1.35]) | Consistent; precise | Fair quality; urinary incontinence is self-reported | Moderate for harm | Generally healthy postmenopausal women age ≥50 years
2 RCTs;^108,^ ^112^; 144 (DVT) and 91 (PE) events in 10,739 women contributed to effect estimates (based on 1 RCT^67^); During cumulative followup, 471 events in 9,939 women contributed to effect estimates (based on 1 RCT^67^) | Venous thromboembolism; Intervention followup of 7.1 years, significant increased risk of DVT with HT (HR, 1.48 [95% CI, 1.06 to 2.07]) and no significant risk reduction/increase with HT in PE (HR, 1.35 [95% CI, 0.89 to 2.05]); Cumulative followup of 13.0 years, no significant risk reduction/increase with HT in DVT (HR, 1.05 [95% CI, 0.82 to 1.33]) or PE (HR, 1.15 [95% CI, 0.87 to 1.51]) | Consistent; imprecise | Fair quality; none | Moderate for harm | Generally healthy postmenopausal women age ≥50 years
1 RCT^67^; observed in 10,739 women | Quality of life; Intervention followup of 7.1 years, similar scores on most items of the SF-36 | Inconsistent regarding subscales; precise | Fair quality; none | Moderate for similar risks | Generally healthy postmenopausal women age ≥50 years
3 RCTs;^92,^ ^108,^ ^113^; 613 events in 11,587 women contributed to meta-analysis | All-cause mortality; Intervention followup of 2 to 7.2 years in meta-analysis, no significant risk increase/reduction with HT (RR, 1.04 [95% CI, 0.89 to 1.21]) | Consistent; precise | Fair quality; none | High for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^101^; 613 events in 10,739 women contributed to effect estimate | All-cause mortality; Cumulative followup of 19.4 years, no significant risk reduction/increase with HT (HR, 0.97 [95% CI, 0.91 to 1.03]) | NA; precise | Fair quality; evidence is limited to a single study | High for similar risks | Generally healthy postmenopausal women age ≥50 years

* Strength of evidence ratings refer to the intervention phase except for mortality, for which they refer to cumulative followup.

Abbreviations: CI=confidence interval; DVT=deep vein thrombosis; HR=hazard ratio; HT=hormonal therapy; KQ=key question; NA=not applicable; No.=number; NR=not reported; PE=pulmonary embolism; RCT=randomized, controlled trial; RR=relative risk; SF-36=36-Item Short-Form Survey.

Table 8 Summary of Evidence: Estrogen Plus Progestin Trials

No. of studies/study designs; No. of participants | Summary of Findings by Outcome | Consistency and Precision | Limitations | Strength of Evidence^*^ | Applicability
6 RCTs;^32,^ ^36,^ ^67,^ ^87,^ ^88,^ ^110,^ ^132–138,^ ^143^ ^113^ during the intervention phase 420 events in 25,442 women contributed to effect estimates (based on 2 RCTs^67,^ ^136^); During cumulative followup, 1,006 events in 16,608 women contributed to effect estimate (based on 1 RCT^101^) | Invasive breast cancer; Intervention followup of 4.1–5.6 years, significant risk increase with HT (HR, 1.24 [95% CI, 1.01 to 1.53]) in WHI and nonsignificant increase with HT in HERS I (HR, 1.38 [95% CI, 0.82 to 2.31]); During cumulative followup, the risk remained significantly increased at 19.4 years (HR, 1.28 [95% CI, 1.13 to 1.45]) | Consistent; precise | Fair; none | High for harm | Generally healthy postmenopausal women age ≥50 years
1 RCT;^87^ during intervention period, 9 events in 16,608 women contributed to effect estimate; During cumulative followup, 124 events in 16,608 women contributed to effect estimate | Breast cancer mortality; Intervention followup of 5.6 years, similar risk (HR, 1.08 [95% CI, 0.29 to 4.03]), no significant risk increase/reduction with HT during cumulative followup at 20.3 years (HR, 1.35 [95% CI, 0.94 to 1.95]) | NA; imprecise | Fair; none | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^126^ 13 events in 16,608 women contributed to effect estimate | Cervical cancer; Intervention followup of 5.6 years, no significant risk increase/reduction with HT (HR, 1.44 [95% CI, 0.47 to 4.42]) | NA; imprecise | Fair; 1 study followed participants for a relatively short duration (5.6 years) to evaluate a rare cancer outcome | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
4 RCTs;^36,^ ^67,^ ^91,^ ^110,^ ^132,^ ^136,^ ^138,^ ^140,^ ^141^ during the intervention period, 152 events in 19,371 women contributed to effect estimates (based on 2 RCTs^67,^ ^136^); During cumulative followup, number of events that contributed to effect estimate NR; based on 2 RCTs^67,^ ^136^ | Colorectal cancer; Intervention followup of 4.1 to 5.6 years, significant risk reduction with HT (HR, 0.62 [95% CI, 0.43 to 0.89]) in the WHI and nonsignificant risk reduction with HT (HR, 0.69 [95% CI, 0.32 to 1.49]) in HERS; During cumulative followup, nonsignificant risk increase in WHI (13.0 years followup, HR, 1.13 [95% CI, 0.85 to 1.51]) and nonsignificant decreased risk in HERS (6.8 years followup, HR, 0.82 [95% CI, 0.46 to 1.47]) | Consistent; precise | Fair; long-term evidence is limited to the WHI | Moderate (https://researchtriangleinstitute.sharepoint.com/sites/HormoneTherapyReview/Shared%20Documents/General/i.%20Draft%20Report/_HT%20Report%20Section%20Tracker.xlsx?web=1) for benefit | Generally healthy postmenopausal women age ≥50 years
1 RCT;^88^ during intervention period, 22 events in 16,608 women contributed to effect estimate; During cumulative followup, 103 events in 16,608 women contributed to effect estimate | Colorectal cancer mortality; Intervention followup 5.6 years, no significant differences (HR, 0.87 [95% CI, 0.38 to 1.98]) or cumulative followup 17.7 years (HR, 1.01 [95% CI, 0.69 to 1.49]) | NA; imprecise | Fair; estimates based on a single study | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
4 RCTs;^32,^ ^36,^ ^67,^ ^110,^ ^113,^ ^116,^ ^126,^ ^132,^ ^136^ 64 events in 19,371 women contributed to effect estimates (based on 2 RCTs^36,^ ^67,^ ^110,^ ^116,^ ^126,^ ^132,^ ^136^); 1 retrospective cohort study^179^ with 4,379 events in more than 900,000 women | Endometrial cancer; Intervention followup of 4.1 to 5.6 years, no significant risk increase/reduction with HT (HR, 0.83 [95% CI, 0.49 to 1.40]) in the WHI and (HR, 0.39 [95% CI, 0.08 to 2.02]) in HERS; Statistically significant risk reduction with HT after 13.2 years of followup in the WHI (HR, 0.65 [95% CI, 0.48 to 0.89]) | Consistent; imprecise | Fair; long-term evidence is limited to the WHI and a retrospective cohort study; because endometrial cancer is rare, overall few events in RCTs (n = 161 after 13.2 years followup) | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
3 RCTs;^67,^ ^136,^ ^141,^ ^142,^ ^98^ during intervention period, 191 events in 19,371 women contributed to effect estimates (based on 2 RCTs^67,^ ^136,^ ^142^); During cumulative followup, 433 events in 15,327 women contributed to effect estimates (based on 2 RCTs^67,^ ^136^) | Lung cancer; Intervention followup of 4.1 to 5.6 years, no significant risk increase/reduction with HT (HR, 1.05 [95% CI, 0.76 to 1.45]) in the WHI and (HR, 1.28 [95% CI, 0.70 to 2.33]) in HERS; During cumulative followup, no significant risk increase with HT in WHI (13.2 years followup, HR, 1.10 [95% CI, 0.89 to 1.35]) and HERS (6.8 years followup, HR, 1.43 [95% CI, 0.87 to 2.37]) | Consistent; precise | Fair; long-term evidence is limited to the WHI | Moderate for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^180^ for cumulative followup, 285 events in 16,608 women contributed to effect estimate | Lung cancer mortality; Followup of 14.0 years, no significant risk increase with HT in WHI (HR, 1.09 [95% CI, 0.87 to 1.38]) | NA; imprecise | Fair; estimates based on a single study | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^96^ 223 events in 16,544 women contributed to effect estimate | Non-Hodgkin’s lymphoma; Cumulative followup of 13.5 years, no significant risk increase/reduction with HT (HR, 0.98 [95% CI, 0.76 to 1.28]) | NA; imprecise | Fair; none | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^67,^ ^126^ 40 events in 16,608 women contributed to effect estimate | Ovarian cancer; Intervention followup of 5.6 years, no significant risk increase/reduction with HT (HR, 1.41 [95% CI, 0.75 to 2.66]) | NA; imprecise | Fair; study followed participants for a relatively short duration (5.6 years) to evaluate a rare cancer outcome | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^88^ during intervention followup, 244 events in 16,608 women contributed to effect estimate; During cumulative followup, 1,344 events in 16,608 women contributed to effect estimate | Total cancer mortality; Intervention followup of 5.6 years, no significant risk reduction/increase with HT (HR, 1.10 [95% CI, 0.86 to 1.42]); Cumulative followup of 17.7 years, no significant risk reduction/increase with HT (HR, 1.06 [95% CI, 0.95 to 1.18]) | NA; precise | Fair; evidence is limited to a single study | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
6 RCTs;^32,^ ^67,^ ^113,^ ^137,^ ^138,^ ^141^ during intervention period, 487 events in 18,085 women contributed to meta-analysis (based on 3 RCTs^32,^ ^67,^ ^98,^ ^137^); During cumulative followup, 1,362 events in 15,730 women contributed to effect estimate (based on 1 RCT^101^) | Coronary heart disease; Intervention followup of 2 to 5.6 years in meta-analysis, no significant risk reduction/increase with HT (RR, 1.12 [95% CI, 0.94 to 1.33]); Cumulative followup of 19.4 years, no significant risk reduction/increase with HT (HR, 1.05 [95% CI, 0.95 to 1.17]) | Consistent; precise | Fair; none | High for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^88^ during intervention period, 80 events in 16,608 women contributed to effect estimate; During cumulative followup, 595 events in 16,608 women contributed to effect estimate | Coronary heart disease mortality; Intervention followup of 5.6 years, no significant risk reduction/increase with HT (HR, 0.94 [95% CI, 0.60 to 1.45]); Cumulative followup of 17.7 years, no significant risk reduction/increase with HT (HR, 1.05 [95% CI, 0.89 to 1.23]) | NA; precise | Fair; evidence is limited to a single study | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT,^80^; 98 events in 16,608 women contributed to effect estimate | Peripheral arterial disease; Intervention followup of 5.6 years, no significant risk reduction/increase with HT (HR, 0.89 [95% CI, 0.60 to 1.32]) | NA; imprecise | Fair quality; evidence is limited to a single study | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^143^ 61 events in 4,532 women contributed to effect estimate | Probable dementia; Intervention followup of 4 years, significant risk increase with HT (HR, 2.05 [95% CI, 1.21 to 3.48]) | NA; imprecise | Fair; none | Low for harm | Generally healthy postmenopausal women age ≥50 years
1 RCT;^88^ during intervention period, 0 events in 16,608 women contributed to effect estimate; During cumulative followup, 456 events in 16,608 women contributed to effect estimate | Alzheimer’s disease or other dementia mortality; No events during intervention followup of 5.6 years; Cumulative followup of 17.7 years, no significant risk increase/reduction with HT (HR, 0.93 [95% CI, 0.77 to 1.11]) | NA; imprecise | Fair; evidence based on a single study | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
2 RCTs;^67,^ ^148,^ ^149^ during intervention followup, 861 events in 17,903 women contributed to effect estimates; During cumulative followup, 1,786 events in 15,874 women contributed to effect estimate (based on 1 RCT^67^) | Diabetes; Intervention followup of 4.1 to 5.6 years, significant risk reduction with HT in WHI (HR, 0.81 [95% CI, 0.70 to 0.94]) and HERS (HR, 0.65 [95% CI, 0.48 to 0.89]); Cumulative followup of 13.2 years, no significant risk increase/reduction with HT in WHI (HR, 1.02 [95% CI, 0.93 to 1.12]) | Consistent; precise | Fair; diabetes is self-reported | Moderate for benefit | Generally healthy postmenopausal women age ≥50 years
5 RCTs;^36,^ ^67,^ ^113,^ ^132,^ ^136,^ ^137,^ ^141,^ ^150^ during intervention period, 2,004 events in 20,499 women contributed to meta-analysis; During postintervention followup, 1,184 events in 10,134 women contributed to effect estimate (based on 1 RCT^97^) | Fractures; Intervention followup of 2 to 5.6 years, significant risk reduction with HT (RR, 0.79 [95% CI, 0.66 to 0.94]); Postintervention followup of 4.2 years, no significant risk increase/reduction with HT (HR, 0.97 [95% CI, 0.87 to 1.09]) | Consistent; precise | Fair; none | High for benefit | Generally healthy postmenopausal women age ≥50 years
2 RCTs;^32,^ ^67^ 847 events in 14,203 women contributed to effect estimate (based on 1 RCT^67^) | Gallbladder disease; Intervention followup of 5.6 years, significant risk increase with HT (HR, 1.57 [95% CI, 1.36 to 1.80]) | Consistent; precise | Fair; gallbladder disease is self-reported | Moderate for harm | Generally healthy postmenopausal women age ≥50 years
3 RCTs;^67,^ ^137,^ ^141^ during intervention period, 270 events in 17,385 women contributed to effect estimates (based on 2 RCTs^67,^ ^137^); During cumulative followup, 1,071 events in 16,608 women contributed to effect estimate (based on 1 RCT^101^) | Stroke; Intervention followup, significant increase with HT after 5.6 years in WHI (HR, 1.37 [95% CI, 1.07 to 1.76]) and no significant risk reduction/increase with HT after 3.4 years in EPHT (HR, 1.06 [95% CI, 0.07 to 17.2]); Cumulative followup of 19.4 years, increased risk with HT (HR, 1.13 [95% CI, 1.00 to 1.27]) | Consistent; precise | Fair; outcome measures heterogeneous (stroke incidence vs. composite risk of various cerebrovascular events) | Moderate for harm | Generally healthy postmenopausal women age ≥50 years
1 RCT;^88^ during intervention period, 43 events in 16,608 women contributed to the effect estimate; During cumulative followup, 349 events in 16,608 women contributed to effect estimate (based on 1 RCT^101^) | Stroke mortality; Intervention followup of 5.6 years, no significant risk reduction/increase with HT (HR, 1.58 [95% CI, 0.85 to 2.94]); Cumulative followup of 17.7 years, no significant risk reduction/increase with HT (HR, 1.12 [95% CI, 0.91 to 1.38]) | NA; imprecise | Fair; evidence is limited to a single study | Low for similar risks | Generally healthy postmenopausal women age ≥50 years
2 RCTs;^67,^ ^152^ during the intervention period, 2,346 events in 12,786 women contributed to effect estimates; During postintervention followup, 2,211 events in 10,073 women contributed to the effect estimate (based on 1 RCT^67^) | Urinary incontinence; Intervention followup of 1 to 4.2 years, significant risk increase with HT in WHI (HR, 1.49 [95% CI, 1.36 to 1.63]) and HERS (OR, 1.60 [95% CI, 1.30 to 1.90]); Postintervention followup of 8.2 years, significant risk increase with HT in WHI (HR, 1.16 [95% CI, 1.08 to 1.25]) | Consistent; precise | Fair; urinary incontinence is self-reported | Moderate for harm | Generally healthy postmenopausal women age ≥50 years
5 RCTs;^113,^ ^136,^ ^137,^ ^141,^ ^153^ during intervention period, 216 DVT events and 143 PE events in 19,371 women contributed to effect estimates (based on 2 RCTs^67^); During cumulative followup, 674 events in 15,730 women contributed to effect estimate (based on 1 RCT^67^) | Venous thromboembolism; Intervention followup of 4.1–5.6 years, significant increased risk with HT in DVT in WHI (HR, 1.87 [95% CI, 1.37 to 2.54]) and in HERS (HR, 2.82 [95% CI, 1.32 to 6.04]); significant increased risk with HT in PE in WHI (HR, 1.98 [95% CI, 1.36 to 2.87]) but not in HERS (HR, 2.78 [95% CI, 0.89 to 8.74]); Cumulative followup of 13.2 years, significant increase with HT in DVT (HR, 1.24 [95% CI, 1.01 to 1.53]) or PE (HR, 1.26 [95% CI, 1.00 to 1.59]) in WHI | Consistent; precise | Fair; 3 studies followed participants for a relatively short duration (2–3 years) | Moderate for harm | Generally healthy postmenopausal women age ≥50 years
1 RCT;^67^ observed in 16,608 women | Quality of life; Intervention followup of 5.6 years, similar scores on most items of the SF-36 | Inconsistent regarding subscales; precise | Fair; none | Moderate for similar risks | Generally healthy postmenopausal women age ≥50 years
3 RCTs;^113,^ ^132,^ ^136^ 751 events in 19,580 women contributed to meta-analysis | All-cause mortality; Intervention followup of 3.2 to 5.6 years in meta-analysis, no significant risk increase/reduction with HT (RR, 1.01 [95% CI, 0.88 to 1.16]) | Consistent; precise | Fair; none | High for similar risks | Generally healthy postmenopausal women age ≥50 years
1 RCT;^101^ 5,440 events in 16,608 women contributed to effect estimate | All-cause mortality; Cumulative followup of 19.4 years, no significant risk reduction/increase with HT (HR, 1.02 [95% CI, 0.97 to 1.08]) | NA; precise | Fair; evidence is limited to a single study | High for similar risks | Generally healthy postmenopausal women age ≥50 years

* Strength of evidence ratings refer to the intervention phase except for mortality, for which they refer to cumulative followup.

Abbreviations: CI=confidence interval; DVT=deep vein thrombosis; EPHT=Estonian Postmenopausal Hormone Therapy Trial; HERS=Heart and Estrogen/Progestin Replacement Study; HR=hazard ratio; HT=hormone therapy; KQ=key question; NA=not applicable; No.=number; NR=not reported; OR=odds ratio; PE=pulmonary embolism; RCT=randomized, controlled trial; RR=relative risk; SF-36=36-Item Short Form Survey; WHI=Women’s Health Initiative.

The WHI was the only trial designed and powered to evaluate the effectiveness of hormone therapy for the primary prevention of the multiple conditions that are the focus of this review. The WHI met criteria for fair quality, and it provided most of the estimates of benefits and harms. Including the posttrial phases, it had up to 20.4 years of followup to assess how risk of chronic conditions change after women stopped hormone therapy.

Results of our review indicate some benefits of hormone therapy regarding the prevention of chronic conditions (KQ 1). For women using estrogen only, risk of diabetes (134 fewer cases per 10,000 women over 7.1 years) and risk of fractures (388 fewer cases per 10,000 women over 7.2 years) were statistically significantly reduced compared with women taking placebo. The risk for invasive breast cancer was numerically reduced in women using estrogen only, but the difference compared with placebo did not reach statistical significance (HR, 0.79 [95% CI, 0.61 to 1.02]). Women using estrogen plus progestin therapy experienced statistically significantly reduced risk of colorectal cancer (34 fewer cases per 10,000 women over 5.6 years), diabetes (78 fewer cases per 10,000 women over 5.6 years), and fractures (230 fewer cases per 10,000 women over 2 to 5.6 years) compared with women in the placebo groups. Benefits of hormone therapy for colorectal cancer attenuated with extended followup and were no longer statistically significant.

Our review also documented several important harms of hormone therapy (KQ 2). Women taking estrogen-only therapy had a statistically significant increased risk of gallbladder disease (377 more cases per 10,000 women over 7.1 years), stroke (79 more cases per 10,000 women over 7.2 years), urinary incontinence (885 more cases per 10,000 women over 1.0 year), and venous thromboembolism (77 more cases per 10,000 women over 7.2 years) compared with women in the placebo groups.

Likewise, for women taking estrogen plus progestin therapy, risks of invasive breast cancer (51 more cases per 10,000 women over 5.6 years), probable dementia (88 more cases per 10,000 women over 4 years), gallbladder disease (260 more cases per 10,000 women over 5.6 years), stroke (52 more cases per 10,000 women over 5.6 years), urinary incontinence (562 more cases per 10,000 women over 1 year), and venous thromboembolism (120 more cases per 10,000 women over 5.6 years) were statistically significantly increased compared with women taking placebo. A Danish retrospective cohort study also reported an increased risk for endometrial cancer (RR, 1.71 [1.58 to 1.86] over 9.8 years).

Based on high- or moderate-strength evidence, the risks for coronary heart disease and all-cause mortality were similar between estrogen-only hormone therapy and placebo. Likewise, high- or moderate-strength evidence indicates similar risks for lung cancer and all-cause mortality between estrogen plus progestin hormone therapy and placebo.

The WHI used a global index based on beneficial and harmful events to assess the trade-off between advantages and disadvantages of hormone therapy. Overall, estrogen plus progestin led to 20 additional adverse events per 10,000 person-years at the end of the intervention phase (HR, 1.12 [95% CI, 1.02 to 1.24]).^67^ After 18 years of cumulative followup, no statistically significant differences between groups were still apparent.^91^

For women who were randomized to estrogen-only therapy, the global index did not show a statistically significant difference in overall beneficial or harmful events (HR, 1.03 [95% CI, 0.93 to 1.13]). Long-term followup also did not show any statistically significant differences between groups.^91^

### Information About Subgroups (KQ 3)

Subgroups (KQ 3) of interest for this report include the following characteristics: race/ethnicity; persons with premature menopause; persons with surgical menopause; age; duration of use; type, dose, and mode of delivery of hormone therapy; timing of the intervention; and presence of coexisting conditions.

Trials did not report results for most of these subgroups. Subgroup analyses of trial results based on these characteristics were restricted to race/ethnicity, age, oophorectomy status, and a limited number of comorbid conditions or risk factors. In general, tests of interactions did not detect any statistically significant subgroup effects that are of interest for this report. An exception is the influence of age on myocardial infarction, colorectal cancer, and all-cause mortality. Analyses that compared women ages 50 to 59, 60 to 69, and 70 to 79 years using estrogen-only therapy yielded a statistically significant trend for increasing risk by age for myocardial infarction (p=0.02 for trend), colorectal cancer (p=0.02 for trend), and all-cause mortality (p=0.04 for trend). The significant interaction of colorectal cancer and all-cause mortality with age was no longer present with extended followup of 13 to 18 years.

These findings, however, have to be interpreted cautiously. For example, 489 women died in the WHI estrogen-only trial, which could lead to chance findings when assessing differences in subgroups. In addition, many of the subgroup analyses were post hoc analyses. In its study protocol, the WHI specified only age, race/ethnicity, obesity, hysterectomy, and cardiovascular disease at baseline as subgroups of interest.

Recent subgroup analyses of the WHI regarding the effect of timing on risk of coronary events provide consistent findings. Time since menopause did not have a statistically significant effect on the risk of coronary heart disease in women using estrogen-only therapy. Women who initiated combination therapy within 10 years of menopause did not have an increased coronary risk compared with those who initiated later. Early initiation in this group, however, also did not lead to any beneficial effects regarding cardiovascular risk. It remains unclear whether a shorter time interval than 10 years might have been a more appropriate measure to assess the effect of timing. An additional subgroup analysis took hormone therapy use before enrollment into the WHI into consideration (e.g., about 40% of women in the estrogen-only trial used hormone therapy before enrollment) and also found no difference in coronary risk between early and late initiation of hormone therapy. The onset of menopause in women who had undergone hysterectomy without oophorectomy, however, cannot always be determined with certainty. Results, therefore, have to be interpreted cautiously.

Two recent trials, KEEPS and ELITE,^46,^ ^53^ addressed whether timing of therapy initiation affected either benefits or harms of hormone therapy. Both trials enrolled women who were younger than participants in the WHI. Both trials assessed surrogate outcomes of cardiovascular disease (primary outcome in both trials was carotid artery intima-media thickness). They provided mixed results regarding beneficial effects of early initiation of hormone therapy on carotid artery intima-media thickness.

A Cochrane review assessed the timing hypothesis by stratifying trials in a meta-analysis according to when any hormone therapy treatment was started (the review did not stratify between estrogen-only and combination hormone therapy, which is a substantial limitation of this review).^29^ If this information was not available, the authors used the mean age of participants at baseline as a surrogate. Results provided some support of the timing hypothesis. All-cause mortality was lower in the subgroup of studies in which treatment was started within 10 years of menopause compared with studies in which more than 10 years had elapsed (p=0.01). Likewise, the risk of coronary heart disease was lower in women who initiated hormone therapy early (p=0.02). Nevertheless, because of issues of potential ecological fallacy, findings of such study-level analyses have to be viewed cautiously.

Another study that is sometimes viewed as supporting the timing hypothesis is the Danish Osteoporosis Prevention Study.^154^ We did not consider this study because of poor quality due to lack of blinding of outcomes assessors. The study included 1,006 women who, on average, were younger than those in the WHI; it reported that hormone therapy given to early postmenopausal women reduced the risk of cardiovascular disease without any significant increase in harms after 10 years of treatment and 16 years of cumulative followup. These findings would support the timing hypothesis, but they are limited by the small number of events and the precision of the estimates. For example, during 10 years of treatment, only 49 cardiovascular events took place.

To date, the evidence regarding the effect of dose and mode of delivery of hormone therapy on benefits and risks is still insufficient to draw firm conclusions. In treatment studies, progestins and natural progesterones differ in their metabolic action and risk of adverse effects on blood lipids, breast tenderness, and headaches. The risk-benefit profile of each type of progestin and progesterone for use in hormone therapy is currently still unclear.^29^ For this report, the PEPI trial was the only eligible study that used different types (regular synthetic and micronized progestins) and regimens of progestins (continuous and sequential progestin regimens) within the same study.^32^ Results reported no differences in benefits and harms between different types and regimens. The sample size of the PEPI trial (N=875) was too small to detect potential differences in outcomes that are of interest for this report. All the other studies included in this review used continuous progestin regimens. While observational studies suggest transdermal estrogen has a lower risk of venous thromboembolism compared with oral estrogen, there were no eligible trials of transdermal estrogen identified.

## Limitations and Future Research

In our analyses, we stratified results by regimen because findings from the WHI suggested that the risk-benefit profiles for estrogen-only and estrogen plus progestin therapy are different. As a consequence, we were not able to include four trials that did not report results stratified by treatment regimen in our analyses.^93,^ ^105–107^

The WHI provided the best and most applicable information for many of our outcomes of interest. During our review, we noticed that effect estimates were not always consistent across various publications. Because it was impossible for us to discern which were the most correct estimates, in general, we relied on articles that focused on specific outcomes (e.g., gallbladder disease, urinary incontinence), when available. Based on a communication with the WHI Researcher Help Desk (https://www.whi.org/helpdesk; July 2021), we relied on a publication by Manson et al.^67^ for results of patient-reported outcomes (i.e., diabetes, urinary incontinence, gallbladder disease). In general, differences in effect estimates affected the magnitude of risks and benefits but never the direction of effects. For each effect estimate that we present in the report, we provide the respective citation of the WHI publication.

Low event rates also limited conclusions for some outcomes in the report. For example, in the WHI estrogen plus progestin trial, 40 women developed ovarian cancer. Likewise, event rates for cervical and endometrial cancer were low, rendering wide CIs that encompassed clinically meaningful differences in risk. The confidence in conclusions about benefits and risks of hormone therapy regarding these outcomes is low.

A recent analysis of individual patient data from 52 epidemiological studies on more than 21,000 women with ovarian cancer detected a higher risk of ovarian cancer in women who used hormone therapy (RR, 1.37 [95% CI, 1.29 to 1.46]).^155^ The risk was similar between estrogen-only and estrogen plus progestin therapies. Even 10 years after stopping long-duration hormone therapy, the risk of serious and endometrioid ovarian tumors was still elevated (RR, 1.25 [95% CI, 1.07 to 1.46]).

Some outcomes that relied on self-reporting (e.g., diabetes and urinary incontinence) might be affected by potential biases or limited by disparate adherence rates (e.g., cognitive function) (WHIMS: 61.4% vs. 32.3% for placebo vs. estrogen plus progestin, respectively). Trials often used different measures for ascertaining outcomes, which limited comparisons across trials. For cognitive function, WHIMS was the only trial to use a thorough adjudication process for probable dementia and mild cognitive impairment, whereas other trials used batteries of cognitive tests. For diabetes, the WHI relied on participants’ self-reports of new diagnoses or new treatment for diabetes, whereas HERS used fasting glucose levels. For urinary incontinence, all trials relied on self-reported measures.

In addition, we did not find any evidence on functional capacity.

The main limitation of our review process was that we restricted inclusion criteria to trials published in English-language journals. However, we did not identify any relevant trials from English-language abstracts of non-English journals, additional citation searches, or expert reviewers. Given the large number of eligible trials for this report, the effect of potentially missed non-English publications on the overall effect estimates and conclusions is probably negligible.

Most trials had high attrition or low adherence to medications; this was true even for the WHI, in which 40 to 50 percent of participants discontinued their medications during the trial. Nevertheless, secondary analyses of the WHI limited to adherent women (i.e., censoring women within 6 months of reporting with <80% compliance with study pills) were generally similar to intention-to-treat results^67^ but with accentuated findings. For example, the adherence-adjusted HRs for breast cancer were 0.58 (95% CI, 0.39 to 0.84) for women taking estrogen-only therapy and 1.52 (95% CI, 1.15 to 2.00) for women taking estrogen plus progestin (compared with HR, 0.79 [95% CI, 0.61 to 1.02] and HR, 1.26 [95% CI, 1.02 to 1.55], respectively, in the intention-to-treat analyses).^67^

The applicability of our findings may be limited by three main aspects. First, the average age of women in the included studies ranged from 50 to 79 years, which is older than the average age of women experiencing menopause (51 years). For example, in the WHI, the average age of women was 64 years; approximately 30 percent of women in the WHI were ages 50 to 59 years at the time of enrollment, and 12.5 percent were ages 50 to 54, an age range when most women are likely to consider hormone therapy for the treatment of menopausal symptoms. Second, the majority of women (around 80%) were White. Subgroup analyses did not reveal differences in beneficial or harmful effects among racial/ethnic groups, but such analyses might have been underpowered. Third, the majority of findings came from the WHI, which tested only one dose, formulation, and route of administration of hormone therapy in each trial (0.625 mg/day of oral conjugated equine estrogen, with or without 2.5 mg/day of medroxyprogesterone). The PEPI trial was the only study that directly compared different formulations of estrogen and progestin combinations. To date, however, the evidence regarding the effect of different formulations, doses, and modes of delivery of hormone therapy on benefits and risks is insufficient to draw firm conclusions.

Continuing research on long-term outcomes, such as cancer, mortality, or debilitating diseases that have not been assessed by the available studies, will be important to provide a full understanding of the implications of hormone therapy. In the WHI studies, some of the risk reductions and increases disappeared after women had stopped treatment. Other risks, such as risk of invasive breast cancer, were still elevated years after women had stopped estrogen plus progestin treatment. Given that most women who use hormone therapy start treatment of menopausal symptoms during perimenopause or early postmenopause, future research needs to further explore the effect of early initiation on health outcomes and the primary prevention of chronic diseases. Future studies also need to explore the comparative benefits and harms of different formulations and treatment durations of hormone therapy.

Finally, most subgroup analyses of the WHI were probably not powered to detect clinically relevant differences between subgroups of interest. Combining individual patient data from all trials to conduct individual patient data meta-analyses could probably overcome this issue and provide more definitive answers.

## Conclusions

Hormone therapy plays an important role in the clinical management of menopausal symptoms, but it has a complex pattern of risks and benefits in the primary prevention of chronic conditions. Depending on the treatment regimen, the risk-benefit profile of hormone therapy for the prevention of chronic conditions differs for women ages 50 to 79 years. Women undergoing hormone therapy experience some beneficial effects (e.g., reduced risk of fractures or diabetes) but also an increased risk of harms (e.g., higher risk of stroke, thromboembolic events, gallbladder disease, and possibly urinary incontinence), particularly among women older than age 60 years. Some evidence suggests that age at the initiation of hormone therapy can modify the risk-benefit profile (with more favorable results in younger women), particularly for overall mortality and cardiovascular events. To date, however, the available evidence regarding benefits and harms of early initiation of hormone therapy is inconclusive.