# Chapter 3 Results

This chapter begins with the results of our literature searches and a general description of the included trials that form the basis of our analyses and findings. As noted, we used systematic reviews only for finding trials of hormone therapy that our searches might have missed. Furthermore, because we had sufficient evidence from randomized trials for most outcomes, we used observational studies only to address outcomes for which we had no or very little evidence from RCTs.

Following those sections, we present a summary of the available trial evidence regarding benefits and harms (KQ 1 and KQ 2) and differences in effects among subgroups (KQ 3). We then document the evidence in more detail for each outcome of interest stratified by the hormone therapy treatment (estrogen only or estrogen plus progestin).

Because results of the WHI have been published in multiple publications, we chose articles that focused on specific outcomes (e.g., gallbladder disease, urinary incontinence) over more general publications, when available.

## Results of Literature Searches

For this update, we identified 2,208 citations. Of these, we excluded 1,920 abstracts and reviewed 288 full-text articles; we also reviewed 68 full-text articles included in the previous review. We retained 20 new articles reporting on three new trials, two previously included trials, and three new observational studies; we retained 30 additional articles that met inclusion criteria for observational studies. Combined with articles we carried forward from the previous review, we included 85 articles representing 20 unique fair- or good-quality trials and three large controlled cohort studies (Figure 2). Appendix D lists articles excluded at full-text review, and Appendix E provides quality ratings for included studies and studies excluded for poor quality.^81–86^

Figure 2 Literature Flow Diagram

Abbreviations: KQ=key question; RCT=randomized, controlled trial; USPSTF=U.S. Preventive Services Task Force.

This figure is a preferred reporting of systematic review and meta-analysis (PRISMA) tree that summarizes the search and selection of articles: There were 2,193 new references identified through database searching and 15 citations identified from other sources, resulting in 2.208 citations screened for potential inclusion. Of these, 1,920 were excluded and 288 were deemed appropriate for full-text review to determine eligibility. From the previous USPSTF review, 68 articles were also included for full text review for a total of 356 full-text articles assessed for eligibility. After full-text review, 244 articles were excluded: 10 for not original research, 10 for ineligible population, 10 for ineligible intervention, 9 for duration less than 1 year, 72 for outcomes not relevant to primary prevention of chronic conditions, 7 for ineligible comparator or no comparator, 10 ineligible study design, 27 for systematic review with eligibility criteria that does not meet criteria for this review, 3 for ineligible setting, 5 for non-English full text, 61 for ineligible publication type, 3 for poor quality, 9 for duplicate, 8 for systematic review for hand search. For includes, 82 were RCTs (20 studies), and 30 were eligible observational studies, with 3 included to address outcomes with little evidence from RCTs. Eighty five articles (23 studies) were included for KQ1/KQ2 and 30 articles (8 studies) were included for KQ3.

## Description of Trials

The 20 RCTs provided data on 39,145 perimenopausal and postmenopausal women comparing the effects of estrogen, either alone or in combination with progestin, versus placebo for the prevention of chronic conditions (Table 3).

Table 3 Characteristics of Randomized, Controlled Trials of Use of Hormone Therapy

Trial Name (Acronym) | Author, Year | Country; Participants | Intervention; Duration | Quality Rating
Early vs. Late Intervention Trial with Estradiol, Cognitive Endpoints (ELITE-Cog) | Henderson et al, 2016^92^ | - United States; - Ages 41–84 years; - Within 6 years of natural or surgical menopause (early postmenopause group) or at least 10 years beyond natural or surgical menopause (late menopause group); - Serum estradiol level <25 pg/mL | 17β-estradiol 1 mg/day (N=323); Placebo (N=320); Women with a uterus: cyclic micronized progesterone (45 mg) as a 4% vaginal gel; Mean 4.8 years | Fair
Estrogen Memory Study (EMS) | Tierney et al, 2009^141^ | - Canada; - Ages 61–87 years; - Last menstrual cycle >12 months before screening; - Fluent in English and could read normal print and hear normal speech | 17β-estradiol 1 mg/day for 4 days then 17β-estradiol 1 mg plus norethindrone 0.35 mg/day for 3 days, repeated every week (N=70); Placebo (N=72); 2 years | Fair
Estrogen in the Prevention of Atherosclerosis (EPAT) | Hodis et al, 2001^112^ | - United States; - Postmenopausal women; - Ages 46–80 years; - Low-density lipoprotein cholesterol level ≥130 mg/dL | Micronized 17β-estradiol 1 mg/day (N=111); Placebo (N=111); 2 years | Fair
Estonian Postmenopausal Hormone Therapy Trial (EPHT) | Veerus et al, 2006^137^ | - Estonia; - Ages 50–64 years; - An elapsed ≥12 months since last period at the randomization stage | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=404); Placebo (N=373); Mean 3.4 years | Fair
Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis (ERA) | Herrington et al, 2000^113^ | - United States; - Ages 41–79 years; - Postmenopausal women not currently receiving estrogen replacement therapy; - With >1 epicardial coronary stenosis of ≥30% of the luminal diameter | CEE 0.625 mg/day (N=100); CEE 0.625 mg/day plus MPA 2.5 mg/day (N=104); Placebo (N=105); 3.2 years | Fair
Greenspan et al | Greenspan et al, 2005^107^ | - United States; - Ages 65–90 years; - Community-dwelling women | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=121); CEE 0.625 mg/day (N=66); Placebo (N=186); 3 years | Good
Heart and Estrogen/Progestin Replacement Study (HERS) | Grady et al, 1998;^167^ Hulley et al, 1998;^168^ Kanaya et al, 2003;^148^ Steinauer et al, 2005^136,^ ^152^ | - United States; - Age ≤80 years (mean, 66.7); - Intact uterus; - Postmenopausal; - Established coronary artery disease | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=1,380); Placebo (N=1,383); Mean 4.1 years; CEE 0.625 mg/day plus MPA 2.5 mg/day (N=1,156); Placebo (N=1,165); Mean 6.8 years | Good
Kronos Early Estrogen Prevention Study–Cognitive and Affective Study (KEEPS-Cog) | Gleason et al, 2015^146^ | - United States; - Ages 42–58 years; - Intact uterus; - Recently postmenopausal; - At risk for cardiovascular disease | CEE 0.45 mg/day plus MP 200 mg/day for 12 days/month (N=220); Transdermal estradiol 50 μg/day plus MP 200 mg/day for 12 days/month (N=211); Placebo (N=262); 4 years | Fair
Kronos Early Estrogen Prevention Study-MRI (KEEPS-MRI) | Kantarci et al, 2016^100^ | - United States; - Ages 42–59 years; - In good cardiovascular health; - 5–36 months past menopause; - No MRI contraindications for safety and neurological disorders | CEE 0.45 mg/day plus MP 200 mg/day for 12 days/month (N=31); Transdermal 17β-estradiol 50 μg/day plus MP 200 mg/day for 12 days/month (N=31); Placebo (N=39); 4 years | Fair
Postmenopausal Estrogen and Progestin Interventions Trial (PEPI) | PEPI, 1995^32^ | - United States; - Ages 45–64 years; - With or without a uterus; - Naturally or surgically menopausal | CEE 0.625 mg/day (N=175); CEE 0.625 mg/day plus MPA 10 mg/day for 12 days/month (N=174); CEE 0.625 mg/day plus MP 200 mg/day for 12 days/month (N=178); Placebo (N=174); 3 years | Fair
STOP-IT | Gallagher et al, 2001^106^ | - United States; - Ages 65–77 years; - Femoral neck density within normal range for age | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=121); CEE 0.625 mg/day plus MPA 2.5 mg/day plus calcitriol 0.25 μg twice daily (N=122); Calcitriol 0.25 μg twice daily (N=123); Placebo (N=123); 3 years | Fair
Ultra-Low-Dose Transdermal Estrogen Assessment (ULTRA) | Ettinger et al, 2004;^169^ Johnson et al, 2005;^115^ Waetjen et al, 2005;^129^ Yaffe et al, 2006^124^ | - United States; - Ages 60–80 years; - Intact uterus; - ≥5 years past menopause; - Bone mineral density normal for age | Unopposed transdermal estradiol 0.014 mg/day (N=208); Placebo (N=209); 2 years | Good
Women’s Angiographic Vitamin and Estrogen Trial (WAVE) | Waters et al, 2002^105^ | - United States, Canada; - Postmenopausal; - Mean age of 65 years; - Coronary angiogram performed within 4 months of study entry | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=86); CEE 0.625 mg/day (N=124); Placebo (N=213); Mean 2.8 years | Fair
Women’s Health Initiative (WHI) E Trial | Anderson et al, 2004;^37^ Bonds et al, 2006;^125^ Brunner et al, 2005;^170^ Chlebowski et al, 2010;^116^ Cirillo et al, 2005;^127^ Curb et al, 2006;^131^ Hendrix et al, 2005;^130^ Hendrix et al, 2006;^128^ Hsia et al, 2006;^117^ Manson et al, 2013;^67^ Ritenbaugh et al, 2008;^114^ Rossouw et al, 2007^52^ | - United States; - Postmenopausal; - Ages 50–79 years; - Prior hysterectomy; - 3-month washout period required for women using hormone therapy at baseline | CEE 0.625 mg/day (N=5,310); Placebo (N=5,429); Median 7.2 years | Fair
WHI E Postintervention and Postintervention Extension Phases | Chlebowski et al, 2010;^134^ LaCroix et al, 2011;^108^ Manson et al, 2013;^67^ Manson, 2017;^88^ Prentice, 2020;^91^ Prentice, 2020^101^ | - 9,666 participants from WHI (90%) had any postintervention followup and 7,645 (71%) consented to participate in the extension phase | Postintervention followup; CEE 0.625 mg/day (N=4,794); Placebo (N=4,872); Mean 6.6 years; Postintervention extension followup; CEE 0.625 mg/day (N=3,778); Placebo (N=3,867) | Fair
WHI E+P Trial | Anderson et al, 2012;^109^ Anderson et al, 2003;^126^ Canonico et al, 2014;^171^ Cauley et al, 2003;^150^ Chlebowski et al, 2003;^133^ Chlebowski et al, 2004;^140^ Cirillo et al, 2005;^127^ Cushman et al, 2004;^153^ Hays et al, 2003;^172^ Hendrix et al, 2003;^173^ Hendrix et al, 2005;^130^ Hsia et al, 2004;^80^ Manson et al, 2003;^174^ Manson et al, 2013;^67^ Margolis et al, 2004;^149^ Prentice et al, 2009;^110^ Rossouw et al, 2002;^36^ Rossouw et al, 2007;^52^ Tang et al, 2011;^175^ Toh et al, 2010;^176^ Wassertheil-Smoller et al, 2003^151^ | - United States; - Postmenopausal; - Ages 50–79 years; - 3-month washout period for women using hormone therapy at baseline | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=8,506); Placebo (N=8,102); Median 5.6 years | Fair
WHI E+P Postintervention and Postintervention Extension Phases | Chlebowski et al, 2009;^142^ Chlebowski et al, 2010;^134^ Gramling et al, 2009;^135^ Heiss et al, 2008;^132^ Manson et al, 2013;^67^ Manson, 2017;^88^ Prentice, 2020;^91^ Prentice, 2020^101^ | - 15,747 participants from WHI (95%) had any postintervention followup and 12,788 (77%) consented to participate in the extension phase | Postintervention followup; CEE 0.625 mg/day plus MPA 2.5 mg/day (N=8,060); Placebo (N=7,687); Median 8.2 years; Postintervention extension followup; CEE 0.625 mg/day plus MPA 2.5 mg/day (N=6,545); Placebo (N=6,243) | Fair
Women’s Health Initiative Memory Study (WHIMS) E | Espeland et al, 2004;^121^ Shumaker et al, 2004^119^ | - United States; - WHI participants enrolled in the estrogen-only trial; - Ages 65–79 years; - Free of probable dementia; - Able and willing to undergo annual cognitive assessment | CEE 0.625 mg/day (N=1,464); Placebo (N=1,483); 5.2 years | Good
WHIMS E+P | Culhane, 2003;^177^ Rapp et al, 2003;^147^ Shumaker et al, 2003^143^ | - United States; - WHI participants enrolled in the E+P trial; - Age >65 years; - Free of probable dementia; - Able and willing to undergo annual cognitive assessment | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=2,229); Placebo (N=2,303); 5.4 years | Good
Women’s Health Initiative Memory Study of the Epidemiology of Cognitive Health Outcomes (WHIMS-ECHO) | Espeland et al, 2017^93^ | - United States; - Postmenopausal; - Ages 65–79 years; - 3-month washout period for women using hormone therapy at baseline; - Received clinic-based cognitive testing as part of WHIMS | CEE 0.625 mg/day plus MPA 2.5 mg/day or CEE 0.625 mg/day only^*^ (N=1,402); Placebo (N=1,478); 6.4 years overall group; 7.1 years for those with prior hysterectomy; 5.4 years for those without prior hysterectomy | Fair
Women’s Health Initiative Memory Study of Younger Women (WHIMSY) | Espeland et al, 2013^93,^ ^123^ | - United States; - Postmenopausal; - Ages 50–55 years; - 3-month washout period for women using hormone therapy at baseline | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=696); Placebo (N=630); 7.2 years | Fair
Women’s Health Initiative Study of Cognitive Aging (WHISCA) E | Espeland et al, 2010;^122^ Resnick et al, 2009^120^ | - United States; - WHIMS E-only trial participants; - Free of probable dementia; - At 1 of 14 WHIMS centers; - Began 3 years after enrollment in WHI | CEE 0.625 mg/day (N=434); Placebo (N=452); 3.6 years | Good
WHISCA E Post intervention Phase | Espeland et al, 2010;^122^ | - United States; - WHIMS E-only trial participants; - Free of probable dementia; - At 1 of 14 WHIMS centers; - Began 3 years after enrollment in WHI | CEE 0.625 mg/day (N=434); Placebo (N=452); 2.4 years | Good
WHISCA E+P | Espeland et al, 2010;^122^ Resnick et al, 2006^144^ | - United States; - WHIMS E+P trial participants; - Free of probable dementia; - At 1 of 14 WHIMS centers; - Began 3 years after enrollment in WHI | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=690); Placebo (N=726); 2 years | Good
WHISCA E+P Post intervention Phase | Espeland et al, 2010;^122^ | - United States; - WHIMS E+P trial participants; - Free of probable dementia; - At 1 of 14 WHIMS centers; - Began 3 years after enrollment in WHI | CEE 0.625 mg/day plus MPA 2.5 mg/day (N=690); Placebo (N=726); 4 years | Good
Women’s International Study of Long Duration Oestrogen After Menopause (WISDOM) | Vickers et al, 2007^138^ | - United Kingdom, Australia, New Zealand; - Postmenopausal; - Ages 50–69 years | CEE 0.625 mg/day plus MPA 2.5–5.0 mg/day (N=2,196); CEE 0.625 mg/day (N=826); Placebo (N=2,189); 1 year | Fair

* Analysis did not stratify by treatment regimen.

Abbreviations: AAFP=American Academy of Family Physicians; CEE=conjugated equine estrogen; HT=hormone therapy; MP=micronized progesterone; MPA=medroxyprogesterone acetate; MRI=magnetic resonance imaging; N=number; WHI=Women’s Health Initiative.

Of the 20 included trials, 17 were conducted in the United States. The remaining trials were conducted in Australia, Canada, Estonia, New Zealand, and the United Kingdom. The duration of followup in the trials averaged 4.3 years. The mean age of women participating in trials ranged from 53 (Kronos Early Estrogen Prevention Study–Cognitive and Affective [KEEPS-Cog]) to 75 years (Estrogen Memory Study [EMS]). The majority of women were White; the proportions of non-White women ranged from 1 (Women’s International Study of Long Duration Oestrogen After Menopause [WISDOM]) to 43 percent (Estrogen in the Prevention of Atherosclerosis [EPAT]). The proportions of women with previous or current hormone therapy use ranged from 2 to 74 percent. Between 3 and 58 percent of women in the trials were current smokers.

Most studies assessed conjugated estrogens with or without progestogen. The majority of FDA-approved hormone therapy formulations have not been assessed in clinical trials. Table 4 presents approved hormone therapy formulations and the number of included trials using these formulations. Of the 20 included studies, the WHI trials^67^ were the only studies powered to assess the effectiveness of hormone therapy for the primary prevention of various chronic conditions. They enrolled generally healthy postmenopausal women ages 50 to 79 years and compared 0.625 mg/day of oral conjugated equine estrogen with or without 2.5 mg/day of medroxyprogesterone with placebo. The WHI trials also had the longest durations of followup among included trials (median intervention of 7.2 years for the estrogen-only trial and 5.6 years for the estrogen plus progestin trial; long-term followup of up to 20.4 years).

Table 4 Number of Trials Using FDA-Approved Hormone Therapy Formulations

Substance | Number of Trials and References
Estrogen-only formulation
Conjugated estrogens | 8 trials: Greenspan et al, 2005;^107^ Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis (ERA);^113^ Postmenopausal Estrogen and Progestin Interventions Trial (PEPI);^32^ Women’s Angiographic Vitamin and Estrogen Trial (WAVE);^105^ Women’s Health Initiative (WHI) E Trial;^37,^ ^52,^ ^67,^ ^79,^ ^88,^ ^91,^ ^101,^ ^108,^ ^114,^ ^116,^ ^117,^ ^125,^ ^127,^ ^128,^ ^130,^ ^131,^ ^134,^ ^170^ Women’s Health Initiative Memory Study (WHIMS) E;^119,^ ^121^ Women’s Health Initiative Study of Cognitive Aging (WHISCA) E;^120,^ ^122^ Women’s International Study of Long Duration Oestrogen After Menopause (WISDOM)^138^
Conjugated estrogen/bazedoxifene | No trials
Estradiol | 3 trials: Early vs. Late Intervention Trial with Estradiol, Cognitive Endpoints (ELITE-Cog);^92^ Estrogen in the Prevention of Atherosclerosis (EPAT);^112^ Ultra-Low-Dose Transdermal Estrogen^115,^ ^124,^ ^129,^ ^169^
Estradiol acetate | No trials
Estradiaol valerate | No trials
Esterified estrogen | No trials
Estropipate | No trials
Synthetic conjugated estrogens | No trials
Estrogen plus progestogen formulations
Conjugated estrogens + medroxyprogesterone acetate | 14 trials: Estonian Postmenopausal Hormone Therapy Trial (EPHT);^137^ Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis (ERA);^113^ Greenspan et al, 2005;^107^ Heart and Estrogen/Progestin Replacement Study (HERS);^148,^ ^152,^ ^167,^ ^168^ Postmenopausal Estrogen and Progestin Interventions Trial (PEPI);^32^ STOP-IT;^106^ Women’s Angiographic Vitamin and Estrogen Trial (WAVE);^105^ WHI E+P Trial;^36,^ ^52,^ ^67,^ ^80,^ ^88,^ ^91,^ ^101,^ ^109,^ ^110,^ ^126,^ ^127,^ ^130,^ ^132–135,^ ^140,^ ^142,^ ^149–151,^ ^153,^ ^171–176^ WHIMS E+P;^143,^ ^147,^ ^177^ Women’s Health Initiative Memory Study of the Epidemiology of Cognitive Health Outcomes (WHIMS-ECHO);^93^ Women’s Health Initiative Memory Study of Younger Women (WHIMSY);^93,^ ^123^ WHISCA E+P;^120,^ ^122^ Women’s International Study of Long Duration Oestrogen After Menopause (WISDOM)^138^
Estradiol + drospirenone | No trials
Estradiol + levonorgestrel | No trials
Estradiol + norethindrone acetate | 1 trial: Estrogen Memory Study^141^
Estradiol + norgestimate | No trials
Estradiol + micronized progesterone | 3 trials: Kronos Early Estrogen Prevention Study–Cognitive and Affective Study (KEEPS-Cog);^146^ KEEPS-MRI;^100^ Postmenopausal Estrogen and Progestin Interventions Trial (PEPI)^32^
Ethinyl estradiol + norethindrone acetate | No trials

Abbreviation: FDA=Food and Drug Administration.

Table 5 presents baseline characteristics of participants in the included trials.

Table 5 Baseline Characteristics of Participants in Randomized, Controlled Trials of Hormone Therapy to Prevent Chronic Conditions

Part A

Characteristic (Hormone Therapy; Placebo)^*^ | ELITE-Cog | EMS E+P | EPAT | EPHT | ERA | Greenspan et al | HERS E+P | KEEPS-Cog | KEEPS-MRI | PEPI | STOP-IT
N | 323; 320 | 70; 72 | 111; 111 | 404; 373 | 100; 104; 105 | 187; 186 | 1,380; 1,383 | 220; 211; 262 | 31; 31; 39 | 175; 174; 178; 174 | 121; 122; 123; 123
Age (mean years) | 60.9; 60.5 | 75; 74.5 | 60.9; 62.1 | 58.5; 59.0 | 66.3; 65.5; 65.6 | 71.1; 71.3 | 67; 67 | 52.8; 52.6; 52.5 | 53; 53; 53 | - | 72; 71; 72; 74
Non-White race (%) | 27.1; 32.9 | 4.3; 9.7 | 43.0; 38.0 | - | 19.0; 16.0; 19.0 | - | 12; 10 | 22.3; 22.7; 23.3 | - | - | -
Previous or current HT (%) | 73.6; 70.7 | 31.4; 23.6 | - | 9.2; 6.4 | 9.0; 8.0; 10.0 | - | 1.7; 1.7 | 26.4; 20.4; 18.3 | - | - | -
Hysterectomy at age <40 years (%) | - | - | - | - | - | - | - | - | - | - | -
Hysterectomy at ages 40–49 years (%) | - | - | 33.0; 44.0^†^ | 11.4; 12.9^†^ | 56.0; 62.0; 66.0 | - | - | - | - | - | -
Bilateral oophorectomy (%) | 9.9; 11.3 | - | 32.0; 19.0 | - | 25.0; 30.0; 36.0 | - | - | - | - | - | -
Never pregnant (%) | - | - | - | 8.9; 8.1 | - | - | - | - | - | - | -
First pregnancy at age ≥30 years (%) | - | - | - | - | - | - | - | - | - | - | -
Female relative with breast cancer (%) | - | - | - | 7.2; 7.0 | - | - | 12; 11 | - | - | - | -
Current smoker (%) | 3.9; 2.8 | - | 58.0; 46.0 | 16.3; 13.9 | 18.0; 16.0; 21.0 | - | 13; 13 | 5.9; 6.6; 6.9 | 7; 10; 9 | - | -
Mean BMI (kg/m^2^) | 27.5; 26.9 | 27; 26.6 | 28.7; 29.0 | 27.0; 26.9 | - | 27.5; 27.7 | 29; 29 | 26.1; 26.1; 26.6 | 28; 26; 27 | - | -
History of MI (%) | - | 5.7; 4.2 | - | 0.5; 0.3 | 48.0; 41.0; 55.0 | - | 50; 52 | - | - | - | -
History of stroke (%) | - | - | - | - | - | - | - | - | - | - | -
History of DVT or PE (%) | - | - | - | - | - | - | - | - | - | - | -
Mean SBP (mm Hg) | 117.8; 117.3 | - | 127.8; 128.6 | 137; 137 | 131.0; 136.2; 134.4 | - | 135; 135 | 119.1; 117.5; 120.1 | 122; 120; 122 | 115; 115; 114; 116 | -
Mean DBP (mm Hg) | 74.9; 74.9 | - | 78.1; 77.0 | 85.7; 86 | 73.4; 74.1; 74.4 | - | 73; 73 | 75.3; 74.1; 75.5 | 77; 73; 76 | 72; 72; 73; 71 | -
Treated for hypertension or BP >140/90 mm Hg (%) | - | - | - | 13.1; 12.1 | 60.0; 73.0; 69.0 | - | - | - | - | - | -
Elevated cholesterol requiring medication (%) | - | - | - | - | 34.0; 38.0; 37.0 | - | - | - | - | - | -
Prior aspirin use or use at baseline (%) | - | - | - | - | 67.0; 73.0; 70.0 | - | 79; 79 | - | - | - | -
History of or treatment for diabetes (%) | - | 7.1; 11.1 | 2.0; 4.0 | - | 25.0; 29.0; 30.0 | - | 19; 18 | - | - | - | -
Fracture at age ≥55 years (%) | - | - | - | - | - | - | - | - | - | - | -

Part B

Characteristic (Hormone Therapy; Placebo)^*^ | ULTRA E | WAVE | WHI E | WHI E+P | WHIMSY | WHIMS E | WHIMS E+P | WHIMS-ECHO | WHISCA E | WHISCA E+P | WISDOM E+P
N | 208; 209 | 124; 86; 213 | 5,310; 5,429 | 8,506; 8,102 | 696; 630 | 1,464; 1,483 | 2,229; 2,303 | 1,402; 1,478 | 434; 452 | 690; 726 | 2,196; 2,189
Age (mean years) | 66.8; 66.7 | 65.0; 69.0 | 63.6; 63.6 | 63.2; 63.3 | 53.0; 52.9 | 63.6; 63.6 | 63.2; 63.3 | 70.3; 70.3 | 74.01; 74.02 | 73.69; 73.86 | 63.3; 63.3
Non-White race (%) | 7.2; 8.1 | 35.0; 32.0 | 24.5; 24.9 | 16.1; 16.0 | 20.0; 19.2 | 17.3; 16.4 | - | 11.6; 10.8 | 14.09; 13.08 | 8.4; 7.0 | 1; 1.4
Previous or current HT (%) | - | - | 47.8; 48.9 | 26.1; 25.6 | 47.9; 53.2 | 45.8; 44.7 | 21.8; 22.4 | 46.9; 43.4 | 49.54; 46.24 | 21.2; 22.6 | 55; 54.3
Hysterectomy at age <40 years (%) | - | - | 39.8; 39.8 | - | 56.6; 57.3 | - | - | - | - | - | -
Hysterectomy at ages 40–49 years (%) | - | 59.0; 58.0^†^ | 43.2; 42.2 | - | 20.9; 16.5 | - | - | 37.0; 35.9 | - | - | -
Bilateral oophorectomy (%) | - | 36.0; 37.0 | 39.5; 42.0 | - | - | - | - | - | - | - | -
Never pregnant (%) | - | - | 9.3; 8.5 | 10.1; 10.3 | - | - | - | - | - | - | -
First pregnancy at age ≥30 years (%) | - | - | 4.9; 5.9 | 10.6; 9.7 | - | - | - | - | - | - | -
Female relative with breast cancer (%) | - | - | 18.0; 17.1 | 16.0; 15.3 | - | - | - | - | - | - | 8; 9
Current smoker (%) | 7.7; 6.2 | 19.0; 19.0 | 10.3; 10.6 | 10.5; 10.5 | 13.5; 16.3 | 7.3; 8.0 | 6.7; 6.9 | 4.2; 5.6 | 3.72; 7.59 | 6.2; 5.0 | 12; 14
Mean BMI (kg/m^2^) | 28.3; 28.0 | 31.1; 30.3 | 30.1; 30.1 | 28.5; 28.5 | - | - | - | 25-29; 25-29 | 29.40; 29.21 | 28.5; 28.1 | 27.9; 28.0
History of MI (%) | - | 46.0; 40.0 | 3.1; 3.2 | 1.6; 1.9 | - | - | - | 16.9; 15.4 | - | - | 2; 1
History of stroke (%) | - | - | 1.4; 1.7 | 0.7; 1.0 | - | 1.8; 2.1 | 1.0; 1.9 | 16.9; 15.4 | 1.15; 1.77 | 1; 1 | 1; 2
History of DVT or PE (%) | - | - | 1.6; 1.5 | 0.9; 0.8 | - | - | - | 16.9; 15.4 | - | - | -
Mean SBP (mm Hg) | - | 140.0; 138.0 | 130.4; 130.2 | 127.6; 127.8 | - | - | - | - | - | - | -
Mean DBP (mm Hg) | - | 76.0; 75.0 | 76.5; 76.5 | 75.6; 75.8 | - | - | - | - | - | - | -
Treated for hypertension or BP >140/90 mm Hg (%) | - | 77.0; 74.0 | 48.0; 47.4 | 35.7; 36.4 | 21.0; 21.0 | 47.3; 42.3 | - | 35.6; 33.2 | 53.69; 51.11 | 44.4; 46.0 | -
Elevated cholesterol requiring medication (%) | - | - | 14.5; 15.9 | 12.5; 12.9 | - | - | - | - | - | - | -
Prior aspirin use or use at baseline (%) | - | 84.0; 86.0 | 19.4; 19.7 | 19.1; 20.1 | - | 28.0; 30.9 | 28.1; 29.6 | - | - | - | -
History of or treatment for diabetes (%) | - | 42.0; 31.0 | 7.7; 7.6 | 4.4; 4.4 | - | 11.3; 10.6 | 7.0; 6.5 | 5.8; 6.4 | 10.14; 10.84 | 5.4; 6.2 | 3; 4
Fracture at age ≥55 years (%) | - | - | 14.0; 13.2 | 13.5; 13.6 | - | - | - | - | - | - | -

* Intervention dosages are listed in Table 3 by trial.

† Participants of all ages.

Abbreviations: BMI=body mass index; BP=blood pressure; DBP=diastolic blood pressure; DVT=deep vein thrombosis; E=estrogen; E+P=estrogen plus progestin; ELITE-Cog=Early vs. Late Intervention Trial with Estradiol, Cognitive Endpoints; EMS=Estrogen Memory Study; EPAT=Estrogen in the Prevention of Atherosclerosis; EPHT=Estonian Postmenopausal Hormone Therapy Trial; ERA=Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis; HERS=Heart and Estrogen/Progestin Replacement Study; HT=hormone therapy; KEEPS=Kronos Early Estrogen Prevention Study; KEEPS-MRI=Kronos Early Estrogen Prevention Study-MRI; MI=myocardial infarction; P=progestin; PE=pulmonary embolism; PEPI=Postmenopausal Estrogen and Progestin Interventions Trial; SBP=systolic blood pressure; ULTRA=Ultra-Low-Dose Transdermal Estrogen Assessment; WAVE=Women’s Angiographic Vitamin and Estrogen Trial; WHI=Women’s Health Initiative; WHIMS=Women’s Health Initiative Memory Study; WHIMS-ECHO=Women’s Health Initiative Memory Study; WHISCA=Women’s Health Initiative Study of Cognitive Aging; WISDOM=Women’s International Study of Long Duration Oestrogen After Menopause.

## Summary of Evidence

The WHI reported most of the results and was most applicable to the target population of interest to the USPSTF. This summary section provides an overview of results. More detailed findings by chronic condition and regimen follow this summary.

Figures 3 and 4 depict the absolute risk reductions or increases for various benefit or harm outcomes of interest for women who received hormone therapy for 5 to 7 years compared with those who received placebo. Results are depicted as point estimates (fewer or more events per 10,000 women) with 95 percent CIs based on meta-analyses of included trials or, if meta-analyses were not feasible, based on results from the largest and most reliable trial (usually the WHI).

Figure 3 Absolute Risk Reductions or Increases During the Intervention Period for Women Treated With Estrogen Only^*^ * Findings are based on meta-analyses of included trials or, if meta-analyses were not feasible, based on results from the largest and most reliable trial (usually the WHI); followup periods for all outcomes are 7.1 years except all-cause mortality, 2 to 7.2 years; fractures, 7.2 years; dementia, 5.2 years; and urinary incontinence, 1 year.

^†^ We calculated relative risks to determine absolute risk reductions and increases presented in this figure because it is unclear whether the proportional hazards assumption is always met in long-term hormone therapy trials. Estimates of relative risks might differ from HRs of trials that are presented in the text.

Abbreviations: CI=confidence interval; HR=hazard ratio; N=number; RR=relative risk; SOE=strength of evidence.

This figure displays the relative risks of various outcomes, comparing estrogen only hormone therapy with placebo, and includes a forest plot of events per 10,000 women for each outcome. Relatives risks were calculated to determine absolute risk reductions and increases presented in this figure because it is unclear whether the proportional hazards assumption is always met in long-term hormone therapy trials; estimates of relative risks might differ from hazard ratios of trials that are presented in the text. Based on the best available study, a single trial representing 10,739 women provided moderate strength of evidence of a relative risk for invasive breast cancer of 0.79 with a 95 percent confidence interval of 0.61 to 1.02. This is represented by a bar that is almost entirely green to demonstrate a risk reduction. Based on the best available study, a single trial representing 10,739 women provided low strength of evidence of a relative risk for colorectal cancer of 1.15 with a 95 percent confidence interval of 0.81 to 1.64. This is represented by a green and red bar to demonstrate a mixed effect. Based on the best available study, a single trial representing 10,739 women provided low strength of evidence of a relative risk for lung cancer of 1.04 with a 95 percent confidence interval of 0.73 to 1.48. This is represented by a green and red bar to demonstrate a mixed effect. Based on the best available study, a single trial representing 10,739 women provided low strength of evidence of a relative risk for total cancer mortality of 0.96 with a 95 percent confidence interval of 0.75 to 1.22. This is represented by a green and red bar to demonstrate a mixed effect. Three trials representing 11,310 women produced high strength of evidence of a relative risk for coronary heart disease of 0.95 with a 95 percent confidence interval of 0.79 to 1.14. This is represented by a green and red bar to demonstrate a mixed effect. Based on the best available study, a single trial representing 2,947 women provided low strength of evidence of a relative risk for probable dementia of 1.49 with a 95 percent confidence interval of 0.84 to 2.66. This is represented by a red and bar to demonstrate a mixed effect. Based on the best available study, a single trial representing 9,917 women provided moderate strength of evidence of a relative risk for diabetes of 0.86 with a 95 percent confidence interval of 0.76 to 0.98. This is represented by a green bar to demonstrate a risk reduction. Based on the best available study, a single trial representing 10,739 women provided high strength of evidence of a relative risk for fractures (osteoporotic) of 0.73 with a 95 percent confidence interval of 0.65 to 0.80. This is represented by a green bar to demonstrate a risk reduction. Based on the best available study, a single trial representing 8,376 women provided moderate strength of evidence of a relative risk for gallbladder disease of 1.51 with a 95 percent confidence interval of 1.32 to 1.73. This is represented by a red bar to demonstrate a risk increase. Based on the best available study, a single trial representing 10,739 women provided moderate strength of evidence of a relative risk for stroke of 1.35 with a 95 percent confidence interval of 1.07 to 1.70. This is represented by a red bar to demonstrate a risk increase. Based on the best available study, a single trial representing 6,767 women provided moderate strength of evidence of a relative risk for urinary incontinence of 1.61 with a 95 percent confidence interval of 1.46 to 1.79. This is represented by a red bar to demonstrate a risk increase. Based on the best available study, a single trial representing 10,739 women provided moderate strength of evidence of a relative risk for venous thromboembolism of 1.32 with a 95 percent confidence interval of 1.00 to 1.76. This is represented by a red bar to demonstrate a risk increase. Three trials representing 11,587 women provided high strength of evidence of a relative risk for all-cause mortality of 1.04 with a 95 percent confidence interval of 0.89 to 1.21. This is represented by a green and red bar to demonstrate a mixed effect.

Figure 4 Absolute Risk Reductions or Increases During the Intervention Period for Women Treated With Estrogen Plus Progestin^*^ * Findings are based on meta-analyses of included trials or, if meta-analyses were not feasible, based on results from the largest and most reliable trial (usually the WHI); followup periods for all outcomes are 5.6 years except fractures, 2 to 5.6 years; coronary heart disease, 2 to 5.6 years; dementia, 4 years; and urinary incontinence, 1 year.

^†^ We calculated relative risks to determine absolute risk reductions and increases presented in this figure because it is unclear whether the proportional hazards assumption is always met in long-term hormone therapy trials. Estimates of relative risks might differ from HRs of trials that are presented in the text.

Abbreviations: CI=confidence interval; HR=hazard ratio; N=number; RR=relative risk; SOE=strength of evidence.

This figure displays the relative risks of various outcomes, comparing estrogen plus progestin hormone therapy with placebo, and includes a forest plot of events per 10,000 women for each outcome. Relatives risks were calculated to determine absolute risk reductions and increases presented in this figure because it is unclear whether the proportional hazards assumption is always met in long-term hormone therapy trials; estimates of relative risks might differ from hazard ratios of trials that are presented in the text. Based on the best available study, a single trial representing 16,608 women provided high strength of evidence of a relative risk for invasive breast cancer of 1.27 with a 95 percent confidence interval of 1.03 to 1.56. This is represented by a red bar to demonstrate a risk increase. Based on the best available study, a single trial representing 16,608 women provided low strength of evidence of a relative risk for cervical cancer of 1.52 with a 95 percent confidence interval of 0.50 to 4.66. This is represented by a green and red bar to demonstrate a mixed effect. Based on the best available study, a single trial representing 16,608 women provided moderate strength of evidence of a relative risk for colorectal cancer of 0.62 with a 95 percent confidence interval of 0.43 to 0.89. This is represented by a green bar to demonstrate a risk reduction. Based on the best available study, a single trial representing 16,608 women provided low strength of evidence of a relative risk for endometrial cancer of 0.83 with a 95 percent confidence interval of 0.49 to 1.40. This is represented by a green and red bar to demonstrate a mixed effect. Based on the best available study, a single trial representing 16,608 women provided moderate strength of evidence of a relative risk for lung cancer of 1.06 with a 95 percent confidence interval of 0.77 to 1.46. This is represented by a green and red bar to demonstrate a mixed effect. Based on the best available study, a single trial representing 16,608 women provided low strength of evidence of a relative risk for ovarian cancer of 1.41 with a 95 percent confidence interval of 0.75 to 2.66. This is represented by a green and red bar to demonstrate a mixed effect. Based on the best available study, a single trial representing 16,608 women provided low strength of evidence of a relative risk for total cancer mortality of 1.14 with a 95 percent confidence interval of 0.89 to 1.47. This is represented by a green and red bar to demonstrate a mixed effect. Three trials representing 18,155 women produced high strength of evidence of a relative risk for coronary heart disease of 1.12 with a 95 percent confidence interval of 0.94 to 1.33. This is represented by a red bar to demonstrate a risk increase. Based on the best available study, a single trial representing 4,532 women provided low strength of evidence of a relative risk for probable dementia of 1.97 with a 95 percent confidence interval of 1.16 to 3.33. This is represented by a red bar to demonstrate a risk increase. Based on the best available study, a single trial representing 15,874 women provided moderate strength of evidence of a relative risk for diabetes of 0.81 with a 95 percent confidence interval of 0.70 to 0.94. This is represented by a green bar to demonstrate a risk reduction. Five trials representing 20,499 women provided high strength of evidence of a relative risk for fractures (osteoporotic) of 0.79 with a 95 percent confidence interval of 0.66 to 0.94. This is represented by a green bar to demonstrate a risk reduction. Based on the best available study, a single trial representing 14,203 women provided moderate strength of evidence of a relative risk for gallbladder disease of 1.56 with a 95 percent confidence interval of 1.36 to 1.79. This is represented by a red bar to demonstrate a risk increase. Based on the best available study, a single trial representing 16,608 women provided moderate strength of evidence of a relative risk for stroke of 1.37 with a 95 percent confidence interval of 1.07 to 1.76. This is represented by a red bar to demonstrate a risk increase. Based on the best available study, a single trial representing 11,578 women provided moderate strength of evidence of a relative risk for urinary incontinence of 1.49 with a 95 percent confidence interval of 1.36 to 1.63. This is represented by a red bar to demonstrate a risk increase. Based on the best available study, a single trial representing 16,608 women provided moderate strength of evidence of a relative risk for venous thromboembolism of 2.06 with a 95 percent confidence interval of 1.57 to 2.70. This is represented by a red bar to demonstrate a risk increase. Three trials representing 19,580 women provided moderate strength of evidence of a relative risk for all-cause mortality of 1.01 with a 95 percent confidence interval of 0.88 to 1.16. This is represented by a green and red bar to demonstrate a mixed effect.

Figures 3 and 4 also present the relative risk (RR) and the SOE for each outcome. We calculated RRs based primarily on a publication summarizing results of the WHI trials.^67^ Therefore, effect estimates might differ slightly from hazard ratios (HRs) reported in WHI publications. We chose RR because it is more intuitive to interpret than HR.

Outcomes associated with a statistically significant benefit of treatment included a reduction of fractures, diabetes, and colorectal cancer. Outcomes associated with statistically significant harm included probable dementia, gallbladder disease, stroke, urinary incontinence, and venous thromboembolism; these are described below. Some of the statistically nonsignificant outcomes, however, had wide CIs that encompassed both clinically relevant benefits and harms, leading to inconclusive results. Specifically for cervical cancer, endometrial cancer, lung cancer, and ovarian cancer, event rates in studies were too low to draw firm conclusions about differences in benefits and harms.

### KQ 1 What Are the Benefits of Menopausal Hormone Therapy When Used for Primary Prevention of Chronic Conditions?

Compared with the 2017 review, we added 20 new publications^79,^ ^80,^ ^87–104^ of three new trials, two previously included trials, and three new observational studies. We excluded one RCT,^63^ which was conducted in persons who took hormone therapy for the secondary prevention of cardiovascular events. The majority of the new publications reported long-term results of WHI. Three ancillary studies of previously reported RCTs assessed cognitive functioning. Despite this change in the body of evidence, the overall conclusions about the benefits of hormone therapy for the primary prevention of chronic conditions remain unchanged from the prior report.

Overall, trials reported several statistically significant benefits of treatment. For women using estrogen only, risk of fractures (388 fewer cases per 10,000 women over 7.2 years [95% CI, 489 to 277 fewer]) and diabetes (134 fewer cases per 10,000 women over 7.1 years [95% CI, 237 to 18]) were statistically significantly reduced compared with women taking placebo (Figure 3). The risk of breast cancer was numerically reduced but did not reach statistical significance (HR, 0.79 [95% CI, 0.61 to 1.02]).

Women using estrogen plus progestin therapy experienced statistically significantly reduced risk of colorectal cancer (34 fewer cases per 10,000 women over 5.6 years [95% CI, 9 to 51]), fractures (230 fewer cases per 10,000 women over 5.0 years [95% CI, 372 to 66 fewer]), and diabetes (78 fewer cases per 10,000 women over 5.6 years [95% CI, 133 to 15 fewer]) compared with women in the placebo groups (Figure 4).

Long-term followup studies of the WHI showed that most beneficial effects dissipated after stopping hormone therapy. An exception was the risk of invasive breast cancer in women who received estrogen-only therapy. The risk reduction became statistically significant during cumulative (trial and postintervention phase) followup (median 13 years: HR, 0.79 [95% CI, 0.65 to 0.97];^67^ median 20.7 years: HR, 0.78 [95% CI, 0.65 to 0.93]^87^). Likewise, after 13.2 years of cumulative followup, the risk for endometrial cancer became statistically significantly lower in women who were on estrogen plus progestin therapy (HR, 0.65 [95% CI, 0.48 to 0.89]). We did not find any evidence on functional capacity.

### KQ 2 What Are the Harms of Menopausal Hormone Therapy When Used for Primary Prevention of Chronic Conditions?

The 20 new publications also provided evidence on potential harms of hormone therapy.^79,^ ^80,^ ^87–104^ Despite the new evidence, the overall conclusions about harms of hormone therapy remained unchanged from the prior report.

Results of trials and our meta-analyses indicate several important harms for hormone therapy. They differ by treatment formulation (i.e., estrogen only or estrogen plus progestin).

Women receiving estrogen-only therapy had statistically significantly increased risk of gallbladder disease (377 more cases per 10,000 women over 7.1 years [95% CI, 234 to 540]), stroke (79 more cases per 10,000 women over 7.2 years [95% CI, 15 to 159]), urinary incontinence (885 more cases per 10,000 women over 1 year [95% CI, 659 to 1,135]), and venous thromboembolism (77 more cases per 10,000 women over 7.2 years [95% CI, 19 to 153]; Figure 3).

For women receiving estrogen plus progestin therapy, risk of invasive breast cancer (51 more cases per 10,000 women over 5.6 years [95% CI, 6 to 106]), probable dementia (88 more cases per 10,000 women over 4 years [95% CI, 15 to 212]), gallbladder disease (260 more cases per 10,000 women over 5.6 years [95% CI, 169 to 364]), stroke (52 more cases per 10,000 women over 5.6 years [95% CI, 12 to 104]), urinary incontinence (562 more cases per 10,000 women over 1 year [95% CI, 412 to 726]), and venous thromboembolism (120 more cases per 10,000 women over 5.6 years [95% CI, 68 to 185]) were statistically significantly increased compared with women taking placebo (Figure 4). We did not find any evidence on other harms or on the effect of harms on functional capacity.

### KQ 3 Do the Benefits and Harms of Menopausal Hormone Therapy Differ by Subgroup or by Timing of Intervention?

Compared with the 2017 review, 12 new publications reported on subgroups or the timing of the intervention.^79,^ ^80,^ ^87–93,^ ^95,^ ^97,^ ^102^ Overall conclusions about differences in benefits and harms of hormone therapy for subgroups did not change in the updated report.

Subgroups specified for this KQ included the following: race/ethnicity; women with premature menopause; women with surgical menopause; age; duration of use; type, dose, and mode of delivery of hormone therapy; and presence of comorbid conditions. Trials did not report results for most of these subgroups. Subgroup analyses of trial results based on these characteristics were restricted to age, race/ethnicity, oophorectomy status, and a limited number of coexisting conditions or risk factors.

Some subgroup analyses indicated that age may modify the effects of hormone therapy. Analyses that compared younger (ages 50 to 59 years) with older (ages 70 to 79 years) women using estrogen-only therapy yielded a statistically significant trend for increasing risk by age of myocardial infarction (HR, 0.55 [95% CI, 0.31 to 1.00] vs. HR, 1.24 [95% CI, 0.88 to 1.75]; p=0.02 for trend),^67^ colorectal cancer (HR, 0.71 [95% CI, 0.30 to 1.67] vs. HR, 2.24 [95% CI, 1.16 to 4.30]; p=0.02 for trend),^67^ and all-cause mortality (HR, 0.71 [95% CI, 0.46 to 1.09] vs. HR, 1.22 [95% CI, 0.95 to 1.56]; p=0.04 for trend).^67^ Post hoc subgroup analyses regarding the effects of time since menopause were inconclusive.

Some of these subgroup differences, however, are based on relatively few events and need to be interpreted cautiously. In addition, many of the subgroup analyses were post hoc analyses. In its study protocol, WHI specified age, race/ethnicity, obesity, hysterectomy, and cardiovascular disease at baseline as subgroups of interest.

## Detailed Presentation of the Evidence

In the sections below, we present benefits and harms first for estrogen-only hormone therapy and then for estrogen plus progestin by outcome of interest. We specifically comment on the various types of cancer (breaking out the gynecologic cancers by specific type, such as cervical or ovarian) and then turn to the various other condition-specific outcomes. Evidence about all-cause mortality is presented last. We also address differences of effects by subgroups and by the timing of the intervention, when such data were available. Appendix F presents results of individual trials for each outcome in more detail. Although data from the four trials that did not stratify results by treatment regimen were not analyzed in our main analyses, they are included in Tables 1, 3, 4, 10, 13, 14, 15, 16, 17, 19, and 21 in Appendix F.^93,^ ^105–107^ In Appendix G, we present HRs for outcomes with results from three or more time points, and in Appendix H, we present meta-analyses. We present eligible observational studies in Appendix I. In Appendix J, we present literature addressing the contextual question on differences in hormone therapy use by subgroups. We did not find any evidence addressing the contextual question on average duration of hormone therapy use in women who initiate its use for the treatment of menopausal symptoms.

Because the two WHI trials were the largest studies, we summarize results on outcomes of interest at the end of the intervention phase of the WHI trials according to treatment (estrogen only or estrogen plus progestin) in Table 6. In the sections that follow, effect estimates are based on meta-analyses of included trials or, if meta-analyses were not feasible, based on results from the largest and most reliable trial (usually the WHI). Furthermore, the same trial (e.g., WHI) may have reported a different sample size for different outcomes because of differences in missing baseline or followup data across the many various outcomes reported.

Table 6 Results of WHI at the End of the Intervention Phase, by Category and Subcategory of Outcome

Outcome^*^,^†^ | Estrogen Only^‡^ vs. Placebo^§^ | Estrogen Plus Progestin^‡^ vs. Placebo^‖^
Outcome^*^,^†^ | Hazard Ratio; (95% CI) | Hazard Ratio; (95% CI)
Cancer
Breast (invasive) | 0.79 (0.61 to 1.02)^67,^ ^108^ | 1.24 (1.01 to 1.53)^67^
Cervical | Not reported | 1.44 (0.47 to 4.42)^126^
Colorectal | 1.15 (0.81 to 1.64)^67^ | 0.62 (0.43 to 0.89)^67^
Endometrial | Not reported | 0.83 (0.49 to 1.40)^67^
Lung | 1.05 (0.74 to 1.49)^67^ | 1.05 (0.76 to 1.45)^67^
Non-Hodgkin’s lymphoma | 0.89 (0.56 to 1.42)^96^ | 0.81 (0.51 to 1.29)^96^
Ovarian | Not reported | 1.41 (0.75 to 2.66)^67^
Cardiovascular disease
Cardiovascular events (all) | 1.11 (1.01 to 1.22)^67^ | 1.13 (1.02 to 1.25)^67^
Coronary heart disease | 0.95 (0.79 to 1.16)^117^ | 1.18 (0.95 to 1.45)^67^
Cognitive functioning and dementia^¶^
Mild cognitive impairment | 1.34 (0.95 to 1.89)^119^ | 1.07 (0.74 to 1.55)^143^
Probable dementia | 1.49 (0.83 to 2.66)^119^ | 2.05 (1.21 to 3.48)^143^
Diabetes
Self-reported new diagnosis requiring treatment with drugs | 0.86 (0.76 to 0.98)^67^ | 0.81 (0.70 to 0.94)^67,^ ^126^
Fractures
Total fractures | 0.72 (0.64 to 0.80)^67^ | 0.76 (0.69 to 0.83)^67^
Gallbladder events | 1.67 (1.35 to 2.06)^127^ | 1.59 (1.28 to 1.97)^127^
Gallbladder disease | 1.55 (1.34 to 1.79)^67^ | 1.57 (1.36 to 1.80)^67^
Cholecystectomy | 1.93 (1.52 to 2.44)^127^ | 1.67 (1.32 to 2.11)^127^
Peripheral arterial disease
Overall peripheral arterial disease | 1.35 (0.97 to 1.88)^79^ | 0.89 (0.60 to 1.32)^80^
Urinary incontinence (stress, urge, or mixed)
Overall urinary incontinence | 1.61 (1.46 to 1.79)^67^ | 1.49 (1.36 to 1.63)^67^
Stroke | 1.35 (1.07 to 1.70)^67^ | 1.37 (1.07 to 1.76)^67^
Thromboembolic events
Deep vein thrombosis | 1.48 (1.06 to 2.07)^67^ | 1.87 (1.37 to 2.54)^67^
Pulmonary embolism | 1.35 (0.89 to 2.05)^67^ | 1.98 (1.36 to 2.87)^67^
Mortality
All-cause mortality | 1.04 (0.89 to 1.22)^67,^ ^178^ | 0.97 (0.81 to 1.16)^88,^ ^132^
Total cancer mortality | 0.96 (0.75 to 1.22)^88^ | 1.10 (0.86 to 1.42)^88^

* Assumes a constant rate of events across the study period, although rates varied depending on outcome (e.g., thromboembolic events occurred early during therapy, cancer cases later).

† HRs not reported for quality of life.

‡ Intervention dosages are listed in Table 3 by trial.

§ Followup periods for all estrogen-only outcomes are 7.1 years except for fractures, 7.2 years; dementia, 5.2 years; and urinary incontinence, 1 year.

‖ Followup periods for all estrogen plus progestin outcomes are 5.6 years except for dementia, 4 years; and urinary incontinence, 1 year.

¶ Results from the WHIMS trial, a subset of the WHI trial, limited to women ages 65 to 79 years at baseline, free of probable dementia, and recruited from 39 of 40 WHI trial centers. Participants in WHIMS Estrogen only were followed for approximately 5.2 years and in WHIMS Estrogen and Progestin for approximately 4 years.

Abbreviations: CI=confidence interval; HR=hazard ratio; WHI=Women’s Health Initiative; WHIMS=Women’s Health Initiative Memory Study.

### Estrogen Only: Cancer

#### Breast Cancer

##### Benefits and Harms of Hormone Therapy

Four RCTs (WHI [N=10,739],^37,^ ^67,^ ^87–91,^ ^95,^ ^101,^ ^108–111^ Estrogen in the Prevention of Atherosclerosis [EPAT] [N=222],^112^ Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis [ERA] [N=205],^113^ and Postmenopausal Estrogen and Progestin Interventions Trial [PEPI] [N=349]^32^) comparing estrogen only with placebo reported on breast cancer incidence (Appendix F Table 1). We did not pool trial results, primarily because of heterogeneity in study duration and definitions of breast cancer incidence.

Only the WHI followed women for more than 3 years and reported on risk of invasive breast cancer (vs. any breast cancer). In the WHI, the decrease in invasive breast cancer risk among women assigned to estrogen alone compared with placebo during the 7.2-year (median) intervention phase (2.0% vs. 2.5%; HR, 0.79 [95% CI, 0.61 to 1.02]) was not statistically significant.^67,^ ^108^ The risk reduction became statistically significant during cumulative (trial and postintervention phase) followup (median 13 years: HR, 0.79 [95% CI, 0.65 to 0.97];^67^ median 20.7 years: HR, 0.78 [95% CI, 0.65 to 0.93]^87^). Appendix G Figure 1 presents HRs for invasive breast cancer at different followup periods of the WHI. The three other trials reported on any breast cancer incidence over 2 to 3 years, and results were inconclusive.^32,^ ^112,^ ^113^ Only four cases of breast cancer were reported across the trials (2 cases each in the estrogen-only and placebo groups).

Only the WHI reported on breast cancer mortality. During the 7.2-year intervention period, breast cancer mortality between the estrogen-only and the placebo group did not differ statistically significantly (HR, 0.45 [95% CI, 0.14 to 1.46]).^88^ During cumulative followup at 17.7 years (HR, 0.55 [95% CI, 0.33 to 0.92])^88^ and 20.7 years (HR, 0.60 [95% CI, 0.37 to 0.97]),^87^ however, women who received only estrogen during the intervention phase had statistically significantly lower risk of breast cancer mortality than women who were in the placebo group. Appendix G Figure 2 presents HRs for breast cancer mortality at different followup periods of the WHI.

##### Differences in Treatment Effects Based on Subgroups

In the WHI, no difference in risk for invasive breast cancer or breast cancer mortality by subgroups based on age,^67,^ ^87,^ ^88,^ ^91^ race,^87,^ ^95^ or oophorectomy status^89^ could be detected.

##### Differences in Treatment Effects Based on Timing of the Intervention

Risk of invasive breast cancer in the WHI trial was similar in women who initiated estrogen soon after menopause (<5 years) vs. later (≥5 years).^110^ During the 20.7-year cumulative followup, the risk remained similar.^87^

#### Cervical Cancer

We found no studies reporting cervical cancer incidence outcomes among women who received estrogen-only hormone therapy.

#### Colorectal Cancer

##### Benefits and Harms of Hormone Therapy

One trial (WHI [N=10,739]) estimated the incidence of colorectal cancer among 5,310 women with previous hysterectomy who received estrogen-only hormone therapy and 5,429 women with previous hysterectomy who received placebo (Appendix F Table 3).^37,^ ^67,^ ^108,^ ^110,^ ^114^

During the WHI intervention phase, 1.2 percent of women who received estrogen-only hormone therapy and 1.1 percent of women who received placebo developed colorectal cancer (HR, 1.15 [95% CI, 0.81 to 1.64]).^67^ Similarly, in the postintervention phase (median 6.6 years) and cumulative followup (median 13.0 years), there were no significant differences in colorectal cancer incidence among women receiving estrogen-only hormone therapy vs. placebo (HR, 1.10 [95% CI, 0.68 to 1.78] and HR, 1.13 [95% CI, 0.85 to 1.51], respectively).^67^

We identified one prospective cohort study with data on 85,734 postmenopausal women who have ever or never used hormone therapy (Appendix F Table 3).^103^ During 16 years of followup, there were fewer cases of colorectal cancer among those who had ever taken estrogen-only therapy compared with those who had never used hormone therapy. Risk of colorectal cancer among ever and current users of estrogen-only therapy in this study was statistically significantly lower compared with never users (HR, 0.85 [95% CI, 0.76 to 0.94] and HR, 0.77 [95% CI, 0.66 to 0.89], respectively).

One publication of the WHI estrogen-only trial examined colorectal cancer mortality at the completion of the intervention phase (7.2 years’ followup), the postintervention phase (10.8 years’ followup), and cumulative followup at 17.7 years.^88^ Colon cancer mortality did not differ statistically between treatment groups at any of the followup times (HR, 0.98 [95% CI, 0.50 to 1.95], HR, 1.36 [95% CI, 0.79 to 2.34], and HR, 1.21 [95% CI, 0.79 to 1.84] at each respective followup time).^88^

##### Differences in Treatment Effects Based on Subgroups

In the WHI intervention phase, there was a statistically significant trend toward higher risk of developing colorectal cancer in older women compared with younger women, relative to women taking placebo (p=0.02). Among women ages 50 to 59 years and 60 to 69 years at randomization, there were no statistically significant differences in the risk of colorectal cancer between women taking estrogen-only hormone therapy and placebo (HR, 0.71 [95% CI, 0.30 to 1.67] vs. HR, 0.88 [95% CI, 0.53 to 1.47], respectively). The risk of colorectal cancer among women ages 70 to 79 years was significantly higher for those taking estrogen-only therapy than for those taking placebo (HR, 2.24 [95% CI, 1.16 to 4.30]). The significant interaction with age at randomization was no longer present after a median cumulative followup of 13.0 years^67^ or 18.0 years.^91^

The WHI did not detect any statistically significant subgroup effects regarding race/ethnicity, diabetes status, previous use of menopausal hormone therapy, or bilateral oophorectomy status after a mean of 7.1 years.^114^ Additionally, there were no differences by race^95^ at cumulative followup of 13.0 years, nor oophorectomy status at cumulative followup of 18.0 years.^89,^ ^91^

For the outcome of colon cancer mortality, there were no differences by age after the intervention and postintervention phases.^88^ However, after cumulative followup of 17.7 years, higher colon cancer mortality was observed in older women (ages 70 to 79: HR, 2.13 [95% CI, 1.10 to 4.12]) compared with younger women (ages 50 to 59: HR, 0.65 [95% CI, 0.21 to 2.00]; ages 60 to 69: HR, 0.81 [95% CI, 0.41 to 1.60]) (p=0.03).^88^

##### Differences in Treatment Effects Based on Timing of the Intervention

No statistically significant differences in incidence of colorectal cancer emerged between women who received estrogen-only hormone therapy and those who received placebo according to years since menopause (i.e., <10 years, 10 to <20 years, and ≥20 years since menopause) in the WHI.^67^ The effect of hormone therapy on the risk of invasive colorectal cancer did not differ significantly between women who initiated hormone therapy within the first 5 years after menopause and those who initiated combined hormone therapy after 5 years following menopause.^110^

#### Endometrial Cancer

##### Benefits and Harms of Hormone Therapy

Four trials (ERA [N=205],^113^ EPAT [N=222],^112^ PEPI [N=349],^32^ and Ultra-Low-Dose Transdermal Estrogen Assessment [ULTRA] [N=417]^115^) provided data on endometrial cancer incidence among women who received estrogen-only hormone therapy or placebo. We present results in Appendix F Table 4 but do not discuss them here because of the well-known risk of endometrial hyperplasia and cancer associated with unopposed estrogen use.

##### Differences in Treatment Effects Based on Subgroups

A large, retrospective Danish cohort study assessed the risk of endometrial cancer with hormone therapy during an average followup time of 9.8 years reported no statistically significant differences in risk of endometrial cancer among women based on age, hypertension, or diabetes.^102^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Lung Cancer

##### Benefits and Harms of Hormone Therapy

One trial (WHI [N=10,739]) estimated the incidence of lung cancer among 5,310 women with previous hysterectomy who received estrogen-only hormone therapy and 5,429 women with previous hysterectomy who received placebo (Appendix F Table 5).^67,^ ^116^

Only 1.2 percent of women who received estrogen-only hormone therapy and 1.1 percent of women who received placebo developed lung cancer during the WHI intervention phase over a median followup period of 7.2 years (HR, 1.05 [95% CI, 0.74 to 1.49]).^67^ During the postintervention followup period (mean duration 6.8 years) and cumulative followup (median 13.0 years), the risk between treatment groups remained similar.^67^ Appendix G Figure 3 presents HRs for incident lung cancer at different followup periods of the WHI.

The WHI also reported lung cancer mortality after followup of 7.9 years. There was no difference in lung cancer mortality between estrogen-only and placebo groups (HR, 1.17 [95% CI, 0.81 to 1.69]).^116^

##### Differences in Treatment Effects Based on Subgroups

The WHI reported no statistically significant differences in risk of lung cancer incidence among women based on age at randomization^67^ or in lung cancer mortality among women based on age, race, or ethnicity.^116^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Non-Hodgkin’s Lymphoma

##### Benefits and Harms of Hormone Therapy

One trial (WHI [N=10,685]) evaluated the incidence of non-Hodgkin’s lymphoma among women who received either estrogen-only hormone therapy or placebo (Appendix F Table 6).^96^ The incidence of non-Hodgkin’s lymphoma did not differ significantly between groups during the 7.2-year intervention phase (HR, 0.89 [95% CI, 0.56 to 1.42]).^96^ Risk remained similar during a median cumulative followup of 12.9 years (HR, 1.02 [95% CI, 0.74 to 1.39]). Eighty women who received estrogen and 80 women who received placebo developed non-Hodgkin’s lymphoma during this cumulative followup period.^96^

##### Differences in Treatment Effects Based on Subgroups

We found no evidence about differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Ovarian Cancer

##### Benefits and Harms of Hormone Therapy

No eligible RCTs reported on incidence of ovarian cancer (Appendix F Table 7). However, we identified one prospective cohort study with data on 7,166 postmenopausal Black women who have taken estrogen-only therapy or have never used hormone therapy.^104^ During 18 years of followup, there were fewer cases of ovarian cancer among those who had ever taken estrogen-only therapy compared with those who had never used hormone therapy (0.7% vs. 1.3%), although the difference in risk was not statistically significant (HR, 1.66 [95% CI, 0.90 to 3.07]).

##### Differences in Treatment Effects Based on Subgroups

We found no evidence about differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Total Cancer Mortality

##### Benefits and Harms of Hormone Therapy

Only the WHI reported total cancer mortality (N=10,739, Appendix F Table 8).^67,^ ^88^ Death by any cancer was similar between the estrogen-only and placebo groups during the 7.2-year intervention phase (0.33% annualized vs. 0.34% annualized; HR, 0.96 [95% CI, 0.75 to 1.22]), as well as at various postintervention and cumulative followup. Appendix G Figure 4 presents available HRs for total cancer mortality for different followup periods of the WHI trial.

##### Differences in Treatment Effects Based on Subgroups

The WHI reported no statistically significant differences in risk of lung cancer incidence among women based on age or oophorectomy status.^67,^ ^88,^ ^89^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

### Estrogen Only: Other Chronic Conditions

#### COPD

##### Benefits and Harms of Hormone Therapy

No eligible studies reported on COPD incidence. The WHI [N=10,739]^88^) was the only trial that provided information about the prevention of COPD mortality with estrogen only (Appendix F Table 9). COPD mortality was measured at multiple time points and identified via data linkage to the U.S. National Death Index (NDI). Women assigned to estrogen alone had a similar risk of COPD mortality compared with placebo during the 7.2-year (median) intervention phase (HR, 0.76 [95% CI, 0.26 to 2.20]). The risk remained similar during a 10.8-year (median) postintervention followup (HR, 1.09 [95% CI, 0.79 to 1.51]) and 17.7-year (median) cumulative followup (HR, 1.07 [95% CI, 0.78 to 1.45]). Appendix G Figure 5 presents HRs for COPD mortality at different followup periods of the WHI.

##### Differences in Treatment Effects Based on Subgroups

In the WHI, no difference in risk of COPD mortality by subgroups based on age at randomization (in age bands 50 to 59 years, 60 to 69 years, or 70 to 79 years) could be detected during the 7.2-year (median) intervention phase.^88^ However, women ages 50 to 59 years at randomization who had been assigned to estrogen only experienced a statistically significant reduction in risk compared with placebo at the 10.8-year (median) postintervention followup (4 vs. 16 events; HR, 0.24 [95% CI, 0.08 to 0.73]). This risk reduction among women ages 50 to 59 years persisted at the 17.7-year (median) cumulative followup (6 vs. 17 events; HR, 0.35 [95% CI, 0.14 to 0.88]). These findings, however, need to be viewed cautiously because only 20 and 23 women, respectively, in the 50- to 59-year-old age group had died of COPD at these two followup periods.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Coronary Heart Disease

##### Benefits and Harms of Hormone Therapy

Four trials (EPAT [N=222],^112^ PEPI [N=349],^32^ WHI [N=10,739],^117^ and ERA [N=205]^113^) provided data on the risk of coronary heart disease in women who used estrogen only (Appendix F Table 10).

Of these, three trials (EPAT,^112^ PEPI,^32^ and WHI^117^) were similar enough to be combined in a meta-analysis (Appendix H Figure 1). We did not include the ERA study in the meta-analysis because only women with an elevated cardiovascular risk were eligible for enrollment.^113^ Studies in the meta-analysis provide information about the prevention of coronary heart disease with estrogen only based on data for 11,310 women who had previously undergone hysterectomy. Treatment duration ranged from 2 to 7.2 years. The WHI and EPAT trials defined coronary heart disease as nonfatal myocardial infarction or coronary death;^112,^ ^117^ the definition used in the PEPI trial was unclear.^32^ A meta-analysis of these three trials, which was limited by the domination of the WHI (i.e., contributed 99% of events), rendered no statistically significant difference in coronary events between women taking estrogen therapy and those taking placebo (RR, 0.95 [95% CI, 0.79 to 1.14]). In the meta-analysis, 3.6 percent of women receiving estrogen-only therapy and 4.0 percent of those receiving placebo experienced coronary heart disease during a mean followup of 4.1 years. A sensitivity analysis including the ERA trial rendered similar results.

A postintervention followup study of the WHI reported that 3.9 years after stopping the randomized treatment, the risk for coronary heart disease was still similar between women who received hormone therapy during the trial and those who were randomized to placebo (HR, 0.97 [95% CI, 0.75 to 1.25]).^108^ Risk remained similar between treatment groups at 13 and 19.4 years of cumulative followup (HR, 0.94 [95% CI, 0.82 to 1.09] and HR, 0.97 [95% CI, 0.86 to 1.09], respectively).^67,^ ^101^ Appendix G Figure 6 presents available HRs for coronary heart disease for different followup periods of the WHI trial.

Only the WHI reported mortality due to coronary heart disease. Death from coronary heart disease was similar between the estrogen-only and placebo groups during the 7.2-year intervention phase (66 vs. 67 events), at 10.8 years postintervention (174 vs. 210 events), and after 17.7 years of cumulative followup (240 vs. 277 events).^88^ Appendix G Figure 7 presents available HRs for coronary heart disease mortality for different followup periods of the WHI trial.

##### Differences in Treatment Effects Based on Subgroups

In the WHI trial, no statistically significant difference in risk of coronary heart disease attributable to hormone therapy could be detected between subgroups based on race/ethnicity, age, diabetes, hypertension, high cholesterol requiring medication, coronary risk factors, and years since bilateral oophorectomy.^52,^ ^67,^ ^117^ Although risk for coronary heart disease in women taking estrogen-only therapy increased numerically with age, this trend did not reach statistical significance.^67^ The HR for women ages 50 to 59 years was 0.60 (95% CI, 0.35 to 1.04) in favor of hormone therapy. By comparison, the HRs for women ages 60 to 69 years and 70 to 79 years at baseline were 0.95 (95% CI, 0.72 to 1.24) and 1.09 (95% CI, 0.80 to 1.49), respectively (p=0.08). Analyses that focused just on myocardial infarction yielded a statistically significant trend for increasing risk by age (comparing ages 50 to 59, 60 to 69, and 70 to 79 years), with more favorable effects among younger women (p=0.02).^67^ These findings, however, need to be viewed cautiously because only 48 women in the 50- to 59-year-old age group experienced a myocardial infarction.^67^ No differences in coronary heart disease mortality between treatments were detected by subgroups based on age or by oophorectomy status within any age group.^88,^ ^89^

##### Differences in Treatment Effects Based on Timing of the Intervention

In the WHI, time since menopause did not have a statistically significant effect on the risk of coronary heart disease.^67^ Likewise, an analysis of WHI data that took the first use of hormone therapy (before enrollment into the WHI) into consideration to assess the effect of timing of hormone therapy did not find an effect of early initiation on the risk of coronary heart disease (p=0.40).^110^

#### Peripheral Arterial Disease

##### Benefits and Harms of Hormone Therapy

The WHI [N=10,739]^79^ was the only trial that provided information about peripheral arterial disease with estrogen only (Appendix F Table 11). Peripheral arterial disease was defined as incident carotid artery disease, abdominal aortic aneurysm, or lower extremity arterial disease. In participants who did not have coronary heart disease or peripheral arterial disease at baseline, women assigned to estrogen alone had a similar risk of developing peripheral arterial disease compared with placebo during the 7.1-year (median) intervention phase (HR, 1.35 [95% CI, 0.97 to 1.88]).

##### Differences in Treatment Effects Based on Subgroups

In the WHI, no difference in risk of incident peripheral arterial disease by subgroups based on age, ethnicity, diabetes, or body mass index could be detected during the 7.1-year (median) intervention phase.^79^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Cognitive Functioning and Dementia

##### Benefits and Harms of Hormone Therapy

Dementia and mild cognitive impairment incidence. The WHI trials evaluated the incidence of dementia or mild cognitive impairment (Appendix F Table 12). The Women’s Health Initiative Memory Study (WHIMS) trial (N=2,947), a subset of the WHI trial, was limited to women ages 65 to 79 years at baseline, free of probable dementia, and recruited from 39 of 40 WHI trial centers. Participants in WHIMS were followed for approximately 5.2 years. Women’s Health Initiative Study of Cognitive Aging (WHISCA), an ancillary study (N=434 in the estrogen arm, N=452 in the placebo arm) of the WHIMS trial, began 3 years after the start of the WHI and WHIMS trials; was limited to 14 of 39 trial centers; and was designed to evaluate changes in more detailed, domain-specific cognitive functioning over time.^118^ Participants in WHISCA were followed for approximately 2.7 years during the WHISCA trial. Neither WHIMS nor WHISCA found an elevated risk of probable dementia among women taking hormone therapy; likewise, both studies found no difference in mild cognitive impairment between women taking hormone therapy vs. placebo.^119,^ ^120^ When using a composite outcome measure of probable dementia or mild cognitive impairment, the WHIMS study found a statistically significantly higher risk among women taking estrogen-only therapy compared with women taking placebo (6.4% vs. 4.7%; cumulative HR, 1.38 [95% CI, 1.01 to 1.89]).^119^

The WHI estrogen-only trial (n=10,739) evaluated Alzheimer’s disease or other dementia mortality following the intervention phase (median 7.2 years), postintervention phase (median 10.8 years), and cumulative followup of 17.7 years (median).^88^ There was no difference in dementia-related mortality at the end of the intervention phase (5 vs. 6 deaths). However, participants randomized to estrogen were less likely to have dementia-related mortality compared with the placebo group at postintervention followup at 10.8 years (122 vs. 169; HR, 0.73 [95% CI, 0.58 to 0.92]) and cumulative followup (127 vs. 175; HR, 0.74 [95% CI, 0.59 to 0.94]).^88^ Appendix G Figure 8 presents available HRs for dementia-related mortality for different followup periods of the WHI estrogen-only trial.

Global cognitive function. Four trials (WHIMS [N=4,344],^121^ WHISCA [N=1,213],^122^ Women’s Health Initiative Memory Study of Younger Women [WHIMSY] [N=1,326],^123^ and ULTRA [N=417]^124^) measured global cognitive functioning using the Modified Mini-Mental State (3MSE) examination or the Telephone Interview for Cognitive Status-modified (TICS-m); heterogeneity in timing precluded meta-analysis (Appendix F Table 13). The WHIMS and WHISCA trials are described above. The WHIMSY trial, an extension of the WHI trial, was limited to 1,326 enrolled active participants in treatment or placebo arms in the WHI trials who were ages 50 to 55 years at enrollment and agreed to be contacted for recruitment (N by treatment regimen not reported); women in this extension were followed for 7.2 years after the end of the trials.^123^ The ULTRA trial randomized women to estrogen only or placebo transdermal patches, with all participants receiving 400 mg of calcium twice daily and 400 IU of vitamin D once daily.^124^ The ULTRA trial followed participants for 2 years. The WHI trials found larger cognitive deficits among the intervention group (change in 3MSE score at 3.6 years during the WHISCA trial, −0.092; p=0.02;^122^ change in 3MSE score at 5.4 years at the end of the WHIMS trial, −0.26 [95% CI, −0.52 to 0.00]; p=0.04^121^). In a long-term extension of the WHISCA trial, with outcomes measured at 2.4 years after stopping therapy, these differences were not sustained.^122^ The ULTRA and WHIMSY studies found no differences.^123,^ ^124^

Other cognitive measures. Four trials (WHISCA [N=1,213],^120,^ ^122^ WHIMSY [N=1,326],^123^, Early vs. Late Intervention Trial with Estradiol, Cognitive Endpoints [ELITE-Cog] [N=643],^92^ and ULTRA [N=417]^124^) evaluated other measures of cognitive functioning (e.g., spatial ability, verbal knowledge, verbal fluency, verbal memory, figural memory, attention, and working memory); heterogeneity in outcome measures precluded meta-analysis (Appendix F Table 13). The WHISCA, WHIMSY, and ULTRA trials are described above. ELITE-Cog examined differences in cognitive changes for women enrolled in the ELITE trial, which was designed to test the timing hypothesis.^92^ All four trials found no differences between women receiving estrogen only or placebo for the majority of outcomes.

##### Differences in Treatment Effects Based on Subgroups

The WHIMS study reported no difference in risk for probable dementia by race/ethnicity or history of diabetes, stroke, hypertension, or cardiovascular disease.^119^ There were no differences in other measures of cognitive function (i.e., change in verbal memory, executive function, or global cognition) by women experiencing surgical vs. natural menopause in the ELITE-Cog study.^92^ The WHI study reported no difference in risk for dementia-related mortality by age.^88^

##### Differences in Treatment Effects Based on Timing of the Intervention

In the ELITE-Cog study, there were no differences in treatment effects on other cognitive measures (i.e., change in verbal memory, executive function, or global cognition) based on timing of the intervention.^92^

#### Diabetes

##### Benefits and Harms of Hormone Therapy

The WHI (N=9,917)^67,^ ^125^ was the only trial that reported on the incidence of diabetes among women not receiving treatment for diabetes at baseline (Appendix F Table 14). Incident diabetes was self-reported and defined as a new diagnosis of diabetes by a physician followed by treatment with oral hypoglycemic drugs or insulin.^125^

During a median of 7.2 years of followup, 1.34 percent (annualized) of women receiving estrogen therapy and 1.55 percent (annualized) of those receiving placebo reported a new diabetes diagnosis. The difference in risks between these groups reached statistical significance (HR, 0.86 [95% CI, 0.76 to 0.98]).^67^ The overall reduction in diabetes risk was no longer observed 6.6 years postintervention (HR, 1.07 [95% CI, 0.92 to 1.25]) or after 13.0 years of cumulative followup (HR, 0.94 [95% CI, 0.85 to 1.04]).^67^ Appendix G Figure 9 presents hazard ratios for incident diabetes at different followup periods of WHI.

##### Differences in Treatment Effects Based on Subgroups

A test for interaction did not detect any statistically significant subgroup effects with respect to race/ethnicity, age at screening, hypertension, or metabolic syndrome at baseline among women in the WHI estrogen-only trial.^125^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Fractures

##### Benefits and Harms of Hormone Therapy

Two trials (the WHI [N=10,739]^67^ and ERA [N=205]^113^) provided information on preventing fractures with estrogen-only therapy among 10,944 women (Appendix F Table 15). The WHI found a reduced risk of total fractures in the estrogen-only arm compared with placebo during the 7.2-year intervention phase (1.53% annualized vs. 2.14% annualized; HR, 0.72 [95% CI, 0.64 to 0.80])^67^ and after 4.3 years of postintervention followup (3.11% annualized vs. 3.69% annualized; HR, 0.85 [95% CI, 0.73 to 0.98]).^97^ The ERA trial randomized women to the same treatment regimen as the WHI and followed them for 3.2 years. The study found fewer fractures at all sites in the estrogen-only arm (6.0% vs. 14.3%), but the difference was not statistically significant (calculated RR, 0.42 [95% CI, 0.17 to 1.04]).^113^ Appendix G Figure 10 presents effect estimates for total fractures at different followup periods of the WHI and the ERA.

##### Differences in Treatment Effects Based Subgroups

Tests for interaction did not detect any statistically significant subgroup effects with respect to age^67,^ ^89,^ ^91,^ ^97,^ ^108,^ ^126^ among women in the WHI estrogen-only trial.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects for total fractures based on timing of the intervention.

#### Gallbladder Disease

##### Benefits and Harms of Hormone Therapy

Two trials (PEPI [N=349]^32^ and WHI [N=8,376]^67,^ ^127^) provided information about the prevention of gallbladder disease with estrogen only based on data for 8,725 women with gallbladders and without gallbladder disease (Appendix F Table 16). Treatment duration was 3.0 years among women in PEPI and an average of 7.1 years among those in the WHI. The definition of gallbladder disease used in PEPI is unclear; for WHI, global gallbladder disease was a self-reported endpoint that included all acute or chronic gallbladder inflammation and all gallbladder or biliary tract stone disease.^32,^ ^67,^ ^127^ Gallbladder procedures, including biliary tract procedures such as cholecystectomy, were also reported for women in the WHI.^127^

The larger of the two trials, WHI, reported global gallbladder disease after 7.1 years of treatment for 1.64 percent (annualized) of women receiving estrogen therapy and 1.06 percent (annualized) of those taking placebo.^67^ The difference in global gallbladder disease between these groups was statistically significant (HR, 1.55 [95% CI, 1.34 to 1.79]).^67^ However, the risk of gallbladder disease was no longer significant 6.6 years postintervention (HR, 0.98 [95% CI, 0.68 to 1.41]).^67^

The PEPI trial had few cases of gallbladder disease and reported inconclusive results.^32^

##### Differences in Treatment Effects Based on Subgroups

The risk of gallbladder events attributable to estrogen therapy among women in the WHI increased with age but did not reach statistical significance.^127^ No other evidence is available in the included studies on subgroups of interest.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Stroke

##### Benefits and Harms of Hormone Therapy

Three trials (WHI [N=10,739],^67,^ ^88,^ ^101,^ ^108^ EPAT [N=222],^112^ and ERA [N=205]^113^) reported on risk of stroke (Appendix F Table 17). We did not pool trial results because of heterogeneity in study duration and outcome measures.

During the WHI 7.2-year intervention phase, women receiving estrogen only had a statistically significantly higher risk of stroke compared with those receiving placebo (3.2% vs. 2.4%; HR, 1.35 [95% CI, 1.07 to 1.70]).^67^ During the postintervention period (3.9 years after stopping therapy), the risk between the two treatment groups was similar.^108^ Cumulatively across the intervention and postintervention periods (19.4 years of followup), stroke risk was not significantly different between the estrogen-only and placebo groups (7.5% vs. 7.2%; HR, 1.06 [95% CI, 0.92 to 1.22]).^101^ Appendix G Figure 11 presents available HRs for stroke for different followup periods of the WHI trial.

The two smaller trials (EPAT^112^ and ERA)^113^ also reported on stroke risk among women randomized to estrogen or placebo; however, few events occurred overall and results were inconclusive. In the EPAT trial, one participant (randomized to placebo) had a cerebrovascular accident at 2 years.^112^ In the ERA trial, the risk of stroke or transient ischemic attack was similar in the estrogen-only and placebo groups (5 vs. 6 events, respectively).^113^

Only the WHI reported stroke mortality. Death from stroke was similar between the estrogen-only and placebo groups during the 7.2-year intervention phase (23 vs. 24 events, respectively).^88^ Stroke mortality remained similar between the two groups during the postintervention period (10.8 years after stopping therapy) and during cumulative followup (17.7 years of followup).^88^

##### Differences in Treatment Effects Based on Subgroups

In the WHI estrogen-only trial, no differences in stroke risk between treatments were detected by subgroups, including those based on race/ethnicity, age, prior cardiovascular disease, diabetes, hypertension, or oophorectomy status within any age group.^128^ No differences by age were detected in risk for death from stroke.^88^

##### Differences in Treatment Effects Based on Timing of the Intervention

The risk of stroke in the WHI was similar among women who initiated estrogen soon after menopause (<5 years) vs. later (≥5 years).^110^

#### Urinary Incontinence

##### Benefits and Harms of Hormone Therapy

Two trials (WHI [N=5,644 continent]^67^ and ULTRA [N=239 continent]^129^) provided results on incident urinary incontinence (self-reported). The WHI followed continent women through 1 year of intervention and then evaluated incontinence at study closeout (i.e., median followup of 6.6 years postintervention). The ULTRA study followed participants for 2 years.^124^ Both studies defined urinary incontinence as at least one episode weekly.^67,^ ^129^ The WHI also evaluated various subtypes of urinary incontinence.^130^ Detailed results can be found in Appendix F Table 18.

The WHI found a higher risk of urinary incontinence in the estrogen-only treatment arm at 1 year (22.6% annualized vs. 14.0% annualized; HR, 1.61 [95% CI, 1.46 to 1.79]) and 6.6 years after stopping treatment (28.6% vs. 23.1%; HR, 1.24 [95% CI, 1.13 to 1.35]).^67^ Results from the smaller ULTRA trial at 2 years did not find a statistically significant difference between groups (39.0% vs. 36.8%; odds ratio [OR], 1.2 [95% CI, 0.7 to 2.2]).^129^ Appendix G Figure 12 presents effect estimates for incident weekly urinary incontinence at different followup periods of the WHI and the ULTRA.

##### Differences in Treatment Effects Based on Subgroups

We found no evidence on differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Venous Thromboembolism

##### Benefits and Harms of Hormone Therapy

Three trials (WHI [N=10,739],^67,^ ^101,^ ^108^ EPAT [N=222],^112^ and ERA [N=205]^113^) reported on risk of thromboembolism (Appendix F Table 19). We did not pool trials because of heterogeneity in study duration and outcome measures.

In the WHI, women randomized to estrogen alone had a marginally significant increased risk of venous thromboembolism compared with women receiving placebo during the 7.2-year intervention phase (2.1% vs. 1.6%; HR, 1.32 [95% CI, 1.00 to 1.76]).^101^ Women receiving estrogen alone had an increased risk of deep vein thrombosis compared with placebo that was statistically significant (1.6% vs. 1.0%; HR, 1.48 [95% CI, 1.06 to 2.07]);^67^ the risk of pulmonary embolism was also higher in the estrogen group than in the placebo group, but results were not significant (0.98% vs. 0.72%; HR, 1.35 [95% CI, 0.89 to 2.05]).^67^ After 3.9 years postintervention, women in the estrogen-only group had lower risk of deep vein thrombosis compared with those in the placebo group (HR, 0.63 [95% CI, 0.41 to 0.98]); there was no difference between groups for risk of pulmonary embolism in the postintervention period.^108^ Risks of deep vein thrombosis and of pulmonary embolism were similar in the estrogen-only and placebo groups after 13 years of cumulative followup.^67^ After 19.4 years of cumulative followup, risk of venous thromboembolism overall was similar between the two groups.^101^ Appendix G Figures 13 and 14 present available HRs for deep vein thrombosis and pulmonary embolism, respectively, for different followup periods of the WHI trial.

The EPAT and ERA trials had shorter followup than the WHI (2.0 and 3.2 years, respectively). No venous thromboembolic events were reported in either group in the EPAT trial; in the ERA trial, events were reported for five women receiving estrogen-only therapy and one woman receiving placebo.^112,^ ^113^

##### Differences in Treatment Effects Based on Subgroups

The WHI reported no differences between treatments by subgroups based on race/ethnicity, age, history of cardiovascular disease, or within any age group during the intervention period.^67,^ ^91,^ ^131^ During cumulative followup, risk remained similar by age but not by race.^67,^ ^95^ After 13 years, Black women had a lower risk of venous thromboembolism than White women (HR, 0.63 [95% CI, 0.38 to 1.06] vs. HR, 1.11 [95% CI, 0.88 to 1.39], respectively, p=0.049).^95^

##### Differences in Treatment Effects Based on Timing of the Intervention

The risk of venous thromboembolism or pulmonary embolism specifically in the WHI estrogen-only trial was similar among women who initiated estrogen soon after menopause vs. later.^67,^ ^110^

#### Health-Related Quality of Life

##### Benefits and Harms of Hormone Therapy

The WHI (N=10,739)^67^ was the only trial that reported on health-related quality of life (Appendix F Table 20). It used the Short Form Health Survey (SF-36) form, which assesses physical functioning, physical role, bodily pain, general health, vitality, social functioning, emotional role, and mental health. At post-intervention (mean 7.2 years), women in both groups had similar scores on all items except for emotional role and social functioning, for which women taking placebo had statistically significantly better scores than women taking estrogen-only therapy (p=0.04 and p=0.01, respectively).

##### Differences in Treatment Effects Based on Subgroups

We found no evidence on differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### All-Cause Mortality

##### Benefits and Harms of Hormone Therapy

Three trials (ELITE-Cog [N=643],^92^ ERA [N=205],^113^ and WHI [N=10,739]^67,^ ^88,^ ^101,^ ^108^) provided information about the risk of death from any cause among 11,587 women receiving estrogen therapy (Appendix F Table 21). The treatment duration of these trials ranged from 2 to 7.2 years.^108,^ ^113^ A meta-analysis of these trials, which was limited by the domination of WHI (i.e., contributed 97% of events), rendered no statistically significant difference in all-cause mortality between women receiving estrogen therapy and those receiving placebo (Appendix H Figure 2; RR, 1.04 [95% CI, 0.89 to 1.21]) during a mean followup of 7.1 years.

The WHI, the largest of the three trials, reported an HR of 1.04 (95% CI, 0.89 to 1.22), with deaths among 5.7 and 5.5 percent of women in the active and placebo groups, respectively.^88^ The difference in risk between the two groups remained similar at various postintervention and cumulative followup. Appendix G Figure 15 presents HRs for all-cause mortality at different followup periods of the WHI.

##### Differences in Treatment Effects Based on Subgroups

In the WHI, authors observed a significant trend toward lower risk of death in younger women receiving estrogen therapy compared with older women at postintervention (mean 7.2 years followup) relative to women receiving placebo (p=0.04 for trend).^88^ The HR was 0.71 (95% CI, 0.46 to 1.09) among women ages 50 to 59 years compared with 1.02 (95% CI, 0.80 to 1.30) among women ages 60 to 69 years and 1.22 (95% CI, 0.95 to 1.56) among women ages 70 to 79 years. We found no evidence of differences in treatment effects by age for longer postintervention or cumulative followup except by age among women with oophorectomy after 18 years of cumulative followup (p=0.034).^67,^ ^88,^ ^89,^ ^101^ Further, we found no evidence of differences in treatment effects during cumulative followup by race, by oophorectomy status in the overall sample or prior hormone therapy use, by age at oophorectomy among younger or older women, or by age among women without oophorectomy.^89,^ ^95^

##### Differences in Treatment Effects Based on Timing of the Intervention

The effect of estrogen-only therapy on all-cause mortality did not differ significantly between women who initiated hormone therapy sooner after menopause and those who initiated hormone therapy later.^67,^ ^110^

### Estrogen Plus Progestin: Cancer

#### Breast Cancer

##### Benefits and Harms of Hormone Therapy

Six trials (WHI [N=16,608],^36,^ ^67,^ ^87,^ ^88,^ ^91,^ ^101,^ ^110,^ ^111,^ ^132–135^ Heart and Estrogen/Progestin Replacement Study [HERS] [N=2,763],^136^ PEPI [N=700],^32^ EPHT [N=777],^137^ ERA [N=209],^113^ and WISDOM [N=4,385])^138^ comparing estrogen plus progestin with placebo reported on breast cancer incidence (Appendix F Table 1). We did not pool trial results because of heterogeneity in study duration and outcome measures. Only two trials followed women for more than 4 years (WHI and HERS), and only the WHI reported on the risk of invasive breast cancer (vs. any breast cancer).

During the 5.6-year intervention phase of the WHI, women assigned to estrogen plus progestin had a significantly increased risk of invasive breast cancer compared with women taking placebo (2.4% vs. 1.9%; HR, 1.24 [95% CI, 1.01 to 1.53]).^67^ The risk of invasive breast cancer in women who took estrogen plus progestin remained significantly increased compared with women who took placebo during a median postintervention followup of 8.2 years (HR, 1.32 [95% CI, 1.08 to 1.61])^67^ and during 19.4 years of cumulative (trial and postintervention phase) followup (HR, 1.28 [95% CI, 1.13 to 1.45).^101^ Appendix G Figure 16 presents HRs for invasive breast cancer at different followup periods of the WHI.

In the HERS trial, more women randomized to estrogen plus progestin developed breast cancer during the 4.1-year intervention phase than women receiving placebo, but the results were not statistically significant (2.5% vs. 1.8%; HR, 1.38 [95% CI, 0.82 to 2.31]).^136^ Four other trials also reported any breast cancer incidence but for shorter intervention periods.^32,^ ^113,^ ^137,^ ^139^ In three small trials, few cases occurred overall, and risk of breast cancer incidence was similar between groups randomized to estrogen plus progestin and placebo over approximately 3 years (no cases overall in ERA and 3 vs. 3 cases, respectively, across PEPI and EPHT); few cases of breast cancer were reported overall.^32,^ ^113,^ ^137^ The fourth trial, WISDOM, was stopped after 1 year because of the WHI results that indicated excess breast cancer risk in women receiving estrogen plus progestin; breast cancer incidence was similar between estrogen plus progestin and placebo groups at 1 year (5 vs. 7 cases, respectively).^138^

Only the WHI reported on breast cancer mortality. During the 5.6-year intervention period, breast cancer mortality between the estrogen plus progestin and the placebo groups did not reach statistical significance (HR, 1.08 [95% CI, 0.29 to 4.03]).^88^ During cumulative followup to 20.3 years (median), the risk of breast cancer mortality was numerically higher for women in the estrogen plus progestin than in the placebo group, but the difference did not reach statistical significance (HR, 1.35 [95% CI, 0.94 to 1.95]).^87^ Appendix G Figure 17 presents HRs for breast cancer mortality at different followup periods of the WHI.

##### Differences in Treatment Effects Based on Subgroups

In the WHI estrogen plus progestin trial, incidence of invasive breast cancer did not differ based on age at randomization^67^ or race.^87,^ ^90^ Breast cancer mortality did not differ by age.^88^

##### Differences in Treatment Effects Based on Timing of the Intervention

Risk of invasive breast cancer in the WHI trial was similar in women who initiated estrogen plus progestin soon after menopause (<5 years) vs. later (≥5 years) for most followup periods.^67,^ ^87^ An exception was the 11-year cumulative followup, which showed a higher risk for women who initiated within 5 years of menopause. (p=0.03 for interaction).^110^

#### Cervical Cancer

##### Benefits and Harms of Hormone Therapy

The WHI (N=16,608) evaluated the incidence of cervical cancer among women with an intact uterus who received either estrogen plus progestin or placebo (Appendix F Table 2).^126^ The incidence of cervical cancer did not differ significantly between women who received estrogen plus progestin hormone therapy and women who received placebo (HR, 1.44 [95% CI, 0.47 to 4.42]) during a median followup period of 5.6 years; 0.09 percent of women receiving hormone therapy and 0.06 percent of women receiving placebo were diagnosed with cervical cancer.^126^ WHI investigators did not provide cervical cancer incidence from the postintervention and postintervention extension phases.

##### Differences in Treatment Effects Based on Subgroups

We found no evidence about differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Colorectal Cancer

##### Benefits and Harms of Hormone Therapy

Four trials (WHI [N=16,608],^36,^ ^67,^ ^88,^ ^91,^ ^110,^ ^132,^ ^140^ EMS [N=142],^141^ HERS [N=2,763],^136^ and WISDOM [N=4,385]^138^) reported on the incidence of colorectal cancer (Appendix F Table 3). In the WHI intervention phase, women receiving estrogen plus progestin were less likely to develop colorectal cancer than women in the placebo group (HR, 0.62 [95% CI, 0.43 to 0.89]); 0.59 percent of women in the estrogen plus progestin therapy group and 0.93 percent of women in the placebo group developed colorectal cancer over a median followup period of 5.6 years.^67^ Over the entire median followup period of 13.2 years, the risk of colorectal cancer remained lower in the hormone therapy arm (HR, 0.80 [95% CI, 0.63 to 1.01]) but lost statistical significance.^67^ In the HERS trial, there was a numeric decrease in the risk of colorectal cancer with estrogen plus progestin use (HR, 0.69 [95% CI, 0.32 to 1.49]) over a mean of 4.1 years, which persisted after cumulative followup of a mean of 6.8 years (HR, 0.82 [95% CI, 0.46 to 1.47]).^136^ However, this decrease was not statistically significant at any time point. Appendix G Figure 18 presents HRs of colorectal cancer at different time points in the WHI and HERS trials.

The EMS and WISDOM trials reported no statistically significant differences in risk of colorectal cancer. Event rates in these studies, however, were low (no events in EMS and 4 events in WISDOM), and very short followup time periods (i.e., <2 years) precluded them from being combined with the WHI and HERS trial data in meta-analysis.

We identified one prospective cohort study with data on 85,734 postmenopausal women who had ever or never used hormone therapy (Appendix F Table 3).^103^ During 16 years of followup, there were fewer cases of colorectal cancer among those who had ever taken estrogen plus progestin therapy compared with those who had never used hormone therapy. Risk of colorectal cancer among ever and current users of estrogen plus progestin therapy in this study was statistically significantly lower compared with never users (HR, 0.76 [95% CI, 0.68 to 0.86] and HR, 0.72 [95% CI, 0.62 to 0.84], respectively).

Only the WHI examined colorectal cancer mortality after a median of 5.6 years, 12.5 years, and 17.7 years.^88^ There were no statistically significant differences for women receiving hormone therapy compared with placebo at each respective followup time (HR, 0.87 [95% CI, 0.38 to 1.98]; HR, 1.06 [95% CI, 0.68 to 1.64)]; and HR, 1.01 [95% CI, 0.69 to 1.49]).

##### Differences in Treatment Effects Based on Subgroups

In the WHI intervention phase, the incidence of colorectal cancer did not differ significantly between women who received estrogen plus progestin hormone therapy and women who received placebo according to the following variables: age,^67,^ ^91^ race/ethnicity, and family history of colorectal cancer.^110,^ ^140^ Likewise, there were no statistically significant difference in incidence of colorectal cancer by age after cumulative followup of 13.2 years^67^ and 18.0 years.^91^ For the outcome of colon cancer mortality, there were no statistically significant differences by age between women who received estrogen plus progestin hormone therapy and women who received placebo after the intervention period or cumulative followup of 12.5 years and 17.7 years, respectively.^88^

##### Differences in Treatment Effects Based on Timing of the Intervention

The incidence of colorectal cancer in the WHI did not differ significantly between women who received hormone therapy and women who received placebo according to the number of years since menopause (i.e., <10 years, 10 to <20 years, and ≥20 years) in the WHI intervention phase.^67^ The effect of estrogen plus progestin on the risk of invasive colorectal cancer did not differ significantly between women who initiated hormone therapy within the first 5 years after menopause and those who initiated it after 5 years following menopause.^110^

#### Endometrial Cancer

##### Benefits and Harms of Hormone Therapy

Two trials (WHI [N=16,608]^67,^ ^91,^ ^94^ and HERS^136^ [N=2,763]) estimated the incidence of endometrial cancer among a total of 9,886 women with an intact uterus who received estrogen plus progestin hormone therapy and 9,485 women with an intact uterus who received placebo. In addition, we included one retrospective cohort study^102^ with data on more than 900,000 women (Appendix F Table 4).

In both trials, the incidence of endometrial cancer did not differ significantly between women who received estrogen plus progestin hormone therapy and women who received placebo. During the WHI’s intervention phase (median followup 5.6 years), 0.32 percent of women who received estrogen plus progestin and 0.37 percent of women who received placebo developed endometrial cancer (HR, 0.83 [95% CI, 0.49 to 1.40]).^67^ Likewise, during the HERS trial phase (mean followup 4.1 years), no statistically significant differences in risk could be detected (0.14% vs. 0.36%; HR, 0.39 [95% CI, 0.08 to 2.02]).^136^ Overall, however, only 64 women experienced endometrial cancer in these studies.

A large, retrospective Danish cohort study based on more than 900,000 women between ages 50 and 79 years without hysterectomy assessed the risk of endometrial cancer with hormone therapy during an average followup time of 9.8 years.^102^ The analysis was based on 4,475 cases of endometrial cancer. Compared with women who never used hormone therapy, women with current use of estrogen plus progestin had a statistically significantly higher risk for endometrial cancer (RR, 1.71 [95% CI, 1.58 to 1.86]). A stratification by treatment regimen, however, revealed that a continuous combined estrogen and progestin regimen (which was also used in the WHI) had no increased risk (RR, 1.02 [95% CI, 0.87 to 1.20]); by comparison, a cyclic combined regimen increased the risk to a statistically significant level (RR, 2.06 [95% CI, 1.88 to 1.20]), as did a long cyclic combined regimen (RR, 2.89 [95% CI, 2.27 to 3.67]). No difference in risks could be detected between oral and transdermal use.

During 8.2 years of the WHI postintervention period, statistically significantly fewer women who were randomized to hormone therapy during the trial phase developed endometrial cancer (HR, 0.59 [95% CI, 0.40 to 0.88]) compared with women who had received placebo.^94^ Likewise, when assessing 13.2 years of cumulative followup (i.e., intervention plus postintervention period), the risk for endometrial cancer was lower in women who were on hormone therapy (HR, 0.65 [95% CI, 0.48 to 0.89]).^94^ Appendix G Figure 19 presents the HRs for endometrial cancer over different followup periods.

Two additional trials (ERA [N=209]^113^ and PEPI [N=700]^32^) reported no endometrial cancer cases as adverse events over a period of 3 years; the trials were too small and short in duration to draw inferences on differences in risk or to combine in meta-analysis with the WHI and HERS.

##### Differences in Treatment Effects Based on Subgroups

The WHI reported no significant differences by age at randomization, race, diabetes, or hypertension in the incidence of endometrial cancer between women who received estrogen plus progestin hormone therapy and those who received placebo.^67,^ ^94^ The large Danish retrospective cohort study described above also reported no statistically significant differences in the incidence of endometrial cancer among women based on age, hypertension, or diabetes.^102^

##### Differences in Treatment Effects Based on Timing of the Intervention

The effect of estrogen plus progestin on the risk of invasive endometrial cancer in the WHI did not differ significantly between women who started estrogen plus progestin hormone therapy within the first 5 years after menopause and women who began it after 5 years following menopause.^94,^ ^110^

#### Lung Cancer

##### Benefits and Harms of Hormone Therapy

Two trials (WHI [N=16,608]^67,^ ^142^ and HERS [N=2,763]^136^) estimated the incidence of lung cancer among a total of 9,886 women with an intact uterus who received estrogen plus progestin and 9,485 women with an intact uterus who received placebo (Appendix F Table 5).

In both the WHI and HERS, lung cancer incidence did not differ significantly between women who received estrogen plus progestin and those who received placebo. In the WHI intervention phase (median followup 5.6 years), 0.92 percent of women who received estrogen plus progestin and 0.86 percent of women who received placebo developed lung cancer (HR, 1.05 [95% CI, 0.76 to 1.45]).^67^ In the HERS trial phase (mean followup, 4.1 years), 1.74 percent of women who received estrogen plus progestin and 1.37 percent of women who received placebo developed lung cancer (HR, 1.28 [95% CI, 0.70 to 2.33]).^136^ The risk between groups remained similar during the postintervention followup and cumulative followup in both trials.^67,^ ^136^ Appendix G Figure 20 presents hazard ratios for incident lung cancer at different followup periods of the WHI and HERS.

The WHI trial reported mortality from lung cancer (median followup 14 years) of 0.13 percent of women receiving estrogen plus progestin compared with 0.12 percent of women receiving placebo (HR, 1.09 [95% CI, 0.87 to 1.38]).^98^

A small trial (EMS [N=142]^141^) reported only a single lung cancer case among women receiving estrogen plus progestin and no cases among women receiving placebo during a comparatively short 2-year trial period, precluding it from being combined with the WHI and HERS in meta-analysis.^141^

##### Differences in Treatment Effects Based on Subgroups

In the WHI, no significant differences in the incidence of lung cancer emerged among 10-year age groups at randomization between women who received estrogen plus progestin and women who received placebo.^67^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Non-Hodgkin’s Lymphoma

##### Benefits and Harms of Hormone Therapy

One trial (WHI [N=16,544]) evaluated the incidence of non-Hodgkin’s lymphoma among women who received either estrogen plus progestin hormone therapy or placebo (Appendix F Table 6).^96^ The incidence of non-Hodgkin’s lymphoma did not differ significantly between groups at a median followup of 5.6 years during the intervention phase (HR, 0.81 [95% CI, 0.51 to 1.29]).^96^ Risk remained similar during a median cumulative followup of 13.5 years (HR, 0.98 [95% CI, 0.76 to 1.28]); 113 women who received estrogen plus progestin hormone therapy and 110 women who received placebo developed non-Hodgkin’s lymphoma during this cumulative followup period.^96^

##### Differences in Treatment Effects Based on Subgroups

We found no evidence about differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Ovarian Cancer

##### Benefits and Harms of Hormone Therapy

The WHI (N=16,608) evaluated the incidence of invasive ovarian cancer among women with an intact uterus who received either estrogen plus progestin hormone therapy or placebo (Appendix F Table 7).^67,^ ^126^ The incidence of invasive ovarian cancer did not differ significantly between groups (HR, 1.41 [95% CI, 0.75 to 2.66]); 0.28 percent of women who received estrogen plus progestin and 0.20 percent of women who received placebo developed invasive ovarian cancer over a median followup of 5.6 years during the intervention phase.^67^ Risk remained similar during the postintervention followup (during the 8.2 years after stopping therapy; HR, 1.12 [95% CI, 0.65 to 1.90]).^67^

Further, we identified one prospective cohort study with data on 6,525 postmenopausal Black women who have taken estrogen plus progestin therapy or have never used hormone therapy.^104^ During 18 years of followup, there were fewer cases of ovarian cancer among those who had ever taken estrogen plus progestin therapy compared with those who had never used hormone therapy (0.8% vs. 1.3%), although the difference in risk was not statistically significant (HR, 1.37 [95% CI, 0.73 to 2.55]).

##### Differences in Treatment Effects Based on Subgroups

In the WHI, there were no significant differences in the incidence of invasive ovarian cancer among 10-year age groups at randomization between women who received estrogen plus progestin and those who received placebo.^67^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Total Cancer Mortality

##### Benefits and Harms of Hormone Therapy

Only the WHI reported total cancer mortality (N=16,608, Appendix F Table 8).^67,^ ^88^ Death from any cancer was similar between the estrogen plus progestin and placebo groups during the 5.6-year intervention phase (0.27% annualized vs. 0.24% annualized; HR, 1.10 [95% CI, 0.86 to 1.42]), as well as at various postintervention and cumulative followups.^67,^ ^88^ Appendix G Figure 21 presents available HRs for total cancer mortality for different followup periods of the WHI trial.

##### Differences in Treatment Effects Based on Subgroups

We found no evidence on differences in treatment effects by subgroups based on age for total cancer mortality.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

### Estrogen Plus Progestin: Other Chronic Conditions

#### COPD

##### Benefits and Harms of Hormone Therapy

No eligible studies reported on COPD incidence. The WHI (N=16,608)^88^ was the only trial that provided information about the prevention of COPD mortality with estrogen plus progestin (Appendix F Table 9). COPD mortality was measured at multiple time points and identified via data linkage to the NDI. The WHI found a reduced risk of COPD mortality among women who took estrogen plus progestin compared with those who received placebo during the 5.6-year (median) intervention phase (1 vs. 8 events; HR, 0.12 [95% CI, 0.01 to 0.93]). This finding needs to be viewed cautiously because only nine women had died of COPD by this time point. However, the reduction in risk was no longer observed during a 12.5-year (median) postintervention followup (HR, 1.13 [95% CI, 0.85 to 1.49]) or 17.7-year (median) cumulative followup (HR, 1.03 [95% CI, 0.79 to 1.36]). Appendix G Figure 22 presents HRs for COPD mortality at different followup periods of the WHI.

##### Differences in Treatment Effects Based on Subgroups

In the WHI, no differences in risk of COPD mortality by subgroups based on age at randomization were detected at any phase of followup.^88^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence about differences in treatment effects based on timing of the intervention.

#### Coronary Heart Disease

##### Benefits and Harms of Hormone Therapy

Overall, six trials (EMS [N=142],^141^ EPHT [N=777)],^137^ PEPI [N=700],^32^ WHI [N=16,608],^36^ WISDOM [N=4,385],^138^ and ERA [N=209]^113^) provided information about preventing coronary heart disease with estrogen plus progestin (Appendix F Table 10).

Of these, three trials (EPHT,^137^ PEPI,^32^ and WHI^67^) were similar enough to be combined in a meta-analysis (Appendix H Figure 3). We did not include the ERA study, which enrolled only women with an elevated cardiovascular risk;^113^ the EMS trial^141^ because its definition of cardiovascular events also included deep vein thrombosis and cerebrovascular events; and the WISDOM trial because it had a followup time of only 1 year.^138^ Trials included in the meta-analysis provided data on 18,085 women with treatment durations of 2 to 5.6 years. Results of the meta-analysis showed a numerically higher (but not statistically significant) risk of coronary heart disease in women treated with hormone therapy than in those treated with placebo (2.8% vs. 2.6%; RR, 1.12 [95% CI, 0.94 to 1.33]) during a mean followup of 4 years.

Postintervention followup of women in the WHI showed that 2.4 years after stopping therapy, the risk of coronary heart disease was similar between women who took estrogen plus progestin during the trial and those who received placebo (HR, 1.04 [95% CI, 0.89 to 1.21]).^132^ Risk remained similar between treatment groups at 13 and 19.4 years of cumulative followup (HR, 1.09 [95% CI, 0.96 to 1.24] and HR, 1.05 [95% CI, 0.95 to 1.17], respectively).^67,^ ^101^ Appendix G Figure 23 presents available HRs for coronary heart disease for different followup periods of the WHI trial.

The WISDOM trial was prematurely closed because of findings of the WHI. However, after 1 year of followup (6,498 women-years), women taking estrogen plus progestin had a statistically significantly higher risk of cardiovascular events (0.3% vs. 0.0%; p=0.016) than women taking placebo.^138^

Only the WHI reported mortality due to coronary heart disease. Death from coronary heart disease was similar between the estrogen plus progestin and placebo groups during the 5.6-year intervention phase (40 vs. 40 events), at 12.5 years postintervention (270 vs. 245 events), and after 17.7 years of cumulative followup (310 vs. 285 events).^88^ Appendix G Figure 24 presents available HRs for coronary heart disease mortality for different followup periods of the WHI trial.

##### Differences in Treatment Effects Based on Subgroups

WHI subgroup analyses indicated no significant differences in subgroups based on age.^67^ No differences in coronary heart disease mortality between treatments were detected by subgroups based on age.^88^

##### Differences in Treatment Effects Based on Timing of the Intervention

Subgroup analysis in the WHI indicated that women who had started hormone therapy closer to menopause (within 10 years of menopause) did not have the same elevated risk of coronary heart disease as women who had initiated hormone therapy later.^67^ When the analyses focused just on myocardial infarction, women who initiated estrogen plus progestin therapy closer to menopause did not have the elevated risk of myocardial infarction compared with women who started therapy more than 20 years after menopause (p=0.01). Findings, however, need to be viewed cautiously because only 67 women who initiated hormone therapy within 10 years of menopause experienced a myocardial infarction.^67^

An additional analysis based on WHI data took into consideration the time between menopause and the first use of hormone therapy (before enrollment into the WHI) to assess the effect of timing.^110^ This analysis, therefore, addressed the effect of timing better than analyses that focused exclusively on the time between menopause and randomization. The effect of estrogen plus progestin on the risk of cardiovascular events did not differ significantly between women who initiated hormone therapy within the first 5 years after menopause and those who started it after 5 years following menopause (p=0.42).^110^

Two other trials did not meet our eligibility criteria because they assessed only surrogate endpoints for cardiovascular disease. They did, however, address the timing hypothesis. Specifically, the KEEPS (Kronos Early Estrogen Prevention Study) and ELITE (Early vs. Late Intervention Trial with Estradiol) trials used change in carotid artery intima-media thickness as the primary outcome.^46,^ ^53^ Secondary endpoints included changes in markers of cardiovascular risk. KEEPS and ELITE enrolled women free from cardiovascular disease and stratified them according to time since menopause.

KEEPS enrolled healthy women ages 42 to 58 years within 3 years of menopause. It compared women receiving low-dose daily oral conjugated equine estrogen (0.45 mg/day) or transdermal estrogen (17β-estradiol, 50 μg/day), both with cyclic progesterone (200 mg for 12 days) treatment, with women receiving placebo. After 4 years of followup, investigators did not detect any statistically significant differences in the primary endpoint and found only mixed results for secondary endpoints.^53^

By contrast, ELITE used a higher oral estrogen dose (17β-estradiol, 1 mg/day) than KEEPS and vaginal micronized progesterone (45 mg/day for 10 days) for 5 years. Compared with placebo, hormone therapy resulted in a significantly lower rate of atherosclerosis progression among early postmenopausal women (<6 years since menopause) but not among late postmenopausal women (>10 years since menopause). The clinical significance of this difference, however, is unclear.

#### Peripheral Arterial Disease

##### Benefits and Harms of Hormone Therapy

The WHI [N=16,608]^80^ was the only trial that provided information about peripheral arterial disease among women taking estrogen plus progestin (Appendix F Table11). Peripheral arterial disease was defined as incident carotid artery disease, abdominal aortic aneurysm, or lower extremity arterial disease. In participants who did not have coronary heart disease or peripheral arterial disease at baseline, women assigned to estrogen alone had a similar risk of developing peripheral arterial disease compared with placebo during the 5.6-year (median) intervention phase (HR, 0.89 [95% CI, 0.60 to 1.32]).

##### Differences in Treatment Effects Based on Subgroups

In the WHI, no difference in risk of incident peripheral arterial disease by subgroups based on age, diabetes, or body mass index could be detected during the 5.6-year (median) intervention phase.^80^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Cognitive Functioning and Dementia

##### Benefits and Harms of Hormone Therapy

Dementia and mild cognitive impairment incidence. Two WHI trials (WHIMS [N=4,532]^143^ and WHISCA, a subset of WHIMS [N=1,416]^144^) evaluated the risk of the two outcomes on probable dementia and mild cognitive impairment among women taking estrogen plus progestin (Appendix F Table 12). Women using estrogen plus progestin had a higher risk of probable dementia than those taking placebo (1.8% vs. 0.9%; HR, 2.05 [95% CI, 1.21 to 3.48]); the difference in risk of mild cognitive impairment was not statistically significant.^143^ The WHISCA trial did not find an elevated risk of probable dementia or mild cognitive impairment among women receiving estrogen plus progestin compared with placebo after 4.4 years of intervention (1.4 years in WHISCA after being enrolled in the WHI for 3 years).^119,^ ^144^

The WHI estrogen plus progestin trial (n=16,608) evaluated Alzheimer’s disease or other dementia mortality.^88^ There were no cases of dementia-related mortality at the end of the 5.6-year intervention phase in either group, and no significant differences in dementia-related mortality 12.5 years after stopping therapy (HR, 0.94 [95% CI, 0.78 to 1.13]) or after 17.7 years of cumulative followup (HR, 0.93 [95% CI, 0.77 to 1.11]).^88^

Global cognitive function. Three studies (HERS, KEEPS, and WHI) comprising six trials (HERS [N=1,328],^145^ KEEPS-Cog [N=693],^146^ Kronos Early Estrogen Prevention Study-MRI [KEEPS-MRI] [N=101],^100^ WHIMS [N=4,532],^121,^ ^147^ WHISCA [N=1,213],^122^ and WHIMSY [N=1,326]^123^) measured global cognitive functioning using a short form of the 3MSE or the TICS-m (Appendix F Table 12). The HERS trial had a treatment regimen similar to that used in the WHI studies. It included 662 women randomized to estrogen plus progestin and 666 women randomized to placebo; participants were followed for 4.2 years. HERS found no difference in 3MSE scores between groups through 4 years of followup (−0.4, p=0.36).^145^ Similarly, there were no significant difference in change in 3MSE scores in the WHIMS estrogen plus progestin trial during 5.4 years of followup (−0.18, p=0.055). In WHISCA, the WHIMS ancillary study, differences in 3MSE scores during the 2-year intervention period among participants for the estrogen and progestin arm (−0.09, p=0.02) were not sustained at the postintervention followup (−0.081, p=0.09).^122^ The WHIMSY trial, a subset of the WHI limited to women ages 50 to 55 years at enrollment, found no difference in mean TICS-m scores with adjustment for age and visit year between women assigned to estrogen plus progestin and women assigned placebo 7.2 years after stopping therapy.^123^ Neither KEEPS-Cog, an ancillary study that recruited patients from all sites of the KEEPS trial, nor KEEPS-MRI, an ancillary study that recruited patients from one site of the KEEPS trial, found differences between women randomized to either estrogen plus progestin therapy and women randomized to placebo in change in 3MSE score over a 4-year period of observation for either oral or transdermal estrogen.^100,^ ^146^

Other cognitive measures. Four trials (EMS [N=142],^141^ HERS [N=1,328],^145^ WHISCA [N=1,213],^122^ and WHIMSY [N=1,326]^93,^ ^123^) evaluated other measures of cognitive functioning; heterogeneity in outcome measures precluded meta-analysis (Appendix F Table 13). The HERS, WHISCA, and WHIMSY trials are described above. The EMS trial randomized 70 women to estrogen plus progestin and 72 women to placebo and followed them for 2 years. Women in HERS were followed for 4.2 years. All trials found no differences in groups as randomized for the majority of other cognitive functioning measures evaluated.

##### Differences in Treatment Effects Based on Subgroups

WHIMS found no difference in possible dementia by history of diabetes, stroke, hypertension, cardiovascular disease, or race/ethnicity.^119^ It also found no difference in the rate of change in 3MSE scores by race/ethnicity, body mass index, history of cardiovascular disease, hypertension, diabetes, or length of use.^147^ There was no difference in dementia-related mortality by age at randomization in the WHI estrogen plus progestin trial at the postintervention followup (12.5 years) or cumulative followup (17.7 years).^88^

##### Differences in Treatment Effects Based on Timing of the Intervention

WHIMS found no difference in the rate of change in 3MSE scores by time to initiation of hormone therapy after the last menstrual period.^147^

#### Diabetes

##### Benefits and Harms of Hormone Therapy

Two trials (HERS [N=2,029]^148^ and WHI [N=15,874]^67,^ ^149^) provided information about the prevention of diabetes with estrogen plus progestin among 17,903 women without diabetes or not receiving treatment for diabetes at baseline (Appendix F Table 14). Incident diabetes was defined in HERS as having a fasting glucose level of 6.9 mmol/L or greater (≥126 mg/dL), self-report of new diabetes or diabetes-related complications (diabetic neuropathy, diabetic retinopathy, diabetic foot ulcer, diabetic renal disease, or hypoglycemia if taking an antidiabetic medication), or initiation of hypoglycemic medication; this analysis was conducted post hoc and should be considered cautiously.^148^ In the WHI, incident diabetes was limited to self-reported new diagnoses of diabetes by a physician followed by treatment with oral hypoglycemic drugs or insulin.^149^

Estrogen plus progestin therapy reduced incident diabetes among women in HERS (mean followup, 4.1 years; HR, 0.65 [95% CI, 0.48 to 0.89]) and the WHI (mean followup, 5.6 years; HR, 0.81 [95% CI, 0.70 to 0.94]) through the end of the intervention phase.^148,^ ^149^ In the WHI, the larger trial of the two, new diabetes diagnoses were reported during followup by 0.72 percent (annualized) of women randomized to active treatment and 0.88 percent (annualized) of those taking placebo.^67,^ ^149^ However, women receiving active treatment actually experienced an increased risk of diabetes compared with those taking placebo 8.2 years postintervention (HR, 1.19 [95% CI, 1.05 to 1.34]).^67^ No between-group difference in risk was observed after 13.2 years of cumulative followup (HR, 1.02 [95% CI, 0.93 to 1.12]).^67^ Appendix G Figure 25 presents HRs for incident diabetes at different followup periods of HERS and the WHI.

##### Differences in Treatment Effects Based on Subgroups

A test for interaction did not detect any statistically significant subgroup effects with respect to race/ethnicity, age at screening, or hypertension at baseline for women in the WHI.^149^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Fractures

##### Benefits and Harms of Hormone Therapy

Five trials (EMS [N=142],^141^ EPHT [N=777],^137^ ERA [N=209],^113^ HERS [N=2,763],^136^ and WHI [N=16,608]^36,^ ^67,^ ^132,^ ^150^) provided information on preventing fractures with estrogen plus progestin among 20,499 women (Appendix F Table 15). These trials spanned reporting periods from 2 through 5.6 years. The studies varied widely in sample size, from a total of 142 patients in the smallest study (EMS) to 16,608 in the largest (WHI).

A random-effects meta-analysis of these five trials measuring total fractures during or at the end of the intervention period (N=20,499) yielded a statistically significantly reduction of fractures in women taking estrogen plus progestin (RR, 0.79 [95% CI, 0.66 to 0.94]) (Appendix H Figure 4). In the meta-analysis, 8.7 percent of women taking estrogen plus progestin and 10.9 percent of women taking placebo experienced fractures. Appendix G Figure 26 presents HRs for total fractures at different followup periods of the five trials.

##### Differences in Treatment Effects Based on Subgroups

Tests for interaction did not detect any statistically significant subgroup effects with respect to age in the WHI.^67,^ ^97^

##### Differences in Treatment Effects Based on Timing of the Intervention

In the WHI and EPHT, no statistically significant differences in incidence of total fractures emerged between women who received estrogen plus progestin hormone therapy and those who received placebo according to years since menopause (i.e., ≤3 years or <10 years, 10 to <20 years, and ≥20 years).^97,^ ^137^

#### Gallbladder Disease

##### Benefits and Harms of Hormone Therapy

Two trials (PEPI [N=700]^32^ and WHI [N=14,203]^67,^ ^127^) provided information about the prevention of gallbladder disease with estrogen plus progestin among 14,903 women with gallbladders and without gallbladder disease (Appendix F Table 16). Treatment duration was 3.0 years for women in PEPI and 5.6 years, on average, for women in the WHI. The definition of gallbladder disease used in PEPI is unclear; for the WHI, global gallbladder disease was a self-reported endpoint that included all acute or chronic gallbladder inflammation and all gallbladder or biliary tract stone disease.^32,^ ^67,^ ^127^ Gallbladder procedures were also reported in the WHI, which included biliary tract procedures such as cholecystectomy.^127^

The WHI, which is the larger of the two trials, reported global gallbladder disease during followup for 1.31 percent (annualized) of women randomized to active treatment and 0.84 percent (annualized) of those taking placebo; this difference was statistically significant (HR, 1.57 [95% CI, 1.36 to 1.80]).^67^ During postintervention followup (median 8.2 years), the risk of gallbladder disease continued to favor placebo over estrogen plus progestin therapy (HR, 1.24 [95% CI, 1.01 to 1.52]).^67^

The PEPI trial had few cases of gallbladder disease and reported inconclusive results.^32^

##### Differences in Treatment Effects Based on Subgroups

A test for interaction did not detect any subgroup effects with respect to age of women in the WHI.^127^

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Stroke

##### Benefits and Harms of Hormone Therapy

Four trials reported on risk of stroke (WHI [N=16,608],^37,^ ^67,^ ^88,^ ^101,^ ^108,^ ^110,^ ^151^ EMS [N=142],^141^ EPHT [N=777],^137^ and ERA [N=209]^113^) (Appendix F Table 17). We did not pool trial results because of heterogeneity in study duration and outcome measures.

During the WHI 5.6-year intervention phase, stroke risk was significantly higher with estrogen plus progestin than with placebo (1.9% vs. 1.3%; HR, 1.37 [95% CI, 1.07 to 1.76]).^67^ During postintervention followup (2.4 years after stopping therapy), stroke risk was similar between these two groups (HR, 1.04 [95% CI, 0.86 to 1.26]).^67^ Cumulatively, after 19.4 years of total followup, stroke risk was statistically higher in the estrogen plus progestin group compared with the placebo group (HR, 1.13 [95% CI, 1.00 to 1.27]).^101^

The three other trials comparing estrogen plus progestin and placebo reported on the incidence of various cerebrovascular events as harms of treatment.^113,^ ^137,^ ^141^ In EPHT, although risk of stroke was similar between the treatment and placebo groups (0.2% vs. 0.3%; HR, 1.06 [95% CI, 0.07 to 17.2]) after 3.4 years of intervention, risk of any cerebrovascular event (composite stroke, transient ischemic attack, and subarachnoid hemorrhage) was higher among women randomized to estrogen plus progestin than placebo (5.7% vs. 2.4%; HR, 2.46 [95% CI, 1.14 to 5.34]).^137^ In EMS, few events occurred over 2 years (3 events total), and the results were inconclusive.^141^ In the ERA trial, the risk of stroke or transient ischemic attack was similar in both groups (6 events each).^113^ Appendix G Figure 27 presents available HRs for stroke for different followup periods.

Only the WHI reported stroke mortality. Death from stroke was similar between the estrogen plus progestin and placebo groups during the 5.6-year intervention phase (0.3% vs. 0.2%; HR, 1.58 [95% CI, 0.85 to 2.94]).^88^ Stroke mortality remained similar between the two groups during the postintervention period (12.5 years after stopping therapy: HR, 1.08 [95% CI, 0.86 to 1.35]) and during cumulative followup (17.7 years of followup: HR, 1.12 [95% CI, 0.91 to 1.38]).^88^

##### Differences in Treatment Effects Based on Subgroups

No difference between treatments was seen in stroke risk in the WHI by subgroups based on race/ethnicity, age, diabetes, or hypertension.^151^ No differences by age were detected in risk for death from stroke.^88^

##### Differences in Treatment Effects Based on Timing of the Intervention

Risk of stroke in the WHI was similar for women who started estrogen plus progestin soon after menopause (<5 years) and those who started later (≥5 years).^110^

#### Urinary Incontinence

##### Benefits and Harms of Hormone Therapy

Two trials (WHI [N=10,073]^67^ and HERS [N=1,208]^152^) provided results on incident urinary incontinence (self-reported) in women who had been continent at baseline. The WHI followed continent women through year 1 and then evaluated incontinence at study closeout (i.e., median followup of 8.2 years after stopping therapy) for those continent at year 1. The HERS trial had a similar treatment regimen as the WHI studies and followed women for 4.2 years. These studies defined urinary incontinence as at least one episode weekly.^67,^ ^152^ Both the WHI^130^ and HERS^152^ also evaluated various subtypes of urinary incontinence. Detailed results can be found in Appendix F Table 18.

Both studies showed a consistently higher risk of urinary incontinence at all time points for the estrogen plus progestin group compared with placebo. In the WHI, 16.6 percent (annualized) of women taking hormone therapy reported incident incontinence after 1 year of treatment compared with 11.1 percent (annualized) of women taking placebo (HR, 1.49 [95% CI, 1.36 to 1.63]).^67^ After 8.2 years of stopping therapy, the risk remained statistically significantly elevated (HR, 1.16 [95% CI, 1.08 to 1.25]).^67^ In the HERS trial, women taking estrogen plus progestin had a higher risk of incontinence compared with women taking placebo at the 4.2-year followup (OR, 1.60 [95% CI, 1.30 to 1.90]).^152^ Appendix G Figure 28 presents effect estimates for incident weekly urinary incontinence at different followup periods of the WHI and the HERS.

##### Differences in Treatment Effects Based on Subgroups

We found no evidence on differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### Venous Thromboembolism

##### Benefits and Harms of Hormone Therapy

Five trials (WHI [N=16,608],^67,^ ^101,^ ^110,^ ^132,^ ^153^ ERA [N=209],^113^ EMS [N=142],^141^ EPHT [N=777],^137^ and HERS [N=2,763]^136^) reported on risk of thromboembolism (Appendix F Table 19). We did not pool trials because of heterogeneity in study duration and outcome measures.

In the WHI 5.6-year intervention period, women randomized to estrogen plus progestin had an increased risk of venous thrombosis (1.96% vs. 0.94%; HR, 2.06 [95% CI, 1.57 to 2.70]), deep vein thrombosis (1.4% vs. 0.8%; HR, 1.87 [95% CI, 1.37 to 2.54]), and pulmonary embolism (1.0% vs. 0.5%; HR, 1.98 [95% CI, 1.36 to 2.87]) compared with women in the placebo group.^67,^ ^153^ In the HERS 4.1 intervention period, women randomized to estrogen plus progestin had a significantly increased risk of total thromboembolic events (2.5% vs. 0.9%; HR, 2.66 [95% CI, 1.41 to 5.04]) and deep vein thrombosis (1.8% vs. 0.7%; HR, 2.82 [95% CI, 1.32 to 6.04]), but not of pulmonary embolism (0.8% vs. 0.3%; HR, 2.78 [95% CI, 0.89 to 8.74]).^136^ The WHI groups did not differ for risk of deep vein thrombosis or pulmonary embolism during the 2.4-year postintervention period after women stopped therapy.^132^ However, increased risk for deep vein thrombosis and pulmonary embolism remained for women in the estrogen plus progestin group after 13.2 years of cumulative followup (HR, 1.24 [95% CI, 1.01 to 1.53] and HR, 1.26 [95% CI, 1.00 to 1.59], respectively). In the HERS trial, higher risk for overall venous thromboembolism remained after 6.8 years of cumulative followup (4.2% vs. 1.7%; HR, 2.06 [95% CI, 1.26 to 3.36]) but was no longer statistically significant in the WHI trial after 19.4 years of cumulative followup (4.9% vs. 4.3%; HR, 1.14 [95% CI, 0.99 to 1.31]).^67,^ ^101^ Appendix G Figures 29 and 30 present available HRs for deep vein thrombosis and pulmonary embolism, respectively, for different followup periods of the WHI and HERS trials.

In the three smaller trials (N=142 to 777), groups did not differ in risk of venous thromboembolic events among participants randomized to estrogen plus progestin or placebo over 2 to 3.4 years (3 events vs. 1 event across all three trials).^113,^ ^137,^ ^141^

##### Differences in Treatment Effects Based on Subgroups

In the WHI, risk of pulmonary embolism or deep vein thrombosis did not differ between treatments by subgroups based on age.^67,^ ^91^

##### Differences in Treatment Effects Based on Timing of the Intervention

Risk of venous thromboembolism or pulmonary embolism in the WHI was similar for women who began hormone therapy within 5 or 10 years after menopause and for those who started later.^67,^ ^110^

#### Health-Related Quality of Life

##### Benefits and Harms of Hormone Therapy

The WHI (N=16,608)^67^ was the only trial that reported on health-related quality of life (Appendix F Table 20). It used the SF-36 form, which assesses physical functioning, physical role, bodily pain, general health, vitality, social functioning, emotional role, and mental health. Women in both groups had similar scores on all items except for physical functioning (p<0.001), physical role (p=0.02), bodily pain (p<0.001), and general health (p=0.02), for which women taking hormone therapy had statistically significantly better scores than women taking placebo.

##### Differences in Treatment Effects Based on Subgroups

We found no evidence on differences in treatment effects by subgroups.

##### Differences in Treatment Effects Based on Timing of the Intervention

We found no evidence on differences in treatment effects based on timing of the intervention.

#### All-Cause Mortality

##### Benefits and Harms of Hormone Therapy

Three trials (ERA [N=209],^113^ HERS [N=2,763],^136^ and WHI [N=16,608]^132^) provided information about the risk of death from any cause (i.e., all-cause mortality) among 19,580 women with treatment of estrogen plus progestin (Appendix F Table 21). The treatment duration for these trials ranged from 3.2 to 5.6 years.^113,^ ^132,^ ^136^ A meta-analysis of these trials yielded no statistically significant difference in all-cause mortality between women taking hormone therapy or placebo (Appendix H Figure 5; RR, 1.01 [95% CI, 0.88 to 1.16]).

The WHI, the largest of the three trials, reported an HR of 0.97 (95% CI, 0.81 to 1.16) for its 5.6-year intervention period; 2.9 percent of women in both treatment groups died.^132^ The risk of death among women who had received estrogen plus progestin and those who had received placebo remained similar at various postintervention and cumulative followup (Appendix G Figure 31).^67,^ ^88,^ ^101,^ ^132^

##### Differences in Treatment Effects Based on Subgroups

We found no evidence on differences in treatment effects by subgroups based on age for all-cause mortality.

##### Differences in Treatment Effects Based on Timing of the Intervention

The effect of estrogen plus progestin on all-cause mortality did not differ significantly between women who initiated hormone therapy within 5 or 10 years after menopause and those who started it later.^67,^ ^110^