# Chapter 2 Methods

## Key Questions and Analytic Framework

The investigators, USPSTF members, and AHRQ Medical Officers developed the scope, key questions (KQs), and analytic framework (Figure 1) that guided our literature search and review. Specifically, the KQs were:

Figure 1 Analytic Framework

* Definitions of perimenopausal and postmenopausal women are based on STRAW+ 10 criteria.

Abbreviation: KQ=key question.

This figure is an analytic framework depicting the key questions (KQs) within the context of the populations, interventions, comparisons, outcomes, time frames, and settings (PICOTS) relative to the benefits and harms of the primary prevention of chronic conditions with estrogen or combination estrogen and progestogen menopausal hormone therapy (HT). This figure illustrates the HT pathway for the population of interest, namely perimenopausal and postmenopausal women eligible for HT. The definitions of perimenopausal and postmenopausal women are based on STRAW+10 criteria. From the population of interest listed on the left side of the figure, there is an arrow going across to intermediate outcomes in the middle of the figure and an arrow going from intermediate outcomes to improved health outcomes, reduction in mortality on the right side of the figure. There is also an arrow pointing down to adverse effects from the arrow connecting perimenopausal and postmenopausal women and intermediate outcomes. There are two overarching questions for the review that span the entire analytic framework. The first (KQ 1) examines the benefits that may result from use of HT when used for the primary prevention of chronic conditions and the second (KQ 3) evaluates whether those benefits differ by subgroups (including race or ethnicity; women with premature menopause; surgical menopause; age of use; duration of use, type, dose, and mode of hormone delivery; and comorbid conditions) or by timing of intervention (initiation of HT during perimenopause or postmenopause). There are two questions for the review that apply to adverse events. The first (KQ 2) examines the harms associated with HT when used for the primary prevention of chronic conditions and the second (KQ3) evaluates whether those harms differ by subgroups or by timing of intervention.

1. What are the benefits of menopausal hormone therapy when used for the primary prevention of chronic conditions?
2. What are the harms of menopausal hormone therapy when used for the primary prevention of chronic conditions?
3. Do the benefits and harms of menopausal hormone therapy when used for the primary prevention of chronic conditions differ by subgroup (race or ethnicity; women with premature menopause; women with surgical menopause; age during use; duration of use; type, dose, and mode of delivery; and comorbid condition) or by timing of intervention (initiation during perimenopause vs. postmenopause)?

We also looked to answer the following contextual questions:

1. What is the average treatment duration of hormone therapy in women who initiate its use for the treatment of menopausal symptoms?
2. Does the use of hormone therapy differ by subgroup?

## Data Sources and Searches

For this update, we searched MEDLINE® (via PubMed), the Cochrane Library, and Embase for English-language articles published from January 1, 2016, through January 28, 2021. We conducted a bridge search on October 12, 2021, and surveillance through June 1, 2022. We used Medical Subject Headings as search terms when available and keywords when appropriate. Appendix A describes the search strategies in detail.

We conducted targeted searches for unpublished literature by searching ClinicalTrials.gov, HSRProj, the World Health Organization’s International Clinical Trials Registry Platform, NIH RePORTER, and Drugs@FDA.gov. To supplement electronic searches, we reviewed the reference lists of pertinent review articles and studies meeting our inclusion criteria and added all previously unidentified relevant articles. Additionally, to ensure that our update was cumulative of all relevant evidence, we reviewed included citations from recent systematic reviews^54–60^ and included all relevant citations that met our criteria for fair or good quality. (We also manually reviewed all literature suggested by peer reviewers or public comment respondents and, if appropriate, incorporated it into the final review.)

Since January 2021, we conducted active surveillance of the literature through article alerts and targeted searches of high-impact journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation.

## Study Selection

We selected hormone therapy studies using inclusion and exclusion criteria that we developed for each KQ based on population, intervention, comparator, outcome, timing, and setting and other elements such as study designs. The basic criteria are described below, and Appendix B provides more details. For this update, we excluded populations who used hormone therapy for secondary prevention of chronic conditions.

In addition to the searches for the updated literature, we incorporated all except one included citation from the previous reports, which covered the publication period of January 2002 through August 2016.^61,^ ^62^ We excluded the Oestrogen in the Prevention of Reinfarction Trial because it assessed secondary prevention.^63^

### Populations

We included studies of generally healthy perimenopausal and postmenopausal women who were eligible for hormone therapy. Women with and without menopausal symptoms were included if the focus of the analysis was either on the primary prevention of chronic conditions or on the harms of hormone therapy.

### Interventions

We included studies that examined the use of systemic therapy with estrogen-only formulations or combination preparations of estrogen plus progestogens for the primary prevention of chronic conditions. We limited our evaluation to medications that have been approved by the FDA for this purpose and that are available for use in the United States. Table 1 lists the drugs in these two classes by generic name and gives the brand names, the type of product (i.e., patch, pill, or injection), and information on dosage. We focused our analysis on studies that present the effect of the intervention by type of hormone therapy (i.e., estrogen only or estrogen plus progestogens).

### Comparators

We included placebo-controlled trials and studies with inactive treatments as a comparator.

### Outcomes

Because of the main focus on primary prevention of chronic conditions, we included trials that measured various incidence outcomes for the following: several types of cancer (breast, cervical, endometrial, ovarian, colorectal, non-Hodgkin’s lymphoma, and lung), coronary heart disease, stroke (ischemic and hemorrhagic), and thromboembolism (deep vein thrombosis and pulmonary embolism). We also included trials that assessed cognitive functioning and dementia, diabetes, fractures, gallbladder disease (cholecystitis and cholelithiasis), chronic obstructive pulmonary disease (COPD), peripheral arterial disease, quality of life, and urinary incontinence (stress, urge, and overall). Finally, we included studies that measured disease-specific and all-cause mortality.

With respect to harms, we sought information on adverse events, unanticipated negative consequences, or side effects attributable to hormone therapy.

### Timing

We searched for studies that reported on outcomes of 1 year or more of hormone therapy for the outcomes outlined above (duration of the intervention).

### Settings

For all KQs, we included trials conducted in all primary care or primary care–like settings but not inpatient, hormone specialist, or institutional settings such as nursing homes or similar facilities. With respect to geography, we searched for studies conducted in the United States or in countries designated by the United Nations Development Programme as having a very high Human Development Index.^64^

### Study Designs

In our searches, we included the following study designs: RCTs, controlled trials, and systematic reviews. We also included large, controlled cohort studies (>10,000 women) for outcomes for which we had little or no evidence from trials or systematic reviews. We included data from long-term followup studies of trials if they provided information on how elevated or reduced risk changed after women had stopped hormone therapy. We present these findings in the context of results from the randomized trials.

Because we had sufficient evidence from randomized trials for most outcomes, we used observational studies only to address outcomes for which we had no or very little evidence from RCTs. Systematic reviews were used only to identify studies (from their reference lists) that we might otherwise have missed.

Two investigators independently reviewed titles and abstracts. We then dually and independently reviewed the full text of all articles that either reviewer marked for potential inclusion. We resolved disagreements by discussion and consensus or with a third reviewer if necessary.

### Subgroups

Our subgroups of interest included race/ethnicity; women with premature menopause (defined as women who experienced menopause before the age of 40); women with surgical menopause (defined as women who underwent bilateral oophorectomy before natural menopause); age during use; duration of use; type, dose, and mode of delivery; and comorbid conditions.

## Data Abstraction and Quality Rating

One reviewer abstracted pertinent information from each included study, including study characteristics (i.e., population, intervention, comparator) and data for eligible outcomes, into a structured form. A second investigator checked all data abstractions for completeness and accuracy. We resolved differences by consensus or adjudication by a third senior investigator. We contacted study authors to clarify data when needed.

Using predefined criteria developed by the USPSTF, two investigators independently assessed the quality of each study as good, fair, or poor.^65^ The USPSTF criteria are listed in Appendix C. Disagreements were resolved by discussion and consensus. We rated trials with fatal flaws as poor quality (i.e., high risk of bias). Fatal flaws that resulted in poor-quality ratings included initially assembled groups that were not close to being comparable or were not maintained throughout the study, high overall or differential attrition, and use of unreliable or invalid measurement instruments or unequal application among groups (including not masking outcome assessment). For RCTs, the lack of intention-to-treat analysis was also a reason for rating a trial as poor quality.

## Data Synthesis and Analysis

We qualitatively synthesized findings for each KQ by summarizing the characteristics and results of included studies in tabular or narrative format. To determine whether meta-analyses were appropriate, we assessed both the number of trials available and their clinical and methodological heterogeneity following established guidance.^66^ To do this, we qualitatively assessed the populations, similarities and differences in treatments used, and similarities in outcomes and timing of outcomes assessed.

Our analysis prioritized outcomes that were prespecified by study authors. We generally do not present the full results for multiple measures of a single construct (e.g., for cognitive function), unless the results were statistically significant. We also elected to prioritize individual rather than composite outcomes when both were available. Based on a communication with the WHI Researcher Help Desk (https://www.whi.org/helpdesk; July 2021), we relied on a publication by Manson et al.^67^ for results of patient-reported outcomes (i.e., diabetes, urinary incontinence, gallbladder disease).

When at least three similar trials were available, we conducted quantitative synthesis of studies with random-effects models (restricted maximum likelihood method). For all quantitative syntheses, we calculated the chi-squared statistic and the I^2^ statistic (the proportion of variation in study estimates attributable to heterogeneity rather than chance) to assess statistical heterogeneity in effects between studies.^68,^ ^69^ An I^2^ from 0 to 40 percent might not be important, 30 to 60 percent may represent moderate heterogeneity, 50 to 90 percent may represent substantial heterogeneity, and 75 percent or greater represents considerable heterogeneity.^70^ The importance of the observed value of I^2^ depends on the magnitude and direction of effects and on the strength of evidence (SOE) for heterogeneity (e.g., p-value from the chi-squared test or a confidence interval [CI] for I^2^). However, as precision and the number of subjects increase, I^2^ may become inflated toward 100 percent and may not reflect clinically relevant heterogeneity.^71^ We conducted all the quantitative analyses using Stata 16.1 (StataCorpLLC, College Station, TX).

We rated the SOE for each major outcome for each KQ using the domains set out in the AHRQ guidance:^72^ study limitations,^73^ consistency,^74^ precision,^75^ directness,^76^ and reporting bias.^77^ We also considered other optional domains that may be relevant for some scenarios, such as a dose-response association, plausible confounding that would decrease the observed effect, and strength of association (magnitude of effect).^78^

Two reviewers assessed each SOE domain for each key outcome and developed the overall SOE grades. The reviewers were two senior members of the review team (including at least one subject matter expert and one methodologist); they resolved any differences by consensus discussion. SOE grades reflect the confidence that the reviewers have that various estimates of effect are close to true effects with respect to the KQs in a systematic review. A high grade indicates confidence that the estimate of effect lies close to the true effect for this outcome, the body of evidence has few or no deficiencies, and the findings are stable. A moderate grade suggests that although the estimate of effect lies close to the true effect for this outcome, the body of evidence has some deficiencies, and some doubt persists as to the stability of the findings. A low grade suggests limited confidence about the estimate of effect, with the need for additional studies. Insufficient evidence means that we have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome.

## Expert Review and Public Comment

A draft research plan for this topic was posted on the USPSTF website for public comment from February 18, 2021, to March 17, 2021. In response, we added language to clarify the term “chronic conditions” based on a definition of the Centers for Disease Control and Prevention. The final version of the research plan was posted on the USPSTF website on May 27, 2021.

A draft report was reviewed by four content experts, five representatives of Federal partners, USPSTF members, and AHRQ Medical Officers and was revised based on comments received. In response to these comments, we provided additional information regarding overall mortality in the abstract, clarified the definition of subgroups, and emphasized in the Introduction that this report does not address hormone therapy for the treatment of menopausal symptoms.

The draft evidence report was posted on the USPSTF website for public comment from April 19, 2022, to May 16, 2022. In response to public comments, we added three publications which met inclusion criteria but were not part of this evidence report. Two studies of WHI data were of moderate risk of bias and did not detect any statistically significant differences in the risk of peripheral arterial disease in women taking estrogen-only^79^ or a combination of estrogen and progesterone.^80^ One study on atrial fibrillation linked data from the WHI with data from the Centers for Medicare and Medicaid Services.^81^ We rated this study as high risk of bias because of potential assessment bias and did not include it in the evidence synthesis of the report. Overall, these three studies did not change any conclusions of the evidence report.

## USPSTF and AHRQ Involvement

Members of the USPSTF helped to develop the scope of the work, including the analytic framework and KQs, and to review the evidence synthesis. AHRQ staff provided project oversight, conducted reviews of the draft report, and helped facilitate an external review of the evidence synthesis.