# Chapter 1 Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to update its 2017 recommendation on the use of hormone therapy for postmenopausal persons^a^ to prevent chronic health conditions such as cardiovascular disease, types of cancer, and osteoporotic fractures.^1^ In 2017, the USPSTF recommended against the use of estrogen plus progestogens for the prevention of chronic conditions in postmenopausal persons (grade D recommendation) and against the use of estrogen for the prevention of chronic conditions in postmenopausal persons who have had a hysterectomy (grade D recommendation).^1^ These recommendations do not apply to persons with primary ovarian insufficiency or who have had surgical menopause.

The purposes of this report are to update evidence about the benefits and harms of systemic hormone therapy for preventing chronic conditions in postmenopausal persons and to examine whether outcomes vary among persons in different subgroups. While hormone therapy plays an important role in treatment of menopausal symptoms, such as vasomotor hot flashes, indications other than primary prevention of chronic health conditions are outside the scope of this review.

## Condition Definition

Menopause is the cessation of the menstrual cycle and the end of reproductive years; it is defined retrospectively, 12 months after the final menstrual period.^2^ Natural menopause results from the relative depletion of ovarian follicles responsive to the gonadotropins and the consequent decline in estrogen and progesterone concentration. The Stages of Reproductive Aging Workshop describes menopause as a series of four stages along a reproductive continuum.^3^ Early and late perimenopause are characterized by variable to progressive menstrual irregularity, respectively. Early postmenopause is the interval within 4 years of the final menstrual period, and late postmenopause is 5 or more years after the final menstrual period. Menopause transition is the period of time with menstrual irregularity prior to the final menstrual period. Although current use of hormone therapy targets the earlier stages of menopause for the treatment of menopause-associated symptoms,^4^ in the past, hormone therapy was prescribed across the stages of menopause for chronic conditions.

“Chronic conditions” are broadly defined as conditions that last 1 or more years and require ongoing medical attention, limit activities of daily living, or both. The following are classified as major chronic diseases by the Centers for Disease Control and Prevention because they are leading drivers of death, disability, and healthcare costs: heart disease, cancer, chronic lung disease, stroke, Alzheimer’s disease, diabetes, and chronic kidney disease.^5^ These conditions all have multiple risk factors, such as lack of physical activity, poor nutrition, tobacco use, and others. Before 2002, hormone therapy was believed to help prevent some of these conditions based on evidence from observational studies,^6,^ ^7^

Prior to 2002, menopause was viewed as a risk factor for several chronic conditions attributable primarily to two (related) bodies of evidence: 1) large observational studies showing an increased risk of chronic conditions in relationship to age at natural menopause^8,^ ^9^ (as well as increased incidence of biomarkers associated with chronic conditions, such as elevated lipid levels^10^) and 2) several observational studies and meta-analyses suggesting that hormone therapy including estrogen was beneficial for the prevention of chronic diseases such as coronary heart disease, osteoporosis, dementia, and all-cause mortality.^6,^ ^11–13^ Before the publication of randomized, controlled trials (RCTs) of hormone therapy in postmenopausal persons, guidelines advocated for the use of hormone therapy for prevention of chronic diseases, and it was commonly prescribed for primary prevention of these conditions and others such as osteoporosis in persons without menopausal symptoms.^14^ After the publication of RCTs, the indication for hormone treatment shifted toward menopausal symptom management in the earlier stages of menopause.

## Prevalence and Burden

Natural menopause occurs at a median age of 51.3 years.^15^ Premature menopause (defined as menopause that occurs before the age of 40 years) may be induced by surgery (bilateral oophorectomy), chemotherapy, or radiation; in the absence of one of these causes, menopause before age 40 years is referred to as primary ovarian insufficiency.^16^ In some persons, menopause is associated with its own morbidity. Approximately 85 percent of persons transitioning through menopause report experiencing symptoms such as vasomotor symptoms (hot flashes), sleep disturbances, psychological symptoms (depressive symptoms, anxiety, or mood disturbances), urogenital problems, and sexual dysfunction.^15,^ ^17^ Vasomotor symptoms in particular are reported by 80 percent of menopausal persons and persist for a median of 7.4 years.^18^

The prevalence and incidence of most chronic diseases increase with age, and the average U.S. person who reaches menopause is expected to live another 30 years.^19^ However, the excess risk for chronic conditions that can be attributed to menopause alone is uncertain for at least two reasons: 1) the hormone events associated with natural menopause and aging do not happen in isolation^17^ and 2) chronic conditions are multifactorial. In a recent scientific statement, the American Heart Association identified the menopausal transition as a time of accelerating cardiovascular risk,^20^ associated with increases in lipid levels (cholesterol, low-density lipoprotein, and apolipoprotein B) independent of aging alone^21,^ ^22^ and adverse vascular changes (carotid atherosclerosis and arterial stiffness) not explained by aging or traditional cardiovascular risk factors.^23,^ ^24^ The American Heart Association concluded that future risk assessment guidelines should include menopause among cardiovascular risk factors in women.^20^ Meta-analyses pooling data across 32 observational studies show persons with early-onset menopause (<45 years of age) have significantly increased risk of overall and fatal coronary heart disease compared with persons with menopause ≥ 45 years,^25^ though data are conflicting regarding older ages of natural menopause and associated cardiovascular risk. Data suggest that timing of surgical menopause relative to natural menopause affects cardiovascular risk; in a 2007 review, there was limited association between surgical menopause and cardiovascular disease risk when bilateral oophorectomy occurred around the time of natural menopause, although coronary heart disease risk was significantly higher if surgery was performed at a younger age (<40–45 years).^26^

## Interventions

### Hormone Therapy

Currently, hormone therapy is approved by the U.S. Food and Drug Administration^27^ only for treatment of menopausal symptoms and prevention, and treatment of osteoporosis, with the recommendation to use hormone therapy at the lowest dose that relieves symptoms and for the shortest time needed.^28^ Hormone therapy includes the use of various forms, doses, and regimens of estrogen with or without progestogen (progestin or progesterone).^27^ Persons who have not had a previous hysterectomy should use a combination therapy of estrogen plus progestogen (sometimes denoted combined hormone therapy, but hereafter in this report specified as estrogen plus progestogen) to prevent endometrial proliferation and endometrial cancer, whereas persons with a previous hysterectomy should use only estrogen (estrogen-only hormone therapy). Products approved for use in the United States are listed in Table 1.

Table 1 List of Included Interventions, Extracted From FDA List of Approved Hormone Therapy^*^

Category of Hormone Therapy and Generic Name | Brand Name | Product Type | Dosage^†^
Estrogen-Only or Progestogen-Only Formulations
Conjugated estrogens^¶^ | Premarin | Pill, IM, IV | 0.3 mg/day cyclically,^§^ single 25-mg injection
Estradiol^ǂ^ | Estrace | Pill | 0.5–2 mg/day
Estradiol^ǂ^ | Alora | Patch | 0.025–0.1 mg/day twice weekly
Estradiol^ǂ^ | Climara | Patch | 0.025–0.1 mg/day once weekly
Estradiol^ǂ^ | Menostar | Patch | 0.014 mg/day once weekly
Estradiol^ǂ^ | Minivelle | Patch | 0.025–0.1 mg/day twice weekly
Estradiol^ǂ^ | Vivelle | Patch | 0.0375–0.1 mg/day twice weekly
Estradiol^ǂ^ | Vivelle-Dot | Patch | 0.025–0.1 mg twice weekly
Estradiol^ǂ^ | Divigel | Topical | 0.25-1.25 g/day
Estradiol^ǂ^ | Elestrin | Topical | 0.87 g/day
Estradiol^ǂ^ | Estrogel | Topical | 1.25 g/day
Estradiol^ǂ^ | Evamist | Topical | 1.53–4.59 mg/day
Estradiol valerate | Delestrogen | IM | 10/20/40 mg/mL/month
Esterified estrogen^ǂ^ | Menest | Pill | 0.3–1.25 mg/day cyclically^§^
Micronized progesterone | Prometrium | Pill | 0.625 mg/day
Medroxyprogesterone acetate | Provera | Pill | 100–200 mg/day
Combination Estrogen Plus Progestogen Formulations
Estradiol^ǂ^ + drospirenone^**^ | Angeliq | Pill | Drospirenone 0.25–0.5 mg/day with estradiol 0.5–1.0 mg/day
Estradiol^ǂ^ + norethindrone acetate^#^ | Activella | Pill | Estradiol 0.5–1.0 mg/day with norethindrone 0.1 mg/day
Estradiol^ǂ^ + norgestimate^**^ | Prefest | Pill | Repeat estradiol 1 mg/day for 3 days followed by estradiol 1 mg/day with norgestimate 0.09 mg/day for 3 days
Estradiol^ǂ^ + levonorgestrel^**^ | Climara Pro | Patch | Estradiol 0.045 mg with levonorgestrel 0.015 mg worn for 24 hours once weekly
Estradiol + micronized progesterone | Bijuvia | Pill | Estradiol 1 mg/micronized progesterone 100 mg daily
Estradiol^ǂ^ + norethindrone acetate^**^ | Combipatch | Patch | Estradiol 0.05 mg with norethindrone 0.14–0.25 mg worn for 24 hours once weekly
Estradiol valerate + dienogest | Natazia | Pill | Estrogen valerate 1 mg–3 mg/day; dienogest 1–2 mg/day
Conjugated estrogene + medroxyprogesterone acetate^**^ | Prempro | Pill | Conjugated estrogen 0.625 mg/day with medroxyprogesterone acetate 5 mg/day
Ethinyl estradiol^ǂ^ + norethindrone acetate^#^ | Femhrt | Pill | Ethinyl estradiol 0.0025 mg/day with norethindrone acetate 0.500 mg/day

* Source: U.S. Food and Drug Administration. Menopause: Medicines to Help You. https://www.fda.gov/consumers/free-publications-women/menopause-medicines-help-you. Accessed August 30, 2021 .

† Dosages are based on the package inserts for the brand name formulations.

ǂ Estradiol can be from natural sources or prepared synthetically.

§ Cyclically means “within a cycle” (e.g., repeat 3 weeks of treatment and 1 week off).

¶ Conjugated estrogens, such as conjugated equine estrogens, are derived wholly or partially from the urine of pregnant mares or synthetic estrone and equilin.

# Synthetic conjugated estrogens are prepared using plant sources, such as yams and soy, and use only synthetic resources.

** Synthetic progestin.

Abbreviations: FDA=Food and Drug Administration; IM=intramuscular injection; IV=intravenous injection.

Hormone therapy can be taken orally, vaginally, or intranasally or as an implant, skin patch, cream, gel, or spray. Formulations of oral estrogen may include estradiol (derived from the Mexican yam), estradiol valerate (a prodrug for estradiol), ethinyl estradiol, estropipate, estradiol acetate, esterified estrogens, synthetic conjugated estrogen (prepared from plant sources), or conjugated equine estrogen (derived from horse mare urine).^29^ Observational studies suggest that oral estrogen may carry a higher risk of venous thromboembolism compared with transdermal estrogen,^30^ and a large case-control study did not observe an elevated risk of venous thromboembolism in individuals using transdermal estrogen across several different regimens.^31^

The progestogens include synthetic derivatives of progesterone or progestins (e.g., norethindrone acetate, levonorgstrel, drosperinone, norgestimate, and medroxyprogesterone acetate) and natural progesterones derived from plants (e.g., orally administered micronized progesterone) and identical to the steroid produced by the corpus luteum. Progestins and micronized progesterone differ in that micronized progesterone appears metabolically neutral with lower risk of adverse effects on blood lipids, breast tenderness, and headaches, although data are limited.^29,^ ^32^ For estrogen plus progestogen therapy, progestogen can be taken either every day (continuous combined therapy) or cyclically with estrogens taken daily and progestogen taken for part of the month (sequentially combined hormone therapy).

A systematic review supported by the Agency for Healthcare Research and Quality (AHRQ) synthesized evidence from 283 RCTs, published through January 2014, analyzing the effectiveness of treatments for menopausal symptoms. Symptoms of interest included vasomotor, psychological, and urogenital symptoms; quality of life; sexual function; and sleep disturbance.^33^ The authors concluded that estrogens are the most effective treatment for vasomotor symptom relief and confer the greatest improvement in quality-of-life measures with high strength of evidence for both outcomes compared with nonhormonal treatments, which had lower effect sizes and strength of evidence. The authors concluded that compared with placebo, nonhormonal treatments show similar effects as estrogens for other common symptoms, such as psychological symptoms, urogenital symptoms, and sleep disturbance.^33^ The review also highlighted potential long-term harms of long-term hormone therapy, including increased risk of venous thromboembolism, stroke, breast cancer, and other conditions.

### Current Clinical Practice

The number of persons using menopausal hormone therapy has declined significantly in recent years.^34^ Between 1988 and 1994, an estimated 44 percent of postmenopausal women in the United States reported current or past use of at least one form of hormone therapy.^35^ Results from the Women’s Health Initiative (WHI),^36,^ ^37^ a large U.S.-based RCT of hormone therapy versus placebo, were first released in 2002; findings indicated that hormone therapy use was associated with important adverse health effects. Between 2003 and 2004, use of all formulations of hormone therapy decreased to 11.9 percent among non-Hispanic White women; however, among non-Hispanic Black and Hispanic women, prevalence did not decline substantially until 2005 to 2006. The reduction in hormone therapy has been sustained: in 2010, the prevalence of hormone therapy use in the National Health and Nutrition Examination Survey was estimated at 4.7 percent overall, and the Study of Women’s Health Across the Nation estimated initiation of menopausal hormone therapy of 2.8 percent in 2013 compared with 8.6 percent before the WHI.^38,^ ^39^ A growing proportion of hormone therapy users have turned to compounded bioidentical hormone therapy as an alternative to Food and Drug Administration (FDA)-approved hormone therapies,^40^ considering them safer or “more natural” than medications studied in trials. However, professional societies have recommended against the use of compounded bioidentical hormone therapy because of the lack of regulatory oversight and lack of scientific evidence for efficacy or safety.^41^

Despite an overall decline in hormone therapy use, some current recommendations by professional societies consider the use of hormone therapy for prevention in some cases and advocate hormone therapy use to treat menopausal symptoms. For example, some guidelines recommend considering hormone therapy for persons at increased risk of osteoporosis and fracture.^42–44^ Some organizations also cite data suggesting that the overall net benefit of hormone therapy use may be increased for persons who initiate treatment during the menopause transition or early postmenopause rather than late postmenopause and can be considered in patients with vasomotor symptoms.^42,^ ^44^ This approach is often referred to as the “timing hypothesis” (i.e., a critical window for favorable outcomes of hormone therapy treatment).^45^ The hypothesis proposes that hormone therapy given at or soon after menopause reduces the risk of cardiovascular disease, but the potential beneficial effects are attenuated or not experienced when hormone therapy is initiated several years after menopause.^46^

The timing hypothesis arose initially from data from the Framingham study, which indicated that natural menopause increases the risk of cardiovascular disease. Studies in female monkeys^47^ and large observational studies in women^6,^ ^48,^ ^49^ showed that early commencement of hormone therapy prevents the progression of atherosclerosis. The purported health benefits of early hormone therapy have been extended to lower mortality,^50^ reduced risk of dementia, and better cognition.^51^ Most of these claims are based on observational studies; post hoc subgroup analyses of the WHI also reported benefits of an early commencement of hormone therapy, although most differences did not reach statistical significance.^52^ Two RCTs assessing the intermediate cardiovascular outcome of carotid artery intima-media thickness showed mixed results regarding the timing hypothesis.^46,^ ^53^

### Summary of Guidelines From Other Groups

Several organizations have issued clinical practice guidelines related to using hormone therapy in postmenopausal persons for the prevention of chronic conditions (Table 2). No current guidelines recommend the routine use of hormone therapy for primary or secondary prevention of heart disease, and most recommend against the use of hormone therapy for prevention of any chronic conditions. The American College of Obstetricians and Gynecologists guidelines,^42^ the American Association of Clinical Endocrinologists guidelines,^43^ and the North American Menopause Society^44^ note that hormone therapy is FDA approved for persons at increased risk of osteoporosis and fracture. The American College of Obstetricians and Gynecologists guidelines also mention the uncertainty about whether the potential cardiovascular benefits may differ based on early versus late initiation of hormone therapy.^42,^ ^44^ The North American Menopause Society guidelines^44^ focus primarily on considerations for persons with symptoms; they note that the balance of potential health benefits and risks should be weighed individually for each person.

Table 2 Clinical Practice Guidelines and Recommendations About Use of Hormone Therapy for Prevention of Chronic Conditions

Organization, Year | Recommendations
American Academy of Family Physicians (AAFP), 2018^156^ | Recommends against the use of combined estrogen and progestin for the prevention of chronic conditions in postmenopausal women (Grade: D recommendation). AAFP recommends against the use of estrogen for the prevention of chronic conditions in postmenopausal women who have had a hysterectomy (Grade: D recommendation).
American College of Obstetricians and Gynecologists, 2013–2014^157^ | Recommends against the use of menopausal HT for primary and secondary prevention of coronary heart disease because of insufficient evidence for benefit.; The guidelines also note the following considerations:; - Recent evidence suggests that women in early menopause who are in good cardiovascular health and are at low risk of adverse cardiovascular outcomes should be considered candidates for the use of estrogen therapy or conjugated equine estrogen plus a progestin for relief of menopausal symptoms.; - There is some evidence that lends support to the “timing hypothesis,” which posits that cardiovascular benefit may be derived when estrogen therapy or HT is used close to the onset of menopause, but the relationship of duration of therapy to cardiovascular outcomes awaits further study with cardiovascular health outcomes rather than surrogate CVD outcomes.; - HT (i.e., estrogen or combined estrogen/progestogen) positively affects bone health; it is approved for use in women with an increased risk of osteoporosis^158^ and fracture.; Reaffirmed 2020.
American Heart Association, 2011, 2014^159,^ ^160^ | Recommends against the use of HT and selective estrogen-receptor modulators for primary and secondary prevention of CVD in women (Class III, Level of Evidence A).; HT (CEE with or without medroxyprogesterone) should not be used for primary or secondary prevention of stroke in postmenopausal women (Class III; Level of Evidence A).
American Association of Clinical Endocrinologists, 2017^161,^ ^162^ | Reaffirmation of 2011 statement; - Menopausal HT is not recommended for primary or secondary prevention of CVD (Grade D; Best Evidence Level [BEL] 1).; - HT should be used for the prevention and treatment of osteoporosis within the context of the overall benefit vs. risk analysis of each patient. Data from multiple RCTs substantiate the efficacy of estrogens in preserving bone mass and, less consistently, preventing fractures, but nonhormonal therapeutic options for bone health exist (Grade A; BEL 1).; - HT for the prevention or treatment (or both) of dementia is not recommended (Grade D; BEL 1).
American College of Physicians, 2015, 2017^163,^ ^164^ | Recommends the U.S. Preventive Services Task Force website and the North American Menopause Society^165^ guidelines.; Recommends against using menopausal estrogen therapy or menopausal estrogen plus progestin therapy or raloxifene for the treatment of osteoporosis in women. (Grade: strong recommendation; moderate-quality evidence)
The North American Menopause Society, 2014, 2017^44^ | HT should not be prescribed for chronic disease prevention. (Level I); Benefits are most likely to outweigh risks for symptomatic women who initiate HT when age 60 years or younger or who are within 10 years of menopause onset. (Level I); Decisions about duration of HT require individualization, including consideration of personal preferences, balancing potential ongoing benefits and risks, and decisions to continue HT for preventive and/or QOL purposes. (Level III)
Society of Obstetricians and Gynaecologists of Canada, 2014^166^ | Healthcare providers should not initiate HT for the sole purpose of preventing CVD (coronary artery disease and stroke) in older postmenopausal women because there are no data to support this indication for HT. (I-A); If prescribing HT to older postmenopausal women, healthcare providers should address cardiovascular risk factors; low- or ultralow-dose estrogen therapy is preferred. (I-B)

Abbreviations: AAFP=American Academy of Family Physicians; BEL=Best Evidence Level; CEE=conjugated equine estrogen; CVD=cardiovascular disease; HT=hormone therapy; QOL=quality of life; RCT=randomized, controlled trial.

a We refer to postmenopausal persons in overview sections of the report to be as inclusive as possible. However, most studies were limited to generally healthy perimenopausal and postmenopausal women who have traditionally been targeted for hormone therapy, and we use the term “women” when discussing individual and pooled study results.