# Appendix J Contextual Questions

## CQ 1 What Is the Average Treatment Duration of Hormone Therapy in Women Who Initiate Its Use for the Treatment of Menopausal Symptoms?

We did not identify any evidence to address this CQ.

## CQ 2 Does the Use of Hormone Therapy Differ by Subgroup?

Five articles reported on the use of hormone therapy by subgroups of interest identified in KQ 3.^181–185^

Race or ethnicity. A secondary analysis of data from the Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial, a large multicenter randomized trial from 1993 to 2001 with 75,587 women ages 55 to 74 years, found that more women who never used hormone therapy (estrogen only or estrogen plus progestin) were non-Hispanic Black compared with current hormone therapy users and former hormone therapy users (8.5% vs. 3.4% vs. 6.7%; p<0.001).^181^

Age. A retrospective cohort study with data from 353,173 perimenopausal and postmenopausal women (ages 45 to 70 years) from the Optimum Patient Care Research Database (OPCRD) in the United Kingdom found use of any hormone therapy, estrogen-only therapy, or estrogen plus progestin therapy was highest among women ages 51 to 55 years compared with use in other age groups.^184^

Comorbid condition. Five articles reported on the use of hormone therapy by BMI.^181–185^ In the PLCO Cancer Screening Trial, the group of women who never used hormone therapy had the highest average BMI (kg/m^2^) compared with current hormone therapy users and former hormone therapy users (27.9 vs. 26.5 vs. 27.5; p<0.001).^181^ The WHI Observational Study of postmenopausal women with a hysterectomy similarly found that women who used hormone therapy tended to have a lower BMI.^182^ In a national prescription register study in Finland among women ages 40 to 44 years, a larger proportion of women with a BMI less than 30 kg/m^2^ started hormone therapy (estrogen, progesterone, or progesterone plus estrogen) compared with women with a BMI of 30 or greater.^185^ In addition, the OPRCD retrospective cohort found the use of any hormone therapy was highest among women with a BMI less than 25 kg/m^2^ compared with the use in women with a higher BMI score.^184^ The WHI Observational Study found that a higher proportion of women with an intact uterus who used oral estradiol plus progestin (56%) and transdermal estradiol plus progestin (56%) had a BMI less than 25 kg/m^2^ compared with women who used oral CEE plus progestin (50%).^183^ Among women who had a prior hysterectomy, the proportion of women with a BMI less than 25 kg/m^2^ was similar across groups: oral CEE alone (41%) vs. oral estradiol alone (43%) vs. transdermal estradiol alone (42%).^183^