# Appendix I Eligible Observational Studies

1 Bethea TN, Palmer JR, Adams-Campbell LL, . A prospective study of reproductive factors and exogenous hormone use in relation to ovarian cancer risk among Black women. Cancer Causes Control. 2017 May;28(5):385–91. doi: 10.1007/s10552-016-0840-4. PMID: 28025764.28025764
2 Bhupathiraju SN, Grodstein F, Rosner BA, . Hormone therapy use and risk of chronic disease in the Nurses’ Health Study: a comparative analysis with the Women’s Health Initiative. Am J Epidemiol. 2017 Sep 15;186(6):696–708. doi: 10.1093/aje/kwx131. PMID: 28938710.28938710
3 Botteri E, Støer NC, Sakshaug S, . Menopausal hormone therapy and colorectal cancer: a linkage between nationwide registries in Norway. BMJ Open. 2017 Nov 15;7(11):e017639. doi: 10.1136/bmjopen-2017-017639. PMID: 29146641.29146641
4 Brusselaers N, Maret-Ouda J, Konings P, . Menopausal hormone therapy and the risk of esophageal and gastric cancer. Int J Cancer. 2017 Apr 1;140(7):1693–9. doi: 10.1002/ijc.30588. PMID: 28006838.28006838
5 Cervenka I, Al Rahmoun M, Mahamat-Saleh Y, . Postmenopausal hormone use and cutaneous melanoma risk: a French prospective cohort study. Int J Cancer. 2019 Oct 1;145(7):1754–67. doi: 10.1002/ijc.32150. PMID: 30671928.30671928
6 Curhan SG, Eliassen AH, Eavey RD, . Menopause and postmenopausal hormone therapy and risk of hearing loss. Menopause. 2017 Sep;24(9):1049–56. doi: 10.1097/gme.0000000000000878. PMID: 28486246.28486246
7 Dartois L, Fagherazzi G, Baglietto L, . Proportion of premenopausal and postmenopausal breast cancers attributable to known risk factors: estimates from the E3N-EPIC cohort. Int J Cancer. 2016 May 15;138(10):2415–27. doi: 10.1002/ijc.29987. PMID: 26756677.26756677
8 Eun Y, Jeon KH, Han K, . Menopausal factors and risk of seropositive rheumatoid arthritis in postmenopausal women: a nationwide cohort study of 1.36 million women. Sci Rep. 2020 Nov 27;10(1):20793. doi: 10.1038/s41598-020-77841-1. PMID: 33247198.33247198
9 Holm M, Olsen A, Au Yeung SL, . Pattern of mortality after menopausal hormone therapy: long-term follow up in a population-based cohort. BJOG. 2019 Jan;126(1):55–63. doi: 10.1111/1471-0528.15433. PMID: 30106241.30106241
10 Jeon KH, Shin DW, Han K, . Female reproductive factors and the risk of lung cancer in postmenopausal women: a nationwide cohort study. Br J Cancer. 2020 Apr;122(9):1417–24. doi: 10.1038/s41416-020-0789-7. PMID: 32203211.32203211
11 Jiang Y, Xie Q, Chen R. Breast cancer incidence and mortality in relation to hormone replacement therapy use among postmenopausal women: results from a prospective cohort study. Clin Breast Cancer. 2021 Jun 26doi: 10.1016/j.clbc.2021.06.010. PMID: 34548240.34548240
12 Jones ME, Schoemaker MJ, Wright L, . Menopausal hormone therapy and breast cancer: what is the true size of the increased risk? Br J Cancer. 2016 Aug 23;115(5):607–15. doi: 10.1038/bjc.2016.231. PMID: 27467055.27467055
13 Kabat GC, Kamensky V, Rohan TE. Reproductive factors, exogenous hormone use, and risk of pancreatic cancer in postmenopausal women. Cancer Epidemiol. 2017 Aug;49:1–7. doi: 10.1016/j.canep.2017.05.002. PMID: 28521283.28521283
14 Kilander C, Lagergren J, Konings P, . Menopausal hormone therapy and biliary tract cancer: a population-based matched cohort study in Sweden. Acta Oncol. 2019 Mar;58(3):290–5. doi: 10.1080/0284186x.2018.1549367. PMID: 30656997.30656997
15 Laaksonen MA, Arriaga ME, Canfell K, . The preventable burden of endometrial and ovarian cancers in Australia: a pooled cohort study. Gynecol Oncol. 2019 Jun;153(3):580–8. doi: 10.1016/j.ygyno.2019.03.102. PMID: 30935715.30935715
16 Liu Q, Simin J, Debelius J, . Menopausal hormone therapies and risk of colorectal cancer: a Swedish matched-cohort study. Aliment Pharmacol Ther. 2021 Jun;53(11):1216–25. doi: 10.1111/apt.16362. PMID: 33857339.33857339
17 Løkkegaard E, Nielsen LH, Keiding N. Risk of stroke with various types of menopausal hormone therapies: a national cohort study. Stroke. 2017 Aug;48(8):2266–9. doi: 10.1161/strokeaha.117.017132. PMID: 28626058.28626058
18 Mørch LS, Kjaer SK, Keiding N, . The influence of hormone therapies on type I and II endometrial cancer: a nationwide cohort study. Int J Cancer. 2016 Mar 15;138(6):1506–15. doi: 10.1002/ijc.29878. PMID: 26421912.26421912
19 Nwaru BI, Shah SA, Tibble H, . Hormone replacement therapy and risk of severe asthma exacerbation in perimenopausal and postmenopausal women: 17-year national cohort study. J Allergy Clin Immunol Pract. 2021 Jul;9(7):2751–60.e1. doi: 10.1016/j.jaip.2021.02.052. PMID: 33705997.33705997
20 Nyrønning L, Videm V, Romundstad PR, . Female sex hormones and risk of incident abdominal aortic aneurysm in Norwegian women in the HUNT study. J Vasc Surg. 2019 Nov;70(5):1436–45.e2. doi: 10.1016/j.jvs.2019.02.032. PMID: 31248762.31248762
21 Park SY, Wilkens LR, Kolonel LN, . Inverse associations of dietary fiber and menopausal hormone therapy with colorectal cancer risk in the Multiethnic Cohort Study. Int J Cancer. 2016 Sep 15;139(6):1241–50. doi: 10.1002/ijc.30172. PMID: 27137137.27137137
22 Peila R, Arthur R, Rohan TE. Risk factors for ductal carcinoma in situ of the breast in the UK Biobank cohort study. Cancer Epidemiol. 2020 Feb;64:101648. doi: 10.1016/j.canep.2019.101648. PMID: 31837535.31837535
23 Qureshi AI, Malik AA, Saeed O, . Hormone replacement therapy and the risk of subarachnoid hemorrhage in postmenopausal women. J Neurosurg. 2016 Jan;124(1):45–50. doi: 10.3171/2014.12.Jns142329. PMID: 26162033.26162033
24 Román M, Graff-Iversen S, Weiderpass E, . Postmenopausal hormone therapy and breast cancer prognostic characteristics: a linkage between nationwide registries. Cancer Epidemiol Biomarkers Prev. 2016;25(11):1464. doi: 10.1158/1055-9965.EPI-16-0240.27461048
25 Roura E, Travier N, Waterboer T, . The influence of hormonal factors on the risk of developing cervical cancer and pre-cancer: results from the EPIC Cohort. PLoS One. 2016;11(1):e0147029. doi: 10.1371/journal.pone.0147029. PMID: 26808155.26808155
26 Shah SA, Tibble H, Pillinger R, . Hormone replacement therapy and asthma onset in menopausal women: national cohort study. J Allergy Clin Immunol. 2020 Dec 3doi: 10.1016/j.jaci.2020.11.024. PMID: 33279576.33279576
27 Simin J, Tamimi R, Lagergren J, . Menopausal hormone therapy and cancer risk: an overestimated risk? Eur J Cancer. 2017 Oct;84:60–8. doi: 10.1016/j.ejca.2017.07.012. PMID: 28783542.28783542
28 Symer MM, Wong NZ, Abelson JS, . Hormone replacement therapy and colorectal cancer incidence and mortality in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. Clin Colorectal Cancer. 2018 Jun;17(2):e281–e8. doi: 10.1016/j.clcc.2018.01.003. PMID: 29398422.29398422
29 Vajaranant TS, Ray RM, Pasquale LR, . Racial differences in the effects of hormone therapy on incident open-angle glaucoma in a randomized trial. Am J Ophthalmol. 2018;195:110–20. doi: 10.1016/j.ajo.2018.07.035.30081016
30 Wang Z, Butler LM, Wu AH, . Reproductive factors, hormone use and gastric cancer risk: the Singapore Chinese Health Study. Int J Cancer. 2016 Jun 15;138(12):2837–45. doi: 10.1002/ijc.30024. PMID: 26829904.26829904