# Appendix H Meta-Analyses Forest Plots

Appendix H Figure 1 Forest Plot of Meta-Analyses: Estrogen Only, Coronary Heart Disease

Abbreviations: CI=confidence interval; EPAT=Estrogen in the Prevention of Atherosclerosis; HT=hormone therapy; PEPI=Postmenopausal Estrogen and Progestin Interventions Trial; REML=restricted maximum likelihood; WHI=Women’s Health Initiative.

This figure displays a forest plot of the relative risks of developing coronary heart disease after receiving estrogen only therapy versus placebo in three trials. The relative risk for developing coronary heart disease following treatment compared with placebo was 2.98 with a 95 percent confidence interval of 0.12 to 72.72 in the PEPI (1995) trial. The relative risk for developing coronary heart disease following treatment compared with placebo was 0.50 with a 95 percent confidence interval of 0.05 to 5.43 in the EPAT trial (Hodis, 2001). The relative risk for developing coronary heart disease following treatment compared with placebo was 0.95 with a 95 percent confidence interval of 0.78 to 1.14 in the WHI trial (Hsia, 2006). Meta-analysis of these three trials resulted in a relative risk of 0.95 with a 95 percent confidence interval of 0.79 to 1.14.

Appendix H Figure 2 Forest Plot of Meta-Analyses: Estrogen Only, All-Cause Mortality

Abbreviations: CI=confidence interval; ELITE=Early versus Late Intervention Trial with Estradiol, Cognitive Endpoints; ERA=Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis; HT=hormone therapy; REML=restricted maximum likelihood; WHI=Women’s Health Initiative.

This figure displays a forest plot of the relative risks of dying after receiving estrogen only therapy versus placebo in three trials. The relative risk for dying following treatment compared with placebo was 0.99 with a 95 percent confidence interval of 0.50 to 3.89 in the ERA trial (Herrington, 2000). The relative risk for dying following treatment compared with placebo was 1.40 with a 95 percent confidence interval of 0.06 to 15.77 in the ELITE-Cog trial (Henderson, 2016). The relative risk for dying following treatment compared with placebo was 1.03 with a 95 percent confidence interval of 0.88 to 1.21 in the WHI (LaCroix, 2011) trial. Meta-analysis of these three trials resulted in a relative risk of 1.04 with a 95 percent confidence interval of 0.89 to 1.21.

Appendix H Figure 3 Forest Plot of Meta-Analyses: Estrogen Plus Progestin, Coronary Heart Disease

Abbreviations: CI=confidence interval; EPHT=Estonian Postmenopausal Hormone Therapy Trial; HT=hormone therapy; PEPI=Postmenopausal Estrogen and Progestin Interventions Trial; REML=restricted maximum likelihood; WHI=Women’s Health Initiative.

This figure displays a forest plot of the relative risks of developing coronary heart disease after receiving estrogen plus progestin therapy versus placebo in three trials. The relative risk for developing coronary heart disease following treatment compared with placebo was 2.99 with a 95 percent confidence interval of 0.16 to 55.23 in the PEPI trial (1995). The relative risk for developing coronary heart disease following treatment compared with placebo was 4.62 with a 95 percent confidence interval of 0.22 to 95.86 in the EPHT trial (Veerus, 2006). The relative risk for developing coronary heart disease following treatment compared with placebo was 1.17 with a 95 percent confidence interval of 0.95 to 1.44 in the WHI trial (Manson, 2013). Meta-analysis of these three trials resulted in a relative risk of 1.12 with a 95 percent confidence interval of 0.94 to 1.33.

Appendix H Figure 4 Forest Plot of Meta-Analyses: Estrogen Plus Progestin, Fractures

Abbreviations: CI=confidence interval; EMS=Estrogen Memory Study; EPHT=Estonian Postmenopausal Hormone Therapy Trial; ERA=Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis; HERS=Heart and Estrogen/Progestin Replacement Study; REML=restricted maximum likelihood; WHI=Women’s Health Initiative.

This figure displays a forest plot of the relative risks of experiencing a fracture after receiving estrogen plus progestin therapy versus placebo in five trials. The relative risk of fracture following treatment compared with placebo was 0.47 with a 95 percent confidence interval of 0.20 to 1.11 in the ERA trial (Herrington, 2000). The relative risk of fracture following treatment compared with placebo was 0.55 with a 95 percent confidence interval of 0.30 to 1.03 in the EPHT trial (Veerus, 2006). The relative risk of fracture following treatment compared with placebo was 0.44 with a 95 percent confidence interval of 0.12 to 1.64 in the EMS trial (Tierney, 2009). The relative risk of fracture following treatment compared with placebo was 0.78 with a 95 percent confidence interval of 0.71 to 0.86 in the WHI trial (Manson, 2013). The relative risk of fracture following treatment compared with placebo was 0.95 with a 95 percent confidence interval of 0.76 to 1.18 in the HERS trial (Hulley, 2002). Meta-analysis of these five trials resulted in a relative risk of 0.79 with a 95 percent confidence interval of 0.66 to 0.94.

Appendix H Figure 5 Forest Plot of Meta-Analyses: Estrogen Plus Progestin, All-Cause Mortality

Abbreviations: CI=confidence interval; ERA=Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis; HERS=Heart and Estrogen/Progestin Replacement Study; HT=hormone therapy; REML=restricted maximum likelihood; WHI=Women’s Health Initiative.

This figure displays a forest plot of the relative risks of dying after receiving estrogen plus progestin therapy versus placebo in three trials. The relative risk for dying following treatment compared with placebo was 0.50 with a 95 percent confidence interval of 0.13 to 1.97 in the ERA trial (Herrington, 2000). The relative risk for dying following treatment compared with placebo was 1.06 with a 95 percent confidence interval of 0.84 to 1.34 in the HERS trial (Hulley, 2002). The relative risk for dying following treatment compared with placebo was 1.00 with a 95 percent confidence interval 0.84 to 1.19 in the WHI I trial (Heiss, 2008). Meta-analysis of these 3 trials resulted in a relative risk of 1.01 with a 95 percent confidence interval of 0.88 to 1.16.