# Appendix G Hazard Ratios

Appendix G Figure 1 Hazard Ratios for Invasive Breast Cancer for Estrogen-Only Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for invasive breast cancer for estrogen-only trials. The hazard ratio for Manson, 2013 (WHI intervention) at 7.2 years followup was 0.79 with a 95 percent confidence interval of 0.61 to 1.02. The hazard ratio for Manson, 2013 (WHI postintervention) at 6.6 years followup was 0.80 with a 95 percent confidence interval of 0.58 to 1.11. The hazard ratio for Manson, 2017 (WHI postintervention) at 10.8 years followup was 0.57 with a 95 percent confidence interval of 0.32 to 1.02. The hazard ratio for Manson, 2013 (WHI cumulative) at 13 years followup was 0.79 with a 95 percent confidence interval of 0.65 to 0.97. The hazard ratio for Prentice, 2020 (WHI cumulative) at 19.4 years followup was 0.80 with a 95 percent confidence interval of 0.68 to 0.95. The hazard ratio for Chlebowski, 2020 (WHI cumulative) at 20.7 years followup was 0.78 with a 95 percent confidence interval of 0.65 to 0.93.

Appendix G Figure 2 Hazard Ratios for Breast Cancer Mortality for Estrogen-Only Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for breast cancer mortality for estrogen-only trials. The hazard ratio for Manson, 2017 (WHI intervention) at 7.2 years followup was 0.45 with a 95 percent confidence interval of 0.14 to 1.45. The hazard ratio for Manson, 2017 (WHI cumulative) at 17.7 years followup was 0.55 with a 95 percent confidence interval of 0.33 to 0.92. The hazard ratio for Chlebowski, 2020 (WHI cumulative) at 20.7 years followup was 0.60 with a 95 percent confidence interval of 0.37 to 0.97.

Appendix G Figure 3 Hazard Ratios for Lung Cancer for Estrogen-Only Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for lung cancer for estrogen-only trials. The hazard ratio for Manson, 2013 (WHI intervention) at 7.2 years followup was 1.05 with a 95 percent confidence interval of 0.74 to 1.49. The hazard ratio for Manson, 2013 (WHI postintervention) at 6.6 years followup was 0.90 with a 95 percent confidence interval of 0.61 to 1.33. The hazard ratio for Manson, 2013 (WHI cumulative) at 13 years followup was 0.98 with a 95 percent confidence interval of 0.75 to 1.28.

Appendix G Figure 4 Hazard Ratios for Total Cancer Mortality for Estrogen-Only Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for total cancer mortality for estrogen-only trials. The hazard ratio for Manson, 2017 (WHI intervention) at 7.2 years followup was 0.96 with a 95 percent confidence interval of 0.75 to 1.22. The hazard ratio for Manson, 2017 (WHI postintervention) at 10.8 years followup was 1.00 with a 95 percent confidence interval of 0.85 to 1.17. The hazard ratio for Manson, 2013 (WHI cumulative) at 13 years followup was 0.95 with a 95 percent confidence interval of 0.81 to 1.13. The hazard ratio for Manson, 2017 (WHI cumulative) at 17.7 years followup was 0.99 with a 95 percent confidence interval of 0.86 to 1.13.

Appendix G Figure 5 Hazard Ratios for COPD Mortality for Estrogen-Only Trials

Abbreviations: CI=confidence interval; COPD=chronic obstructive pulmonary disease.

The figure displays a forest plot of the hazard ratios for COPD mortality for estrogen-only trials. The hazard ratio for Manson, 2017 (intervention) at 7.2 years followup was 0.76 with a 95 percent confidence interval of 0.26 to 2.20. The hazard ratio for Manson, 2017 (postintervention) at 10.8 years followup was 1.09 with a 95 percent confidence interval of 0.79 to 1.51. The hazard ratio for Manson, 2017 (cumulative) at 17.7 years followup was 1.07 with a 95 percent confidence interval of 0.78 to 1.45.

Appendix G Figure 6 Hazard Ratios for Coronary Heart Disease for Estrogen-Only Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for coronary heart disease for estrogen-only trials. The hazard ratio for Hsia, 2006 (WHI intervention) at 7.2 years followup was 0.95 with a 95 percent confidence interval of 0.79 to 1.16. The hazard ratio for LaCroix, 2011 (WHI postintervention) at 3.9 years followup was 0.97 with a 95 percent confidence interval of 0.75 to 1.25. The hazard ratio for Manson, 2013 (WHI cumulative) at 13 years followup was 0.94 with a 95 percent confidence interval of 0.82 to 1.09. The hazard ratio for Prentice, 2020 (WHI cumulative) at 19.4 years followup was 0.97 with a 95 percent confidence interval of 0.86 to 1.09.

Appendix G Figure 7 Hazard Ratios for Coronary Heart Disease Mortality for Estrogen-Only Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for coronary heart disease mortality for estrogen-only trials. The hazard ratio for Manson, 2017 (WHI intervention) at 7.2 years followup was 1.02 with a 95 percent confidence interval of 0.72 to 1.43. The hazard ratio for Manson, 2017 (WHI postintervention) at 10.8 years followup was 0.84 with a 95 percent confidence interval of 0.69 to 1.03. The hazard ratio for Manson, 2017 (WHI cumulative) at 17.7 years followup was 0.89 with a 95 percent confidence interval of 0.75 to 1.05.

Appendix G Figure 8 Hazard Ratios for Dementia-Related Mortality for Estrogen-Only Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for dementia-related mortality for estrogen-only trials. The hazard ratio for Manson, 2017 (WHI intervention) at 7.2 years followup was 0.90 with a 95 percent confidence interval of 0.27 to 2.95. The hazard ratio for Manson, 2017 (WHI postintervention) at 10.8 years followup was 0.73 with a 95 percent confidence interval of 0.58 to 0.98. The hazard ratio for Manson, 2017 (WHI cumulative) at 17.7 years followup was 0.74 with a 95 percent confidence interval of 0.59 to 0.94.

Appendix G Figure 9 Hazard Ratios for Incident Diabetes for Estrogen-Only Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for incident diabetes for estrogen-only trials. The hazard ratio for Manson, 2013 (WHI intervention) at 7.2 years followup was 0.86 with a 95 percent confidence interval of 0.76 to 0.98. The hazard ratio for Manson, 2013 (WHI postintervention) at 6.6 years followup was 1.07 with a 95 percent confidence interval of 0.92 to 1.25. The hazard ratio for Manson, 2013 (WHI cumulative) at 13 years followup was 0.94 with a 95 percent confidence interval of 0.85 to 1.04.

Appendix G Figure 10 Effect Estimates for Total Fractures for Estrogen-Only Trials

* The ERA trial’s effect estimate was a calculated risk ratio.

Abbreviations: CI=confidence interval; ERA=Estrogen Replacement and Atherosclerosis; WHI=Women’s Health Initiative.

The figure displays a forest plot of the effect estimates for total fractures for estrogen-only trials. The effect estimate for Herrington, 2000 (ERA intervention) at 3.2 years followup was 0.42 with a 95 percent confidence interval of 0.17 to 1.04. The effect estimate for Manson, 2013 (WHI intervention) at 7.2 years followup was 0.72 with a 95 percent confidence interval of 0.64 to 0.80. The effect estimate for Watts, 2017 (WHI postintervention) at 4.3 years followup was 0.85 with a 95 percent confidence interval of 0.73 to 0.98.

Appendix G Figure 11 Hazard Ratios for Stroke for Estrogen-Only Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for stroke for estrogen-only trials. The hazard ratio for Manson, 2013 (WHI intervention) at 7.2 years followup was 1.35 with a 95 percent confidence interval of 1.07 to 1.70. The hazard ratio for LaCroix, 2011 (WHI postintervention) at 3.9 years followup was 0.89 with a 95 percent confidence interval of 0.64 to 1.24. The hazard ratio for Manson, 2013 (WHI cumulative) at 13 years followup was 1.15 with a 95 percent confidence interval of 0.97 to 1.37. The hazard ratio for Prentice, 2020 (WHI cumulative) at 19.4 years followup was 1.06 with a 95 percent confidence interval of 0.92 to 1.22.

Appendix G Figure 12 Effect Estimates for Incident Weekly Urinary Incontinence for Estrogen-Only Trials

* The ULTRA trial’s effect estimate was an odds ratio.

Abbreviations: CI=confidence interval; ULTRA=Ultra Low-Dose Transdermal Estrogen Replacement Assessment; WHI=Women’s Health Initiative.

The figure displays a forest plot of the effect estimates for incident weekly urinary incontinence for estrogen-only trials. The effect estimate for Manson, 2013 (WHI intervention) at 1 year followup was 1.61 with a 95 percent confidence interval of 1.46 to 1.79. The effect estimate for Waetjen, 2005 (ULTRA followup) at 2 years followup was 1.20 with a 95 percent confidence interval of 0.70 to 2.30. The effect estimate for Manson, 2013 (WHI postintervention) at 6.6 years followup was 1.24 with a 95 percent confidence interval of 1.13 to 1.36.

Appendix G Figure 13 Hazard Ratios for Deep Vein Thrombosis for Estrogen-Only Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for deep vein thrombosis for estrogen-only trials. The hazard ratio for Manson, 2013 (WHI intervention) at 7.2 years followup was 1.48 with a 95 percent confidence interval of 1.06 to 2.07. The hazard ratio for LaCroix, 2011 (WHI postintervention) at 3.9 years followup was 0.63 with a 95 percent confidence interval of 0.41 to 0.98. The hazard ratio for Manson, 2013 (WHI cumulative) at 13 years followup was 1.05 with a 95 percent confidence interval of 0.82 to 1.33.

Appendix G Figure 14 Hazard Ratios for Pulmonary Embolism for Estrogen-Only Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for pulmonary embolism for estrogen-only trials. The hazard ratio for Manson, 2013 (WHI intervention) at 7.2 years followup was 1.35 with a 95 percent confidence interval of 0.89 to 2.05. The hazard ratio for LaCroix, 2011 (WHI postintervention) at 3.9 years followup was 0.98 with a 95 percent confidence interval of 0.62 to 1.55. The hazard ratio for Manson, 2013 (WHI cumulative) at 13 years followup was 1.15 with a 95 percent confidence interval of 0.87 to 1.51.

Appendix G Figure 15 Hazard Ratios for All-Cause Mortality for Estrogen-Only Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for all-cause mortality for estrogen-only trials. The hazard ratio for LaCroix, 2011 (WHI intervention) at 7.2 years followup was 1.04 with a 95 percent confidence interval of 0.89 to 1.22. The hazard ratio for LaCroix, 2011 (WHI postintervention) at 3.9 years followup was 1.00 with a 95 percent confidence interval of 0.84 to 1.18. The hazard ratio for Manson, 2017 (WHI postintervention) at 10.8 years followup was 0.92 with a 95 percent confidence interval of 0.85 to 0.99. The hazard ratio for Manson, 2013 (WHI cumulative) at 13 years followup was 0.99 with a 95 percent confidence interval of 0.90 to 1.10. The hazard ratio for Manson, 2017 (WHI cumulative) at 17.7 years followup was 0.94 with a 95 percent confidence interval of 0.88 to 1.01. The hazard ratio for Prentice, 2020 (WHI cumulative) at 19.4 years followup was 0.97 with a 95 percent confidence interval of 0.91 to 1.03.

Appendix G Figure 16 Hazard Ratios for Invasive Breast Cancer for Estrogen Plus Progestin Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for invasive breast cancer for estrogen plus progestin trials. The hazard ratio for Manson, 2013 (WHI intervention) at 5.6 years followup was 1.24 with a 95 percent confidence interval of 1.01 to 1.52. The hazard ratio for Heiss, 2008 (WHI postintervention) at 2.4 years followup was 1.27 with a 95 percent confidence interval of 0.91 to 1.78. The hazard ratio for Manson, 2013 (WHI postintervention) at 8.2 years followup was 1.32 with a 95 percent confidence interval of 1.08 to 1.61. The hazard ratio for Chlebowski, 2016 (WHI cumulative) at 13.2 years followup was 1.28 with a 95 percent confidence interval of 1.11 to 1.48. The hazard ratio for Chlebowski, 2020 (WHI cumulative) at 18.9 years followup was 1.28 with a 95 percent confidence interval of 1.13 to 1.45. The hazard ratio for Prentice, 2020 (WHI cumulative) at 19.4 years followup was 1.28 with a 95 percent confidence interval of 1.13 to 1.45.

Appendix G Figure 17 Hazard Ratios for Breast Cancer Mortality for Estrogen Plus Progestin Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for breast cancer mortality for estrogen plus progestin trials. The hazard ratio for Manson, 2017 (WHI intervention) at 5.6 years followup was 1.08 with a 95 percent confidence interval of 0.29 to 4.03. The hazard ratio for Chlebowski, 2010 (WHI cumulative) at 11 years followup was 1.96 with a 95 percent confidence interval of 1.00 to 4.04. The hazard ratio for Manson, 2017 (WHI postintervention) at 12.5 years followup was 1.50 with a 95 percent confidence interval of 0.99 to 2.28. The hazard ratio for Manson, 2017 (WHI cumulative) at 17.7 years followup was 1.44 with a 95 percent confidence interval of 0.97 to 2.15. The hazard ratio for Chlebowski, 2020 (WHI cumulative) at 20.3 years followup was 1.35 with a 95 percent confidence interval of 0.94 to 1.94.

Appendix G Figure 18 Hazard Ratios of Colorectal Cancer for Estrogen Plus Progestin Trials

Abbreviations: CI=confidence interval; HERS=Heart and Estrogen/Progestin Replacement Study; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for colorectal cancer for estrogen plus progestin trials. The hazard ratio for Hulley, 2002 (HERS intervention) at 4.1 years followup was 0.69 with a 95 percent confidence interval of 0.32 to 1.49. The hazard ratio for Manson, 2013 (WHI intervention) at 5.6 years followup was 0.62 with a 95 percent confidence interval of 0.43 to 0.89. The hazard ratio for Hulley, 2002 (HERS cumulative) at 6.8 years followup was 0.82 with a 95 percent confidence interval of 0.46 to 1.47. The hazard ratio for Manson, 2013 (WHI postintervention) at 8.2 years followup was 0.97 with a 95 percent confidence interval of 0.70 to 1.33. The hazard ratio for Chlebowski, 2019 (WHI cumulative) at 13.2 years followup was 0.80 with a 95 percent confidence interval of 0.63 to 1.01.

Appendix G Figure 19 Hazard Ratios for Endometrial Cancer for Estrogen Plus Progestin Trials

Abbreviations: CI=confidence interval; HERS=Heart and Estrogen/Progestin Replacement Study; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for endometrial cancer for estrogen plus progestin trials. The hazard ratio for Hulley, 2002 (HERS intervention) at 4.1 years followup was 0.39 with a 95 percent confidence interval of 0.08 to 2.02. The hazard ratio for Manson, 2013 (WHI intervention) at 5.6 years followup was 0.83 with a 95 percent confidence interval of 0.49 to 1.40. The hazard ratio for Hulley, 2002 (HERS cumulative) at 6.8 years followup was 0.25 with a 95 percent confidence interval of 0.05 to 1.18. The hazard ratio for Chlebowski, 2016 (WHI postintervention) at 8.2 years followup was 0.59 with a 95 percent confidence interval of 0.40 to 0.88. The hazard ratio for Chlebowski, 2020 (WHI cumulative) at 13.2 years followup was 0.65 with a 95 percent confidence interval of 0.48 to 0.89.

Appendix G Figure 20 Hazard Ratios for Lung Cancer for Estrogen Plus Progestin Trials

Abbreviations: CI=confidence interval; HERS=Heart and Estrogen/Progestin Replacement Study; WHI=Women’s Health Initiatives.

The figure displays a forest plot of the hazard ratios for lung cancer for estrogen plus progestin trials. The hazard ratio for Hulley, 2002 (HERS intervention) at 4.1 years followup was 1.28 with a 95 percent confidence interval of 0.70 to 2.33. The hazard ratio for Manson, 2013 (WHI intervention) at 5.6 years followup was 1.05 with a 95 percent confidence interval of 0.76 to 1.45. The hazard ratio for Hulley, 2002 (HERS cumulative) at 6.8 years followup was 1.43 with a 95 percent confidence interval of 0.87 to 2.37. The hazard ratio for Manson, 2013 (WHI postintervention) at 8.2 years followup was 1.13 with a 95 percent confidence interval of 0.86 to 1.47. The hazard ratio for Chlebowski, 2019 (WHI cumulative) at 14 years followup was 1.12 with a 95 percent confidence interval of 0.92 to 1.37.

Appendix G Figure 21 Hazard Ratios for Total Cancer Mortality for Estrogen Plus Progestin Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for total cancer mortality for estrogen plus progestin trials. The hazard ratio for Manson, 2017 (WHI intervention) at 5.6 years followup was 1.10 with a 95 percent confidence interval of 0.86 to 1.42. The hazard ratio for Manson, 2017 (WHI postintervention) at 12.5 years followup was 1.05 with a 95 percent confidence interval of 0.93 to 1.18. The hazard ratio for Manson, 2013 (WHI cumulative) at 13.2 years followup was 1.07 with a 95 percent confidence interval of 0.93 to 1.23. The hazard ratio for Manson, 2017 (WHI cumulative) at 17.7 years followup was 1.06 with a 95 percent confidence interval of 0.95 to 1.18.

Appendix G Figure 22 Hazard Ratios for COPD Mortality for Estrogen Plus Progestin Trials

Abbreviations: CI=confidence interval; COPD=chronic obstructive pulmonary disease; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for COPD mortality for estrogen plus progestin trials. The hazard ratio for Manson, 2017 (WHI intervention) at 5.6 years followup was 0.12 with a 95 percent confidence interval of 0.01 to 0.93. The hazard ratio for Manson, 2017 (WHI postintervention) at 12.5 years followup was 1.13 with a 95 percent confidence interval of 0.85 to 1.49. The hazard ratio for Manson, 2017 (WHI cumulative) at 17.7 years followup was 1.03 with a 95 percent confidence interval of 0.79 to 1.36.

Appendix G Figure 23 Hazard Ratios for Coronary Heart Disease for Estrogen Plus Progestin Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for coronary heart disease for estrogen plus progestin trials. The hazard ratio for Manson, 2013 (WHI intervention) at 5.6 years followup was 1.18 with a 95 percent confidence interval of 0.96 to 1.45. The hazard ratio for Heiss, 2008 (WHI postintervention) at 2.4 years followup was 1.04 with a 95 percent confidence interval of 0.89 to 1.21. The hazard ratio for Manson, 2013 (WHI cumulative) at 13.2 years followup was 1.09 with a 95 percent confidence interval of 0.96 to 1.24. The hazard ratio for Prentice, 2020 (WHI cumulative) at 19.4 years followup was 1.06 with a 95 percent confidence interval of 0.95 to 1.17.

Appendix G Figure 24 Hazard Ratios for Coronary Heart Disease Mortality for Estrogen Plus Progestin Trials

Abbreviations: CI=confidence interval; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for coronary heart disease mortality for estrogen plus progestin trials. The hazard ratio for Manson, 2017 (WHI intervention) at 5.6 years followup was 0.94 with a 95 percent confidence interval of 0.60 to 1.46. The hazard ratio for Manson, 2017 (WHI postintervention) at 12.5 years followup was 1.08 with a 95 percent confidence interval of 0.91 to 1.28. The hazard ratio for Manson, 2017 (WHI cumulative) at 17.7 years followup was 1.05 with a 95 percent confidence interval of 0.89 to 1.23.

Appendix G Figure 25 Hazard Ratios for Incident Diabetes for Estrogen Plus Progestin Trials

Abbreviations: CI=confidence interval; HERS=Heart and Estrogen/progestin Replacement Study; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for incident diabetes for estrogen plus progestin trials. The hazard ratio for Kanya, 2003 (HERS intervention) at 4.1 years followup was 0.65 with a 95 percent confidence interval of 0.48 to 0.89. The hazard ratio for Manson, 2004 (WHI intervention) at 5.6 years followup was 0.81 with a 95 percent confidence interval of 0.70 to 0.94. The hazard ratio for Manson, 2013 (WHI postintervention) at 8.2 years followup was 1.19 with a 95 percent confidence interval of 1.05 to 1.34. The hazard ratio for Manson, 2013 (WHI cumulative) at 13.2 years followup was 1.02 with a 95 percent confidence interval of 0.93 to 1.12.

Appendix G Figure 26 Hazard Ratios for Total Fractures for Estrogen Plus Progestin Trials

* The ERA trial’s effect estimate was a calculated risk ratio.

Abbreviations: CI=confidence interval; EPHT=Estonian Postmenopausal Hormones Therapy Trial; ERA=Estrogen Replacement and Atherosclerosis; HERS=Heart and Estrogen/progestin Replacement Study; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for total fractures for estrogen plus progestin trials. The calculated risk ratio for Herrington, 2000 (ERA intervention) at 3.2 years followup was 0.47 with a 95 percent confidence interval of 0.24 to 1.11. The hazard ratio for Hulley, 2002 (HERS intervention) at 4.1 years followup was 0.96 with a 95 percent confidence interval of 0.76 to 1.20. The hazard ratio for Veerus, 2006 (EPHT intervention) at 5 years followup was 0.52 with a 95 percent confidence interval of 0.27 to 0.98. The hazard ratio for Manson, 2013 (WHI intervention) at 5.6 years followup was 0.76 with a 95 percent confidence interval of 0.69 to 0.83. The hazard ratio for Heiss, 2008 (WHI postintervention) at 2.4 years followup was 0.91 with a 95 percent confidence interval of 0.78 to 1.06. The hazard ratio for Watts, 2017 (WHI postintervention) at 4.2 years followup was 0.97 with a 95 percent confidence interval of 0.87 to 1.09.

Appendix G Figure 27 Hazard Ratios for Stroke for Estrogen Plus Progestin Trials

Abbreviations: CI=confidence interval; EPHT=Estonian Postmenopausal Hormones Therapy Trial; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for stroke for estrogen plus progestin trials. The calculated risk ratio for Veerus, 2006 (EPHT intervention) at 3.4 years followup was 1.06 with a 95 percent confidence interval of 0.07 to 17.2. The hazard ratio for Manson, 2013 (WHI intervention) at 5.6 years followup was 1.37 with a 95 percent confidence interval of 1.07 to 1.76. The hazard ratio for Manson, 2013 (WHI postintervention) at 2.4 years followup was 1.04 with a 95 percent confidence interval of 0.86 to 1.26. The hazard ratio for Manson, 2013 (WHI cumulative) at 13.2 years followup was 1.16 with a 95 percent confidence interval of 1.00 to 1.35. The hazard ratio for Prentice, 2020 (WHI cumulative) at 19.4 years followup was 1.13 with a 95 percent confidence interval of 1.00 to 1.27.

Appendix G Figure 28 Effect Estimates for Incident Weekly Urinary Incontinence for Estrogen Plus Progestin Trials

* The HERS trial’s effect estimate was an odds ratio.

Abbreviations: CI=confidence interval; HERS=Heart and Estrogen/Progestin Replacement Study; WHI=Women’s Health Initiative.

The figure displays a forest plot of the effect estimates for incident weekly urinary incontinence for estrogen plus progestin trials. The hazard ratio for Manson, 2013 (WHI intervention) at 1 year followup was 1.49 with a 95 percent confidence interval of 1.36 to 1.63. The odds ratio for Steinauer, 2005 (HERS intervention) at 4.2 years followup was 1.60 with a 95 percent confidence interval of 1.30 to 1.90. The hazard ratio for Manson, 2013 (WHI postintervention) at 8.2 years followup was 1.16 with a 95 percent confidence interval of 1.08 to 1.25.

Appendix G Figure 29 Hazard Ratios for Deep Vein Thrombosis for Estrogen Plus Progestin Trials

Abbreviations: CI=confidence interval; HERS=Heart and Estrogen/Progestin Replacement Study; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for deep vein thrombosis for estrogen plus progestin trials. The hazard ratio for Hulley, 2002 (HERS intervention) at 4.1 years followup was 2.82 with a 95 percent confidence interval of 1.32 to 6.04. The hazard ratio for Manson, 2013 (WHI intervention) at 5.6 years followup was 1.87 with a 95 percent confidence interval of 1.37 to 2.54. The hazard ratio for Heiss, 2008 (WHI postintervention) at 2.4 years followup was 1.07 with a 95 percent confidence interval of 0.66 to 1.75. The hazard ratio for Manson, 2013 (WHI cumulative) at 13.2 years followup was 1.24 with a 95 percent confidence interval of 1.01 to 1.53.

Appendix G Figure 30 Hazard Ratios for Pulmonary Embolism for Estrogen Plus Progestin Trials

Abbreviations: CI=confidence interval; HERS=Heart and Estrogen/Progestin Replacement Study; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for pulmonary embolism for estrogen plus progestin trials. The hazard ratio for Hulley, 2002 (HERS intervention) at 4.1 years followup was 2.78 with a 95 percent confidence interval of 0.89 to 8.74. The hazard ratio for Manson, 2013 (WHI intervention) at 5.6 years followup was 1.98 with a 95 percent confidence interval of 1.36 to 2.87. The hazard ratio for Heiss, 2008 (WHI postintervention) at 2.4 years followup was 1.07 with a 95 percent confidence interval of 0.62 to 1.86. The hazard ratio for Manson, 2013 (WHI cumulative) at 13.2 years followup was 1.26 with a 95 percent confidence interval of 1.00 to 1.59.

Appendix G Figure 31 Hazard Ratios for All-Cause Mortality for Estrogen Plus Progestin Trials

Abbreviations: CI=confidence interval; HERS=Heart and Estrogen/Progestin Replacement Study; WHI=Women’s Health Initiative.

The figure displays a forest plot of the hazard ratios for all-cause mortality for estrogen plus progestin trials. The hazard ratio for Hulley, 2002 (HERS intervention) at 4.1 years followup was 1.06 with a 95 percent confidence interval of 0.83 to 1.36. The hazard ratio for Heiss, 2008 (WHI intervention) at 5.6 years followup was 0.97 with a 95 percent confidence interval of 0.81 to 1.16. The hazard ratio for Heiss, 2008 (WHI postintervention) at 2.4 years followup was 1.15 with a 95 percent confidence interval of 0.95 to 1.39. The hazard ratio for Manson, 2013 (WHI postintervention) at 8.2 years followup was 1.01 with a 95 percent confidence interval of 0.91 to 1.11. The hazard ratio for Manson, 2017 (WHI postintervention) at 12.5 years followup was 1.04 with a 95 percent confidence interval of 0.97 to 1.10. The hazard ratio for Hulley, 2002 (HERS cumulative) at 6.8 years followup was 1.10 with a 95 percent confidence interval of 0.92 to 1.31. The hazard ratio for Manson, 2013 (WHI cumulative) at 13.2 years followup was 0.99 with a 95 percent confidence interval of 0.91 to 1.08. The hazard ratio for Manson, 2017 (WHI cumulative) at 17.7 years followup was 1.02 with a 95 percent confidence interval of 0.96 to 1.08. The hazard ratio for Prentice, 2020 (WHI cumulative) at 19.4 years followup was 1.02 with a 95 percent confidence interval of 0.97 to 1.08.