# Appendix F Outcome Tables

Appendix F Table 1 Outcomes From Trials Reporting Incidence of Breast Cancer

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
EPAT Estrogen-only trial; Hodis, 2001^112^ | 111 Estrogen; 111 Placebo | [underlined: Intervention followup: Mean 2 years]; Breast cancer (not defined); 0 (0%) vs. 1 (1%)
EPHT Estrogen plus progestin trial; Veerus, 2006^137^ | 404 Estrogen plus progestin; 373 Placebo | [underlined: Intervention followup: Mean 3.4 years]; Breast cancer (not defined); 1 (0.2%) vs. 2 (0.5%); HR, 0.55 (95% CI, 0.05 to 6.06)
ERA Estrogen-only and estrogen plus progestin trial; Herrington, 2000^113^ | 100 Estrogen alone; 104 Estrogen plus progestin; 105 Placebo | [underlined: Intervention followup: Mean 3.2 years]; Breast cancer (not defined); 1 vs. 0 vs. 0; p=0.35
Greenspan, et al Estrogen-only and estrogen plus progestin trial; Greenspan, 2005^107^ | 66 Estrogen; 121 Estrogen plus progestin; 186 Placebo | [underlined: Intervention followup: Mean 3 years]; Breast cancer (not defined); Analysis did not stratify by treatment regimen; 2 (hormone therapy) vs. 2; p=1.0
HERS Estrogen plus progestin trial; Hulley, 2002^136^ | 1380 Estrogen plus progestin; 1383 Placebo; Cumulative followup:; 1156 Estrogen plus progestin; 1383 Placebo | [underlined: Intervention followup: Mean 4.1 years]; Breast cancer (not defined); 34 (2.5%) vs. 25 (1.8%); HR, 1.38 (95% CI, 0.82 to 2.31); p=0.22; [underlined: Postintervention followup: Mean 2.7 years]; Breast cancer (not defined); HR, 1.08 (95% CI, 0.52 to 2.24); p=0.83; [underlined: Cumulative followup: Mean 6.8 years]; Breast cancer (not defined); HR, 1.27 (95% CI, 0.84 to 1.94); p=0.26
PEPI Estrogen-only and estrogen plus progestin trial; Writing Group for PEPI trial, 1995^32^ | 175 Estrogen; 174 Estrogen plus progestin (cyclic); 174 Estrogen plus progestin (continuous); 178 Estrogen plus progestin (micronized); 174 Placebo | [underlined: Intervention followup: Mean 3 years]; Breast cancer (not defined); 1 (estrogen) vs. 2 (estrogen plus progestin) vs. 4 (estrogen plus micronized progestin) vs. 1 (placebo); p=0.29
STOP-IT Estrogen-only and estrogen plus progestin trial; Gallagher, 2001^106^ | 121 Hormone therapy; 122 Hormone therapy plus calcitriol; 123 Calcitriol only; 123 Placebo | [underlined: Intervention followup: Mean 3 years]; Breast cancer (not defined); Analysis did not stratify by treatment regimen; 0 (hormone therapy with or without calcitriol) vs. 4 (calcitriol only and placebo)
WAVE Estrogen-only and estrogen plus progestin trial; Waters, 2002^105^ | 124 Estrogen; 86 Estrogen plus progestin; 213 Placebo | [underlined: Intervention followup: Mean 2.8 years]; Breast cancer (any); Analysis did not stratify by treatment regimen; 3 vs. 1; p=0.37
WHI Estrogen-only trial; Anderson, 2004;^37^ Anderson, 2012;^109^ LaCroix, 2011;^108^ Prentice, 2009;^110^ Manson, 2013;^67^ Chlebowski, 2015;^111^ Manson, 2019;^89^ Chlebowski, 2016;^90^ Chlebowski, 2020;^87^ Chlebowski, 2017;^95^ Prentice, 2019;^101^ Prentice, 2020;^91^ Manson, 2017^88^ | 5,310 Estrogen; 5,429 Placebo; Postintervention extension followup:; 3,778 Estrogen; 3,867 Placebo; Cumulative followup (intervention plus postintervention extension phases):; 4,911 Estrogen; 5,028 Placebo | [underlined: Intervention followup: Median 7.2 years]; Invasive breast cancer^67,^ ^108^; 104 (0.28%) vs. 135 (0.35%); HR, 0.79 (95% CI, 0.61 to 1.02); p=0.07; Subgroups:; No significant differences by race,^95^ age at randomization,^67,^ ^111^ and oophorectomy status^89^; Risk based on timing of intervention: No significant differences by timing of intervention^67,^ ^110^; Breast cancer mortality ^88^; 4 (0.010% annualized) vs. 9 (0.023%); HR, 0.45 (95% CI, 0.14 to 1.46); p=0.17; Subgroups:; No significant difference by age at randomization; [underlined: Postintervention followup: Median 6.6 years] ^67^; Invasive breast cancer; HR, 0.80 (95% CI, 0.58 to 1.11); p=0.19; [underlined: Postintervention followup: Median 10.8 years] ^88^; Invasive breast cancer; 18 (0.037% annualized) vs. 32 (0.065% annualized); HR, 0.57 (95% CI, 0.32 to 1.02); p=0.06; Subgroups:; No significant difference by age at randomization; [underlined: Cumulative followup: Median 13.0 years]; Invasive breast cancer; 168 (0.28% annualized) vs. 216 (0.35% annualized); HR, 0.79 (95% CI, 0.65 to 0.97); p=0.02^67^; Subgroups:; No significant differences by age^67^ or race^90,^ ^95^; [underlined: Cumulative followup: Median 17.7 years] ^88^; Breast cancer mortality; 22 (0.025% annualized) vs. 41 (0.046% annualized); HR, 0.55 (95% CI, 0.33 to 0.92); p=0.02; Subgroups:; No significant difference by age at randomization; [underlined: Cumulative followup: Median 18.0 years] ^91^; Invasive breast cancer; 231 (0.30% annualized) vs. 291 (0.38% annualized); no HR reported; p=NR; Subgroups:; No significant difference by age^91^ or oophorectomy status^89^; [underlined: Cumulative followup: Median 19.4 years] ^101^; Invasive breast cancer; 231 (4.4% calculated) vs. 291 (5.4% calculated); HR, 0.80 (95% CI, 0.68 to 0.95); p=NR; [underlined: Cumulative followup: Median 20.7 years] * ^†^ ^87^; Invasive breast cancer; 238 (0.30%) vs. 296 (0.37%); HR, 0.78 (95% CI, 0.65 to 0.93); p=0.005; Breast cancer mortality; 30 (0.031%) vs. 46 (0.046%); HR, 0.60 (95% CI, 0.37 to 0.97); p=0.04; Subgroups:; No significant differences by age, race/ethnicity, and oophorectomy status; Risk based on timing of intervention:; No significant differences by timing of intervention
WHI Estrogen plus progestin trial; Writing Group for the WHI, 2002;^36^ Heiss, 2008;^132^ Chlebowski, 2003;^133^ Chlebowski, 2010;^134^ Gramling, 2009;^135^ Prentice, 2009^110^; Manson, 2013;^67^ Chlebowski, 2015;^111^ Chlebowski, 2016;^90^ Chlebowski, 2020;^87^ Prentice, 2019;^101^ Prentice, 2020^88,^ ^91^ | 8,506 Estrogen plus progestin 8,102 Placebo; Postintervention extension followup:; 6,545 Estrogen plus progestin; 6,243 Placebo; Cumulative followup^87,^ ^88,^ ^90^; 8506 Estrogen plus progestin; 8,102 Placebo | [underlined: Intervention followup: Median 5.6 years] ^67^; Invasive breast cancer; 206 (0.43% annualized) vs. 155 (0.35% annualized); HR, 1.24 (95% CI, 1.01 to 1.53); p=0.04; Subgroups:; No significant difference by age; Risk based on timing of intervention:; No significant differences by timing of intervention; Breast cancer mortality ^88^; 5 (0.010% annualized) vs. 4 (0.009%); HR, 1.08 (95% CI, 0.29 to 4.03); p=0.91; [underlined: Postintervention followup: Mean 2.4 years] ^132^; Invasive breast cancer; HR, 1.27 (95% CI, 0.91 to 1.78); [underlined: Postintervention followup: Median 8.2 years] ^67^; Invasive breast cancer; 228 (0.43% annualized) vs. 168 (0.33% annualized); HR, 1.32 (95% CI, 1.08 vs. 1.61); p=0.007; [underlined: Postintervention followup: Median 12.5 years] ^88^; Breast cancer mortality; 56 (0.060% annualized) vs. 36 (0.041%); HR, 1.50 (95% CI, 0.98 to 2.27); p=0.06; Subgroups:; No significant difference by age at randomization; [underlined: Cumulative followup: Mean 11.0 years]; Invasive breast cancer; Risk based on timing of intervention: ^110^; Initiation of hormone therapy within 5 years of menopause: HR, 2.06 (95% CI, 1.30 to 3.27); Initiation of hormone therapy after 5 years of menopause: HR, 1.30 (95% CI, 0.57 to 2.99); p=0.03 for gap time interaction; Subgroups:; [underlined: Time since randomization] (p=0.008 for trend) ^111^; 2 years since randomization: HR, 0.71 (95% CI, 0.47 to 1.08); 4 years since randomization: HR, 1.36 (95% CI, 0.95 to 1.94); 6 years since randomization: HR, 1.65 (95% CI, 1.17 to 2.32); Breast cancer mortality ^134^; 25 (0.03% annualized) vs. 12 (0.02% annualized); HR, 1.96 (95% CI, 1.00 to 4.04); p=0.049; [underlined: Cumulative followup: 13.2 years]; Invasive breast cancer; 434 (0.43% annualized) vs. 323 (0.34% annualized); HR, 1.28 (95% CI, 1.11 to 1.48); p<0.001^90^; Subgroups:; No significant difference by age^67^ or race^90^; [underlined: Cumulative followup: Median 17.7 years] ^88^; Breast cancer mortality; 61 (0.043% annualized) vs. 40 (0.030%); HR, 1.44 (95% CI, 0.97 to 2.15); p=0.07; Subgroups:; No significant difference by age at randomization; [underlined: Cumulative followup: Median 18.0 years] ^91^; Invasive breast cancer; 574 (0.45% annualized) vs. 432 (0.36% annualized); Subgroups:; No significant difference by age; [underlined: Cumulative followup: Median 18.9 years] ^87^; Invasive breast cancer; 584 (0.45%) vs. 447 (0.36%); HR, 1.28 (95% CI, 1.13 to 1.45); p<0.001; Subgroups:; No significant differences by age and race/ethnicity; Risk based on timing of intervention:; No significant differences by timing of intervention; [underlined: Cumulative followup: Median 19.4 years] ^101^; Invasive breast cancer; 574 (6.7% calculated) vs. 432 (5.3% calculated); HR, 1.28 (95% CI, 1.13 to 1.45); p=NR; [underlined: Cumulative followup: Median 20.3 years] ^87^; Breast cancer mortality; 71 (0.045%) vs. 53 (0.035%); HR, 1.35 (95% CI, 0.94 to 1.95); p=0.11
WISDOM Estrogen plus progestin trial; Vickers, 2007^138^ | 2,196 Estrogen plus progestin; 2,189 Placebo | [underlined: Intervention followup: Mean 1 year]; Breast cancer incidence; 5 (0.2%) vs. 7 (0.3%); Breast cancer mortality; 0 vs. 0

* Intervention dosages are listed in Table 3 by trial.

† It was 20.7 years for participants who consented to extended followup beyond September 30, 2010 (i.e., extension II), but 16.2 years overall when including patients who did not consent to participate in extension II. These data reflect both those who consented and did not consent to extended followup.

Abbreviations: CI=confidence interval; EPAT=Estrogen in the Prevention of Atherosclerosis; EPHT=Estonian Postmenopausal Hormone Therapy Trial; ERA=Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis; EPAT=Estrogen in the Prevention of Atherosclerosis; EPHT=Estonian Postmenopausal Hormone Therapy Trial; HERS=Heart and Estrogen/Progestin Replacement Study; HR=hazard ratio;; PEPI=Postmenopausal Estrogen and Progestin Interventions Trial; STOP-IT=Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; vs.=versus; WAVE=Women’s Angiographic Vitamin and Estrogen; WHI=Women’s Health Initiative; WISDOM=Women’s International Study of Long-Duration Oestrogen After Menopause.

Appendix F Table 2 Outcomes From Trials Reporting Incidence of Cervical Cancer

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
WHI Estrogen plus progestin trial; Anderson, 2003^126^ | 8,506 Estrogen plus progestin; 8,102 Placebo | [underlined: Followup: Median 5.6 years]; 8 (0.09%) vs. 5 (0.06%); HR, 1.44 (95% CI, 0.47 to 4.42)

* Intervention dosages are listed in Table 3 by trial.

Abbreviations: CI=confidence interval; HR=hazard ratio; vs.=versus; WHI=Women’s Health Initiative.

Appendix F Table 3 Outcomes From Trials Reporting Incidence of Colorectal Cancer

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
EMS Estrogen plus progestin trial; Tierney, 2009^141^ | 70 Estrogen plus progestin; 72 Placebo | [underlined: Intervention Followup: 2 years]; 0 vs. 0
Greenspan, et al Estrogen-only and estrogen plus progestin trial; Greenspan, 2005^107^ | 66 Estrogen; 121 Estrogen plus progestin; 186 Placebo | [underlined: Intervention Followup: 3 years]; Analysis did not stratify by treatment regimen; 3 vs. 1; p=0.62
HERS Estrogen plus progestin trial ^†^; Hulley, 2002^136^ | 1,380 Estrogen plus progestin; 1,383 Placebo; Cumulative followup:; 1,156 Estrogen plus progestin; 1,383 Placebo | [underlined: Intervention Followup: Mean 4.1 years]; 11 (0.80%) vs. 16 (1.16%); HR, 0.69 (95% CI, 0.32 to 1.49); p=0.43; [underlined: Cumulative followup: Mean 6.8 years]; HR, 0.82 (95% CI, 0.46 to 1.47); p=NR
Multiethnic Cohort Study; Park, 2016^103^ | 46,723 Hormone therapy ever users; 39,011 Never users | [underlined: Followup: 16 years]; Ever used estrogen only: 547 (1.2% calculated) vs. 903 (2.3% calculated); HR, 0.85 (95% CI, 0.76 to 0.94); Currently use estrogen only: 214 vs. 903 (2.3% calculated); HR, 0.77 (95% CI, 0.66 to 0.89); Ever used estrogen plus progestin: 405 vs. 903 (2.3% calculated); HR, 0.76 (95% CI, 0.68 to 0.86); Currently use estrogen plus progestin: 214 vs. 903 (2.3% calculated); HR, 0.72 (95% CI, 0.62 to 0.84)
PEPI Estrogen-only and estrogen plus progestin trial; Writing Group for PEPI trial, 1995^32^ | 175 Estrogen only; 174 Estrogen plus progestin (cyclic); 174 Estrogen plus progestin (continuous); 178 Estrogen plus progestin (micronized); 174 Placebo | [underlined: Intervention followup: 3 years]; Analysis did not stratify by treatment regimen; 2 colon cancer cases
STOP-IT Estrogen-only and Estrogen plus progestin trial; Gallagher, 2001^106^ | 121 Hormone therapy; 122 Hormone therapy plus calcitriol; 123 Calcitriol only; 123 Placebo | [underlined: Intervention followup: 3 years]; Analysis did not stratify by treatment regimen; 1 (hormone therapy with or without calcitriol) vs. 6 (calcitriol only and placebo)
WHI Estrogen-only trial; Anderson, 2004;^37^ Ritenbaugh, 2008;^114^ Prentice, 2009;^110^ LaCroix, 2011;^108^ Manson, 2013;^67^ Manson, 2019;^89^ Chlebowski, 2017;^95^ Prentice, 2020;^91^ Manson, 2017;^88^ Prentice, 2020^91^ | 5,310 Estrogen only; 5,429 Placebo; Postintervention followup:; 4,794 Estrogen only; 4,872 Placebo; Postintervention extension followup:; 4,851 Estrogen only; 4,935 Placebo | [underlined: Intervention followup: Median 7.2 years]; Colorectal cancer; 65 (1.22%) vs. 58 (1.07%); HR, 1.15 (95% CI, 0.81 to 1.64); p=0.44^67^; Subgroups:; No significant difference by race or ethnic group,^‡^,^95,^ ^114^ bilateral oophorectomy status, family history of colorectal cancer, or treated diabetes status^‡^,^114^; [underlined: Age at randomization] (p=0.02 for trend)^67,^ ^91^; Among women 50–59 years at randomization: HR, 0.71 (95% CI, 0.30 to 1.67); Among women 60–69 years at randomization: HR, 0.88 (95% CI, 0.53 to 1.47); Among women 70–79 years at randomization: HR, 2.24 (95% CI, 1.16 to 4.30); Risk based on timing of intervention:^110^; No significant association by timing of the intervention; Invasive colorectal cancer ^‡^ ^114^; HR, 1.12 (95% CI, 0.77 to 1.63); p=0.55; Invasive colon cancer ^‡^ ^114^; HR, 1.26 (95% CI, 0.84 to 1.88); p=0.26; Invasive rectal cancer ^‡^ ^114^; HR, 0.53 (95% CI, 0.18 to 1.56); p=0.25; Colorectal cancer mortality ^88^; 16 (0.041% annualized) vs. 17 (0.043%); HR, 0.98 (95% CI, 0.50 to 1.95); p=0.96; Subgroups; No significant difference by age; [underlined: Postintervention only followup: Median 6.6 years] ^67^; Colorectal cancer; HR, 1.10 (95% CI, 0.68 to 1.78); p=0.69; [underlined: Intervention and postintervention Followup: Median 10.8 years] ^88^; Colorectal cancer mortality; 31 (0.064% annualized) vs. 23 (0.046%); HR, 1.36 (95% CI, 0.79 to 2.34); p=0.26; Subgroups; No significant difference by age; [underlined: Cumulative followup: Median 13.0 years] ^67^; Colorectal cancer; HR, 1.13 (95% CI, 0.85 to 1.51); p=0.39; Subgroups:; No significant difference by age at randomization;^67^ no significant difference by race^95^; [underlined: Cumulative followup: Median 17.7 years]; Colorectal cancer mortality ^88^; 47 (0.054% annualized) vs. 40 (0.045%); HR, 1.21 (95% CI, 0.79 to 1.84); p=0.38; Subgroups:; [underlined: Age at randomization] (p=0.03); 50–59: 5 (0.017% annualized) vs. 8 (0.027%); HR, 0.65 (95% CI, 0.21 to 2.00); 60–69: 15 (0.038%) vs. 19 (0.047%); HR, 0.81 (95% CI, 0.41 to 1.60); 70–79: 27 (0.14%) vs. 13 (0.068%); HR, 2.13 (95% CI, 1.10 to 4.12); [underlined: Cumulative followup: Median 18.0 years]; Colorectal cancer; Subgroups:; No significant difference by oophorectomy status within any age group at randomization^89,^ ^91^
WHI Estrogen plus progestin trial; Writing Group for the Women’s Health Initiative Investigators, 2002;^36^ Chlebowski, 2004;^140^ Heiss, 2008;^132^ Prentice, 2009;^110^ Manson, 2013;^67^ Prentice, 2020;^91^ Manson, 2017^88^ | 8,506 Estrogen plus progestin; 8,102 Placebo; Postintervention followup:; 8,060 Estrogen plus progestin; 7,687 Placebo; Postintervention extension followup:^§^; 6,545 Estrogen plus progestin; 6,243 Placebo | [underlined: Intervention followup: Median 5.6 years]; Colorectal cancer; 50 (0.59%) vs. 75 (0.93%); HR, 0.62 (95% CI, 0.43 to 0.89); p=0.009^67^; Subgroups:; No significant difference by age at randomization,^67,^ ^91^ race or ethnic group, family history of colorectal cancer^‖,110,^ ^140^; Risk based on timing of intervention: ^110^; No significant association by timing of the intervention; Invasive colorectal cancer ^‖^ ^,^ ^140^; HR, 0.56 (95% CI, 0.38 to 0.81); p=0.003; Invasive colon cancer ^‖^ ^,^ ^140^; HR, 0.54 (95% CI, 0.36 to 0.82); p=0.004; Invasive rectal cancer ^‖^ ^,^ ^140^; HR, 0.66 (95% CI, 0.26 to 1.64); p=0.37; Colorectal cancer mortality ^88^; 11 (0.022% annualized) vs. 12 (0.026%); HR, 0.87 (95% CI, 0.38 to 1.98); p=0.74; Subgroups: No difference by age at randomization; [underlined: Postintervention followup: Median 8.2 years] ^67^; Colorectal cancer; HR, 0.97 (95% CI, 0.70 to 1.33); p=0.83; [underlined: Intervention and postintervention phase followup: Median 12.5 years] ^88^; Colorectal cancer mortality; 42 (0.045% annualized) vs. 38 (0.043%); HR, 1.06 (95% CI, 0.68 to 1.64); p=0.80; Subgroups:; No difference by age at randomization; [underlined: Cumulative followup: Median 13.2 years] ^67^; Colorectal cancer; HR, 0.80 (95% CI, 0.63 to 1.01); p=0.06; Subgroups: ^67^; No significant difference by age at randomization; [underlined: Cumulative followup: Median 17.7 years] ^88^; Colorectal cancer mortality; 53 (0.037% annualized) vs. 50 (0.037%); HR, 1.01 (95% CI, 0.69 to 1.49); p=0.96; Subgroups:; No difference by age at randomization; [underlined: Cumulative followup: Median 18.0 years] ^91^; Colorectal cancer; Subgroups:; No difference by age at randomization
WISDOM Estrogen plus progestin trial; Vickers, 2007^138^ | 2,196 Estrogen plus progestin^¶^; 2,189 Placebo^¶^ | [underlined: Intervention followup: Median 11.9 months]; 2 vs. 2

* Intervention dosages are listed in Table 3 by trial.

† HERS was a blinded randomized, controlled trial, that had a mean followup of 4.1 years. At the end of HERS, participants were unblinded and 93 percent reenrolled in HERS2, an open label study, for an additional 2.7 years.

‡ The mean followup for some of these analyses (Ritenbaugh, 2008^114^ and Prentice, 2009^110^) was 7.1 years, suggesting that the results are based on an earlier adjudication of intervention phase data than the most recent intervention data from Manson (2013).^67^

§ The mean followup for this analysis was 5.5 years, suggesting that the results are based on an earlier adjudication of intervention phase data than the most recent intervention data from Manson (2013).^67^

‖ The analysis was based on 122 centrally adjudicated colorectal cancers, which were diagnosed before 7/8/2002, the date participants were instructed to discontinue their study medication.

¶ The estrogen plus progestin arm included 1,862 women with an intact uterus and 334 women with a prior hysterectomy who had agreed to be randomized to estrogen plus progestin, estrogen only, or placebo (the women randomized to estrogen only included women who agreed to placebo [n=341] and women who did not agree to placebo [n=485]), so there is a selection bias that precludes us from including any results for the estrogen-only women.

Abbreviations: CI=confidence interval; EMS=Estrogen Memory Study; HERS=Heart and Estrogen/Progestin Replacement Study; HR=hazard ratio; NR=not reported; PEPI=Postmenopausal Estrogen/Progestin Interventions Trial; STOP-IT=Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; vs.=versus; WHI=Women’s Health Initiative; WISDOM=Women’s International Study of Long-Duration Oestrogen After Menopause.

Appendix F Table 4 Outcomes From Trials Reporting Incidence of Endometrial Cancer

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
EPAT Estrogen-only trial; Hodis, 2001^112^ | 133 (60%) of enrolled women had an intact uterus; 111 Estrogen only; 111 Placebo | [underlined: Intervention followup: Mean 2 years] ^†^; 0 (0.0%) vs. 0 (0.0%)
ERA Estrogen only and estrogen plus progestin trial; Herrington, 2000^113^ | 120 (39%) of enrolled women had an intact uterus, including 44 (44%) women in the estrogen-only arm, 40 (38%) women in the estrogen plus progestin arm, and 36 (34%) women in the placebo arm; 100 Estrogen only; 104 Estrogen plus progestin; 105 Placebo | [underlined: Intervention followup: Mean 3.2 years]; 0 (0.0%) vs. 0 (0.0%)
Greenspan, et al Estrogen-only and estrogen plus progestin trial; Greenspan, 2005^107^ | 243 (65%) of enrolled women had an intact uterus, including 121 (65%) in the hormone therapy arm and 122 (66%) in the placebo arm. Women with an intact uterus received estrogen plus progestin; women with a hysterectomy received estrogen only; 187 Hormone therapy; 186 Placebo | [underlined: Intervention followup: Mean 3 years]; 1 vs. 0; p=1.0^‡^
HERS Estrogen plus progestin trial; Hulley, 2002^136^ | All enrolled women had an intact uterus; 1,380 Estrogen plus progestin; 1,383 Placebo; Cumulative followup:; 1156 Estrogen plus progestin; 1165 Placebo | [underlined: Intervention followup: Mean 4.1 years]; 2 (0.14%) vs. 5 (0.36%); HR, 0.39 (95% CI, 0.08 to 2.02); p=0.26; [underlined: Cumulative followup: Mean 6.8 years]; HR, 0.25 (95% CI, 0.05 to 1.18); p=0.08
Danish Sex Hormone Register Study; Morch, 2016^102^ | Women with an intact uterus from the Danish Sex Hormone Register Study; 22,853 Continuous combined estrogen plus progestin; 25,209 Cyclic combined estrogen plus progestin; 2,071 Long cyclic combined estrogen plus progestin; 593,207 Never hormone use | [underlined: Followup: Mean 9.8 years]; Estrogen only: adjusted RR, 2.70 (95% CI, 2.41 to 3.02); Estrogen plus progestin: adjusted RR, 1.71 (95% CI, 1.58 to 1.86); Continuous combined estrogen plus progestin: adjusted RR, 1.02 (95% CI, 0.87 to 1.20); Cyclic combined regimen: adjusted RR, 2.06 (95% CI, 1.88 to 2.27); Long cyclic combined regimen: adjusted RR, 2.89 (95% CI, 2.27 to 3.67); Subgroups:; No significant differences by age, hypertension, or diabetes.
PEPI Estrogen-only and estrogen plus progestin trial; Writing Group for PEPI trial, 1995^32^ | Approximately 68% of women had an intact uterus; women with an intact uterus had to have a normal endometrial biopsy at baseline; 175 Estrogen only; 174 Estrogen plus progestin (cyclic); 174 Estrogen plus progestin (continuous); 178 Estrogen plus progestin (micronized); 174 Placebo | [underlined: Intervention followup: Mean 3 years]; 0 (estrogen plus progestin) vs. 0 (estrogen plus micronized progestin) vs. 0 (placebo)
STOP-IT Estrogen only and estrogen plus progestin; Gallagher, 2001^106^ | 199 (41%) of enrolled women had an intact uterus; women with a prior hysterectomy who were randomized to receive estrogen plus progestin, with or without calcitriol, received estrogen only; 121 Estrogen plus progestin; 122 Estrogen plus progestin plus calcitriol; 123 Calcitriol only; 123 Placebo | [underlined: Intervention followup: Mean 3 years]; Analysis did not stratify by treatment regimen; 0 (hormone therapy with or without calcitriol) vs. 1 (calcitriol only or placebo)
ULTRA Estrogen-only trial; Johnson, 2005^115^ | All enrolled women had an intact uterus; 208 Estrogen only; 209 Placebo | [underlined: Intervention followup: Mean 2 years]; 0 (0.0%) vs. 0 (0.0%); difference, 0.0 (95% CI, −4.2 to 3.1); p=1.000
WHI Estrogen plus progestin trial; Writing Group for the Women’s Health Initiative Investigators, 2002;^36^ Anderson, 2003;^126^ Heiss, 2008;^132^ Prentice, 2009;^110^ Chlebowski, 2010;^116^ Manson, 2013;^67,^ ^94^ Chlebowski, 2016;^94^ Prentice, 2020^91^ | Women with an intact uterus; 8,506 Estrogen plus progestin; 8,102 Placebo; Postintervention followup:; 8,060 Estrogen plus progestin; 7,687 Placebo; Postintervention extension followup:^§^; 6,545 Estrogen plus progestin; 6,243 Placebo | [underlined: Intervention followup: Median 5.6 years] ^67^; 27 (0.32%) vs. 30 (0.37%); HR, 0.83 (95% CI, 0.49 to 1.40); p=0.49; Subgroups:^67^; No significant difference by age at randomization; [underlined: Postintervention followup: Median 8.2 years] ^94^; 41 (0.08% annualized) vs. 65 (0.13% annualized); HR, 0.59 (95% CI, 0.40 to 0.88); p=0.008; [underlined: Cumulative followup: Median 13.2 years] ^94^; 66 (0.06% annualized) vs. 95 (0.10% annualized); HR, 0.65 (95% CI, 0.48 to 0.89); p=0.007; Subgroups:^67,^ ^94^; No significant differences by age at randomization,^67^ race,^94^ diabetes,^94^ or hypertension^94^; Risk based on timing of intervention: ^94^; No significant difference by time since menopause; [underlined: Cumulative followup: Median 18.0 years] ^91^; Subgroups:; No significant difference by age

* Intervention dosages are listed in Table 3 by trial.

† Adverse event reporting was only among women who received uterine biopsies (30 women in the estrogen-only arm and 5 women in the placebo arm).

‡ Because women with an intact uterus received estrogen plus progestin if they were randomized to the hormone therapy arm, this woman had received estrogen plus progestin.

§ Women were ineligible if they were deceased or provided no contact through the postintervention phase. By the end of the postintervention phase, 7,878/8,506 (93% of women randomized to estrogen plus progestin) and 7,530/8,102 (93% of women randomized to placebo) were eligible for the postintervention extension phase.

Abbreviations: CI=confidence interval; EPAT=Estrogen in the Prevention of Atherosclerosis Trial; ERA=Estrogen Replacement and Atherosclerosis; HERS=Heart and Estrogen/Progestin Replacement Study; HR=hazard ratio; PEPI=Postmenopausal Estrogen/Progestin Interventions Trial; RR=relative risk; STOP IT=Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; ULTRA=Ultra-Low-Dose Transdermal Estrogen Replacement Assessment; vs.=versus; WHI=Women’s Health Initiative.

Appendix F Table 5 Outcomes From Trials Reporting Incidence of Lung Cancer

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
EMS Estrogen plus progestin trial; Tierney, 2009^141^ | 70 Estrogen plus progestin; 72 Placebo | [underlined: Intervention followup: 2 years]; 1 (1.4%) vs. 0 (0.0%)
HERS Estrogen plus progestin trial ^†^; Hulley, 2002^136^ | 1,380 Estrogen plus progestin; 1,383 Placebo; Cumulative followup:; 1156 Estrogen plus progestin; 1383 Placebo | [underlined: Intervention followup: Mean 4.1 years]; 24 (1.74% calculated) vs. 19 (1.37% calculated); HR, 1.28 (95% CI, 0.70 to 2.33); p=0.43; [underlined: Cumulative followup: Mean 6.8 years]; 37 (3.2% calculated) vs. 27 (2.0% calculated); Unadjusted ITT: HR, 1.39 (95% CI, 0.84 to 2.28); p=0.20; Adjusted ITT: HR, 1.43 (95% CI, 0.87 to 2.37); Adjusted as-treated: HR, 1.73 (95% CI, 0.93 to 3.21)
PEPI Estrogen-only and estrogen plus progestin trial; Writing Group for PEPI trial, 1995^32^ | 175 Estrogen only; 174 Estrogen plus progestin (cyclic); 174 Estrogen plus progestin (continuous); 178 Estrogen plus progestin (micronized); 174 Placebo | [underlined: Intervention followup: 3 years]; Analysis did not stratify by treatment regimen; 2 lung cancer cases
WHI Estrogen-only trial; Chlebowski, 2010;^116^ Manson, 2013^67^ | 5,310 Estrogen only; 5,429 Placebo; Postintervention followup:; 4,794 Estrogen only; 4,872 Placebo; Postintervention extension followup:; 4,851 Estrogen only; 4,935 Placebo | [underlined: Intervention followup: Median 7.2 years] ^67^; 62 (0.16% annualized) vs. 61 (0.16% annualized); HR, 1.05 (95% CI, 0.74 to 1.49); p=0.79; Subgroups:^67^; No significant difference by age at randomization; [underlined: Intervention and partial postintervention followup: Mean 7.9 years] ^116^ ^,^ ^‡^; Lung cancer; 61 (0.15% annualized) vs. 54 (0.13% annualized); HR, 1.17 (95% CI, 0.81 to 1.69); p=0.39; NSCLC; 51 (0.12% annualized) vs. 48 (0.11% annualized); HR, 1.10 (95% CI, 0.74 to 1.64); p=0.62; SCLC; 9 (0.02% annualized) vs. 6 (0.01% annualized); HR, 1.57 (95% CI, 0.56 to 4.41); p=0.39; Mortality from lung cancer; 34 (0.08% annualized) vs. 33 (0.08% annualized); HR, 1.07 (95% CI, 0.66 to 1.72); p=0.79; Mortality from NSCLC; 25 (0.06% annualized) vs. 29 (0.07% annualized); HR, 0.89 (95% CI, 0.52 to 1.52); p=0.67; Mortality from SCLC; 8 (0.02% annualized) vs. 4 (0.01% annualized); HR, 2.11 (95% CI, 0.62 to 7.01); p=0.22; Subgroups:^116^; No significant difference by age at randomization, race, or ethnicity; Risk based on timing of intervention: ^116^; No significant differences by timing of intervention; [underlined: Postintervention followup: Median 6.6 years] ^67^; 47 (0.20% annualized) vs. 53 (0.22% annualized); HR, 0.90 (95% CI, 0.61 to 1.34); p=0.61; [underlined: Cumulative followup: Median 13.0 years] ^67^; 109 (0.18% annualized) vs. 114 (0.18% annualized); HR, 0.98 (95% CI, 0.75 to 1.27); p=0.87; Subgroups:^67^; No significant difference by age at randomization
WHI Estrogen plus progestin trial; Chlebowski, 2009;^142^ Manson, 2013;^67^ Chlebowski, 2019^98^ | 8,506 Estrogen plus progestin; 8,102 Placebo; Postintervention followup:; 8,060 Estrogen plus progestin; 7,687 Placebo; Postintervention extension followup:^§^; 6,545 Estrogen plus progestin; 6,243 Placebo | [underlined: Intervention followup: Median 5.6 years] ^67^; 78 (0.92%) vs. 70 (0.86%); HR, 1.05 (95% CI, 0.76 to 1.45); p=0.78; Subgroups:^67^; No significant difference by age at randomization; [underlined: Intervention and postintervention followup: Mean 7.9 years] ^‡^ ^142^; Lung cancer; 109 (0.16% annualized) vs. 85 (0.13% annualized); HR, 1.23 (95% CI, 0.92 to 1.63); p=0.16; NSCLC; 96 (0.14% annualized) vs. 72 (0.11% annualized); HR, 1.28 (95% CI, 0.94 to 1.73); p=0.12; SCLC; 13 (0.02% annualized) vs. 13 (0.02% annualized); HR, 0.96 (95% CI, 0.44 to 2.07); p=0.91; [underlined: Postintervention followup: Median 8.2 years] ^67^; 120 (0.22% annualized) vs. 101 (0.19% annualized); HR, 1.13 (95% CI, 0.86 to 1.47); p=0.38; [underlined: Cumulative followup: Median 13.2 years] ^67^; 198 (0.19% annualized) vs. 171 (0.18% annualized); HR, 1.10 (95% CI, 0.89 to 1.35); p=0.38; Subgroups:^67^; No significant difference by age at randomization; [underlined: Cumulative followup: Median 14 years] ^98^; Lung cancer; 219 (0.19% annualized) vs. 184 (0.17% annualized); HR, 1.12 (95% CI, 0.92 to 1.37); p=0.24; NSCLC; 160 (0.14% annualized) vs. 125 (0.11% annualized); HR, 1.23 (95% CI, 0.97 to 1.55); p=0.08; SCLC; 20 (0.02% annualized) vs. 23 (0.02% annualized); HR, 1.09 (95% CI, 0.60 to 1.98); p=0.78; Mortality from lung cancer; 153 (0.13% annualized) vs. 132 (0.12% annualized); HR, 1.09 (95% CI, 0.87 to 1.38); p=0.45; Mortality from NSCLC; 109 (0.09% annualized) vs. 85 (0.08% annualized); HR, 1.23 (95% CI, 0.92 to 1.63); p=0.16; Mortality from SCLC; 17 (0.02% annualized) vs. 21 (0.02% annualized); HR, 1.16 (95% CI, 0.61 to 2.21); p=0.64; Significant linear trend over time in lung cancer mortality (p=0.042), suggesting that the nonsignificant increase in risk of mortality in the hormone therapy group through year 9 decreased after both randomization groups stopped taking study pills after active intervention (median 5.6 years)

* Intervention dosages are listed in Table 3 by trial.

† HERS was a blinded randomized, controlled trial that had a mean followup of 4.1 years. At the end of HERS, participants were unblinded and 93 percent re-enrolled in HERS2, an open-label study, for an additional 2.7 years.

‡ Authors state ascertainment of lung cancer cases is through 3/31/2005, which is the end of the postintervention phase according to Manson^67^; this would mean these results are for trial and posttrial phases combined together.

§ Women were ineligible if they were deceased or provided no contact through the postintervention phase. By the end of the postintervention phase, 7,878/8,506 (93% of women randomized to estrogen plus progestin) and 7,530/8,102 (93% of women randomized to placebo) were eligible for the postintervention extension phase.

Abbreviations: CI=confidence interval; EMS=Estrogen Memory Study; HERS=Heart and Estrogen/Progestin Replacement Study; HR=hazard ratio; ITT=intention to treat; NSCLC=non-small cell lung cancer; PEPI=Postmenopausal Estrogen/Progestin Interventions; SCLC=small-cell lung cancer; vs.=versus; WHI=Women’s Health Initiative.

Appendix F Table 6 Outcomes From Trials Reporting Incidence of Non-Hodgkin’s Lymphoma

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
Women’s Health Initiative, Estrogen-only trial ^96^ | 5,283 Estrogen; 5,402 Placebo | [underlined: Intervention followup: Median 7.2 years]; Incidence of non-Hodgkin’s lymphoma; HR, 0.89 (95% CI, 0.56 to 1.42); [underlined: Cumulative followup: Median 12.9 years]; Incidence of non-Hodgkin’s lymphoma; 80 (0.117% annualized) vs. 80 (0.115% annualized); HR, 1.02 (95% CI, 0.74 to 1.39)
Women’s Health Initiative, Estrogen plus progestin trial ^96^ | 8,469 Estrogen and progestin; 8,075 Placebo | [underlined: Intervention followup: Median 5.6 years]; Incidence of non-Hodgkin’s lymphoma; HR, 0.81 (95% CI, 0.51 to 1.29); [underlined: Cumulative followup: Median 13.5 years]; Incidence of non-Hodgkin’s lymphoma; 113 (0.099% annualized) vs. 110 (0.101% annualized); HR, 0.98 (95% CI, 0.76 to 1.28)

* Intervention dosages are listed in Table 3 by trial.

Abbreviations: CI=confidence interval; HR=hazard ratio; vs.=versus.

Appendix F Table 7 Outcomes From Trials Reporting Incidence of Ovarian Cancer

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
Black Women’s Health Study; Bethea, 2017^104^ | 2,477 Estrogen only; 1,836 Estrogen plus progestin; 4,689 Never used or used <1 year | [underlined: Followup: 18 years]; 17 (0.7% calculated) vs. 14 (0.8% calculated) vs. 61 (1.3% calculated); Estrogen only: HR, 1.66 (95% CI, 0.90 to 3.07); Estrogen plus progestin: HR, 1.37 (95% CI, 0.73 to 2.55)
WHI Estrogen plus progestin trial; Anderson, 2003;^126^ Manson, 2013^67^ | 8,506 Estrogen plus progestin; 8,102 Placebo; Postintervention followup:; 8,060 Estrogen plus progestin; 7,687 Placebo; Postintervention extension followup:^†^; 6,545 Estrogen plus progestin; 6,243 Placebo | [underlined: Intervention followup: Median 5.6 years] ^67^; 24 (0.28%) vs.16 (0.20%); HR, 1.41 (95% CI, 0.75 to 2.66); p=0.28; Subgroups:; No significant difference by age at randomization; [underlined: Postintervention followup: Median 8.2 years] ^67^; HR, 1.12 (95% CI, 0.65 to 1.90); p=0.69; [underlined: Cumulative followup: Median 13.2 years] ^67^; HR, 1.24 (95% CI, 0.83 to 1.87); p=0.30; Subgroups:; [underlined: Age (p=0.005 for trend)]; 50–59 years: HR, 0.55 (95% CI, 0.24 to 1.25); 60–69 years: HR, 1.25 (95% CI, 0.72 to 2.18); 70–79 years: HR, 3.82 (95% CI, 1.27 to 11.52)

* Intervention dosages are listed in Table 3 by trial.

† At enrollment, 24% of women reported having a hysterectomy. After the 2-year intervention period, women with an intact uterus were sent a letter each year for the first 5 years after stopping treatment to remind them to seek medical attention if they experienced vaginal bleeding. No attempt was made after the end of 2-year intervention to obtain medical information from women or their physicians about the use of medications or health events.

Abbreviations: CI=confidence interval; HR=hazard ratio; vs.=versus; WHI=Women’s Health Initiative.

Appendix F Table 8 Outcomes From Trials Reporting Incidence Total Cancer Mortality

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
WHI Estrogen-only trial; Manson, 2013;^67^ Manson, 2019;^89^ Manson, 2017^88^ | 5,310 Estrogen; 5,429 Placebo; Postintervention followup:; 5,009 Estrogen; 5,130 Placebo; Cumulative followup (intervention plus postintervention phases):; 5,310 Estrogen; 5,429 Placebo | [underlined: Intervention followup: Mean 7.2 years] ^88^; 126 (0.33% annualized) vs. 136 (0.34% annualized); HR, 0.96 (95% CI, 0.75 to 1.22); p=0.72; Subgroups:; No significant difference by age group; [underlined: Postintervention followup: Median 10.8 years] ^88^; 298 (0.61% annualized) vs. 303 (0.61% annualized); HR, 1.00 (95% CI, 0.85 to 1.17); p=1.00; Subgroups:; No significant difference by age group; [underlined: Cumulative followup: Median 13.0 years] ^67^; 260 (0.42% annualized) vs. 278 (0.44% annualized); HR, 0.95 (95% CI, 0.81 to 1.13); p=0.58; Subgroups:; No significant difference by age; [underlined: Cumulative followup: Median 17.7 years] ^88^; 424 (0.49% annualized) vs. 439 (0.49% annualized); HR, 0.99 (95% CI, 0.86 to 1.13); p=0.86; Subgroups:; No significant difference by age group; [underlined: Cumulative followup: Median 18.0 years] ^89^; Subgroups:; No significant difference by oophorectomy status by age group
WHI Estrogen plus progestin trial; Manson, 2013;^67^ Manson, 2017^88^ | 8,506 Estrogen plus progestin; 8,102 Placebo; Postintervention extension followup:; 8,256 Estrogen plus progestin; 7,864 Placebo; Cumulative followup (intervention plus postintervention phases):; 8,506 Estrogen plus progestin; 8,102 Placebo | [underlined: Intervention followup: Median 5.6 years] ^88^; 133 (0.27% annualized) vs. 111 (0.24% annualized); HR, 1.10 (95% CI, 0.86 to 1.42); p=0.44; Subgroups:; No significant difference by age group; [underlined: Postintervention followup: Median 12.5 years] ^88^; 573 (0.62% annualized) vs. 527 (0.59% annualized); HR, 1.05 (95% CI, 0.93 to 1.18); p=0.43; Subgroups:; No significant difference by age group; [underlined: Cumulative followup: Median 13.2 years] ^67^; 428 (0.42% annualized) vs. 379 (0.39% annualized); HR, 1.07 (95% CI, 0.93 to 1.23); p=0.32; Subgroups:; No significant difference by age; [underlined: Cumulative followup: Median 17.7 years] ^88^; 706 (0.50% annualized) vs. 638 (0.47% annualized); HR, 1.06 (95% CI, 0.95 to 1.18); p=0.31; Subgroups:; No significant difference by age group

* Intervention dosages are listed in Table 3 by trial.

Abbreviations: CI=confidence interval; HR=hazard ratio; NR=not reported; vs.=versus; WHI=Women’s Health Initiative.

Appendix F Table 9 Outcomes From Trials Reporting COPD Mortality

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
WHI Estrogen-only trial; Manson, 2017^88^ | 5,310 Estrogen; 5,429 Placebo | [underlined: Intervention phase followup: Median 7.2 years]; COPD-specific mortality; 6 (0.016% annualized) vs. 8 (0.020% annualized); HR, 0.76 (95% CI, 0.26 to 2.20); p=0.62; Subgroups:; No significant difference by age at randomization; [underlined: Postintervention phase followup: Median 10.8 years]; COPD-specific mortality; 77 (0.16% annualized) vs. 71 (0.14% annualized); HR, 1.09 (95% CI, 0.79 to 1.51); p=0.60; Subgroups:; [underlined: Age at randomization (p=0.002)]; 50–59: 4 (0.024% annualized) vs. 16 (0.095% annualized); HR, 0.24 (95% CI, 0.08 to 0.73); 60–69: 35 (0.16% annualized) vs. 32 (0.14% annualized); HR, 1.12 (95% CI, 0.69 to 1.81); 70–79: 38 (0.39% annualized) vs. 23 (0.23% annualized); HR, 1.65 (95% CI, 0.98 to 2.77); [underlined: Cumulative followup: Median 17.7 years]; COPD-specific mortality; 83 (0.095% annualized) vs. 79 (0.088% annualized); HR, 1.07 (95% CI, 0.78 to 1.45); p=0.68; Subgroups:; [underlined: Age at randomization (p=0.005)]; 50–59: 6 (0.020% annualized) vs. 17 (0.057% annualized); HR, 0.35 (95% CI, 0.14 to 0.88); 60–69: 36 (0.092% annualized) vs. 36 (0.089% annualized); HR, 1.04 (95% CI, 0.65 to 1.64); 70–79: 41 (0.22% annualized) vs. 26 (0.14% annualized); HR, 1.59 (95% CI, 0.97 to 2.60)
WHI Estrogen plus progestin trial; Manson, 2017^88^ | 8,506 Estrogen plus progestin; 8,102 Placebo | [underlined: Intervention phase followup: Median 5.6 years]; COPD-specific mortality; 1 (0.002% annualized) vs. 8 (0.017% annualized); HR, 0.12 (95% CI, 0.01 to 0.93); p=0.01; [underlined: Postintervention phase followup: Median 12.5 years]; COPD-specific mortality; 107 (0.12% annualized) vs. 92 (0.10% annualized); HR, 1.13 (95% CI, 0.85 to 1.49); p=0.41; Subgroups:; No difference by age at randomization; [underlined: Cumulative followup: Median 17.7 years]; COPD-specific mortality; 108 (0.076% annualized) vs. 100 (0.074% annualized); HR, 1.03 (95% CI, 0.79 to 1.36); p=0.81; Subgroups:; No difference by age at randomization

* Intervention dosages are listed in Table 3 by trial.

Abbreviations: CI=confidence interval; COPD=chronic obstructive pulmonary disease; HR=hazard ratio; vs.=versus; WHI=Women’s Health Initiative.

Appendix F Table 10 Outcomes From Trials Reporting Incidence of Coronary Heart Disease

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
EMS Estrogen plus progestin trial; Tierney, 2009^141^ | 70 Estrogen plus progestin; 72 Placebo | [underlined: Followup: Mean 2 years]; Any cardiovascular event; 11 (15.7%) vs. 8 (11.1%); no statistically significant differences between groups
EPAT Estrogen-only trial; Hodis, 2001^112^ | 111 Estrogen; 111 Placebo | [underlined: Followup: Mean 2 years]; Cardiovascular events; 3 (2.7%) vs. 4 (3.6%); p>0.2; Nonfatal or fatal myocardial infarction; 1 (0.9%) vs. 2 (0.9%); p=NR
EPHT Estrogen plus progestin trial; Veerus, 2006^137^ | 404 Estrogen plus progestin; 373 Placebo; Timing of intervention analysis: 251 total (analysis did not report by regimen) | [underlined: Followup: Mean 3.4 years]; CHD; 66 (16.3%) vs. 62 (16.6%); HR, 1.03 (95% CI, 0.73 to 1.46); Risk based on timing of intervention:; No significant difference among women within 3 years of menopause; Myocardial infarction only; 2 (0.5%) vs. 0 (0%)
ERA Estrogen-only and estrogen plus progestin trial; Herrington, 2000^113^ | Women with angiographically verified coronary disease; 100 Estrogen; 104 Estrogen plus progestin; 105 Placebo | [underlined: Followup: Mean 3.2 years]; Cardiovascular events; 29 (29.0%) vs. 28 (26.9%) vs. 34 (32.4%); p=0.69
Greenspan, et al Estrogen-only and estrogen plus progestin trial; Greenspan, 2005^107^ | 66 Estrogen; 121 Estrogen plus progestin; 186 Placebo | [underlined: Followup: Mean 3 years]; Myocardial infarction; Analysis did not stratify by treatment regimen; 1 (0.5%) vs. 3 (1.6%); p=0.37
PEPI Estrogen-only and estrogen plus progestin trial; Writing Group for PEPI trial, 1995^32^ | 175 Estrogen only; 174 Estrogen plus progestin (cyclic); 174 Estrogen plus progestin (continuous); 178 Estrogen plus progestin (micronized); 174 Placebo | [underlined: Followup: Mean 3 years]; CHD; 1 (estrogen: 0.6%) vs. 1 (estrogen plus progestin: 0.3%) vs. 3 (estrogen plus micronized progestin: 1.7%) vs. 0 (placebo); p=0.29
STOP-IT Estrogen-only and estrogen plus progestin trial; Gallagher, 2001^106^ | 121 Hormone therapy; 122 Hormone therapy plus calcitriol; 123 Calcitriol only; 123 Placebo | [underlined: Followup: Mean 3 years]; Cardiovascular events; Analysis did not stratify by treatment regimen; 8 (hormone therapy with or without calcitriol: 3.3%) vs. 7 (calcitriol only or placebo: 2.8%)
WAVE Estrogen-only and estrogen plus progestin trial; Waters, 2002^105^ | Women with a coronary stenosis of 15%–75%; 124 Estrogen (with or without vitamin C and E); 86 Estrogen plus progestin (with or without vitamin C and E); 213 Placebo (with or without vitamin C and E) | [underlined: Followup: Mean 2.8 years]; Nonfatal myocardial infarction or cardiovascular death; Analysis did not stratify by treatment regimen; 18 (8.6%) vs. 12 (5.6%)
WHI Estrogen-only trial; Anderson, 2004;^37^ Rossouw, 2007;^52^ Hsia, 2006;^117^ Prentice, 2009;^110^ LaCroix, 2011;^108^ Manson, 2013;^67^ Manson, 2019;^89^ Liu, 2020;^99^ Chlebowski, 2017;^95^ Prentice, 2020;^101^ Manson, 2017^88^ | 5,310 Estrogen; 5,429 Placebo; Postintervention Followup:; 3,778 Estrogen; 3,867 Placebo | [underlined: Intervention followup: Mean 7.1 years/Median 7.2 years]; Overall CHD (nonfatal myocardial infarction or coronary death) ^117^; 201 (annualized 0.53%) vs. 217 (annualized 0.56%); HR, 0.95 (95% CI, 0.79 to 1.16); Subgroups:^67,^ ^117^; No significant difference by race/ethnicity, age, years since bilateral oophorectomy, diabetes, hypertension, high cholesterol requiring medication, coronary risk factors, CVD at baseline, or CHD at baseline; Risk based on timing of intervention:^67,^ ^110^; No significant difference by timing of intervention; CHD; Subgroups:; No significant difference by race,^95^ by oophorectomy status in the overall sample,^89^ or within any age group at randomization.^89^ Among those age <60 years at randomization, no significant difference among those having had oophorectomy regardless of whether it was performed at age <45 years or ≥45 years.^89^ Among those age ≥60 years at randomization, no significant difference among those having had oophorectomy regardless of whether it was performed at age <45 years or ≥45 years^89^; All cardiovascular events^67^; 877 (2.51% annualized) vs. 813 (2.24%); HR, 1.11 (95% CI, 1.01 to 1.22); p=0.03; Subgroups:; No significant difference by age group; Myocardial infarction^67^; 164 (0.44% annualized) vs. 173 (0.45); HR, 0.97 (95% CI, 0.79 to 1.21); p=0.81; Subgroups:; [underlined: Age (p=0.02)]; 50–59 years: 17 (0.14% annualized) vs. 31 (0.25%); HR, 0.55 (95% CI, 0.31 to 1.00); 60–69 years: 76 (0.46%) vs. 82 (0.48%); HR, 0.95 (95% CI, 0.69 to 1.30); 70–79 years: 71 (0.83%) vs. 60 (0.69%); HR, 1.24 (95% CI, 0.88 to 1.75); Risk based on timing of intervention:; No significant difference by timing of intervention; Total HF^99^; 120 (2.30%) vs. 119 (2.22%); HR, 1.04 (95% CI, 0.81 to 1.34); Subgroups:; No significant difference in total hospitalized HF by age at randomization; Hospitalized HFrEF; 38 (0.75%) vs. 43 (0.82%); HR, 0.91 (95% CI, 0.59 to 1.41); Hospitalized HFpEF; 49 (0.96%) vs. 50 (0.95%); HR, 1.01 (95% CI, 0.68 to 1.50); CHD mortality^88^; 66 (0.17%) vs. 67 (0.17%); HR, 1.02 (95% CI, 0.72 to 1.43); p=0.92; Subgroups:; No significant difference by age group; [underlined: Postintervention followup: Mean 3.9 years]; Overall CHD (nonfatal myocardial infarction or coronary death)^108^; HR, 0.97 (95% CI, 0.75 to 1.25); [underlined: Postintervention followup: Median 10.8 years] ^88^; CHD mortality; 174 (0.36%) vs. 210 (0.42%); HR, 0.84 (95% CI, 0.69 to 1.03); p=0.09; Subgroups:; No significant difference by age group; [underlined: Cumulative followup: Median 13.0 years]; Overall CHD (nonfatal myocardial infarction or coronary death)^67^; 363 (0.60% annualized) vs. 393 (0.63% annualized); HR, 0.94 (95% CI, 0.82 to 1.09); p=0.43; Subgroups:; No significant difference by race^95^ or age^67^; All cardiovascular events^67^; 1,267 (2.30% annualized) vs. 1,227 (2.15%); HR, 1.06 (95% CI, 0.98 to 1.15); p=0.12; Subgroups:; No significant difference by age group; Myocardial infarction ^67^; 285 (0.47% annualized) vs. 288 (0.47%); HR, 1.01 (95% CI, 0.86 to 1.19); p=0.90; Subgroups:; [underlined: Age (p=0.007)] ^67^; 50–59 years: 35 (0.17% annualized) vs. 58 (0.29%); HR, 0.60 (95% CI, 0.39 to 0.91); 60–69 years: 140 (0.52%) vs. 139 (0.49%); HR, 1.03 (95% CI, 0.82 to 1.31); 70–79 years: 110 (0.82%) vs. 91 (0.67%); HR, 1.25 (95% CI, 0.95 to 1.65); [underlined: Cumulative followup: Median 17.7 years]; CHD mortality ^88^; 240 (0.28%) vs. 277 (0.31%); HR, 0.89 (95% CI, 0.75 to 1.05), p=0.17; Subgroups:; No significant difference by age group; [underlined: Cumulative followup: Median 18.0 years] ^89^; CHD; Subgroups:; No significant difference by oophorectomy status in the overall sample (p=0.31 for interaction) or within any age group at randomization (p values ranged from 0.44 to 0.55 for interaction trend). Among women age <60 years at randomization, no significant difference among those having had oophorectomy regardless of whether it was performed at age <45 years or ≥45 years (p=0.51 for trend). Among women age ≥60 years at randomization, no significant difference among those having had oophorectomy regardless of whether it was performed at age <45 years or ≥45 years (p=0.86 for trend). No significant difference by oophorectomy status, regardless of prior menopausal hormone therapy use (p values ranged from 0.60 to 0.72 for interaction); Myocardial infarction; Subgroups:; No significant difference by oophorectomy status within any age group at randomization (p ranged from 0.053 to 0.27 for interaction trend); Total CVD mortality; Subgroups:; No significant difference by oophorectomy status within any age group at randomization; [underlined: Cumulative followup: Median 18.9 years] ^99^; Total HF; 359 (6.9%) vs. 353 (6.6%); HR, 1.04 (95% CI, 0.90 to 1.20); Subgroups:; No significant difference in by age at randomization; Hospitalized HFrEF; 108 (2.2%) vs. 127 (2.5%); HR, 0.87 (95% CI, 0.67 to 1.13); Subgroups:; No significant difference in by age at randomization; Hospitalized HFpEF; 168 (3.3%) vs. 151 (2.9%); HR, 1.13 (95% CI, 0.91 to 1.41); Subgroups:; No significant difference by age at randomization; [underlined: Cumulative followup: Median 19.4 years] ^101^; Overall CHD (nonfatal myocardial infarction or coronary death); 521 (9.8% calculated) vs. 550 (10.1%); HR, 0.97 (95% CI, 0.86 to 1.09); p=NR
WHI Estrogen plus progestin trial; Writing Group for the WHI, 2002;^36^ Manson, 2003;^174^ Rossouw, 2007;^52^ Heiss, 2008;^132^ Prentice, 2009;^110^ Manson, 2013;^67^ Liu, 2020;^99^ Prentice, 2020;^101^ Manson, 2017^88^ | 8,506 Estrogen plus progestin; 8,102 Placebo; Postintervention followup:; 8,052 Estrogen plus progestin; 7,678 Placebo | [underlined: Intervention followup: Mean 5.2 years/Median 5.6 years]; Overall CHD (nonfatal myocardial infarction or coronary death) ^67^; 196 (0.41% annualized) vs. 159 (0.35% annualized); HR, 1.18 (95% CI, 0.95 to 1.45); Subgroups:; No significant difference by age group^67,^ ^174^; Risk based on timing of intervention:; No significant difference by timing of intervention^67,^ ^110,^ ^174^; All cardiovascular events ^67^; 786 (1.7% annualized) vs. 663 (1.52%); HR, 1.13 (95% CI, 1.02 to 1.25); p=0.02; Subgroups:; No significant difference by age; Myocardial infarction ^67^; 168 (0.35% annualized) vs. 129 (0.29%); HR, 1.24 (95% CI, 0.98 to 1.56); p=0.07; Subgroups:; No significant difference by age group; Risk for based on timing of intervention (p=0.01 for trend):; <10 years after menopause: HR, 0.91 (95% CI and p=NR); 10 to <20 years after menopause: HR, 1.16 (95% CI and p=NR); ≥20 years after menopause: HR, 1.99 (95% CI and p=NR); Total HF ^99^; 89 (1.05%) vs. 82 (1.02%); HR, 1.01 (95% CI, 0.75 to 1.37); Subgroups:; No significant difference by age at randomization; Hospitalized HFrEF ^99^; 32 (0.38%) vs. 28 (0.35%); HR, 1.06 (95% CI, 0.64 to 1.76); Hospitalized HFpEF^99^; 31 (0.37%) vs. 31 (0.39%); HR, 0.93 (95% CI, 0.57 to 1.53); CHD mortality ^88^; 40 (0.082% annualized) vs. 40 (0.087%); HR, 0.94 (95% CI, 0.60 to 1.45); p=0.77; Subgroups:; No significant difference by age group; [underlined: Postintervention followup: Mean 2.4 years] ^132^; Overall CHD; HR, 1.04 (95% CI, 0.89 to 1.21); [underlined: Postintervention followup: Median 12.5 years]; CHD mortality ^88^; 270 (0.29%) vs. 245 (0.28%); HR, 1.08 (95% CI, 0.91 to 1.28); p=0.39; Subgroups:; No significant difference by age group; [underlined: Cumulative followup: Median 13.0 years] ^67^; Overall CHD (nonfatal myocardial infarction or coronary death); 487 (0.48% annualized) vs. 430 (0.45%); HR, 1.09 (95% CI, 0.96 to 1.24); p=0.19; Subgroups:; No significant difference by age group; All cardiovascular events ^67^; 1,606 (1.7% annualized) vs. 1,446 (1.6% annualized); HR, 1.08 (95% CI, 1.00 to 1.15); p=0.05; Subgroups:; No significant difference by age; Myocardial infarction; 389 (0.39% annualized) vs. 324 (0.34%); HR, 1.15 (95% CI, 0.99 to 1.34); p=0.06; Subgroups:; No significant difference by age group; [underlined: Cumulative followup: Median 17.7 years]; CHD mortality ^88^; 310 (0.22%) vs. 285 (0.21%); HR, 1.05 (95% CI, 0.89 to 1.23); p=0.57; Subgroups:; No significant difference by age group; [underlined: Cumulative followup: Median 18.9 years] ^99^; Total HF; 433 (5.1%) vs. 418 (5.2%); HR, 0.98 (95% CI, 0.86 to 1.13); Subgroups:; No significant difference by age at randomization; Hospitalized HFrEF; 139 (1.7%) vs. 143 (1.8%); HR, 0.93 (95% CI, 0.73 to 1.17); Subgroups:; No significant difference by age at randomization; Hospitalized HFpEF; 205 (2.5%) vs. 196 (2.5%); HR, 0.99 (95% CI, 0.82 to 1.21); Subgroups:; No significant difference by age at randomization; [underlined: Cumulative followup: Median 19.4 years] ^101^; Overall CHD (nonfatal myocardial infarction or coronary death); 710 (8.3% calculated) vs. 652 (8.0%); HR, 1.05 (95% CI, 0.95 to 1.17); p=NR
WISDOM Estrogen plus progestin trial; Vickers, 2007^138^ | 826 Estrogen; 2,196 Estrogen plus progestin; 2,189 Placebo | [underlined: Followup: Mean 1 year]; Cardiovascular events; 2 (0.2%) vs. 7 (0.3%) vs. 0 (0.0%); p=0.016

* Intervention dosages are listed in Table 3 by trial.

Abbreviations: CHD=coronary heart disease; CI=confidence interval; CVD=cardiovascular disease; EMS=Estrogen Memory Study; EPAT=Estrogen in the Prevention of Atherosclerosis Trial; EPHT=Estonian Postmenopausal Hormone Therapy Trial; ERA=Estrogen Replacement and Atherosclerosis; HF=heart failure; HFpEF=HF with preserved ejection fraction; HFrEF=HF with reduced ejection fraction; HR=hazard ratio; NR=not reported; PEPI=Postmenopausal Estrogen/Progestin Interventions Trial; STOP-IT=Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; vs.=versus; WAVE=Women’s Angiographic Vitamin and Estrogen Trial; WHI=Women’s Health Initiative; WISDOM=Women’s International Study of Long Duration Oestrogen After Menopause.

Appendix F Table 11 Outcomes From Trials Reporting Incidence of Peripheral Arterial Disease

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
WHI Estrogen-only trial; Hsia, 2006^79^ | 5,310 Estrogen; 5,429 Placebo | [underlined: Followup: Mean 7.1 years]; Peripheral arterial disease; 82 vs. 62; HR, 1.35 (95% CI, 0.97 to 1.88); Subgroups:; No significant difference by age, ethnicity, diabetes, or body mass index
WHI Estrogen plus progestin trial; Hsia, 2004^80^ | 58,506 Estrogen plus progestin; 8,102 Placebo | [underlined: Followup: Mean 5.6 years]; Peripheral arterial disease; 48 vs. 50; HR, 0.89 (95% CI, 0.60 to 1.32); p=0.57; Subgroups:; No significant difference by age, ethnicity, diabetes, or body mass index

* Intervention dosages are listed in Table 3 by trial.

Abbreviations: CI=confidence interval; HR=hazard ratio; vs.=versus; WHI=Women’s Health Initiative.

Appendix F Table 12 Outcomes From Trials Reporting Incidence of Dementia

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
Study; Author, Year | Population | Probable Dementia Incidence | MCI Incidence | Other Dementia Diagnosis Outcomes
WHIMS Estrogen-only trial; Shumaker, 2004^119^ | Women without probable dementia; Dementia outcomes, WHI:^119^; 1,464 Estrogen; 1,483 Placebo | [underlined: Intervention followup: 5.2 years] ^119^; Probable dementia; 28 (1.9%) vs. 19 (1.3%); cumulative HR, 1.49 (95% CI, 0.83 to 2.66); p=0.18; Subgroups: ^119^; No difference in the hazard rate for probable dementia by race or history of cardiovascular disease, diabetes, hypertension, or stroke. | [underlined: Intervention followup: 5.2 years] ^119^; 76 (5.2%) vs. 58 (3.9%); cumulative HR, 1.34 (95% CI, 0.95 to 1.89); p=NS | [underlined: Intervention followup: 5.2 years] ^119^; Probable dementia or MCI; 93 (6.4%) vs. 69 (4.7%); cumulative HR, 1.38 (95% CI, 1.01 to 1.89); p=0.04
WHIMS Estrogen plus progestin trial; Shumaker, 2003;^143^ Shumaker, 2004^119^ | Women without probable dementia; Dementia and cognitive impairment outcomes:^143^ 2,229 Estrogen plus progestin 2,303 Placebo | [underlined: Intervention followup: ~4 years] ^143^; Probable dementia; 40 (1.8%) vs. 21 (0.9%); cumulative HR, 2.05 (95% CI, 1.21 to 3.48); p=0.01; Subgroups: ^143^; No difference in the hazard rate for probable dementia by race or history of cardiovascular disease, diabetes, hypertension, or stroke. | [underlined: Intervention followup: ~4 years] ^143^; 56 (2.5%) vs. 55 (2.4%); cumulative HR, 1.07 (95% CI, 0.74 to 1.55); p=0.72 | [underlined: Intervention followup: ~4 years] ^143^; Probable dementia or MCI; 85 (3.8%) vs. 66 (2.9%); cumulative HR, 1.37 (95% CI, 0.99 to 1.89)
WHISCA Estrogen-only trial; Resnick, 2009^120^ | Dementia outcomes, WHISCA:^120^; 434 Estrogen; 452 Placebo | [underlined: Intervention followup: 2.7 years] (during WHISCA, after being enrolled in WHI for 3 years)^120^; Probable dementia; 4 (0.9%) vs. 2 (0.4%); calculated RR, 2.08 (95% CI, 0.38 to 11.31); p=0.40 | [underlined: Intervention followup: 2.7 years] (during WHISCA, after being enrolled in WHI for 3 years)^120^; 18 (4.1%) vs. 15 (3.3%); calculated RR, 1.25 (95% CI, 0.64 to 2.45); p=0.52 | NR
WHISCA Estrogen plus progestin trial; Resnick, 2006^144^ | Probable dementia or cognitive impairment, WHIMS:^144^; 690 Estrogen plus progestin; 726 Placebo | [underlined: Intervention followup: 1.4 years] (during WHISCA, after being enrolled in WHI for 3 years)^144^; Probable dementia; 5 (0.7%) vs. 6 (0.8%); calculated RR, 0.88 (95% CI, 0.27 to 2.86); p=0.83 | [underlined: Intervention followup: 1.4 years] (during WHISCA, after being enrolled in WHI for 3 years)^144^; 6 (0.9%) vs. 13 (1.8%); calculated RR, 0.49 (95% CI, 0.19 to 1.27); p=0.14 | NR
WHI Estrogen-only trial; Manson, 2017^88^ | 5,310 Estrogen; 5,429 Placebo | [underlined: Intervention followup: Median 7.2 years]; Alzheimer’s disease or other dementia mortality; 5 (0.013% annualized) vs. 6 (0.015%); HR, 0.90 (95% CI, 0.27 to 2.95); p=0.86; [underlined: Postintervention followup: Median 10.8 years]; Alzheimer’s disease or other dementia mortality; 122 (0.25% annualized) vs. 169 (0.34%); HR, 0.73 (95% CI, 0.58 to 0.92); p=0.008; Subgroups:; No difference by age at randomization.; [underlined: Cumulative followup: Median 17.7 years]; Alzheimer’s disease or other dementia mortality; 127 (0.15% annualized) vs. 175 (0.20%); HR, 0.74 (95% CI, 0.59 to 0.94); p=0.01; Subgroups:; No difference by age at randomization. | NR | NR
WHI Estrogen plus progestin trial; Manson, 2017^88^ | 8,506 Estrogen plus progestin; 8,102 Placebo | [underlined: Intervention followup: Median 5.6 years]; Alzheimer’s disease or other dementia mortality; 0 (0% annualized) vs. 0 (0%); HR not estimatable; [underlined: Postintervention followup: Median 12.5 years]; Alzheimer’s disease or other dementia mortality; 223 (0.24% annualized) vs. 233 (0.26%); HR, 0.94 (95% CI, 0.78 to 1.13); p=0.52; Subgroups:; No difference by age at randomization.; [underlined: Cumulative followup: Median 17.7 years]; Alzheimer’s disease or other dementia mortality; 223 (0.16% annualized) vs. 233 (0.17%); HR, 0.93 (95% CI, 0.77 to 1.11); p=0.42; Subgroups:; No difference by age at randomization. | NR | NR

* Intervention dosages are listed in Table 3 by trial.

Abbreviations: CI=confidence interval; HR=hazard ratio; MCI=mild cognitive impairment; NR=not reported; NS=not significant; RR=relative risk; vs.=versus; WHI=Women’s Health Initiative; WHIMS=Women’s Health Initiative Memory Study; WHISCA=Women’s Health Initiative Study of Cognitive Aging.

Appendix F Table 13 Outcomes From Trials Reporting Incidence of Cognitive Function Scores

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
Study; Author, Year | Population | Global Cognitive Function (3MS Scores or TICS-m Scores) | Other Cognitive Measures
ELITE-Cog; Henderson, 2016^92^ | 323 Estrogen; 320 Placebo | NR | [underlined: Followup: Mean 4.8 years]; Change in verbal episodic memory; 0.33 (SE, 0.06) vs. 0.40 (SE, 0.07); difference, −0.07 (95% CI, −0.25 to 0.10); p=0.25; Subgroups:; No difference for women with surgical vs. natural menopause.; Risk based on timing of intervention:; No difference by timing of intervention.^†^; Change in executive functions; −0.08 (SE, 0.04) vs. −0.05 (SE, 0.05); difference, −0.03 (95% CI, −0.15 to 0.10); p=0.085; Subgroups:; No difference for women with surgical vs. natural menopause.; Risk based on timing of intervention:; No difference by timing of intervention.; Change in global cognition; 0.36 (SE, 0.06) vs. 0.39 (SE, 0.07); difference, −0.03 (95% CI, −0.21 to 0.15); p=0.75; Subgroups:; No difference for women with surgical vs. natural menopause.; Risk based on timing of intervention:; No difference by timing of intervention.; Neuropsychological test scores; No significant treatment effect.
EMS Estrogen plus progestin trial; Tierney, 2009^141^ | Women with normal to just below normal scores on cognitive battery tests, but free of dementia: 70 Estrogen plus progestin 72 Placebo | NR | [underlined: Followup: 1 year]; CVLT short-delay verbal recall; No significant differences by group.; [underlined: Followup: 2 years]; CVLT short-delay verbal recall; No significant differences by group.
HERS Estrogen plus progestin trial; Grady, 2002^145^ | 662 Estrogen plus progestin; 666 Placebo | [underlined: Followup: 4.2 years]; 3MS; 93.1 (SD, 6.4) vs. 93.4 (SD, 6.4); difference,; −0.4 (95% CI, −1.1 to 0.4); p=0.36 | [underlined: Followup: 4.2 years]; Verbal fluency; 15.9 (SD, 4.8) vs. 16.6 (SD, 4.8); difference,; −0.7 (95% CI, −1.3 to −0.1); p=0.02; Boston Naming Test; No significant differences by group.; Word List Memory; No significant differences by group.; Word List Recall; No significant differences by group.; Trials B; No significant differences by group.
KEEPS-Cog Estrogen plus progestin trial; Gleason, 2015^146^ | 220 Estrogen (oral) plus progesterone; 211 Estrogen (transdermal) plus progesteroone; 262 Placebo | [underlined: Followup: 4 years]; 3MS; Oral estrogen: Beta estimate, 1.02 × 10^−2^ (95% CI, −4.45 × 10^−3^ to 2.48 × 10^−2^); p=0.178; Transdermal estrogen: Beta estimate, −9.40 × 10^−4^ (95% CI, −1.57 × 10^−2^ to 1.38 × 10^−2^); p=0.840 | NR
KEEPS-MRI; Kantarci, 2016^100^ | 31 Estrogen (oral) plus progesterone; 31 Estrogen (transdermal) plus progesterone; 39 Placebo | Followup: 4 years; 3MS; No significant differences in changes in global cognitive function.^ǂ^ | NR
ULTRA Estrogen-only trial; Yaffe, 2006^124^ | 417 Enrolled; 208 Estrogen; 209 Placebo | [underlined: Followup: 2 years]; Baseline 3MS ≤90; 5.90 vs. 7.10; difference, −1.21 (95% CI, −5.05 to 2.64); p=0.53; Baseline 3MS >90; 0.57 vs. 0.87; difference, −0.30 (95% CI, −0.74 to 0.14); p=0.18 | [underlined: Followup: 2 years]; Logical Memory; No significant differences by group.; Brief Visuospatial Memory Test; No significant differences by group.; Word List; No significant differences by group.; Trials B; No significant differences by group.; Modified Boston Naming Test; No significant differences by group.; Verbal Fluency; No significant differences by group.
WHIMS-ECHO; Espeland, 2017^93^ | 1,402 Hormone therapy; 1,478 Placebo | [underlined: Postintervention followup: 6.4 years]; Analysis did not stratify by treatment regimen; Global cognitive function; TICS-m: 33.93 (SE, 0.11) vs. 34.30 (SE, 0.11); difference, −0.37 (SE, 0.15); p=0.01 | [underlined: Postintervention followup: 6.4 years]; Analysis did not stratify by treatment regimen; Executive function; OTMT-B: 57.49 (SE, 0.69) vs. 55.24 (SE, 0.67); difference, 2.25 (SE, 0.96); p=0.02; DST forward for working memory; 7.44 (SE, 0.05) vs. 7.61 (SE, 0.04); difference −0.17 (SE, 0.06); p=0.008; DST backward for working memory; No significant differences by group.; Verbal Fluency; No significant differences by group.; Verbal Memory; No significant differences by group.; Attention; No significant differences by group.; Subgroups:; No difference by CEE-alone and CEE + MPA therapy, for diabetes.
WHIMS Estrogen-only trial; Espeland, 2004^121^ | Women without probable dementia; General cognitive function, enrolled in WHIMS >6 months after initiation of assigned WHI therapy and with >1 postrandomization 3MS score:^121^ 1,387 Estrogen 1,421 Placebo; Subgroup analysis:; 1,464 Estrogen; 1,483 Placebo | [underlined: Followup: Mean 5.4 years]; 3MS; Mean difference in change from baseline, −0.26 (95% CI, −0.52 to 0.00); p=0.04 | NR
WHIMS Estrogen plus progestin trial; Rapp, 2003;^147^; Espeland, 2004^121^ | Women without probable dementia; Cognitive function outcomes:^121^; 2,131 Estrogen plus progestin; 2,213 Placebo | [underlined: Followup: 5.4 years] ^121^; 3MS; Mean difference in change from baseline,; −0.18 (95% CI, −0.37 to 0.00); p=0.055; Subgroups: ^147^; No difference in the rate of change by race, length of use, or history of cardiovascular disease, diabetes, or hypertension.; Risk based on timing of intervention:^147^; No difference in the rate of change by time to initiation of therapy after last menstrual period. | NR
WHIMSY Estrogen-only trial; Espeland, 2013;^123^ Espeland, 2017^93^ | 696 Hormone therapy^§^; 630 Placebo | [underlined: Postintervention followup: 7.2 years]; TICS-m; 37.67 (SE, 0.26) vs. 37.28 (SE, 0.27); p=NR | [underlined: Postintervention followup: 7.2 years]; Verbal Fluency; No significant differences by group.; Verbal Memory; No significant differences by group.; Attention; No significant differences by group.; Executive function; No significant differences by group.; Working Memory; No significant differences by group.; East Boston Memory Test; No significant differences by group.; Composite cognitive function; No significant differences by group.
WHIMSY Estrogen plus progestin trial; Espeland, 2013;^123^ Espeland, 2017^93^ | 696 Hormone therapy^§^; 630 Placebo^ǁ^ | [underlined: Postintervention followup: 7.2 years]; TICS-m: 38.08 (SE, 0.20) vs. 38.26 (SE, 0.21); p=NR | [underlined: Postintervention followup: 7.2 years]; Verbal Fluency; No significant differences by group.; Verbal Memory; No significant differences by group.; Attention; No significant differences by group.; Executive function; No significant differences by group.; Working Memory; No significant differences by group.; East Boston Memory Test; No significant differences by group.; Composite cognitive function; No significant differences by group.
WHISCA Estrogen-only trial; Espeland, 2010^122^ | Cognitive measures, WHISCA extension:^122^; 601 Hormone therapy; 612 Placebo | [underlined: Followup: 3.6 years] (during WHISCA, after being enrolled in WHI for 3 years)^122^; Mean decrement in global cognitive function, 3MS; −0.092 (SE, 0.039); p=0.02; [underlined: Postintervention followup: Mean 2.4 years] (after being enrolled in WHI for 3 years and WHISCA for 3.6 years)^122^; Mean decrement in global cognitive function, 3MS; −0.081 (SE, 0.047); p=0.09 | [underlined: Followup: Mean 3.6 years] ^122^; Verbal knowledge; −0.100 (SE, 0.051); p=0.05; Verbal fluency; −0.118 (SE, 0.054); p=0.03; Figural memory; −0.132 (SE, 0.048); p=0.006; Spatial ability; −0.137 (SE, 0.057); p=0.02; Verbal Memory; No significant differences by group.; Attention; No significant differences by group.; Working Memory; No significant differences by group.; [underlined: Postintervention followup: 2.4 years] ^122^; Spatial ability; −0.179 (SE, 0.063); p=0.004; Verbal Knowledge; No significant differences by group.; Verbal Fluency; No significant differences by group.; Verbal Memory; No significant differences by group.; Figural Memory; No significant differences by group.; Attention; No significant differences by group.; Working Memory; No significant differences by group.
WHISCA Estrogen plus progestin trial; Espeland, 2010^122^ | Cognitive measures, WHISCA extension^122^; 601 Hormone therapy; 612 Placebo | [underlined: Followup: Mean 2 years] (during WHISCA, after being enrolled in WHI for 3 years)^122^; Mean decrement in global cognitive function, 3MS; −0.080 (SE, 0.034); p=0.02; [underlined: Postintervention followup: Mean 4 years] (after being enrolled in WHI for 3 years and in WHISCA for 2 years)^122^; Mean decrement in global cognitive function, 3MS; −0.059 (SE, 0.032); p=0.06 | [underlined: Followup: Mean 3 years] (pre-WHISCA, 2 years during WHISCA trial)^122^; Spatial Ability; No significant differences by group.; Verbal Knowledge; No significant differences by group.; Verbal Fluency; No significant differences by group.; Verbal Memory; No significant differences by group.; Figural Memory; No significant differences by group.; Attention; No significant differences by group.; Working Memory; No significant differences by group.; [underlined: Postintervention followup: Mean 4 years] ^122^; Spatial Ability; No significant differences by group.; Verbal Knowledge; No significant differences by group.; Verbal Fluency; No significant differences by group.; Verbal Memory; No significant differences by group.; Figural Memory; No significant differences by group.; Attention; No significant differences by group.; Working Memory; No significant differences by group.

* Intervention dosages are listed in Table 3 by trial.

† In the ELITE study, early-group women were within 6 years of a final menstrual period or surgical menopause. In the late group, women were at least 10 years beyond natural or surgical menopause.

ǂ Authors did not report absolute values of 3MS by group, visual display only.

§ CEE and CEE+MPA group numbers not reported.

ǁ N reported from Espeland.^123^ Subsequent study^93^ reports: 701 HT and 635 placebo. Unclear reason for discrepancy.

Abbreviations: 3MS=Modified Mini-Mental State Examination; CEE=conjugated equine estrogen; CI=confidence interval; DST=Digit Span Test; ELITE=Early versus Late Intervention Trial with Estradiol; EMS=Estrogen Memory Study; HERS=Heart and Estrogen/Progestin Replacement Study; HT=hormone therapy; KEEPS=Kronos Early Estrogen Prevention Study; KEEPS-MRI=Kronos Early Estrogen Prevention Study-MRI; MPA=medroxyprogesterone acetate; NR=not reported; OTMT-B=Oral Trail Making Test Part B; SD=standard deviation; SE=standard error; TICS=Telephone Interview for Cognitive Status; ULTRA=Ultra-Low-Dose Transdermal Estrogen Replacement Assessment; vs.=versus; WHI=Women’s Health Initiative; WHIMS=Women’s Health Initiative Memory Study; WHIMS-ECHO=Women’s Health Initiative Memory Study of the Epidemiology of Cognitive Health Outcomes; WHIMSY=Women’s Health Initiative Memory Study of Younger Women; WHISCA=Women’s Health Initiative Study of Cognitive Aging.

Appendix F Table 14 Outcomes From Trials Reporting Incidence of Diabetes

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
Greenspan et al Estrogen-only and estrogen plus progestin trial; Greenspan, 2005^107^ | 66 Estrogen; 121 Estrogen plus progestin; 186 Placebo | [underlined: Intervention followup: 3 years]; Analysis did not stratify by regimen.; 2 (1.1%) vs. 6 (3.2%); p=0.17
HERS Estrogen plus progestin trial; Kanaya, 2003^148^ | Women without self-reported diabetes at baseline; 999 Estrogen plus progestin; 1,030 Placebo | [underlined: Intervention followup: Mean 4.1 years]; Overall; 62 (6.2%) vs. 98 (9.5%); HR, 0.65 (95% CI, 0.48 to 0.89); p=0.006
WHI Estrogen-only trial; Bonds, 2006;^125^ Manson, 2013;^67^ Prentice, 2020^101^ | Women not receiving treatment for diabetes at baseline; 4,900 Estrogen; 5,017 Placebo | [underlined: Intervention followup: Mean 7.1/median 7.2 years]; Self-reported treated diabetes ^67^; 449 (1.34% annualized) vs. 527 (1.55% annualized); HR, 0.86 (95% CI, 0.76 to 0.98); p=0.02; Subgroups: ^125^; No significant difference by race/ethnicity, age at screening, hypertension, or metabolic syndrome at baseline.; [underlined: Postintervention followup: Median 6.6 years] ^67^; Self-reported treated diabetes; 323 (1.64% annualized) vs. 306 (1.54% annualized); HR, 1.07 (95% CI, 0.92 to 1.25); p=0.39; [underlined: Cumulative followup: Median 13.0 years] ^67^; Self-reported treated diabetes; 772 (1.45% annualized) vs. 833 (1.55% annualized); HR, 0.94 (95% CI, 0.85 to 1.04); p=0.22
WHI Estrogen plus progestin trial; Margolis, 2004;^149^ Manson, 2013;^67^ Prentice, 2020^101^ | Women not receiving treatment for diabetes at baseline; 8,132 Estrogen plus progestin; 7,742 Placebo | [underlined: Intervention followup: Mean 5.6 years]; Self-reported treated diabetes ^67^; 328 (0.72% annualized) vs. 373 (0.88% annualized); HR, 0.81 (95% CI, 0.70 to 0.94); p=0.005; Subgroups:^149^; No significant difference by race/ethnicity, age at screening, or hypertension at baseline.; [underlined: Postintervention followup: Median 8.2 years] ^67^; Self-reported treated diabetes; 603 (1.24% annualized) vs. 482 (1.04% annualized); HR, 1.19 (95% CI, 1.05 to 1.34); p=0.005; [underlined: Cumulative followup: Median 13.2 years] ^67^; Self-reported treated diabetes; 931 (0.99% annualized) vs. 855 (0.96% annualized); HR, 1.02 (95% CI, 0.93 to 1.12); p=0.66

* Intervention dosages are listed in Table 3 by trial.

Abbreviations: CI=confidence interval; HERS=Heart and Estrogen/Progestin Replacement Study; HR=hazard ratio; vs.=versus; WHI=Women’s Health Initiative.

Appendix F Table 15 Outcomes From Trials Reporting Incidence of Fractures

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
EMS Estrogen plus progestin trial; Tierney, 2009^141^ | 70 Estrogen plus progestin; 72 Placebo | [underlined: Intervention followup: 2 years]; Total; 3 (4.3%) vs. 7 (9.7%); p=NR; Hip; 0 (0.0%) vs. 1 (1.4%); p=NR
EPHT Estrogen plus progestin trial; Veerus, 2006^137^ | 404 Estrogen plus progestin; 373 Placebo; Timing of intervention analysis: 251 total (analysis did not report by regimen) | [underlined: Intervention followup: 5 years]; Bone fractures ^†^; 15 (3.7%) vs. 25 (6.7%); HR, 0.52 (95% CI, 0.27 to 0.98); p=NR; Risk based on timing of intervention:; No significant difference among women within 3 years of menopause.
ERA Estrogen-only and estrogen plus progestin trial; Herrington, 2000^113^ | 100 Estrogen; 104 Estrogen plus progestin; 105 Placebo | [underlined: Intervention followup: Mean 3.2 years]; Fractures (all sites); 6 (6.0%) vs. 7 (6.7%) vs. 15 (14.3%); Estrogen: Calculated RR, 0.42 (95% CI, 0.17 to 1.04); p=0.06; Estrogen plus progestin: Calculated RR, 0.47 (95% CI, 0.24 to 1.11); p=0.09
HERS Estrogen plus progestin trial; Hulley, 2002^136^ | 1,380 Estrogen plus progestin; 1,383 Placebo | [underlined: Intervention followup: Mean 4.1 years]; Any; 140 vs. 148; HR, 0.96 (95% CI, 0.76 to 1.20); p=0.70; Hip; 15 vs. 13; HR, 1.16 (95% CI, 0.55 to 2.44); p=0.69; Wrist; 29 vs. 29; HR, 1.01 (95% CI, 0.60 to 1.68); p=0.98; Vertebral; 14 vs. 19; HR, 0.74 (95% CI, 0.37 to 1.48); p=0.40; Other (i.e., not hip, wrist, or vertebral); 91 vs. 101; HR, 0.91 (95% CI, 0.69 to 1.21); p=0.52
STOP-IT Estrogen plus progestin trial; Gallagher 2001^106^ | 121 Hormone therapy; 122 Hormone therapy plus calcitriol; 123 Calcitriol only; 123 Placebo | [underlined: Intervention followup: 3 years]; Vertebral; Analysis did not stratify by regimen.; 2 (hormone therapy with or without calcitriol) vs. 1 (calcitriol only or placebo)
WHI Estrogen-only trial; LaCroix, 2011;^108^ Anderson, 2004;^126^ Manson, 2013;^67^ Manson, 2019;^89^ Watts, 2017;^97^ Prentice, 2020;^101^ Chlebowski, 2017;^95^ Prentice, 2020^91^ | 5,310 Estrogen; 5,429 Placebo; Postintervention followup:^108^; 3,778 Estrogen; 3,867 Placebo; Postintervention followup:^89^; 2,521 Estrogen; 2,532 Placebo | [underlined: Intervention followup: Median 7.2 years]; Total ^67^; 544 (1.53% annualized) vs. 767 (2.14% annualized); HR, 0.72 (95% CI, 0.64 to 0.80); p<0.001; Subgroups:; No significant difference by age.^67^; Hip^67,^ ^108^; 48 (0.13% annualized) vs. 74 (0.19% annualized); HR, 0.67 (95% CI, 0.46 to 0.96); p=0.03; Subgroups:; No significant difference by age or race.^67,^ ^95,^ ^126^; Risk based on timing of intervention (p=0.03): ^67^; <10 years since menopause: 5 (0.08% annualized) vs. 1 (0.02% annualized); HR, 4.83 (95% CI, 0.56 to 41.41); 10–19 years since menopause: 9 (0.09% annualized) vs. 10 (0.09% annualized); HR, 0.97 (95% CI, 0.39 to 2.39); ≥20 years since menopause: 26 (0.17% annualized) vs. 49 (0.31% annualized); HR, 0.56 (95% CI, 0.35 to 0.90); Vertebral ^67^; 44 (0.12% annualized) vs. 70 (0.18% annualized); HR, 0.64 (95% CI, 0.44 to 0.93); p=0.02; Subgroups:; No significant difference by age.^67,^ ^126^; [underlined: Postintervention followup: Mean 3.9 years] ^108^; Hip; 66 (0.36% annualized) vs. 53 (0.28% annualized); HR, 1.27 (95% CI, 0.88 to 1.82); p=NR; [underlined: Postintervention followup: Calculated mean 4.3 years] ^97^; Total; 321 (3.11% annualized) vs. 378 (3.69% annualized); HR, 0.85 (95% CI, 0.73 to 0.98); p=0.03; Subgroups:; No significant difference by age.; Hip; 30 (0.28% annualized) vs. 29 (0.27% annualized); HR, 1.04 (95% CI, 0.62 to 1.73); p=0.89; Subgroups:; No significant difference by age.; [underlined: Cumulative followup: Mean 10.7 years] ^108^; Hip; 114 (0.20% annualized) vs. 127 (0.22% annualized); HR, 0.92 (95% CI, 0.71 to 1.18); p=NR; Subgroups:; No significant difference by age.; [underlined: Cumulative followup: Median 13.0 years]; Hip; 134 (0.22% annualized) vs. 148 (0.24% annualized; HR, 0.91 (95% CI, 0.72 to 1.15); p=0.44^67^; Subgroups:; No significant difference by race.^95^; [underlined: Cumulative followup: Median 18.0 years]; Hip; Subgroups:; No significant difference by age or oophorectomy status within any age group at randomization.^89,^ ^91^; [underlined: Cumulative followup: Median 19.4 years] ^101^; Hip; 208 (3.9% calculated) vs. 229 (4.2% calculated); HR, 0.92 (95% CI, 0.76 to 1.11); p=NR
WHI Estrogen plus progestin trial; Heiss, 2008;^132^ Cauley, 2003;^150^ Rossouw, 2002;^36^ Manson, 2013;^67^ Watts, 2017;^97^ Prentice, 2020;^101^ Prentice, 2020^91^ | 8,506 Estrogen plus progestin; 8,102 Placebo; Postintervention followup:; 8,052 Estrogen plus progestin; 7,678 Placebo | [underlined: Intervention followup: Mean 5.6 years]; Total ^67^; 741 (1.61% annualized) vs. 903 (2.12% annualized); HR, 0.76 (95% CI, 0.69 to 0.83); p<0.001; Subgroups; No significant difference by age.; Hip ^67^; 53 (0.11% annualized) vs. 75 (0.17% annualized); HR, 0.67 (95% CI, 0.47 to 0.96); p=0.03; Subgroups; No significant difference by age.; Risk based on timing of intervention:; No significant difference by timing of intervention.; Vertebral ^67^; 56 (0.12% annualized) vs. 78 (0.17% annualized); HR, 0.68 (95% CI, 0.48 to 0.96); p=0.03; Subgroups; No significant difference by age.; Other osteoporotic fractures ^132^; 650 (1.41% annualized) vs. 800 (1.87% annualized); HR, 0.75 (95% CI, 0.68 to 0.83); p=NR; [underlined: Postintervention followup: Mean 2.4 years]; Total (hip, vertebral, or other osteoporotic fractures) ^132^; 337 (1.95% annualized) vs. 346 (2.16% annualized); HR, 0.91 (95% CI, 0.78 to 1.06); p=0.06; Hip; 54 (0.28% annualized) vs. 57 (0.31% annualized); HR, 0.92 (95% CI, 0.64 to 1.34); p=0.20^132^; Risk based on timing of intervention:; No significant difference by years since menopause.^67^; Vertebral ^132^; 46 (0.24% annualized) vs. 47 (0.26% annualized); HR, 0.96 (95% CI, 0.64 to 1.44); p=0.23; Other osteoporotic fractures ^132^; 267 (1.52% annualized) vs. 285 (1.75% annualized); HR, 0.87 (95% CI, 0.74 to 1.03); p=0.16; [underlined: Postintervention followup: Calculated mean 4.2 years] ^97^; Total; 572 (2.89% annualized) vs. 612 (2.99% annualized); HR, 0.97 (95% CI, 0.87 to 1.09); p=0.63; Subgroups:; No significant difference by age.; Risk based on timing of intervention:; No significant difference in total fractures by years since menopause.; Hip; 50 (0.24% annualized) vs. 56 (0.26% annualized); HR, 0.93 (95% CI, 0.63 to 1.36); p=0.70; Subgroups:; No significant difference by age.; [underlined: Cumulative followup: Median 13.2 years] ^67^; [underlined: Hip]; 232 (0.23% annualized) vs. 270 (0.28% annualized; HR, 0.81 (95% CI, 0.68 to 0.97); p=0.02; [underlined: Cumulative followup: Median 18.0 years] ^91^; Hip; Subgroups ^91^; No significant difference by age.; [underlined: Cumulative followup: Median 19.4 years] ^101^; Hip; 394 (4.6% calculated) vs. 421 (5.2% calculated); HR, 0.90 (95% CI, 0.78 to 1.03); p=NR

* Intervention dosages are listed in Table 3 by trial.

† Bone fractures defined as diagnoses Sx2 (x=1–9) according to ICD-10 (fracture of neck, fractures of ribs, sternum and thoracic spine, fracture of lumbar spine and pelvis, fracture of shoulder and upper arm, fracture of forearm, fracture at wrist and hand level, fracture of femur, fracture of lower leg, including ankle).

Abbreviations: CI=confidence interval; EMS=Estrogen Memory Study; EPHT=Estonian Postmenopausal Hormones Therapy Trial; ERA=Estrogen Replacement and Atherosclerosis Trial; HERS=Heart and Estrogen/Progestin Replacement Study; HR=hazard ratio; ICD-10=10th revision of the International Statistical Classification of Diseases and Related Health Problems; NR=not reported; RR=relative risk; STOP-IT=Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; vs.=versus; WHI=Women’s Health Initiative.

Appendix F Table 16 Outcomes From Trials Reporting Incidence of Gallbladder Disease

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
Greenspan, et al Estrogen-only and estrogen plus progestin trial; Greenspan, 2005^107^ | 66 Estrogen; 121 Estrogen plus progestin; 186 Placebo | [underlined: Intervention followup: 3 years] ^107^; Gallstones; Analysis did not stratify by regimen.; 1 (0.5%) vs. 1 (0.5%)
PEPI Estrogen-only and estrogen plus progestin trial; PEPI, 1995^32^ | 175 Estrogen only; 174 Estrogen plus progestin (cyclic); 174 Estrogen plus progestin (continuous); 178 Estrogen plus progestin (micronized); 174 Placebo | [underlined: Intervention followup: 3 years] ^32^; Gallbladder disease; 2 (estrogen: 1.1%) vs. 9 (estrogen plus progestin: 2.6%) vs. 4 (estrogen plus micronized progestin: 2.2%) vs. 2 (placebo: 1.1%)
STOP-IT Estrogen-only and estrogen plus progestin trial; Gallagher, 2001^106^ | 121 Hormone therapy; 122 Hormone therapy plus calcitriol; 123 Calcitriol only; 123 Placebo | [underlined: Intervention followup: 3 years] ^106^; Gallstones or cholecystitis; Analysis did not stratify by regimen.; 8 (hormone therapy with or without calcitriol: 3.3%) vs. 3 (calcitriol only or placebo: 1.2%)
WHI Estrogen-only trial; Cirillo, 2005;^127^ LaCroix, 2011;^108^ Manson, 2013;^67^ Prentice, 2020^101^ | Women without cholecystectomy or gallbladder disease at baseline; 4,141 Estrogen; 4,235 Placebo | [underlined: Intervention followup: Mean 7.1 years]; Gallbladder event incidence ^127^; 228 (5.5%) vs. 143 (3.4%); HR, 1.67 (95% CI, 1.35 to 2.06); p<0.001; Cholecystectomy ^127^; 192 (4.6%) vs. 104 (2.5%); HR, 1.93 (95% CI, 1.52 to 2.44); p<0.001; Global gallbladder disease ^67^; 461 (1.64% annualized) vs. 312 (1.06% annualized); HR, 1.55 (95% CI, 1.34 to 1.79); p<0.001; Cholecystitis ^127^; 186 (4.5%) vs. 107 (2.5%); HR, 1.80 (95% CI, 1.42 to 2.28); p<0.001; Subgroups: ^127^; No significant difference by age.; [underlined: Postintervention followup: Median 6.6 years] ^67^; Gallbladder disease; 57 (1.65% annualized) vs. 61 (1.66% annualized); HR, 0.98 (95% CI, 0.68 to 1.41); p=0.92
WHI Estrogen plus progestin trial; Cirillo, 2005;^127^ Manson, 2013;^67^ Prentice, 2020^101^ | Women without cholecystectomy or gallbladder disease at baseline; 7,308 Estrogen plus progestin; 6,895 Placebo | [underlined: Intervention followup: Mean 5.6 years]; Gallbladder event incidence ^127^; 228 (3.1%) vs. 135 (2.0%); HR, 1.59 (95% CI, 1.28 to 1.97); p<0.001; Cholecystectomy ^127^; 190 (2.6%) vs. 107 (1.6%); HR, 1.67 (95% CI, 1.32 to 2.11); p<0.001; Global gallbladder disease ^67^; 528 (1.31% annualized) vs. 319 (0.84% annualized); HR, 1.57 (95% CI, 1.36 to 1.80); p<0.001; Cholecystitis ^127^; 192 (2.6%) vs. 117 (1.7%); HR, 1.54 (95% CI, 1.22 to 1.94); p<0.001; Subgroups: ^127^; No significant difference by age.; [underlined: Postintervention followup: Median 8.2 years] ^67^; Gallbladder disease; 213 (1.27% annualized) vs. 166 (1.01% annualized); HR, 1.24 (95% CI, 1.01 to 1.52); p=0.04

* Intervention dosages are listed in Table 3 by trial.

Abbreviations: CI=confidence interval; HR=hazard ratio; PEPI=Postmenopausal Estrogen/Progestin Interventions; STOP-IT=Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; WHI=Women’s Health Initiative.

Appendix F Table 17 Outcomes From Trials Reporting Incidence of Stroke

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
EMS Estrogen plus progestin trial; Tierney, 2000^141^ | 70 Estrogen plus progestin; 72 Placebo | [underlined: Followup: 2 years]; Intracerebral hemorrhage; 1 (1.4%) (fatal) vs. 0; p=NS; Transient ischemic attack; 1 (1.4%) vs. 1 (1.4%); p=NS
EPAT Estrogen-only trial; Hodis, 2001^112^ | 111 Estrogen^†^; 111 Placebo^†^ | [underlined: Followup: 2 years]; Cerebrovascular accidents; 0 vs. 1
EPHT Estrogen plus progestin trial; Veerus, 2006^137^ | 404 Estrogen plus progestin; 373 Placebo | [underlined: Followup: Mean 3.4 years]; Any cerebrovascular disease ^‡^; 23 (5.7%) vs. 9 (2.4%); HR, 2.46 (95% CI, 1.14 to 5.34); p=NR; Stroke; 1 (0.2%) vs. 1 (0.3%); HR, 1.06 (95% CI, 0.07 to 17.2); p=NR
ERA Estrogen-only and estrogen plus progestin trial; Herrington, 2000^113^ | Women with angiographically verified coronary disease; 100 Estrogen; 104 Estrogen plus progestin; 105 Placebo | [underlined: Followup: Mean 3.2 years]; Stroke or transient ischemic attack; 5 vs. 6 vs. 6; p=1.0
STOP-IT Estrogen-only and estrogen plus progestin trial; Gallagher, 2001^106^ | 121 Hormone therapy; 122 Hormone therapy plus calcitriol; 123 Calcitriol only; 123 Placebo | [underlined: Followup: Mean 3 years]; Cerebrovascular accidents; Analysis did not stratify by regimen.; 10 (hormone therapy with or without calcitriol) vs. 7 (calcitriol only or placebo)
WAVE Estrogen-only and estrogen plus progestin trial; Waters, 2002^105^ | Women with a coronary stenosis of 15%–75%; 124 Estrogen (with or without vitamin C and E); 86 Estrogen plus progestin (with or without vitamin C and E); 213 Placebo (with or without vitamin C and E) | [underlined: Followup: Mean 2.8 years]; Stroke; Analysis did not stratify by regimen.; 9 (4.3%) vs. 4 (1.9%); p=0.17
WHI Estrogen-only trial; Hendrix, 2006;^128^ LaCroix, 2011;^108^ Manson, 2013;^67^ Prentice, 2009;^110^ Manson, 2019;^89^ Chlebowski, 2017;^95^ Prentice, 2020;^101^ Manson, 2017;^88^ Prentice, 2020^91^ | 5,310 Estrogen; 5,429 Placebo; Postintervention followup:; 3,778 Estrogen; 3,867 Placebo; Cumulative followup (intervention plus postintervention phases):; 4,911 Estrogen; 5,028 Placebo | [underlined: Intervention followup: Median 7.2 years]; Ischemic or hemorrhagic stroke ^67^; 169 (3.2% calculated) vs. 129 (2.4%); HR, 1.35 (95% CI, 1.07 to 1.70); p=0.01; Subgroups:; No significant difference by race/ethnicity, age, prior CVD, diabetes, hypertension.^95,^ ^128^; Risk based on timing of intervention:^67,^ ^110^; No significant difference by timing of intervention.; Stroke mortality ^88^; 23 (0.060%) vs. 24 (0.060%); HR, 1.00 (95% CI, 0.57 to 1.78); p=0.99; [underlined: Postintervention followup: Mean 3.9 years] ^108^; All stroke; 66 (0.36% annualized) vs. 77 (0.41%); HR, 0.89 (95% CI, 0.64 to 1.24); p=NR; [underlined: Postintervention followup: Median 10.8 years] ^88^; Stroke mortality; 103 (0.21%) vs. 108 (0.22%); HR, 0.98 (95% CI, 0.75 to 1.28); p=0.86; Subgroups:; No significant difference by age.; [underlined: Cumulative followup: Median 13.0 years]^67,^ ^108^; All stroke; 278 (0.46% annualized) vs. 253 (0.41%); HR, 1.15 (95% CI, 0.97 to 1.37); p=0.10; [underlined: Cumulative followup: Median 17.7 years] ^88^; Stroke mortality; 126 (0.14%) vs. 132 (0.15%); HR, 0.98 (95% CI, 0.77 to 1.26); p=0.89; Subgroups:; No significant difference by age.; [underlined: Cumulative followup: Median 18.0 years]; All stroke; Subgroups:; No significant difference by race or oophorectomy status within any age group at randomization.^89,^ ^95^ No significant difference within age groups.^91^; [underlined: Cumulative Followup: Median 19.4 years] ^101^; Ischemic or hemorrhagic stroke; 399 (7.5% calculated) vs. 392 (7.2%); HR, 1.06 (95% CI, 0.92 to 1.22); p=NR
WHI Estrogen plus progestin trial; Wassertheil-Smoller, 2003;^151^ Heiss, 2008;^132^ Cushman, 2004;^153^ Manson, 2013;^67^ Prentice, 2020^101^ Manson, 2017;^88^ Prentice, 2020^91^ | 8,506 Estrogen plus progestin; 8,102 Placebo; Postintervention Followup:; 8,052 Estrogen plus progestin; 7,678 Placebo | [underlined: Intervention followup: Mean 5.6 years]; Ischemic or hemorrhagic stroke ^67^; 159 (1.9% calculated) vs. 109 (1.3%); HR, 1.37 (95% CI, 1.07 to 1.76); p=0.01^67^; Subgroups:; No significant difference by race/ethnicity, age, diabetes, or hypertension.^151^ No significant difference within age groups.^91^; Risk based on timing of intervention:^67,^ ^110^; No significant difference by timing of intervention.; Ischemic stroke ^151^; 125 vs. 81; HR, 1.44 (95% CI, 1.09 to 1.90); Hemorrhagic stroke ^151^; 18 vs. 20; HR, 0.82 (95% CI, 0.43 to 1.56); Stroke mortality ^88^; 27 (0.055% annualized) vs. 16 (0.035%); HR, 1.58 (95% CI, 0.85 to 2.94); p=0.14; Subgroups:; No significant difference by age.; [underlined: Postintervention followup: Mean 2.4 years] ^67^; All stroke; 217 (0.40% annualized) vs. 202 (0.39%); HR, 1.04 (95% CI, 0.86 to 1.26); p=0.67; [underlined: Postintervention followup: Median 12.5 years] ^88^; Stroke mortality; 161 (0.17%) vs. 145 (0.16%); HR, 1.08 (95% CI, 0.86 to 1.35); p=0.52; Subgroups:; No significant difference by age.; [underlined: Cumulative followup: Median 13.2 years] ^67^; All stroke; 376 (0.37% annualized) vs. 311 (0.32%); HR, 1.16 (95% CI, 1.00 to 1.35); p=0.06; [underlined: Cumulative followup: Median 17.7 years] ^88^; Stroke mortality; 188 (0.13% annualized) vs. 161 (0.12%); HR, 1.12 (95% CI, 0.91 to 1.38); p=0.29; Subgroups:; No significant difference by age.; [underlined: Cumulative followup: Median 18.0 years] ^91^; Stroke; Subgroups:; No significant difference within age groups.; [underlined: Cumulative followup: Median 19.4 years] ^101^; Ischemic or hemorrhagic stroke; 579 (6.8% calculated) vs. 492 (6.1%); HR, 1.13 (95% CI, 1.00 to 1.27); p=NR

* Intervention dosages are listed in Table 3 by trial.

† Unopposed micronized 17V-estradiol (1 mg/d).

‡ Defined as diagnoses of one of the following (ICD-10 or 160-169 codes): subarachnoid hemorrhage, intracerebral hemorrhage, cerebral infarction, stroke, occlusion and stenosis of precerebral arteries, occlusion and stenosis of cerebral arteries, other cerebrovascular diseases, cerebrovascular disorders, or sequelae of cerebrovascular disease.

Abbreviations: CI=confidence interval; CVD=cardiovascular disease; EMS=Estrogen Memory Study; EPAT=Estrogen in the Prevention of Atherosclerosis; EPHT=Estonian Postmenopausal Hormone Therapy Trial; ERA=Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis; HR=hazard ratio; ICD-10=10th revision of the International Statistical Classification of Diseases and Related Health Problems; NR=not reported; NS=not significant; STOP-IT=Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; vs.=versus; WAVE=Women’s Angiographic Vitamin and Estrogen Trial; WHI=Women’s Health Initiative.

Appendix F Table 18 Outcomes From Trials Reporting Incidence of Urinary Incontinence

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
HERS Estrogen plus progestin trial; Steinauer, 2005^152^ | Women reporting no episodes of incontinence in the past week at baseline; 597 Estrogen plus progestin; 611 Placebo | [underlined: Followup: 4.2 years]; Weekly total urinary incontinence; 382 vs. 302; OR, 1.6 (95% CI, 1.3 to 1.9); p<0.001; Weekly stress urinary incontinence; OR, 1.7 (95% CI, 1.5 to 2.1); p<0.001; Weekly urge urinary incontinence; OR, 1.5 (95% CI, 1.2 to 1.8); p<0.001
ULTRA Estrogen-only trial; Waetjen, 2005^129^ | Women who were continent at baseline; 122 Estrogen (calculated); 117 Placebo (calculated) | [underlined: Followup: 2 years]; Weekly total urinary incontinence; 39.0% vs. 36.8%; OR, 1.2 (95% CI, 0.7 to 2.2); p=0.74
WHI Estrogen-only trial; Hendrix, 2005;^130^ Manson, 2013^67^ | Women with urinary incontinence data at baseline and 1 year; [underlined: Intervention followup: 1 year for total urinary incontinence] ^67^; 3,316 Estrogen (all continent at baseline)^†^; 3,451 Placebo (all continent at baseline)^†^; [underlined: Intervention followup: 1 year for all outcomes, except total urinary incontinence] ^130^; 1,526 Estrogen (all continent at baseline); 1,547 Placebo (all continent at baseline); [underlined: Intervention followup: 3 years] ^130^; 96 Estrogen (all continent at baseline and 1 year); 136 Placebo (all continent at baseline and 1 year); [underlined: Postintervention followup: Median 6.6 years] ^67^; 2,781 Estrogen (all continent at baseline); 2,863 Placebo (all continent at baseline) | [underlined: Intervention followup: 1 year]; Weekly total urinary incontinence ^67^; 773 (22.6% annualized) vs. 499 (14.0% annualized); HR, 1.61 (95% CI, 1.46 to 1.79); p<0.001; Incident urinary incontinence (≥1 episode/year) ^130^; 557 (36.5%) vs. 368 (23.8%); RR, 1.53 (95% CI, 1.37 to 1.71); p=NR; Stress urinary incontinence (≥1 episode/year) ^130^; 266 (17.4%) vs. 131 (8.5%); RR, 2.15 (95% CI, 1.77 to 2.62); p<0.001; Urge urinary incontinence (≥1 episode/year) ^130^; 210 (13.8%) vs. 184 (11.9%); RR, 1.32 (95% CI, 1.10 to 1.58); p=0.003; Mixed urinary incontinence (≥1 episode/year) ^130^; 76 (5.0%) vs. 50 (3.2%); RR, 1.79 (95% CI, 1.26 to 2.53); p=0.001; [underlined: Intervention followup: 3 years] ^130^; Incident urinary incontinence (≥1 episode/year); 27 (28.1%) vs. 26 (19.1%); RR, 1.47 (95% CI, 0.92 to 2.36); p=NR; [underlined: Postintervention followup: Median 6.6 years] ^67^; Weekly total urinary incontinence; 795 calculated (28.6%) vs. 661 calculated (23.1%); HR, 1.24 (95% CI, 1.13 to 1.35); p<0.001
WHI Estrogen plus progestin trial; Hendrix, 2005;^130^ Manson, 2013^67^ | Women with urinary incontinence data at baseline and 1 year; [underlined: Intervention followup: 1 year for total urinary incontinence] ^67^; 5,981 Estrogen plus progestin (all continent at baseline)^†^; 5,597 Placebo (all continent at baseline)^†^; [underlined: Intervention followup: 1 year for all outcomes, except total urinary incontinence] ^130^; 2,675 Estrogen plus progestin (all continent at baseline); 2,507 Placebo (all continent at baseline); [underlined: Intervention followup: 3 years] ^130^; 153 Estrogen plus progestin (all continent at baseline and 1 year); 185 Placebo (all continent at baseline and 1 year); [underlined: Postintervention followup: Median 6.6 years] ^67^; 5,194 Estrogen plus progestin (all continent at baseline); 4,879 Placebo (all continent at baseline) | [underlined: Intervention followup: 1 year]; Weekly total urinary incontinence ^67^; 1,021 (16.6% annualized) vs. 641 (11.1% annualized); HR, 1.49 (95% CI, 1.36 to 1.63); p<0.001; Incident urinary incontinence (≥1 episode/year) ^130^; 834 (31.2%) vs. 563 (22.5%); RR, 1.39 (95% CI, 1.27 to 1.52); Stress urinary incontinence (≥1 episode/year) ^130^; 429 (16.0%) vs. 218 (8.7%); RR, 1.87 (95% CI, 1.61 to 2.18); p<0.001; Urge urinary incontinence (≥1 episode/year) ^130^; 304 (11.4%) vs. 272 (10.8%); RR, 1.15 (95% CI, 0.99 to 1.34); p=0.06; Mixed urinary incontinence (≥1 episode/year) ^130^; 99 (3.7%) vs. 69 (2.8%); RR, 1.49 (95% CI, 1.10 to 2.01); p=0.01; [underlined: Intervention followup: 3 years] ^130^; Incident urinary incontinence (≥1 episode/year); 39 (25.5%) vs. 26 (14.1%); RR, 1.81 (95% CI, 1.16 to 2.84); p=NR; [underlined: Postintervention followup: Median 8.2 years] ^67^; Weekly total urinary incontinence; 1,221 calculated (23.5%) vs. 990 calculated (20.3%); HR, 1.16 (95% CI, 1.08 to 1.25); p<0.001

* Intervention dosages are listed in Table 3 by trial.

† The Ns of participants continent at baseline and included in the WHI trials’ urinary incontinence analyses after 1 year of intervention followup were provided through a communication with the WHI Researcher Help Desk (July 2021).

Abbreviations: CI=confidence interval; HERS=Heart and Estrogen/Progestin Replacement Study; HR=hazard ratio; N=number; NR=not reported; OR=odds ratio; RR=relative risk; ULTRA=Ultra Low-Dose Transdermal Estrogen Replacement Assessment; vs.=versus; WHI=Women’s Health Initiative.

Appendix F Table 19 Outcomes From Trials Reporting Incidence of Venous Thromboembolism

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
EMS Estrogen plus progestin trial; Tierney, 2000^141^ | 70 Estrogen plus progestin; 72 Placebo | [underlined: Followup: 2 years]; Deep vein thrombosis; 1 vs. 0; p=NS
EPAT Estrogen-only trial; Hodis, 2001^112^ | 111 Estrogen; 111 Placebo | [underlined: Followup: 2 years]; Deep vein thrombosis or pulmonary embolism; 0 (0.0%) vs. (0.0%)
EPHT Estrogen plus progestin trial; Veerus, 2006^137^ | 404 Estrogen plus progestin; 373 Placebo | [underlined: Followup: Mean 3.4 years]; Venous thromboembolism; 0 (0.0%) vs. 0 (0.0%)
ERA Estrogen-only and estrogen plus progestin trial; Herrington, 2000^113^ | 100 Estrogen; 104 Estrogen plus progestin; 105 Placebo | [underlined: Followup: 3.2 years]; Deep vein thrombosis or pulmonary embolism; 5 vs. 2 vs. 1; p=0.16 (For estrogen vs. placebo, p=0.11)
Greenspan, et al Estrogen-only and estrogen plus progestin trial; Greenspan, 2005^107^ | 66 Estrogen; 121 Estrogen plus progestin; 186 Placebo | [underlined: Followup: 3 years]; Deep vein thrombosis; Analysis did not stratify by regimen.; 2 vs. 1; p=1.0
HERS Estrogen plus progestin trial ^†^; Hulley, 2002^136^ | 1,380 Estrogen plus progestin; 1,383 Placebo; Cumulative followup:; 1,156 Estrogen plus progestin; 1,383 Placebo | [underlined: Intervention followup: Mean 4.1 years]; Total thromboembolic events; 34 (2.5% calculated) vs. 13 (0.9% calculated); HR, 2.66 (95% CI, 1.41 to 5.04); p=0.003; Deep vein thrombosis; 25 (1.8% calculated) vs. 9 (0.7% calculated); HR, 2.82 (95% CI, 1.32 to 6.04); p=0.008; Pulmonary embolism; 11 (0.8% calculated) vs. 4 (0.3% calculated); HR, 2.78 (95% CI, 0.89 to 8.74); p=0.08; [underlined: Cumulative followup: Mean 6.8 years]; Total thromboembolic events; 49 (4.2% calculated) vs. 24 (1.7% calculated); HR, 2.06 (95% CI, 1.26 to 3.36); p=NR
STOP-IT Estrogen-only and estrogen plus progestin trial; Gallagher, 2001^106^ | 121 Hormone therapy; 122 Hormone therapy plus calcitriol; 123 Calcitriol only; 123 Placebo | [underlined: Followup: 3 years]; Deep vein thrombosis; Analysis did not stratify by regimen.; 4 (hormone therapy with or without calcitriol) vs. 1 (calcitriol only or placebo)
WAVE Estrogen-only and estrogen plus progestin trial; Waters, 2002^105^ | Women with a coronary stenosis of 15%–75%; 124 Estrogen (with or without vitamin C and E); 86 Estrogen plus progestin (with or without vitamin C and E); 213 Placebo (with or without vitamin C and E) | [underlined: Followup: 2.8 years]; Deep vein thrombosis or pulmonary embolism; Analysis did not stratify by treatment regimen.; 4 vs. 4; p=0.93
WHI Estrogen-only trial; LaCroix, 2011;^108^ Curb, 2006;^131^ Prentice, 2009;^110^ Manson, 2013;^67^ Manson, 2019;^89^ Chlebowski, 2017;^95^ Prentice, 2020;^101^ Prentice, 2020^91^ | 5,310 Estrogen; 5,429 Placebo; Postintervention followup:; 3,778 Estrogen; 3,867 Placebo; Cumulative followup (intervention plus postintervention phases):; 4,911 Estrogen; 5,028 Placebo | [underlined: Intervention followup: Mean 7.1 years/Median 7.2 years]; Venous thromboembolism; 111 (2.1% calculated) vs. 86 (1.6%); HR, 1.32 (95% CI, 1.00 to 1.76); p=NR^101^; Subgroups: ^95^; No significant difference by race.; Risk based on timing of intervention: ^110^; No significant difference by timing of intervention.; Deep vein thrombosis; 85 (1.6%) vs. 59 (1.0%); HR, 1.48 (95% CI, 1.06 to 2.07); p=0.02^67,^ ^108^; Subgroups:^67,^ ^131^; No significant difference by race/ethnicity, age, or history of CVD.; Pulmonary embolism; 52 (0.14% annualized) vs. 39 (0.10%); HR, 1.35 (95% CI, 0.89 to 2.05); p=0.15^67^; Subgroups: ^91^; No significant difference within any age group.; Risk based on timing of intervention: ^67^; No significant difference by timing of intervention.; [underlined: Postintervention followup: Mean 3.9 years]; Venous thromboembolism ^95^; Subgroups:; [underlined: Race (p=0.049)]; White: 157 (0.34%) vs. 147 (0.31%); HR, 1.11 (95% CI, 0.88 to 1.39); Black: 23 (0.26%) vs. 40 (0.42%); HR, 0.63 (95% CI, 0.38 to 1.06); Deep vein thrombosis ^108^; HR, 0.63 (95% CI, 0.41 to 0.98); p=0.003; Pulmonary embolism ^108^; HR, 0.98 (95% CI, 0.62 to 1.55); p=0.29; [underlined: Cumulative followup: Median 13.0 years] ^67^; Deep vein thrombosis; 135 (0.22% annualized) vs. 133 (0.21%); HR, 1.05 (95% CI, 0.82 to 1.33); p=0.71; Subgroups:; No significant difference by age group.; Pulmonary embolism; 107 (0.17% annualized) vs. 96 (0.15%); HR, 1.15 (95% CI, 0.87 to 1.51); p=0.34; Subgroups:; No significant difference by age group.; [underlined: Cumulative followup: Median 18.0 years]; Pulmonary embolism; Subgroups:; No significant difference within any age group^91^ or by oophorectomy status within any age group.^89^; [underlined: Cumulative followup: Median 19.4 years] ^101^; Venous thromboembolism; 270 (5.1% calculated) vs. 288 (5.3% calculated); HR, 0.97 (95% CI, 0.82 to 1.14); p=NR
WHI Estrogen plus progestin trial; Heiss, 2008;^132^ Cushman, 2004;^153^ Manson, 2013;^67^ Prentice, 2009;^110^ Prentice, 2020;^101^ Prentice, 2020^91^ | 8,506 Estrogen plus progestin; 8,102 Placebo; Postintervention followup:; 8,052 Estrogen plus progestin; 7,678 Placebo | [underlined: Intervention followup: Median 5.6 years]; Venous thrombosis ^153^; 167 (1.96% calculated) vs. 76 (0.94%); HR, 2.06 (95% CI, 1.57 to 2.70); Risk based on timing of intervention: ^110^; No significant difference by timing of intervention.; Deep vein thrombosis ^67^; 122 (1.4% calculated) vs. 61 (0.8%); HR, 1.87 (95% CI, 1.37 to 2.54); p<0.001; Subgroups:; No significant difference by age.^67^; Pulmonary embolism ^67^; 87 (1.0% calculated) vs. 41 (0.5%); HR, 1.98 (95% CI, 1.36 to 2.87); p<0.001; Subgroups:; No significant difference by age.^67^; [underlined: Age (p=NR)] ^91^; 50–59 years: HR, 2.15 (95% CI, 0.96 to 4.80); 60–69 years: HR, 1.69 (95% CI, 1.01 to 2.86); 70–79 years: HR, 2.48 (95% CI, 1.23 to 4.99); Risk based on timing of intervention: ^67^; No significant difference by timing of intervention.; [underlined: Postintervention followup: Mean 2.4 years] ^132^; Deep vein thrombosis; HR, 1.07 (95% CI, 0.66 to 1.75); Pulmonary embolism; HR, 1.07 (95% CI, 0.62 to 1.86); [underlined: Cumulative followup: Median 13.2 years] ^67^; Deep vein thrombosis; 212 (0.21% annualized) vs. 162 (0.17%); HR, 1.24 (95% CI, 1.01 to 1.53); p=0.04; Subgroups:; No significant difference by age.; Pulmonary embolism; 172 (0.17% annualized) vs. 128 (0.13%); HR, 1.26 (95% CI, 1.00 to 1.59); p=0.05; Subgroups:; No significant difference by age.; [underlined: Cumulative followup: Median 18.0 years] ^91^; Pulmonary embolism; Subgroups:; No significant difference within any age group.; [underlined: Cumulative followup: Median 19.4 years] ^101^; Venous thromboembolism; 416 (4.9% calculated) vs. 348 (4.3%); HR, 1.14 (95% CI, 0.99 to 1.31); p=NR

* Intervention dosages are listed in Table 3 by trial.

† HERS was a blinded randomized, controlled trial that had a mean followup of 4.1 years. At the end of HERS, participants were unblinded and 93 percent reenrolled in the HERS II open-label study for an additional 2.7 years.

Abbreviations: CI=confidence interval; CVD=cardiovascular disease; EMS=Estrogen Memory Study; EPAT=Estrogen in the Prevention of Atherosclerosis; EPHT=Estonian Postmenopausal Hormone Therapy Trial; ERA=Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis; HERS=Heart and Estrogen/Progestin Replacement Study; HR=hazard ratio; NR=not reported; NS=not significant; STOP-IT=Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; vs.=versus; WAVE=Women’s Angiographic Vitamin and Estrogen Trial; WHI=Women’s Health Initiative.

Appendix F Table 20 Outcomes From Trials Reporting Incidence of Quality of Life

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
WHI Estrogen-only trial; Manson, 2013^67^ | 5,310 Estrogen; 5,429 Placebo | [underlined: Followup: Mean 7.2 years] ^67^; SF-36: Similar scores on all items except for emotional role (81.0 vs. 82.2; p=0.04) and social functioning (85.8 vs. 86.9; p=0.01), for which women taking placebo had statistically significantly better scores than women taking estrogen-only therapy
WHI Estrogen plus progestin trial; Manson, 2013;^67^ Hays, 2003^172^ | 8,506 Estrogen plus progestin; 8,102 Placebo | [underlined: Followup: Mean 5.6 years] ^67^; SF-36: Similar scores on all items except for physical functioning (82.6 vs. 81.8; p<0.001), physical role (77.4 vs. 76.2; p=0.02), bodily pain (77.6 vs. 75.6; p<0.001), and general health (76.6 vs. 76.1; p=0.02), for which women taking hormone therapy had statistically significantly better scores than women taking placebo

* Intervention dosages are listed in Table 3 by trial.

Abbreviations: SF-36=36-Item Short Form Survey; vs.=versus; WHI=Women’s Health Initiative.

Appendix F Table 21 Outcomes From Trials Reporting Incidence of All-Cause Mortality

Study; Author, Year | Population | Results (Treatment^*^ vs. Placebo)
ELITE-Cog; Henderson, 2016^92^ | 323 Estrogen; 320 Placebo | [underlined: Followup: Mean 4.8 years]; All-cause mortality; 1 (0.3%) vs. 1 (0.3%)
ERA Estrogen-only and estrogen plus progestin trial; Herrington, 2000^113^ | 100 Estrogen; 104 Estrogen plus progestin; 105 Placebo | [underlined: Followup: Mean 3.2 years]; All-cause mortality; 8 (8.0%) vs. 3 (2.9%) vs. 6 (5.7%); p=0.28
HERS Estrogen plus progestin trial; Hulley, 2002^136^ | 1,380 Estrogen plus progestin; 1,383 Placebo; Cumulative followup:; 1,156 Estrogen plus progestin; 1,383 Placebo | [underlined: Followup: Mean 4.1 years]; All-cause mortality; 130 (9.4%) vs. 123 (8.9%); HR, 1.06 (95% CI, 0.83 to 1.36); p=0.62; [underlined: Cumulative followup: Mean 6.8 years]; All-cause mortality; 261 (22.6%) vs. 239 (17.3%); HR, 1.08 (95% CI, 0.91 to 1.29); p=NR
STOP-IT Estrogen-only and estrogen plus progestin trial; Gallagher, 2001^106^ | 121 Hormone therapy; 122 Hormone therapy plus calcitriol; 123 Calcitriol only; 123 Placebo | [underlined: Followup: 3 years]; All-cause mortality; Analysis not stratified by hormone therapy regimen.; 3 (hormone therapy with or without calcitriol: 1.2%) vs. 2 (calcitriol only or placebo: 0.8%)
WAVE Estrogen-only and estrogen plus progestin trial; Waters, 2002^105^ | 124 Estrogen (with or without vitamin C and E); 86 Estrogen plus progestin (with or without vitamin C and E); 213 Placebo (with or without vitamin C and E) | [underlined: Followup: Mean 2.8 years]; All-cause mortality; Analysis not stratified by hormone therapy regimen.; 14 (6.7%) vs. 8 (3.8%)
WHI Estrogen-only trial; LaCroix, 2011;^108^ Manson, 2013;^67^ Prentice, 2009;^110^ Manson, 2019;^89^ Prentice, 2020;^101^ Chlebowski, 2017;^95^ Manson, 2017;^88^ Prentice, 2020^91^ | 5,310 Estrogen; 5,429 Placebo; Postintervention followup:; 3,778 Estrogen; 3,867 Placebo; Cumulative followup (intervention plus postintervention phases):; 4,911 Estrogen; 5,028 Placebo | [underlined: Intervention followup: Mean 7.2 years]; All-cause mortality ^108^; 300 (5.6%) vs. 297 (5.5%); HR, 1.04 (95% CI, 0.89 to 1.22); p=NR; Subgroups:; No significant difference by race,^95^ oophorectomy status in the overall sample or by age group, or by age at oophorectomy among younger or older women.^89^; [underlined: Age (p=0.04)]^88,^ ^91^; 50–59 years: 35 (0.28% annualized) vs. 50 (0.39% annualized); HR, 0.71 (95% CI, 0.46 to 1.09); 60–69 years: 130 (0.76% annualized) vs. 134 (0.75% annualized); HR, 1.02 (95% CI, 0.80 to 1.30); 70–79 years: 136 (1.53% annualized) vs. 115 (1.27% annualized); HR, 1.22 (95% CI, 0.95 to 1.56); Comparing younger women (ages 50–59) to older women (ages 70–79): ratio of HRs, 0.58 (95% CI, 0.35 to 0.96); Risk based on timing of intervention:; No significant difference by timing of intervention in the overall sample^67^ or among women without prior hormone therapy use.^110^; [underlined: Postintervention followup: Mean 3.9 years] ^108^; All-cause mortality; 277 (1.47% annualized) vs. 284 (1.48% annualized); HR, 1.00 (95% CI, 0.84 to 1.18); p=NR; [underlined: Postintervention followup: Median 10.8 years] ^88^; All-cause mortality; 1,204 (2.48% annualized) vs. 1,331 (2.69%); HR, 0.92 (95% CI, 0.85 to 0.99); p=0.03; Subgroup:; No significant difference by age group.; [underlined: Cumulative followup: Mean 10.7 years] ^108^; All-cause mortality; 577 (1.02% annualized) vs. 581 (1.00% annualized); HR, 1.02 (95% CI, 0.91 to 1.15); p=NR; [underlined: Cumulative followup: Median 13.0 years]; All-cause mortality ^67^; 704 (1.14% annualized) vs. 725 (1.14% annualized); HR, 0.99 (95% CI, 0.90 to 1.10); p=0.92; Subgroups:; No significant difference by race^95^ or age.^67^; [underlined: Cumulative followup: Median 17.7 years] ^88^; All-cause mortality; 1,505 (1.73% annualized) vs. 1,630 (1.83% annualized); HR, 0.94 (95% CI, 0.88 to 1.01); p=0.11; Subgroups:; No significant difference by age group.; [underlined: Cumulative followup: Median 18.0 years]; All-cause mortality; Subgroups:; No significant difference within age group^91^ or by oophorectomy status in the overall sample or by prior hormone therapy use, by age at oophorectomy among younger or older women, or by age among women without oophorectomy.^89^; [underlined: Age among women with oophorectomy] (p=0.034) ^89^; 50–59 years: 53 (0.56% annualized) vs. 84 (0.79% annualized); HR, 0.68 (95% CI, 0.48 to 0.96); 60–69 years: 225 (1.50% annualized) vs. 280 (1.71% annualized); HR, 0.88 (95% CI, 0.74 to 1.05); 70–79 years: 262 (3.65% annualized) vs. 284 (3.65% annualized); HR, 1.02 (95% CI, 0.86 to 1.21); [underlined: Cumulative followup: Median 19.4 years] ^101^; All-cause mortality; 1,899 (35.8% calculated) vs. 2,004 (36.9% calculated); HR, 0.97 (95% CI, 0.91 to 1.03); p=NR
WHI Estrogen plus progestin trial; Heiss, 2008;^132^ Manson, 2013;^67^ Prentice, 2009;^110^ Prentice, 2020;^101^ Manson, 2017;^88^ Prentice, 2020^91^ | 8,506 Estrogen plus progestin; 8,102 Placebo; Postintervention extension followup:; 6,545 Estrogen plus progestin; 6,243 Placebo; Cumulative followup; 8,506 Estrogen plus progestin; 8,102 Placebo | [underlined: Intervention followup: Median 5.6 years]; All-cause mortality; 250 (2.9% calculated) vs. 239 (2.9% calculated); HR, 0.97 (95% CI, 0.81 to 1.16)^88,^ ^132^; Subgroups: ^88^; No significant difference by age group.; Risk based on timing of intervention:; No significant difference by timing of intervention in the overall sample^67^ or among women without prior hormone therapy use.^110^; [underlined: Post intervention followup: Mean 2.4 years] ^132^; All-cause mortality; 233 (1.20% annualized) vs. 196 (1.06% annualized); HR, 1.15 (95% CI, 0.95 to 1.39); p=0.27; [underlined: Postintervention followup: Median 8.2 years] ^67^; All-cause mortality; 761 (1.39% annualized) vs. 728 (1.39% annualized); HR, 1.01 (95% CI, 0.91 to 1.11); p=0.90; [underlined: Postintervention followup: Median 12.5 years] ^88^; All-cause mortality; 1,994 (2.15% annualized) vs. 1,872 (2.11% annualized); HR, 1.04 (95% CI, 0.97 to 1.10); p=0.28; Subgroups:; No significant difference by age group.; [underlined: Cumulative followup: Median 13.2 years] ^67^; All-cause mortality; 1,011 (0.98% annualized) vs. 966 (0.99% annualized); HR, 0.99 (95% CI, 0.91 to 1.08); p=0.87; Subgroups:; No significant difference by age.; [underlined: Cumulative followup: Median 17.7 years] ^88^; All-cause mortality; 2,244 (1.58% annualized) vs. 2,110 (1.57% annualized); HR, 1.02 (95% CI, 0.96 to 1.08); p=0.51; Subgroups:; No significant difference by age group.; [underlined: Cumulative followup: Median 18.0 years] ^91^; All-cause mortality; Subgroups:; No significant difference by age group.; [underlined: Cumulative followup: Median 19.4 years] ^101^; All-cause mortality; 2,802 (32.9% calculated) vs. 2,638 (32.6% calculated); HR, 1.02 (95% CI, 0.97 to 1.08); p=NR

* Intervention dosages are listed in Table 3 by trial.

Abbreviations: BSO=bilateral salpingo-oophorectomy; CI=confidence interval; ELITE=Early vs. Late Intervention Trial with Estradiol; ERA=Estrogen Replacement and Atherosclerosis Trial; HERS=Heart and Estrogen/Progestin Replacement Study; HR=hazard ratio; HT=hormone therapy; NR=not reported; STOP-IT=Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; vs.=versus; WAVE=Women’s Angiographic Vitamin and Estrogen Trial; WHI=Women’s Health Initiative.