# Appendix E Quality Rating Tables

Appendix E Table 1 Quality Ratings of Randomized, Controlled Trials

Trial | Randomization adequate? | Allocation concealment adequate? | Groups similar at baseline? | Outcome assessors masked? | Care providers masked? | Patient masked? | Loss to followup ≤20% and differential attrition ≤15%? | Intention-to-treat analysis? | Other biases? | Quality Rating
DOPS (Denmark) | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes^*^ | Poor
Clarke 2002 (U.K.) | Unclear | Unclear | Yes | Yes | No | No | No | Yes | No | Poor
ELITE-Cog (U.S.) | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Fair
EMS (Canada) | Yes | Yes | Mostly, except for prior HT use and amnestic mild cognitive impairment | Yes | Yes | Yes | Yes | Unclear | No | Fair
EPAT (U.S.) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes^†^ | Fair
EPHT (Estonia) | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | No | Fair
ERA (U.S.) | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | Yes^‡^ | Fair
Greenspan 2005 (U.S.) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Good
Notelovitz 2002 (U.S.) | Unclear | Unclear | Yes | Yes | Yes | Yes | No | No | Yes^§^ | Poor
HERS (U.S.) | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Good
KEEPS-Cog (U.S.) | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Fair
KEEPS-MRI (U.S.) – global cognition score | Yes | Yes | Yes | Yes | Yes | Yes | No | Unclear | Yes | Poor
KEEPS-MRI (U.S.) – global cognitive function | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Fair
Pefanco 2007 (U.S.) | Yes | Unclear | Yes | Yes | Unclear | Yes | No | No | No | Poor
PEPI (U.S.) | Yes | Unclear | Unclear | Yes | Unclear | Yes | Unclear | No | Yes^‖^ | Fair
STOP-IT (U.S.) | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | No | Fair
Bumbu 2016 (Romania) | Unclear | Unclear | Unclear | Unclear | Unclear | No | Yes | Unclear | Unclear | Poor
ULTRA (U.S.) | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | No | Good
WAVE (U.S., Canada) | Yes | Unclear | Yes | Yes | Yes | Yes | No | Unclear | No | Fair
WHI (U.S.) | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Fair
WHI (U.S.) – breast cancer | Yes | Yes | Yes | Unclear | Yes | No | Yes | Yes | No | Fair
WHI (U.S.) – breast cancer, CHD, stroke, hip fracture, non-Hodgkin’s lymphoma | Yes | Yes | Yes | Unclear | Unclear | Unclear | Unclear | Yes | No | Fair
WHI (U.S.) – fractures | Yes | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | No | Fair
WHI (U.S.) – lung cancer | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | Yes | No | Fair
WHI (U.S.) – stroke, VTE, mortality, breast cancer, CHD | Yes | Yes | Yes | Unclear | Unclear | Unclear | No | Yes | No | Fair
WHI (U.S.) – mortality | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | No | Good
WHI (U.S.) – endometrial cancer | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Good
WHIMS (U.S.) | Yes | Yes | Mostly, except for history of stroke and hypertension | Yes | Yes | Yes | Yes | Yes | No | Good
WHIMS-ECHO (U.S.) | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | No | Fair
WHIMSY (U.S.) | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Fair
WHISCA (U.S.) | Yes | Yes | Mostly, except for smoking status | Yes | Yes | Yes | Yes | Yes | No | Good
WISDOM (U.K., Australia, New Zealand) | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | No | Fair

* High risk of selection bias and contamination. Invited participants chose whether to be part of randomized trial (those who preferred a treatment option were followed in the cohort study). Among those who were randomized to no HT and attended the 5-year followup, 15% had initiated HT. Among those randomized to HT, 18% had changed the type of HT and 22% had stopped HT at 5 years.

† Although the trial conducted an ITT analysis, it was only for evaluable patients (199/222) from the larger set of randomized patients.

‡ There was a statistically significant difference between placebo and CEE in adherence.

§ Risk of measurement bias. Some outcomes (e.g., breast cancer) were assessed as adverse events; ascertainment of these outcomes is unclear. Although mammograms were performed as part of the study protocol, cases of breast cancer appear to have been self-reported. Some were assessed to be benign; methods of determining cancer severity were not described.

‖ Potential risk of contamination and low adherence to assigned study medications. Study authors noted that in women assigned to CEE, continuation rate was lowest and potentially due to endometrial hyperplasia. Some women were also initiated on another hormone regimen (other than the one assigned at randomization); this included up to 18% in some study arms.

Abbreviations: CEE=conjugated equine estrogen; CHD=coronary heart disease; DOPS=Danish Osteoporosis Prevention Trial; ELITE=Early versus Late Intervention Trial with Estradiol; EMS=Estrogen Memory Study; EPAT=Estrogen in the Prevention of Atherosclerosis; EPHT=Estonian Postmenopausal Hormone Therapy Trial; ERA=Effects of Estrogen Replacement on the Progression of Coronary-Artery Atherosclerosis; HERS=Heart and Estrogen/Progestin Replacement Study; HRT=hormone replacement therapy; HT=hormone therapy; ITT=intention to treat; KEEPS=Kronos Early Estrogen Prevention Study; KEEPS-MRI=Kronos Early Estrogen Prevention Study-MRI; PEPI=Postmenopausal Estrogen and Progestin Interventions Trial; STOP-IT=Trial of Short-Course Antimicrobial Therapy for Intraabdominal Infection; ULTRA=Ultra-Low-Dose Transdermal Estrogen Assessment; VTE=venous thromboembolism; WAVE=Women’s Angiographic Vitamin and Estrogen Trial; WHI=Women’s Health Initiative; WHIMS=Women’s Health Initiative Memory Study; WHIMS-ECHO=Women’s Health Initiative Memory Study of the Epidemiology of Cognitive Health Outcomes; WHIMSY=Women’s Health Initiative Memory Study of Younger Women; WHISCA=Women’s Health Initiative Study of Cognitive Aging; WISDOM=Women’s International Study of Long Duration Oestrogen After Menopause.

Appendix E Table 2 Quality Ratings of Observational Studies

Reference | Potential for confounding? | Bias due to confounding | | | Bias in selection of participants into the study | | | Bias in classification of interventions
Reference | Potential for confounding? | Appropriate analysis method to control for all the important confounding domains? | Confounding domains measured reliably? | Risk of bias | Selection based on participants characteristics observed after the start of the intervention? | Most participants followed from the start of the intervention? | Risk of bias | Intervention groups clearly defined? | Risk of bias
Morch, 2016^102^ | Probably yes | Probably yes | Probably yes | Moderate | No | Yes | Low | Yes | Low
Bethea, 2017^104^ | Probably yes | Probably yes | Probably yes | Moderate | No | Probably yes | Low | Probably yes | Moderate
Park, 2016^103^ | Probably yes | Probably yes | Probably yes | Moderate | No | Probably no | Moderate | Probably yes | Moderate
Perez, 2012^81^ | No | No | No information | Low | No | Probably no | Moderate | Yes | Low

Bias due to deviations from intended interventions | | | | Bias due to missing data
Deviations from intended interventions? | Deviations unbalanced between groups? | Co-interventions balanced across intervention groups? | Risk of bias | Outcome data available for nearly all participants? | Participants excluded due to missing data? | Proportions of participants and reasons for missing data similar across interventions? | Results robust? | Risk of bias
No | Probably no | Probably yes | Low | Yes | Probably no | Probably yes | Yes | Low
No | No | Probably yes | Low | Yes | Probably no | Probably yes | Probably yes | Low
No | No | Probably yes | Low | Yes | Yes | Probably yes | Yes | Low
No information | No information | No information | No information | Probably yes | Probably no | Probably yes | Probably yes | Low

Bias in measurement of outcomes | | | | | Bias in selection of the reported result | | Overall risk of bias
Could the outcome measure have been influenced by knowledge of the intervention received? | Were outcome assessors aware of the intervention received by study participants? | Were the methods of outcome assessment comparable across intervention groups? | Risk of Bias | Results likely to be selected from multiple measurements? | Results likely to be selected from different subgroups? | Risk of bias | Overall risk of bias
No | No | Yes | Low | Probably no | Probably no | Low | Moderate risk of bias
No | No | Yes | Low | Probably no | Probably no | Low | Moderate risk of bias
No | No | Yes | Low | Probably no | Probably no | Low | Moderate risk of bias
Probably no | No | Probably no | Low | Probably no | Probably no | Low | Serious risk of bias