# Appendix D Excluded Studies

Exclusion Legend:

- X1: Not original research
- X2: Ineligible population
- X3: Ineligible intervention
- X4: Intervention duration less than 1 year
- X5: Outcomes not relevant to prevention of chronic conditions
- X6: Ineligible comparator or no comparator
- X7: Ineligible study design
- X8: Systematic review with eligibility criteria that does not meet criteria for this review
- X9: Ineligible setting
- X10: Non-English full text
- X11: Ineligible publication type
- X12: Poor quality
- X13: Duplicate
- X14: Systematic review for hand search

1 A 17β-estradiol-progesterone oral capsule for vasomotor symptoms in postmenopausal women: a randomized controlled trial: correction. Obstet Gynecol. 2018 Sep;132(3):786. doi: 10.1097/aog.0000000000002859. PMID: 30134411. Exclusion Code: X1.30134411
2 Hormone therapy during peri- and postmenopause. Deutsche medizinische Wochenschrift (1946). 2018;143(22):1636–47. doi: 10.1055/a-0441-4540. PMID: CN-01932256. Exclusion Code: X10.30376687
3 2017 - Pooled RCTs: in postmenopausal women, hormone therapy for 6 to 7 years did not affect mortality at 18 years. ACP J Club. 2018;168(2):1-. PMID: CN-02113784. Exclusion Code: X11.
4 Hormone therapy effective in preventing depressive symptoms in menopause transition. Brown University psychopharmacology update. 2018;29(5):1–2. doi: 10.1002/pu.30318. PMID: CN-02198431. Exclusion Code: X1.
5 A 17β-estradiol-progesterone oral capsule for vasomotor symptoms in postmenopausal women: a randomized controlled trial. Obstet Gynecol Surv. 2018;73(11):630–2. doi: 10.1097/01.ogx.0000549834.30469.f2. PMID: CN-01925338. Exclusion Code: X1.
6 Erratum: a 17Î²-estradiol-progesterone oral capsule for vasomotor symptoms in postmenopausal women: a randomized controlled trial: correction (Obstetrics and Gynecology (2018) 132 1 (161-170)). Obstet Gynecol. 2018;132(3):786-. doi: 10.1097/AOG.0000000000002859. PMID: CN-02002256. Exclusion Code: X11.
7 The bioavailability of TX-001hr (estradiol and micronized progesterone capsules): effect of food and varying dosing profiles. Endocr Rev. 2018; Conference: 100th Annual Meeting of the Endocrine Society, ENDO 2018. United States. 39(2 Supplement 1). PMID: CN-01920886. Exclusion Code: X11.
8 Prior menopausal hormone treatments and association of peripheral markers of neurovascular unit integrity and beta-amyloid in the brains of menopausal women. FASEB J. 2018; Conference: Experimental Biology 2018, EB. United States. 32(1 Supplement 1)PMID: CN-01920438. Exclusion Code: X5.
9 Estradiol/progesterone (Bijuva) for menopausal vasomotor symptoms. Med Lett Drugs Ther. 2019 Jul 1;61(1575):99–101. PMID: 31381541. Exclusion Code: X1.31381541
10 Menopausal hormone therapy and risks of first hospitalized heart failure and its subtypes during the intervention and extended postintervention follow-up of the Women’s Health Initiative randomized trials. J Card Fail. 2019. doi: 10.1016/j.cardfail.2019.09.006. PMID: CN-02011210. Exclusion Code: X13.
11 Estrogen-based hormone replacement [HRT] therapy is substantially more effective than tamoxifen in reducing breast cancer mortality and breast cancer case fatality ratio: emergence of a new paradigm. Cancer Res. 2019;79(4)doi: 10.1158/1538-7445.SABCS18-P6-13-06. PMID: CN-02081180. Exclusion Code: X6.
12 The effect of estroprogestagen therapy on lipid status in menopause depending on the drug administration route. Vojnosanit Pregl. 2020;77(4):418–25. doi: 10.2298/VSP170318080C. PMID: CN-02164698. Exclusion Code: X5.
13 Abdi F, Mobedi H, Bayat F, . The Effects of transdermal estrogen delivery on bone mineral density in postmenopausal women: a meta-analysis. Iran J Pharm Res. 2017 Winter;16(1):380–9. PMID: 28496491. Exclusion Code: X8.28496491
14 Abdi F, Mobedi H, Mosaffa N, . Hormone therapy for relieving postmenopausal vasomotor symptoms: a systematic review. Arch Iran Med. 2016 Feb;19(2):141–6. PMID: 26838086. Exclusion Code: X5.26838086
15 Ahmed I, Bano F. Hormone replacement therapy (HRT) after hysterectomy? BJOG. 2019;126:183-. doi: 10.1111/1471-0528.13_15703. PMID: CN-01960522. Exclusion Code: X11.
16 Alyono J, Qin F, Hedlin H, . Effects of menopausal hormone therapy on hearing loss. Otolaryngology - Head and Neck Surgery (United States). 2017;157(1):P243. doi: 10.1177/0194599817717250. Exclusion Code: X11.
17 Anonymous. Erratum: a 17beta-estradiol-progesterone oral capsule for vasomotor symptoms in postmenopausal women: a randomized controlled trial: correction (Obstetrics and Gynecology (2018) 132 1 (161-170)). Obstet Gynecol. 2018;132(3):786RCT. PMID: CN-02072353. Exclusion Code: X11.
18 Archer D, Pickar J, Graham S, . Effects of single-capsule 17β-estradiol/progesterone (TX-001HR) on weight and blood pressure in menopausal women of the replenish trial. Menopause. 2018;25(12):1496–7. doi: 10.1097/GME.0000000000001251. Exclusion Code: X11.
19 Archer D, Pickar J, Graham S, . Effects of single-capsule 17beta-estradiol/progesterone (TX-001HR) on weight and blood pressure in menopausal women of the replenish trial. Menopause. Conference: 29th Annual Meeting of the North American Menopause Society. United States. 2018;25(12):1496–7. PMID: CN-01911188. Exclusion Code: X11.
20 Archer DF, Bernick BA, Mirkin S. A combined, bioidentical, oral, 17Î²-estradiol and progesterone capsule for the treatment of moderate to severe vasomotor symptoms due to menopause. Expert Rev Clin Pharmacol. 2019;12(8):729–39. doi: 10.1080/17512433.2019.1637731. PMID: CN-01989692. Exclusion Code: X13.31282768
21 Archer DF, Bernick BA, Mirkin S. A combined, bioidentical, oral, 17beta-estradiol and progesterone capsule for the treatment of moderate to severe vasomotor symptoms due to menopause. Expert Rev Clin Pharmacol. 2019;12(8):729–39. doi: 10.1080/17512433.2019.1637731. PMID: CN-01968598. Exclusion Code: X5.31282768
22 Archer DF, Graham S, Gasper G, . Replenish trial: combination capsule of estradiol/progesterone (TX-001HR) for treating hot flushes. Obstet Gynecol. 2017;129:133S–4S. Exclusion Code: X11.
23 Archer DF, Lobo RA, Kagan R, . Replenish trial: endometrial safety with a 173-estradiol and progesterone combination (TX-001HR) in postmenopausal women with vasomotor symptoms. Endocr Rev. 2017;38(3). Exclusion Code: X11.
24 Archer DF, Pickar JH, Graham R, . Incidence of abnormal mammograms with oral, combined 17β-estradiol and progesterone capsules. Endocr Rev. 2018;39(2). Exclusion Code: X11.
25 Armstrong NM, Espeland MA, Chen JC, . Associations of hearing loss and menopausal hormone therapy with change in global cognition and incident cognitive impairment among postmenopausal women. J Gerontol A Biol Sci Med Sci. 2020 Feb 14;75(3):537–44. doi: 10.1093/gerona/glz173. PMID: 31326978. Exclusion Code: X7.31326978
26 Asi N, Mohammed K, Haydour Q, . Progesterone vs. synthetic progestins and the risk of breast cancer: a systematic review and meta-analysis. Syst Rev. 2016 Jul 26;5(1):121. doi: 10.1186/s13643-016-0294-5. PMID: 27456847. Exclusion Code: X8.27456847
27 Barnes JN, Harvey RE, Eisenmann NA, . Cerebrovascular reactivity after cessation of menopausal hormone treatment. Climacteric. 2019 Apr;22(2):182–9. doi: 10.1080/13697137.2018.1538340. PMID: 30661405. Exclusion Code: X5.30661405
28 Bezwada P, Shaikh A, Misra D. The effect of transdermal estrogen patch use on cardiovascular outcomes: a systematic review. J Womens Health (Larchmt). 2017 Dec;26(12):1319–25. doi: 10.1089/jwh.2016.6151. PMID: 28622476. Exclusion Code: X8.28622476
29 Black DR, Minkin MJ, Graham S, . Effects of combined 17β-estradiol and progesterone on weight and blood pressure in postmenopausal women of the REPLENISH trial. Menopause. 2020 Sep 14;28(1):32–9. doi: 10.1097/gme.0000000000001659. PMID: 32932401. Exclusion Code: X5.32932401
30 Black DR, Minkin MJ, Graham S, . Effects of combined 17β-estradiol and progesterone on weight and blood pressure in postmenopausal women of the REPLENISH trial. Menopause. 2021;28(1):32–9. doi: 10.1097/GME.0000000000001659. Exclusion Code: X13.
31 Blondon M, Timmons AK, Baraff AJ, . Comparative venous thromboembolic safety of oral and transdermal postmenopausal hormone therapies among women Veterans. Menopause. 2021 Jul 26;28(10):1125–9. doi: 10.1097/gme.0000000000001823. PMID: 34313612. Exclusion Code: X6.34313612
32 Brusselaers N, Tamimi RM, Konings P, . Different menopausal hormone regimens and risk of breast cancer. Ann Oncol. 2018 Aug 1;29(8):1771–6. doi: 10.1093/annonc/mdy212. PMID: 29917061. Exclusion Code: X4.29917061
33 Bumbu A, Bianca P, Tit DM, . The effects of soy isoflavones and hormonal replacing therapy on the incidence and evolution of postmenopausal female urinary incontinence. Farmacia. 2016;64(3):419–22. Exclusion Code: X12.
34 Chang WC, Wang JH, Ding DC. Conjugated equine estrogen used in postmenopausal women associated with a higher risk of stroke than estradiol. Sci Rep. 2021 May 24;11(1):10801. doi: 10.1038/s41598-021-90357-6. PMID: 34031535. Exclusion Code: X6.34031535
35 Chaves JDP, Figueredo TFM, Warnavin SVSC, . Sex hormone replacement therapy in periodontology—A systematic review. Oral Dis. 2020;26(2):270–84. doi: 10.1111/odi.13059. Exclusion Code: X8.30739380
36 Chen PJ, Chung CH, Chien WC, . Hormone therapy is not associated with the risk of sudden sensorineural hearing loss in postmenopausal women: a 10-year nationwide population-based study. Menopause. 2019 Aug;26(8):892–8. doi: 10.1097/gme.0000000000001323. PMID: 30969183. Exclusion Code: X2.30969183
37 Chen YY, Su TH, Lau HH. Estrogen for the prevention of recurrent urinary tract infections in postmenopausal women: a meta-analysis of randomized controlled trials. Int Urogynecol J. 2021 Jan;32(1):17–25. doi: 10.1007/s00192-020-04397-z. PMID: 32564121. Exclusion Code: X8.32564121
38 Cherry N, Gilmour K, Hannaford P, . Oestrogen therapy for prevention of reinfarction in postmenopausal women: a randomised placebo controlled trial. Lancet. 2002 Dec 21–28;360(9350):2001–8. PMID: 12504395. Exclusion Code: X5.12504395
39 Cherry N, McNamee R, Heagerty A, . Long-term safety of unopposed estrogen used by women surviving myocardial infarction: 14-year follow-up of the ESPRIT randomised controlled trial. BJOG. 2014 May;121(6):700–5; discussion 5. doi: 10.1111/1471-0528.12598. PMID: 24533510. Exclusion Code: X5.24533510
40 Chi CI. Multicenter randomized controlled trial of low-dose hormone replacement therapy for low bone density in early postmenopause females. http://www.who.int/trialsearch/Trial2.aspx?TrialID=ChiCTR-IOR-16008202. 2016 PMID: CN-01853904. Exclusion Code: X5.
41 Chi CI. Prevention and treatment of estrogen therapy on the perimenopausal diseases of multi-center study in China. http://www.who.int/trialsearch/Trial2.aspx?TrialID=ChiCTR-IPR-16008754. 2016 PMID: CN-01808068. Exclusion Code: X9.
42 ChiCtr. Menopausal hormone therapy in patients with CSVD, a double–blind, double-dummy randomized controlled trial. http://www.who.int/trialsearch/Trial2.aspx?TrialID=ChiCTR2100043205. 2021 PMID: CN-02282985. Exclusion Code: X1.
43 Chlebowski RT, Anderson GL, Aragaki AK, . Long-term influence of estrogen plus progestin and estrogen alone use on breast cancer incidence: The women’s health initiative randomized trials. Cancer Res. 2020;80(4)doi: 10.1158/1538-7445.SABCS19-GS5-00. Exclusion Code: X11.
44 Chlebowski RT, Cirillo DJ, Eaton CB, . Estrogen alone and joint symptoms in the Women’s Health Initiative randomized trial. Menopause. 2018 Nov;25(11):1313–20. doi: 10.1097/gme.0000000000001235. PMID: 30358728. Exclusion Code: X5.30358728
45 Choudhary Y, Walji N. Peri-menopausal estrogen could prevent breast cancer; AGAINST. BJOG. 2021 Jul;128(8):1385. doi: 10.1111/1471-0528.16687. PMID: 33822439. Exclusion Code: X1.33822439
46 Cintron D, Beckman J, Muthuvel J, . Differential effects of menopausal hormone formulations on plasma orexin a levels in women of the Kronos early estrogen prevention study. FASEB Journal. Conference: Experimental Biology 2016, EB. San Diego, CA United States. Conference start: 20160402. Conference end: 20160406. Conference publication: (var.pagings). 2016;30(no pagination)PMID: CN-01266421. Exclusion Code: X11.
47 Cintron D, Beckman JP, Bailey KR, . Plasma orexin A levels in recently menopausal women during and 3 years following use of hormone therapy. Maturitas. 2017 May;99:59–65. doi: 10.1016/j.maturitas.2017.01.016. PMID: 28364870. Exclusion Code: X5.28364870
48 Cintron D, Lahr BD, Bailey KR, . Effects of oral versus transdermal menopausal hormone treatments on self-reported sleep domains and their association with vasomotor symptoms in recently menopausal women enrolled in the Kronos Early Estrogen Prevention Study (KEEPS). Menopause. 2018 Feb;25(2):145–53. doi: 10.1097/gme.0000000000000971. PMID: 28832429. Exclusion Code: X5.28832429
49 Collaborative Group on Hormonal Factors in Breast Cancer. Type and timing of menopausal hormone therapy and breast cancer risk: individual participant meta-analysis of the worldwide epidemiological evidence. Lancet. 2019 Sep 28;394(10204):1159–68. doi: 10.1016/s0140-6736(19)31709-x. PMID: 31474332. Exclusion Code: X14.31474332
50 Constantine G, Graham S, Bernick B, . Improvement in postmenopausal sexual dysfunction with TX004HR (vagicap(tm)) AS measured by FSFI. Obstet Gynecol. 2016;127:S12. PMID: CN-01308402. Exclusion Code: X3.
51 Constantine GD, Santoro N, Graham S, . Nonsmokers may benefit from lower doses of an oral 17β-estradiol/progesterone capsule-data from the replenish trial. Menopause. 2019;26(12):1462. doi: 10.1097/GME.0000000000001456. Exclusion Code: X11.
52 Constantine GD, Santoro N, Graham S, . Nonsmokers may benefit from lower doses of an oral 17Î²-estradiol/progesterone capsule-data from the replenish trial. Menopause (New York, N.Y.). 2019;26(12):1462-. doi: 10.1097/GME.0000000000001456. PMID: CN-02095049. Exclusion Code: X11.
53 Coquoz A, Gruetter C, Stute P. Impact of micronized progesterone on body weight, body mass index, and glucose metabolism: a systematic review. Climacteric. 2019 Apr;22(2):148–61. doi: 10.1080/13697137.2018.1514003. PMID: 30477366. Exclusion Code: X8.30477366
54 Crandal CJ, Hovey K, Stefanick M, . Comparison of global index scores among users of oral and transdermal estrogen-containing therapy in the WHI observational study. Menopause. 2016;23(12):1377. doi: 10.1097/GME.0000000000000783. Exclusion Code: X11.
55 Crandall CJ, Hovey KM, Andrews C, . Comparison of clinical outcomes among users of oral and transdermal estrogen therapy in the Women’s Health Initiative Observational Study. Menopause. 2017 Oct;24(10):1145–53. doi: 10.1097/gme.0000000000000899. PMID: 28697036. Exclusion Code: X6.28697036
56 Derzko C, Sergerie M, Siliman G, . Comparative efficacy and safety of estradiol transdermal preparations for the treatment of vasomotor symptoms in postmenopausal women: an indirect comparison meta-analysis. Menopause. 2016 Mar;23(3):294–303. doi: 10.1097/gme.0000000000000552. PMID: 26382309. Exclusion Code: X8.26382309
57 dx RBR. Evaluation of the sexual function and vaginal environment of menopausal women before and after treatment. http://www.who.int/trialsearch/Trial2.aspx?TrialID=RBR-94dx93. 2018 PMID: CN-01906807. Exclusion Code: X5.
58 El Khoudary SR, Venugopal V, Manson JE, . Impact of menopausal hormone therapy on association between heart fat and carotid artery atherosclerosis progression in recently postmenopausal women: the KEEPS trial. Circulation. 2019;139doi: 10.1161/circ.139.suppl_1.P243. Exclusion Code: X11.
59 El Khoudary SR, Venugopal V, Manson JE, . Heart fat and carotid artery atherosclerosis progression in recently menopausal women: impact of menopausal hormone therapy: the KEEPS trial. Menopause. 2020 Mar;27(3):255–62. doi: 10.1097/gme.0000000000001472. PMID: 32015261. Exclusion Code: X5.32015261
60 El Khoudary SR, Zhao Q, Venugopal V, . Effects of hormone therapy on heart fat and coronary artery calcification progression: secondary analysis from the KEEPS Trial. J Am Heart Assoc. 2019 Aug 6;8(15):e012763. doi: 10.1161/jaha.119.012763. PMID: 31652073. Exclusion Code: X5.31652073
61 Elmahdy M, Abdelsalam EA, Maghraby HA. Combining several interventions to reduce the incidence of OHSS: a prospective cohort study. European Journal of Obstetrics Gynecology and Reproductive Biology. 2017;212:110–4. doi: 10.1016/j.ejogrb.2017.03.016. PMID: CN-01367789. Exclusion Code: X2.28351814
62 Espeland MA, Rapp SR, Manson JAE, . Long term effects on cognitive trajectories of early versus late postmenopausal hormone therapy. Alzheimer’s and Dementia. 2016;12(7):P195–P6. Exclusion Code: X13.
63 Espitia-de la Hoz FJ, Orozco-Gallego H. Estriol vs. Conjugated estrogens of equine origin in the treatment of the genitourinary syndrome of menopause. Ginecol Obstet Mex. 2018;86(2):117–26. doi: 10.24245/gom.v86i2.1881. PMID: CN-01464806. Exclusion Code: X10.
64 Euctr FI. Discontinuation of hormone therapy: impact on cardiovascular function, recurrence of vasomotor symptoms and quality of life. http://www.who.int/trialsearch/Trial2.aspx?TrialID=EUCTR2017-000328-85-FI. 2017 PMID: CN-01894215. Exclusion Code: X3.
65 Faubion L, White TA, Peterson BJ, . Effect of menopausal hormone therapy on proteins associated with senescence and inflammation. Physiol Rep. 2020 Aug;8(16):e14535. doi: 10.14814/phy2.14535. PMID: 32857481. Exclusion Code: X5.32857481
66 Fox KA, Lokken EM, Reed SD, . Evaluation of systemic estrogen for preventing urinary tract infections in postmenopausal women. Menopause. 2021 May 10;28(7):836–44. doi: 10.1097/gme.0000000000001769. PMID: 33973539. Exclusion Code: X5.33973539
67 Gartlehner G, Patel SV, Feltner C, . Hormone therapy for the primary prevention of chronic conditions in postmenopausal women: evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2017 Dec 12;318(22):2234–49. doi: 10.1001/jama.2017.16952. PMID: 29234813. Exclusion Code: X8.29234813
68 Gass M, Larson J, Cochrane B, . Sexual activity and vaginal symptoms in the postintervention phase of the Women’s Health Initiative Hormone Therapy Trials. Menopause. 2018 Mar;25(3):252–64. doi: 10.1097/gme.0000000000000994. PMID: 29112594. Exclusion Code: X5.29112594
69 Geiger PJ, Eisenlohr-Moul T, Gordon JL, . Effects of perimenopausal transdermal estradiol on self-reported sleep, independent of its effect on vasomotor symptom bother and depressive symptoms. Menopause. 2019 Nov;26(11):1318–23. doi: 10.1097/gme.0000000000001398. PMID: 31688579. Exclusion Code: X5.31688579
70 Giannella L, Marconi C, Di Giuseppe J, . Malignant transformation of postmenopausal endometriosis: a systematic review of the literature. Cancers (Basel). 2021 Aug 10;13(16)doi: 10.3390/cancers13164026. PMID: 34439184. Exclusion Code: X8.34439184
71 Goldstein SR, Constantine G, Archer DF, . Effects of TX-001HR on uterine bleeding rates in menopausal women with vasomotor symptoms. Menopause. 2017;24(12):1431–2. doi: 10.1097/GME.0000000000000997. Exclusion Code: X11.
72 Gordon JL, Rubinow DR, Eisenlohr-Moul TA, . Antidepressant effects of transdermal estradiol in the menopause transition are moderated by stressful life events. Menopause. 2017;24(12):1433–4. doi: 10.1097/GME.0000000000000997. Exclusion Code: X11.
73 Gordon JL, Rubinow DR, Eisenlohr-Moul TA, . Efficacy of transdermal estradiol and micronized progesterone in the prevention of depressive symptoms in the menopause transition: a randomized clinical trial. JAMA Psychiatry. 2018 Feb 1;75(2):149–57. doi: 10.1001/jamapsychiatry.2017.3998. PMID: 29322164. Exclusion Code: X2.29322164
74 Gordon JL, Rubinow DR, Watkins L, . The effect of perimenopausal transdermal estradiol and micronized progesterone on markers of risk for arterial disease. J Clin Endocrinol Metab. 2020 May 1;105(5):e2050–60. doi: 10.1210/clinem/dgz262. PMID: 31838497. Exclusion Code: X5.31838497
75 Hameed RH. VTE risk in postmenopausal women receiving oral and non-oral hormone therapy systematic review and meta-analysis. Indian Journal of Forensic Medicine and Toxicology. 2019;13(1):302–6. doi: 10.5958/0973-9130.2019.00060.4. Exclusion Code: X8.
76 Harvey RE, Johnson M, Ranadive SM, . Aortic hemodynamics in postmenopausal women following cessation of hormone therapy. J Vasc Res. 2016;53:56. doi: 10.1159/000452122. Exclusion Code: X11.
77 Hellevik AI, Nordsletten L, Johnsen MB, . Age of menarche is associated with knee joint replacement due to primary osteoarthritis (The HUNT Study and the Norwegian Arthroplasty Register). Osteoarthritis Cartilage. 2017 Oct;25(10):1654–62. doi: 10.1016/j.joca.2017.06.010. PMID: 28705605. Exclusion Code: X5.28705605
78 Henderson VW, St John JA, Hodis HN, . Cognitive effects of estradiol after menopause. Neurology. 2016;87(7):699–708. doi: 10.1212/WNL.0000000000002980. Exclusion Code: X13.27421538
79 Hodis HN, Mack WJ, Henderson VW, . Vascular effects of early versus late postmenopausal treatment with estradiol. N Engl J Med. 2016 Mar 31;374(13):1221–31. doi: 10.1056/NEJMoa1505241. PMID: 27028912. Exclusion Code: X2.27028912
80 Honigberg MC, Patel AP, Lahm T, . Association of premature menopause with incident pulmonary hypertension: a cohort study. PLoS One. 2021;16(3):e0247398. doi: 10.1371/journal.pone.0247398. PMID: 33690615. Exclusion Code: X5.33690615
81 Hussain SM, Wang Y, Giles GG, . Female reproductive and hormonal factors and incidence of primary total knee arthroplasty due to osteoarthritis. Arthritis Rheumatol. 2018 Jul;70(7):1022–9. doi: 10.1002/art.40483. PMID: 29513938. Exclusion Code: X5.29513938
82 Hwang S, Kang SW, Han J, . Female reproductive factors and the risk of exudative age-related macular degeneration: a nationwide cohort study. Retina. 2021 Oct 1;41(10):2088–97. doi: 10.1097/iae.0000000000003164. PMID: 33675332. Exclusion Code: X3.33675332
83 Javed AA, Mayhew AJ, Shea AK, . Association between hormone therapy and muscle mass in postmenopausal women: a systematic review and meta-analysis. JAMA Netw Open. 2019 Aug 2;2(8):e1910154. doi: 10.1001/jamanetworkopen.2019.10154. PMID: 31461147. Exclusion Code: X5.31461147
84 Jayachandran M, Lahr BD, Bailey KR, . Menopausal hormone therapy, blood thrombogenicity, and development of white matter hyperintensities in women of the Kronos Early Estrogen Prevention Study. Menopause. 2020 Mar;27(3):305–10. doi: 10.1097/gme.0000000000001465. PMID: 31934946. Exclusion Code: X5.31934946
85 Jayachandran M, Lahr BD, Miller VM, . Impact of menopausal hormone treatments on intravascular cellular activation and development of white matter hyperintensities in healthy postmenopausal women. FASEB J. 2018;32(1). Exclusion Code: X11.
86 Jin X, Lin Z, Liu Y, . Hormone replacement therapy benefits meibomian gland dysfunction in perimenopausal women. Medicine (Baltimore). 2016 Aug;95(31):e4268. doi: 10.1097/md.0000000000004268. PMID: 27495030. Exclusion Code: X5.27495030
87 Johnson BE, Johnson CA. Pooled RCTs: In postmenopausal women, hormone therapy for 6 to 7 years did not affect mortality at 18 years. Ann Intern Med. 2018;168(2):JC4. doi: 10.7326/ACPJC-2018-168-2-004. Exclusion Code: X11.29335716
88 Jung JH, Kim JH, Lee YH, . Serum uric acid levels and hormone replacement therapy type: a retrospective case-control study of postmenopausal women. Annals of the Rheumatic Diseases. Conference: Annual European Congress of Rheumatology, EULAR 2017. Spain. 2017;76(Supplement 2):1037–8. doi: 10.1136/annrheumdis-2017-eular.1950. PMID: CN-01467712. Exclusion Code: X11.
89 Kagan R, Abreu P, Andrews E. Vaginal bleeding/spotting with conjugated estrogens/bazedoxifene, conjugated estrogens/medroxyprogesterone acetate, and placebo. Postgrad Med. 2018 Nov;130(8):687–93. doi: 10.1080/00325481.2018.1520046. PMID: 30280946. Exclusion Code: X5.30280946
90 Kagan R, Constantine G, Kaunitz A, . TX-001HR improved the medical outcomes study-sleep (MOS-Sleep) questionnaire in menopausal women with vasomotor symptoms. Menopause. 2017;24(12):1431. doi: 10.1097/GME.0000000000000997. Exclusion Code: X11.
91 Kagan R, Gillespie J, Yu CR, . Vaginal bleeding/spotting with conjugated estrogens/bazedoxifene (CE/BZA), conjugated estrogens/medroxyprogesterone acetate (CE/MPA), and placebo (PBO). Climacteric. 2016;19:36–7. doi: 10.1080/13697137.2016.1242242. Exclusion Code: X11.
92 Kagan R, McClung MR, Graham S, . Effects of E2/P4 oral capsules on bone turnover in women with vasomotor symptoms. Obstet Gynecol. 2020;135:62S. Exclusion Code: X11.
93 Kantarci K, Lowe VJ, Lesnick TG, . Early postmenopausal transdermal 17beta-estradiol therapy and amyloid-beta deposition. J Alzheimers Dis. 2016;53(2):547–56. doi: 10.3233/JAD-160258. PMID: CN-01178865. Exclusion Code: X5.27163830
94 Kantarci K, Lowe VJ, Lesnick TG, . Early postmenopausal transdermal 17β-estradiol therapy and amyloid-β deposition. J Alzheimers Dis. 2016 May 7;53(2):547–56. doi: 10.3233/jad-160258. PMID: 27163830. Exclusion Code: X5.27163830
95 Kantarci K, Tosakulwong N, Lesnick TG, . Effects of hormone therapy on brain structure: A randomized controlled trial. Neurology. 2016 Aug 30;87(9):887–96. doi: 10.1212/wnl.0000000000002970. PMID: 27473135. Exclusion Code: X5.27473135
96 Kantarci K, Tosakulwong N, Lesnick TG, . Changes in brain structure three years after the end of menopausal hormone therapies in a randomized controlled trial. Alzheimer’s and Dementia. 2017;13(7):P570. Exclusion Code: X11.
97 Kantarci K, Tosakulwong N, Lesnick TG, . Brain structure and cognition 3 years after the end of an early menopausal hormone therapy trial. Neurology. 2018 Apr 17;90(16):e1404–e12. doi: 10.1212/wnl.0000000000005325. PMID: 29661902. Exclusion Code: X12.29661902
98 Kaunitz AM, Bitner D, Constantine GD, . 17beta-estradiol/progesterone in a single, oral, softgel capsule (TX-001HR) significantly increased the number of vasomotor symptom-free days in the REPLENISH trial. Menopause (New York, N.Y.). 2020doi: 10.1097/GME.0000000000001615. PMID: CN-02174504. Exclusion Code: X4.
99 Kaunitz AM, Constantine G, Bernick B, . 17beta-estradiol/progesterone in a single, oral, softgel capsule (TX-001HR) significantly increased the number of symptom-free days in the replenish trial. Menopause. Conference: 29th Annual Meeting of the North American Menopause Society. United states. 2018;25(12):1489. PMID: CN-01911198. Exclusion Code: X11.
100 Kaunitz AM, Kagan R, Graham S, . Oral 17β-estradiol/progesterone (e2/p4) improved sleep outcomes in the replenish trial. Menopause. 2019;26(12):1467. doi: 10.1097/GME.0000000000001456. Exclusion Code: X11.
101 Kaunitz AM, Kagan R, Graham S, . Oral 17Î²-estradiol/progesterone (e2/p4) improved sleep outcomes in the replenish trial. Menopause (New York, N.Y.). 2019;26(12):1467-. doi: 10.1097/GME.0000000000001456. PMID: CN-02095375. Exclusion Code: X11.
102 Khialani D, Vasan S, Cushman M, . Tissue factor pathway inhibitor, activated protein c resistance and risk of venous thrombosis associated with menopausal hormone therapy. Research and Practice in Thrombosis and Haemostasis. 2020;4(SUPPL 1):1170–1. doi: 10.1002/rth2.12393. Exclusion Code: X11.
103 Kim S, Ko Y, Lee HJ, . Menopausal hormone therapy and the risk of breast cancer by histological type and race: a meta-analysis of randomized controlled trials and cohort studies. Breast Cancer Res Treat. 2018 Aug;170(3):667–75. doi: 10.1007/s10549-018-4782-2. PMID: 29713854. Exclusion Code: X14.29713854
104 Kjartansdottir OJ, Sigurdardottir LG, Olafsdottir EJ, . Estrogen-progestin use and breast cancer characteristics in lean and overweight postmenopausal women. Breast Cancer Res Treat. 2017 Jun;163(2):363–73. doi: 10.1007/s10549-017-4171-2. PMID: 28281022. Exclusion Code: X7.28281022
105 Kling JM, Dowling NM, Bimonte-Nelson HA, . Impact of menopausal hormone formulations on pituitary-ovarian regulatory feedback. Am J Physiol Regul Integr Comp Physiol. 2019 Dec 1;317(6):R912–r20. doi: 10.1152/ajpregu.00234.2019. PMID: 31663769. Exclusion Code: X5.31663769
106 Kling JM, Miller VM, Tosakulwong N, . Associations of pituitary-ovarian hormones and white matter hyperintensities in recently menopausal women using hormone therapy. Menopause. 2020 Aug;27(8):872–8. doi: 10.1097/gme.0000000000001557. PMID: 32520900. Exclusion Code: X5.32520900
107 Kling JM, Miller VM, Tosakulwong N, . Associations of pituitary-ovarian hormones and brain structure in recently menopausal women using hormone therapy. Alzheimer’s and Dementia. 2019;15(7):P1188. doi: 10.1016/j.jalz.2019.06.3594. Exclusion Code: X11.
108 Kotecha PT, Godsland IF, Crook D, . Effects of tibolone or continuous combined oestradiol and norethisterone acetate on lipids, high-density lipoprotein subfractions and apolipoproteins in postmenopausal women in a two-year, randomized, double-blind, placebo-controlled trial. Clin Endocrinol (Oxf). 2020 Apr;92(4):303–11. doi: 10.1111/cen.14155. PMID: 31925799. Exclusion Code: X5.31925799
109 Lee JH, Choo SP, Park Y, . Clinical impact of hormone replacement therapy on lone atrial fibrillation in postmenopausal women: a nationwide cohort study. Fertil Steril. 2021;116(3):e359. doi: 10.1016/j.fertnstert.2021.07.962. Exclusion Code: X11.
110 Li W, Lin X, Wang R, . Hormone therapy and lung cancer mortality in women: Systematic review and meta-analysis. Steroids. 2017 Feb;118:47–54. doi: 10.1016/j.steroids.2016.12.005. PMID: 27964943. Exclusion Code: X2.27964943
111 Lieberman A, Curtis L. In defense of progesterone: a review of the literature. Altern Ther Health Med. 2017 Nov;23(6):24–32. PMID: 29055286. Exclusion Code: X8.29055286
112 Lin SY, Hung MC, Chang SF, . Efficacy and safety of postmenopausal osteoporosis treatments: a systematic review and network meta-analysis of randomized controlled trials. J Clin Med. 2021 Jul 8;10(14)doi: 10.3390/jcm10143043. PMID: 34300210. Exclusion Code: X5.34300210
113 Lindberg E, Bonsignore MR, Polo-Kantola P. Role of menopause and hormone replacement therapy in sleep-disordered breathing. Sleep Med Rev. 2020 Feb;49:101225. doi: 10.1016/j.smrv.2019.101225. PMID: 31739179. Exclusion Code: X5.31739179
114 Liu JH, Black DR, Larkin L, . Breast effects of oral, combined 17β-estradiol, and progesterone capsules in menopausal women: a randomized controlled trial. Menopause. 2020 Dec;27(12):1388–95. doi: 10.1097/gme.0000000000001631. PMID: 32842052. Exclusion Code: X5.32842052
115 Liu JY, Chen TJ, Hwang SJ. The risk of breast cancer in women using menopausal hormone replacement therapy in Taiwan. Int J Environ Res Public Health. 2016 May 11;13(5)doi: 10.3390/ijerph13050482. PMID: 27187426. Exclusion Code: X9.27187426
116 Liu Y, Ma L, Yang X, . Menopausal hormone replacement therapy and the risk of ovarian cancer: a meta-analysis. Front Endocrinol (Lausanne). 2019;10:801. doi: 10.3389/fendo.2019.00801. PMID: 31849838. Exclusion Code: X14.31849838
117 Lobo R, Liu J, Kaunitz AM, . Effects of single-capsule 17β-estradiol/progesterone (TX-001HR) on metabolic parameters and cardiovascular outcomes in menopausal women of the replenish trial. Menopause. 2018;25(12):1484–5. doi: 10.1097/GME.0000000000001251. Exclusion Code: X11.
118 Lobo R, Liu J, Kaunitz AM, . Effects of single-capsule 17beta-estradiol/progesterone (TX-001HR) on metabolic parameters and cardiovascular outcomes in menopausal women of the replenish trial. Menopause. Conference: 29th Annual Meeting of the North American Menopause Society. United States. 2018;25(12):1484–5. PMID: CN-01911201. Exclusion Code: X11.
119 Lobo RA, Archer DF, Constantine G, . 17b-estradiol/progesterone in a single oral softgel capsule (TX-001HR) significantly reduced moderate-to-severe vasomotor symptoms without endometrial hyperplasia. Menopause. 2017;24(12):1430–1. doi: 10.1097/GME.0000000000000997. Exclusion Code: X11.
120 Lobo RA, Archer DF, Kagan R, . A 17β-estradiol-progesterone oral capsule for vasomotor symptoms in postmenopausal women: a randomized controlled trial. Obstet Gynecol. 2018 Jul;132(1):161–70. doi: 10.1097/aog.0000000000002645. PMID: 29889748. Exclusion Code: X5.29889748
121 Lobo RA, Archer DF, Kagan R, . A 17beta-estradiol-progesterone oral capsule for vasomotor symptoms in postmenopausal women a randomized controlled trial. Obstet Gynecol. 2018;132(1):161–70. doi: 10.1097/AOG.0000000000002645. PMID: CN-01984815. Exclusion Code: X13.29889748
122 Lobo RA, de Moura KFQ. The use of hormone therapy after surgery for endometriosis: an analysis. Journal of Endometriosis. 2016;8(4):152–6. doi: 10.5301/je.5000256. Exclusion Code: X8.
123 Lobo RA, Kaunitz AM, Santoro N, . Metabolic and cardiovascular effects of TX-001HR in menopausal women with vasomotor symptoms. Climacteric. 2019 Dec;22(6):610–6. doi: 10.1080/13697137.2019.1640197. PMID: 31364889. Exclusion Code: X5.31364889
124 Lobo RA, Liu J, Stanczyk FZ, . Estradiol and progesterone bioavailability for moderate to severe vasomotor symptom treatment and endometrial protection with the continuous-combined regimen of TX-001HR (oral estradiol and progesterone capsules). Menopause. 2019 Jul;26(7):720–7. doi: 10.1097/gme.0000000000001306. PMID: 30694918. Exclusion Code: X5.30694918
125 Lorentzon M, Johansson H, Harvey NC, . Hormone therapy decreases the risk of fracture both in fallers and nonfallers - Data from the combined women’s health initiative hormone therapy trials. J Bone Miner Res. 2019;34:359. Exclusion Code: X11.
126 Lorentzon M, Johansson H, Harvey NC, . Hormone therapy reduces the risk of fracture in fallers and in non-fallers: Results from the women’s health initiative hormone therapy trials. Osteoporos Int. 2019;30(SUPPL 2):S163. doi: 10.1007/s00198-019-04990-z. Exclusion Code: X11.
127 Manson JE, Aragaki AK, Bassuk SS, . Menopausal estrogen-alone therapy and health outcomes in women with and without bilateral oophorectomy. Ann Intern Med. 2019;171(6):406–14. doi: 10.7326/M19-0274. Exclusion Code: X13.31499528
128 Manson JE, Bassuk SS, Kaunitz AM, . The Women’s Health Initiative trials of menopausal hormone therapy: lessons learned. Menopause. 2020 Aug;27(8):918–28. doi: 10.1097/gme.0000000000001553. PMID: 32345788. Exclusion Code: X1.32345788
129 Marjoribanks J, Farquhar C, Roberts H, . Long-term hormone therapy for perimenopausal and postmenopausal women. Cochrane Database Syst Rev. 2017 Jan 17;1(1):Cd004143. doi: 10.1002/14651858.CD004143.pub5. PMID: 28093732. Exclusion Code: X14.28093732
130 Marjoribanks J, Farquhar C, Roberts H, . Long-term hormone therapy for perimenopausal and postmenopausal women. Cochrane Database Syst Rev. 2017(1)doi: 10.1002/14651858.CD004143.pub5. PMID: CD004143. Exclusion Code: X13.
131 Marko KI, Simon JA. Clinical trials in menopause. Menopause. 2018 Feb;25(2):217–30. doi: 10.1097/gme.0000000000000978. PMID: 28953214. Exclusion Code: X7.28953214
132 Mauvais-Jarvis F, Manson JE, Stevenson JC, . Menopausal hormone therapy and type 2 diabetes prevention: evidence, mechanisms, and clinical implications. Endocr Rev. 2017 Jun 1;38(3):173–88. doi: 10.1210/er.2016-1146. PMID: 28323934. Exclusion Code: X7.28323934
133 McCarthy CE, Field JK, Marcus MW. Age at menopause and hormone replacement therapy as risk factors for head and neck and oesophageal cancer (Review). Oncol Rep. 2017 Oct;38(4):1915–22. doi: 10.3892/or.2017.5867. PMID: 28765919. Exclusion Code: X8.28765919
134 Mehedintu C, Plotogea M, Pituru S, . Quality of life and psychosomatic symptoms of menopause-national multicenter study. Climacteric. Conference: 15th World Congress on Menopause. Czech Republic. 2016;19:108. doi: 10.1080/13697137.2016.1242242. PMID: CN-01406201. Exclusion Code: X11.
135 Miller VM, Hodis HN, Lahr BD, . Changes in carotid artery intima-media thickness 3 years after cessation of menopausal hormone therapy: follow-up from the Kronos Early Estrogen Prevention Study. Menopause. 2019 Jan;26(1):24–31. doi: 10.1097/gme.0000000000001167. PMID: 30020254. Exclusion Code: X5.30020254
136 Miller VM, Jenkins GD, Biernacka JM, . Pharmacogenomics of estrogens on changes in carotid artery intima-medial thickness and coronary arterial calcification: Kronos Early Estrogen Prevention Study. Physiol Genomics. 2016 Jan;48(1):33–41. doi: 10.1152/physiolgenomics.00029.2015. PMID: 26508701. Exclusion Code: X5.26508701
137 Miller VM, Lahr BD, Bailey KR, . Longitudinal effects of menopausal hormone treatments on platelet characteristics and cell-derived microvesicles. Platelets. 2016;27(1):32–42. doi: 10.3109/09537104.2015.1023273. PMID: 25856160. Exclusion Code: X5.25856160
138 Miller VM, Naftolin F, Asthana S, . The Kronos Early Estrogen Prevention Study (KEEPS): what have we learned? Menopause. 2019 Sep;26(9):1071–84. doi: 10.1097/gme.0000000000001326. PMID: 31453973. Exclusion Code: X5.31453973
139 Mirkin S, Goldstein SR, Archer DF, . Endometrial safety and bleeding profile of a 17β-estradiol/progesterone oral softgel capsule (TX-001HR). Menopause. 2020 Apr;27(4):410–7. doi: 10.1097/gme.0000000000001480. PMID: 31913228. Exclusion Code: X5.31913228
140 Mirkin S, Goldstein SR, Archer DF, . Endometrial safety and bleeding profile of a 17Î²-estradiol/progesterone oral softgel capsule (TX-001HR). Menopause (New York, N.Y.). 2020. doi: 10.1097/GME.0000000000001480. PMID: CN-02073214. Exclusion Code: X5.
141 Mirkin S, Graham S, Constantine G, . REPLENISH trial: Endometrial protection with a 17β-estradiol and progesterone combination (TX-001HR) in postmenopausal women with vasomotor symptoms. Maturitas. 2017;100:130. doi: 10.1016/j.maturitas.2017.03.282. Exclusion Code: X11.
142 Mittal N, Chitongo P, Supramaniam PR, . A randomised controlled trial assessing the effect of micronised progesterone versus medroxyprogesterone acetate on the coagulation cascade of women with premature ovarian insufficiency. Human reproduction. Conference: 35th annual meeting of the European society of human reproduction and embryology. ESHRE. Vienna, Austria. 2019;34 Suppl 1 PMID: CN-02072304. Exclusion Code: X4.
143 Moyer AM, de Andrade M, Weinshilboum RM, . Influence of SULT1A1 genetic variation on age at menopause, estrogen levels, and response to hormone therapy in recently postmenopausal white women. Menopause. 2016 Aug;23(8):863–9. doi: 10.1097/gme.0000000000000648. PMID: 27300114. Exclusion Code: X5.27300114
144 Nakhostin L, Stadler A, Stute P. Impact of menopausal hormone therapy on colorectal cancer risk-A systematic review. Clin Endocrinol (Oxf). 2021 Sep;95(3):390–7. doi: 10.1111/cen.14469. PMID: 33752259. Exclusion Code: X8.33752259
145 Nct. Efficacy Study of Progesterone Tablet in Post-menopausal Women. https://clinicaltrials.gov/show/NCT02841137. 2016 PMID: CN-01506977. Exclusion Code: X11.
146 Nct. Effects of Hormone Replacement Therapy on Arthralgia in Postmenopausal Women. https://clinicaltrials.gov/show/NCT02838576. 2016 PMID: CN-01506928. Exclusion Code: X11.
147 Nct. E4Relief (Response to Estetrol in Life Improvement for MEnopausal-associated Hot Flushes). https://clinicaltrials.gov/show/NCT02834312. 2016 PMID: CN-01506833. Exclusion Code: X3.
148 Nct. Estrogen Diastolic Heart Failure. https://clinicaltrials.gov/show/NCT02693002. 2016 PMID: CN-01556092. Exclusion Code: X4.
149 Nct. The Anabolic Effects of Estrogen on Skeletal Muscles. https://clinicaltrials.gov/show/NCT03020953. 2017 PMID: CN-01561266. Exclusion Code: X4.
150 Nct. Estrogen and the Urogenital Microbiome in GSM. https://clinicaltrials.gov/show/NCT03336437. 2017 PMID: CN-01577655. Exclusion Code: X3.
151 Nct. Study of Progesterone in Treatment of Vasomotor Symptoms. https://clinicaltrials.gov/show/NCT03202186. 2017 PMID: CN-01495306. Exclusion Code: X4.
152 Nct. The Benefits and Risks of Different Menopausal Hormone Replacement Therapy Regimes in the Treatment of Menopause Syndrome. https://clinicaltrials.gov/show/NCT03436303. 2018 PMID: CN-01523065. Exclusion Code: X6.
153 Nct. The Kronos Early Estrogen Prevention Study (KEEPS). https://clinicaltrials.gov/show/NCT03718494. 2018 PMID: CN-01664416. Exclusion Code: X11.
154 Nct. Effect of Menopause Relief EP-40 in Women With Menopausal Symptoms. https://clinicaltrials.gov/show/NCT03461380. 2018 PMID: CN-01483854. Exclusion Code: X3.
155 Nct. Effects of RP101 in Post-menopausal Women With Dry Eye Syndrome. https://clinicaltrials.gov/show/NCT03821415. 2019 PMID: CN-01796131. Exclusion Code: X3.
156 Nct. Advancing Postmenopausal Preventive Therapy. https://clinicaltrials.gov/show/NCT04103476. 2019 PMID: CN-01984744. Exclusion Code: X11.
157 Nct. Discontinuation of Postmenopausal Hormone Therapy: impact on the Cardiovascular System and Quality of Life. https://clinicaltrials.gov/show/NCT04050592. 2019 PMID: CN-01966288. Exclusion Code: X11.
158 Nct. Oophorectomy, Estrogen Therapy and Cardiovascular Disease Risk in Young Women. https://clinicaltrials.gov/show/NCT03815929. 2019 PMID: CN-01796048. Exclusion Code: X2.
159 Nct. Pilot Study of Effects of Duavee® on Imaging and Blood Biomarkers In Women With Menopausal Symptoms. https://clinicaltrials.gov/show/NCT04379024. 2020 PMID: CN-02103799. Exclusion Code: X11.
160 Nct. Effects of Hormone Replacement Therapy on Cardiovascular Risk and Body Composition Parameters. https://clinicaltrials.gov/show/NCT04453332. 2020 PMID: CN-02134048. Exclusion Code: X4.
161 Nct. Impact of Estradiol on Endothelial Function in Peri-Menopausal Women. https://clinicaltrials.gov/show/NCT04255160. 2020 PMID: CN-02080073. Exclusion Code: X4.
162 Nudy M, Chinchilli VM, Foy AJ. A systematic review and meta-regression analysis to examine the ‘timing hypothesis’ of hormone replacement therapy on mortality, coronary heart disease, and stroke. Int J Cardiol Heart Vasc. 2019 Mar;22:123–31. doi: 10.1016/j.ijcha.2019.01.001. PMID: 30705938. Exclusion Code: X14.30705938
163 Nyrønning LÅ, Videm V, Romundstad PR, . Impact of sex hormones, postmenopausal hormone therapy and risk factors on development of abdominal aortic aneurysm in women: a population-based prospective study in Norway: a hunt study. Eur J Vasc Endovasc Surg. 2019;58(6):e219. doi: 10.1016/j.ejvs.2019.06.794. Exclusion Code: X11.
164 Ober BA, Shenaut GK, Taylor SL. Effects of hormone therapy on list and story recall in post-menopausal women. Exp Aging Res. 2019 May–Jun;45(3):199–222. doi: 10.1080/0361073x.2019.1609169. PMID: 31021713. Exclusion Code: X5.31021713
165 Oliver-Williams C, Glisic M, Shahzad S, . The route of administration, timing, duration and dose of postmenopausal hormone therapy and cardiovascular outcomes in women: a systematic review. Hum Reprod Update. 2019 Mar 1;25(2):257–71. doi: 10.1093/humupd/dmy039. PMID: 30508190. Exclusion Code: X2.30508190
166 Owen CM, Pal L, Mumford SL, . Effects of hormones on skin wrinkles and rigidity vary by race/ethnicity: four-year follow-up from the ancillary skin study of the Kronos Early Estrogen Prevention Study. Fertil Steril. 2016 Oct;106(5):1170–5.e3. doi: 10.1016/j.fertnstert.2016.06.023. PMID: 27393520. Exclusion Code: X5.27393520
167 Pearson AG, Jayachandran M, Lahr BD, . Association between cerebrovascular reactivity and intravascular cellular activation in postmenopausal women following use of menopausal hormone treatments. FASEB J. 2018;32(1). Exclusion Code: X11.
168 Perez MV, Wang PJ, Larson JC, . Effects of postmenopausal hormone therapy on incident atrial fibrillation: the Women’s Health Initiative randomized controlled trials. Circ Arrhythm Electrophysiol. 2012 Dec;5(6):1108–16. doi: 10.1161/circep.112.972224. PMID: 23169946. Exclusion Code: X12.23169946
169 Peters SAE, Woodward M. Oestradiol and the risk of myocardial infarction in women: a cohort study of UK Biobank participants. Int J Epidemiol. 2021 Aug 30;50(4):1241–9. doi: 10.1093/ije/dyaa284. PMID: 33734370. Exclusion Code: X3.33734370
170 Petra S, Johanna W, Anne-Sophie K, . Cognitive health after menopause: Does menopausal hormone therapy affect it? Best Pract Res Clin Endocrinol Metab. 2021 Aug 17:101565. doi: 10.1016/j.beem.2021.101565. PMID: 34538724. Exclusion Code: X8.34538724
171 Pickar JH, Archer DF, Goldstein SR, . Uterine bleeding rates with hormone therapies in menopausal women with vasomotor symptoms. Menopause. 2019;26(12):1475. doi: 10.1097/GME.0000000000001456. Exclusion Code: X11.
172 Pickar JH, Bernick B, Mirkin S. Novel oral, continuous-combined solubilized 17β-estradiol and natural progesterone provides endometrial protection: comparison of two randomized controlled trials. Endocr Rev. 2018;39(2). Exclusion Code: X11.
173 Poornima IG, Mackey RH, Allison MA, . Coronary artery calcification (CAC) and post-trial cardiovascular events and mortality within the Women’s Health Initiative (WHI) estrogen-alone trial. J Am Heart Assoc. 2017 Oct 27;6(11)doi: 10.1161/jaha.117.006887. PMID: 29079563. Exclusion Code: X7.29079563
174 Prentice RL, Aragaki AK, Chlebowski RT, . Randomized trial evaluation of the benefits and risks of menopausal hormone therapy among women 50–59 years of age. Am J Epidemiol. 2021;190(3):365–75. PMID: CN-02272198. Exclusion Code: X1.33025002
175 Prentice RL, Aragaki AK, Chlebowski RT, . Dual-outcome intention-to-treat analyses in the women’s health initiative randomized controlled hormone therapy trials. Am J Epidemiol. 2020 Sep 1;189(9):972–81. doi: 10.1093/aje/kwaa033. PMID: 32314781. Exclusion Code: X5.32314781
176 Prior JC, Seifert-Klauss VR, Giustini D, . Estrogen-progestin therapy causes a greater increase in spinal bone mineral density than estrogen therapy - a systematic review and meta-analysis of controlled trials with direct randomization. J Musculoskelet Neuronal Interact. 2017 Sep 1;17(3):146–54. PMID: 28860416. Exclusion Code: X5.28860416
177 Ran SY, Yu Q, Chen Y, . Prevention of postmenopausal osteoporosis in Chinese women: a 5-year, double-blind, randomized, parallel placebo-controlled study. Climacteric. 2017 Aug;20(4):391–6. doi: 10.1080/13697137.2017.1325459. PMID: 28523945. Exclusion Code: X9.28523945
178 Rasmussen ELK, Hannibal CG, Dehlendorff C, . Parity, infertility, oral contraceptives, and hormone replacement therapy and the risk of ovarian serous borderline tumors: a nationwide case-control study. Gynecol Oncol. 2017 Mar;144(3):571–6. doi: 10.1016/j.ygyno.2017.01.002. PMID: 28108026. Exclusion Code: X7.28108026
179 Raz L, Hunter LV, Dowling NM, . Differential effects of hormone therapy on serotonin, vascular function and mood in the KEEPS. Climacteric. 2016;19(1):49–59. doi: 10.3109/13697137.2015.1116504. PMID: 26652904. Exclusion Code: X5.26652904
180 Ren M, Ruan X, Gu L, . Ultra-low-dose estradiol and dydrogesterone: a phase III study for vasomotor symptoms in China. Climacteric. 2021 Aug 17:1–7. doi: 10.1080/13697137.2021.1956894. PMID: 34402360. Exclusion Code: X5.33459067
181 Rocca WA, Gazzuola-Rocca L, Smith CY, . Accelerated accumulation of multimorbidity after bilateral oophorectomy: a population-based cohort study. Mayo Clin Proc. 2016 Nov;91(11):1577–89. doi: 10.1016/j.mayocp.2016.08.002. PMID: 27693001. Exclusion Code: X2.27693001
182 Rosenberg L, Bethea TN, Viscidi E, . Postmenopausal female hormone use and estrogen receptor-positive and -negative breast cancer in African American women. J Natl Cancer Inst. 2016 Apr;108(4)doi: 10.1093/jnci/djv361. PMID: 26613937. Exclusion Code: X7.26613937
183 Rovinski D, Ramos RB, Fighera TM, . Risk of venous thromboembolism events in postmenopausal women using oral versus non-oral hormone therapy: a systematic review and meta-analysis. Thromb Res. 2018 Aug;168:83–95. doi: 10.1016/j.thromres.2018.06.014. PMID: 29936403. Exclusion Code: X8.29936403
184 Salagame U, Banks E, Sitas F, . Menopausal hormone therapy use and breast cancer risk in Australia: Findings from the New South Wales Cancer, Lifestyle and Evaluation of Risk study. Int J Cancer. 2016 Apr 15;138(8):1905–14. doi: 10.1002/ijc.29942. PMID: 26599391. Exclusion Code: X7.26599391
185 Santoro N, Allshouse A, Neal-Perry G, . Longitudinal changes in menopausal symptoms comparing women randomized to low-dose oral conjugated estrogens or transdermal estradiol plus micronized progesterone versus placebo: the Kronos Early Estrogen Prevention Study. Menopause. 2017 Mar;24(3):238–46. doi: 10.1097/gme.0000000000000756. PMID: 27779568. Exclusion Code: X5.27779568
186 Savolainen-Peltonen H, Tuomikoski P, Korhonen P, . Reduced cardiac death risk in relation to the younger age at initiation of various postmenopausal hormone therapies. Endocr Rev. 2016;37(2). Exclusion Code: X11.
187 Scarabin PY. Progestogens and venous thromboembolism in menopausal women: an updated oral versus transdermal estrogen meta-analysis. Climacteric. 2018 Aug;21(4):341–5. doi: 10.1080/13697137.2018.1446931. PMID: 29570359. Exclusion Code: X8.29570359
188 Segarra TJ, Ritchie M, Zehtabchi S. Hormone therapy for primary prevention of cardiovascular disease in postmenopausal women. Am Fam Physician. 2018 Oct 1;98(7):Online. PMID: 30252424. Exclusion Code: X1.30252424
189 Shah SA, Tibble H, Pillinger R, . Hormone replacement therapy and asthma onset in menopausal women: National cohort study. J Allergy Clin Immunol. 2021 May;147(5):1662–70. doi: 10.1016/j.jaci.2020.11.024. PMID: 33279576. Exclusion Code: X13.33279576
190 Shekar C, Kinninger A, Cespedes L, . Effect of menopausal hormonal therapy and coronary artery calcium on volumetric bone mineral density by serial computed tomography angiography. Circulation. 2019;140. Exclusion Code: X11.
191 Shi LF, Wu Y, Li CY. Hormone therapy and risk of ovarian cancer in postmenopausal women: a systematic review and meta-analysis. Menopause. 2016 Apr;23(4):417–24. doi: 10.1097/gme.0000000000000550. PMID: 26506499. Exclusion Code: X8.26506499
192 Shufelt C, Bairey Merz CN, Pettinger MB, . Estrogen-alone therapy and invasive breast cancer incidence by dose, formulation, and route of delivery: findings from the WHI observational study. Menopause. 2018 Sep;25(9):985–91. doi: 10.1097/gme.0000000000001115. PMID: 29738414. Exclusion Code: X6.29738414
193 Shufelt C, Merz CNB, Pettinger MB, . Estrogen-alone therapy and invasive breast cancer incidence by dose, formulation, and route of delivery: Findings from the WHI observational study. Menopause. 2016;23(12):1370. doi: 10.1097/GME.0000000000000783. Exclusion Code: X6.
194 Simon J, Kaunitz A, Kroll R, . TX-001HR improved quality of life in menopausal women with vasomotor symptoms. Menopause. 2017;24(12):1432. doi: 10.1097/GME.0000000000000997. Exclusion Code: X11.
195 Simon J, Parish S, Bernick B, . 020 Bioidentical combined estradiol and progesterone capsules improved vaginal dryness in women with vasomotor symptoms. J Sex Med. 2019;16(6):S9–S10. doi: 10.1016/j.jsxm.2019.03.477. Exclusion Code: X11.
196 Simon JA, Kaunitz AM, Kroll R, . Oral 17β-estradiol/progesterone (TX-001HR) and quality of life in postmenopausal women with vasomotor symptoms. Menopause. 2019 May;26(5):506–12. doi: 10.1097/gme.0000000000001271. PMID: 30489424. Exclusion Code: X5.30489424
197 Simon JA, Kaunitz AM, Kroll R, . Oral 17beta-estradiol/progesterone (TX-001HR) and quality of life in postmenopausal women with vasomotor symptoms. Menopause (New York, N.Y.). 2019;26(5):506–12. doi: 10.1097/GME.0000000000001271. PMID: CN-01968593. Exclusion Code: X5.
198 Sjögren LL, Mørch LS, Løkkegaard E. Hormone replacement therapy and the risk of endometrial cancer: a systematic review. Maturitas. 2016 Sep;91:25–35. doi: 10.1016/j.maturitas.2016.05.013. PMID: 27451318. Exclusion Code: X14.27451318
199 Skinner BD, Davies RJ, Weaver SR, . A systematic review and meta-analysis examining whether changing ovarian sex steroid hormone levels influence cerebrovascular function. Front Physiol. 2021;12:687591. doi: 10.3389/fphys.2021.687591. PMID: 34220552. Exclusion Code: X5.34220552
200 Song YJ, Li SR, Li XW, . The effect of estrogen replacement therapy on Alzheimer’s disease and Parkinson’s disease in postmenopausal women: a meta-analysis. Front Neurosci. 2020;14:157. doi: 10.3389/fnins.2020.00157. PMID: 32210745. Exclusion Code: X8.32210745
201 Sriprasert I, Hodis H, Bernick B, . Effect of estradiol dose and serum estradiol level on coagulation and anti-coagulation factors in early and late postmenopausal women in the REPLENISH trial. Menopause. 2018;25(12):1500. doi: 10.1097/GME.0000000000001251. Exclusion Code: X11.
202 Sriprasert I, Hodis H, Bernick B, . Determinants of attained estradiol levels in response to oral estradiol plus progesterone therapy. Menopause. 2019;26(12):1477–8. doi: 10.1097/GME.0000000000001456. Exclusion Code: X5.
203 Sriprasert I, Hodis H, Bernick B, . Modifying effect of time-since-menopause and age on the association of estradiol dose and estradiol level on coagulation measures. Menopause. 2019;26(12):1478. doi: 10.1097/GME.0000000000001456. Exclusion Code: X11.
204 Sriprasert I, Hodis H, Bernick B, . Effect of estradiol dose and serum estradiol level on metabolic measures in early and late postmenopausal women in the replenish trial. Menopause. 2019;26(12):1456. doi: 10.1097/GME.0000000000001456. Exclusion Code: X5.
205 Sriprasert I, Hodis HN, Bernick B, . Effects of estradiol dose and serum estradiol levels on metabolic measures in early and late postmenopausal women in the REPLENISH Trial. J Womens Health (Larchmt). 2020 Aug;29(8):1052–8. doi: 10.1089/jwh.2019.8238. PMID: 32644875. Exclusion Code: X5.32644875
206 Sriprasert I, Hodis HN, Bernick B, . Association of oral estradiol dose/levels with coagulation measures in early/late postmenopausal women. Climacteric. 2020 Jun;23(3):273–8. doi: 10.1080/13697137.2019.1703939. PMID: 31939316. Exclusion Code: X5.31939316
207 Sriprasert I, Hodis HN, Bernick B, . Determinants of attained estradiol levels in response to oral estradiol plus progesterone therapy. Climacteric. 2020 Nov 12:1–6. doi: 10.1080/13697137.2020.1838477. PMID: 33179515. Exclusion Code: X5.31951763
208 Sriprasert I, Hodis HN, Karim R, . Differential effect of plasma estradiol on subclinical atherosclerosis progression in early vs late postmenopause. J Clin Endocrinol Metab. 2019 Feb 1;104(2):293–300. doi: 10.1210/jc.2018-01600. PMID: 30272234. Exclusion Code: X5.30272234
209 Sriprasert I, Kono N, Karim R, . Factors associated with serum estradiol levels among postmenopausal women using hormone therapy. Obstet Gynecol. 2020 Oct;136(4):675–84. doi: 10.1097/aog.0000000000004006. PMID: 32925623. Exclusion Code: X5.32925623
210 Sriprasert I, Mert M, Mack WJ, . Use of oral estradiol plus vaginal progesterone in healthy postmenopausal women. Maturitas. 2021;154:13–9. doi: 10.1016/j.maturitas.2021.09.002. Exclusion Code: X5.34736575
211 Stevenson J. Optimising cardiovascular safety of HRT. Climacteric. 2016;19:23-. doi: 10.1080/13697137.2016.1242242. PMID: CN-01406152. Exclusion Code: X11.
212 Stute P, Neulen J, Wildt L. The impact of micronized progesterone on the endometrium: a systematic review. Climacteric. 2016 Aug;19(4):316–28. doi: 10.1080/13697137.2016.1187123. PMID: 27277331. Exclusion Code: X8.27277331
213 Stute P, Wildt L, Neulen J. The impact of micronized progesterone on breast cancer risk: a systematic review. Climacteric. 2018 Apr;21(2):111–22. doi: 10.1080/13697137.2017.1421925. PMID: 29384406. Exclusion Code: X7.29384406
214 Swica Y, Warren MP, Manson JE, . Effects of oral conjugated equine estrogens with or without medroxyprogesterone acetate on incident hypertension in the Women’s Health Initiative hormone therapy trials. Menopause. 2018 Jul;25(7):753–61. doi: 10.1097/gme.0000000000001067. PMID: 29381666. Exclusion Code: X5.29381666
215 Taylor HS, Tal A, Pal L, . Effects of oral vs transdermal estrogen therapy on sexual function in early postmenopause: ancillary study of the Kronos Early Estrogen Prevention Study (KEEPS). JAMA Intern Med. 2017 Oct 1;177(10):1471–9. doi: 10.1001/jamainternmed.2017.3877. PMID: 28846767. Exclusion Code: X5.28846767
216 Tempfer CB, Hilal Z, Kern P, . Menopausal hormone therapy and risk of endometrial cancer: a systematic review. Cancers (Basel). 2020 Aug 6;12(8)doi: 10.3390/cancers12082195. PMID: 32781573. Exclusion Code: X8.32781573
217 Tsai CH, Fan YH, Chung HJ, . Protective effect of postmenopausal hormone replacement against urolithiasis. J Urol. 2020;203:e651-. PMID: CN-02143963. Exclusion Code: X11.
218 Tsiligiannis S, Wick-Urban BC, van der Stam J, . Efficacy and safety of a low-dose continuous combined hormone replacement therapy with 0.5 mg 17β-estradiol and 2.5 mg dydrogesterone in subgroups of postmenopausal women with vasomotor symptoms. Maturitas. 2020 Sep;139:20–6. doi: 10.1016/j.maturitas.2020.05.002. PMID: 32747036. Exclusion Code: X3.32747036
219 Vaisar T, Gordon JL, Wimberger J, . Perimenopausal transdermal estrogen replacement therapy reduces serum high-density lipoprotein cholesterol efflux capacity but improves cardiovascular risk factors. Arterioscler Thromb Vasc Biol. 2019;39. Exclusion Code: X11.
220 Vajaranant TS, Maki PM, Pasquale LR, . Effects of hormone therapy on intraocular pressure: The Women’s Health Initiative-Sight Exam Study. Am J Ophthalmol. 2016 May;165:115–24. doi: 10.1016/j.ajo.2016.02.025. PMID: 26940165. Exclusion Code: X5.26940165
221 Vajaranant TS, Ray R, Pasquale LR, . Racial differences in the effect of hormone therapy on incident open-angle glaucoma. Invest Ophthalmol Vis Sci. 2017;58(8). Exclusion Code: X11.
222 van Tuijl LA, Voogd AC, de Graeff A, . Psychosocial factors and cancer incidence (PSY-CA): protocol for individual participant data meta-analyses. Brain Behav. 2021 Sep 2:e2340. doi: 10.1002/brb3.2340. PMID: 34473425. Exclusion Code: X5.34473425
223 Vargiu V, Amar ID, Rosati A, . Hormone replacement therapy and cervical cancer: a systematic review of the literature. Climacteric. 2020 Nov 25:1–8. doi: 10.1080/13697137.2020.1826426. PMID: 33236658. Exclusion Code: X8.31951763
224 Vargiu V, Amar ID, Rosati A, . Hormone replacement therapy and cervical cancer: a systematic review of the literature. Climacteric. 2021 Apr;24(2):120–7. doi: 10.1080/13697137.2020.1826426. PMID: 33236658. Exclusion Code: X8.33236658
225 Vermeulen RFM, Korse CM, Kenter GG, . Safety of hormone replacement therapy following risk-reducing salpingo-oophorectomy: systematic review of literature and guidelines. Climacteric. 2019 Aug;22(4):352–60. doi: 10.1080/13697137.2019.1582622. PMID: 30905183. Exclusion Code: X8.30905183
226 Vinogradova Y, Coupland C, Hippisley-Cox J. Use of hormone replacement therapy and risk of venous thromboembolism: nested case-control studies using the QResearch and CPRD databases. BMJ. 2019 Jan 9;364:k4810. doi: 10.1136/bmj.k4810. PMID: 30626577. Exclusion Code: X7.30626577
227 von Stockum S, Barnett C, Bauerfeind A, . Estradiol is associated with decreased cardiovascular risk compared to ethinylestradiol when contained in combined hormonal preparations: implications for the development of new endometriosis therapies. Fertil Steril. 2020;114(3):e78–e9. doi: 10.1016/j.fertnstert.2020.08.241. Exclusion Code: X2.
228 Wang BJ, Zhang B, Yan SS, . Hormonal and reproductive factors and risk of esophageal cancer in women: a meta-analysis. Dis Esophagus. 2016 Jul;29(5):448–54. doi: 10.1111/dote.12349. PMID: 25809699. Exclusion Code: X8.25809699
229 Webber L, Anderson RA, Davies M, . HRT for women with premature ovarian insufficiency: a comprehensive review. Hum Reprod Open. 2017;2017(2):hox007. doi: 10.1093/hropen/hox007. PMID: 30895225. Exclusion Code: X1.30895225
230 Whedon JM, KizhakkeVeettil A, Rugo NA, . Bioidentical estrogen for menopausal depressive symptoms: a systematic review and meta-analysis. J Womens Health (Larchmt). 2017 Jan;26(1):18–28. doi: 10.1089/jwh.2015.5628. PMID: 27603786. Exclusion Code: X5.27603786
231 Wikana J. Utilizing bioidentical hormone as efficacious and safe hormone. Journal of Global Pharma Technology. 2019;11(6):130–44. Exclusion Code: X8.
232 Windler E, Stute P. Postmenopausal hormone replacement therapy and vascular risk. Der gynakologe. 2017:1–6. doi: 10.1007/s00129-017-4104-5. PMID: CN-01395073. Exclusion Code: X10.
233 Woodis CB, Ghassemi E, McLendon AN. Bioidentical oral 17β-estradiol and progesterone for the treatment of moderate to severe vasomotor symptoms of menopause. Ann Pharmacother. 2021 Sep;55(9):1153–8. doi: 10.1177/1060028020982611. PMID: 33345556. Exclusion Code: X5.33345556
234 Xue W, Sun AJ, Zheng TP, . Analysis of the effects on menopausal symptoms, quality of Life, and cardiovascular risk factors of five different therapy in women at early stage of menopause. Zhonghua yi xue za zhi. 2016;96(29):2327–11. doi: 10.3760/cma.j.issn.0376-2491.2016.29.009. PMID: CN-01342598. Exclusion Code: X10.27524190
235 Yang Z, Hu Y, Zhang J, . Estradiol therapy and breast cancer risk in perimenopausal and postmenopausal women: a systematic review and meta-analysis. Gynecol Endocrinol. 2017 Feb;33(2):87–92. doi: 10.1080/09513590.2016.1248932. PMID: 27898258. Exclusion Code: X14.27898258
236 Yeh YT, Li PC, Wu KC, . Hysterectomies are associated with an increased risk of osteoporosis and bone fracture: A population-based cohort study. PLoS One. 2020;15(12):e0243037. doi: 10.1371/journal.pone.0243037. PMID: 33259542. Exclusion Code: X2.33259542
237 Yoo JE, Shin DW, Han K, . Association of female reproductive factors with incidence of fracture among postmenopausal women in Korea. JAMA Netw Open. 2021 Jan 4;4(1):e2030405. doi: 10.1001/jamanetworkopen.2020.30405. PMID: 33404618. Exclusion Code: X3.33404618
238 Yu CG, Zhao SH, Shi JY, . A translational study of low-dose estrogen replacement therapy on Kupperman score and levels of hormones in patients with perimenopausal syndrome. Journal of International Translational Medicine. 2016;4(2):143–6. doi: 10.11910/2227-6394.2016.04.02.12. PMID: CN-01285595. Exclusion Code: X4.
239 Zannas A, Gordon J, Hinderliter A, . Stress-related inflammation predicts 12-month cardiometabolic outcomes in perimenopausal women. Biol Psychiatry. 2020;87(9):S443-. doi: 10.1016/j.biopsych.2020.02.1129. PMID: CN-02123724. Exclusion Code: X11.
240 Zeydan B, Lowe VJ, Tosakulwong N, . Sleep quality and cortical amyloid-β deposition in postmenopausal women of the Kronos early estrogen prevention study. Neuroreport. 2021 Jan 18doi: 10.1097/wnr.0000000000001592. PMID: 33470769. Exclusion Code: X5.33470769
241 Zhang T, Casanova R, Resnick SM, . Effects of hormone therapy on brain volumes changes of postmenopausal women revealed by optimally-discriminative voxel-based morphometry. PLoS One. 2016;11(3):e0150834. doi: 10.1371/journal.pone.0150834. PMID: 26974440. Exclusion Code: X5.26974440
242 Zhong GC, Liu Y, Chen N, . Reproductive factors, menopausal hormone therapies and primary liver cancer risk: a systematic review and dose-response meta-analysis of observational studies. Hum Reprod Update. 2016 Dec;23(1):126–38. doi: 10.1093/humupd/dmw037. PMID: 27655589. Exclusion Code: X8.27655589
243 Zhou HH, Yu Z, Luo L, . The effect of hormone replacement therapy on cognitive function in healthy postmenopausal women: a meta-analysis of 23 randomized controlled trials. Psychogeriatrics. 2021 Oct 7doi: 10.1111/psyg.12768. PMID: 34622524. Exclusion Code: X14.34622524
244 Zuo HL, Deng Y, Wang YF, . Effect of low-dose or standard-dose conjugated equine estrogen combined with different progesterone on bone density in menopause syndrome women. Zhonghua fu chan ke za zhi. 2018;53(4):243–7. doi: 10.3760/cma.j.issn.0529-567x.2018.04.007. PMID: CN-01603683. Exclusion Code: X10.29747269