# Appendix B Inclusion and Exclusion Criteria

| Include | Exclude
Population | - Generally healthy perimenopausal and postmenopausal women eligible for menopausal HT; - Women with and without menopausal symptoms will be included if the focus of the analysis is on the primary prevention of chronic conditions | - Animals; men; premenopausal women; postmenopausal women with contraindications for HT use such as history of breast cancer, coronary heart disease, a previous venous thromboembolic event or stroke, active liver disease, or those at high risk for these complications; populations not applicable to U.S. primary care; - Postmenopausal women who use HT for secondary prevention of chronic conditions
Interventions | Systemic therapy with estrogen-only formulations or combinations with progestogens (progesterone or progestin) for prevention of chronic conditions. Medications are FDA-approved and available for use in the United States (see Table 1) | Localized (nonsystemic) treatments such as rings, creams, or gels; contraceptives; other hormones; treatments of menopausal symptoms such as over-the-counter preparations or compounded bioidentical therapies that are not FDA-approved
Control interventions | Placebo, no treatment | Active comparator
Outcomes | - Overall mortality; - Disease-specific mortality (if related to chronic conditions^*^ of interest); - Coronary heart disease; - Stroke; - Thromboembolism; - Cancer (breast, colorectal, endometrial, ovarian, and non-small cell lung); - Cholecystitis; - Fractures; - Cognition; - Quality of life (if related to chronic conditions of interest); - Functional capacity; - Urinary incontinence; - Diabetes | Any outcomes that are not health outcomes of chronic conditions associated with HT; intermediate outcomes, such as bone density and cholesterol level
Duration of intervention | ≥1 year of treatment | Less than 1 year of treatment
Publication language | English | Non-English language
Study design | All outcomes:; - RCTs; - Controlled clinical trials; - Systematic reviews; For outcomes or subgroups with no evidence from trials or systematic reviews:; - Large cohort studies (more than 10,000 women) | All other study designs
Publication type | Published or unpublished original research | Nonsystematic review article, letter, editorial, results reported elsewhere, no original data
Geography | U.S. adult population or comparable populations (categorized as “Very High” using the Human Development Index, as defined by the United Nations Development Programme) | Not comparable or applicable to U.S. adult population
Setting | Primary care or primary-care–like settings | Inpatient facilities, nursing homes, hormone specialist offices

* The Centers for Disease Control and Prevention defines chronic diseases as conditions that last 1 or more years and require ongoing medical attention, limit activities of daily living, or both. The following are classified as chronic diseases: heart disease, cancer, chronic lung disease, stroke, Alzheimer’s disease, diabetes, and chronic kidney disease.

Source: Centers for Disease Control and Prevention. About Chronic Diseases. https://www.cdc.gov/chronicdisease/about/index.htm. Accessed May 7, 2021 .

Abbreviations: FDA=Food and Drug Administration; HT=hormone therapy; RCT=randomized, controlled trial.