# Appendix A Search Strategies

28 January 2021

PubMed:

Search | Query | Results
#1 | “Hormone Replacement Therapy”[Mesh] OR “Hormone Replacement Therapy”[tiab] OR “Hormone Replacement Therapies”[tiab] OR “Estrogen Replacement Therapy”[Mesh] OR “estrogen replacement”[tiab] OR “estrogen replacements”[tiab] OR “estrogen therapy”[tiab] OR “estrogen therapies”[tiab] OR “progestin replacement”[tiab] OR “estrogen progestin combination therapy”[tiab] OR Alora[tiab] OR Cenestin[tiab] OR Climara[tiab] OR Delestrogen[tiab] OR Esclim[tiab] OR Estrace[tiab] OR Estraderm[tiab] OR Menostar[tiab] OR Minivelle[tiab] OR “Ortho-Est”[tiab] OR Prometrium[tiab] OR Provera[tiab] OR Vivelle[tiab] OR “Vivelle-Dot”[tiab] OR Femtrace[tiab] OR Menest[tiab] OR Ogen[tiab] OR Premarin[tiab] OR Enjuvia[tiab] OR Angeliq[tiab] OR Activella[tiab] OR Prefest[tiab] OR Climara Pro[tiab] OR Combipatch[tiab] OR Prempro[tiab] OR Femhrt[tiab] OR “Estradiol”[Mesh] OR Estradiol[tiab] OR Oestradiol[tiab] OR Progynova[tiab] OR Vivelle[tiab] OR Aerodiol[tiab] OR Estrace[tiab] OR “Estraderm TTS”[tiab] OR “Progynon-Depot”[tiab] OR “Progynon Depot”[tiab] OR Delestrogen[tiab] OR Ovocyclin[tiab] OR Estropipate[tiab] OR “Micronized progesterone”[tiab] OR “Medroxyprogesterone Acetate”[Mesh] OR “Medroxyprogesterone acetate”[tiab] OR “Medroxyprogesterone 17-Acetate”[tiab] OR “Medroxyprogesterone 17 Acetate”[tiab] OR Depo-Provera[tiab] OR Depo Provera[tiab] OR DepoProvera[tiab] OR Farlutal[tiab] OR Gestapuran[tiab] OR Curretab[tiab] OR Perlutex[tiab] OR Provera[tiab] OR Veramix[tiab] OR Cycrin[tiab] OR “Estrogens, Esterified (USP)”[Mesh] OR “Esterifield Estrogen”[tiab] OR “Esterifield Estrogens”[tiab] OR “Estrogens, Conjugated (USP)”[Mesh] OR “Conjugated Estrogen”[tiab] OR “Conjugated Estrogens”[tiab] OR “Conjugated Estrogenic”[tiab] OR “Conjugated Equine Estrogens”[tiab] OR “Conjugated Equine Estrogen”[tiab] OR Dagynil[tiab] OR Oestrofeminal[tiab] OR “Oestro-Feminal”[tiab] OR “Oestro Feminal”[tiab] OR “Estro-Feminal”[tiab] OR “Estro Feminal”[tiab] OR Premarin[tiab] OR Climopax[tiab] OR Climarest[tiab] OR Presomen[tiab] OR Progens[tiab] OR Progen[tiab] OR Transannon[tiab] OR Femavit[tiab] OR Carentil[tiab] OR Prelestrin[tiab] OR “Estradiol Congeners”[Mesh:NoExp] OR “Synthetic Estrogen”[tiab] OR “Synthetic Estrogens”[tiab] | 162,654
#2 | “Climacteric”[Mesh:NoExp] OR climacteric[tiab] OR “Menopause”[Mesh] OR menopause[tiab] OR menopausal[tiab] OR perimenopause[tiab] OR perimenopausal[tiab] OR “Hot Flashes”[Mesh] OR “hot flashes”[tiab] OR “Postmenopause”[Mesh] OR “Post-Menopausal”[tiab] OR Postmenopausal[tiab] OR “Post-Menopause”[tiab] OR Postmenopause[tiab] OR “Osteoporosis, Postmenopausal”[Mesh] OR “Hysterectomy”[Mesh] OR Hysterectomy[tiab] | 160,379
#3 | #1 AND #2 | 31,390
#4 | #3 AND (“2016/01/01”[Date – Publication] : “3000”[Date – Publication]) | 3,522
#5 | #4 AND English[lang] | 3,420
#6 | #5 NOT (animals[mh] NOT humans[mh]) | 3,116
#7 | #6 AND (“Clinical Trial” [Publication Type:NoExp] OR “controlled clinical trial”[pt] OR “randomized controlled trial”[pt] OR “Randomized Controlled Trials as Topic”[mh] OR “Random Allocation”[mh] OR “randomized”[tiab] OR “nglisht”[tiab] OR “randomization”[tiab] OR “nglishtion”[tiab] OR “randomly”[tiab] OR placebo*[tiab] OR “Double-Blind Method”[Mesh] OR “Single-Blind Method”[Mesh] OR “Clinical Trials as Topic”[mh] OR trial[ti] OR “Clinical Trial, Phase III”[pt] OR “Clinical Trials, Phase III as Topic”[mh] OR “Clinical Trial, Phase IV”[pt] OR “Clinical Trials, Phase IV as Topic”[mh] OR systematic[sb] OR “systematic review”[tiab] OR “meta-analysis”[pt] OR “meta-analysis as topic”[mh] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “Cohort Studies”[Mesh:NoExp] OR “cohort study”[tiab] OR “cohort analysis”[tiab] OR “cohort analyses”[tiab]) NOT (Editorial[pt] OR Letter[pt] OR Case Reports[pt] OR “a case report”[ti] OR “: case report”[ti] OR Comment[pt]) | 1,012

Embase:

Search | Query | Results
#1 | ‘hormone substitution’/exp OR ‘Hormone Replacement Therapy’:ti,ab OR ‘Hormone Replacement Therapies’:ti,ab OR ‘estrogen replacement’:ti,ab OR ‘estrogen replacements’:ti,ab OR ‘estrogen therapy’:ti,ab OR ‘estrogen therapies’:ti,ab OR ‘progestin replacement’:ti,ab OR ‘estrogen progestin combination therapy’:ti,ab OR Alora:ti,ab OR Cenestin:ti,ab OR Climara:ti,ab OR Delestrogen:ti,ab OR Esclim:ti,ab OR Estrace:ti,ab OR Estraderm:ti,ab OR Menostar:ti,ab OR Minivelle:ti,ab OR ‘Ortho-Est’:ti,ab OR Prometrium:ti,ab OR Provera:ti,ab OR Vivelle:ti,ab OR ‘Vivelle-Dot’:ti,ab OR Femtrace:ti,ab OR Menest:ti,ab OR Ogen:ti,ab OR Premarin:ti,ab OR Enjuvia:ti,ab OR Angeliq:ti,ab OR Activella:ti,ab OR Prefest:ti,ab OR Climara Pro:ti,ab OR Combipatch:ti,ab OR Prempro:ti,ab OR Femhrt:ti,ab OR ‘estradiol’/exp OR Estradiol:ti,ab OR Oestradiol:ti,ab OR Progynova:ti,ab OR Vivelle:ti,ab OR Aerodiol:ti,ab OR Estrace:ti,ab OR ‘Estraderm TTS’:ti,ab OR ‘Progynon-Depot’:ti,ab OR ‘Progynon Depot’:ti,ab OR Delestrogen:ti,ab OR Ovocyclin:ti,ab OR Estropipate:ti,ab OR ‘Micronized progesterone’:ti,ab OR ‘medroxyprogesterone acetate’/exp OR ‘Medroxyprogesterone acetate’:ti,ab OR ‘Medroxyprogesterone 17-Acetate’:ti,ab OR ‘Medroxyprogesterone 17 Acetate’:ti,ab OR Depo-Provera:ti,ab OR Depo Provera:ti,ab OR DepoProvera:ti,ab OR Farlutal:ti,ab OR Gestapuran:ti,ab OR Curretab:ti,ab OR Perlutex:ti,ab OR Provera:ti,ab OR Veramix:ti,ab OR Cycrin:ti,ab OR ‘conjugated estrogen’/exp OR ‘Esterifield Estrogen’:ti,ab OR ‘Esterifield Estrogens’:ti,ab OR ‘Conjugated Estrogen’:ti,ab OR ‘Conjugated Estrogens’:ti,ab OR ‘Conjugated Estrogenic’:ti,ab OR ‘Conjugated Equine Estrogens’:ti,ab OR ‘Conjugated Equine Estrogen’:ti,ab OR Dagynil:ti,ab OR Oestrofeminal:ti,ab OR ‘Oestro-Feminal’:ti,ab OR ‘Oestro Feminal’:ti,ab OR ‘Estro-Feminal’:ti,ab OR ‘Estro Feminal’:ti,ab OR Premarin:ti,ab OR Climopax:ti,ab OR Climarest:ti,ab OR Presomen:ti,ab OR Progens:ti,ab OR Progen:ti,ab OR Transannon:ti,ab OR Femavit:ti,ab OR Carentil:ti,ab OR Prelestrin:ti,ab OR ‘estradiol derivative’/exp OR ‘Synthetic Estrogen’:ti,ab OR ‘Synthetic Estrogens’:ti,ab | 174,757
#2 | ‘menopause and climacterium’/exp OR climacteric:ti,ab OR menopause:ti,ab OR menopausal:ti,ab OR perimenopause:ti,ab OR perimenopausal:ti,ab OR ‘hot flush’/exp OR “hot flashes”:ti,ab OR “Post-Menopausal”:ti,ab OR Postmenopausal:ti,ab OR “Post-Menopause”:ti,ab OR Postmenopause:ti,ab OR ‘menopause related disorder’/exp OR ‘hysterectomy’/exp OR Hysterectomy:ti,ab | 266,960
#3 | #1 AND #2 | 27,670
#4 | AND ([nglish review]/lim OR [systematic review]/lim OR [meta analysis]/lim OR [controlled clinical trial]/lim OR [randomized controlled trial]/lim) AND [humans]/lim AND [nglish]/lim AND [2016-2021]/py | 754

Cochrane Library:

Search | Query | Results
#1 | (“Hormone Replacement Therapy” OR “Hormone Replacement Therapies” OR “estrogen replacement” OR “estrogen replacements” OR “estrogen therapy” OR “estrogen therapies” OR “progestin replacement” OR “estrogen progestin combination therapy” OR Alora OR Cenestin OR Climara OR Delestrogen OR Esclim OR Estrace OR Estraderm OR Menostar OR Minivelle OR “Ortho-Est” OR Prometrium OR Provera OR Vivelle OR “Vivelle-Dot” OR Femtrace OR Menest OR Ogen OR Premarin OR Enjuvia OR Angeliq OR Activella OR Prefest OR Climara Pro OR Combipatch OR Prempro OR Femhrt OR Estradiol OR Oestradiol OR Progynova OR Vivelle OR Aerodiol OR Estrace OR “Estraderm TTS” OR “Progynon-Depot” OR “Progynon Depot” OR Delestrogen OR Ovocyclin OR Estropipate OR “Micronized progesterone” OR “Medroxyprogesterone acetate” OR “Medroxyprogesterone 17-Acetate” OR “Medroxyprogesterone 17 Acetate” OR Depo-Provera OR Depo Provera OR DepoProvera OR Farlutal OR Gestapuran OR Curretab OR Perlutex OR Provera OR Veramix OR Cycrin OR “Esterifield Estrogen” OR “Esterifield Estrogens” OR “Conjugated Estrogen” OR “Conjugated Estrogens” OR “Conjugated Estrogenic” OR “Conjugated Equine Estrogens” OR “Conjugated Equine Estrogen” OR Dagynil OR Oestrofeminal OR “Oestro-Feminal” OR “Oestro Feminal” OR “Estro-Feminal” OR “Estro Feminal” OR Premarin OR Climopax OR Climarest OR Presomen OR Progens OR Progen OR Transannon OR Femavit OR Carentil OR Prelestrin OR “Synthetic Estrogen” OR “Synthetic Estrogens”):ti,ab,kw | 16,824
#2 | (climacteric OR menopause OR menopausal OR perimenopause OR perimenopausal OR “hot flashes” OR “Post-Menopausal” OR Postmenopausal OR “Post-Menopause” OR Postmenopause OR Hysterectomy):ti,ab,kw | 33,180
#3 | #1 AND #2 | 7,592
#4 | #3 AND (“2016/01/01”[Date – Publication] : “3000”[Date – Publication]) | 1,105