# References

1 Siu AL, U. S. Preventive Services Task Force. Screening for depression in children and adolescents: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2016 Mar 1;164(5):360–6. doi: 10.7326/M15-2957. PMID: 26858097.26858097
2 Crosby AE, Ortega L, Melanson C. Self-directed violence surveillance: uniform definitions and recommended data elements. Atlanta, GA: Centers for Disease Control and Prevention, National Center for Injury Prevention and Control; 2011.
3 Ivey-Stephenson AZ, Demissie Z, Crosby AE, . Suicidal ideation and behaviors among high school students—Youth Risk Behavior Survey, United States, 2019. MMWR Suppl. 2020 Aug 21;69(1):47–55. doi: 10.15585/mmwr.su6901a6. PMID: 32817610.32817610
4 National Institute of Mental Health. Suicide. Bethesda, MD: National Institute of Mental Health; 2019. https://www.nimh.nih.gov/health/statistics/suicide.shtml. Accessed March 3, 2020.
5 Andover MS, Morris BW, Wren A, . The co-occurrence of non-suicidal self-injury and attempted suicide among adolescents: distinguishing risk factors and psychosocial correlates. Child Adolesc Psychiatry Ment Health. 2012 Mar 30;6:11. doi: 10.1186/1753-2000-6-11. PMID: 22463065.22463065
6 Grandclerc S, De Labrouhe D, Spodenkiewicz M, . Relations between nonsuicidal self-injury and suicidal behavior in adolescence: a systematic review. PLoS One. 2016;11(4):e0153760. doi: 10.1371/journal.pone.0153760. PMID: 27089157.27089157
7 Sellers CM, Diaz-Valdes A, Porter AC, . Nonsuicidal self-injury, suicide planning, and suicide attempts among high-risk adolescents prior to psychiatric hospitalization. Res Child Adolesc Psychopathol. 2021 Nov;49(11):1503–11. doi: 10.1007/s10802-021-00830-z. PMID: 34059987.34059987
8 Robinson K, Garisch JA, Wilson MS. Nonsuicidal self-injury thoughts and behavioural characteristics: Associations with suicidal thoughts and behaviours among community adolescents. J Affect Disord. 2021 Mar 1;282:1247–54. doi: 10.1016/j.jad.2020.12.201. PMID: 33601703.33601703
9 Voss C, Hoyer J, Venz J, . Non-suicidal self-injury and its co-occurrence with suicidal behavior: An epidemiological-study among adolescents and young adults. Acta Psychiatr Scand. 2020 Dec;142(6):496–508. doi: 10.1111/acps.13237. PMID: 32979220.32979220
10 Jacobson CM, Gould M. The epidemiology and phenomenology of non-suicidal self-injurious behavior among adolescents: a critical review of the literature. Arch Suicide Res. 2007;11(2):129–47. doi: 10.1080/13811110701247602. PMID: 17453692.17453692
11 Cha CB, Franz PJ, E MG, . Annual research review: Suicide among youth - epidemiology, (potential) etiology, and treatment. J Child Psychol Psychiatry. 2018 Apr;59(4):460–82. doi: 10.1111/jcpp.12831. PMID: 29090457.29090457
12 Hawton K, Harriss L. Deliberate self-harm in young people: characteristics and subsequent mortality in a 20-year cohort of patients presenting to hospital. J Clin Psychiatry. 2007 Oct;68(10):1574–83. PMID: 17960975.17960975
13 American Psychiatric Association. Diagnostic and statistical manual of mental disorders (DSM-5), fifth edition. Arlington, VA: American Psychiatric Association; 2013.
14 Ferdinand RF, de Nijs PF, van Lier P, . Latent class analysis of anxiety and depressive symptoms in referred adolescents. J Affect Disord. 2005 Nov;88(3):299–306. doi: 10.1016/j.jad.2005.08.004. PMID: 16182373.16182373
15 Foley DL, Goldston DB, Costello EJ, . Proximal psychiatric risk factors for suicidality in youth: the Great Smoky Mountains Study. Arch Gen Psychiatry. 2006 Sep;63(9):1017–24. doi: 10.1001/archpsyc.63.9.1017. PMID: 16953004.16953004
16 Merikangas KR, Calkins ME, Burstein M, . Comorbidity of physical and mental disorders in the neurodevelopmental genomics cohort study. Pediatrics. 2015 Apr;135(4):e927–38. doi: 10.1542/peds.2014-1444. PMID: 25755242.25755242
17 Melvin GA, Dudley AL, Gordon MS, . What happens to depressed adolescents? A follow-up study into early adulthood. J Affect Disord. 2013 2013/10/01/;151(1):298–305. doi: 10.1016/j.jad.2013.06.012.23829999
18 Woodward LJ, Fergusson DM. Life course outcomes of young people with anxiety disorders in adolescence. J Am Acad Child Adolesc Psychiatry. 2001 Sep;40(9):1086–93. doi: 10.1097/00004583-200109000-00018. PMID: 11556633.11556633
19 Leone M, Kuja-Halkola R, Leval A, . Association of youth depression with subsequent somatic diseases and premature death. JAMA Psychiatry. 2021;78(3):302–10. doi: 10.1001/jamapsychiatry.2020.3786.33295952
20 Bufferd SJ, Dougherty LR, Olino TM. Mapping the frequency and severity of depressive behaviors in preschool-aged children. Child Psychiatry Hum Dev. 2017 Dec;48(6):934–43. doi: 10.1007/s10578-017-0715-2. PMID: 28281019.28281019
21 Luby JL, Heffelfinger AK, Mrakotsky C, . Preschool major depressive disorder: preliminary validation for developmentally modified DSM-IV criteria. J Am Acad Child Adolesc Psychiatry. 2002 Aug;41(8):928–37. doi: 10.1097/00004583-200208000-00011. PMID: 12162628.12162628
22 Whalen DJ, Dixon-Gordon K, Belden AC, . Correlates and consequences of suicidal cognitions and behaviors in children ages 3 to 7 years. J Am Acad Child Adolesc Psychiatry. 2015 Nov;54(11):926–37.e2. doi: 10.1016/j.jaac.2015.08.009. PMID: 26506583.26506583
23 Nock MK, Green JG, Hwang I, . Prevalence, correlates, and treatment of lifetime suicidal behavior among adolescents: results from the National Comorbidity Survey Replication Adolescent Supplement. JAMA Psychiatry. 2013 Mar;70(3):300–10. doi: 10.1001/2013.jamapsychiatry.55. PMID: 23303463.23303463
24 Sampasa-Kanyinga H, Dupuis LC, Ray R. Prevalence and correlates of suicidal ideation and attempts among children and adolescents. Int J Adolesc Med Health. 2017 Apr 1;29(2)doi: 10.1515/ijamh-2015-0053. PMID: 26556839.26556839
25 Mars B, Heron J, Klonsky ED, . Predictors of future suicide attempt among adolescents with suicidal thoughts or non-suicidal self-harm: a population-based birth cohort study. Lancet Psychiatry. 2019 Apr;6(4):327–37. doi: 10.1016/s2215-0366(19)30030-6. PMID: 30879972.30879972
26 Kessler RC. National comorbidity survey: adolescent supplement (NCS-A), 2001-2004: Inter-university Consortium for Political and Social Research; 2011.
27 Kessler RC, Avenevoli S, Costello EJ, . Prevalence, persistence, and sociodemographic correlates of DSM-IV disorders in the National Comorbidity Survey Replication Adolescent Supplement. Arch Gen Psychiatry. 2012 Apr;69(4):372–80. doi: 10.1001/archgenpsychiatry.2011.160. PMID: 22147808.22147808
28 Substance Abuse and Mental Health Services Administration. Results from the 2011 National Survey on Drug Use and Health: Mental Health Findings. NSDUH Series H-45, HHS Publication No. (SMA) 12-4725 Substance Abuse and Mental Health Services Administration. Rockville, MD: 2012.
29 National Institute of Mental Health. Suicide prevention. Bethesda, MD: National Institute of Mental Health; 2019. https://www.nimh.nih.gov/health/topics/suicide-prevention/index.shtml. Accessed April 6, 2021.
30 Miron O, Yu KH, Wilf-Miron R, . Suicide rates among adolescents and young adults in the United States, 2000-2017. JAMA. 2019 Jun 18;321(23):2362–4. doi: 10.1001/jama.2019.5054. PMID: 31211337.31211337
31 Twenge JM, Joiner TE, Rogers ML, . Increases in depressive symptoms, suicide-related outcomes, and suicide rates among US adolescents after 2010 and links to increased new media screen time. Clin Psychol Sci. 2018;6(1):3–17. doi: 10.1177/2167702617723376. PMID: 2017-58243-001.
32 Haas AP, Eliason M, Mays VM, . Suicide and suicide risk in lesbian, gay, bisexual, and transgender populations: review and recommendations. J Homosex. 2010;58(1):10–51.
33 Marshal MP, Dermody SS, Shultz ML, . Mental health and substance use disparities among urban adolescent lesbian and bisexual girls. J Am Psychiatr Nurses Assoc. 2013 Sep–Oct;19(5):271–9. doi: 10.1177/1078390313503552. PMID: 24055956.24055956
34 Hatchel T, Espelage DL, Huang Y. Sexual harassment victimization, school belonging, and depressive symptoms among LGBTQ adolescents: temporal insights. Am J Orthopsychiatry. 2018;88(4):422–30. doi: 10.1037/ort0000279. PMID: 2017-26162-001.28617003
35 Peyre H, Hoertel N, Stordeur C, . Contributing factors and mental health outcomes of first suicide attempt during childhood and adolescence: results from a nationally representative study. J Clin Psychiatry. 2017 Jun;78(6):e622–e30. doi: 10.4088/JCP.16m10876. PMID: 28355042.28355042
36 Zubrick SR, Hafekost J, Johnson SE, . The continuity and duration of depression and its relationship to non-suicidal self-harm and suicidal ideation and behavior in adolescents 12-17. J Affect Disord. 2017 Oct 1;220:49–56. doi: 10.1016/j.jad.2017.05.050. PMID: 28595098.28595098
37 Gomez SH, Tse J, Wang Y, . Are there sensitive periods when child maltreatment substantially elevates suicide risk? Results from a nationally representative sample of adolescents. Depress Anxiety. 2017 Aug;34(8):734–41. doi: 10.1002/da.22650. PMID: 28544045.28544045
38 Winsper C, Lereya T, Zanarini M, . Involvement in bullying and suicide-related behavior at 11 years: a prospective birth cohort study. J Am Acad Child Adolesc Psychiatry. 2012 Mar;51(3):271–82.e3. doi: 10.1016/j.jaac.2012.01.001. PMID: 22365463.22365463
39 Pyke JE, Murphy EM. Australian health and fitness survey 1985: the fitness, health and physical performance of Australian school students aged 7-15 years: Australian Council for Health, Physical Education and Recreation; 1987.
40 Auerbach RP, Stewart JG, Johnson SL. Impulsivity and suicidality in adolescent inpatients. J Abnorm Child Psychol. 2017 Jan;45(1):91–103. doi: 10.1007/s10802-016-0146-8. PMID: 27025937.27025937
41 Kasen S, Cohen P, Chen H. Developmental course of impulsivity and capability from age 10 to age 25 as related to trajectory of suicide attempt in a community cohort. Suicide Life Threat Behav. 2011 Apr;41(2):180–92. doi: 10.1111/j.1943-278X.2011.00017.x. PMID: 21342218.21342218
42 Stewart JG, Esposito EC, Glenn CR, . Adolescent self-injurers: comparing non-ideators, suicide ideators, and suicide attempters. J Psychiatr Res. 2017 Jan;84:105–12. doi: 10.1016/j.jpsychires.2016.09.031. PMID: 27716512.27716512
43 Mann JJ. Neurobiology of suicidal behaviour. Nat Rev Neurosci. 2003 Oct;4(10):819–28. doi: 10.1038/nrn1220. PMID: 14523381.14523381
44 Xiao Y, Romanelli M, Lindsey MA. A latent class analysis of health lifestyles and suicidal behaviors among US adolescents. J Affect Disord. 2019 Aug 1;255:116–26. doi: 10.1016/j.jad.2019.05.031. PMID: 31150941.31150941
45 Essau CA, Lewinsohn PM, Lim JX, . Incidence, recurrence and comorbidity of anxiety disorders in four major developmental stages. J Affect Disord. 2018 Mar 1;228:248–53. doi: 10.1016/j.jad.2017.12.014. PMID: 29304469.29304469
46 Beesdo-Baum K, Hofler M, Gloster AT, . The structure of common mental disorders: a replication study in a community sample of adolescents and young adults. Int J Methods Psychiatr Res. 2009 Dec;18(4):204–20. doi: 10.1002/mpr.293. PMID: 20024895.20024895
47 Tandon M, Cardeli E, Luby J. Internalizing disorders in early childhood: a review of depressive and anxiety disorders. Child Adolesc Psychiatr Clin N Am. 2009 Jul;18(3):593–610. doi: 10.1016/j.chc.2009.03.004. PMID: 19486840.19486840
48 Beesdo K, Bittner A, Pine DS, . Incidence of social anxiety disorder and the consistent risk for secondary depression in the first three decades of life. Arch Gen Psychiatry. 2007 Aug;64(8):903–12. doi: 10.1001/archpsyc.64.8.903. PMID: 17679635.17679635
49 Ehrenreich JT, Santucci LC, Weiner CL. Separation anxiety disorder in youth: Phenomenology, assessment, and treatment. Behavioral Psychology. 2008;16(3):389–412. PMID: 2014-29992-003.
50 Riordan DM, Singhal D. Anxiety-related disorders: an overview. J Paediatr Child Health. 2018 Oct;54(10):1104–9. doi: 10.1111/jpc.14167. PMID: 30294986.30294986
51 Beesdo K, Pine DS, Lieb R, . Incidence and risk patterns of anxiety and depressive disorders and categorization of generalized anxiety disorder. Arch Gen Psychiatry. 2010 Jan;67(1):47–57. doi: 10.1001/archgenpsychiatry.2009.177. PMID: 20048222.20048222
52 Yap MB, Jorm AF. Parental factors associated with childhood anxiety, depression, and internalizing problems: a systematic review and meta-analysis. J Affect Disord. 2015 Apr 1;175:424–40. doi: 10.1016/j.jad.2015.01.050. PMID: 25679197.25679197
53 Lemstra M, Neudorf C, D’Arcy C, . A systematic review of depressed mood and anxiety by SES in youth aged 10–15 years. Can J Public Health. 2008;99(2):125–9.18457287
54 Knappe S, Beesdo-Baum K, Fehm L, . Social fear and social phobia types among community youth: differential clinical features and vulnerability factors. J Psychiatr Res. 2011 Jan;45(1):111–20. doi: 10.1016/j.jpsychires.2010.05.002. PMID: 20684833.20684833
55 Laurin CA, Hottenga JJ, Willemsen G, . Genetic analyses benefit from using less heterogeneous phenotypes: an illustration with the hospital anxiety and depression scale (HADS). Genet Epidemiol. 2015 May;39(4):317–24. doi: 10.1002/gepi.21897. PMID: 25832296.25832296
56 Kagan J, Reznick JS, Snidman N. Biological bases of childhood shyness. Science. 1988 Apr 8;240(4849):167–71. doi: 10.1126/science.3353713. PMID: 3353713.3353713
57 Hyde JS, Mezulis AH, Abramson LY. The ABCs of depression: integrating affective, biological, and cognitive models to explain the emergence of the gender difference in depression. Psychol Rev. 2008 Apr;115(2):291–313. doi: 10.1037/0033-295x.115.2.291. PMID: 18426291.18426291
58 Sheftall AH, Asti L, Horowitz LM, . Suicide in elementary school-aged children and early adolescents. Pediatrics. 2016 Oct;138(4)doi: 10.1542/peds.2016-0436. PMID: 27647716.27647716
59 Beesdo-Baum K, Knappe S, Asselmann E, . The ‘Early Developmental Stages of Psychopathology (EDSP) study’: a 20-year review of methods and findings. Soc Psychiatry Psychiatr Epidemiol. 2015 Jun;50(6):851–66. doi: 10.1007/s00127-015-1062-x. PMID: 25982479.25982479
60 Bogels SM, Brechman-Toussaint ML. Family issues in child anxiety: attachment, family functioning, parental rearing and beliefs. Clin Psychol Rev. 2006 Nov;26(7):834–56. doi: 10.1016/j.cpr.2005.08.001. PMID: 16473441.16473441
61 Bufferd SJ, Dougherty LR, Carlson GA, . Parent-reported mental health in preschoolers: findings using a diagnostic interview. Compr Psychiatry. 2011 Jul–Aug;52(4):359–69. doi: 10.1016/j.comppsych.2010.08.006. PMID: 21683173.21683173
62 Bufferd SJ, Dougherty LR, Carlson GA, . Psychiatric disorders in preschoolers: continuity from ages 3 to 6. Am J Psychiatry. 2012 Nov;169(11):1157–64. doi: 10.1176/appi.ajp.2012.12020268. PMID: 23128922.23128922
63 Luby JL, Gaffrey MS, Tillman R, . Trajectories of preschool disorders to full DSM depression at school age and early adolescence: continuity of preschool depression. Am J Psychiatry. 2014 Jul;171(7):768–76. doi: 10.1176/appi.ajp.2014.13091198. PMID: 24700355.24700355
64 Costello EJ, Copeland W, Angold A. Trends in psychopathology across the adolescent years: what changes when children become adolescents, and when adolescents become adults? J Child Psychol Psychiatry. 2011 Oct;52(10):1015–25. doi: 10.1111/j.1469-7610.2011.02446.x. PMID: 21815892.21815892
65 Rohde P, Lewinsohn PM, Klein DN, . Key characteristics of major depressive disorder occurring in childhood, adolescence, emerging adulthood, adulthood. Clin Psychol Sci. 2013 Jan;1(1)doi: 10.1177/2167702612457599. PMID: 24273703.24273703
66 Hankin BL. Depression from childhood through adolescence: risk mechanisms across multiple systems and levels of analysis. Curr Opin Psychol. 2015 Aug;4:13–20. doi: 10.1016/j.copsyc.2015.01.003. PMID: 25692174.25692174
67 Costello EJ, Mustillo S, Erkanli A, . Prevalence and development of psychiatric disorders in childhood and adolescence. Arch Gen Psychiatry. 2003 Aug;60(8):837–44. doi: 10.1001/archpsyc.60.8.837. PMID: 12912767.12912767
68 Wilson S, Hicks BM, Foster KT, . Age of onset and course of major depressive disorder: associations with psychosocial functioning outcomes in adulthood. Psychol Med. 2015 Feb;45(3):505–14. doi: 10.1017/s0033291714001640. PMID: 25007761.25007761
69 Franz L, Angold A, Copeland W, . Preschool anxiety disorders in pediatric primary care: prevalence and comorbidity. J Am Acad Child Adolesc Psychiatry. 2013 Dec;52(12):1294–303.e1. doi: 10.1016/j.jaac.2013.09.008. PMID: 24290462.24290462
70 Cicchetti D, Lynch M. Toward an ecological/transactional model of community violence and child maltreatment: consequences for children’s development. Psychiatry. 1993 Feb;56(1):96–118. doi: 10.1080/00332747.1993.11024624. PMID: 8488217.8488217
71 Shortt AL, Spence SH. Risk and protective factors for depression in youth. Behav Change. 2006;23(1):1–30.
72 Sullivan PF, Neale MC, Kendler KS. Genetic epidemiology of major depression: review and meta-analysis. Am J Psychiatry. 2000 Oct;157(10):1552–62. doi: 10.1176/appi.ajp.157.10.1552. PMID: 11007705.11007705
73 Saluja G, Iachan R, Scheidt PC, . Prevalence of and risk factors for depressive symptoms among young adolescents. Arch Pediatr Adolesc Med. 2004 Aug;158(8):760–5. doi: 10.1001/archpedi.158.8.760. PMID: 15289248.15289248
74 Shore L, Toumbourou JW, Lewis AJ, . Longitudinal trajectories of child and adolescent depressive symptoms and their predictors–a systematic review and meta-analysis. Child Adolesc Ment Health. 2018;23(2):107–20.32677332
75 Nanni V, Uher R, Danese A. Childhood maltreatment predicts unfavorable course of illness and treatment outcome in depression: a meta-analysis. Am J Psychiatry. 2012 Feb;169(2):141–51. doi: 10.1176/appi.ajp.2011.11020335. PMID: 22420036.22420036
76 Maughan B, Collishaw S, Stringaris A. Depression in childhood and adolescence. J Can Acad Child Adolesc Psychiatry. 2013 Feb;22(1):35–40. PMID: 23390431.23390431
77 Thapar A, Collishaw S, Pine DS, . Depression in adolescence. Lancet. 2012 Mar 17;379(9820):1056–67. doi: 10.1016/s0140-6736(11)60871-4. PMID: 22305766.22305766
78 Hariri AR, Mattay VS, Tessitore A, . Serotonin transporter genetic variation and the response of the human amygdala. Science. 2002 Jul 19;297(5580):400–3. doi: 10.1126/science.1071829. PMID: 12130784.12130784
79 Heron M. Deaths: leading causes for 2019 National Center for Health Statistics. Hyattsville, MD: 2021.
80 Centers for Disease Control and Prevention. WISQARS. https://wisqars.cdc.gov/data/explore-data/home.
81 Sheftall AH, Vakil F, Ruch DA, . Black youth suicide: investigation of current trends and precipitating circumstances. J Am Acad Child Adolesc Psychiatry. 2021doi: 10.1016/j.jaac.2021.08.021. PMID: 34509592.34509592
82 Ream GL. What’s unique about lesbian, gay, bisexual, and transgender (LGBT) youth and young adult suicides? Findings from the National Violent Death Reporting System. J Adolesc Health. 2019;64(5):602–7. doi: 10.1016/j.jadohealth.2018.10.303. PMID: 2019-05735-001.30711364
83 Kann L, McManus T, Harris WA, . Youth risk behavior surveillance—United States, 2017. MMWR Surveill Summ. 2018;67(8):1.
84 The Trevor Project. 2021 National Survey on LGBTQ Youth Mental Health The Trevor Project. West Hollywood, CA: 2021.
85 Toomey RB, Syvertsen AK, Shramko M. Transgender adolescent suicide behavior. Pediatrics. 2018 Oct;142(4)doi: 10.1542/peds.2017-4218. PMID: 30206149.30206149
86 Basile K, Clayton H, DeGue S, . Interpersonal violence victimization among high school students—Youth Risk Behavior Survey, United States, 2019. MMWR Supplements. 2020;69(1):28.32817605
87 DeVille DC, Whalen D, Breslin FJ, . Prevalence and family-related factors associated with suicidal ideation, suicide attempts, and self-injury in children aged 9 to 10 years. JAMA Netw Open. 2020 Feb 5;3(2):e1920956. doi: 10.1001/jamanetworkopen.2019.20956. PMID: 32031652.32031652
88 Jones JD, Boyd RC, Calkins ME, . Parent-adolescent agreement about adolescents’ suicidal thoughts. Pediatrics. 2019 Feb;143(2)doi: 10.1542/peds.2018-1771. PMID: 30642950.30642950
89 U.S. Department of Commerce. 2020 National Survey of Children’s Health: topical frequencies U.S. Census Bureau. Washington, DC: 2021.
90 Ghandour RM, Sherman LJ, Vladutiu CJ, . Prevalence and treatment of depression, anxiety, and conduct problems in US children. J Pediatr. 2019 Mar;206:256–67.e3. doi: 10.1016/j.jpeds.2018.09.021. PMID: 30322701.30322701
91 Substance Abuse and Mental Health Services Administration. Key substance use and mental health indicators in the United States: results from the 2019 National Survey on Drug Use and Health Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration. Rockville, MD: 2020.
92 Manzo K, Tiesman H, Stewart J, . A comparison of risk factors associated with suicide ideation/attempts in American Indian and white youth in Montana. Arch Suicide Res. 2015;19(1):89–102. doi: 10.1080/13811118.2013.840254. PMID: 25010183.25010183
93 Bridge JA, Horowitz LM, Fontanella CA, . Age-related racial disparity in suicide rates among US youths from 2001 through 2015. JAMA Pediatr. 2018 Jul 1;172(7):697–9. doi: 10.1001/jamapediatrics.2018.0399. PMID: 29799931.29799931
94 Bridge JA, Asti L, Horowitz LM, . Suicide trends among elementary school–aged children in the United States from 1993 to 2012. JAMA Pediatr. 2015;169(7):673–7. doi: 10.1001/jamapediatrics.2015.0465.25984947
95 Lindsey MA, Sheftall AH, Xiao Y, . Trends of suicidal behaviors among high school students in the United States: 1991–2017. Pediatrics. 2019;144(5)doi: 10.1542/peds.2019-1187. PMID: 2019-77312-001.
96 Louie P, Wheaton B. Prevalence and patterning of mental disorders through adolescence in 3 cohorts of black and white Americans. Am J Epidemiol. 2018 Nov 1;187(11):2332–8. doi: 10.1093/aje/kwy144. PMID: 29992256.29992256
97 Alegría M, Green JG, McLaughlin KA, . Disparities in child and adolescent mental health and mental health services in the US. New York, NY: William T. Grant Foundation. 2015.
98 Ettman CK, Cohen GH, Abdalla SM, . Do assets explain the relation between race/ethnicity and probable depression in U.S. adults? PLoS One. 2020;15(10):e0239618. doi: 10.1371/journal.pone.0239618. PMID: 33006988.33006988
99 Assari S, Caldwell CH. High risk of depression in high-income African American boys. J Racial Ethn Health Disparities. 2018 Aug;5(4):808–19. doi: 10.1007/s40615-017-0426-1. PMID: 28842841.28842841
100 Assari S, Gibbons FX, Simons R. Depression among black youth; interaction of class and place. Brain Sci. 2018 Jun 12;8(6)doi: 10.3390/brainsci8060108. PMID: 29895752.29895752
101 Yeh M, McCabe K, Hurlburt M, . Referral sources, diagnoses, and service types of youth in public outpatient mental health care: a focus on ethnic minorities. J Behav Health Serv Res. 2002 Feb;29(1):45–60. doi: 10.1007/bf02287831. PMID: 11840904.11840904
102 Bailey RK, Mokonogho J, Kumar A. Racial and ethnic differences in depression: current perspectives. Neuropsychiatr Dis Treat. 2019;15:603–9. doi: 10.2147/ndt.S128584. PMID: 30863081.30863081
103 Fadus MC, Ginsburg KR, Sobowale K, . Unconscious bias and the diagnosis of disruptive behavior disorders and ADHD in African American and Hispanic youth. Acad Psychiatry. 2020 Feb;44(1):95–102. doi: 10.1007/s40596-019-01127-6. PMID: 31713075.31713075
104 Liang J, Matheson BE, Douglas JM. Mental health diagnostic considerations in racial/ethnic minority youth. J Child Fam Stud. 2016 Jun;25(6):1926–40. doi: 10.1007/s10826-015-0351-z. PMID: 27346929.27346929
105 Bernard DL, Calhoun CD, Banks DE, . Making the “C-ACE” for a Culturally-informed Adverse Childhood Experiences framework to understand the pervasive mental health impact of racism on black youth. J Child Adolesc Trauma. 2021 Jun;14(2):233–47. doi: 10.1007/s40653-020-00319-9. PMID: 33986909.33986909
106 Lu W. Treatment for adolescent depression: national patterns, temporal trends, and factors related to service use across settings. J Adolesc Health. 2020;67(3):401–8. doi: 10.1016/j.jadohealth.2020.02.019. PMID: 32331929.32331929
107 Lu W. Child and adolescent mental disorders and health care disparities: results from the National Survey of Children’s Health, 2011-2012. J Health Care Poor Underserved. 2017;28(3):988–1011. doi: 10.1353/hpu.2017.0092. PMID: 28804073.28804073
108 Merikangas KR, He JP, Burstein M, . Service utilization for lifetime mental disorders in U.S. adolescents: results of the National Comorbidity Survey-Adolescent Supplement (NCS-A). J Am Acad Child Adolesc Psychiatry. 2011 Jan;50(1):32–45. doi: 10.1016/j.jaac.2010.10.006. PMID: 21156268.21156268
109 Howell E, McFeeters J. Children’s mental health care: differences by race/ethnicity in urban/rural areas. J Health Care Poor Underserved. 2008 Feb;19(1):237–47. doi: 10.1353/hpu.2008.0008. PMID: 18263999.18263999
110 Emergency TaskForce on Black Youth Suicide and Mental Health. Ring the alarm: The crisis of Black youth suicide in America. 2019. https://watsoncoleman.house.gov/uploadedfiles/full_taskforce_report.pdf
111 Pavkov TW, Travis L, Fox KA, . Tribal youth victimization and delinquency: analysis of Youth Risk Behavior Surveillance Survey data. Cultur Divers Ethnic Minor Psychol. 2010 Apr;16(2):123–34. doi: 10.1037/a0018664. PMID: 20438150.20438150
112 Garcia JL. Historical trauma and American Indian/Alaska Native youth mental health development and delinquency. New Dir Child Adolesc Dev. 2020 Jan;2020(169):41–58. doi: 10.1002/cad.20332. PMID: 32324321.32324321
113 Kessler RC, Avenevoli S, Ries Merikangas K. Mood disorders in children and adolescents: an epidemiologic perspective. Biol Psychiatry. 2001 Jun 15;49(12):1002–14. doi: 10.1016/s0006-3223(01)01129-5. PMID: 11430842.11430842
114 Kramer T, Iliffe S, Murray E, . Which adolescents attend the GP? Br J Gen Pract. 1997 May;47(418):327. PMID: 9219415.9219415
115 Kramer T, Garralda ME. Psychiatric disorders in adolescents in primary care. Br J Psychiatry. 1998 Dec;173:508–13. doi: 10.1192/bjp.173.6.508. PMID: 9926080.9926080
116 Yates P, Kramer T, Garralda E. Depressive symptoms amongst adolescent primary care attenders. Levels and associations. Soc Psychiatry Psychiatr Epidemiol. 2004 Jul;39(7):588–94. doi: 10.1007/s00127-004-0792-y. PMID: 15243698.15243698
117 Ahmedani BK, Simon GE, Stewart C, . Health care contacts in the year before suicide death. J Gen Intern Med. 2014 Jun;29(6):870–7. doi: 10.1007/s11606-014-2767-3. PMID: 24567199.24567199
118 Martini R, Hilt R, Marx L, . Best principles for integration of child psychiatry into the pediatric health home. Washington, DC: American Academy of Child & Adolescent Psychiatry; 2012.
119 O’Connor E, Gaynes BN, Burda BU, . Screening for and treatment of suicide risk relevant to primary care: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013 May 21;158(10):741–54. doi: 10.7326/0003-4819-158-10-201305210-00642. PMID: 23609101.23609101
120 Substance Abuse and Mental Health Services Administration. Treatment for suicidal ideation, self-harm, and suicide attempts among youth National Mental Health and Substance Use Policy Laboratory. Substance Abuse and Mental Health Services Administration. Rockville, MD: 2020.
121 Robinson J, Bailey E, Witt K, . What works in youth suicide prevention? A systematic review and meta-analysis. EClinicalMedicine. 2018 Oct–Nov;4–5:52–91. doi: 10.1016/j.eclinm.2018.10.004. PMID: 31193651.31193651
122 Morken IS, Dahlgren A, Lunde I, . The effects of interventions preventing self-harm and suicide in children and adolescents: an overview of systematic reviews. F1000Research. 2020;8doi: 10.12688/f1000research.19506.2.
123 Wang Z, Whiteside S, Sim L, . Anxiety in children Comparative Effectiveness Reviews No. 192. (Prepared by the Mayo Clinic Evidence-based Practice Center under Contract No. 290-2015-00013-I.). Report No.: 17-EHC023-EF. Rockville, MD: Agency for Healthcare Research and Quality; Aug 2017. www.effectivehealthcare.ahrq.gov/reports/final.cfm
124 Wehry AM, Beesdo-Baum K, Hennelly MM, . Assessment and treatment of anxiety disorders in children and adolescents. Curr Psychiatry Rep. 2015 Jul;17(7):52. doi: 10.1007/s11920-015-0591-z. PMID: 25980507.25980507
125 Connolly SD, Suarez L, Sylvester C. Assessment and treatment of anxiety disorders in children and adolescents. Curr Psychiatry Rep. 2011 Apr;13(2):99–110. doi: 10.1007/s11920-010-0173-z. PMID: 21225481.21225481
126 Comer JS, Hong N, Poznanski B, . Evidence base update on the treatment of early childhood anxiety and related problems. J Clin Child Adolesc Psychol. 2019 Jan–Feb;48(1):1–15. doi: 10.1080/15374416.2018.1534208. PMID: 30640522.30640522
127 Higa-McMillan CK, Francis SE, Rith-Najarian L, . Evidence base update: 50 years of research on treatment for child and adolescent anxiety. J Clin Child Adolesc Psychol. 2016;45(2):91–113. doi: 10.1080/15374416.2015.1046177. PMID: 26087438.26087438
128 March J, Silva S, Petrycki S, . Fluoxetine, cognitive-behavioral therapy, and their combination for adolescents with depression: Treatment for Adolescents With Depression Study (TADS) randomized controlled trial. JAMA. 2004 Aug 18;292(7):807–20. doi: 10.1001/jama.292.7.807. PMID: 15315995.15315995
129 Pampallona S, Bollini P, Tibaldi G, . Combined pharmacotherapy and psychological treatment for depression: a systematic review. Arch Gen Psychiatry. 2004 Jul;61(7):714–9. doi: 10.1001/archpsyc.61.7.714. PMID: 15237083.15237083
130 Ruch DA, Sheftall AH, Schlagbaum P, . Trends in suicide among youth aged 10 to 19 years in the United States, 1975 to 2016. JAMA network open. 2019;2(5):e193886–e.31099867
131 David-Ferdon C, Kaslow NJ. Evidence-based psychosocial treatments for child and adolescent depression. J Clin Child Adolesc Psychol. 2008 Jan;37(1):62–104. doi: 10.1080/15374410701817865. PMID: 18444054.18444054
132 Merry SN, Stasiak K, Shepherd M, . The effectiveness of SPARX, a computerised self help intervention for adolescents seeking help for depression: randomised controlled non-inferiority trial. BMJ. 2012;344:e2598. doi: 10.1136/bmj.e2598. PMID: 22517917.22517917
133 Mufson L, Sills R. Interpersonal psychotherapy for depressed adolescents (IPT-A): an overview. Nord J Psychiatry. 2006;60(6):431–7. doi: 10.1080/08039480601022397. PMID: 17162450.17162450
134 Cheung AH, Zuckerbrot RA, Jensen PS, . Guidelines for adolescent depression in primary care (GLAD-PC): II. treatment and ongoing management. Pediatrics. 2007 Nov;120(5):e1313–26. doi: 10.1542/peds.2006-1395. PMID: 17974724.17974724
135 Centers for Medicare & Medicaid Services. Antidepressant medications: U.S. Food and Drug Administration-approved indications and dosages for use in pediatric patients. Baltimore, MD: Centers for Medicare & Medicaid Services; 2015. https://www.cms.gov/Medicare-Medicaid-Coordination/Fraud-Prevention/Medicaid-Integrity-Education/Pharmacy-Education-Materials/Downloads/ad-pediatric-dosingchart11-14.pdf. Accessed March 3, 2020.
136 Romer D, McIntosh M. Chapter 31. The role of primary care physicians in detection and treatment of adolescent mental health problems. In: Evans DL, Foa EB, Gur RE, Hendin H, O’Brien CP, Romer D, ., eds. Treating and preventing adolescent mental health disorders: what we know and what we don’t know: A research agenda for improving the mental health of our youthd. 2nd ed. New York, NY: Oxford University Press; 2012.
137 Zenlea IS, Milliren CE, Mednick L, . Depression screening in adolescents in the United States: a national study of ambulatory office-based practice. Acad Pediatr. 2014 Mar–Apr;14(2):186–91. doi: 10.1016/j.acap.2013.11.006. PMID: 24602582.24602582
138 Deepa L Sekhar, Djibril M Ba, Guodong Liu, . Major depressive disorder screening remains low even among privately insured adolescents. J Pediatr. 2019;204:203–7. doi: 10.1016/j.jpeds.2018.07.086.30244990
139 Habis A, Tall L, Smith J, . Pediatric emergency medicine physicians’ current practices and beliefs regarding mental health screening. Pediatr Emerg Care. 2007 Jun;23(6):387–93. doi: 10.1097/01.pec.0000278401.37697.79. PMID: 17572523.17572523
140 Frankenfield DL, Keyl PM, Gielen A, . Adolescent patients--healthy or hurting? Missed opportunities to screen for suicide risk in the primary care setting. Arch Pediatr Adolesc Med. 2000 Feb;154(2):162–8. doi: 10.1001/archpedi.154.2.162. PMID: 10665603.10665603
141 American Academy of Family Physicians. Summary of recommendations for clinical preventive services. Leawood, KS: American Academy of Family Physicians; 2017. https://www.aafp.org/dam/AAFP/documents/patient_care/clinical_recommendations/cps-recommendations.pdf. Accessed April 19, 2021.
142 American Academy of Pediatrics. Screening for suicide risk in clinical practice. American Academy of Pediatrics; 2022. https://www.aap.org/en/patient-care/blueprint-for-youth-suicide-prevention/strategies-for-clinical-settings-for-youth-suicide-prevention/screening-for-suicide-risk-in-clinical-practice/. Accessed April 8, 2022.
143 American Academy of Child and Adolescent Psychiatry. Policy statement on suicide prevention. Washington, DC: American Academy of Child and Adolescent Psychiatry; 2019. Accessed April 19, 2021.
144 The Joint Commission. National Patient Safety Goal for suicide prevention. 2019. https://www.jointcommission.org/-/media/tjc/documents/standards/r3-reports/r3_18_suicide_prevention_hap_bhc_cah_11_4_19_final1.pdf
145 Walter HJ, Bukstein OG, Abright AR, . Clinical practice guideline for the assessment and treatment of children and adolescents with anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2020 Oct;59(10):1107–24. doi: 10.1016/j.jaac.2020.05.005. PMID: 32439401.32439401
146 National Institute for Health and Care Excellence (NICE). Assessment of children and young people with possible social anxiety disorder. London: National Institute for Health and Care Excellence; 2013. https://www.nice.org.uk/guidance/cg159/chapter/1-Recommendations#identification-and-assessment-of-children-and-young-people. Accessed April 29, 2021.
147 Zuckerbrot RA, Cheung A, Jensen PS, . Guidelines for Adolescent Depression in Primary Care (GLAD-PC): part I. Practice preparation, identification, assessment, and initial management. Pediatrics. 2018 Mar;141(3)doi: 10.1542/peds.2017-4081. PMID: 29483200.29483200
148 Beck A, LeBlanc JC, Morissette K, . Screening for depression in children and adolescents: a protocol for a systematic review update. Syst Rev. 2021 Jan 12;10(1):24. doi: 10.1186/s13643-020-01568-3. PMID: 33436094.33436094
149 MacMillan HL, Patterson CJ, Wathen CN, . Screening for depression in primary care: recommendation statement from the Canadian Task Force on Preventive Health Care. CMAJ. 2005 Jan 4;172(1):33–5. doi: 10.1503/cmaj.1030823. PMID: 15632399.15632399
150 Weitzman C, Wegner L. Promoting optimal development: screening for behavioral and emotional problems. Pediatrics. 2015 Feb;135(2):384–95. doi: 10.1542/peds.2014-3716. PMID: 25624375.25624375
151 American College of Obstetricians and Gynecologists (ACOG). Mental health disorders in adolescents. Washington, DC: American College of Obstetricians and Gynecologists; 2017. https://www.acog.org/clinical/clinical-guidance/committee-opinion/articles/2017/07/mental-health-disorders-in-adolescents. Accessed April 19, 2021.
152 Forman-Hoffman V, McClure E, McKeeman J, . Screening for major depressive disorder in children and adolescents: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2016 Mar 1;164(5):342–9. doi: 10.7326/m15-2259. PMID: 26857836.26857836
153 Viswanathan M, Kennedy SM, McKeeman J, . Treatment of depression in children and adolescents: a systematic review AHRQ Comparative Effectiveness Review Number 224. AHRQ Publication No. 20-EHC005-EF. Rockville (MD): Agency for Healthcare Research and Quality; April 2020.
154 United Nations Development Programme. Human development report 2019. New York, NY: United Nations Development Programme; 2019. http://hdr.undp.org/sites/default/files/hdr2019.pdf. Accessed April 6, 2021.
155 Sterne JAC, Savovic J, Page MJ, . RoB 2: a revised tool for assessing risk of bias in randomised trials. BMJ. 2019 Aug 28;366:l4898. doi: 10.1136/bmj.l4898. PMID: 31462531.31462531
156 Sterne JA, Hernan MA, Reeves BC, . ROBINS-I: a tool for assessing risk of bias in non-randomised studies of interventions. BMJ. 2016 Oct 12;355:i4919. doi: 10.1136/bmj.i4919. PMID: 27733354.27733354
157 Whiting P, Savovic J, Higgins JP, . ROBIS: a new tool to assess risk of bias in systematic reviews was developed. J Clin Epidemiol. 2016 Jan;69:225–34. doi: 10.1016/j.jclinepi.2015.06.005. PMID: 26092286.26092286
158 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011 Oct 18;155(8):529–36. doi: 10.7326/0003-4819-155-8-201110180-00009. PMID: 22007046.22007046
159 U.S. Preventive Services Task Force. Appendix VI. Criteria for assessing internal validity of individual studies. In Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. https://www.uspreventiveservicestaskforce.org/Page/Name/appendix-vi-criteria-for-assessing-internal-validity-of-individual-studies.
160 West SL, Gartlehner G, Mansfield AJ, . Comparative effectiveness review methods: clinical heterogeneity. 10-EHC070-EF. Rockville, MD: Agency for Healthcare Research and Quality; Sep 2010. https://www.ncbi.nlm.nih.gov/pubmed/21433337
161 Deeks JJ, Higgins JPT, Altman DG, . Chapter 10: analysing data and undertaking meta-analyses. 10.10 Heterogeneity. 10.10.1 What is heterogeneity? London: Cochrane Training. https://training.cochrane.org/handbook/current/chapter-10#section-10-10. Accessed April 6, 2021.
162 Borenstein M, Hedges L, Higgins J, . Comprehensive meta-analysis version 3. Englewood, NJ: Biostat; 2013.
163 Arendt K, Thastum M, Hougaard E. Efficacy of a Danish version of the Cool Kids program: a randomized wait-list controlled trial. Acta Psychiatr Scand. 2016;133(2):109–21. doi: 10.1111/acps.12448. PMID: 2016-00713-002.26016532
164 Asarnow JR, Hughes JL, Babeva KN, . Cognitive-behavioral family treatment for suicide attempt prevention: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2017 Jun;56(6):506–14. doi: 10.1016/j.jaac.2017.03.015. PMID: 28545756.28545756
165 Asbrand J, Heinrichs N, Schmidtendorf S, . Experience versus report: where are changes seen after exposure-based cognitive-behavioral therapy? A randomized controlled group treatment of childhood social anxiety disorder. Child Psychiatry Hum Dev. 2020 Jan 20doi: 10.1007/s10578-019-00954-w. PMID: 31960175.31960175
166 Bailey KA, Chavira DA, Stein MT, . Brief measures to screen for social phobia in primary care pediatrics. J Pediatr Psychol. 2006 Jun;31(5):512–21. doi: 10.1093/jpepsy/jsj044. PMID: 16034004.16034004
167 Barrett PM, Dadds MR, Rapee RM. Family treatment of childhood anxiety: a controlled trial. J Consult Clin Psychol. 1996 Apr;64(2):333–42. doi: 10.1037//0022-006x.64.2.333. PMID: 8871418.8871418
168 Birmaher B, Axelson DA, Monk K, . Fluoxetine for the treatment of childhood anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2003 Apr;42(4):415–23. doi: 10.1097/01.Chi.0000037049.04952.9f. PMID: 12649628.12649628
169 Black B, Uhde TW. Treatment of elective mutism with fluoxetine: a double-blind, placebo-controlled study. J Am Acad Child Adolesc Psychiatry. 1994 Sep;33(7):1000–6. doi: 10.1097/00004583-199409000-00010. PMID: 7961338.7961338
170 Canals J, Blade J, Carbajo G, . The Beck Depression Inventory: psychometric characteristics and usefulness in nonclinical adolescents. Eur J Psychol Assess. 2001;17(1):63–8.
171 Canals J, Hernández-Martínez C, Cosi S, . Examination of a cutoff score for the Screen for Child Anxiety Related Emotional Disorders (SCARED) in a non-clinical Spanish population. J Anxiety Disord. 2012 Dec;26(8):785–91. doi: 10.1016/j.janxdis.2012.07.008. PMID: 23023158.23023158
172 Christensen KS, Haugen W, Sirpal MK, . Diagnosis of depressed young people—criterion validity of WHO-5 and HSCL-6 in Denmark and Norway. Fam Pract. 2015;32(3):359–63. doi: 10.1093/fampra/cmv011. PMID: 2015-24236-019.25800246
173 Cipriani A, Zhou X, Del Giovane C, . Comparative efficacy and tolerability of antidepressants for major depressive disorder in children and adolescents: a network meta-analysis. Lancet. 2016 Aug 27;388(10047):881–90. doi: 10.1016/s0140-6736(16)30385-3. PMID: 27289172.27289172
174 Clarke GN, Rohde P, Lewinsohn PM, . Cognitive-behavioral treatment of adolescent depression: efficacy of acute group treatment and booster sessions. J Am Acad Child Adolesc Psychiatry. 1999 Mar;38(3):272–9. doi: 10.1097/00004583-199903000-00014. PMID: 10087688.10087688
175 Clarke G, Debar L, Lynch F, . A randomized effectiveness trial of brief cognitive-behavioral therapy for depressed adolescents receiving antidepressant medication. J Am Acad Child Adolesc Psychiatry. 2005 Sep;44(9):888–98. PMID: 16113617.16113617
176 Clarke G, DeBar LL, Pearson JA, . Cognitive behavioral therapy in primary care for youth declining antidepressants: a randomized trial. Pediatrics. 2016 May;137(5). doi: 10.1542/peds.2015-1851. PMID: 27244782.27244782
177 Cobham VE, Filus A, Sanders MR. Working with parents to treat anxiety-disordered children: a proof of concept RCT evaluating Fear-less Triple P. Behav Res Ther. 2017 Aug;95:128–38. doi: 10.1016/j.brat.2017.06.004. PMID: 28641122.28641122
178 Cornacchio D, Furr JM, Sanchez AL, . Intensive group behavioral treatment (IGBT) for children with selective mutism: a preliminary randomized clinical trial. J Consult Clin Psychol. 2019 Aug;87(8):720–33. doi: 10.1037/ccp0000422. PMID: 31294589.31294589
179 Cottrell DJ, Wright-Hughes A, Collinson M, . Effectiveness of systemic family therapy versus treatment as usual for young people after self-harm: a pragmatic, phase 3, multicentre, randomised controlled trial. Lancet Psychiatry. 2018 Mar;5(3):203–16. doi: 10.1016/s2215-0366(18)30058-0. PMID: 29449180.29449180
180 Cottrell DJ, Wright-Hughes A, Collinson M, . A pragmatic randomised controlled trial and economic evaluation of family therapy versus treatment as usual for young people seen after second or subsequent episodes of self-harm: the Self-Harm Intervention - Family Therapy (SHIFT) trial. Health Technol Assess. 2018 Mar;22(12):1–222. doi: 10.3310/hta22120. PMID: 29532784.29532784
181 Cottrell DJ, Wright-Hughes A, Eisler I, . Longer-term effectiveness of systemic family therapy compared with treatment as usual for young people after self-harm: an extended follow up of pragmatic randomised controlled trial. EClinicalMedicine. 2020 Jan;18:100246. doi: 10.1016/j.eclinm.2019.100246. PMID: 31956857.31956857
182 Diamond GS, Wintersteen MB, Brown GK, . Attachment-based family therapy for adolescents with suicidal ideation: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2010 Feb;49(2):122–31. doi: 10.1097/00004583-201002000-00006. PMID: 20215934.20215934
183 Donovan CL, March S. Online CBT for preschool anxiety disorders: a randomised control trial. Behav Res Ther. 2014 Jul;58:24–35. doi: 10.1016/j.brat.2014.05.001. PMID: 24927471.24927471
184 Ehrenreich-May J, Rosenfield D, Queen AH, . An initial waitlist-controlled trial of the unified protocol for the treatment of emotional disorders in adolescents. J Anxiety Disord. 2017 Mar;46:46–55. doi: 10.1016/j.janxdis.2016.10.006. PMID: 27771133.27771133
185 Emslie GJ, Ventura D, Korotzer A, . Escitalopram in the treatment of adolescent depression: a randomized placebo-controlled multisite trial. J Am Acad Child Adolesc Psychiatry. 2009 Jul;48(7):721–9. doi: 10.1097/CHI.0b013e3181a2b304. PMID: 19465881.19465881
186 Findling RL, Robb A, Bose A. Escitalopram in the treatment of adolescent depression: a randomized, double-blind, placebo-controlled extension trial. J Child Adolesc Psychopharmacol. 2013 Sep;23(7):468–80. doi: 10.1089/cap.2012.0023. PMID: 24041408.24041408
187 Fristad MA, Vesco AT, Young AS, . Pilot randomized controlled trial of omega-3 and individual-family psychoeducational psychotherapy for children and adolescents with depression. J Clin Child Adolesc Psychol. 2019;48(sup1):S105–s18. doi: 10.1080/15374416.2016.1233500. PMID: 27819485.27819485
188 Garcia-Lopez LJ, Sáez-Castillo AJ, Beidel D, . Brief measures to screen for social anxiety in adolescents. J Dev Behav Pediatr. 2015 Oct;36(8):562–8. doi: 10.1097/dbp.0000000000000213. PMID: 26349070.26349070
189 Garrison CZ, Addy CL, Jackson KL, . The CES-D as a screen for depression and other psychiatric disorders in adolescents. J Am Acad Child Adolesc Psychiatry. 1991 Jul;30(4):636–41. doi: 10.1097/00004583-199107000-00017. PMID: 1890099.1890099
190 Ginsburg GS, Pella JE, Pikulski PJ, . School-Based Treatment for Anxiety Research Study (STARS): a randomized controlled effectiveness trial. J Abnorm Child Psychol. 2020 Mar;48(3):407–17. doi: 10.1007/s10802-019-00596-5. PMID: 31749064.31749064
191 Green JM, Wood AJ, Kerfoot MJ, . Group therapy for adolescents with repeated self harm: randomised controlled trial with economic evaluation. BMJ. 2011 Apr 1;342:d682. doi: 10.1136/bmj.d682. PMID: 21459975.21459975
192 Griffiths H, Duffy F, Duffy L, . Efficacy of mentalization-based group therapy for adolescents: the results of a pilot randomised controlled trial. BMC Psychiatry. 2019 Jun 6;19(1):167. doi: 10.1186/s12888-019-2158-8. PMID: 31170947.31170947
193 Hazell PL, Martin G, McGill K, . Group therapy for repeated deliberate self-harm in adolescents: failure of replication of a randomized trial. J Am Acad Child Adolesc Psychiatry. 2009 Jun;48(6):662–70. doi: 10.1097/CHI.0b013e3181aOacec. PMID: 19454922.19454922
194 Hill RM, Pettit JW. Pilot randomized controlled trial of LEAP: a selective preventive intervention to reduce adolescents’ perceived burdensomeness. J Clin Child Adolesc Psychol. 2019;48:S45–S56. doi: 10.1080/15374416.2016.1188705. PMID: CN-01916512.27532425
195 Hirshfeld-Becker DR, Masek B, Henin A, . Cognitive behavioral therapy for 4- to 7-year-old children with anxiety disorders: a randomized clinical trial. J Consult Clin Psychol. 2010 Aug;78(4):498–510. doi: 10.1037/a0019055. PMID: 20658807.20658807
196 Holmes MC, Donovan CL, Farrell LJ, . The efficacy of a group-based, disorder-specific treatment program for childhood GAD--a randomized controlled trial. Behav Res Ther. 2014 Oct;61:122–35. doi: 10.1016/j.brat.2014.08.002. PMID: 25193003.25193003
197 Hooven C, Walsh E, Pike KC, . Promoting CARE: including parents in youth suicide prevention. Fam Community Health. 2012 Jul–Sep;35(3):225–35. doi: 10.1097/FCH.0b013e318250bcf9. PMID: 22617413.22617413
198 Ishikawa SI, Kikuta K, Sakai M, . A randomized controlled trial of a bidirectional cultural adaptation of cognitive behavior therapy for children and adolescents with anxiety disorders. Behav Res Ther. 2019 Sep;120:103432. doi: 10.1016/j.brat.2019.103432. PMID: 31299461.31299461
199 Johnson JG, Harris ES, Spitzer RL, . The patient health questionnaire for adolescents: validation of an instrument for the assessment of mental disorders among adolescent primary care patients. J Adolesc Health. 2002;30(3):196–204. doi: 10.1016/S1054-139X(01)00333-0. PMID: 2002-02042-008.11869927
200 King CA, Klaus N, Kramer A, . The Youth-Nominated Support Team-Version II for suicidal adolescents: a randomized controlled intervention trial. J Consult Clin Psychol. 2009 Oct;77(5):880–93. doi: 10.1037/a0016552. PMID: 19803568.19803568
201 King CA, Arango A, Kramer A, . Association of the youth-nominated support team intervention for suicidal adolescents with 11- to 14-year mortality outcomes: secondary analysis of a randomized clinical trial. JAMA Psychiatry. 2019 May 1;76(5):492–8. doi: 10.1001/jamapsychiatry.2018.4358. PMID: 30725077.30725077
202 King CA, Gipson PY, Horwitz AG, . Teen options for change: an intervention for young emergency patients who screen positive for suicide risk. Psychiatr Serv. 2015 Jan 1;66(1):97–100. doi: 10.1176/appi.ps.201300347. PMID: 25321886.25321886
203 Lau W-y, Chan CK-y, Li JC-h, . Effectiveness of group cognitive-behavioral treatment for childhood anxiety in community clinics. Behav Res Ther. 2010;48(11):1067–77. doi: 10.1016/j.brat.2010.07.007. PMID: 2010-16900-001.20696421
204 Luby JL, Barch DM, Whalen D, . A randomized controlled trial of parent-child psychotherapy targeting emotion development for early childhood depression. Am J Psychiatry. 2018 Nov 1;175(11):1102–10. doi: 10.1176/appi.ajp.2018.18030321. PMID: 29921144.29921144
205 Hoyniak CP, Whalen DJ, Barch D, . Sleep problems in preschool-onset major depressive disorder: the effect of treatment with parent–child interaction therapy-emotion development. Eur Child Adolesc Psychiatry. 2020doi: 10.1007/s00787-020-01641-1. PMID: CN-02193938.
206 Lyneham HJ, Rapee RM. Evaluation of therapist-supported parent-implemented CBT for anxiety disorders in rural children. Behav Res Ther. 2006;44(9):1287–300. doi: 10.1016/j.brat.2005.09.009. PMID: 2006-09968-007.16313883
207 March J, Silva S, Petrycki S, . Fluoxetine, cognitive-behavioral therapy, and their combination for adolescents with depression: Treatment for Adolescents With Depression Study (TADS) randomized controlled trial. JAMA. 2004 Aug 18;292(7):807–20. doi: 10.1001/jama.292.7.807. PMID: 15315995.15315995
208 Curry J, Rohde P, Simons A, . Predictors and moderators of acute outcome in the Treatment for Adolescents with Depression Study (TADS). J Am Acad Child Adolesc Psychiatry. 2006 Dec;45(12):1427–39. doi: 10.1097/01.chi.0000240838.78984.e2. PMID: 17135988.17135988
209 Emslie G, Kratochvil C, Vitiello B, . Treatment for Adolescents with Depression Study (TADS): safety results. J Am Acad Child Adolesc Psychiatry. 2006 Dec;45(12):1440–55. doi: 10.1097/01.chi.0000240840.63737.1d. PMID: 17135989.17135989
210 Kennard B, Silva S, Vitiello B, . Remission and residual symptoms after short-term treatment in the Treatment of Adolescents with Depression Study (TADS). J Am Acad Child Adolesc Psychiatry. 2006 Dec;45(12):1404–11. doi: 10.1097/01.chi.0000242228.75516.21. PMID: 17135985.17135985
211 Vitiello B, Rohde P, Silva S, . Functioning and quality of life in the Treatment for Adolescents with Depression Study (TADS). J Am Acad Child Adolesc Psychiatry. 2006 Dec;45(12):1419–26. doi: 10.1097/01.chi.0000242229.52646.6e. PMID: 17135987.17135987
212 Mehlum L, Tørmoen AJ, Ramberg M, . Dialectical behavior therapy for adolescents with repeated suicidal and self-harming behavior: a randomized trial. J Am Acad Child Adolesc Psychiatry. 2014 Oct;53(10):1082–91. doi: 10.1016/j.jaac.2014.07.003. PMID: 25245352.25245352
213 Mehlum L, Ramberg M, Tørmoen AJ, . Dialectical behavior therapy compared with enhanced usual care for adolescents with repeated suicidal and self-harming behavior: outcomes over a one-year follow-up. J Am Acad Child Adolesc Psychiatry. 2016 Apr;55(4):295–300. doi: 10.1016/j.jaac.2016.01.005. PMID: 27015720.27015720
214 Mehlum L, Ramleth RK, Tørmoen AJ, . Long term effectiveness of dialectical behavior therapy versus enhanced usual care for adolescents with self-harming and suicidal behavior. J Child Psychol Psychiatry. 2019 Oct;60(10):1112–22. doi: 10.1111/jcpp.13077. PMID: 31127612.31127612
215 Haga E, Aas E, Grøholt B, . Cost-effectiveness of dialectical behaviour therapy vs. enhanced usual care in the treatment of adolescents with self-harm. Child Adolesc Psychiatry Ment Health. 2018;12:22. doi: 10.1186/s13034-018-0227-2. PMID: 29743941.29743941
216 Mufson L, Dorta KP, Wickramaratne P, . A randomized effectiveness trial of interpersonal psychotherapy for depressed adolescents. Arch Gen Psychiatry. 2004 Jun;61(6):577–84. doi: 10.1001/archpsyc.61.6.577. PMID: 15184237.15184237
217 McGlinchey EL, Reyes-Portillo JA, Turner JB, . Innovations in Practice: The relationship betweensleep disturbances, depression, and interpersonal functioning in treatment for adolescent depression. Child Adolesc Ment Health. 2017 May;22(2):96–9. doi: 10.1111/camh.12176. PMID: 28947892.28947892
218 Muris P, Merckelbach H, Kindt M, . The utility of Screen for Child Anxiety Related Emotional Disorders (SCARED) as a tool for identifying children at high risk for prevalent anxiety disorders. Anxiety, Stress & Coping: An International Journal. 2001;14(3):265–83. doi: 10.1080/10615800108248357. PMID: 2002-00834-002.
219 O’Connor S, Ferguson E, Carney T, . The development and evaluation of the paediatric index of emotional distress (PI-ED). Soc Psychiatry Psychiatr Epidemiol. 2016 Jan;51(1):15–26. doi: 10.1007/s00127-015-1134-y. PMID: 26687238.26687238
220 Öst L-G, Cederlund R, Reuterskiöld L. Behavioral treatment of social phobia in youth: does parent education training improve the outcome? Behav Res Ther. 2015;67:19–29. doi: 10.1016/j.brat.2015.02.001. PMID: 2015-12473-003.25727679
221 Ougrin D, Boege I, Stahl D, . Randomised controlled trial of therapeutic assessment versus usual assessment in adolescents with self-harm: 2-year follow-up. Arch Dis Child. 2013 Oct;98(10):772–6. doi: 10.1136/archdischild-2012-303200. PMID: 23709314.23709314
222 Ougrin D, Zundel T, Ng A, . Trial of therapeutic assessment in London: randomised controlled trial of therapeutic assessment versus standard psychosocial assessment in adolescents presenting with self-harm. Arch Dis Child. 2011 Feb;96(2):148–53. doi: 10.1136/adc.2010.188755. PMID: 21030367.21030367
223 Patton GC, Coffey C, Posterino M, . A computerised screening instrument for adolescent depression: population-based validation and application to a two-phase case-control study. Soc Psychiatry Psychiatr Epidemiol. 1999 Mar;34(3):166–72. PMID: 10327843.10327843
224 Perrin S, Bevan D, Payne S, . GAD-specific cognitive behavioral treatment for children and adolescents: a pilot randomized controlled trial. Cognit Ther Res. 2019doi: 10.1007/s10608-019-10020-3. PMID: CN-01941262.
225 Pine DS, Walkup JT, Labellarte MJ, . Fluvoxamine for the treatment of anxiety disorders in children and adolescents. N Engl J Med. 2001;344(17):1279–85. doi: 10.1056/NEJM200104263441703. PMID: CN-00343009.11323729
226 Walkup JT, Labellarte MJ, Riddle MA, . Searching for moderators and mediators of pharmacological treatment effects in children and adolescents with anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2003 Jan;42(1):13–21. doi: 10.1097/00004583-200301000-00006. PMID: 12500072.12500072
227 Ginsburg GS, Riddle MA, Davies M. Somatic symptoms in children and adolescents with anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2006 Oct;45(10):1179–87. doi: 10.1097/01.chi.0000231974.43966.6e. PMID: 17003663.17003663
228 Reinblatt SP, dosReis S, Walkup JT, . Activation adverse events induced by the selective serotonin reuptake inhibitor fluvoxamine in children and adolescents. J Child Adolesc Psychopharmacol. 2009;19(2):119–26. doi: 10.1089/cap.2008.040. PMID: 2009-05505-003.19364290
229 Pineda J, Dadds MR. Family intervention for adolescents with suicidal behavior: a randomized controlled trial and mediation analysis. J Am Acad Child Adolesc Psychiatry. 2013 Aug;52(8):851–62. doi: 10.1016/j.jaac.2013.05.015. PMID: 23880495.23880495
230 Queen AH, Ehrenreich-May J, Hershorin ER. Preliminary validation of a screening tool for adolescent panic disorder in pediatric primary care clinics. Child Psychiatry Hum Dev. 2012 Apr;43(2):171–83. doi: 10.1007/s10578-011-0256-z. PMID: 21938484.21938484
231 Ranta K, Kaltiala-Heino R, Rantanen P, . Screening social phobia in adolescents from general population: the validity of the Social Phobia Inventory (SPIN) against a clinical interview. Eur Psychiatry. 2007 May;22(4):244–51. doi: 10.1016/j.eurpsy.2006.12.002. PMID: 17346941.17346941
232 Ranta K, Kaltiala-Heino R, Rantanen P, . The Mini-Social Phobia Inventory: psychometric properties in an adolescent general population sample. Compr Psychiatry. 2012 Jul;53(5):630–7. doi: 10.1016/j.comppsych.2011.07.007. PMID: 21944882.21944882
233 Richardson LP, Ludman E, McCauley E, . Collaborative care for adolescents with depression in primary care: a randomized clinical trial. JAMA. 2014 Aug 27;312(8):809–16. doi: 10.1001/jama.2014.9259. PMID: 25157724.25157724
234 Rivera-Riquelme M, Piqueras JA, Cuijpers P. The Revised Mental Health Inventory-5 (MHI-5) as an ultra-brief screening measure of bidimensional mental health in children and adolescents. Psychiatry Res. 2019 Apr;274:247–53. doi: 10.1016/j.psychres.2019.02.045. PMID: 30818147.30818147
235 Roberts RE, Lewinsohn PM, Seeley JR. Screening for adolescent depression: a comparison of depression scales. J Am Acad Child Adolesc Psychiatry. 1991 Jan;30(1):58–66. doi: 10.1097/00004583-199101000-00009. PMID: 2005065.2005065
236 Rossouw TI, Fonagy P. Mentalization-based treatment for self-harm in adolescents: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2012 Dec;51(12):1304–13.e3. doi: 10.1016/j.jaac.2012.09.018. PMID: 23200287.23200287
237 Rudy BM, Zavrou S, Johnco C, . Parent-led exposure therapy: a pilot study of a brief behavioral treatment for anxiety in young children. J Child Fam Stud. 2017;26(9):2475–84. doi: 10.1007/s10826-017-0772-y. PMID: 2017-22955-001.
238 Rynn MA, Siqueland L, Rickels K. Placebo-controlled trial of sertraline in the treatment of children with generalized anxiety disorder. Am J Psychiatry. 2001 Dec;158(12):2008–14. doi: 10.1176/appi.ajp.158.12.2008. PMID: 11729017.11729017
239 Salzer S, Stefini A, Kronmüller KT, . Cognitive-behavioral and psychodynamic therapy in adolescents with social anxiety disorder: a multicenter randomized controlled trial. Psychother Psychosom. 2018;87(4):223–33. doi: 10.1159/000488990. PMID: 29895001.29895001
240 Sánchez-García R, Olivares Rodríguez J. Effectiveness of a program for early detection/intervention in children/adolescents with generalized social phobia. Anales de Psicología. 2009.
241 Shortt AL, Barrett PM, Fox TL. Evaluating the FRIENDS program: a cognitive-behavioral group treatment for anxious children and their parents. J Clin Child Psychol. 2001 Dec;30(4):525–35. doi: 10.1207/s15374424jccp3004_09. PMID: 11708240.11708240
242 Stjerneklar S, Hougaard E, McLellan LF, . A randomized controlled trial examining the efficacy of an internet-based cognitive behavioral therapy program for adolescents with anxiety disorders. PLoS One. 2019;14(9):e0222485. doi: 10.1371/journal.pone.0222485. PMID: 31532802.31532802
243 Strawn JR, Prakash A, Zhang Q, . A randomized, placebo-controlled study of duloxetine for the treatment of children and adolescents with generalized anxiety disorder. J Am Acad Child Adolesc Psychiatry. 2015 Apr;54(4):283–93. doi: 10.1016/j.jaac.2015.01.008. PMID: 25791145.25791145
244 Strawn JR, Mills JA, Schroeder H, . Escitalopram in adolescents with generalized anxiety disorder: a double-blind, randomized, placebo-controlled study. J Clin Psychiatry. 2020 Aug 25;81(5)doi: 10.4088/JCP.20m13396. PMID: 32857933.32857933
245 Tang TC, Jou SH, Ko CH, . Randomized study of school-based intensive interpersonal psychotherapy for depressed adolescents with suicidal risk and parasuicide behaviors. Psychiatry Clin Neurosci. 2009 Aug;63(4):463–70. doi: 10.1111/j.1440-1819.2009.01991.x. PMID: 19531111.19531111
246 Thirlwall K, Cooper PJ, Karalus J, . Treatment of child anxiety disorders via guided parent-delivered cognitive-behavioural therapy: randomised controlled trial. Br J Psychiatry. 2013;203(6):436–44. doi: 10.1192/bjp.bp.113.126698. PMID: CN-00910881.23969483
247 Thompson EA, Eggert LL. Using the suicide risk screen to identify suicidal adolescents among potential high school dropouts. J Am Acad Child Adolesc Psychiatry. 1999 Dec;38(12):1506–14. doi: 10.1097/00004583-199912000-00011. PMID: 10596250.10596250
248 Topooco N, Berg M, Johansson S, . Chat- and internet-based cognitive-behavioural therapy in treatment of adolescent depression: randomised controlled trial. BJPsych Open. 2018 Jul;4(4):199–207. doi: 10.1192/bjo.2018.18. PMID: 29988969.29988969
249 Topooco N, Byléhn S, Dahlström Nysäter E, . Evaluating the efficacy of internet-delivered cognitive behavioral therapy blended with synchronous chat sessions to treat adolescent depression: randomized controlled trial. J Med Internet Res. 2019 Nov 1;21(11):e13393. doi: 10.2196/13393. PMID: 31682572.31682572
250 Tsai CF, Wang SJ, Juang KD, . Use of the Chinese (Taiwan) version of the Social Phobia Inventory (SPIN) among early adolescents in rural areas: reliability and validity study. J Chin Med Assoc. 2009 Aug;72(8):422–9. doi: 10.1016/s1726-4901(09)70399-5. PMID: 19686998.19686998
251 Villabø MA, Narayanan M, Compton SN, . Cognitive–behavioral therapy for youth anxiety: an effectiveness evaluation in community practice. J Consult Clin Psychol. 2018;86(9):751–64. doi: 10.1037/ccp0000326. PMID: 2018-41322-004.30138014
252 Wagner KD, Jonas J, Findling RL, . A double-blind, randomized, placebo-controlled trial of escitalopram in the treatment of pediatric depression. J Am Acad Child Adolesc Psychiatry. 2006 Mar;45(3):280–8. doi: 10.1097/01.chi.0000192250.38400.9e. PMID: 16540812.16540812
253 Waite P, Marshall T, Creswell C. A randomized controlled trial of internet-delivered cognitive behaviour therapy for adolescent anxiety disorders in a routine clinical care setting with and without parent sessions. Child Adolesc Ment Health. 2019. doi: 10.1111/camh.12311. PMID: CN-01917999.
254 Walkup JT, Albano AM, Piacentini J, . Cognitive behavioral therapy, sertraline, or a combination in childhood anxiety. N Engl J Med. 2008 Dec 25;359(26):2753–66. doi: 10.1056/NEJMoa0804633. PMID: 18974308.18974308
255 Albano AM, Comer JS, Compton SN, . Secondary outcomes from the child/adolescent anxiety multimodal study: implications for clinical practice. Evid Based Pract Child Adolesc Ment Health. 2018;3(1):30–41. doi: 10.1080/23794925.2017.1399485. PMID: 30906874.30906874
256 Taylor JH, Lebowitz ER, Jakubovski E, . Monotherapy insufficient in severe anxiety? Predictors and moderators in the child/adolescent anxiety multimodal study. J Clin Child Adolesc Psychol. 2018 Mar–Apr;47(2):266–81. doi: 10.1080/15374416.2017.1371028. PMID: 28956620.28956620
257 Compton SN, Peris TS, Almirall D, . Predictors and moderators of treatment response in childhood anxiety disorders: results from the CAMS trial. J Consult Clin Psychol. 2014 Apr;82(2):212–24. doi: 10.1037/a0035458. PMID: 24417601.24417601
258 Caporino NE, Read KL, Shiffrin N, . Sleep-related problems and the effects of anxiety treatment in children and adolescents. J Clin Child Adolesc Psychol. 2017 Sep–Oct;46(5):675–85. doi: 10.1080/15374416.2015.1063429. PMID: 26467211.26467211
259 Sanchez AL, Comer JS, Coxe S, . The effects of youth anxiety treatment on school impairment: differential outcomes across CBT, sertraline, and their combination. Child Psychiatry Hum Dev. 2019 Dec;50(6):940–9. doi: 10.1007/s10578-019-00896-3. PMID: 31087216.31087216
260 Rynn MA, Walkup JT, Compton SN, . Child/adolescent anxiety multimodal study: evaluating safety. J Am Acad Child Adolesc Psychiatry. 2015 Mar;54(3):180–90. doi: 10.1016/j.jaac.2014.12.015. PMID: 25721183.25721183
261 Gordon-Hollingsworth AT, Becker EM, Ginsburg GS, . Anxiety disorders in Caucasian and African American children: a comparison of clinical characteristics, treatment process variables, and treatment outcomes. Child Psychiatry Hum Dev. 2015;46(5):643–55. doi: 10.1007/s10578-014-0507-x. PMID: 2014-43106-001.25293650
262 Ginsburg GS, Kendall PC, Sakolsky D, . Remission after acute treatment in children and adolescents with anxiety disorders: findings from the CAMS. J Consult Clin Psychol. 2011 Dec;79(6):806–13. doi: 10.1037/a0025933. PMID: 22122292.22122292
263 Weersing VR, Brent DA, Rozenman MS, . Brief behavioral therapy for pediatric anxiety and depression in primary care: a randomized clinical trial. JAMA Psychiatry. 2017 Jun 1;74(6):571–8. doi: 10.1001/jamapsychiatry.2017.0429. PMID: 28423145.28423145
264 Brent DA, Porta G, Rozenman MS, . Brief behavioral therapy for pediatric anxiety and depression in primary care: a follow-up. J Am Acad Child Adolesc Psychiatry. 2019 Jul 3doi: 10.1016/j.jaac.2019.06.009. PMID: 31278996.31278996
265 Wood A, Trainor G, Rothwell J, . Randomized trial of group therapy for repeated deliberate self-harm in adolescents. J Am Acad Child Adolesc Psychiatry. 2001 Nov;40(11):1246–53. doi: 10.1097/00004583-200111000-00003. PMID: 11699797.11699797
266 Lindqvist K, Mechler J, Carlbring P, . Affect-focused psychodynamic internet-based therapy for adolescent depression: randomized controlled trial. J Med Internet Res. 2020;22(3):e18047. doi: 10.2196/18047. PMID: CN-02099453.32224489
267 Gould MS, Marrocco FA, Kleinman M, . Evaluating iatrogenic risk of youth suicide screening programs: a randomized controlled trial. JAMA. 2005 Apr 6;293(13):1635–43. doi: 10.1001/jama.293.13.1635. PMID: 15811983.15811983
268 Robinson J, Pan Yuen H, Martin C, . Does screening high school students for psychological distress, deliberate self-harm, or suicidal ideation cause distress--and is it acceptable? An Australian-based study. Crisis. 2011;32(5):254–63. doi: 10.1027/0227-5910/a000087. PMID: 21940259.21940259
269 Muris P, Steerneman P. The revised version of the Screen for Child Anxiety Related Emotional Disorders (SCARED–R): first evidence for its reliability and validity in a clinical sample. Br J Clin Psychol. 2001;40(1):35–44. doi: 10.1348/014466501163463. PMID: 2001-06105-003.11317947
270 O’Connor E, Senger CA, Henninger M, . US Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Interventions to Prevent Perinatal Depression: A Systematic Evidence Review for the US Preventive Services Task Force. Agency for Healthcare Research and Quality; 2019.
271 Mammarella IC, Donolato E, Caviola S, . Anxiety profiles and protective factors: a latent profile analysis in children. Pers Individ Dif. 2018;124:201–8. doi: 10.1016/j.paid.2017.12.017. PMID: 2018-01016-035.
272 Beck AT, Ward CH, Mendelson M, . An inventory for measuring depression. Arch Gen Psychiatry. 1961 Jun;4:561–71. doi: 10.1001/archpsyc.1961.01710120031004. PMID: 13688369.13688369
273 Radloff LS. The CES-D Scale: a self-report depression scale for research in the general population. Appl Psychol Meas. 1977;1(3):385–401. doi: 10.1177/014662167700100306.
274 Fillenbaum GG, Burchett BM, Blazer DG. Identifying a National Death Index match. Am J Epidemiol. 2009 Aug 15;170(4):515–8. doi: 10.1093/aje/kwp155. PMID: 19567777.19567777
275 Osimo EF, Stochl J, Zammit S, . Longitudinal population subgroups of CRP and risk of depression in the ALSPAC birth cohort. Compr Psychiatry. 2020;96doi: 10.1016/j.comppsych.2019.152143. PMID: 2020-00258-001.
276 van Gastel W, Ferdinand RF. Screening capacity of the Multidimensional Anxiety Scale for Children (MASC) for DSM-IV anxiety disorders. Depress Anxiety. 2008;25(12):1046–52. doi: 10.1002/da.20452. PMID: 18833579.18833579
277 Wagner KD, Robb AS, Findling RL, . A randomized, placebo-controlled trial of citalopram for the treatment of major depression in children and adolescents. Am J Psychiatry. 2004 Jun;161(6):1079–83. doi: 10.1176/appi.ajp.161.6.1079. PMID: 15169696.15169696
278 Jacobson NS, Truax P. Clinical significance: a statistical approach to defining meaningful change in psychotherapy research. J Consult Clin Psychol. 1991;59(1):12–9. doi: 10.1037/0022-006x.59.1.12.2002127
279 Johnco CJ, Salloum A, Lewin AB, . Refining clinical judgment of treatment response and symptom remission identification in childhood anxiety using a signal detection analysis on the Pediatric Anxiety Rating Scale. J Child Adolesc Psychopharmacol. 2015 Nov;25(9):674–83. doi: 10.1089/cap.2015.0102. PMID: 26579629.26579629
280 Vitiello B, Silva SG, Rohde P, . Suicidal events in the Treatment for Adolescents With Depression Study (TADS). J Clin Psychiatry. 2009 Apr 21;70(5):741–7. doi: 10.4088/jcp.08m04607. PMID: 19552869.19552869
281 Horowitz LM, Bridge JA, Teach SJ, . Ask Suicide-Screening Questions (ASQ): a brief instrument for the pediatric emergency department. Arch Pediatr Adolesc Med. 2012 Dec;166(12):1170–6. doi: 10.1001/archpediatrics.2012.1276. PMID: 23027429.23027429
282 Aguinaldo LD, Sullivant S, Lanzillo EC, . Validation of the ask suicide-screening questions (ASQ) with youth in outpatient specialty and primary care clinics. Gen Hosp Psychiatry. 2021 Jan–Feb;68:52–8. doi: 10.1016/j.genhosppsych.2020.11.006. PMID: 33310014.33310014
283 The Joint Commission. Suicide prevention. 2021. https://www.jointcommission.org/resources/patient-safety-topics/suicide-prevention/.
284 National Institutes of Health. Ask Suicide-Screening Questions (ASQ) toolkit. no date. https://www.nimh.nih.gov/research/research-conducted-at-nimh/asq-toolkit-materials.
285 Rinke ML, Bundy DG, Stein REK, . Increasing recognition and diagnosis of adolescent depression: Project RedDE: a cluster randomized trial. Pediatr Qual Saf. 2019 Sep–Oct;4(5):e217. doi: 10.1097/pq9.0000000000000217. PMID: 31745520.31745520
286 eCQI. Preventive care and screening: screening for depression and follow-up plan. eCQI; n.d. https://ecqi.healthit.gov/ecqm/ep/2019/cms002v8. Accessed April 30, 2021.
287 Quality Payment Program. MIPS explore measures & activities. Baltimore, MD: Centers for Medicare & Medicaid Services; n.d. https://qpp.cms.gov/mips/explore-measures?tab=qualityMeasures&py=2021. Accessed April 30, 2021.
288 NCQA. HEDIS depression measures for electronic clinical data. NCQA; n.d. https://www.ncqa.org/hedis/the-future-of-hedis/hedis-depression-measures-for-electronic-clinical-data/. Accessed April 30, 2021.
289 Pfizer. Patient health questionnaire (PHQ) screeners. Pfizer; n.d. https://www.phqscreeners.com/select-screener. Accessed April 30, 2021.
290 Aboustate N, Raven M, Klau J, . 28 reanalysis of the treatment for adolescents with depression study (TADS) under the restoring invisible and abandoned trials initiative (RIAT). BMJ Evidence-Based Medicine. 2019;24:A20–A1. doi: 10.1136/bmjebm-2019-POD.42.
291 Doshi P, Dickersin K, Healy D, . Restoring invisible and abandoned trials: a call for people to publish the findings. BMJ. 2013 Jun 13;346:f2865. doi: 10.1136/bmj.f2865. PMID: 23766480.23766480
292 U.S. Food and Drug Administration. Suicidality in children and adolescents being treated with antidepressant medications. Silver Spring, MD: Food and Drug Administration; 2018. https://www.fda.gov/drugs/postmarket-drug-safety-information-patients-and-providers/suicidality-children-and-adolescents-being-treated-antidepressant-medications. Accessed February 15, 2021.
293 Hammad TA, Laughren T, Racoosin J. Suicidality in pediatric patients treated with antidepressant drugs. Arch Gen Psychiatry. 2006 Mar;63(3):332–9. doi: 10.1001/archpsyc.63.3.332. PMID: 16520440.16520440
294 Paauw C, de Roos C, Tummers J, . Effectiveness of trauma-focused treatment for adolescents with major depressive disorder. Eur J Psychotraumatol. 2019;10(1):1682931. doi: 10.1080/20008198.2019.1682931. PMID: 31762948.31762948
295 McCrory E, De Brito SA, Viding E. The link between child abuse and psychopathology: a review of neurobiological and genetic research. J R Soc Med. 2012 Apr;105(4):151–6. doi: 10.1258/jrsm.2011.110222. PMID: 22532655.22532655
296 Horowitz LM, Mournet AM, Lanzillo E, . Screening pediatric medical patients for suicide risk: is depression screening enough? J Adolesc Health. 2021 Jun;68(6):1183–8. doi: 10.1016/j.jadohealth.2021.01.028. PMID: 33712380.33712380
297 Mournet AM, Bridge JA, Ross A, . A comparison of suicide attempt histories of pediatric and adult medical inpatients and implications for screening. Arch Suicide Res. 2021 Jun 8:1–15. doi: 10.1080/13811118.2021.1931596. PMID: 34101537.34101537
298 Ford I, Norrie J. Pragmatic trials. N Engl J Med. 2016;375(5):454–63. doi: 10.1056/NEJMra1510059. PMID: 27518663.27518663
299 Asarnow JR, Jaycox LH, Duan N, . Effectiveness of a quality improvement intervention for adolescent depression in primary care clinics: a randomized controlled trial. JAMA. 2005 Jan 19;293(3):311–9. doi: 10.1001/jama.293.3.311. PMID: 15657324.15657324
300 Asarnow JR, Jaycox LH, Tang L, . Long-term benefits of short-term quality improvement interventions for depressed youths in primary care. Am J Psychiatry. 2009 Sep;166(9):1002–10. doi: 10.1176/appi.ajp.2009.08121909. PMID: 19651711.19651711
301 McCauley E, Berk MS, Asarnow JR, . Efficacy of dialectical behavior therapy for adolescents at high risk for suicide: a randomized clinical trial. JAMA Psychiatry. 2018 Aug 1;75(8):777–85. doi: 10.1001/jamapsychiatry.2018.1109. PMID: 29926087.29926087
302 Miller IW, Camargo CA, Jr., Arias SA, . Suicide prevention in an emergency department population: the ED-SAFE Study. JAMA Psychiatry. 2017 Jun 1;74(6):563–70. doi: 10.1001/jamapsychiatry.2017.0678. PMID: 28456130.28456130
303 National Institute for Health and Care Excellence. Depression in children and young people: identifification and management. NICE guideline [NG134]. United Kingdom: National Institute for Health and Care Excellence; 2019. https://www.nice.org.uk/guidance/ng134/chapter/Recommendations. Accessed August 12, 2019.
304 Kliem S, Lohmann A, Mößle T, . Psychometric properties and measurement invariance of the Beck hopelessness scale (BHS): results from a German representative population sample. BMC Psychiatry. 2018 Apr 25;18(1):110. doi: 10.1186/s12888-018-1646-6. PMID: 29699522.29699522
305 King CA, Hill RM, Wynne HA, . Adolescent suicide risk screening: the effect of communication about type of follow-up on adolescents’ screening responses. J Clin Child Adolesc Psychol. 2012;41(4):508–15. doi: 10.1080/15374416.2012.680188. PMID: 22540534.22540534
306 Erford BT, Jackson J, Bardhoshi G, . Selecting suicide ideation assessment instruments: a meta-analytic review. Measurement and Evaluation in Counseling and Development. 2017;51(1):42–59. doi: 10.1080/07481756.2017.1358062.
307 Reynolds WM, Mazza JJ. Assessment of suicidal ideation in inner-city children and young adolescents: reliability and validity of the suicidal ideation questionnaire-JR. School Psych Rev. 1999;28(1):17–30.
308 Gowers SG, Harrington RC, Whitton A, . Health of the Nation Outcome Scales for Children and Adolescents (HoNOSCA). Glossary for HoNOSCA score sheet. Br J Psychiatry. 1999 May;174:428–31. doi: 10.1192/bjp.174.5.428. PMID: 10616610.10616610
309 NSW Department of Health - MH-Oat Project. Childrens Global Assessment Scale (CGAS). St. Leonards, Australia: NSW Department of Health; 2002. https://www.thereachinstitute.org/images/CGAS.pdf. Accessed April 19, 2021.
310 Silverman WK, Albano AM. The anxiety disorders interview schedule for children for DSM-IV: clinician manual (child and parent versions). San Antonio, TX: The Psychological Corporation; 1996.
311 Carruthers S, Kent R, Hollocks MJ, . Brief report: testing the psychometric properties of the Spence Children’s Anxiety Scale (SCAS) and the Screen for Child Anxiety Related Emotional Disorders (SCARED) in Autism Spectrum Disorder. J Autism Dev Disord. 2020 Jul;50(7):2625–32. doi: 10.1007/s10803-018-3774-8. PMID: 30334126.30334126
312 Bunnell BE, Beidel DC, Liu L, . The SPAIC-11 and SPAICP-11: two brief child- and parent-rated measures of social anxiety. J Anxiety Disord. 2015 Dec;36:103–9. doi: 10.1016/j.janxdis.2015.10.002. PMID: 26500188.26500188
313 Busner J, Targum SD. The clinical global impressions scale: applying a research tool in clinical practice. Psychiatry (Edgmont). 2007 Jul;4(7):28–37. PMID: 20526405.20526405
314 Gilroy S. The Revised Children’s Manifest Anxiety Scale (RCMAS). “What I think and feel”. n.d. http://www.clintools.com/victims/resources/assessment/affect/rcmas.html. Accessed April 19, 2021.
315 The pediatric anxiety rating scale (PARS): development and psychometric properties. J Am Acad Child Adolesc Psychiatry. 2002 Sep;41(9):1061–9. doi: 10.1097/00004583-200209000-00006. PMID: 12218427.12218427
316 Ginsburg GS, Keeton CP, Drazdowski TK, . The utility of clinicians ratings of anxiety using the Pediatric Anxiety Rating Scale (PARS). Child & Youth Care Forum. 2011;40(2):93–105. doi: 10.1007/s10566-010-9125-3. PMID: 2011-06151-001.
317 Sparse whole-genome sequencing identifies two loci for major depressive disorder. Nature. 2015 Jul 30;523(7562):588–91. doi: 10.1038/nature14659. PMID: 26176920.26176920
318 Langley AK, Falk A, Peris T, . The child anxiety impact scale: examining parent- and child-reported impairment in child anxiety disorders. J Clin Child Adolesc Psychol. 2014;43(4):579–91. doi: 10.1080/15374416.2013.817311. PMID: 23915200.23915200
319 Evans R, Thirlwall K, Cooper P, . Using symptom and interference questionnaires to identify recovery among children with anxiety disorders. Psychol Assess. 2017 Jul;29(7):835–43. doi: 10.1037/pas0000375. PMID: 27845527.27845527
320 Psychiatry & Behavioral Health Learning Network. Beck Depression Inventory-II (BDI-II). Psychiatry & Behavioral Health Learning Network; 1996. https://www.psychcongress.com/saundras-corner/scales-screenersdepression/beck-depression-inventory-ii-bdi-ii. Accessed April 26, 2021.
321 Mayes TL, Bernstein IH, Haley CL, . Psychometric properties of the Children’s Depression Rating Scale-Revised in adolescents. J Child Adolesc Psychopharmacol. 2010 Dec;20(6):513–6. doi: 10.1089/cap.2010.0063. PMID: 21186970.21186970