# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Iris Mabry-Hernandez, MD, AHRQ Medical Officer; Tracy Wolf, MD, MPH, Scientific Director, U.S. Preventive Services Task Force Division, AHRQ; current and former members of the U.S. Preventive Services Task Force; expert peer reviewers Gregory Simon, MD, MPH; Joan Asarnow, PhD; Natalie Cort, PhD; and Raquel Halfond, PhD; Centers for Disease Control and Prevention and other Federal partner reviewers; and RTI International–University of North Carolina EPC staff: Carol Woodell, BSPH; Candi Wines, MPH; Nila A. Sathe, MA, MLIS; Christiane Voisin, MSLS; Sharon Barrell, MA; and Loraine Monroe.