# Chapter 4 Discussion

## Summary of Evidence

We summarize the evidence, including strength of evidence ratings, by KQ in Table 18.

Table 18 Summary of Outcomes

Key Question | No. of Studies; Study Designs; (No. of Participants) | Summary of Findings | Consistency and Precision | Limitations | Strength of Evidence | Applicability
KQ 1 Benefits of screening | None | Not applicable | Not applicable | Not applicable | Insufficient | NA
KQ 2 Accuracy of screening | Suicide: 1 study (580) | Varies by reference standard; Sensitivity range: 0.87 to 0.91; Specificity: 0.60 | Consistency unknown, imprecise | Unclear whether thresholds were established a priori or whether interviewers were blinded; single study | Insufficient | Participants were potential high school dropouts; instrument was a 20-item screener embedded into a longer questionnaire so unclear whether feasible in primary care
KQ 2 Accuracy of screening | Anxiety: 10 studies^166,^ ^171,^ ^188,^ ^199,^ ^218,^ ^219,^ ^230–232,^ ^250^ (3,260) | Varies by screener, threshold, and condition; Sensitivity range: 0.34 to 1.00; Specificity range: 0.47 to 0.99 | Consistency unknown, imprecise | No replication of results for specific thresholds and screeners, unclear whether thresholds were established a priori or whether index and reference standard results were blinded | Low to moderate (varies by instrument) | Participants were primarily adolescents, but children were included in 4 studies. Applicable to both primary care and school-based settings. A variety of different screeners, only two are widely used in practice for detecting anxiety (i.e., SCARED and SPIN)
KQ 2 Accuracy of screening | Depression: 7 studies^170,^ ^172,^ ^189,^ ^199,^ ^219,^ ^223,^ ^235^ (3,316) | Varies by screener and threshold; Sensitivity (excluding outliers) range: 0.59 to 0.94; Specificity range (excluding outliers): 0.38 to 0.96; PHQ-A: sensitivity, 0.73 (95% CI, 0.58 to 0.85); specificity, 0.94 (95% CI, 0.91 to 0.96) | Consistent when multiple studies are available, precise for specificity, precision varies for sensitivity | Unclear whether thresholds were established a priori or whether index and reference standard results were blinded; no replication of approaches for most screeners | Low to moderate for sensitivity (varies by instrument); Moderate for specificity | Primarily adolescents as only one study included children younger than age 12 years; seven different screeners evaluated but most not being used in practice; the most commonly cited instrument for use in current practice is PHQ-9
KQ 3 Harms of screening tests | Suicide: 2 RCTs^267,^ ^268^ (2,675); Depression: 0 studies; Anxiety: 0 studies | No significant differences in measures of short-term distress/emotions for students exposed to suicide screening items compared with those not exposed (2 RCTs); No significant differences in suicidal ideation between students exposed to screening items and those not exposed (1 RCT) | Consistent, precise | Fair-quality trials with some attrition; only evaluated measures of immediate and short-term emotions (over 1 to 2 days) | Low for no short-term harms from screening for suicide risk; insufficient for screening for depression and anxiety | High school students; one study entirely comprised males
KQ 4: Benefits of treatment | Suicide: 16 RCTs^164,^ ^179–182,^ ^191–194,^ ^197,^ ^200,^ ^202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^245,^ ^265^ (3,034) | Statistically significant difference favoring interventions on all deaths in the National Death Index (hazard ratio for treatment as usual: 6.62 [95% CI, 1.49 to 29.35]; N=448; k=1); Beck Hopelessness Scale (pooled mean difference: −2.35 (95% CI, −4.06 to −0.65); N=644; k=4; I^2^=46%); nonstatistically differences favoring suicide risk interventions on the SIQ and SIQ-Junior, mixed on other measures; No statistically significant differences on suicide deaths, hospitalization or ED visits, number of self-harm events, proportion with self-harm events, or functioning | Consistent, imprecise | All interventions cannot mask treatment, leading to the potential for bias in outcome reporting; all comparison groups are TAU comparisons, which in many cases were quite active treatments and could bias results toward null effects | Psychotherapy; Low for benefit for suicidal ideation and clinical response; insufficient for all other outcomes | Applicable to adolescents (predominantly females); no studies recruited children younger than age 11 years; most recruited from mental health or specialist settings
KQ 4: Benefits of treatment (continued) | Anxiety: 29 RCTs (22 on CBT, 6 on pharmacotherapy, 1 on CBT, sertraline, and combination)^163,^ ^165,^ ^167–169,^ ^177,^ ^178,^ ^183,^ ^190,^ ^195,^ ^196,^ ^198,^ ^203,^ ^206,^ ^220,^ ^224–228,^ ^237–244,^ ^246,^ ^251,^ ^253–262^ (2,970) | CBT:; Statistically significant differences favoring CBT on several pooled measures of symptom improvement, response (pooled RR: 1.89 [95% CI, 1.17 to 3.05]; N=606; k=5; I^2^=64%), remission (RR: 2.68 [95% CI, 1.48 to 4.88]; N=321; k=4; I^2^=48%), and loss of diagnosis (RRs range from 3.02 to 3.09); Statistically significant improvement on Children’s Global Assessment Scale (pooled mean difference: 7.54 [95% CI, 2.84 to 12.23]; N=811; k=8; I^2^=90%) but not Children’s Anxiety Impact Scale; Pharmacotherapy:; Statistically significant differences favoring pharmacotherapy on pooled measures of symptom improvement and response (RR: 2.11 [95% CI, 1.58 to 2.98]; N=370; k=5; I^2^=18%).; Statistically significant differences favoring pharmacotherapy on pooled functional measure (Children’s Global Assessment Scale): mean difference: 5.14 [95% CI, 3.21 to 7.08]; N=551; k=3; I^2^=0%, but not other measures of functioning | CBT; Mostly consistent, mostly precise; Pharmacotherapy; Mostly consistent, mostly precise | Potential for bias from attrition, additionally CBT studies cannot mask treatments, leading to the potential for bias in outcome reporting | CBT:; Moderate for anxiety symptoms, response, remission, and loss of diagnosis; low for functioning depending on the measure used; Pharmacotherapy:; Moderate for anxiety symptoms, response, remission, and loss of diagnosis; low for functioning depending on the measure used | 15 CBT studies targeted any anxiety disorders; only 1 pharmacotherapy study targeted any anxiety disorders; Studies addressed youth from ages 3 to 20 years, but 11 were conducted exclusively in adolescents; Psychotherapy studies were limited to CBT; pharmacotherapy studies were limited to drugs with FDA approval for pediatric use
KQ 4: Benefits of treatment (continued) | Depression: 13 RCTs^174–176,^ ^185,^ ^187,^ ^204,^ ^205,^ ^207,^ ^216,^ ^233,^ ^248,^ ^249,^ ^252,^ ^266^ (2 on pharmacotherapy; 9 on psychotherapy; 1 on CBT, fluoxetine, and combination; 1 on collaborative care) (2,156) | Psychotherapy:; Varied by measure with some pooled estimates of effect favoring psychotherapy for symptoms (BDI or BDI-II standardized mean difference: −0.58 [95% CI,−0.83 to −0.34]; N=471; k=4; I^2^=0%; Hamilton Depression mean difference: −2.25 [95% CI,−4.09 to −0.41]; N=262; k=3; I^2^=0%), clinical response (3 studies with statistically significant results using varying thresholds), and loss of diagnosis (RR: 1.73 [95% CI, 1.00 to 3.00]; N=395; k=4; I^2^=81%), but other outcome measures do not consistently demonstrate a statistically significant difference; Pharmacotherapy:; Statistically significant differences favoring pharmacotherapy for one measure of symptoms (Children’s Depression Rating Scale-Revised mean difference: −3.76 [95% CI, −5.95 to −1.57]; N=793; k=3; I^2^=49%); Pooled differences favor pharmacotherapy but are not statistically significant for remission; Other outcome measures do not demonstrate a statistically significant difference; Collaborative care:; Statistically significant differences favoring collaborative care for symptoms at 6 months (CDRS-R change: 8.5 [95% CI, 13.4 to −3.6]; p=0.001), response by 12 months (OR for ≥50% reduction in CDRS-R score from baseline: 3.3 [95% CI, 1.4 to 8.2]); remission (OR for PHQ-9 <5 at 6 months: 5.2 [95% CI, 1.6 to 17.3]; no benefits for functioning) | Mostly consistent, Mostly imprecise | Psychotherapy cannot mask treatment, leading to the potential for bias in outcome reporting | Psychotherapy:; Low for benefit for all outcomes other than remission; Pharmacotherapy:; Low for benefit for all outcomes other than response; Collaborative care:; Low for benefit for symptoms, response, and remission; Insufficient for functioning | Studies addressed youth from ages 3 to 19 years, but 9 were conducted exclusively in adolescents; Pharmacotherapy studies were limited to drugs with FDA approval for pediatric use
KQ 5: Harms of treatment | Suicide: 2 RCTs^179,^ ^192^ (885) | No statistically significant differences on adverse events (such as attendance at minor injury units, walk-in centers, accident and emergency centers; re-referral to mental health service; and hospital attendance) | Consistent, imprecise | All interventions cannot mask treatment, leading to the potential for bias in outcome reporting; all comparison groups are TAU comparisons, which in many cases were quite active treatments and could lead to bias toward null effects | Insufficient | Applicable to adolescents, primarily females in these trials, both recruited from mental health or specialist settings
KQ 5: Harms of treatment | Anxiety: 11 RCTs^168,^ ^169,^ ^224–228,^ ^238,^ ^239,^ ^242–244,^ ^253–262^ (4 on CBT; 6 on pharmacotherapy; 1 on CBT, sertraline, and combination) (1,293) | Psychotherapy:; Inconsistent results on suicide-related events; harms were events and not statistically significant; Pharmacotherapy:; More suicide-related events and withdrawals due to adverse events in the pharmacotherapy arm but harms were rare and not statistically significant | Consistent to mostly consistent, imprecise | All CBT interventions cannot mask treatment, leading to the potential for bias in outcome reporting | Psychotherapy:; Insufficient evidence; Pharmacotherapy:; Low for harms | 2 of 4 CBT studies included any anxiety disorders; 1 of 7 pharmacotherapy studies included any anxiety disorders; Studies addressed children from age 5 to 20 years, but 4 were conducted exclusively in adolescents; Psychotherapy studies are limited to CBT, and pharmacotherapy studies are limited to drugs with FDA approval for pediatric use
KQ 5: Harms of treatment (continued) | Depression: 6 RCTs^176,^ ^185,^ ^186,^ ^207–211,^ ^233,^ ^252,^ ^266^ and 1 meta-analysis^173^ (3 on pharmacotherapy; 2 on psychotherapy; 1 on CBT, fluoxetine, and combination; 1 on collaborative care) (1,352 from trials) | Psychotherapy:; Increased risk for suicide-related outcomes in one study, magnitude unclear due to inconsistent study reporting; no differences in negative effects in one trial; Pharmacotherapy:; Increased risk of suicide-related outcomes, withdrawal due to adverse events and serious adverse events, magnitude unclear due to inconsistent study reporting; Collaborative care:; Inconsistent results for psychiatric hospitalizations and emergency department visits | Consistent to inconsistent, imprecise | Psychotherapy trials cannot mask treatment, leading to the potential for bias in outcome reporting, inconsistent results across publications from one trial | Psychotherapy:; Insufficient; Pharmacotherapy:; Low for harms; Collaborative care:; Insufficient | Studies addressed youth from ages 6 to 18 years, but 5 were conducted exclusively in adolescents; Pharmacotherapy studies were limited to drugs with FDA approval for pediatric use.

Abbreviations: BDI=Beck Depression Inventory; BDI-II=Beck Depression Inventory, version 2; CBT=cognitive behavioral therapy; CDRS-R=Children’s Depression Rating Scale-Revised; CI=confidence interval; ED=emergency department; FDA=Food and Drug Administration; I^2^=percentage of variation across studies that is due to heterogeneity rather than chance; k=number of studies; KQ=key question; MDD=major depressive disorder; N=number of participants; NA=not applicable; OR=odds ratio; PHQ-9=Patient Health Questionnaire-9; PHQ-A=Patient Health Questionnaire—Adolescent; RCT=randomized, controlled trial; RR=relative risk; SIQ=Suicidal Ideation Questionnaire; TAU=treatment as usual.

## Benefits of Screening (Key Question 1)

We did not identify any studies reporting on the direct benefits of screening.

## Screening Test Accuracy (Key Question 2)

We only identified one study assessing the accuracy of screening for suicide risk in adolescents evaluated against a clinical diagnostic interview reference standard; the instrument used was the SRS, a 20-item instrument that was embedded in a longer questionnaire, and the study population was recruited from youth identified as potential high school dropouts.^247^ We rated the strength of evidence for screening as insufficient because of inconsistency in estimates based on the reference standard used, imprecision, and study limitations. Given that most depression screening instruments include an assessment of suicidal ideation, it is unclear whether a separate, stand-alone instrument to screen for increased suicide risk has value for universal screening in primary care practice. The Ask Suicide Screening Questions (ASQ) is a brief 4-item instrument that was initially developed for youth age 8 years or older in emergency department settings but has since been evaluated in other medical settings including outpatient specialty and primary care.^281,^ ^282^ The Joint Commission recommends suicide risk screening for all medical patients in all medical settings, including outpatient practices.^283^ The National Institute for Mental Health developed an ASQ toolkit to support implementation of suicide risk screening in medical settings, including for youth in primary care.^284^ We identified one study evaluating the ASQ in outpatient settings, including primary care, but we excluded it because its accuracy was compared against another suicide risk screening instrument and not against a diagnostic clinical interview by a qualified professional.^282^

We identified evidence for test accuracy related to seven different instruments for screening for MDD, but five of those instruments were limited to single-study bodies of evidence.^172,^ ^199,^ ^219,^ ^223^ Across this body of evidence, the sensitivity of screening tests compared with clinical diagnostic interview ranged from 0.59 to 0.94, and we rated most comparisons as low strength of evidence. Specificity ranged from 0.53 to 0.97, and we rated this body of evidence as moderate strength of evidence. All but one study were focused exclusively on adolescents.

The depression module (PHQ-9) of the full PHQ is the instrument highlighted for use in screening for depression by the AAP in a quality improvement collaborative designed to improve diagnostic performance for depression.^285^ The Centers for Medicare & Medicaid Services Merit-based Incentive Payment System and the National Committee on Quality Assurance HEDIS measure set include a depression screening quality measure that is applicable to persons age 12 and older.^286–288^ These measures require that standardized screening tools normalized and validated based on age for which they are being used should be used for screening, but they do not specify a specific tool. Similarly, the AAP Guidelines for Adolescent Depression in Primary Care recommended screening using a formal self-report tool.^147^ For these measures and guidelines, multiple tools are listed, but the CES-D is the only instrument included in this review update that are among the listed examples. We identified one study of the accuracy of the full PHQ modified for adolescents, and we identified no studies evaluating the PHQ-9, which is the depression module of the full PHQ. The PHQ-9 may offer advantages over the CES-D with respect to feasibility of implementation because it is already the basis for quality measures related to monitoring depression remission and response to treatment and includes an item specific to suicidal ideation (unlike the CES-D). However, the full PHQ, which also includes modules for anxiety, somatoform disorders, eating disorders, and substance abuse, may be more feasible for use as a transdiagnostic screener compared to the use of separate screeners for different conditions.^289^

Based on the accuracy characteristics for the one included study of PHQ-A in this update review,^199^ per 1,000 screening tests conducted, 58 false-positives and eight false-negatives would be generated at the low end of MDD prevalence (3%), and 53 false-positives and 30 false-negatives would be generated at the high end of prevalence (11%). As noted above, we did not identify any evidence related to the harms of screening. The relative frequency of false-negatives is smaller than the number of false-positives, and most of the other instruments included in this update follow a similar pattern. Positive results would require additional diagnostic evaluation to sort out true-positives from false-positives, but it is likely that some youth screening positive but not meeting diagnostic criteria for MDD may have PDD (formerly known as dysthymia) or other behavioral health conditions with symptoms similar to depression. The consequences of a false-negative would largely depend on the severity of the missed diagnosis; the likelihood of missing a severely depressed youth is small because most screen-detected depression is likely to be mild to moderate. However, even mildly to moderately depressed youth may have suicidal ideation, and the consequences of missing such symptoms could be serious.

We examined nine different instruments (i.e., ANS, PHQ-A, PI-ED, SAS, SASA, SCARED, SPAI, SPIN, and SWQ) to screen for anxiety, most of which screened for specific anxiety disorders such as GAD, social anxiety disorder, separation anxiety disorder, and panic disorder. Some screening instruments with subscales screened for more than one anxiety disorder. Thus, we evaluated 15 different approaches (e.g., full scale, subscales) for detecting anxiety disorders, and we had only a single study body of evidence for nine of the approaches (from four studies).^188,^ ^199,^ ^218,^ ^219^ Across all of the screeners and subscales and thresholds for a positive test evaluated, sensitivity ranged between 0.34 and 1.00; we rated most comparisons low strength of evidence. Specificity for this body of evidence ranged between 0.47 and 0.98, and we rated about half of the comparisons as moderate strength of evidence and the other half as low strength of evidence. The confidence intervals around the estimates of sensitivity and specificity were often wide, indicating a lack of precision for most screeners. Of the 10 studies that assessed screeners to detect anxiety, four included both children and adolescents, and the remainder included adolescents only.

In all but two studies, youth were the respondents, and in one of the two both youth and parents completed the same screeners.^171^ This study administered both the full and the short versions of the SCARED to parents and youth ages 9 to 13 years. Sensitivity was greater for the screeners in which youth were the respondents, suggesting that youth are better reporters of their own distress. However, there were more false-positives per 1,000 screens for the youth-administered screeners. Specificity was only minimally worse when youth were the respondents.

One screener designed to detect panic disorder, the ANS, is notable for the perfect sensitivity in all three versions—two items, three items, and five items. The perfect sensitivity of the ANS does not appear to be related to the fact that adolescents were respondents because most of the other screeners were given to youth, and the ANS is the only one with such high sensitivity. In fact, the PHQ-A, which also included adolescents as respondents, had a much lower sensitivity when compared with a clinical diagnosis of panic disorder. Rather, it is more likely that the targeted nature of the ANS’s content contributed to its ability to perfectly detect adolescents with panic disorder. The two gateway items concerned sudden physical and mental feelings of fright or anxiety. In contrast, the PHQ-A is a broader tool used more often to detect depression as well as other mental health disorders.

The difference in accuracy between a broad screening tool and one that is more targeted is seen when comparing the SCARED full scale and some of the SCARED subscales. Sensitivity of the full-scale SCARED with youth as respondents was 0.76,^171^ whereas sensitivity on the SCARED separation anxiety scale was 0.88.^218^ In contrast, the sensitivity of the more global SCARED GAD scale was 0.64.^171^

To facilitate adoption of screening in primary care, screeners should not only be accurate but be short. Both the SCARED and the SPIN have shorter versions that were administered in some of the included studies. The 10-item SCARED short version for youth was somewhat lower (0.67) than the full 41-item version (0.76) with respect to global anxiety symptoms.^171^ With a sensitivity of 0.86, the 3-item Mini-SPIN^232^ was equivalent to that of the 17-item SPIN (0.82)^231^ Thus, accuracy was not compromised for the Mini-SPIN with respect to identifying social anxiety disorder.

Across all screeners and subscales, the rate of false-positives was as high as 500 per 1,000 screens for a range of prevalence values from 2.5 percent to 13 percent. In contrast, the rate of false-negatives for the same range of prevalence values did not exceed 100 per 1,000 screens. The consequences of a high rate of false-positives indicate that many families may needlessly be concerned about their children’s mental health. However, good practice dictates that those who are screened positive should receive a clinical evaluation that can rule out an anxiety disorder. The consequences of the lower rate of false-negatives indicate that fewer truly anxious youth will be missed by a screening program. Yet, astute parents and primary care providers may recognize that even in the absence of screen-detected anxiety youth whose physical complaints include stomachaches, headaches, fatigue, or muscle tension without an organic cause may be manifesting anxiety. Good practice indicates that these youth may also benefit from a clinical evaluation for anxiety disorders.

## Harms of Screening (Key Question 3)

We did not identify any studies reporting on the direct harms of screening for anxiety or depression. Two RCTs reported no increased distress or suicidal ideation following screening for suicide risk.^267,^ ^268^

## Benefits and Harms of Treatment (Key Questions 4 and 5)

### Suicide

Sixteen RCTs of interventions to reduce suicide risk or self-harm addressed the benefits of treatment,^164,^ ^179–182,^ ^191–194,^ ^197,^ ^200–202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^245,^ ^265^ and two reported on harms of treatment.^179,^ ^192^ Nine of 16 RCTs were new to this update.^164,^ ^179–181,^ ^192,^ ^194,^ ^202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236^ The previous review found statistically nonsignificant increases in suicide attempts for psychotherapy interventions and no benefits for suicidal ideation, raising the possibility of harm.^179,^ ^192^ One newly identified update to a previously included study found no statistically significant differences in suicide deaths but found benefits in all-cause mortality over the long term.^201^ Newly identified studies do not report on suicide attempts, and the evidence base on self-harm events is inconsistent. The updated evidence base (including prior and new studies) suggests improvements in suicidal ideation resulting from treatment, but this finding was only statistically significant for one measure. The evidence suggested no statistically significant differences on all other outcomes. Notably, all studies included TAU comparators, which for ethical reasons must be active comparators, such as standard psychotherapy, individual counseling, family sessions, medication assessment and review, medication, and other care coordination activities. Comparable intensity of therapy in study arms, coupled with low event rates for some outcomes (such as suicide deaths, hospitalizations, and suicide attempts), is likely to make differences between study arms difficult to detect. We rated the evidence as low for benefit on suicidal ideation but insufficient for evaluating outcomes such as suicide attempts, hospitalizations, and deaths. Only two studies reported on various harms outcomes (such as attendance at minor injury units, walk-in centers, and accident and emergency centers; re-referral to mental health service; and hospital attendance). The available evidence did not indicate a higher frequency of events in the treatment arm. We rated the strength of evidence as low for no harm. Only one study reported analyses of specific populations. The evidence suggested that hospital attendance for self-harm events did not vary by age across adolescents.

### Anxiety

Twenty-nine RCTs on treatment of anxiety in children and adolescents addressed benefits,^163,^ ^165,^ ^167–169,^ ^177,^ ^178,^ ^183,^ ^190,^ ^195,^ ^196,^ ^198,^ ^203,^ ^206,^ ^220,^ ^224–228,^ ^237–244,^ ^246,^ ^251,^ ^253–262^ and 11 addressed harms.^168,^ ^169,^ ^224,^ ^238,^ ^239,^ ^242–244,^ ^253–262^ All are new in this update. These studies provided evidence on CBT, pharmacotherapy, and a combination of CBT and sertraline. Consistent, precise, statistically significant differences existed for most anxiety outcomes for CBT and pharmacotherapy, and we rated the strength as evidence as moderate for benefit for nearly all outcomes. For response, remission, loss of diagnosis, and functioning, the evidence suggests statistically significant differences favoring CBT; there is less evidence for pharmacotherapy on these outcomes, but the available evidence indicates benefits for clinical response. Results were less consistent for other outcomes. The evidence on CBT is more voluminous (23 RCTs) compared with pharmacotherapy (7 RCTs). Most pharmacotherapy studies (6 of 7) required specific anxiety diagnoses, that is, GAD, separation anxiety, or social anxiety disorders, whereas a minority of CBT studies specified diagnosis (10 of 24). The remainder targeted any anxiety diagnosis. Anxiety studies covered a wide range of ages, from preschool (ages 3 to 7 years)^183,^ ^195,^ ^237^ through adolescence, though 11 studies were focused exclusively on adolescents. Studies focusing on younger children (ages 3 to 7 years^183,^ ^195,^ ^237^) were consistent with the overall findings in demonstrating benefits for symptoms and clinical response.

Few CBT trials reported on harm outcomes, and we rated the strength of this evidence as insufficient. The evidence suggests that suicide-related harms, serious adverse events, and withdrawal due to adverse events are rare in pharmacotherapy studies but more frequent in the treatment arm; thus, we rated this evidence as low for harms.

Few studies reported analyses by age, sex, race, or ethnicity. Studies reporting on analyses of anxiety symptoms consistently reported no effect of age or sex, but there is insufficient evidence available on anxiety symptoms by race or ethnicity. There is insufficient evidence available on specific populations for other outcomes.

### Depression

Thirteen RCTs on treatment of depression in children and adolescents addressed benefits,^174–176,^ ^185,^ ^187,^ ^204,^ ^205,^ ^207,^ ^216,^ ^233,^ ^248,^ ^249,^ ^252^ and five addressed harms.^176,^ ^185,^ ^207,^ ^233,^ ^252,^ ^266^ Eight RCTs were new in this update for KQ 4, all focusing on psychotherapy.^175,^ ^176,^ ^187,^ ^204,^ ^205,^ ^216,^ ^248,^ ^249,^ ^266^ Additionally, one meta-analysis of pharmacotherapy is new to the update on harms.^173^ The prior report on depression in children and adolescents included two trials on psychotherapy; neither^174,^ ^207^ showed improvement on remission or recovery. These two trials were inconsistent on symptoms, response, and functioning. The updated evidence on psychotherapy suggests some benefits for symptom improvement, clinical response, and loss of diagnosis, but the results are not consistent across all measures for other outcomes. The evidence for pharmacotherapy suggests benefit for symptom improvement, but the results are not consistent across all measures for other outcomes. Thus, we rated the strength of evidence for psychotherapy and pharmacotherapy as low for benefit.

The evidence on harms is limited but suggests a higher frequency of suicide-related outcomes for psychotherapy and pharmacotherapy. Notably, one multi-arm trial (Treatment for Adolescent Depression Study, or TADS) with inconsistent reporting on suicide-related events across its various publications contributed to the evidence on psychotherapy, pharmacotherapy, and their combination. These discrepancies increase the uncertainty regarding harms of treatment and have led to a call for independent reanalysis of the TADS results.^290,^ ^291^ The FDA notes a higher frequency of suicide-related events in boxed warnings for antidepressants.^292^ The underlying FDA review for this warning relied on drug trials in populations ineligible for this review.^293^

The prior report found very limited evidence on treatments in children: no psychotherapy trials and just one pharmacotherapy trial^252^ recruited children younger than age 12 years. This updated review included two new studies in children. Of these, one recruited children ages 7 to 14 years, with an average age of 11.6.^187^ This trial is a comparison of psychoeducation psychotherapy plus placebo vs. placebo, where the primary purpose was to examine the effectiveness of omega-3 fatty acids. The sample size for therapy and placebo arms together was 37 participants. The second study of children was a larger trial (N=229)^204,^ ^205^of parent-child interaction therapy (PCIT). The results were not consistent across the two studies: the PCIT trial suggested improved symptoms, loss of diagnosis, and improved functioning, whereas the psychoeducation psychotherapy did not find benefits for treatment for symptoms or remission.

Few studies reported analyses by age, sex, race, or ethnicity. The available evidence on functioning outcomes by age is inconsistent, and there is insufficient evidence available on functioning outcomes by sex, race, or ethnicity. There is insufficient evidence available for specific populations on other outcomes.

## Limitations of the Evidence

We did not identify any direct evidence for the benefits of screening for suicide risk, anxiety, and depression and very limited evidence on harms for suicide risk alone, among children or adolescents in primary care or primary care–relevant settings. Despite the large number of potential instruments that could be used for screening, we identified only one to two studies for any given instrument for the KQ on test accuracy (KQ 2). Further, these studies often evaluated multiple thresholds for determining a positive test, but it is not clear whether the optimal thresholds reported by such studies would remain optimal when used across different age groups or populations. Existing quality measures related to depression screening list examples of several instruments that can be used, but we identified surprisingly little research for those tools. Although studies reporting psychometric characteristics of these tools exists, few have studies evaluating them against a reference standard that includes a clinical diagnostic interview. The PHQ-A is capable of screening across conditions (suicide risk, anxiety, depression), but it is only applicable to adolescents. Although other instruments are available that assess a broad range of mental, behavioral, and emotional health areas, such instruments are typically designed for epidemiologic studies or to augment clinical history-taking and diagnosis and are too long to be considered feasible for use as brief screening instruments in primary care settings. We identified no studies reporting on the harms of screening.

Related to the benefits and harms of treatment, fewer studies were conducted in children compared with adolescents. Although studies generally reported outcomes using validated measures of symptoms, minimally important differences in children and adolescents for these measures are lacking and whether statistically significant differences in mean symptoms scores are clinically meaningful is uncertain. Despite this limitation in such measures, response, remission, and loss of diagnosis outcomes generally mirrored changes in symptom scores, suggesting that the differences observed are likely clinically meaningful. For all conditions, heterogeneity in type and duration of psychotherapy interventions, underlying anxiety and depression subtypes, risk factors, and comorbidities somewhat limited our certainty about the magnitude of benefit for such interventions.

For suicide studies, more than half the studies included participants with comorbid conditions but did not always report how these conditions were treated. Ongoing therapy for these comorbid conditions may have attenuated the effect of the interventions.

Trauma and maltreatment are risk factors for suicide, anxiety, and depression in children,^294,^ ^295^ but no trauma-focused interventions were found to be eligible for this review. Another constraint in interpreting the evidence for psychotherapy relates to the comparators. For suicide, the comparator arms generally included active comparators that may result in understated benefits for the intervention arm. For depression and anxiety, multi-arm studies of drugs, psychotherapy, and their combination,(TADS^207–211^ Child/Adolescent Anxiety Multimodal Study, or CAMS^254–262^) compared these active treatments with placebo. In these cases, the lack of blinding for the psychotherapy and combination therapy arms may also bias outcome reporting.

For pharmacotherapy interventions, the evidence is largely limited to short-term benefits (typically up to 12 weeks). The evidence for increased suicidal events across all three topics is hampered by imprecision because of rare events, conflicting reporting in the published studies for depression in particular, and varying definitions for this type of harm. The ethical considerations and logistical challenges of conducting studies in children often limit the size of trials; future research studies that employ the same type of study designs are likely to encounter similar difficulties with adequately powering trials for rare outcomes.

Treatment studies necessarily exclude low-risk participants from trials to maximize the potential for finding an effect. Screen-detected populations may include low-risk individuals; as a result, whether the benefit observed in treatment studies applies to screen-detected populations is unclear. Further, rates of treatment enrollment and retention in research studies are likely different than what can be expected in routine clinical practice.

## Future Research Needs

More RCTs are needed on the benefits and harms directly arising from screening for suicide risk, anxiety, and depression among children and adolescents in primary care settings (or similar settings), when compared with no screening or usual care. Future research could also elucidate the advantages and disadvantages of combined screening for depression and suicide risk, as currently happens with some instruments (e.g., PHQ-9). Although some studies have demonstrated that screening for depression alone may not be adequate to identify those at high risk for suicide, such studies were conducted among hospitalized medically ill youth and may not be applicable to youth seen in primary care practice.^296,^ ^297^ Because multiple types of anxiety disorders exist, future research could elucidate trade-offs between screening instruments designed to identify any anxiety disorder versus instruments designed for specific anxiety disorders. Lastly, the use of computerized adaptive screening could be explored to allow for the use of broader screening instruments to screen across condition but yet limit respondent burden.

The existing evidence focuses on adolescents, reflecting the higher prevalence of mental health disorders among them. More research on treatment in children is also warranted, across all types of therapies. However, traditional RCTs randomizing individual treatments will necessarily be constrained in size (because of the challenges of recruitment in younger children and because of lower rates of depression and suicide risk) and, therefore, statistical power by ethical and logistical considerations. Cluster-randomized trials and pragmatic trials^298^ may help address size considerations for trials of children or adolescents but may also continue to carry risks of bias in outcome measurement because blinding is not likely to be feasible. Publication of hitherto unreported data on rare or no suicide events from ongoing and completed trials will help supplement the relatively sparse evidence on this outcome.

Studies infrequently measure long-term outcomes or conduct analyses of populations of interest. No studies reported on sexual orientation or gender identity in subgroup analyses; given that these are known risk factors for suicide in particular, further research is needed. In light of rising suicide rates among Black children, more work needs to be done on accurate identification and effective prevention of suicide risk among them.^110^ No studies focused on American Indian youth, who have the highest rates of suicide deaths in the United States.

Little is known about minimal clinically important differences for the multitude of outcome measures evaluated in this report. Studies establishing these thresholds will help stakeholders interpret the existing evidence.

## Limitations of the Review

We limited this review to studies published in English that were conducted in very highly developed countries to maximize applicability of findings to primary care settings in the United States. As a result of the restriction of the screening benefits (KQ 1) and accuracy (KQ 2) questions to primary care and primary care–relevant settings, this review does not address the outcomes from schoolwide or communitywide screening that may result in increased referrals to primary care.

Similarly, we limited the scope of the KQ on test accuracy (KQ 2) to screening instruments feasible for use in primary care settings. For suicide risk, this review was limited to evaluating the diagnostic accuracy of instruments to identify youth at high risk for suicide as compared with a diagnostic clinical interview and did not include predictive accuracy studies. Future reviews on this topic might consider including studies that evaluate the accuracy of screening instruments to predict future suicidal behavior (e.g., suicide attempts, nonfatal self-injury).

For our review, for suicide risk intervention and anxiety treatment questions, all participants in eligible trials needed to have an anxiety diagnosis or recognized suicide risk. As a result, we may have excluded studies with participants with subsyndromal anxiety or studies that included a spectrum of recognized suicide risk. We expanded the inclusion criteria for treatment studies of depression to those where 50 percent or more of participants had MDD in an attempt to identify studies that included other relevant depression diagnoses. Nonetheless, this criterion resulted in the review excluding studies that may have otherwise been eligible and demonstrated benefit.^299,^ ^300^

Because questions on the treatment of these conditions are framed relatively narrowly to support a screening recommendation, eligible studies compared treatment with no treatment, usual care, or placebo. As a result, the review cannot speak to the suggested sequence of treatments (e.g., psychotherapy vs. pharmacotherapy for depression). Because ethical concerns limit the ability to conduct comparative studies for suicide prevention using placebo or wait-list controls, we included treatment-as-usual comparators with durations and intensity comparable to active arms. Nonetheless, this review does not summarize the state of evidence for studies comparing two active interventions simultaneously^301^ or comparing usual care and active treatments sequentially,^302^ as may be the case in some suicide prevention studies.

We limited the scope of pharmacotherapy agents to drugs approved by the FDA for pediatric use and often likely to be first-line therapy for treatment for screen-detected conditions because of their relevance to primary care. We also limited the scope of psychotherapy for anxiety to CBT; Appendix A summarizes the evidence for other available therapies. We refer readers to recent AHRQ Effective Health Care Program reviews for more comprehensive information about additional medications that may not be used as first-line treatment and comparative effectiveness of various psychotherapy and pharmacotherapy treatments for depression^153^ and anxiety^123^ in children and adolescents.

We also focused on health outcomes as benefits. Studies that focus on healthcare utilization (e.g., demonstrating an increase in referral or uptake of services) or intermediate outcomes would have been excluded from the review if they did not also report on health outcomes. In practice, achieving positive results following the implementation of an intervention requires adequate diagnostic followup (Appendix A, CQ 1) and engagement with care (Appendix A, CQ 6).

## Conclusions

We found no eligible studies that reported on benefits directly arising from screening when compared with usual care or no screening. Limited direct evidence suggests no short-term harms from screening for suicide risk. The evidence for screening for suicide risk, anxiety, and depression in children and adolescents relies on indirect evidence on the accuracy of screening and the benefits and harms of treatment. Both pharmacotherapy and psychotherapy treatments have some benefit for some depression and anxiety outcomes (specifically, CBT for anxiety alone was reviewed); the evidence is limited for suicide risk interventions. Harms are rare in treatment studies but more frequent in pharmacotherapy arms when compared with placebo. Evidence gaps persist in children younger than age 11 years for test accuracy, depression and suicide risk interventions, and for screening and treatment differences by sex, race/ethnicity, sexual orientation, and gender identity.