# Chapter 3 Results

We screened 37,706 titles and abstracts and 798 full-text articles to identify 80 unique studies from 106 publications for inclusion (Figure 2).^163–268^ Nine of these studies were new to the update of suicide^164,^ ^179–181,^ ^192,^ ^194,^ ^202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236^ and 8 primary studies and one meta-analysis were new to the update of depression.^172,^ ^173,^ ^176,^ ^187,^ ^204,^ ^205,^ ^216,^ ^217,^ ^248,^ ^249,^ ^266^ We identified no studies reporting on the benefits (KQ 1) of screening.

Figure 2 Flow Diagram of Studies

Abbreviations: KQ=key question; X=exclusion number.

This figure documents the results of the literature searchers. It is a preferred reporting of systematic review and meta-analysis (PRISMA) tree that summarizes the search and selection of articles: There were 37,706 new references identified through database searching. The titles and abstracts of the new references were screened for potential inclusion. Of these, 37,157 were excluded and 549 were deemed appropriate for full-text review to determine eligibility. There were also 212 additional records from the previous reviews assessed at full-text and 37 records from other sources, including handsearch, assessed at full-text, for a total of 798 full-text articles assessed for eligibility. After full-text review, 718 were excluded: 15 for non-English language, 171 for wrong population, 102 for wrong intervention, 115 for wrong comparator, 35 for wrong setting, 17 for wrong country, 59 for wrong study design, 18 for wrong publication type, 78 for wrong outcome, 10 for duplicate, 16 for relevant protocol or ongoing study, 26 for companion publication of included study, 5 for superseded by paper publication, and 51 for poor quality. There were 80 studies reported in 106 publications that were included. No studies were included for key question 1. Seventeen studies were included for key question 2. Two studies were included for key question 3. 60 studies were included for key question 4. 20 studies were included for key question 5.

We identified 17 studies on accuracy of screening (KQ 2).^166,^ ^170–172,^ ^188,^ ^189,^ ^199,^ ^218,^ ^219,^ ^223,^ ^230–232,^ ^234,^ ^235,^ ^247,^ ^250^ Of these, one reported on suicide,^247^ 10 on anxiety,^166,^ ^171,^ ^188,^ ^199,^ ^218,^ ^219,^ ^230–232,^ ^250^ seven on depression,^170,^ ^172,^ ^189,^ ^199,^ ^219,^ ^223,^ ^235^ and two on combined screeners for anxiety or depression.^219,^ ^234^ Three of these studies reported on more than one condition.^199,^ ^219,^ ^234^ We included two studies, both on harms of screening for suicide risk (KQ 3).^267,^ ^268^ Sixty studies were included for benefits (KQ 4); of these, 16 reported on suicide,^164,^ ^179–182,^ ^191–194,^ ^197,^ ^200–202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^245,^ ^265^ 29 on anxiety,^163,^ ^165,^ ^167–169,^ ^177,^ ^178,^ ^183,^ ^190,^ ^195,^ ^196,^ ^198,^ ^203,^ ^206,^ ^220,^ ^224–228,^ ^237–244,^ ^246,^ ^251,^ ^253–262^ 13 on depression,^174–176,^ ^185–187,^ ^204,^ ^205,^ ^207–211,^ ^216,^ ^217,^ ^233,^ ^248,^ ^249,^ ^252,^ ^266^ and two on depression or anxiety.^184,^ ^263,^ ^264^ Twenty studies were included on harms (KQ 5), including two on suicide,^179–181,^ ^192^ 11 on anxiety,^168,^ ^169,^ ^224–228,^ ^238,^ ^239,^ ^242–244,^ ^253–262^ and seven on depression.^173,^ ^176,^ ^185,^ ^186,^ ^207–211,^ ^233,^ ^252,^ ^266^ Details of quality assessments of included studies and studies excluded based on poor quality are provided in Appendix D. Appendix E presents details of screeners, reference standards, and outcome measures. Appendix F presents detailed results organized by outcome and Appendix G presents forest plots for meta-analyses described in Chapter 3. Appendix H presents results for off-target symptoms (e.g., improvement in anxiety for interventions designed to address depression). Appendix I presents complete evidence tables for all studies. Appendix J lists studies excluded at full-text screening.

The results below present findings by KQ first, then by condition for suicide risk, anxiety, depression, and finally studies requiring dual diagnoses or including more than one diagnosis. Within each section, we describe study characteristics and results for each outcome for the overall population and for specific populations (for priority populations defined by age, sex, race/ethnicity, gender identity, and sexuality and within age groups).

## KQ 1 Do Depression, Anxiety, or Suicide Risk Screening Programs in Primary Care or Comparable Settings Result in Improved Health Outcomes in Children and Adolescents?

We found no eligible studies addressing KQ 1 on direct evidence for health outcomes of screening for depression, anxiety, or suicide risk on health outcomes in primary care or primary care–relevant settings. KQs 2 and 4 provide indirect evidence by summarizing the accuracy of screening and benefits of treatment, respectively.

## KQ 2 Do Instruments to Screen for Depression, Anxiety, or Suicide Risk Accurately Identify Children and Adolescents With Depression, Anxiety, and Increased Risk of Suicide in Primary Care or Comparable Settings?

### Suicide Risk

We included one fair-quality study, which was included in the previous review.^247^

#### Study Characteristics

The one identified study recruited participants (N=580) from seven high schools in the Pacific Northwest region of the United States.^247^ Eligible participants were potential high school dropouts ages 14 to 20 years. Forty-two percent were female; 57 percent were White, 20 percent were African American, 14 percent were Asian American, 8 percent were Latino, and 2 percent were American Indian. Authors used the Suicide Risk Screen (SRS), a 20-item screener, that was embedded into a longer questionnaire. The screen is considered positive if the youth scores in any one of three categories designating increased risk. This study evaluated the SRS against two reference standards both of which were completed within 7 to 10 days of screening. The first reference standard was a direct suicide risk as determined during the Measure of Adolescent Potential for Suicide (MAPS) clinical interview, and the second reference standard was a clinical risk assessment (CRA) global rating made after completing the MAPS.

#### Results of Included Studies

The prevalence of increased suicide risk was 19 percent based on the Direct Suicide Risk reference standard and 22 percent based on the Clinical Risk Assessment reference standard.^247^ The sensitivity and specificity of the SRS against the DSR reference standard was 0.91 and 0.60, respectively.^247^ Against the CRA reference standard, the sensitivity and specificity were 0.87 and 0.60, respectively.^247^

#### Results: Findings for Specific Populations

##### Subgroup Analyses

Authors reported no results by populations of interest prespecified for this update.

##### Findings Within Age Groups

All studies reported results for adolescent participants.

### Anxiety

#### Study Characteristics

We included 10 studies that assessed accuracy of screeners for detecting anxiety,^166,^ ^171,^ ^188,^ ^199,^ ^218,^ ^219,^ ^230–232,^ ^250^ all of which were of fair quality. Detailed study characteristics are provided in Appendix I Table 1. All 10 studies were new in this update. Three studies^166,^ ^199,^ ^230^ were located in the United States; two^171,^ ^188^ in Spain; two^231,^ ^232^ in Finland; and one each in the Netherlands,^218^ United Kingdom,^219^ and Taiwan.^250^ Six studies recruited their samples from schools;^171,^ ^188,^ ^218,^ ^231,^ ^232,^ ^250^ three recruited from primary care,^166,^ ^199,^ ^230^ and one from hospital outpatient departments and pediatric mental health clinics.^219^

Studies examining accuracy of anxiety screeners included adolescents only^188,^ ^199,^ ^230–232,^ ^250^ and both children and adolescents.^166,^ ^171,^ ^218,^ ^219^ In studies where sex was reported,^166,^ ^171,^ ^188,^ ^199,^ ^218,^ ^219,^ ^230^ the percentage of females ranged from 43 to 63 percent. In the four studies that reported race/ethnicity,^166,^ ^199,^ ^219,^ ^230^ the percentage of non-White youth ranged from 1 to 58 percent.

##### Index Screeners

Overall, the studies assessed 12 different screeners for detecting anxiety in youth, some of which were examined in multiple studies. Appendix E Table 1 provides a brief description of each. Three studies evaluated the Screen for Child Anxiety Related Disorders (SCARED),^166,^ ^171,^ ^218^ administering both the parent and child versions. Canals et al^171^ also assessed the SCARED short version with both parents and children respondents. Two studies evaluated the Social Anxiety Scale (SAS), one of which^166^ assessed the use for children (SAS-C) and both of which assessed the version for adolescents (SAS-A).^166,^ ^188^ Whereas Bailey et al^166^ administered the SAS-C and the SAS-A with both parents and children/adolescents as informants, Garcia-Lopez et al^188^ administered the SAS-A to adolescents only. Two studies^188,^ ^250^ evaluated the Social Phobia Inventory (SPIN), and two studies^188,^ ^232^ evaluated the related Mini-SPIN, all with adolescents; however, Garcia-Lopez et al^188^ did not report sensitivity or specificity and thus is not discussed further. One study assessed the Social Worries Questionnaire (SWQ-P),^166^ administering it to parents of both children and adolescents. One study each evaluated the Paediatric Index of Emotional Distress (PI-ED),^219^ the Autonomic Nervous System Questionnaire (ANS),^230^ and the Patient Health Questionnaire—Adolescents (PHQ-A),^199^ for detecting panic disorder and GAD. One study^188^ assessed the Social Phobia and Anxiety Inventory-Brief (SPAI-B), the Social Phobia Inventory (SoPhI), the Escala para la Deteccion de Ansiedad Social (EDAS), and the Liebowitz Social Anxiety Scale for Children and Adolescents (LSAS-CA) with adolescents. The Garcia-Lopez study^188^ only reported area under the curve (AUC) rather than sensitivity or specificity data for the SPIN, Mini-SPIN, EDAS, LSAS-CA, or SoPhI; these data appear in the evidence tables in Appendix I Table 1 but are not discussed hereafter. The results focus on the nine instruments (comprising 15 variations) with results on sensitivity and specificity.

##### Reference Standards

In all cases, the diagnostic assessment used as the reference standard was a clinical interview. Appendix E Table 2 provides a description of each interview. Three studies^166,^ ^188,^ ^230^ used the Anxiety Disorders Interview Schedule for DSM-IV-for Children (ADIS). One study^166^ interviewed parents, one study^230^ interviewed adolescents, and one study^188^ interviewed both parents and adolescents. Two studies^171,^ ^250^ interviewed the children and adolescents using the MINI International Neuropsychiatric Interview for Kids (MINI-Kid). Two studies^231,^ ^232^ used the Schedule for Affective Disorders and Schizophrenia for School-Age Children-Present and Lifetime Version (K-SADS-PL). One study each interviewed the youth with the Child edition of the Structured Clinical Interview for Diagnostic and Statistical Manual of Mental Disorders Version IV (DSM-IV) (child edition of the structured clinical interview for DSM-IV [KSCID]),^269^ the Computerized Diagnostic Schedule for Children (C-DISC),^219^ and a diagnostic interview using items from several different interview schedules.^199^ Five of the eight studies^171,^ ^219,^ ^230,^ ^250^ provided information on the timing of the diagnostic assessment in relation to the screening. One study^219^ clinically interviewed participants at the same time as the screener was administered, one study^171^ interviewed participants within a week of the screener administration, and four studies^230–232,^ ^250^ administered the diagnostic assessment within a month of the screener.

#### Results of Included Studies

Results pertaining to accuracy are found in Table 2 and are organized by condition. All but one study^230^ reported prevalence. The prevalence of anxiety disorders based on the clinical interviews ranged from 2.5 percent to 41 percent. The three studies with the highest prevalence (i.e., 20%, 24%, and 41%)^171,^ ^188,^ ^218^ oversampled youth with scores on the screener that were in the at-risk range; thus, we did not use these values when calculating the percentage of false-positives and false-negatives per 1,000 screens. The estimates of prevalence varied by condition. The lowest prevalence of 2.5 percent was for a study detecting GAD,^199^ and two studies with unselected samples each had a prevalence of 13 percent, one to detect GAD^218,^ ^219^ and one to detect social anxiety disorder.^166^

Table 2 Results of Diagnostic Test Accuracy Studies on Screening for Anxiety Compared With Structured Clinical Interview (KQ 2)

| | | | | | | | Per 1,000 Screens Across a Prevalence From 3% to 13% | Per 1,000 Screens Across a Prevalence From 3% to 13%
Author, Year; Quality | Age Range; Mean Age (SD), Years | Total N (% Female) | Index Test Cutoff | Respondent | Prevalence % | Sensitivity (95% CI) | Specificity (95% CI) | No. False-Negatives | No. False-Positives
Anxiety (Global, that is positive on total anxiety score)
Screen for Anxiety Related Emotional Disorders (SCARED)
Canals et al, 2012^171^; Fair | 11 (1.0); 9 to 13 | 562; (55) | SCARED-C; Cutoff ≥ 25 | Youth | 24 | 0.76; (0.68 to 0.92) | 0.68; (0.63 to 0.72) | 6 to 31 | 278 to 312
Canals et al, 2012^171^; Fair | 11 (1.0); 9 to 13 | 562; (55) | SCARED-P; Cutoff ≥ 17 | Parents | 24 | 0.63; (0.54 to 0.74) | 0.70; (0.65 to 0.74) | 9 to 48 | 261 to 293
Canals et al, 2012^171^; Fair | 11 (1.0); 9 to 13 | 562; (55) | SCARED-C Short; Cutoff ≥ 3 | Youth | 24 | 0.67; (0.59 to 0.74) | 0.74; (0.70 to 0.78) | 8 to 43 | 226 to 254
Canals et al, 2012^171^; Fair | 11 (1.0); 9 to 13 | 562; (55) | SCARED-P Short; Cutoff ≥ 3 | Parents | 24 | 0.34; (0.26 to 0.42) | 0.86; (0.82 to 0.89) | 17 to 86 | 122 to 137
GAD
Patient Health Questionnaire—Adolescent (PHQ-A)
Johnson et al, 2002^199^; Fair | 16 (1.2); 13 to 18 | 403; (63) | PHQ-A; Cutoff NR | Youth | 2.5 | 0.50; (0.24 to 0.76) | 0.98; (0.86 to 0.99) | 13 to 65 | 17 to 20
SCARED—GAD Scale
Muris et al, 2001^218^; Fair | 10 (1.4); 7 to 14 | 82; (61) | SCARED-C; Male cutoff ≥ 10; Female cutoff ≥ 13 | Youth | 13 | 0.64; (0.35 to 0.85) | 0.63; (0.52 to 0.74) | 9 to 47 | 322 to 361
Paediatric Index of Emotional Distress (PI-ED)—Anxiety Scale
O’Connor et al, 2016^219^; Fair | 12 (2.5); 8 to 17 | 100; (48) | PI-ED; Cutoff ≥ 9 | Youth | 6 | 0.88; (0.53 to 98) | 0.85; (0.78 to 0.90) | 3 to 16 | 130 to 146
Panic Disorder
Autonomic Nervous System Questionnaire (ANS)
Queen et al, 2012^230^; Fair | 14 (1.8); 12 to 17 | 45; (43) | ANS 2 questions; (cutoff ≥ 1) | Youth | NR | 1.00; (NR) | 0.47; (NR) | 0 to 0 | 461 to 517
Queen et al, 2012^230^; Fair | 14 (1.8); 12 to 17 | 45; (43) | ANS 3 questions; (cutoff ≥ 2) | Youth | NR | 1.00; (NR) | 0.57; (NR) | 0 to 0 | 374 to 419
Queen et al, 2012^230^; Fair | 14 (1.8); 12 to 17 | 45; (43) | ANS 5 questions; (cutoff ≥ 3) | Youth | NR | 1.00; (NR) | 0.65; (NR) | 0 to 0 | 304 to 341
Patient Health Questionnaire—Adolescent (PHQ-A)
Johnson et al, 2002^199^; Fair | 16 (1.2); 13 to 18 | 403; (63) | PHQ – A; Cutoff NR | Youth | 3 | 0.42; (0.19 to 0.68) | 0.99; (0.97 to 1.0) | 15 to 75 | 9 to 10
Separation Anxiety Disorder
Screen for Anxiety Related Emotional Disorders (SCARED)-Separation Anxiety Scale
Muris et al, 2001^218^; Fair | 10 (1.4); 7 to 14 | 82; (61) | SCARED-C; Male cutoff ≥ 10; Female cutoff ≥ 12 | Youth | 10 | 0.88; (0.52 to 0.98) | 0.73; (0.62 to 0.82) | 3 to 16 | 235 to 263
Social Anxiety Disorder
Screen for Anxiety Related Emotional Disorders (SCARED)—Social Phobia Scale
Bailey et al, 2006^166^; Fair | Children; Mean: NR; 8 to 12; Adolescents; 14 (1.3); 13 to 16 | 101 | SCARED-SP; cutoff ≥5 | Parents | 9 | 0.78; (0.45 to 0.94) | 0.69; (0.59 to 0.78) | 6 to 29 | 226 to 254
Bailey et al, 2006^166^; Fair | Children; Mean: NR; 8 to 12; Adolescents; 14 (1.3); 13 to 16 | 89; (49)^*^ | SCARED-SP; Cutoff ≥ 6 | Parents | 13 | 0.83; (0.55 to 0.95) | 0.81; (0. 71 to 0.88) | 4 to 22 | 165 to 185
Social Anxiety Scale (SAS) Children/Adolescents
Bailey et al, 2006^166^; Fair | Children; Mean: NR; 8 to 12; Adolescents; 14 (1.3; 13 to 17 | 101 | SAS-C; Cutoff ≥ 45 | Parents | 9 | 0.78; (0.45 to 0.94) | 0.74; (0.65 to 0.82) | 6 to 29 | 148 to 166
Bailey et al, 2006^166^; Fair | Children; Mean: NR; 8 to 12; Adolescents; 14 (1.3; 13 to 17 | 89; (49)^*^ | SAS-A; Cutoff ≥ 47 | Parents | 13 | 0.75; (0.47 to 0.91) | 0.80; (0.69 to 0.87) | 6 to 32 | 174 to 195
Garcia-Lopez et al, 2015^188^; Fair | 15 (1.3); 12 to 18 | 1,034; (54) | SAS-A; Cutoff ≥ 48 | Youth | 41 | 0.93; (0.91 to 0.96) | 0.78; (0.74 to 81) | 2 to 9 | 189 to 215
Social Anxiety Scale for Adolescents (SASA)
Garcia-Lopez et al, 2015^188^; Fair | 15 (1.3); 12 to 18 | 1,034; 54 | SASA; Cutoff ≥ 73 | Youth | 41 | 0.93; (0.85 to 0.98) | 0.79; (0.70 to 87) | 2 to 9 | 183 to 205
Social Phobia and Anxiety Inventory-Brief (SPAI-B)
Garcia-Lopez et al, 2015^188^; Fair | 15 (1.3); 12 to 18 | 1034; (54) | SPAI-B; Cutoff ≥26.4 | Youth | 41 | 0.86; (0.83 to 0.89) | 0.88; (0.85 to 0.91) | 4 to 18 | 104 to 117
Social Phobia Inventory (SPIN)/Mini Social Phobia Inventory (Mini-SPIN)
Ranta et al, 2007^231^; Fair | 14.7 (1.1); 12 to 17 | 350; (49) | SPIN; Cutoff ≥ 24 | Youth | 6 | 0.82; (0.61 to 0.93) | 0.85; (0.81 to 0.89) | 5 to 23 | 130 to 146
Tsai et al, 2009^250^; Fair | Mean NR; 13 to 15 | 144; (50) | SPIN; Cutoff ≥25 | Yourh | 10 | 0.80; (0.55 to 0.93) | 0.77; (0.69 to 0.83) | 5 to 26 | 200 to 224
Ranta et al, 2012^232^; Fair | 14.7 (1.1); 12 to 17 | 350; (49) | Mini-SPIN; Cutoff ≥ 6 | Youth | 6 | 0.86; (0.67 to 0.92) | 0.84; (0.79 to 0.87) | 4 to 18 | 139 to 156
Social Worries Questionnaire (SWQ)
Bailey et al, 2006^166^ | Children; Mean NR; 8 to 12; Adolescents; 14 (1.3); 13 to 17 | 101 | SWQ; Cutoff ≥ 10 | Parents | 9 | 0.67; (0.35 to 0.88) | 0.94; (0.88 to 0.98) | 8 to 43 | 52 to 58
Bailey et al, 2006^166^ | Children; Mean NR; 8 to 12; Adolescents; 14 (1.3); 13 to 17 | 89; (49)^*^ | SWQ; Cutoff ≥ 5.3 | Parents | 13 | 0.83; (0.55 to 0.95) | 0.84; (0.74 to 0.90) | 4 to 22 | 139 to 156
Any Anxiety Disorder (at least one specific anxiety disorder)
Screen for Anxiety Related Emotional Disorders (PHQ-A)
Johnson et al, 2002^199^; Fair | 16 (1.2); 13 to 18 | 403; (63) | PHQ-A; Cutoff NR | Youth | 5 | 0.50; (0.30 to 0.70) | 0.98; (0.96 to 0.99) | 12 to 65 | 17 to 20
Screen for Anxiety Related Emotional Disorders (SCARED)
Muris et al, 2001^218^; Fair | 10 (1.4); 7 to 14 | 82; (61) | SCARED-C; NA | Youth | 20 | 0.88; (0.63 to 0.96) | 0.56; (0.44 to 0.67) | 3 to 16 | 383 to 429

* Percentage of females in Bailey is for entire sample.

Abbreviations: ANS=Autonomic Nervous System Questionnaire; CI=confidence interval; GAD=general anxiety disorder; KQ=key question; NA=not applicable; NR=not reported; PHQ-A=Patient Health Questionnaire—Adolescent; PI-ED=pediatric index of emotional distress; SAS=social anxiety scale; SAS-A (SASA)=social anxiety scale-adolescents; SASC=social anxiety scale for children; SCARED=Screen for Anxiety Related Emotional Disorders; SCARED-C=Screen for Anxiety Related Emotional Disorders Child version; SCARED-P=Screen for Anxiety Related Emotional Disorders – Parent version; SCARED-SP=Screen for Anxiety Related Emotional Disorders-Social Phobia Scale; SD=standard deviation; SPAI-B=social phobia and anxiety inventory-brief; SPIN=Social Phobia Inventory; SWQ=social worries questionnaire.

##### Global Anxiety

One study evaluated the SCARED^171^ to detect global anxiety. In the study of the SCARED, the authors administered the full version of 41 items and a short 10-item version to both children and their parents. Cutoff scores to determine a positive screener varied by screener and respondent. Using the reported index test thresholds,^171^ sensitivity ranged between 0.34 and 0.76, and specificity ranged between 0.68 and 0.87 for varying cutoffs on the screeners. With the exception of the full screener administered to children, all sensitivity values were lower than specificity values.

##### GAD

Three studies assessed screeners to detect GAD. One study^199^ assessed the PHQ-A. The sensitivity was 0.5 and the specificity was 0.98. The second study^218^ examined the SCARED-GAD scale, finding a somewhat higher sensitivity (0.64) but lower specificity (0.63) than the PHQ-A. The third study assessed the PI-ED (Anxiety Scale)^171^ and had a higher sensitivity (0.88) with a comparable specificity (0.85).

##### Panic Disorder

Two studies assessed screeners for detecting panic disorder—the ANS^230^ and the PHQ-A.^199^ The study of the ANS assessed accuracy for three versions, with two, three, and four questions. The sensitivity was 1.0 for all versions, whereas the specificity ranged between 0.47 and 0.66. The PHQ-A reported a sensitivity of 0.42 and a specificity of 0.99.

##### Separation Anxiety Disorder

Only one study^218^ examined a screener to detect separation anxiety disorder in adolescents. Using the SCARED—Separation Anxiety Scale, the study found sensitivity to be 0.88 and specificity 0.73.

##### Social Anxiety Disorder

Several studies reported on screeners to detect social anxiety disorder. Two studies assessed the SAS,^166,^ ^188^ one of which administered both the child and adolescent versions.^166^ The sensitivity of the SAS varied as a function of the respondent. In one study^188^ in which adolescents were the respondents, sensitivity was 0.93 but was 0.75 in another study^166^ when parents were responding about their adolescents’ symptoms. Specificity in the two studies was comparable—0.80^166^ and 0.78.^188^ Sensitivity and specificity for parent-reported social anxiety disorder in children^166^ was 0.78 and 0.74, respectively.

Three studies assessed the SPIN^231,^ ^250^ or the Mini-SPIN.^232^ Sensitivity was similar in the two SPIN studies: 0.82^231^ and 0.80,^250^ as was specificity: 0.85^231^ and 0.77,^250^ with similar thresholds for a positive screening: 24^231^ and 25.^250^ The study examining the Mini-SPIN^232^ found equally high sensitivity and specificity despite significantly fewer items (3 as opposed to 17 in the SPIN).

Reports on three other screeners to detect social anxiety disorder were in two studies. One study^188^ found that the Social Anxiety Scale for Adolescents (SASA) had sensitivity of 0.93 and specificity of 0.79 and that the SPAI-B had sensitivity and specificity of 0.86 and 0.88, respectively. The second study^166^ reported that the SWQ had sensitivity of 0.67 for detecting social anxiety disorder in children and 0.83 for detecting social anxiety disorder in adolescents; specificity was 0.94 in children and 0.84 in adolescents.

##### Any Anxiety Disorder

Two studies^199,^ ^218^ examined the utility of screeners to detect any anxiety disorder. One assessed the PHQ-A^199^ for detecting either panic disorder or GAD, finding a prevalence of 5 percent, sensitivity of 50 percent, and a specificity of 98 percent. The second study^218^ used the SCARED, combining the adolescents who screened positive for GAD, separation anxiety disorder, and/or social anxiety disorder. In this study, the prevalence was 20 percent, with a sensitivity of 0.88 and a specificity of 0.56.

Based on the reported sensitivity and specificity data, the number of false-negatives and false-positives per 1,000 screening tests at the lowest (2.5%)^199^ and highest (13)^166,^ ^219,^ ^230^ prevalence in an unselected population reported in the included studies is presented in Table 2. Three studies reported a higher prevalence for anxiety, but we did not use these values because they sampled all the screen-positive cases, resulting in an artificially high prevalence value. With the exception of the scales from the PHQ-A,^199^ the number of false-negatives is lower than the number of false-positives.

#### Results: Findings for Specific Populations

##### Subgroup Analyses

No subgroup analyses for specific populations were reported.

##### Findings Within Age Groups

Seven studies reported on adolescents , and reported on eight instruments (PHQ-A, ANS, SAS, SASA, SPAI-B, SCARED-SP, SPIN, Mini SPIN) for GAD, global anxiety, panic disorder, and social anxiety disorder.^166,^ ^188,^ ^199,^ ^230–232,^ ^250^ Inclusion criteria ranged from 12 to 18, with a mean age of 14.8.

Four studies reported on older children and adolescents on seven instruments (full scale, subscale, or short versions of SCARED, PI-ED, and SAS) for GAD, SAD, separation anxiety, and global anxiety.^166,^ ^171,^ ^270,^ ^271^ Inclusion criteria for these studies ranged 7 to 17 years, with a mean of 11.0 years.

No studies reported on younger children.

Only one study (Bailey et al. 2006^166^) reported results separately for adolescents and children for the same instruments (SCARED-SP, SAS-A, SAS-C, and SWQ); these results did not suggest consistent differences in sensitivity and specificity by age of the children, and variations in instruments and thresholds may explain differences in results. No other studies reported on both children and adolescents for a single instrument and condition.

Across instruments and conditions, differences between studies reporting on adolescents versus adolescents and children also did not suggest age-related patterns; the wide range of instruments, thresholds, and conditions preclude making conclusions about accuracy for children versus adolescents.

### Depression

We included seven fair-quality studies of diagnostic test accuracy.^170,^ ^172,^ ^189,^ ^199,^ ^219,^ ^223,^ ^235^ Two studies were new to this update.^172,^ ^219^ Brief study characteristics are provided in Table 3.

Table 3 Characteristics and Results of Test Accuracy Studies for Screening for Major Depressive Disorder Compared With Structured Clinical Interview (KQ 2)

| | | | | | | Per 1,000 Screens Across a Prevalence From 3% to 11% | Per 1,000 Screens Across a Prevalence From 3% to 11%
Author, Year; Quality | Age Range; Mean Age (SD), Years | Total N (% Female) | Index Test Cutoff | Prevalence (%) | Sensitivity | Specificity | No. False-Negatives | No. False-Positives
Beck Depression Inventory (BDI)
Canals et al, 2001^170^; Fair | 17.5 to 18.5; 18 (NR) | 290 (50) | ≥10; ≥11; ≥14; ≥16 | Unclear | 1.0; 0.90; 0.90; 0.90 | 0.82; 0.86; 0.92; 0.96 | 0 to 0; 3 to 11; 3 to 11; 3 to 11 | 175 to 160; 136 to 125; 78 to 71; 39 to 36
Roberts et al, 1991^235^; Fair | 15 to 18^*^; 16.6 (1.2) | 1,704 (53) | ≥11 | 3 | 0.84 | 0.81 | 5 to 18 | 184 to 169
Center for Epidemiologic Studies—Depression (CES-D)
Roberts et al, 1991^235^; Fair | 15 to 18^*^; 16.6 (1.2) | 1,704 (53) | ≥24 | | 0.84 | 0.75 | 5 to 18 | 243 to 223
Garrison et al, 1991^189^; Fair | 12 to 15; NR | 143 boys | ≥12; ≥16; ≥20; ≥22 | 8.2 | 0.85; 0.59; 0.19; 0.18 | 0.49; 0.66; 0.78; 0.83 | 5 to 17; 12 to 45; 24 to 89; 25 to 90 | 495 to 454; 330 to 303; 213 to 196; 165 to 151
| | 189 girls | ≥12; ≥16; ≥20; ≥22 | 8.7 | 0.84; 0.83; 0.84; 0.83 | 0.38; 0.53; 0.70; 0.77 | 5 to 18; 5 to 19; 5 to 18; 5 to 19 | 601 to 552; 456 to 418; 291 to 267; 223 to 205
Clinical Interview Schedule—Revised (CIS-R)
Patton et al, 1999^223^; Fair | NR^†^; 15.7 (0.5) | 158 (53^‡^) | NA^§^ | 6 | 0.18 (95% CI, 0.05 to 0.32)^‖^ | 0.97 (95% CI, 0.96 to 0.99)^¶^ | 25 to 90 | 29 to 27
Hopkins Symptom Checklist (HSCL)
Christensen et al, 2015^172^; Fair | 14 to 16; NR | 294 (NR) | ≥9 | 11 | 0.85 (95% CI, 0.70 to 0.94) | 0.78 (95% CI, 0.72 to 0.83) | 5 to 17 | 213 to 196
Patient-Health Questionnaire—Adolescent (PHQ-A)
Johnson et al, 2002^199^; Fair | 13 to 18; 16 (1.2) | 403 (63) | NA^§^ | 9 | 0.73 (calculated 95% CI, 0.58 to 0.85) | 0.94 (calculated 95% CI, 0.91 to 0.96) | 8 to 30 | 58 to 53
Pediatric Index of Emotional Distress (PI-ED) Depression Subscale
O’Connor et al, 2016^219^; Fair | 8 to 17; 12 (2.5) | 135 (48) | ≥8 | 11 | 0.94 (calculated 95% CI, 0.71 to 0.99) | 0.81 (calculated 95% CI, 0.73 to 0.87) | 2 to 7 | 184 to 169
World Health Organization Five Item Well-being Index (WHO-5)
Christensen et al, 2015^172^; Fair | 14 to 16; NR | 294 (NR) | ≥11 | 11 | 0.88 (95% CI, 0.74 to 0.96) | 0.80 (95% CI, 0.74 to 0.84) | 4 to 13 | 194 to 178

* This study enrolled persons in high school; 11% were younger than 15 and 13% were age 18 or older.

† The study targeted students in Year 9 of school.

ǂ Proportion in the full study sample; not all were included in the diagnostic test accuracy analysis.

§ Not applicable as test is scored according to an algorithm as either positive or negative.

‖ Based on weighted adjustment; the unweighted sensitivity was 0.74.

¶ Based on weighted adjustment; the unweighted specificity was 0.78.

Abbreviations: BDI=Beck Depression Inventory; CES-D=Center for Epidemiological Studies-Depression; CI=confidence interval; CIS-R=Clinical Interview Schedule-Revised; KQ=key question; NA=not applicable; NR=not reported; PI-ED=Pediatric Index of Emotional Distress; SD=standard deviation; WHO-5=World Health Organization Five Item Well-being Index.

#### Study Characteristics

Three studies were conducted in the United States,^189,^ ^199,^ ^235^ and the rest were conducted in various countries in Europe^170,^ ^172,^ ^219^ and Australia.^223^ One study^219^ enrolled both children and adolescents, while the rest enrolled only adolescents. Studies enrolled boys and girls in relatively equal proportions. In the studies conducted in the United States, the proportion of participants who were Black was between 1 percent and 25 percent; in the rest of the studies, participants were nearly entirely White or race and ethnicity was not reported. Two studies recruited participants from clinical settings (primary care,^172^ mix of primary care and outpatient mental health service^219^), one study recruited participants from primary care and school nurse offices,^199^ and the rest of the studies recruited from either school-based samples^189,^ ^223,^ ^235^ or the community.^170^

##### Index Screeners

Authors of the included studies assessed seven different screening instruments (Beck Depression Inventory [BDI],^170,^ ^235^ Center for Epidemiologic Studies-Depression [CES-D],^189,^ ^235^ Clinical Interview Schedule—Revised [CIS-R],^223^ Hopkins Symptom Checklist [HSCL],^172^ PHQ-A,^199^ PI-ED Depression Subscale,^219^ and the World Health Organization Five Item Well-Being Index [WHO-5]^172^). Some authors assessed more than one instrument or more than one threshold for a positive screen for the same instrument. Few studies prespecified thresholds for a positive screen. Appendix E Table 1 includes detailed screening test characteristics.

##### Reference Standards

Authors used clinical diagnostic interviews administered either concurrently or within 4 weeks of screening as a reference standard; most (but not all) reference standards were structured diagnostic clinical interviews tied to existing diagnostic criteria such as the DSM. Detailed reference standard information is included in Appendix E Table 2. All studies reported sensitivity and specificity for current MDD; many also reported positive and negative predictive value. Only one study reported results separately for boys and girls.^189^ No other data for specific populations were reported.

#### Results of Included Studies

The prevalence of major depression based on reference standard diagnostic clinical interviews ranged from 3 percent to 9 percent across studies enrolling persons recruited from school or community-based settings^170,^ ^189,^ ^223,^ ^235^ and was 11 percent in all three of the studies enrolling persons from nonpsychiatric clinical settings.^172,^ ^199,^ ^219^

Two studies evaluated the original BDI;^170,^ ^235^ the BDI-II published in 1996 was a substantial revision to the original BDI. Both studies reported sensitivity and specificity at a score threshold of 11 or higher (scores less than 9 are considered no or minimal depression, scores between 10 and 18 are considered “mild to moderate” depression^272^ in adults). At a score threshold of 11, the sensitivity and specificity were 0.84 and 0.81, respectively, in one study^219,^ ^235^ and 0.90 and 0.86, respectively, in the other study.^170^ One of these studies also provided estimates of sensitivity and specificity at lower and higher thresholds (Table 3).^170^

Two studies evaluated the CES-D but did not evaluate the same thresholds.^189,^ ^235^ On this instrument, a score of 16 or more is considered positive for subthreshold depression in adults.^273^ In one study, the sensitivity and specificity of a threshold score of 24 or more were 0.84 and 0.75, respectively.^235^ The other study reported sensitivity and specificity separately for boys and girls at four different scoring thresholds (12, 16, 20, and 22). At the threshold of 16, the sensitivity in boys was 0.59 and in girls was 0.83, and the specificity in boys was 0.66 and in girls was 0.53.^189^

The CIS-R,^223^ HSCL,^172^ PHQ-A,^199^ PI-ED,^219^ and WHO-5^172^ were each only evaluated in one study. Across these instruments, the reported sensitivity ranged from 0.18 to 0.94, and the specificity ranged from 0.80 to 0.97. The outlier values were for CIS-R (reported sensitivity of 0.18 and specificity of 0.97, from analysis weighting for selection into the second phase of the study).^223^ Calculated sensitivity without weighting resulted in a sensitivity of 0.74 and specificity of 0.78.^223^

Based on the reported sensitivity and specificity data, the number of false-negatives and false-positives per 1,000 screening tests at the lowest (3%)^235^ and highest (11%)^172,^ ^219^ prevalences reported in the included studies are reported in Table 3. For nearly all studies, the number of false-negatives is lower than the number of false-positives.

#### Results: Findings for Specific Populations

##### Subgroup Analyses

One study reported accuracy results separately for boys and girls for the CES-D instrument.^189^ The area AUC in boys was 0.61 and in girls was 0.77. Except for the lowest score threshold evaluated (greater than or equal to 12), the sensitivity in boys was markedly lower than in girls. The specificity at all four thresholds evaluated was higher in boys than in girls. Authors did not conduct formal statistical significance testing of these differences by sex.

The only study enrolling both children and adolescents did not report results separately by age.^219^ No studies reported results by any other specific populations prespecified in our research plan.

##### Findings Within Age Groups

Only one study, as noted above, enrolled children along with adolescents and did not report the results by age.^189^ All other studies were restricted to adolescents.

### Anxiety or Depression

Two fair-quality studies reported the accuracy of a positive screening test for either or both anxiety or depression diagnoses.^219,^ ^234^ One study reported on the sensitivity and specificity of the PI-ED for either GAD or MDD,^219^ and the other study reported on the accuracy of the 5-item Mental Health Index (MHI-5) for anxiety or depression.^234^

#### Study Characteristics

Authors conducted the study evaluating the PI-ED among youth ages 8 to 17 years (mean age 12 years) recruited from eight hospital outpatient pediatric departments in Scotland and from child and adolescent mental health clinics or psychology services.^219^ Nearly half (48%) were female, and nearly all were White. The-PI-ED test (score threshold of 20 or higher) was compared with the Computerized Diagnostic Schedule for Children, a type of structured clinical interview. Authors conducted the study evaluating the MHI-5 among youth ages 10 to 15 years (mean age 12 years) recruited from schools in Spain, and nearly half were female (49%). Authors evaluated both the full 5-item MHI-5 instrument and also the 3-item “distress” factor; the 2-item well-being factor was not evaluated. The MHI-5 screener was also compared with a structured clinical interview (Anxiety Disorders Interview Schedule for DSM-IV: Child and Parent Version).

#### Results of Included Studies

The sensitivity and specificity of the PI-ED for either a diagnosis of GAD, MDD, or both at a score threshold of 20 was 0.83 and 0.93, respectively.^219^ The AUC for the full MHI-5 instrument for anxiety or depression was 0.78 (95% CI, 0.64 to 0.93). The authors reported that the optimal threshold was a score of 3 or higher on the 3-item distress factor of the full MHI-5, which yielded a sensitivity of 0.69 and a specificity of 0.72 (AUC 0.80; 95% CI, 0.68 to 0.92 for the 3-item distress factor).^234^

#### Results: Findings for Specific Populations

##### Subgroup Analyses

Authors reported no results by specific populations of interest prespecified for this update.

##### Findings Within Age Groups

Both studies included children and adolescents; neither reported on children and adolescents separately.

## KQ 3 What Are the Harms Associated With Screening for Depression, Anxiety, or Suicide Risk in Primary Care or Comparable Settings in Children and Adolescents?

### Suicide Risk

#### Summary

We included two RCTs of fair quality (described in 2 articles).^267,^ ^268^ Neither study is new to this update. Detailed study, population, intervention characteristics, and results are provided in Appendix I Table 2 through Table 4.

#### Study Characteristics

We identified two fair-quality trials (total randomized N=2,675) conducted in high school settings relevant to this KQ.^267,^ ^268^ Both studies randomly assigned students to complete items relating to suicidal ideation and behaviors as part of an assessment of universal mental health screening^267^ or as part of larger questionnaires concerning the evaluation of a workshop.^268^ In the universal screening study (N=2,342), half of the classrooms in six high schools located in Nassau, Suffolk, and Westchester counties (New York State) were randomized to receive the suicide questions on the first day (intervention group), and the other half received them on the second day (control group).^267^ In the workshop evaluation study (N=333), half of the students in Year 10 at a single all-boys school in Melbourne, Australia, were randomized to receive the suicide items on the first day (intervention group), while the others received them on the second day (control group).^268^ Both studies compared measures of distress between Day 1 screened and Day 2 students to assess the impact of screening for suicidal risk.

#### Results

The universal screening study reported no differences in distress immediately after the screening questionnaire or in persistent distress (measured 2 days later) between the intervention and control groups as measured by the adolescent version of the Profile of Mood States (POMS-A).^267^ POMS-A is designed to capture transient mood states and is sensitive to change over short periods of time; detailed POMS-A results are reported in Appendix I Table 4.^267^ Similarly, a workshop evaluation study reported no significant difference in five of the six POMS-A subscales.^268^ One subscale (vigor) was significantly different between groups, but this may be due to chance.^268^

The universal screening measured suicidal ideation in both groups on the Day 2 survey and found no significant differences between groups (mean score 6.5 [standard deviation (SD): 11.5] vs. 6.2 [10.5], p=0.86) as measured by the Suicidal Ideation Questionnaire-Junior (SIQ-JR) instrument on the rates of participants with suicidal ideation between the first and second surveys (4.7% vs. 3.9%, p=0.49).^267^ These results suggest that exposure to the suicide screening items on Day 1 in the intervention group did not result in any increases in suicidal ideation.^267^

In the workshop evaluation study, authors asked students about their level of distress in answering questions about self-harm and suicide after both groups had answered the suicide screening items: 5.2 percent reported that it was “moderately distressing” and 3.7 percent reported that it was “very distressing.”^268^ Fifty percent reported that it was “not at all distressing.”^268^

Neither study examined screening-related harms by sex, race, or ethnicity.

### Depression

We did not identify any studies reporting on harms of screening for depression.

### Anxiety

We did not identify any studies reporting on harms of screening for anxiety.

### Anxiety or Depression

We did not identify any studies reporting on harms of screening in populations with anxiety or depression.

## KQ 4 Does Treatment (Psychotherapy, Pharmacotherapy, or Collaborative Care) of Depression, Anxiety, or Suicide Risk Result in Improved Health Outcomes in Children and Adolescents?

### Suicide Risk

#### Summary

We included 16 RCTs of good or fair quality (described in 23 articles).^164,^ ^179–182,^ ^191–194,^ ^197,^ ^200–202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^245,^ ^265^ Nine of these studies are new to this update.^164,^ ^179–181,^ ^192,^ ^194,^ ^202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236^ Detailed study, population, intervention characteristics, and results are provided in Appendix I Table 5 through Table 16. Detailed outcomes included in meta-analyses are provided in Appendix F Table 1 and Table 2. Meta-analysis forest plots are provided in Appendix G Figure 1 through Figure 7.

#### Study Characteristics

The characteristics of the included studies are summarized in Table 4. Fourteen studies admitted children based on elevated suicide risk,^164,^ ^179–181,^ ^191–194,^ ^197,^ ^200–202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^265^ and two studies admitted children with suicide risk and self-reported depressive symptoms (BDI>19^245^ or BDI>20^182^).

Table 4 Key Characteristics of Included Suicide Risk Studies

Study Characteristics | Subcharacteristics | Number of Studies | Percent
Population characteristics: | Child (mean age <13, ages range from 5 to 12 years) | 0 | 0
Child or adolescent | Adolescent (mean age ≥13, ages range from 11 to 19 years) | 16^164,^ ^179–182,^ ^191–194,^ ^197,^ ^200,^ ^202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^245,^ ^265^ | 100
| Both (mean age varies, ages range from 5 to 19 years) | 0 | 0
Population characteristics: | Mostly female | 16^164,^ ^179–182,^ ^191–194,^ ^197,^ ^200,^ ^202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^245,^ ^265^ | 100
Gender | Mostly male | 0 | 0
Population characteristics: | Mostly White | 11^164,^ ^191,^ ^192,^ ^194,^ ^197,^ ^200,^ ^202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236^ | 69
Race | Mostly non-White | 1^182^ | 6
| Not reported | 4^179–181,^ ^193,^ ^245,^ ^265^ | 25
Population characteristics: | Suicide only | 15^164,^ ^179–182,^ ^191–194,^ ^197,^ ^200,^ ^202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^245,^ ^265^ | 94
Diagnosis | Suicide and depression | 1^245^ | 6
Intervention characteristics: | Nonpharmacological | 16^164,^ ^179–182,^ ^191–194,^ ^197,^ ^200,^ ^202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^245,^ ^265^ | 100
Types of interventions | Pharmacological | 0 | 0
| Both | 0 | 0
Comparator | Treatment as usual | 15^164,^ ^179–182,^ ^191–193,^ ^197,^ ^200,^ ^202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^245,^ ^265^ | 94
| Attention control | 1^194^ | 6
Outcomes | Reporting benefits | 16^164,^ ^179–182,^ ^191–194,^ ^197,^ ^200,^ ^202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^245,^ ^265^ | 100
| Reporting harms | 2^179–181,^ ^192^ | 13
Geographic setting | United States of America | 6^164,^ ^182,^ ^194,^ ^197,^ ^200,^ ^202^ | 38
| United Kingdom | 6^179–181,^ ^191,^ ^192,^ ^221,^ ^222,^ ^236,^ ^265^ | 38
| Australia | 2^193,^ ^229^ | 13
| Norway | 1^212–215^ | 6
| Taiwan | 1^245^ | 6
Recruitment setting | Child and adolescent mental health services | 5^179–181,^ ^191–193,^ ^265^ | 31
| Emergency department | 1,^202^ | 6
| Psychiatic outpatient | 1^181,^ ^212–215^ | 6
| Schools | 2^197,^ ^245^ | 13
| Combination | 6^164,^ ^182,^ ^194,^ ^221,^ ^222,^ ^229,^ ^236^ | 38
| Not specified | 1^200^ | 6
Treatment setting | In person | 11^164,^ ^179–182,^ ^191–193,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^265^ | 69
| Web/computer | 1^194^ | 6
| Combination (computer, in person, phone) | 4^197,^ ^200,^ ^202,^ ^245^ | 25

Mean ages ranged from 14 to 18 years. All 16 included studies focused on adolescents (ages 11 to 19 years)^164,^ ^179–182,^ ^191–194,^ ^197,^ ^200–202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^245,^ ^265^ and included a majority of female participants. Ten studies reported a majority of White participants,^164,^ ^191,^ ^192,^ ^194,^ ^197,^ ^200–202,^ ^221,^ ^222,^ ^229,^ ^236^ one study included a majority of African American participants,^182^ and five studies did not report race or ethnicity.^179–181,^ ^193,^ ^212,^ ^245,^ ^265^

All included studies examined psychotherapy, counseling, support, or a combination with variable intensity and duration. Fifteen studies compared these interventions with treatment as usual (TAU),^164,^ ^179–182,^ ^191–193,^ ^197,^ ^200–202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^245,^ ^265^ and one study compared intervention to attention control.^194^ Fifteen of the included trials^164,^ ^179–182,^ ^191–194,^ ^200–202,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^236,^ ^245,^ ^265^ examined one active arm, and one trial^194^ examined three active treatment arms. Five trials included individual child-/adolescent-only interventions,^194,^ ^197,^ ^202,^ ^221,^ ^222,^ ^245^ three included child-/adolescent-only group-based interventions,^191–193^ one included family-based intervention,^179–181^ three included caregiver-/supporting adult–only interventions,^197,^ ^200,^ ^201,^ ^229^ and six included a combination of individual child-/adolescent-, caregiver-/supporting adult-, group-, or family-based interventions.^164,^ ^182,^ ^197,^ ^212–215,^ ^236,^ ^265^ Duration of treatment ranged between one single session to weekly sessions over 12 months. Overall, 11 trials^164,^ ^179–182,^ ^191–193,^ ^212–215,^ ^229,^ ^236,^ ^245,^ ^265^ examined interventions that required 3 or more sessions), and five trials^194,^ ^197,^ ^200–202,^ ^221,^ ^222^ examined interventions requiring fewer than 3 sessions). No evidence was captured that examined pharmacotherapies.

All 16 studies reported on suicide or self-harm–related outcomes, 13 studies reported on depression,^179–182,^ ^191–194,^ ^197,^ ^200,^ ^202,^ ^212–215,^ ^236,^ ^245,^ ^265^ three studies reported on anxiety,^192,^ ^197,^ ^245^ one trial reported on burdensomeness,^194^ eight studies reported on functioning,^179–181,^ ^191,^ ^193,^ ^200,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^265^ two studies reported on response,^182,^ ^194^ and one study reported on all-cause mortality.^201^ Time of measurement across all outcomes ranged from 2 weeks to 14 years.

Two studies recruited participants from schools;^197,^ ^245^ five recruited from child and adolescent mental health services; one recruited from emergency departments and community mental health services;^229^ two recruited from emergency departments and child and adolescent mental health services;^221,^ ^222,^ ^236^ one recruited from emergency departments and primary care offices;^182^ one recruited from emergency departments, inpatient/patient hospitalization, and outpatient services;^164^ one recruited solely from a hospital emergency department;^202^ one recruited from psychiatric outpatient clinics;^181,^ ^212–215^ one recruited participants from schools and public gathering places frequented by adolescents;^194^ and one study recruited participants from inpatient settings following psychiatric hospitalization.^200,^ ^201^

Included studies were conducted in the United States,^164,^ ^182,^ ^194,^ ^197,^ ^200–202^ United Kingdom,^179–181,^ ^191,^ ^192,^ ^221,^ ^222,^ ^236,^ ^265^ Australia,^193,^ ^229^ Norway,^181,^ ^212–215^ and Taiwan.^245^ Six of the included studies^179–181,^ ^191,^ ^193,^ ^194,^ ^212–215,^ ^265^ were rated as good quality, and 10 studies^164,^ ^182,^ ^192,^ ^197,^ ^200–202,^ ^221,^ ^222,^ ^229,^ ^236,^ ^245^ were rated fair quality. Two of the included studies reported on specific populations of interest.^179–182^

#### Results: Suicide Deaths

##### Psychotherapy, Counseling, Support, or Combined Interventions vs. Treatment as Usual or Attention Control

Three studies reported on the effects of suicide or self-harm interventions with variable intensity and duration on suicide deaths at the end of treatment (19 weeks to 12 months).^191,^ ^200,^ ^212–215^ Studies compared dialectical behavior therapy (DBT),^212–215^ youth-nominated support team,^200^ or group therapy^191^ with TAU. Two of the interventions^191,^ ^212–215^ were high contact (>3 sessions), and one intervention^200^ was low contact (<3 sessions). Two studies^191,^ ^212–215^ reported no suicide deaths at the end of treatment in either arm. One study, using a youth-nominated support team approach (n=346) reported no statistically significant differences between intervention and control at the end of treatment (0 vs. 1, p=NR).^200^ A longer term followup of that study, 11 to 14 years after psychiatric hospitalization for suicide risk (baseline for the study), found no statistically significant differences in suicide-related deaths.^201^ One study of DBT continued to record no deaths in either arm at the 3-year followup.^212–215^

#### Results: Suicide-Related Hospitalization or Emergency Department Use

##### Psychotherapy, Counseling, Support, or Combined Interventions vs. Treatment as Usual or Attention Control

Five studies reported on the effects of suicide or self-harm interventions with variable intensity and duration on suicide-related hospitalization or emergency department use at the end of treatment (12 weeks to 2 years) (Appendix F Table 1).^164,^ ^179–181,^ ^192,^ ^212–215,^ ^221,^ ^222^ Four studies reported nonsignificant differences between intervention and TAU, and one study^164^ reported significant differences. Included studies examined family therapy,^179–181^ DBT,^212–215^ therapeutic assessment,^221,^ ^222^ mentalization-based therapy (MBT)^192^, and CBT.^164^ Four of the interventions^164,^ ^192,^ ^212–215^ were high contact (≥3 sessions), and one intervention^221,^ ^222^ was low contact (<3 sessions).

Results were pooled for the three studies reporting on use of hospitals or emergency departments: hospital attendance for self-harm,^179–181^ self-harm presentation to accident and emergency department,^221,^ ^222^ or self-harm presentation to emergency department.^212–215^ These studies resulted in a pooled RR of 0.998 (Appendix G Figure 1, 95% CI, 0.67 to 1.50; N=978; k=3; I^2^=21%; p=0.28). One study did not report sufficient data to permit pooling and reported no statistically significant differences in the mean number of self-harm emergency department presentations between MBT and TAU (0.36 vs. 0.23, p=NR).^192^ A fifth study^164^ reported significant differences between intervention and TAU; the study reported that the probability of survival at 3-month post-treatment without an emergency department visit for suicidality was lower for the TAU group (0.71, SE 0.11) compared with CBT (0.90, SE 0.07, Z=2.00, p=0.045, number needed to treat=5.26); in sensitivity analyses, these differences were no longer statistically significant. The differences for hospitalization were not statistically significantly different.

The study reporting on self-harm presentation to emergency departments also reported on hospital admissions due to self-harm and found no statistically significant differences between DBT and TAU (2% vs. 5%, p=NS).^212–215^

One study reported on hospital attendance for self-harm event at 12 months, 18 months, and 36 months and continued to find no statistically significant differences between family therapy and TAU.^179–181^ One study of MBT continued to report no statistically significant differences between arms in mean number of self-harm emergency department presentations at 24 weeks.^192^

#### Results: Suicide Attempts or Episode of Deliberate Self-Harm

##### Psychotherapy, Counseling, Support, or Combined Interventions vs. Treatment as Usual or Attention Control

Nine studies reported on the effects of suicide or self-harm interventions with variable intensity and duration on suicide attempts or episodes of deliberate self-harm at the end of treatment (0 to 36 months).^164,^ ^179–181,^ ^191–193,^ ^200,^ ^212–215,^ ^236,^ ^265^ Included studies compared DBT-informed CBT,^164^ family therapy,^179–181^ group psychotherapy,^191,^ ^193^ MBT,^192^ youth-nominated support team,^200^ DBT,^212–215^ mentalization-based treatment,^236^ or developmental group therapy^265^ with TAU. Eight of the interventions^164,^ ^179–181,^ ^191–193,^ ^212–215,^ ^236,^ ^265^ were high contact (>3 sessions), and one intervention^200^ was low contact (<3 sessions). Studies reported on a variety of outcomes including mean number of self-harm events,^179–181,^ ^212–215,^ ^265^ number of self-harm events,^179–181,^ ^191,^ ^193,^ ^236,^ ^265^ number of suicide attempts,^200^ frequency of self-harm,^191^ severity of self-harm,^191^ Risk-Taking and Self-Harm Inventory for Adolescents (RTSHI),^192,^ ^236^ nonsuicidal self-injury,^164^ and percentage with suicide ideation.^164^ Study sample sizes ranged from 42 to 832. The most commonly reported measures were mean number of self-harm events and number of self-harm events. The detailed results of the included studies are summarized in Appendix F Table 1.

Table 5 presents pooled estimates of effect for end-of-treatment measures, specifically mean number of self-harm events (3 studies)^179–181,^ ^212–215,^ ^265^ and proportion of self-harm events (5 studies).^179–181,^ ^191,^ ^193,^ ^236,^ ^265^ Both estimates of effect were not statistically significant and had wide confidence intervals. One study, included in the meta-analysis of posttreatment results, continued to report statistically nonsignificant differences in number of self-harm events between arms at the 1-year. At the 3-year followup, unadjusted analyses favored the intervention. After adjustment for variables used in stratification at randomization (gender, presence of depressive disorder at the time of randomization, and having had at least one suicide attempt within the last 4 months), the differences were no longer statistically significant.^212–215^

Table 5 Suicide Attempts or Episode of Deliberate Self-Harm for Suicide or Self-Harm Interventions: Pooled Estimates

Intervention | Time of Outcome Measurement | Outcome Measure, Range, Threshold | Treatment Range at Followup | Comparator Range at Following | Pooled Results
Family therapy, DBT, developmental group therapy | 19 weeks to 18 months | Mean number of self-harm events | 0.6 to 9.0 | 1.2 to 22.50 | Mean difference: −0.76 (95% CI, −2.15 to 0.63); N=972; k=3;^179–181,^ ^212–215,^ ^265^ I^2^=68; Appendix G Figure 2
Group psychotherapy, family therapy, mentalization-based treatment, developmental group therapy | 6 to 18 months | Proportion with self-harm events | 0.55 to 88 | 1.1 to 83 | RR: 0.88 (95% CI, 0.63 to 1.24); N=1,040; k=5;^179–181,^ ^191,^ ^193,^ ^236,^ ^265^ I^2^=80; Appendix G Figure 3

Abbreviations: CI=confidence interval; DBT=dialectical behavior therapy; k=number of studies; I^2^=percentage of variation across studies that is due to heterogeneity rather than chance; N=number; OR=odds ratio.

Five studies^164,^ ^191,^ ^192,^ ^200,^ ^265^ reported on other suicide attempt or deliberate self-harm outcomes (number of suicide attempts, frequency of self-harm, severity of self-harm, number of persons repeating self-harm, nonsuicidal self-injury, percentage with suicide ideation, and RTSHI) posttreatment (0 to 12 months). Included studies compared DBT-informed CBT,^164^ group psychotherapy,^191^ MBT,^192^ youth-nominated support team,^200^ or developmental group therapy^265^ with TAU. Four of the interventions^164,^ ^191,^ ^192,^ ^265^ were high contact (>3 sessions), and one intervention^200^ was low contact (<3 sessions). These results did not consistently demonstrate statistically significant differences favoring the intervention arm. Studies reported significant differences between intervention and TAU on the outcomes of number of persons repeating self-harm (6% vs. 32%; OR, 6.3 [95% CI, 1.4 to 28.7]),^265^ percentage with suicide ideation (0% vs. 18.2%; p=0.01),^164^ and nonsuicidal self-injury (estimated probabilities of survival without: 0.55 vs. 0.43; p=0.05).^164^ No statistically significant differences were reported when the intervention was compared with TAU on the number of suicide attempts,^200^ frequency of self-harm,^191^ severity of self-harm,^191^ and RTSHI scores.^192^ A study of group psychotherapy continued to report no statistically significant differences in frequency and severity of self-harm between arms at 6 to 12 months.^191^ A study of MBT continued to report no statistically significant differences in RTSHI total score and RTSHI self-harm subscales between arms at 24 and 36 weeks.^192^

#### Results: Suicidal Ideation

##### Psychotherapy, Counseling, Support, or Combined Interventions vs. Treatment as Usual or Attention Control

Twelve studies reported on the effects of suicide or self-harm interventions with variable intensity and duration on measures of suicide risk.^179–182,^ ^191,^ ^193,^ ^194,^ ^197,^ ^200,^ ^202,^ ^212–215,^ ^236,^ ^245,^ ^265^ Included studies compared family therapy,^179–181^ attachment-based therapy,^182^ group psychotherapy,^191,^ ^193^ youth-nominated support team,^200^ motivational interviewing,^202^ DBT,^212–215^ MBT,^236^ intensive interpersonal psychotherapy for depressed adolescents with suicidal risk (IPT-A-IN),^245^ internet-based CBT,^194^ child interview with counseling,^197^ parent sessions,^197^ child interview with counseling plus parent sessions,^197^ or developmental group therapy.^265^ Eight of the interventions^179–182,^ ^191,^ ^193,^ ^212–215,^ ^236,^ ^245,^ ^265^ were high contact (>3 sessions), and four interventions^194,^ ^197,^ ^200,^ ^202^ were low contact (<3 sessions). Eleven studies compared intervention with TAU,^179–182,^ ^191,^ ^193,^ ^197,^ ^200,^ ^202,^ ^212–215,^ ^236,^ ^245,^ ^265^ and one study compared intervention with attention control.^194^ Studies reported on a variety of measures including the Beck Scale for Suicide Ideation (BSS), Beck Hopelessness Scale (BHS), Suicidal Ideation Questionnaire (SIQ), SIQ-JR, Hopelessness Scale for Children (HSFC), Scale for Suicidal Ideation (SSI), Adolescent Suicide Questionnaire–Revised (ASQ-R), burdensomeness, and individual suicide risk indicators. Study sample sizes ranged from 48 to 832. The detailed results of the included studies are summarized in Appendix F Table 2.

The most commonly reported measures were the BHS, SIQ-JR, and SIQ. Table 6 presents pooled estimates for these measures. Our studies^200,^ ^202,^ ^212–215,^ ^245^ reported on the BHS at the end of treatment (2 months to 19 weeks).

Table 6 Suicidal Ideation for Suicide or Self-Harm Interventions: Pooled Estimates

Intervention | Time of Outcome Measurement | Outcome Measure, Range, Threshold | Outcome Range | Outcome Threshold Indicating Clinically Meaningful Effect | Treatment Range at Followup | Comparator Range at Following | Pooled Results
Youth-nominated support team, motivational interviewing, DBT, IPT-A-IN | 2 months to 19 weeks | BHS | 0 to 20^304^ | ≥9 indicative of suicide intentions^304^ | 5.66 to 7.74 | 7.80 to 12.42 | Mean difference: −2.35 (95% CI, −4.06 to −0.65); N=644; k=4;^200,^ ^202,^ ^212–215,^ ^245^ I^2^=46%; Appendix G Figure 4
Attachment-based family therapy, group psychotherapy, group therapy, youth-nominated support team, motivational interviewing, DBT, developmental group therapy | 2 months to 71 weeks | SIQ or SIQ-Jr | SIQ: 0 to 180; SIQ-JR: 0 to 90^305^ | SIQ ≥:41^306^ indicative of suicidal ideation; SIQ-JR^307^ ≥ 31 indicative of suicidal ideation | SIQ: 41.3 to 74.11; SIQ-JR: 5.2 to 25.55 | SIQ: 39.7 to 76.40; SIQ-JR: 16.2 to 29.71 | Standardized mean difference^*^: −0.18 (95% CI, −0.36 to 0.01); N=1,111; k=7;^182,^ ^191,^ ^193,^ ^200,^ ^202,^ ^212–215,^ ^265^ I^2^=45%; p=0.09; Appendix G Figure 5

* Results standardized to pool across two different instruments.

Abbreviations: BHS=Beck Hopelessness Scale; CI=confidence interval; DBT=dialectical behavior therapy; IPT-A-IN=intensive interpersonal psychotherapy for depressed adolescents with suicidal risk; k=number of studies; I^2^=percentage of variation across studies that is due to heterogeneity rather than chance; N=number; SIQ=Suicidal Ideation Questionnaire ; SIQ-Jr=Suicidal Ideation Questionnaire-Junior.

Seven studies^182,^ ^191,^ ^193,^ ^200,^ ^202,^ ^212–215,^ ^265^ reported on the SIQ or SIQ-JR at the end of treatment (2 months to 7 months). The pooled estimate for the BHS was statistically significant and favored treatment arms when compared with controls. The pooled estimate and results from individual studies for the SIQ/SIQ-J, however, favored treatment arms, but the confidence intervals spanned the null.

Regarding longer term outcomes, findings were mixed. Two studies reporting nonsignificant differences on the BHS at 6 weeks and 19 weeks posttreatment continued to report nonsignificant differences on the BHS at additional follow-ups ranging between 3 months and 3.1 years.^200,^ ^212–215^ One study of attachment-based family therapy continued to find statistically significant differences favoring the intervention arm on the SIQ-JR between arms at 24 weeks.^182^ One study of youth-nominated support team continued not to find statistically significant differences on the SIQ-JR between study arms at 3 months or 12 month.^200^ One study of DBT continued not to find any significant difference between study arms on the SIQ-JR at 3.1 years.^212–215^ A study of group psychotherapy^191^ and a study of group therapy^193^ both continued not to find statistically significant differences on the SIQ at 12 months.

Six studies^179–182,^ ^194,^ ^197,^ ^229,^ ^245^ reported on other suicide risk measures (ASQ-R, BSS, HSFC, SSI, individual suicide risk indicators) at the end of treatment (2 weeks to 12 months) that we could not pool because studies used heterogeneous measures or were not sufficient to pool.

Three studies reported on the BSS at the end of treatment, but the specific measures could not be pooled.^179–181,^ ^194,^ ^245^ Specifically, one study reported that a smaller proportion of participants in family therapy reported suicide ideation based on the BSS compared with TAU at the end of treatment (OR, 0.64 [95% CI, 0.44 to 0.94]; p=0.024), but no statistically significant differences were reported at the 18-month followup (OR, 0.76 [95% CI, 0.49 to 1.16]; p=0.20).^179–181^ Two additional studies reported continuous measures of the BSS and found inconsistent results. One reported a statistically significant difference between the IPT-A-IN and TAU at the end of treatment (6 weeks, 8.73 vs. 11.89; p=0.05),^245^ and one reported no statistically significant differences between internet CBT and information-only control at the end of treatment (2.05 vs. 4.49, p=0.12) and at the 8-week followup (1.69 vs. 2.57; p=0.92).^194^

Results from other single studies on the ASQ-Jr, HSFC, SSI, and individual suicide risk indicators generally demonstrated at least some statistically significant benefit for suicide risk intervention.^182,^ ^197,^ ^229^ The only exception was one study that found no differences on the HSFC, but the same study found significantly lower odds of suicidal ideation using the BSS, as noted above.^179–181^

One study^194^ reported on the effects of suicide or self-harm intervention on perceived burdensomeness at the end of treatment (2 weeks) and 8 weeks posttreatment. The study compared internet CBT with information-only control. The study reported no statistically significant differences in mean perceived burdensomeness scores between internet CBT and information control at posttreatment (17.76 vs. 18.81, p=0.26) or at 8 weeks posttreatment (13.90 vs. 15.8; p=0.10).

#### Results: Response, Remission, and Loss of Diagnosis

##### Psychotherapy, Counseling, Support, or Combined Interventions vs. Treatment as Usual or Attention Control

Two studies reported on the effects of suicide or self-harm intervention on clinical response at the end of treatment (8 to 12 weeks).^182,^ ^194^ One study compared attachment-based therapy to enhanced usual care and reported statistically significant differences between groups, favoring intervention.^182^ The study reported greater clinical response in the intervention group compared with TAU based on SIQ-JR scores (defined as ≤13) at the end of treatment and 24 weeks posttreatment (12 weeks: 87% vs. 52%, OR, 6.30 [95% CI, 1.76 to 22.61]; 24 weeks: OR, 4.41; p=0.008). The study also reported that intervention was associated with greater clinical response based on SSI scores (defined as 0 vs. 1 suicide attempt) at the end of treatment and at the 24-week followup (12 weeks: 69% vs. 35%, OR, 4.45 [95% CI, 1.33 to 13.56]; 24 weeks: OR, 5.37 [95% CI, 1.56 to 18.48], p=0.006). A second study comparing internet CBT to information-only control reported no statistically significant differences in response (defined as perceived burdensomeness <14.61) between groups (24% vs. 10%, calculated OR, 2.82 [95% CI, 0.80 to 9.91]) at the end of treatment (8 weeks).^194^

#### Results: All-Cause Mortality

##### Psychotherapy, Counseling, Support, or Combined Interventions vs. Treatment as Usual or Attention Control

A long-term followup of a study on a youth-nominated support team approach,^200^ 11 to 14 years after psychiatric hospitalization for suicide risk (baseline for the study), found a higher number of deaths in the National Death Index in the treatment as usual group when compared with the active treatment group (13/225 vs. 2/223; hazard ratio: 6.62 [95% CI, 1.49 to 29.35]).^201^ The National Death Index can under-ascertain deaths.^274^ The same study did not demonstrate an effect on the primary outcome of suicidal ideation; as a result, findings by chance or through other mechanisms of action (such as improved problem solving) cannot be ruled out.

#### Results: Functioning

##### Psychotherapy, Counseling, Support, or Combined Interventions vs. Treatment as Usual or Attention Control

Eight studies reported on the effects of suicide or self-harm interventions compared with TAU on functioning outcomes in adolescents.^179–181,^ ^191,^ ^193,^ ^200,^ ^212–215,^ ^221,^ ^222,^ ^229,^ ^265^ Table 7 presents pooled estimates of effect for end-of-treatment outcomes on the Health of the Nation Outcome Scales for Children and Adolescents (HoNOSCA)^191,^ ^193,^ ^229,^ ^265^ and Children’s Global Assessment Scale (CGAS).^193,^ ^213,^ ^222^ Both estimates of effect found no statistically significant differences in functioning and had wide confidence intervals spanning the null.

Table 7 Functioning for Suicide or Self-Harm Interventions: Pooled Estimates

Intervention | Time of Outcome Measurement | Outcome Measure, Range, Threshold | Outcome Range | Outcome Threshold Indicating Clinically Meaningful Effect | Treatment Range at Followup | Comparator Range at Followup | Pooled Results
Group psychotherapy; group therapy; developmental group therapy; psychoeducation for parents | 8 weeks to 7 months | HoNOSCA | 0 to 52^308^ | Scores greater than 13 indicate impairment of clinical significance | 8.4 to 16.8 | 6.9 to 17.6 | Mean difference: −0.40 (95% CI, −2.55 to 1.78); N=509; k=4;^191,^ ^193,^ ^229,^ ^265^; I^2^=56%; Appendix G Figure 6
Therapeutic assessment; individual and family DBT; group therapy | 8 to 71 weeks | CGAS | 1 to 100^309^ | >70: no clinically significant functional impairment; <41: major impairment to functioning in several areas^309^ | 58.5 to 65.7 | 60.1 to 64.22 | Mean difference: 1.30 (95% CI, −2.52 to 5.12); N=195; k=3;^193,^ ^213,^ ^222^; I^2^=30%; Appendix G Figure 7

Abbreviations: CGAS=Children’s Global Assessment Scale; CI=confidence interval; DBT=dialectical behavior therapy; HoNOSCA=Health of the Nation Outcome Scales for Children and Adolescents; I^2^=percentage of variation across studies that is due to heterogeneity rather than chance; k=number of studies; N=number; RR=relative risk.

Regarding longer term outcomes, one study^229^ included the meta-analysis for HoNOSCA and demonstrated a statistically significant improvement in functioning favoring at the intervention group posttreatment also found statistically significant differences favoring the intervention group at the 6-month followup (M [SD]=4.77 [4.45] vs. 12.72 [5.29], p<.01).

Three studies reporting on other measures of functioning including the Child and Adolescent Functional Assessment Scale (CAFAS),^200^ General Health Questionnaire (GHQ),^180^ Pediatric Quality of Life Enjoyment and Satisfaction Questionnaire (PQ-LES),^180^ and Strengths and Difficulties Questionnaire (SDQ),^193^ reported nonsignificant differences in functioning outcomes at posttreatment and followup.

#### Results: Findings for Specific Populations

##### Subgroup Analyses

Findings for specific populations are reported in Appendix I Table 15. No studies reported results by race/ethnicity, sexual identity, or gender orientation. One study^179^ comparing family therapy (N=415) with TAU (N=417) reported nonsignificant differences in hospital attendances for self-harm events as a function of age (chi-square: 0.4730, p=0.49) or sex (chi-square: 1.5219, p=0.2173).

##### Findings Within Age Groups

All studies reported results for adolescent participants.

### Anxiety

#### Summary

As noted previously, we limited the synthesis to CBT for psychotherapy; we included pharmacotherapies approved by the FDA for children and adolescents. We included 29 RCTs (described in 40 articles) of good or fair quality.^163,^ ^165,^ ^167–169,^ ^177,^ ^178,^ ^183,^ ^190,^ ^195,^ ^196,^ ^198,^ ^203,^ ^206,^ ^220,^ ^224–228,^ ^237–244,^ ^246,^ ^251,^ ^253–262^ All studies are new to this report because this topic has not been addressed previously by the Task Force. Detailed study, population, intervention characteristics, and results are provided in Appendix I Tables 17 through 22. Detailed outcomes are provided in Appendix F Table 3 through Table 11. Meta-analysis forest plots are provided in Appendix G Figure 8 through Figure 24.

#### Study Characteristics

The characteristics of the included trials are summarized in Table 8. Sixteen studies enrolled children with any anxiety disorder to the trial.^163,^ ^167,^ ^168,^ ^177,^ ^183,^ ^190,^ ^195,^ ^198,^ ^203,^ ^206,^ ^237,^ ^241,^ ^242,^ ^246,^ ^251,^ ^253^ The most common primary diagnoses in these studies were social anxiety disorder and GAD. Of the studies requiring specific anxiety disorders for trial eligibility, five required GAD,^196,^ ^224,^ ^238,^ ^243,^ ^244^ four required social anxiety disorder,^165,^ ^220,^ ^239,^ ^240^ two required selective mutism,^169,^ ^178^ and two required either GAD, social anxiety disorder, or separation anxiety.^225–228,^ ^254–262^ Nine studies set a threshold for severity, ranging from requiring clinically important symptoms or functional impairment to specific minimum thresholds on the Clinical Global Impressions-Severity (CGI-S), Pediatric Anxiety Rating Scale (PARS), or anxiety disorders interview schedule for DSM-IV for Children-Children/Parents (ADIS-C/P) clinician severity ratings (CSR).^168,^ ^196,^ ^220,^ ^225–227,^ ^237,^ ^238,^ ^243,^ ^251^

Table 8 Key Characteristics of Included Anxiety Studies for Benefits

Study Characteristics | Subcharacteristics | Number of Studies | Percent
Population characteristics: Child or adolescent | Child (mean age <13) | 24 | 82.7
| Adolescent (mean age ≥13) | 5 | 17.39
Population characteristics: Gender | Mostly female | 19 | 65.5
| Mostly male | 9 | 31.0
| Equal distribution | 1 | 3.4
Population characteristics: Race | Mostly White | 17 | 58.6
| Mostly non-White | 1 | 3.4
| Not reported | 11 | 37.9
Population characteristics: Diagnosis | Any anxiety disorder | 17 | 58.6
| GAD | 5 | 17.2
| Social anxiety disorder | 4 | 13.8
| Selective mutism | 2 | 6.9
| GAD, social anxiety disorder, or separation anxiety | 1 | 3.4
Intervention characteristics: Types of interventions | Nonpharmacological | 22 | 75.9
| Pharmacological | 6 | 20.7
| Multiple arms of CBT, pharmacotherapy, and combination | 1 | 3.4
Comparator | Treatment as usual | 2 | 6.9
| Placebo comparator | 7 | 24.1
| Wait-list comparator | 20 | 69.0
Geographic setting | United States | 10 | 34.5
| Australia | 6 | 20.7
| United Kingdom | 3 | 10.3
| Denmark | 2 | 6.9
| Germany | 2 | 6.9
| Norway | 1 | 3.4
| Hong Kong | 1 | 3.4
| Japan | 1 | 3.4
| Spain | 1 | 3.4
| Sweden | 1 | 3.4
| Multiple countries | 1 | 3.4
Recruitment setting^*^ | Community recruitment | 15 | NA
| Referrals from mental health professionals | 10 | NA
| Schools | 13 | NA
| Not specified | 2 | NA

* Studies may recruit from multiple settings.

Abbreviations: CBT=cognitive behavioral therapy; GAD=generalized anxiety disorder.

The mean age of enrolled populations ranged from 4.1 to 17.4 years. Three studies focused on early childhood (ages 3 to 7 years),^183,^ ^195,^ ^237^ 11 focused on later childhood (ages 6 to 14 years),^165,^ ^167,^ ^178,^ ^196,^ ^203,^ ^206,^ ^220,^ ^240,^ ^241,^ ^246,^ ^251^ 11 spanned childhood and adolescence,^163,^ ^168,^ ^169,^ ^177,^ ^190,^ ^198,^ ^224–228,^ ^238,^ ^243,^ ^254–262^ and four focused solely on adolescence.^239,^ ^242,^ ^244,^ ^253^ Nine of 29 studies had a majority of male participants.^167,^ ^203,^ ^206,^ ^225–228,^ ^237,^ ^238,^ ^246,^ ^251^

Nineteen of 29 studies provided information about the race or ethnicity of enrolled populations. With the exception of one study with all Japanese participants (set in Japan).^198^ White participants were a majority in all studies.^168,^ ^177,^ ^178,^ ^190,^ ^195,^ ^206,^ ^224–228,^ ^237,^ ^238,^ ^241,^ ^243,^ ^244,^ ^246,^ ^251,^ ^253–262^

Pharmacotherapy trials, with one exception,^169^ used narrow inclusion criteria and excluded persons with other psychiatric conditions. In contrast, psychotherapy trials did not routinely exclude participants with other psychiatric conditions.

Half the studies advertised widely for recruitment.^165,^ ^167,^ ^168,^ ^177,^ ^178,^ ^183,^ ^190,^ ^195,^ ^196,^ ^198,^ ^203,^ ^206,^ ^239,^ ^241,^ ^242^ A minority of studies relied solely on referrals from mental health professionals,^163,^ ^220,^ ^224–228,^ ^237,^ ^238,^ ^244,^ ^246,^ ^251,^ ^253^ two were recruited entirely through schools,^169,^ ^240^ and two did not specify the clinical setting for recruitment.^243,^ ^254–262^ Ten studies recruited participants from the United States,^168,^ ^169,^ ^178,^ ^190,^ ^195,^ ^225–228,^ ^237,^ ^238,^ ^244,^ ^254–262^ and one drew from multiple countries, including the United States, Mexico, and South Africa, but had a majority of participants from the United States.^243^ The other 19 studies recruited participants from other countries with a very high human development index, namely Australia, the United Kingdom, Denmark, Germany, Norway, Hong Kong, Japan, Spain, and Sweden.

With respect to interventions evaluated, 22 RCTs evaluated CBT,^163,^ ^165,^ ^167,^ ^177,^ ^178,^ ^190,^ ^195,^ ^196,^ ^198,^ ^203,^ ^206,^ ^220,^ ^224,^ ^237,^ ^239,^ ^241,^ ^242,^ ^246,^ ^251,^ ^253^ six evaluated pharmacotherapy,^168,^ ^169,^ ^225–228,^ ^238,^ ^243,^ ^244^ and one evaluated both CBT and pharmacotherapy and combinations of CBT and sertraline.^254–262^ As a reminder, psychological interventions in this review for the USPSTF were limited to CBT because it is the most commonly used intervention for anxiety disorders. Our search identified other types of psychological interventions used to treat anxiety disorders, and these are cataloged in Appendix A.

The most commonly studied CBT intervention was individually directed CBT, and the most commonly studied pharmacotherapies were sertraline and fluoxetine. Typically, these interventions were compared with wait-list for CBT and placebo for pharmacotherapy.

For CBT, the duration of therapy ranged from 5 days for group CBT to 31 weeks for individual CBT. The modal duration was 12 weeks. Although trials commonly reported weekly therapy lasting for 30 to 90 minutes, the intensity of treatment could be as high as 5 consecutive days of six to eight hour-long sessions for a 5-day group CBT trial^178^ or 25 individual 50-minute sessions for the 31-week therapy.^239^

Studies relied largely on in-person delivery of interventions; two studies reported on internet CBT.^242,^ ^253^

Fourteen CBT studies reported results comparing a single treatment arm with wait-list control.^163,^ ^165,^ ^177,^ ^178,^ ^183,^ ^195,^ ^196,^ ^198,^ ^203,^ ^224,^ ^239,^ ^241,^ ^242,^ ^253^ Two CBT studies reported results comparing a single treatment arm with TAU in primary care settings.^190,^ ^237^

For pharmacotherapy, the duration of treatment ranged from 8 to 12 weeks, with doses being adjusted either flexibly or in a preplanned manner during therapy. Two studies reported concurrent psychoeducational therapy,^178,^ ^225–228^ and one reported medication therapy management visits.^238^

Six pharmacotherapy studies compared fluoxetine,^168,^ ^169^ fluvoxamine,^225–228^ sertraline,^238^ escitalopram,^244^ or duloxetine^243^ with placebo.

Six studies had more than one active arm compared with wait-list control.^167,^ ^206,^ ^220,^ ^240,^ ^246,^ ^251^ Five had two arms comparing individual CBT versus group CBT,^251^ group CBT with and without cognitive restructuring,^240^ brief CBT versus full CBT,^246^ and child-focused CBT versus parent- or family-inclusive CBT.^167,^ ^220^ A sixth compared three variants of parent-guided CBT, supported by telephone, email, or as needed, against a wait-list control.^206^

One had three active arms compared with placebo or wait-list control. This study (Child/Adolescent Anxiety Multimodal Study, or CAMS) evaluated CBT, sertraline, and CBT plus sertraline versus placebo.^254–262^

All studies reported on continuous or categorical outcome measures for anxiety symptoms, and nearly all studies (except three) reported on response, remission, or loss of diagnosis. Nine studies reported on depression outcomes, and fourteen on functioning. Studies generally reported results at the end of treatment, with the timing ranging from 4 weeks to 6 months; a minority reported results at 12 months.^190,^ ^220^

Six studies reported on analyses of specific populations.^167,^ ^190,^ ^241^

#### Results: Anxiety Symptoms

##### Psychotherapy vs. Wait-List Controls, Treatment as Usual, or Placebo

All 24 CBT studies reported on anxiety symptoms. Studies did not report minimal clinically important differences, but scores above established thresholds indicated clinical benefit and are presented in Table 9 for pooled estimates. All outcomes for each study are reported in Appendix F Table 3 and these were used to generate meta-analyses (Appendix G Figure 8 through Figure 14). Table 9 presents pooled estimates of effect for end-of-treatment measures, specifically ADIS CSR (12 studies^163,^ ^177,^ ^178,^ ^183,^ ^196,^ ^198,^ ^206,^ ^224,^ ^237,^ ^242,^ ^253,^ ^275^); child-rated Spence Children’s Anxiety Scale (SCAS) (9 studies^163,^ ^177,^ ^196,^ ^198,^ ^203,^ ^206,^ ^242,^ ^246,^ ^253^); parent-rated SCAS (9 studies^163,^ ^177,^ ^196,^ ^198,^ ^203,^ ^206,^ ^242,^ ^246,^ ^253^); child-rated SPAI (4 studies^165,^ ^220,^ ^239,^ ^240,^ ^275^); CGI-S (3 studies^190,^ ^237,^ ^254–262^); Multidimensional Anxiety Scale for Children (MASC) (3 studies^220,^ ^251,^ ^254–262,^ ^275^); and Revised Children’s Manifest Anxiety Scale (RCMAS) (3 studies^167,^ ^206,^ ^241^). Results for nearly all measures suggested clinically and statistically significant differences favoring CBT over wait-list control, TAU in primary care, or placebo. The only exceptions was for MASC (3 studies^220,^ ^251,^ ^254–262,^ ^275^). Studies reporting parent- and child-rated MASC outcomes did not consistently show statistically significant differences favoring CBT over wait-list control or placebo. Studies reporting on MASC did not offer a threshold for clinically meaningful effect, and an evaluation of MASC suggests that it may not be possible to identify cutoff scores.^276^

Table 9 Anxiety Interventions and Change in Anxiety Symptoms: Pooled Estimates of Effect

Intervention | Time of Outcome Measurement | Outcome Measure | Outcome Range | Outcome Threshold Indicating Clinically Meaningful Effect | Treatment Range at Followup | Comparator Range at Following | Pooled Results
Psychotherapy
Individual or group; Child-focused, child+parent focused, parent focused; In person, email, telephone, or internet^*^ | 4 to 17 weeks from baseline | ADIS-CSR for the primary diagnosis or all diagnoses^†^ | 0 to 8^310^ | 4 (moderate degree of impairment) or greater indicates a clinical diagnosis^310^ | 1.9 to 4.2 | 3.6 to 6.2 | Mean difference: −2.01 (95% CI, −2.74 to −1.29); N=579; k=11;^163,^ ^177,^ ^178,^ ^183,^ ^196,^ ^198,^ ^224,^ ^237,^ ^242,^ ^253,^ ^275^ I^2^=83%^ǂ^; Appendix G Figure 8
Individual or group; Child-focused, child+parent focused, parent focused; In person, email, telephone, or internet^§^ | 6 to 17 weeks from baseline | SCAS-C | 38 items rated on a 0 to 3 scale, maximum of 114 | Cutoffs vary by age and gender from 33 to 50^311^ (higher scores represent worse outcomes) | 21.6 to 34.9 | 29.4 to 42.1 | Mean difference: −7.81 (95% CI, −10.99 to −4.63; N=668; k=9;^163,^ ^177,^ ^196,^ ^198,^ ^203,^ ^206,^ ^242,^ ^246,^ ^253^ I^2^=29%; Appendix G Figure 13
Individual or group; Child-focused, child+parent focused, parent focused; In person, email, telephone, or internet^§^ | 6 to 17 weeks from baseline | SCAS-P | 38 items rated on a 0 to 3 scale, maximum of 114 | Cutoffs vary by age and gender from 33 to 50^311^ (higher scores represent worse outcomes) | 18.8 to 33.1 | 24.2 to 41.3 | Mean difference: −6.06 (95% CI, −9.58 to −2.56); N=652; k=9;^163,^ ^177,^ ^196,^ ^198,^ ^203,^ ^206,^ ^242,^ ^246,^ ^253^ I^2^=58%; Appendix G Figure 14
Individual or group; Child-focused, child+parent focused; In persont^ǁ^ | 6 to 17 weeks from baseline | SPAI-C | 0 to 52^312^ | ≥18 indicates social anxiety disorder^312^ | 12.5 to 15.5 | 22.8 to 30.8 | Standardized mean difference^¶^: −1.17 (95% CI, −1.99 to −0.35); N=277; k=4;^165,^ ^220,^ ^239,^ ^240,^ ^275^ I^2^=87%; Appendix G Figure 12
Individual; Child-focused or parent-led; In person | 5 to 12 weeks from baseline | CGI-S | 1 to 7^313^ | 2: borderline ill; 3: mildly ill; 4: moderate illness^313^ | 2.0 to 4.0 | 3.3 to 4.2 | Mean difference: −0.60 (95% CI, −1.14 to −0.06); N=453; k=3;^190,^ ^237,^ ^254–262^ I^2^=75%; Appendix G Figure 9
Individual or group; Child-focused, child+parent focused; In person^#^ | 12 weeks from baseline | MASC | 0 to 117 | Unclear,^276^ cutoff scores may not be possible to establish | 40.9 to 48.8 | 42.9 to 54.7 | Mean difference: −4.66 (95% CI, −9.66 to 0.34); N=435; k=3;^220,^ ^251,^ ^254–262,^ ^275^ I^2^=66%; Appendix G Figure 10
Individual or group; Child-focused, child+parent focused; In person, email, telephone, or internet^**^ | 10 to 12 weeks from baseline | RCMAS | | ≥19^314^ indicates clinically significant levels of anxiety | 6.6 to 10.9 | 9.8 to 15.7 | Mean difference: −3.08 (95% CI, −5.91 to −0.24); N=241; k=3;^167,^ ^206,^ ^241^ I^2^=71%; Appendix G Figure 11
Pharmacotherapy
Fluoxetine, fluvoxamine, duloxetine, escitalopram, sertraline | 8 to 12 weeks from baseline | PARS | 0 to 25^315^ | >11.5^316^ discriminates youth without anxiety disorders from those with anxiety disorders | 8.1 to 9.8 | 9.3 to 15.9 | Mean difference: −4.0 (95% CI, −5.5 to −2.5); N=726; k=5;^168,^ ^225–228,^ ^243,^ ^244,^ ^254–262^ I^2^=81%; Appendix G Figure 16
Duloxetine, escitalopram, sertraline | 8 to 12 weeks from baseline | CGI-S | 1 to 7^313^ | 2: borderline ill; 3: mildly ill; 4: moderate illness^313^ | 2.4 to 3.0 | 3.1 to 3.9 | Mean difference: −0.84 (95% CI, −1.13 to −0.55); N=550; k=4;^238,^ ^243,^ ^244,^ ^254–262^ I^2^=75%; Appendix G Figure 15

* We averaged the results across arms for the two studies with multiple treatment arms (child directed or child and parent directed^220^ telephone vs. email vs. client initiated “on their own”^206^ compared with wait-list).

† We selected or combined CSR ratings for primary diagnoses when available.

ǂ Pooled standardized mean differences that included all studies (including one reporting only Cohen’s d estimates of effect^206^) also suggested a statistically significant difference (−1.17 [95% CI, −1.56 to −0.78]; N=676; k=12; I^2^=79%).

§ We averaged the results across arms for the two studies with multiple treatment arms (brief vs. full CBT,^246^ telephone vs. email vs. client initiated “on their own”^206^ compared with wait-list).

ǁ We averaged the results across arms for the two studies with multiple treatment arms (with or without cognitive restructuring,^240^ child or child+parent^220,^ ^275^).

¶ Reported as standardized mean difference because two of the did not present sufficient information to calculate mean differences.

# We averaged the results across arms for the two studies with multiple treatment arms (child or child+parent,^220,^ ^275^ individual or group^251^).

** We averaged the results across arms for the two studies with multiple treatment arms (child directed or child and parent directed^317^).

Abbreviations: ADIS-CSR=Anxiety Disorders Interview Schedule clinician severity ratings; CBT=cognitive behavioral therapy; CGI-S=Clinical Global Impressions-Severity; CI=confidence interval; I^2^=percentage of variation across studies that is due to heterogeneity rather than chance; k=number of studies; MASC=Multidimensional Anxiety Scale for Children; N=number; PARS=Pediatric Anxiety Rating Scale; RCMAS=Revised Children’s Manifest Anxiety Scale; SCAS-C=Spence Children’s Anxiety Scale-Child-rated; SCAS-P=Spence Children’s Anxiety Scale-Parent-rated; SPAI-C=Social Phobia and Anxiety Inventory for Children.

In addition, we found results for several posttreatment measures that we could not pool, either because of heterogeneity in measures or because we found only one or two studies. Heterogenous measures included child-reported SCARED outcomes. measured at 10 to 12 weeks from baseline.^190,^ ^224,^ ^254–262^ One study reported on subscales for SCARED for GAD and anxiety^224^ rather than total scores, and the details regarding the scale and scoring were unclear. Studies reporting parent- and child-rated SCARED outcomes did not consistently show statistically significant differences favoring CBT over wait-list control.

We found one or two studies on several other symptom measures, specifically two studies each on the Fear Survey Schedule for Children-Revised (FSCC-R),^167,^ ^220^ Social Anxiety Scale Children (SASC),^165,^ ^240^ and PARS^237,^ ^254^ and one study each on parent-reported Social Phobia and Anxiety Inventory (SPAI),^220,^ ^275^ Liebowitz Social Anxiety Scale for Children and Adolescents (LSAS-CA),^239^ Preschool Anxiety Scale (PAS),^183^ Penn State Worry Questionnaire for Children (PSWQ-C),^224^ Selective Mutism Questionnaire (SMQ),^178^ CGI-I,^195^ and Diagnostic Interview Schedule for Children, Adolescents, and Parents (DISCAP).^241^ With the exception of one study,^167^ all reported at least one measure favoring CBT compared with wait-list control or placebo for anxiety symptoms.

Three studies reported on outcomes after the initial posttreatment assessment, at 6 and 12 months, using three different instruments. The results were mixed. One study reported on child-rated SPAI outcomes at 6 months and found statistically significant differences favoring CBT.^240^ Two studies reported no statistically significant differences at 12 months using CGI-S outcomes^190^ and SCARED.^190^

##### Pharmacotherapy vs. Placebo

Six studies reported on the effects of pharmacotherapy on anxiety symptoms when compared with placebo (one each on duloxetine,^243^ escitalopram,^244^ fluoxetine,^168^ and fluvoxamine^225–228^ and two on sertraline^238,^ ^254–262^) (Appendix F Table 4). The studies enrolled persons with any anxiety disorder^168,^ ^225–228^ or specifically persons with GAD.^238,^ ^243,^ ^244^ These studies reported on outcomes at the end of treatment using a variety of instruments, including the PARS, CGI-S, ADIS, RCMAS, SCARED, and MASC. Pooled estimates of effect for the PARS^168,^ ^225–228,^ ^243,^ ^244,^ ^254–262^ and CGI-S (4 studies^238,^ ^243,^ ^244,^ ^254–262^) suggested clinically and statistically significant improvement for both measures (Table 9). One or two studies reported findings for other measures (proportion with CGI-S less than 4; continuous measures of the CGI-I, SCARED-C, SCARED-P, child-rated MASC, parent-rated MASC, RCMAS, Hamilton Anxiety Rating Scale [HAM-A], and ADIS-CSR),^168,^ ^238,^ ^254–262^ precluding pooling the results. In all but one instance,^255^ studies reported statistically significant differences favoring pharmacotherapy.

##### Combination Therapy (Sertraline Plus CBT) vs. Placebo

One study reported on outcomes comparing sertraline plus CBT with placebo.^254–262^ The study reported on multiple measures of symptoms including the PARS,^254^ CGI-S,^254^ child-rated MASC,^255^ parent-rated MASC,^255^ SCARED-C,^255^ and SCARED-P.^255^ Results varied by instrument and respondent. PARS scores were significantly different favoring combination treatment at 12 weeks (calculated mean difference: −5.20 [95% CI, −6.91 to −3.50]^254^), but not when evaluating changes from baseline to 12 weeks. Scores for the CGI-S (calculated mean difference: −1.4 [95% CI, −1.77 to −1.03]^254^) and parent-reported MASC (33.4 vs. 49.1, adjusted p<0.001) suggested benefit for the combined therapy arm when compared with placebo.^255^ Results for SCARED (9.6 vs. 19.5, adjusted p<0.001)^255^ were statistically significant and favored combination therapy, but child-reported measures of the MASC and SCARED did not yield statistically significant differences between treatment and control groups.

#### Results: Response, Remission, or Loss of Anxiety Diagnosis

##### Psychotherapy vs. Wait-List Controls, Treatment as Usual, or Placebo

Eight studies reported on clinical response,^178,^ ^190,^ ^195,^ ^237–239,^ ^242,^ ^244,^ ^253–262^ seven on remission of anxiety symptoms,^163,^ ^198,^ ^206,^ ^237,^ ^239,^ ^242,^ ^254–262^ and 19 on loss of diagnosis. Table 10 presents pooled results for these outcomes; detailed outcomes are in Appendix F Table 5 through Table 7.

Table 10 Anxiety Interventions and Clinical Response, Remission From Anxiety, and Loss of Diagnosis: Pooled Estimates of Effect

Intervention | Time of Outcome Measurement | Outcome Measure | Outcome Range | Outcome Threshold Indicating Clinically Meaningful Effect | Treatment Range at Followup | Comparator Range at Followup | Pooled Results
Psychotherapy
Individual or group therapy; Child-, parent-, or child+parent-focused therapy; In-person therapy | 4 weeks to 6 months from baseline | Proportion with a clinical response (CG1=1 or 2) | 0 to 100 | CGI-I scores of 1 or 2 indicate moderate marked improvement, proportion threshold unclear | 40% to 83% | 0 to 37% | RR: 1.89 (95% CI, 1.17 to 3.05); N=606; k=6;^178,^ ^190,^ ^195,^ ^237,^ ^253,^ ^254^ I^2^=64%; Appendix G Figure 17
Individual or group therapy; Child-, parent-, or child+parent-focused therapy; In person, email, telephone, internet therapy | 8 to 16 weeks from baseline | Remission from anxiety symptoms on child-rated SCAS | 0 to 100 | Unclear “clinically significant change” | 43% to 62% | 6% to 38% | RR: 2.68 (95% CI, 1.48 to 4.88); N=321; k=4;^163,^ ^198,^ ^206,^ ^242^ I^2^=48%^*^; Appendix G Figure 18
Individual, group, or individual+group therapy; Child-, parent-, or child+parent-focused therapy; In person, telephone, internet therapy | 8 to 16 weeks from baseline | Loss of all anxiety diagnoses | 0 to 100 | No diagnosis following a structured clinical interview | 15% to 80% | 0 to 35% | RR: 3.09 (95% CI, 1.98 to 4.80); N=1,414; k=15;^163,^ ^167,^ ^177,^ ^183,^ ^190,^ ^195,^ ^196,^ ^198,^ ^224,^ ^241,^ ^242,^ ^246,^ ^251,^ ^253^ I^2^=65%^†^; Appendix G Figure 19
Individual, group, or individual+group therapy; Child-, parent-, or child+parent-focused therapy; In person, telephone, internet therapy | 6 weeks to 12 months from baseline | Loss of primary anxiety diagnosis | 0 to 100 | No diagnosis following a structured clinical interview | 7% to 80% | 0 to 43% | RR: 3.02 (95% CI, 1.84 to 4.95); N=1,079; k=13;^163,^ ^177,^ ^178,^ ^183,^ ^190,^ ^196,^ ^198,^ ^220,^ ^224,^ ^242,^ ^246,^ ^251,^ ^253,^ ^275^ I^2^=75%^‡^; Appendix G Figure 20
Pharmacotherapy
Escitalopram, fluoxetine, sertraline | 8 to 12 weeks from baseline | Proportion with a clinical response (CGI=1 or 2) | 0 to 100 for proportion | CGI-I scores of 1 or 2 indicate moderate marked improvement, proportion threshold unclear | 50% to 91% | 9% to 44% | RR: 2.11 (95% CI, 1.58 to 2.98); N=370; k=5;^168,^ ^169,^ ^238,^ ^244,^ ^254–262^ I^2^=18%; Appendix G Figure 21

* We averaged the results across arms for one study with three intervention arms: telephone, email, and client-initiated CBT.^206^

† We averaged the results across arms for three studies with two intervention arms: individual and group CBT,^251^ brief and full CBT,^246^ and child directed and child and family directed therapy.^167^

‡ We averaged the results across arms for three studies with two intervention arms: individual and group CBT,^251^ brief and full CBT,^246^ and child and child+parent CBT.^220,^ ^275^

Abbreviations: CBT=cognitive behavioral therapy; CG=control group; CGI-I=Clinical Global Impressions-Improvement; CI=confidence interval; I^2^=percentage of variation across studies that is due to heterogeneity rather than chance; k=number of studies; N=number; RR=relative risk; SCAS=Spence Children’s Anxiety Scale.

Of the eight studies reporting measures of clinical response,^178,^ ^190,^ ^195,^ ^237–239,^ ^242,^ ^244,^ ^253–262^ six reported CGI-I response defined as moderately or markedly improved symptoms at the end of treatment, with outcomes measured at 4 weeks to 6 months from baseline (CGI-I score of 1 or 2);^178,^ ^190,^ ^195,^ ^237,^ ^254^ the pooled RR was 1.89 (Appendix G Figure 17, 95% CI, 1.17 to 3.05; N=606; k=6; I^2^=64%). A seventh study defined response as reduction in the LSAS-CA total score of 31 percent or more.^239^ The study reported statistically significant differences favoring CBT (66% vs. 20%, p=0.006). The eighth study defined response as a clinically reliable change in SCAS scores.^242^ The study reported statistically significant differences favoring CBT on the child-reported SCAS (69% vs. 26%, p=0.001) and mother-reported SCAS (69% vs. 22%, p<0.001) but not for the father-reported SCAS (35% vs. 19%, p=0.156).

Of the seven studies reported on anxiety remission,^163,^ ^198,^ ^206,^ ^237,^ ^239,^ ^242,^ ^254–262^ four defined remission as clinically significant change on the child-reported SCAS at the end of treatment, varying from 8 to 16 weeks from baseline.^163,^ ^198,^ ^206,^ ^242^ One study reported outcomes for three separate arms compared with wait-list: telephone, email, and client-initiated CBT.^206^ The pooled estimate of effect (averaging across multiple study arms in the study with more than 1 active arm) yielded an RR of 2.68 (Appendix G Figure 18, 95% CI, 1.48 to 4.88; N=321; k=4; I^2^=48%). Of these four studies, one also reported clinically significant change favoring CBT on the mother-reported SCAS (51.8% vs. 11.3%, p≤0.001) and father-reported SCAS (41.8 vs. 9.8, p≤0.001).^163^ Another reported clinically significant change favoring CBT on the mother-reported SCAS (26% vs. 6%, p=0.032) but not for the father-reported SCAS (4% vs. 7%, p=1.00).^242^ One of these four studies also reported no clinically significant change on a parent-reported SCAS (32.0% vs. 20.83%, p=0.38.^198^ The fifth study defined remission as a LSAS-CA score of 30 or less and reported statistically significant differences favoring CBT (47% vs. 6%, p=0.0009).^239^ The sixth study defined remission as a ADIS-CSR score less than 4 and reported statistically significant differences favoring CBT (66.7% vs. 10.0%, p=0.011).^237^ The seventh study defined remission as a CGI-S score of 2 or less and a CGI-I score of 1.^262^ The study reported no statistically significant differences on the CGI-S (35.9% vs. 27.1%, p=0.49) or the CGI-I (20.4% vs. 15.0%, p=0.61).

Nineteen studies reported on loss of anxiety diagnosis using a variety of measures (presence or absence of primary anxiety diagnosis or any anxiety diagnosis) using clinical interviews (ADIS, K-SADS, DISCAP, and Structured Clinical Interview for DSM-IV [SCID]).^163,^ ^167,^ ^177,^ ^178,^ ^183,^ ^190,^ ^195,^ ^196,^ ^198,^ ^203,^ ^206,^ ^220,^ ^224,^ ^238,^ ^241,^ ^242,^ ^244,^ ^246,^ ^251,^ ^253–262,^ ^275^

Of the 19 studies, 17 reported on loss of any diagnosis, measured primarily using the ADIS structured clinical interview at the end of treatment (6 weeks to 6 months from baseline).^163,^ ^167,^ ^177,^ ^183,^ ^190,^ ^195,^ ^196,^ ^198,^ ^203,^ ^206,^ ^224,^ ^238,^ ^241,^ ^242,^ ^244,^ ^246,^ ^251,^ ^253–262^ Fifteen could be pooled.^163,^ ^167,^ ^177,^ ^183,^ ^190,^ ^195,^ ^196,^ ^198,^ ^224,^ ^241,^ ^242,^ ^246,^ ^251,^ ^253^ The pooled estimate of effect (averaging across multiple study arms in studies with more than one active arm^246,^ ^251^) yielded an RR of 3.09 (Appendix G Figure 19, 95% CI, 1.98 to 4.80; N=1,414; k=15; I^2^=65%). Of the remaining two studies, one study did not report sufficient data to permit pooling but reported statistically significant differences when comparing each of three CBT arms (telephone, email, or client initiated) with a wait-list control.^206^ A second study also could not be pooled because the authors reported on a more expansive definition of loss of diagnosis (presence or absence of anxiety diagnosis or symptoms);^203^ this study also reported statistically significant differences favoring the CBT arm.

Fourteen studies reported on loss of the primary anxiety diagnosis, measured primarily using the ADIS structured clinical interview, at the end of treatment with outcomes measured ranging from 6 weeks to 12 months from baseline.^163,^ ^177,^ ^178,^ ^183,^ ^190,^ ^196,^ ^198,^ ^206,^ ^220,^ ^224,^ ^242,^ ^246,^ ^251,^ ^253,^ ^275^ Of these, 13 could be pooled.^163,^ ^177,^ ^178,^ ^183,^ ^190,^ ^196,^ ^198,^ ^220,^ ^224,^ ^242,^ ^246,^ ^251,^ ^253,^ ^275^ The pooled estimate of effect (averaging across multiple study arms in studies with more than one active arm^220,^ ^246,^ ^251,^ ^275^) yielded an RR of 3.02 (Appendix G Figure 20, 95% CI, 1.84 to 4.95; N=1,079; k=13; I^2^=75%). One study did not report sufficient data to permit pooling but reported statistically significant differences across three CBT arms (telephone, email, or client initiated) when compared with a wait-list control.^206^

##### Pharmacotherapy vs. Placebo

All pharmacotherapy studies reported on clinical response; all reported statistically significant improvement favoring pharmacotherapy; detailed outcomes are in Appendix F Table 8. Five (2 on fluoxetine, 2 on sertraline, and 1 on escitalopram) reported on clinician-rated response defined as moderately or markedly improved symptoms at the end of treatment, varying from 8 to 12 weeks from baseline (CGI-I scores of 1 or 2);^168,^ ^169,^ ^238,^ ^244,^ ^254–262^ the pooled RR was 2.11 (95% CI, 1.58 to 2.98; N=370; k=5; I^2^=18%). Four of the five studies reported statistically significant differences favoring the intervention arms; the fifth study, focusing on selective mutism, did not report statistically significant differences in clinician- or teacher-rated CGI-I scores but did report statistically significant results for parent ratings on the CGI-I scale.^169^

A sixth study, on fluvoxamine, defined response as CGI-I less than 3; that is, the authors included minimal improvement (CGI-I=3) at 8 weeks as response.^225–228^ The study reported statistically significant differences favoring fluvoxamine (76% vs. 29%, p<0.001) but did not report statistically significant differences with the more traditional definition of response (CGI-I <3). The seventh study, on duloxetine, defined response as 50 percent improvement on PARS severity for GAD.^243^ The study reported statistically differences favoring duloxetine (59% vs. 42%, p≤0.05).

Three studies reported on remission at the end of treatment (9 to 12 weeks from baseline, Table 10); detailed outcomes are in Appendix F Table 9. These included two sertraline studies^238,^ ^254–262^ and one duloxetine study.^243^ These results could not be pooled because the measurement of the outcome varied. The results were not consistent across the varied measures. One study limited the definition of remission to CGI-I=1, that is, marked improvement in symptoms, and reported no statistically significant differences at 9 weeks (18% vs. 0%, calculated p=0.28).^238^ A second study included CGI-I=1 as a definition of remission but also looked at CGI-S less than or equal to 2 and loss of diagnosis as additional measures of remission at 12 weeks and found that the only measure yielding statistically significant differences favoring the intervention arm was loss of diagnosis. The results favored the sertraline arm when compared with the placebo arm (45.9% vs. 23.7%; OR, 2.84 [95% CI, 1.01 to 4.67]; p=0.05).^262^ A third study defined remission as CGI-S less than or equal to 2 or as PARS severity for GAD less than or equal to 8 at 10 weeks and reported results favoring duloxetine for both measures.

##### Combination Therapy (Sertraline Plus CBT) vs. Placebo

One study reported on outcomes comparing sertraline plus CBT with placebo.^254–262^ The study reported statistically significantly higher odds (OR, 13.6 [95% CI, 6.9 to 26.8]; p<0.001) of response (CGI-I of 1 or 2)^254^ and loss of diagnosis based on structured clinical interview (OR, 7.47 [95% CI, 2.63 to 12.64]; p=0.01)^262^ at 12 weeks but not remission, defined as CGI-S score of 2 or less and CGI-I score of 1. For remission, the confidence intervals were very wide and spanned the null.^262^

#### Results: All-Cause Mortality

##### Psychotherapy vs. Wait-List Controls, Treatment as Usual, or Placebo

No CBT studies reported on all-cause mortality.

##### Pharmacotherapy vs. Placebo

One study of duloxetine reported no deaths during the 10-week treatment in either arm.^243^ No other pharmacotherapy studies reported on all-cause mortality.

##### Combination Therapy (Sertraline Plus CBT) vs. Placebo

No studies of combination therapy reported on all-cause mortality.

#### Results: Quality of Life and Functioning

##### Psychotherapy vs. Wait-List Controls, Treatment as Usual, or Placebo

Twelve studies reported on functioning and quality-of-life outcomes after CBT treatment, when compared with wait-list, TAU, or placebo controls; detailed outcomes are in Appendix F Table 10.^163,^ ^178,^ ^183,^ ^190,^ ^196,^ ^224,^ ^242,^ ^246,^ ^251,^ ^253–262,^ ^275^ Of these, eight studies, offering individual or group CBT to parents, children, or both, reported on CGAS scores at the end of treatment (with outcomes measured ranging from 4 to 14 weeks).^178,^ ^183,^ ^190,^ ^196,^ ^224,^ ^251,^ ^253–262^ With the exception of one study focusing on selective mutism,^178^ studies enrolled youth with GAD or any anxiety disorder. Three studies reported parent-reported CAIS scores.^246,^ ^253,^ ^255^ The pooled estimate of effect for CGAS (Table 11) indicated statistically significant improvement for participants in the CBT arm when compared with participants in the control arm. For CAIS, however, inconsistencies in direction of effect across the studies resulted in differences between the arms that spanned the null.

Table 11 Anxiety Interventions and Functional Status: Pooled Estimates of Effect

Intervention | Time of Outcome Measurement | Outcome Measure | Outcome Range | Outcome Threshold Indicating Clinically Meaningful Effect | Treatment Range at Followup | Comparator Range at Following | Pooled Results
Psychotherapy
Individual or group therapy; In person, internet or combined; Child-, parent-, or child+parent-focused therapy | 4 to 12 weeks from baseline | CGAS | 1 to 100^309^ | >70: no clinically significant functional impairment; <41: major impairment to functioning in several areas^309^ | 53.6 to 82.1 | 52.5 to 61.9 | Mean difference: 7.54 (95% CI, 2.84 to 12.23); N=811; k=8;^178,^ ^183,^ ^190,^ ^196,^ ^224,^ ^251,^ ^253–262^ I^2^=90%; Appendix G Figure 23
Individual or group therapy; In person, telephone, internet or combined; Child-, parent-, or child+parent-focused therapy | 8 to 12 weeks from baseline | CAIS | 0 to 81^318^ | <7: no anxiety diagnoses^319^ | 6.4 to 21.8 | 15.2 to 19.6 | Mean difference: −2.23 (95% CI, −5.88 to 1.43); N=403; k=3;^246,^ ^253,^ ^255^ I^2^=38%; Appendix G Figure 22
Pharmacotherapy
Duloxetine, fluoxetine, sertraline | 10 to 12 weeks from baseline | CGAS | 1 to 100^309^ | >70: no clinically significant functional impairment; <41: major impairment to functioning in several areas^309^ | 62.1 to 68.5 | 59.3 to 64.6 | Mean difference: 5.14 (95% CI, 3.21 to 7.08); N=551; k=3;^168,^ ^243,^ ^254–262^ I^2^=0%; Appendix G Figure 24

Abbreviations: CAIS=Children’s Anxiety Impact Scale; CGAS=Children’s Global Assessment Scale; CI=confidence interval; I^2^=percentage of variation across studies that is due to heterogeneity rather than chance; k=number of studies; N=number.

Other measures of functioning such as the Child Anxiety Life Interference Scale (CALIS), Child Anxiety Life Interference Scale-Child (CALIS-C), Pediatric QOL Inventory-P, Quality of Life Inventory for Children [QOLI], PQ-LES-Q, and sleep-related problems were reported in one or two studies.^163,^ ^242^ Results were mixed or did not demonstrate statistically significant differences.

##### Pharmacotherapy vs. Placebo

Three studies (duloxetine,^243^ fluoxetine,^168^ and sertraline^254–262^) reported on CGAS scores (a measure of functioning) at the end of treatment (10 to 12 weeks). Table 11 presents pooled estimates of effect for CGAS showing statistically significant differences favoring the pharmacotherapy when compared with placebo. Two studies reported on functional remission (CGAS scores≥70).^168^ One, on duloxetine, reported a statistically significant difference between arms favoring duloxetine (59% vs, 42%, p≤0.05),^243^ and the other, on fluoxetine, reported no statistically significant difference.^168^

The sertraline study also reported parent- and child-reported school functioning (CAIS)^259^ and sleep-related problems.^258^ Child-reported outcomes were not statistically significant. Some parent-reported outcomes (Child Anxiety Impact Scale-Parent) and sleep-related problems associated with separation (but not dysregulated sleep overall) were statistically significantly improved in the treatment arm when compared with placebo.

##### Combination Therapy (Sertraline Plus CBT) vs. Placebo

One study reported on outcomes comparing sertraline plus CBT with placebo.^254–262^ The study reported on multiple measures of symptoms including CGAS,^254^ CAIS,^255^ and sleep-related problems.^255^ CGAS scores were significantly different at 12 weeks favoring combination therapy (calculated mean difference: 8.50 [95% CI, 5.55 to 11.45]^254^) as were parent-reported measures of CAIS at followup (7.4 vs. 15.2, adjusted p<0.001^255^) and sleep problems related to separation (p=.01), but not for child-reported measures of functioning (CAIS)^259^ or other sleep problems.^258^

#### Results: Findings for Specific Populations

Appendix F Table 11 presents qualitative results for specific populations. No studies reported on results by gender identity or sexual orientation.

##### Subgroup Analyses

Four CBT studies reported analyses of specific populations.^167,^ ^190,^ ^241,^ ^254–262^ All four studies reported analyses by age.^167,^ ^190,^ ^241,^ ^255,^ ^260^ Two studies^241,^ ^255^ reported no statistically significant differences in self-,^241,^ ^255^ parent-,^255^ or clinician-reported^241^ measures of symptomatology or severity by age. A third study reported significantly higher response rates at post-treatment, but not at 1-year follow-up, for older participants who received CBT when compared with TAU.^190^ A fourth study reported significantly higher rates of loss of diagnosis at post-treatment and 1-year follow-up for younger participants (7 to 10 years) receiving child and parent-focused CBT in comparison with those receiving child-focused CBT.^167^ Two studies reported analyses by sex.^167,^ ^241^ One^241^ reported no statistically significant differences for clinician-rated severity or self-reported measures of anxiety by sex and the second^167^ reported significantly higher rates of loss of diagnosis at post-treatment and 1-year follow-up for female participants receiving child and parent-focused CBT. One study reported analyses by race and ethnicity.^256,^ ^261^ No statistically significant differences in response, remission, or relapse were reported by race.^261^ Clinicians reported significantly more severe anxiety symptoms for participants of Hispanic ethnicity who received CBT.^256^

Three pharmacotherapy (duloxetine,^243^ fluvoxamine,^225–228^ and sertraline^254–262^) studies reported analyses for populations of interest. All three studies reported analyses by age.^226,^ ^243,^ ^255,^ ^260^ Three studies reported no statistically significant differences in symptoms,^255^ symptom severity,^243^ and all evaluated outcomes^226^) by age. All three studies reported analyses by sex.^226,^ ^243,^ ^259^ Two studies^226,^ ^243^ reported no statisically significant sifferences in for evaluated outcomes (GAD severity in one study^243^ and all outcomes in the other study^226^) by sex. One study^259^ reported significantly less parent-reported, but not youth-reported, anxiety-related school impairments among males who received Sertraline compared to pill placebo. Two studies^226^ ^,^ ^261^ reported analyses by race. Both reported no statistically significant differences in anxiety symptomalogy or severity,^226^ response^226,^ ^261^ or remission or loss of diagnosis^261^ by race. One study reported analyses by ethnicity.^256^ Parents reported significantly more severe anxiety symptoms for participants of Hispanic ethnicity who received Sertraline.

One study^254–262^ of combined pharmacotherapy and CBT reported analyses for symptoms,^255,^ ^256,^ ^259^ response and remission,^261^ by age,^255,^ ^260^ sex,^259^ ethnicity,^256^ or race.^261^ No statistically significant differences in symptoms were reported by age.^255^ Statistically significant differences favored combined treatment in parent-reported psychosocial functioning were reported by sex.^259^ Parents, but not youth, reported a greater benefit in anxiety-related school impairments among males who received sertraline in combination with CBT than among females when compared with placebo recipients.^259^ No statistically significant differences in response, remission, or relapse were reported by race^261^ or ethnicity.^256^

##### Findings Within Age Groups

Categorization of studies into groups mapping to children or adolescents is challenging. Three studies limited their inclusion to young children, with ages ranging from 3 to 7 years.^183,^ ^195,^ ^237^ Four studies limited inclusion to adolescents only, with ages ranging from 13 to 20 years.^239,^ ^242,^ ^244,^ ^253^ The remaining 22 studies were focused on older children (5 to 14 years; 12 studies)^165,^ ^167,^ ^177,^ ^178,^ ^196,^ ^203,^ ^206,^ ^220,^ ^240,^ ^241,^ ^251^ or children and adolescents (7 to 18; 10 studies).^163,^ ^168,^ ^169,^ ^190,^ ^198,^ ^224,^ ^225,^ ^238,^ ^243,^ ^254^ Although studies varied in their specific inclusion criteria and whether they included adolescents, the majority of studies had a mean age between 10 and 14 years.

The results for young children only and adolescents only are largely consistent with the results for the entire evidence base in demonstrating benefit for symptom improvement.

For younger children, all three studies focused on CBT and reported consistent statistically signficant benefits for anxiety symptoms in two^183,^ ^237^ of three studies.^183,^ ^195,^ ^237^ Two studies reported on response and both reported statistically significant differences favoring CBT.^195,^ ^237^ The single studies reporting on remission^237^ and functioning,^183^ respectively, suggested statistically signficant differences favoring CBT. The results for loss of diagnosis were not consistently statistically significant in favoring CBT in the two studies reporting on this outcome.^183,^ ^195^

For adolescents, three studies^239,^ ^242,^ ^253^ reported on CBT and one reported on pharmacotherapy, specifically escitalopram.^244^ Two^239,^ ^242^ of the three^239,^ ^242,^ ^253^ CBT studies reported consistent statistically significant improvement in anxiety symptoms, response, and remission; one reported no statistically significant differences.^253^ Only one CBT study reported on loss of diagnosis and found no statistically signficant differences.^253^ Two studies reported on functioning, and neither consistently found statistically significant differences.^242,^ ^253^ The escitalopram study reported improvement in symptoms and response.^244^

### Depression

#### Summary

We included 13 fair-quality RCTs for KQ 4^174–176,^ ^185,^ ^187,^ ^204,^ ^207,^ ^216,^ ^233,^ ^248,^ ^249,^ ^252,^ ^266^ (described in 20 publications^186,^ ^205,^ ^208–211,^ ^217^). Seven RCTs^176,^ ^187,^ ^204,^ ^205,^ ^216,^ ^217,^ ^248,^ ^249,^ ^266^ were new in this update for KQ 4. One study that was included in the previous USPSTF report on depression treatment and screening for KQ 4 was excluded from this report for ineligible intervention. This study tested citalopram, which was not included in the current review.^277^ Detailed study, population, intervention characteristics, and results are provided in Appendix I Tables 25 through Table 30. Detailed outcomes are provided in Appendix F Table 14 through Table 28. Meta-analysis forest plots are provided in Appendix G Figure 25 through Figure 32.

#### Study Characteristics

The characteristics of the included studies are summarized in Table 12. Six RCTs admitted children or adolescents meeting DSM criteria for MDD,^175,^ ^176,^ ^185,^ ^207,^ ^216,^ ^252^ and five RCTs admitted those with MDD based on a clinical interview (K-SADS, K-SADS-EC, MINI).^204,^ ^233,^ ^248,^ ^249,^ ^266^ Two RCTs admitted children with MDD, dysthymia, or depressive disorder not otherwise specified and enrolled a sample in which more than 50 percent of participants met DSM criteria for MDD.^174,^ ^187^ Eight RCTs set a threshold for severity, ranging from requiring clinical important symptoms to specific minimum thresholds on BDI-II, CDRS-R, Hamilton Depression Rating Scale (HAM-D), and PHQ-9.^185,^ ^187,^ ^207,^ ^216,^ ^233,^ ^248,^ ^249,^ ^252^

Table 12 Key Characteristics of Included Depression Studies for Benefits

Study Characteristics | Subcharacteristics | Number of Studies | Percent
Population characteristics: Child or adolescent | Child (mean age <13) | 3 | 23.1
Population characteristics: Child or adolescent | Adolescent (mean age ≥13) | 10 | 76.9
Population characteristics: Gender | Mostly female | 11 | 84.6
| Mostly male | 2 | 15.4
Population characteristics: Race | Mostly White | 7 | 53.8
| Mostly non-White | 1 | 7.7
| Not reported | 5 | 38.5
Population characteristics: Diagnosis^*^ | MDD | 13 | 100.0
| PDD/DD/DNOS | 4 | 30.1
Intervention characteristics: Types of interventions | Nonpharmacological | 8 | 61.5
| Pharmacological | 2 | 15.4
| Multiple arms of CBT, pharmacotherapy, and combination | 2 | 15.4
| Collaborative care | 1 | 7.7
Comparator | Attention control | 3 | 23.1
| Placebo comparator | 4 | 30.8
| Treatment as usual | 4 | 30.8
| Wait-list comparator | 2 | 15.4
Geographic setting | United States | 10 | 76.9
| Sweden | 3 | 23.1
Recruitment setting | Advertised widely | 7 | 53.8
| Health systems and clinics | 3 | 23.1
| Schools and mental health clinics | 1 | 7.7
| Mental health clinics | 1 | 7.7
| Not specified | 1 | 7.7

* Not mutually exclusive.

Abbreviations: CBT=cognitive behavior therapy; MDD=major depressive disorder; PDD/DD/DNOS=persistent depressive disorder/dysthymia disorder/depression not otherwise specified.

Mean ages ranged from 5 to 17.5 years.^204,^ ^205,^ ^249^ One RCT focused on early childhood (ages 3 to 6 years);^204,^ ^205^ two focused on older children and adolescents (age ranges from 7 to 14 years and 6 to 17 years);^187,^ ^252^ and 10 focused on adolescents (age ranges from 12 to 17 years to 15 to 19 years).^174–176,^ ^185,^ ^207,^ ^216,^ ^233,^ ^248,^ ^249,^ ^266^ Two had a majority male participants.^187,^ ^204,^ ^205^ Eight RCTs provided statistics on race, with the exception of one study with 71 percent Hispanic participants.^216^ White participants were a majority in all RCTs that reported race.^176,^ ^185,^ ^187,^ ^204,^ ^205,^ ^207,^ ^233,^ ^252^

Common exclusion criteria were substance misuse or substance use disorder; bipolar disorder, schizophrenia, or other serious mental health disorders; intellectual disability; autism spectrum disorders; and suicide-related concerns.

Two pharmacotherapy RCTs investigated escitalopram.^185,^ ^252^ One three-arm trial compared included a group that received fluoxetine.^207^ The most commonly assessed psychotherapy was CBT. Six RCTs focused on CBT.^174–176,^ ^187,^ ^248,^ ^249^ Among these, two included individual CBT,^175,^ ^176^ one family CBT,^187^ one group CBT,^174^ and two internet-delivered CBT.^248,^ ^249^ Three RCTs studied psychotherapies other than CBT. One focused on interpersonal psychotherapy^216^ and the other on Parent Child Interaction Therapy-Emotion Development.^204,^ ^205^ One RCT studied collaborative care.^233^ One focused on internet-based psychodynamic therapy.^266^

Eleven RCTs (2 on pharmacotherapy, 8 on psychotherapy, 1 on collaborative care) had a single active treatment compared with attention control or supportive contact, wait-list control, TAU, or placebo. Both pharmacotherapy RCTs compared escitalopram with placebo.^185,^ ^252^ Psychotherapy studies compared treatment with attention control,^248,^ ^249^ supportive contact,^266^ wait-list control,^204,^ ^205^ TAU,^175,^ ^176,^ ^216^ or placebo.^187^ The collaborative care study compared the intervention with enhanced usual care; treatments included a choice of antidepressants, brief CBT, or both.^233^ Another trial, using a collaborative care approach, is discussed under psychotherapy because all participants in the active arm received CBT.^175^ One RCT had two active arms, group CBT with and without parent session, compared with wait-list control.^174^ One RCT had three active arms (fluoxetine, CBT, and fluoxetine plus CBT) compared with placebo.^207^

Two pharmacotherapy trials compared escitalopram with placebo.^185,^ ^252^ One three-arm trial compared fluoxetine, CBT, and placebo.^207^ One study compared collaborative care with enhanced usual care.^233^ Six studies focused on CBT.^174–176,^ ^187,^ ^248,^ ^249^ Among these, two compared individual CBT with TAU,^175,^ ^176^ one compared family CBT with placebo,^187^ one compared group CBT with and without additional parent sessions with wait-list,^174^ and two compared internet-delivered CBT with an attention control group.^248,^ ^249^ Three studies focused on counseling other than CBT.^204,^ ^216,^ ^266^ One compared interpersonal psychotherapy and TAU,^216^ the second compared Parent Child Interaction Therapy-Emotion Development with a wait-list control,^204,^ ^205^ and the third compared internet-based psychodynamic therapy with supportive contact.^266^

Intervention durations ranged from 8 weeks to 12 months. Most studies reported results at the end of treatment. All 13 RCTs reported on continuous outcomes for depression symptoms. The most commonly reported measures were the CDRS-R^176,^ ^185,^ ^187,^ ^207,^ ^233,^ ^252^ and BDI.^174,^ ^216,^ ^248,^ ^249^

Nine RCTs reported response,^175,^ ^176,^ ^185,^ ^207,^ ^233,^ ^248,^ ^249,^ ^252,^ ^266^ ten RCTs reported remission,^175,^ ^176,^ ^185,^ ^187,^ ^207,^ ^216,^ ^233,^ ^248,^ ^249,^ ^266^ and five RCTs reported loss of depression diagnosis.^174,^ ^204,^ ^205,^ ^207,^ ^248,^ ^249^ Three RCTs reported anxiety outcomes,^248,^ ^249,^ ^266^ three studies reported suicide-related outcomes,^176,^ ^185,^ ^207,^ ^252^ and nine studies reported functioning outcomes.^174,^ ^176,^ ^185,^ ^187,^ ^204,^ ^205,^ ^207,^ ^216,^ ^233,^ ^252^ Five studies reported harms.^185,^ ^207,^ ^233,^ ^252,^ ^266^ No psychotherapy studies reported harms.

RCTs relied on in-person delivery of interventions, except for two that reported on internet-delivered CBT^248,^ ^249^ and one that reported on internet-based psychodynamic therapy.^266^

Half the RCTs advertised widely for recruitment;^174,^ ^187,^ ^207,^ ^248,^ ^249,^ ^252,^ ^266^ three recruited from health systems and pediatric clinics;^175,^ ^176,^ ^233^ one RCT recruited from preschools, daycares, primary care, and mental health facilities;^204,^ ^205^ one RCT recruited from mental health clinics;^216^ and one RCT did not specify the recruitment setting.^185^ Ten studies were conducted in the United States,^174–176,^ ^185,^ ^187,^ ^204,^ ^205,^ ^207,^ ^216,^ ^233,^ ^252^ and three studies were conducted in Sweden.^248,^ ^249,^ ^266^

#### Results: Depression Symptoms

##### Psychotherapy vs. Wait-List Controls, Treatment as Usual, Attention Control, or Placebo

Ten studies reported outcomes related to changes in depression symptoms.^174–176,^ ^187,^ ^204,^ ^207,^ ^216,^ ^248,^ ^249,^ ^266^ All outcomes for each study are reported in Appendix I, and for outcomes reported by at least three studies, we conducted meta-analyses (Appendix G). Table 13 presents pooled estimates of the effect for end-of-treatment measures, specifically the BDI/BDI-II,^174,^ ^216,^ ^248,^ ^249^ CDRS-R,^176,^ ^187,^ ^207^ and HAM-D^174,^ ^175,^ ^216^ scales. Two of the pooled effects (BDI/BDI-II and HAM-D) suggested a statistically significant benefit of treatment compared with controls, while the third pooled estimate (CDRS-R) demonstrated no significant effect.

Table 13 Depression Interventions and Depression Symptoms: Pooled Estimates of Effect

Intervention | Time of Outcome Measurement | Outcome Measure | Outcome Range | Outcome Threshold Indicating Clinically Meaningful Effect | Treatment Range at Followup | Comparator Range at Following | Pooled Results
Psychotherapy^310^
Internet-based individual CBT group in-person CBT with and without parents, interpersonal psychotherapy^*^ | 8 to 12 weeks | BDI or BDI-II | BDI: 0 to 39^216^; BDI-II: 0 to 63^320^ | BDI:; <10: minimal depression; 10 to 18: mild to moderate depression; 19 to 29: moderate to severe depression; ≥30: severe depression^170,^ ^235^; BDI-II:; 0–13: minimal depression; 14–19: mild depression; 20–28: moderate depression; 29–63: severe depression^320^ | BDI: 8.4 to 13.3; BDI-II: 16 to 19.9 | BDI: 12.3 to 16; BDI-II: 24.8 to 25.2 | Standardized mean difference: −0.58 (95% CI,−0.83 to −0.34); N=471; k=4;^174,^ ^216,^ ^248,^ ^249^ I^2^=0%^†^; Appendix G Figure 25
Individual in-person youth CBT, group in-person CBT with and without parents, interpersonal psychotherapy^*^ | 8 to 52 weeks from baseline | HAM-D | Unclear (2 studies^174,^ ^175^ used a 14-item version of HAM-D) | Unclear | 4.9 to 8.7 | 6.5 to 12.8 | Mean difference: −2.25 (95% CI,−4.09 to −0.41); N=262; k=3;^174,^ ^175,^ ^216^ I^2^=0%; Appendix G Figure 26
Individual in-person CBT, family CBT | 12 to 52 weeks from baseline | CDRS-R | 17 to 113^321^ | ≥40 indicates depression; ≤28 indicates remission; (minimal or no symptoms^321^) | 30.0 to 42.1 | 28.2 to 41.8 | Mean difference: 0.77 (95% CI,−0.97 to 2.48); N=471; k=3;^176,^ ^187,^ ^207^ I^2^=0%; Appendix G Figure 27
Pharmacotherapy
Escitalopram, fluoxetine | 8 to 12 weeks from baseline | CDRS-R | 17 to 113^321^ | ≥40 indicates depression; ≤28 indicates remission; (minimal or no symptoms^321^) | 32.6 to 36.3 | 36.4 to 41.8 | Mean difference: −3.76 (95% CI,−5.95 to −1.57); N=793; k=3;^185,^ ^207,^ ^252^ I^2^=49%; Appendix G Figure 28

* We averaged the results across arms for the study with multiple treatment arms (group in-person CBT with or without parents^174^) compared with wait-list.

† Mean differences standardized to pool BDI and BDI-II measures.

Abbreviations: BDI=Beck Depression Inventory; BDI-II=Beck Depression Inventory, version 2; CBT=cognitive behavioral therapy; CI=confidence interval; CDRS-R=Children’s Depression Rating Scale-Revised; CI=confidence interval; HAM-D=Hamilton Depression Rating Scale; I^2^=percentage of variation across studies that is due to heterogeneity rather than chance; k=number of studies: N=number.

Several studies also reported other measures of depression symptoms in addition to measures that we pooled (Appendix F Table 14). For some studies, findings from these additional measures (Mood and Feelings Questionnaire,^249^ mean CGI-I and CGI-S,^216^ and Revised Children’s Anxiety and Depression Scale [RADS]^207^) were consistent with what has already been reported by those studies using BDI, BDI-II, CDRS-R, or HAM-D measures. In other cases, findings were not consistent. Two studies by the same author of the same intervention (individual, in-person CBT) compared with TAU, which included any health services, including psychopharmacotherapy, provided by their usual care provider, reported using the CES-D and found mixed results.^175,^ ^176^ One of these studies, published in 2005, reported larger, but nonstatistically significant different improvements in CES-D scores at 52 weeks, consistent with findings from the HAM-D outcomes also reported in that study.^175^ The later of the two studies, published in 2016, larger, statistically significant improvements in CES-D scores at 52 weeks, consistent with reported benefits for the CDRS measure at 52 weeks.^176^ These larger improvements in the treatment group persisted at 104 weeks but were no longer statistically significant, also consistent with CDRS findings at 104 weeks.^176^ A third study reported a larger improvement in PHQ-9 score for the treatment group, but this difference was not statistically significant.^248^ A fourth study evaluated parent-child interaction therapy focused on emotion development compared with wait-list controls and reported outcomes at 18 weeks using the K-SADS-CD MDD core score and the Preschool Feelings Checklist scale.^204^ Participants allocated to the treatment had statistically significant larger improvements on both outcomes (p<0.000).^204^ Lastly, a study comparing internet-based psychodynamic therapy with supportive contact found no statistically significant difference in the primary outcome measured by the Quick Inventory of Depressive Symptomatology for Adolescents (QIDS-A17-SR); a secondary outcome of Montgomery Åsberg Depression Rating Scale–self-rated (MADRS-S) demonstrated a difference favoring the active treatment.^266^

##### Pharmacotherapy vs. Placebo

Three studies reported on the effects of pharmacotherapy on depression symptoms when compared with placebo (2 on escitalopram^185,^ ^252^ and 1 on fluoxetine^207^) (Appendix F Table 15). Three studies reported on outcomes at the end of treatment using CDRS-R,^185,^ ^207,^ ^252^ two reported the CGI-I and CGI-S,^185,^ ^252^ and one reported RADS.^207^ Study sample sizes ranged from 109^207^ to 158.^185^

Table 13 reports pooled differences on the CDRS-R indicating statistically significant benefit favoring pharmacotherapy. Results on other measures did not always yield statistically significant differences favoring pharmacotherapy. On the CGI-S, Emslie et al^185^ reported a significant difference favoring escitalopram when compared with placebo at 8 weeks, whereas Wagner et al^252^ did not report a statistically significant difference. March et al^207^ did not find a statistically significant difference between fluoxetine and placebo on the RADS at 12 weeks.

##### Combination Therapy (Fluoxetine Plus CBT) vs. Placebo

One study comparing fluoxetine plus CBT to placebo reported on depression symptoms measured by the CDSR-R and RADS-2 (Appendix F Table 16).^207^ The results were consistent for CDSR-R and RADS-2 in reporting statistically significant benefits for fluoxetine plus CBT. There was a statistically significant difference in the change in CDSR-R from baseline to 12 weeks when compared with placebo (33.79 vs. 41.8, p=0.001). There was also a statistically significant difference in the change in RADS-2 from baseline to 12 weeks when compared with placebo (56.95 vs. 66.7, p=0.001).

##### Collaborative Care vs. Treatment as Usual

One study comparing a collaborative care intervention with TAU reported on depression symptoms measured by the CDSR-R (Appendix F Table 17). Intervention patients had an 8.5-point greater decrease in mean CDRS-R score from baseline than treatment-as-usual participants (95% CI, −13.4 to −3.6; p=0.001) at 6 months and a 9.4-point greater decrease from baseline at 12 months (95% CI, −15.0 to −3.8; p=0.001). A test of the interaction between group effects and time was statistically significant at p<0.001.^233^

#### Results: Response, Remission, or Loss of Diagnosis

##### Psychotherapy vs. Wait-List Controls, Treatment as Usual, Attention Control, or Placebo

Regarding response, three studies reported responses on the BDI and BDI-II scale (Appendix F Table 18).^216,^ ^248,^ ^249^ These studies could not be pooled because of the varied thresholds used; however, all reported statistically significant differences favoring psychotherapy.

Other measures of response included CGI ≥ 2^207,^ ^210^ and <5^176^ depression symptoms for 8 weeks and fulfilling the Reliable Change Index^266,^ ^278^ The results were not consistent. One study defined response as CGI greater than or equal to 2 and did not report statistically significant differences.^207,^ ^210^ Another study defined response defined as 8 or more weeks below with the threshold of five or more depression symptoms necessary for full diagnosis but where full recovery has not yet occurred; the results were statistically significantly different favoring CBT at 52 and 104 weeks from baseline.^176^ A third study used the Reliable Change Index, that is, a way to ensure that the magnitude of change for individuals is statistically reliable, while scoring 2 standard deviations below the pretreatment mean and found a statistically significant difference favoring the active treatment.^266^

Two studies defined remission as a CDRS-R score ≤ 28; neither reported statistically significant differences.^187,^ ^207,^ ^210^ A third study defined remission as a QIDS-A17-SR score of 6 or lower and found a statistically significant difference favoring the active treatment.^266^

One study reported on recovery, defined as longer than or equal to 8 weeks of no or minimal symptoms on weekly Diagnostic Status Ratings (≤1–2) and little or no impairment. The results were statistically significantly different favoring CBT at 52 and 104 weeks from baseline.^176^

Five studies reported on loss of diagnosis.^174,^ ^204,^ ^207,^ ^210,^ ^248,^ ^249^ Of these, four (all in adolescents) reported sufficient data to be pooled.^174,^ ^207,^ ^248,^ ^249^ The pooled estimate and results from individual studies favored the treatment arms, but the confidence intervals spanned the null. A fifth study,^204^ of parent-child interaction therapy in young children (mean age: 5 years), could not pooled with the other studies but also reported results favoring the psychotherapy arm. Specifically, the study reported adjusted odds ratios when comparing the control arm with the intervention of 9.52 (95% CI, 8.44 to 10.74).^204^

##### Pharmacotherapy vs. Placebo

One study on escitalopram and one on fluoxetine reported response defined as the proportion of participants with CGI-I ≤ 2. Neither study found statistically significant differences between pharmacotherapy and placebo (Appendix F Table 19).^207,^ ^252^

All three pharmacotherapy studies (2 on escitalopram and 1 on fluoxetine) reported on the proportion of participants with CDRS-R score less than or equal to 28 at the end of treatment (8 or 12 weeks). This measure was termed as remission in two studies^185,^ ^207,^ ^210^ and response in one.^252^ Table 14 presents pooled results. The pooled estimate and results from individual studies favored treatment arms, but the confidence intervals spanned the null.^185,^ ^207,^ ^210,^ ^252^

Table 14 Depression Interventions and Remission From Depression, and Loss of Diagnosis: Pooled Estimates of Effect

Intervention | Time of Outcome Measurement | Outcome Measure | Outcome Range | Outcome Threshold Indicating Clinically Meaningful Effect | Treatment Range at Followup | Comparator Range at Following | Pooled Results
Psychotherapy
CBT | 8 to 12 weeks from baseline | Loss of diagnosis measured by clinical interviews | 0 to 100 for proportion | NA | 56% to 71% | 16% to 60% | RR: 1.73 (95% CI, 1.00 to 3.00); N=395; k=4;^174,^ ^207,^ ^248,^ ^249^ I^2^=81%^*^; Appendix G Figure 29
Pharmacotherapy
Escitalopram, fluoxetine | 8 to 12 weeks from baseline | Remission from depression symptoms (CDRS-R≤28) | 0 to 100 for proportion | CDRS-R≤28 indicates moderate marked improvement, proportion threshold unclear | 23% to 46% | 17% to 38% | RR: 1.20 (95% CI, 1.00 to 1.45), N=793; k=3;^185,^ ^207,^ ^210,^ ^252^ I^2^=0%; Appendix G Figure 30

* We averaged the results across arms for one study with two intervention arms: with and without parent sessions.^174^

Abbreviations: CBT=cognitive behavioral therapy; CDRS-R=Children’s Depression Rating Scale-Revised; CI=confidence interval; I^2^=percentage of variation across studies that is due to heterogeneity rather than chance; k=number of studies; NA=not applicable; RR=relative risk.

One study on fluoxetine reported loss of MDD diagnosis based on K-SADS-P/L interview and found that a significantly greater proportion of those receiving fluoxetine no longer met MDD criteria at 12 weeks compared with placebo (78.6% vs. 60.4%, p=0.007).^207,^ ^210^

##### Combination Therapy (Fluoxetine Plus CBT) vs. Placebo

One study^207,^ ^210^ found that the combination therapy arm had a higher and statistically significant rate of response (CGI-I≤2: 71.0% vs. 34.8%; p=0.0001^207^), remission (CDRS-R≤28: 37% vs. 17%; OR: 3.0 [95% CI, 1.58 to 5.79]^210^), and loss of diagnosis (no longer meeting DSM-IV criteria for MDD using the K-SADS-P/L: 85.3% vs. 60.4%; OR: 4.1 [95% CI, 2.00 to 8.44]^210^) when compared with placebo (Appendix F Table 20).

##### Collaborative Care vs. Treatment as Usual

The collaborative care study found intervention participants were more likely than treatment-as-usual patients to achieve depression response (≥50% reduction in CDRS-R score from baseline) by 12 months (OR, 3.3 [95% CI, 1.4 to 8.2]; p=0.009) but not by 6 months (OR, 3.1 [95% CI, 1.2 to 7.9]; p=0.02). Intervention participants were significantly more likely to achieve depression remission (PHQ-9 < 5) at both 6 months (OR, 5.2 [95% CI, 1.6 to 17.3]; p=0.007) and 12 months (OR, 3.9 [95% CI, 1.5 to 10.6]; p=0.007) (Appendix F Table 21 and Table 22).^233^

#### Results: All-Cause Mortality

##### Psychotherapy vs. Wait-List Controls, Treatment as Usual, Attention Control, or Placebo

No studies reported on all-cause mortality.

##### Pharmacotherapy vs. Placebo

No studies reported on all-cause mortality.

##### Combination Therapy (Fluoxetine Plus CBT) vs. Placebo

No studies reported on all-cause mortality.

##### Collaborative Care vs. Treatment as Usual

No studies reported on all-cause mortality.

#### Results: Functioning

##### Psychotherapy vs. Wait-List Controls, Treatment as Usual, Attention Control, or Placebo

Six studies reported functioning outcomes, including quality-of-life outcomes.^174–176,^ ^204,^ ^205,^ ^207,^ ^211,^ ^216^ Four^175,^ ^176,^ ^207,^ ^211,^ ^216^ of five studies reporting on CGAS could be pooled; the results suggested no statistically significant differences (Table 15). A fifth study,^204^ of parent-child interaction therapy in young children, did not report exact p-values and could not pooled with the other studies, but the results favor psychotherapy with a Cohen’s d of 1.16, p<0.0001.

Table 15 Depression Interventions and Functional Status: Pooled Estimates of Effect

Intervention | Time of Outcome Measurement | Outcome Measure | Outcome Range | Outcome Threshold Indicating Clinically Meaningful Effect | Treatment Range at Followup | Comparator Range at Following | Pooled Results
Psychotherapy
Individual in-person CBT, interpersonal psychotherapy | 12 to 52 weeks from baseline | CGAS | 1 to 100^309^ | >70: no clinically significant functional impairment; <41: major impairment to functioning in several areas^309^ | 60.0 to 72.3 | 59.3 to 74.1 | Mean difference: 1.52 (95% CI, −1.54 to 4.58); N=601; k=4;^176,^ ^207,^ ^216^ I^2^=66%; Appendix G Figure 31
Pharmacotherapy
Escitalopram, fluoxetine | 8 to 12 weeks from baseline | CGAS | 1 to 100^309^ | >70: no clinically significant functional impairment; <41: major impairment to functioning in several areas^309^ | 62.1 to 68.5 | 59.3 to 64.6 | Mean difference: 2.60 (95% CI, 0.78 to 4.42); N=793; k=3;^185,^ ^207,^ ^252^ I^2^=0%; Appendix G Figure 32

Abbreviations: CBT=cognitive behavioral therapy; CGAS=Children’s Global Assessment Scale; CI=confidence interval; I^2^=percentage of variation across studies that is due to heterogeneity rather than chance; k=number of studies; N=number.

In addition to CGAS, studies also reported functioning with other measures (Appendix F Table 23). Nearly all studies reported larger improvements in functioning or quality of life with treatment; however, most studies were not powered on these outcomes; thus, estimates may have been imprecise and may not have reached statistical significance. One study reported functioning using the SAS-SR and reported statistically significant larger improvements with interpersonal psychotherapy compared with TAU (school-based clinic care),^216^ and a second reported significantly larger improvements in functioning as measured by the PECFAS^204^ and total sleep problems as measured by CBCL;^205^ these findings were consistent with CGAS outcomes also reported by these studies. A third study reported no statistically significant differences in functioning at 12 weeks between participants allocated to individual, in-person CBT compared with no CBT with a placebo pill as measured with the HoNOSCA and PQ-LES-Q measures, also consistent with CGAS findings of no effect for this study.^207,^ ^211^ In a fourth study, despite finding a statistically significant favorable effect of individual, in-person CBT compared with TAU at 52 weeks as measured by CGAS, the authors observed differences in quality of life as measured by the PEDS-QL measure that were not statistically significant.^176^ A fifth study reported statistically significant improvements in the mental health component score of the Short-Form 12 (SF-12) for an individual, in-person CBT compared with TAU; SF-12 physical component scores and the CGAS scores were also improved more with treatment, but these results were not statistically significant.^175^ Finally, a sixth study reported statistically significant larger improvements in functioning as measured by the Global Assessment of Functioning for the two variations of group CBT intervention compared with placebo.^174^

##### Pharmacotherapy vs. Placebo

Three studies reported functioning outcomes, including quality of life (Appendix F Table 25).^185,^ ^207,^ ^252^ Pooled results for CGAS indicated statistically significant differences favoring pharmacotherapy (Table 15).

In addition to change in CGAS scores, one study reported outcomes using the HoNOSCA and PQ-LES-Q measures.^207,^ ^211^ Although participants allocated to treatment showed larger improvements on these measures consistent with CGAS outcomes, findings were not statistically significant.^207,^ ^211^ In addition, the proportion of participants achieving a CGAS score of less than 70 (the threshold associated with no impairment) was 20 percent in the treatment group compared with 19 percent in the placebo group (p=NS).

##### Combination Therapy (Fluoxetine Plus CBT) vs. Placebo

The Treatment for Adolescents with Depression Study (TADS) study reported functioning outcomes.^207,^ ^211^ In this study, combination therapy was associated with larger improvement in functioning as measured by the CGAS, HoNOSCA, and PQ-LES-Q at 12 weeks compared with no CBT/placebo control (Appendix F Table 27).

##### Collaborative Care vs. Treatment as Usual

The collaborative care study measured functional status on the Columbia Impairment Scale. Differences between the intervention and control arms were not significant at an a priori p-value threshold of less than or equal to 0.01 at 6 months (mean difference, −4.4 [95% CI, −8.4 to −0.5]; p=0.03) or 12 months (mean difference, −4.3 [95% CI, −8.3 to −0.3]; p=0.04).^233^

#### Results: Findings for Specific Populations

##### Subgroup Analyses

Appendix F Table 29 presents qualitative results for specific populations. Two CBT studies reported analyses for specific populations.^174,^ ^207–211^ One study reported analyses by age.^208^ Adolescents who were younger than 16-years-old at baseline had significantly greater improvement in clinician-rated symptom severity than adolescents who were 16 or older across all treatment conditions.^208^ No statistically significant differences in functioning were reported by age.^211^ Two studies reported no statistically significant differences in functioning^211^ or recovery rates^174^ by sex. One study reported no statistically significant differences in functioning by race or ethnicity.^211^

Two pharmacotherapy studies (escitalopram^252^ and fluoxetine^207–211^) reported analyses for specific populations. Both studies reported on functioning outcomes by age.^211,^ ^252^ One study reported that 12- to 17-year-old adolescents, but not 6- to 11-year-old children, in the treatment group had significantly better improvements on a clinician-rated measure of functioning than their counterparts in the pill placebo group.^252^ One study reported no statistically significant differences in clinician- or self-reported functioing by age.^211^ Both studies reported on symptom severity by age.^208,^ ^252^ One study reported that 12- to 17-year-old adolescents, but not 6- to 11-year-old children, in the treatment group had significantly better improvements on measures of symptom severity than their counterparts in the pill placebo group.^252^ One study reported that adolescents who were younger than 16-years-old at baseline had significantly greater improvement in clinician-rated symptom severity than adolescents who were 16 or older across all treatment conditions.^208^ One study reported on symptom improvement by age.^252^ The study found that 12- to 17-year-old adolescents, but not 6- to 11-year-old children, in the treatment group had significantly better clinician-rated improvement in symptoms than their counterparts in the pill placebo group. One study reported no statistically significant differences in functioning by sex, race, or ethnicity.^211^

One study^207–211^ of combined pharmacotherapy (fluoxetine) and CBT reported analyses on symptom severity^208^ and overall functioning^211^ by age,^208^ sex,^211^ or race/ethnicity.^211^ Adolescents who were younger than 16-years-old at baseline had significantly greater improvement in clinician-rated symptom severity than adolescents who were 16 or older across all treatment conditions.^208^ No statistically significant differences in functioning were reported by age, sex, or race/ethnicity.^211^

##### Findings Within Age Groups

One study of psychotherapy (parent-child interaction therapy) restricted inclusion to young children, ages 3 to 6 years, with a mean age of 5 years.^204^ The study reported statistically significant benefit for symptoms, loss of diagnosis, and functioning for psychotherapy. We found no studies of pharmacotherapy in children.

Two studies recruited both children and adolescents. One study on omega-3, individual-family psychoeducational psychotherapy, and their combination recruited children from ages 7 to 14 years, with a mean age of 11.6 years.^187^ The study found that individual-family psychoeducational psychotherapy when compared with placebo did not produce statistically significant differences for symptoms or remission. A second study, on escitalopram, recruited children from 6 to 17 years, with a mean age of 12.3 years. The study found no statistically significant differences for symptoms, response, or functioning.^252^

All other studies were restricted to adolescents only, with ages for inclusion ranging from 12 to 19 years and mean age ranging from 14.6 to 17.5 years. One study had three arms contributing to evidence on psychotherapy, pharmacotherapy, and their combination. In all, the evidence on adolescents included seven studies on psychotherapy,^174–176,^ ^207,^ ^216,^ ^248,^ ^249^ two on pharmacotherapy,^185,^ ^207^ one on combination therapy,^207^ and one on collaborative care,^233^ and their results are described in the main results above.

### Anxiety or Depression

We included two studies of fair quality (described in 3 articles) that studied children with anxiety or depression.^184,^ ^263,^ ^264^ Detailed study, population, intervention characteristics, and results are provided in Appendix I Tables 35 through Table 40.

#### Study Characteristics

One study (N=51) included participants ages 12 to 17 years (mean age: 15.8) with a primary diagnosis of any DSM-IV anxiety disorder (including obsessive compulsive disorder) or depression.^184^ The second study (N=185) included children and adolescents ages 8 to 16 years (mean age: 11.3) meeting DSM-IV criteria for full or probable diagnoses of separation anxiety, GAD, social anxiety disorder, MDD, dysthymic disorder, or minor depression.^263,^ ^264^ In both studies, anxiety disorders were more common than depressive disorders. Female participants constituted 57 percent^184^ to 58 percent^263,^ ^264^ of the samples. The majority of participants were Hispanic (59%, excluding non-Hispanic White participants) in one study^184^ and White in the other (excluding Hispanic participants).^263,^ ^264^

Both studies offered a transdiagnostic approach drawing on cognitive science, with a minimum of eight weekly sessions. One study offered up to maximum of 12 sessions^184^ and the other up to 21 sessions.^263,^ ^264^ The comparison group was put on a wait-list in one study^184^ or offered an assisted referral in the other.^263,^ ^264^

The studies reported on anxiety and depression symptoms and functioning. Additionally, one study reported on response at 16 weeks (end of treatment)^263^ and response and remission at 32 weeks.^264^

Both studies were conducted in the United States and included clinical referrals and self-referrals. The results below describe outcomes for the overall sample in each study.

#### Results: Anxiety Symptoms

##### Psychotherapy Interventions vs. Wait-List or Assisted Referral Controls

One study (mean age: 15.8 years) reported ADIS clinician severity rating scale and reported statistically significant differences favoring treatment at followup (4.1 vs. 5.4 at 8 weeks, p<0.006) and change from baseline to followup.^184^ The threshold for meeting the criteria for diagnosis is 4. The second study (mean age: 11.3 years) reported on PARS and similarly found statistically significant improvements at followup (16 weeks) and change from baseline to followup; the study reported followup values of PARS below 12 (the threshold for clinical response^279^) in both arms (8.6 vs. 11.4).^263,^ ^264^ The benefits continued to be statistically significantly different at 32 weeks (p=0.003, details not reported).^264^

Both studies reported on CGI-S and CGI-I scores. Both reported statistically significant differences for CGI-S favoring treatment (2.6 vs. 3.4, calculated mean difference −0.80 [95% CI, −1.19 to −0.41];^184^ 4.1 vs. 5.1, mean difference: −1.00, p<0.006^263^) and CGI-I (2.3 vs. 3.1, calculated mean difference −0.80 [95% CI, −1.23 to −0.37];^184^ 3.04 vs. 4.00, mean difference: −0.96, p=0.016^263^) favoring transdiagnostic treatment over wait-list or assisted referral.

#### Results: Depression Symptoms

##### Psychotherapy Interventions vs. Wait-List or Assisted Referral Controls

One study reported results for RCADS scores at the end of treatment and the second on CDRS-R scores at the end of treatment at 16 weeks and at 32 weeks. Neither study reported statistically significant differences for measures of depression.^184,^ ^263^ However, as noted above, both studies reported significantly different CGI-S and CGI-S scores at followup, favoring transdiagnostic treatment over wait-list or assisted referral.

#### Results: Response, Remission, and Loss of Diagnosis

##### Psychotherapy Interventions vs. Wait-List or Assisted Referral Controls

One study reported statistically significant results favoring treatment for response, defined as CGI-I≤2, posttreatment at 16 weeks (56.8% vs. 28.2%, p<0.001)^263^ and at 32 weeks (67.5% vs 4.31%^264^). The differences for remission (36.3% vs. 22.2%) at 32 weeks, defined as CGI-I=1, favored transdiagnostic treatment over assisted referral but were not statistically significant (p=0.06).^264^

#### Results: All-Cause Mortality

No studies reported on all-cause mortality.

#### Results: Quality of Life and Functioning

One study reported no statistically significant differences in the Adolescent Life Interference Scale (ALIS) at 8 weeks.^184^ The second study reported statistically significant differences favoring treatment in CGAS at 16 (68.5 vs. 61.9, p=0.001^263^) and 32 weeks (70.9 vs. 65.0, p=0.004^264^); CGAS scores greater than or equal to 70 represent functional remission.

#### Results: Findings for Specific Populations

##### Subgroup Analyses

One study reported that ethnicity moderated response to transdiagnostic treatment, with Hispanic youths having a heightened response and greater improvements in functioning than other participants when compared with Hispanic youths in the assisted referral arm.^263^

##### Findings Within Age Groups

One study^184^ included adolescents only with recruitment restricted to ages 12 to 17 years and a mean age of 15.8 years, and a second study^263,^ ^264^ included both children and adolescents with inclusion ranging from 8 to 16 years and a mean age of 11.3 years. Neither reported results for children versus adolescents.

## KQ 5 What Are the Harms of Treatment (Psychotherapy, Pharmacotherapy, or Collaborative Care) in Children and Adolescents Who Are Treated for Depression, Anxiety, or Suicide Risk?

### Suicide Risk

#### Summary

We included two RCTs of good or fair quality (described in 4 articles).^179–181,^ ^192^ Detailed study, population, and intervention characteristics are provided in Appendix I Table 16.

#### Study Characteristics

The characteristics of the included studies are summarized in Table 4. Two studies admitted children based on elevated suicide risk.^179–181,^ ^192^

Mean ages ranged from 14 to 16 years. Included studies focused on adolescence: one study included adolescents 11 to 17 years^179–181^ and one study included adolescents 12 to 18 years.^192^ The majority of both samples were female.^179–181,^ ^192^ One study included mostly White Scottish adolescents,^192^ and one study did not report race or ethnicity.^179–181^

Included studies examined family therapy^179–181^ and MBT.^192^ Both studies compared intervention with TAU. Duration of treatment ranged between six and 12 sessions over 12 months. No evidence was captured that examined pharmacotherapies.

The two included studies^179–181,^ ^192^ reported on any adverse events, and one study^179–181^ reported on incidence of serious adverse events and other harms. Time of measurement across outcomes ranged from 12 weeks to 4 years.

The two included studies recruited participants from child and adolescent mental health services in the United Kingdom.^179–181,^ ^192^ One study^179–181^ was rated good quality, and one study^192^ was rated fair quality.

#### Results: Other Adverse Events

One study^179–181^ reported on adverse events, serious adverse events, and other harms during the 12- to 18-month followup period. Similar numbers of adverse events, including attendance at minor injury units, walk-in centers, accident and emergency centers, and re-referral to mental health services, occurred in the family therapy group (54%) and treatment-as-usual group (52%). Serious adverse events, defined as hospital attendance, also occurred at similar rates across the intervention (38%) and control (34%) arms. Two participants assigned to the family therapy group died between 3 and 4 years post-randomization. Neither death was related to self-harm. One additional study^192^ reported five adverse events among four participants, but the occurrences were not considered to be trial related and not reported by group.

#### Results: Findings for Specific Populations

##### Subgroup Analyses

No study reported on harms for specific populations.

##### Findings Within Age Groups

Both studies were in adolescents only.

### Anxiety

#### Summary

As noted previously, we limited the synthesis to CBT for psychotherapy; we included pharmacotherapies approved by the FDA for children and adolescents. Eleven studies of good or fair quality addressed harms (described in 22 articles).^168,^ ^169,^ ^224–228,^ ^238,^ ^239,^ ^242–244,^ ^253–262^ Detailed study, population, intervention characteristics, and results are provided in Appendix I Table 24.

#### Study Characteristics

Four studies evaluating CBT,^224,^ ^239,^ ^242,^ ^253^ six evaluating pharmacotherapy,^168,^ ^169,^ ^238,^ ^243,^ ^244^ and one study with three arms evaluating CBT, sertraline, and combination therapy^254–262^ addressed harms. Table 16 describes these studies in detail.

Table 16 Key Characteristics of Included Anxiety Studies for Harms

Study Characteristics | Subcharacteristics | Number of Studies | Percent
Population characteristics: Child or adolescent | Child (mean age <13) | 6 | 54.5
| Adolescent (mean age ≥13) | 5 | 45.5
Population characteristics: Gender | Mostly female | 8 | 72.7
| Mostly male | 2 | 18.2
| Equal distribution | 1 | 9.1
Population characteristics: Race | Mostly White | 8 | 72.7
| Not reported | 3 | 27.3
Population characteristics: Diagnosis | Any anxiety disorder | 3 | 27.3
| GAD | 4 | 36.4
| Social anxiety disorder | 1 | 9.1
| Selective mutism | 1 | 9.1
| GAD, social anxiety disorder, or separation anxiety | 2 | 18.2
Intervention characteristics: Types of interventions | Nonpharmacological | 4 | 36.4
| Pharmacological | 6 | 54.5
| Multiple arms of CBT, pharmacotherapy, and combination | 1 | 9.1
Comparator | Placebo comparator | 7 | 63.6
| Wait-list comparator | 4 | 36.4
Geographic setting | United States | 6 | 54.5
| United Kingdom | 2 | 18.2
| Denmark | 1 | 9.1
| Germany | 1 | 9.1
| Multiple countries | 1 | 9.1
Recruitment setting | Community recruitment | 3 | 27.3
| Referrals from mental health professionals | 5 | 45.5
| Schools | 1 | 9.1
| Not specified | 2 | 18.2

Abbreviations: CBT=cognitive behavioral therapy; GAD=generalized anxiety disorder.

#### Results: Suicide Deaths, Suicide Attempts and Deliberate Self-Harm, or Suicidal Ideation

##### Psychotherapy vs. Wait-List Controls, Treatment as Usual, or Placebo

Two studies of individual CBT reported on suicidal ideation, attempts, or self-harm behavior.^253–262^ One study (internet, child plus parent) of 60 participants^253^ reported that two participants in the wait-list control group withdrew from the study because of risk of suicide by 17 weeks; the study did not note similar withdrawals in the CBT arm. A second child-focused in-person study reported on self-harm behavior without suicidal attempt (1/139 [0.7%] vs. 0/76 [0%]), suicidal ideation (5/139 [3.6%] vs. 1/76 [1.3%]), and suicidal attempts (no events in either arm) by 12 weeks.^254–262^

##### Pharmacotherapy vs. Placebo

Three studies reported on suicide-related harms at the end of treatment at 8 to 12 weeks (duloxetine,^243^ escitalopram,^244^ and sertraline^254–262^). No studies reported suicide deaths, two studies reported on suicide attempts (1/26 for escitalopram vs. 0/25 events for placeb;^244^ no events in 1 study for either sertraline or placebo^254–262^); three reported on suicidal ideation or worsening of suicidality (1/135 vs. 0/137 for duloxetine vs. placebo;^243^ 6/26 for escitalopram vs. 2/25 for placebo;^244^ 0/133 for sertraline vs. 1/76 for placebo^254–262^), and two studies reported on self-injurious behavior (2/26 for escitalopram vs. 1/25 for placebo;^244^ 1/133 for sertraline vs. 0/76 for placebo^254–262^) (Appendix F Table 12). Suicide-related harms were rare, and the differences were not statistically significantly different.

##### Combination Therapy (Pharmacotherapy and Psychotherapy) vs. Placebo

One study reported on outcomes comparing sertraline plus CBT with placebo.^254–262^ The study reported more self-harm behaviors without suicide attempts (1.4% [2/140] vs. 0) and suicidal ideation (3.6% [5/140] vs. 1.3% [1/76]) in the combination arm at 12 weeks, but no suicide attempts in either arm.^254^

#### Results: Other Adverse Events

##### Psychotherapy vs. Wait-List Controls, Treatment as Usual, or Placebo

Two child-focused studies of individual CBT reported on serious adverse events.^254–262^ One study of 73 participants^239,^ reported a single adverse event in the wait-list control group of hospitalization due to the need to remove a dental brace by 31 weeks. No serious adverse events were reported in either arm in the other study by 12 weeks.^254–262^

Four studies reported on withdrawal due to side effects for treatments ranging from 10 to 14 weeks.^224,^ ^242,^ ^253–262^ The studies varied in type of CBT: they included individual and group therapy, delivered in person and on the internet, and child-focused and child and parent therapy. The RR of withdrawal due to side effects was 0.39 (95% CI, 0.08 to 1.87; N=372; k=5; I^2^=0%, Appendix G Figure 33).

One study reported no homicidal ideation or events in either arm of an individual in-person child-focused CBT when compared with placebo by 12 weeks.^254–262^

##### Pharmacotherapy vs. Placebo

Three studies reported on serious adverse events (duloxetine,^243^ escitalopram,^244^ and sertraline^254–262^). The escitalopram study reported one individual experiencing serious adverse events in both arms.^244^ The other two studies reported one individual experiencing serious adverse events in the treatment arm and none in the placebo arm.^243,^ ^254^

Five studies (1 each on duloxetine,^243^ escitalopram,^244^ fluvoxamine,^225–228^ and sertraline,^254–262^ and fluoxetine^168^) reported on withdrawal due to adverse events. Together, the RR of withdrawal across all drugs was 1.72 (95% CI, 0.57 to 5.18; N=734; k=5; I^2^: 26%; Appendix G Figure 34). The risk of withdrawal due to adverse events appeared to be elevated for fluvoxamine and fluoxetine.

One study reported that two participants (1.5%) experienced homicidal ideation (but no homicidal attempts in the intervention and none in placebo arm).^254^

Fluoxetine studies reported greater frequency^168^ or severity^169^ of some adverse events. adverse events reported at statistically higher frequency in the pharmacotherapy arm included gastrointestinal events^168,^ ^225^ and neurological complaints.^168^ Although other pharmacotherapy studies reported higher frequency of some other harms in the treatment arm when compared with placebo, the differences did not reach statistical significance at p=0.05 (Appendix F Table 13).

##### Combination Therapy (Pharmacotherapy and Psychotherapy) vs. Placebo

One study reported on outcomes comparing sertraline plus CBT with placebo.^254–262^ The study reported few or no occurrences of serious adverse events (1 event in the combined therapy arm and no events in the placebo arm), withdrawal due to adverse events (1 event in each arm), homicidal ideation (no events in either arm), and homicidal attempts (no events in either arm). The study did, however, report a higher frequency pf psychiatric adverse events (29.3% vs. 13.2%, calculated absolute risk difference: 16/100 [95% CI, 5 to 27]) and all harms-related adverse events, that is, self-injurious behavior and homicidal ideation (10.0% vs. 1.3%, calculated absolute risk difference: 9/100 [95% CI, 3 to 14]) in the combined therapy arm when compared with placebo.

#### Results: Findings for Specific Populations

##### Subgroup Analyses

One study with three arms (CBT, sertraline, and CBT plus sertraline)^167,^ ^190,^ ^241,^ ^254–262^ reported on harms for specific populations. The authors reported that the rate of psychiatric adverse events, but not physical adverse events, was significantly higher in children compared to adolescents across all treatment arms.^260^ The rate of overall adverse events was significantly higher in children than adolescents who received sertraline.^260^

##### Findings Within Age Groups

No studies reported on harms in young children.

Results for older children or children and adolescents are described above.

Results for studies of adolescents only suggested lower rates of harms for CBT^239,^ ^242,^ ^253^ and higher rates of harms for escitalopram,^244^ but results were not statistically significant.

### Depression

#### Summary

We included seven studies for KQ 5 (described in 12 articles).^173,^ ^176,^ ^185,^ ^186,^ ^207–211,^ ^233,^ ^252,^ ^266^ All KQ 5 studies are also included in KQ 4 except for one meta-analysis, which was new to this review update.^173^ One study that was included in the previous USPSTF report on depression was excluded from this report for ineligible intervention. This study tested citalopram, which was not included in this current update.^277^

#### Study Characteristics

The characteristics of the included studies are summarized in Table 17. Detailed study, population, intervention characteristics, and results are provided in Appendix I Table 32 through Table 34. Detailed outcomes are provided in Appendix F Table 30 through Table 38.

Table 17 Key Characteristics of Included Depression Studies for Harms

Study Characteristics | Subcharacteristics | Number of Studies | Percent
Population characteristics: Child or adolescent | Child (mean age <13) | 1 | 14.3
| Adolescent (mean age ≥13) | 6 | 85.7
Population characteristics: Gender | Mostly female | 7 | 100.0
| Mostly male | 0 | 0.0
Population characteristics: Race | Mostly White | 4 | 57.1
| Mostly non-White | 0 | 0.0
| Not reported | 3 | 42.9
Population characteristics: Diagnosis | MDD | 7 | 100.0
| PDD/DD/DNOS | 1 | 14.3
Intervention characteristics: Types of interventions | Nonpharmacological | 2 | 28.6
| Pharmacological | 3 | 42.9
| Multiple arms of CBT, pharmacotherapy, and combination | 1 | 14.3
| Collaborative care | 1 | 14.3
Comparator | Placebo comparator | 3 | 42.9
| Treatment as usual | 2 | 28.6
| Placebo or another antidepressant | 1 | 14.3
| Attention control | 1 | 14.3
Geographic setting | United States | 5 | 71.4
| Multiple countries | 1 | 14.3
| Sweden | 1 | 14.3
Recruitment setting | Advertised widely | 3 | 42.9
| Health systems and clinics | 2 | 28.6
| Not specified | 2 | 28.6

Abbreviations: CBT=cognitive behavioral therapy; GAD=generalized anxiety disorder; MDD=major depressive disorder; PDD/DD/DNOS=persistent depressive disorder/dysthymia disorder/depression not otherwise specified.

#### Results: Suicide Deaths, Suicide Attempts and Deliberate Self-Harm, or Suicidal Ideation

##### Psychotherapy vs. Wait-List Controls, Treatment as Usual, Attention Control, or Placebo

Two studies of CBT interventions reported on suicide-related events (Appendix F Table 30 and Table 31).^176,^ ^207,^ ^209^ Suicide-related events included suicide attempts and new or worsened ideation. Both reported higher but not statistically significantly different rates in the treatment arm. One study, comparing CBT plus TAU with TAU, reported five events among 106 participants (4.7%) in the CBT with TAU arm compared with two events among 106 participants (1.9%) in the TAU arm (RR, 2.50 [95% CI, 0.50 to 12.60]).^176^ At study entry, all had recently declined or discontinued antidepressants prematurely. During a year-long followup, a minority of participants received antidepressants in each arm (9.4% in the CBT plus TAU arm and 7.6% in the TAU arm). The second study, TADS,^207,^ ^209^ reported inconsistent results across various TADS publications. TADS included four study arms: CBT, fluoxetine, combined CBT and fluoxetine, and a placebo comparator. The events reported by parents and patients were reviewed and subsequently recoded using the Columbia-Classification Algorithm for Suicidal Assessment in a reanalysis. The first analysis published by study authors in 2004 reported five events among 109 participants (4.6%) in the CBT arm compared with four events among 112 participants (3.6%) in the placebo arm (RR, 1.26 [95% CI, 0.35 to 4.57]).^207^ Safety results of reanalyzed data published in 2006 reported three (2.7%) events in the placebo arm, resulting in a higher RR of 1.68 (95% CI, 0.41 to 6.87).^209^ An extended analysis of TADS was published in 2009 that included suicide-related events through blinded (baseline to week 12) and unblinded phases (week 12 to week 36) of the trial.^280^ These analyses are not eligible for the current systematic review because they include events that occurred after unblinding and clinical management of nonresponders. However, the publication included a graphic indicating that five suicide-related events occurred in the placebo arm by week 12, of which two occurred in participants on SSRIs at the time of the event. The placebo arm did not appear to include TAU: the authors reported that they discarded a community-based TAU group because of concerns about variability and access to care.^207^ No further details or per-protocol analyses are available from the authors. A per-protocol analysis that reassigns placebo participants receiving SSRIs to the pharmacotherapy arm would change the denominators and, therefore, relative risks for all comparisons in the study.

The TADS study reported no statistically significant differences on suicidal ideation measured by the SIQ-Jr scale.^207^

##### Pharmacotherapy vs. Placebo

Three studies reported on suicide-related outcomes using a variety of measures (Appendix F Table 32 and Table 33). One study explicitly reported that no completed suicides occurred;^252^ the others did not report data on deaths.^207,^ ^209,^ ^252^ The two escitalopram studies reported similar rates of events potentially related to suicide or self-harm when compared with placebo (1 event among 129 participants [0.8%] vs. 2 events among 132 participants [1.5%];^252^ 6 events among 157 participants [3.8%] vs. 6 events among 155 participants [3.9%]^185^). The fluoxetine study (TADS)^207,^ ^209^ reported inconsistent results across various publications on suicide-related events. The first analysis published by study authors in 2004 suggested a higher but nonstatistically significant rate of suicide-related events in the fluoxetine arm when compared with placebo (9 events among 109 participants [8.3%] vs. 4 events among 112 participants [3.4%]; RR, 2.31 [95% CI, 0.73 to 7.29]).^207^ Safety results published in 2006 reported 10 (9.2%) events in the intervention and three (2.7%) in the placebo arm resulting in a higher RR, 3.43 (95% CI, 0.97 to 12.11).^209^

Two studies reported no statistically significant differences on suicidal ideation measured by the SIQ-Jr scale.^185,^ ^207^

One network meta-analysis examined harms across a range of drugs and populations, including those ineligible for the current review (Appendix I Table 34). The rate of suicide-related behaviors or ideation events appeared similar for escitalopram versus placebo (15/290 [5%] vs. 15/294 [5%], 2 studies) and for fluoxetine versus placebo (51/521 [10%] vs. 44/514 [9%], 7 studies).^173^

##### Pharmacotherapy Plus CBT vs. Placebo

A single study on combination therapy, the TADS trial, reported on suicide-related events, with results varying by publication source (Appendix F Table 34 and Table 35).^207,^ ^209^ The first analysis published by study authors in 2004 reported six suicide-related events among 107 participants (5.6%) in the combined arm compared with four events among 112 participants (3.4%) in the placebo arm (RR, 1.57 [95% CI, 0.46 to 5.41]).^207^ Safety results published in 2006 reported five (4.7%) events in the intervention and three (2.7%) in the placebo arm, resulting in a higher RR, 1.75 ( 95% CI, 0.43 to 7.12).^209^

One study reported a statistically significant difference on suicidal ideation measured by the SIQ-Jr scale, favoring combination therapy (mean score at followup: 11.79 vs. 15.01, p=0.02) in adjusted analyses but not in comparisons of mean differences.^207^

##### Collaborative Care vs. Treatment as Usual

The study did not report suicide-related outcomes.

#### Results: Other Adverse Events

##### Psychotherapy vs. Wait-List Controls, Treatment as Usual, Attention Control, or Placebo

No study reported on withdrawal due to adverse events. The TADS study reported no differences in rate of harm-related adverse events (which included self-harm without suicidal intent, suicide attempt, and harm to others) in the CBT arm when compared with placebo (5 events among 111 participants [4.5%] vs. 6 events among 112 participants [5.4%, OR: 0.8 [95% CI, 0.25 to 2.81]) (Appendix F Table 36).^207^ One study used an open-ended question on the QIDS-A17-SR to assess potential negative effects and found that no participant in the treatment arm deteriorated reliably on the QIDS-A17-SR when compared with three participants in the control arm.^266^

##### Pharmacotherapy vs. Placebo

Two escitalopram trials reported on withdrawal due to adverse events and serious adverse events (Appendix F Table 37). One trial reported higher rates in the treatment arm for both outcomes (4 (2.6%) withdrawals in the treatment arm and 1 (0.6%) in the placebo arm; 4 (2.6%) serious adverse events in the treatment arm and 2 (1.3%) in the placebo arm^185^). The second reported similar rates in both arms for both outcomes (2 [1.5%] withdrawals due to adverse events vs. 2 [1.5%]; 2/131 [1.5%] serious adverse events vs. 3/133 [2.3%]).^252^ These differences were not statistically significantly different in either study.

The fluoxetine study (TADS) study reported a higher but not statistically significantly different rate of harm-related adverse events in the combined therapy arm when compared with placebo (13 events among 109 participants [11.9%] vs. 6 events among 112 participants [5.4%, OR: 2.4, [95% CI, 0.87 to 6.54]).^207^

##### Pharmacotherapy + CBT vs. Placebo

No study reported on withdrawal due to adverse events. The TADS study reported a higher but not statistically significantly different rate of harm-related adverse events in the combined therapy arm when compared with placebo (9 events among 107 participants [8.4%] vs. 6 events among 112 participants [5.4%, OR: 1.6 [95% CI, 0.56 to 4.72]) (Appendix F Table 38).^207^

##### Collaborative Care vs. Treatment as Usual

A single trial of collaborative care found no differences in psychiatric hospitalizations among intervention patients compared with control patients (6% vs. 4%, respectively). More control patients experienced an ED visit with a primary psychiatric diagnosis than intervention patients (1 [2%] vs. 5 [10%] patients, respectively); however, this study was not powered to detect differences.^233^

#### Results: Findings for Specific Populations

##### Subgroup Analyses

No study reported on harms for specific populations.

##### Findings Within Age Groups

The only study in children did not report on harms.^204^

One of the two studies in children and adolescents, specifically on omega-3, individual-family psychoeducational psychotherapy, and their combination, did not report on the harms of individual-family psychoeducational psychotherapy when compared with placebo.^187^ One study on escitalopram reported similar or lower rates of harms in the treatment arm.^252^

The remainder of the studies reported on adolescents only; the results are summarized above.

### Anxiety or Depression

#### Results: Suicide Deaths, Suicide Attempts and Deliberate Self-Harm, or Suicidal Ideation

No studies reported on suicide outcomes.

#### Results: Other Adverse Events

No studies reported on other adverse events.

#### Results: Findings for Specific Populations

No study reported on harms for specific populations.