# Chapter 2 Methods

## Key Questions and Analytic Framework

The scope and key questions (KQs) were developed by the Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers. Figure 1 depicts the analytic framework and KQs that guided the review.

Figure 1 Analytic Framework

Abbreviation: KQ=key question.

This figure is an analytic framework depicting the key questions within the context of the populations, interventions, comparisons, outcomes, time frames, and settings (PICOTS) relative to the effectiveness and harms of screening and treatment for depression, anxiety, and suicide risk in children and adolescents. The figure illustrates screening of adolescents and children in populations representative of primary care, followed by possible harms of screening; diagnosis of major depressive disorder, anxiety disorder, or high risk for suicide; treatment; possible harms of treatment; and health outcomes.

Five KQs were developed for this review:

1. Do depression, anxiety, or suicide risk screening programs in primary care or comparable settings result in improved health outcomes in children and adolescents?
2. Do instruments to screen for depression, anxiety, or suicide risk accurately identify children and adolescents with depression, anxiety, and increased risk of suicide in primary care or comparable settings?
3. What are the harms associated with screening for depression, anxiety, or suicide risk in primary care or comparable settings in children and adolescents?
4. Does treatment (psychotherapy, pharmacotherapy, or collaborative care) of depression, anxiety, or suicide risk result in improved health outcomes in children and adolescents?
5. What are the harms of treatment (psychotherapy, pharmacotherapy, or collaborative care) in children and adolescents who are treated for depression, anxiety, or suicide risk?

In addition to addressing the KQs, this review also looked for evidence related to six contextual questions (CQs):

1. What is the diagnostic yield from screening for depression, anxiety, or suicide risk in typical primary care practice settings?
2. What are the minimal clinically important differences (the smallest value of benefit to patients) for symptoms and functioning on the most common instruments used to measure response to treatment of depression, anxiety, or suicide risk?
3. What are the U.S. FDA boxed warnings for pharmacotherapy for the treatment of depression, anxiety, or suicide risk in children and adolescents?
4. What psychotherapies other than CBT are used to treat anxiety in children and adolescents?
5. What is the effectiveness of evidence-based treatment in children and adolescents with persistent depressive disorder (PDD) and depressive disorders not otherwise specified (DDNOS)?
6. What proportion of children and adolescents who screen positive for depression, anxiety, or increased suicide risk engage with care (i.e., return for clinical evaluation and treatment)?

These CQs were not a part of this systematic review. They are intended to provide additional background information. Appendix A presents a summary of the literature addressing these questions.

## Data Sources and Searches

This review includes three conditions and builds on prior reviews for the USPSTF for suicide risk^119^ and depression,^152^ and AHRQ Effective Healthcare Program (EHC) reviews on anxiety^123^ and depression.^153^ As a result date limits vary by topic and database. PubMed and the Cochrane Library were searched on April 28, 2020. PsycINFO and CINAHL were searched on April 30, 2020. Depression searches were limited to articles published from January 1, 2015 to April 28, 2020; anxiety searches were limited to articles published from January 1, 2017 to April 28, 2020; and suicide risk searches were limited to articles published between June 1, 2012 to April 28, 2020. We conducted a bridge search on July 19, 2021, and surveillance through June 1, 2022. Search terms and Medical Subject Headings (MeSH) focused on terms that describe relevant populations, tests, interventions, outcomes, and study designs was used when applicable. The search relied primarily on the previous systematic reviews for the USPSTF (depression,^152^ suicide^119^) and the AHRQ EHC (anxiety^123^) to identify potentially relevant studies published before the last search data in each of the three reviews. Complete search terms and limits are listed in Appendix B. ClinicalTrials.gov was searched for unpublished literature. To supplement electronic searches, reference lists of relevant articles, systematic reviews, and studies meeting the inclusion criteria were reviewed.

## Study Selection

We developed inclusion and exclusion criteria for populations, interventions, comparators, outcomes, timing, settings, and study designs with input from the USPSTF (Appendix C). We included English-language studies of children and adolescents age 18 years or younger on average conducted in countries categorized as “very high” on the 2019 Human Development Index.^154^

When possible, we aligned inclusion and exclusion criteria across the three conditions (suicide risk, anxiety, depression), with the exception of three criteria. First, population inclusion criteria were broader for depression treatment studies (KQs 4 and 5) than for anxiety or suicide risk. For depression, although the population criterion focuses on MDD (as defined by the DSM), we included treatment studies that had as few as 51 percent of participants with MDD to include studies with participants with PDD or DDNOS. This approach ensures consistency with the prior USPSTF review on screening for depression in children.^152^ Furthermore, we addressed the effectiveness of treatment for PDD and DDNOS in a CQ. For other conditions, we required that treatment studies limit participants to those with anxiety disorder or with increased suicide risk. As noted earlier, anxiety disorders can vary widely, and their onset may vary by age. Given this heterogeneity, eligible anxiety disorders included GAD, social anxiety disorder, panic disorder, agoraphobia, separation anxiety disorder, and selective mutism. Definitions for increased risk of suicide varied by study but could include suicidal ideation (suicidal thoughts or plan for suicide), history of suicide attempts (nonfatal, self-directed, and potentially injurious behavior that is intended to result in death), and deliberate self-harm.

Second, for depression and suicide risk interventions, we were more inclusive of a wide range of psychotherapy, counseling, and care delivery models (such as collaborative care and care management) than for anxiety. For anxiety, we limited nonpharmacological interventions to CBT in the interest of efficiency.

Third, we were more inclusive of a wide range of comparators for suicide risk interventions. We included treatment-as-usual comparators because ethical concerns limit the ability to conduct comparative studies using placebo or wait-list controls. For depression and anxiety interventions, we restricted comparators to placebo, wait-list, no intervention, attention control, and usual care. We did not include treatment-as-usual studies in specialist settings for these conditions because the comparison may understate the benefits of screening in primary care where the comparison is likely to be usual care in primary care settings.

Fourth, we accounted for the condition in assessing the accuracy of screening. For anxiety and depression, we required eligible studies to compare the accuracy of screeners with structured clinical interviews using standard diagnostic criteria. For suicide risk, however, we required the screener to be compared with an assessment of increased suicide risk based on an interview by a qualified professional.

For all conditions, a priori priority subpopulations of interest included younger age (children vs. adolescents), race/ethnicity, sex, gender identity, and sexuality. We limited pharmacotherapy to pharmacotherapy agents approved for pediatric use (e.g., clonidine, duloxetine, fluoxetine, escitalopram, sertraline, fluvoxamine). Interventions were required to be relevant to or referable from primary care; school-wide and community screening and interventions were excluded as a result. Eligible health outcomes across all conditions for KQ 1 and KQ 4 (screening and treatment benefits) included depression or anxiety symptoms as measured through validated instruments, clinical response, or remission; suicide deaths, suicide attempts and deliberate self-harm or suicidal ideation; all-cause mortality; quality of life measured using validated scales or instruments; and functioning (using validated scales or instruments, days of missed school, sleep-related outcomes). Eligible harms included treatment avoidance, deterioration in patient-provider relationship, labeling or stigma, inappropriate/unnecessary treatment, serious adverse effects, withdrawals due to adverse effects, and suicidality. Eligible settings across all KQs included primary care clinics, including school-based health clinics, and virtual or community-based settings. For screening questions (KQs 1 through 3), we also included studies recruiting from general emergency departments and schools. For treatment questions (KQs 4 and 5), we also included specialty clinics. We excluded studies of school-wide screening for KQ 1. We included RCTs for KQs 1, 3, 4, and 5 and diagnostic accuracy studies for KQ 2. Additionally, we included nonrandomized, controlled trials for KQ 1 and KQ 3. We included observational studies for the harms questions (KQ 3 and KQ 5). For KQ 5, we included systematic reviews of comparative cohort and case-control observational studies to capture rare harms but restricted pharmacotherapy harms studies to large (>1,000 participants) comparative cohort and case-control observational studies published after eligible systematic reviews.

Titles and abstracts were independently reviewed by two investigators; those marked for potential inclusion by either reviewer were retrieved for evaluation of the full text. The full texts were then independently reviewed by two investigators to determine final inclusion or exclusion. Disagreements were resolved by discussion and consensus.

## Quality Assessment and Data Abstraction

For newly identified studies, two senior reviewers independently assessed each study’s methodological quality using predefined criteria developed by the USPSTF (Appendix D) conducted using instruments devised for each of the included study designs, specifically Cochrane ROB 2.0 for randomized studies of interventions^155^ (KQs 1, 3, 4, and 5), the ROBINS-I tool^156^ for nonrandomized studies of interventions^123^ (KQ 5), ROBIS for systematic reviews (KQ 5),^157^ and the QUADAS-2 instrument^158^ for diagnostic accuracy (KQ 2). We re-rated all previously included accuracy studies (KQ 2). We spot-checked and carried forward quality ratings of studies included in two recent AHRQ EHC reports on depression^153^ and anxiety^123^ in children and adolescents.^153^ Studies reporting benefits and harms may have been assigned different quality ratings for benefits and harms. Disagreements were resolved by discussion. Only studies rated as having good or fair quality were included in the synthesis. For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. All data extractions were checked by a second investigator for completeness and accuracy.

## Data Synthesis and Analysis

Findings for each KQ were summarized qualitatively and in tabular format. The overall strength of the evidence for each KQ was assessed as high, moderate, low, or insufficient based on the overall quality of the studies, consistency of results between studies, precision of findings, risk of reporting bias, and limitations of the body of evidence, using methods developed for the USPSTF and the EPC program.^159^ Additionally, the applicability of the findings to U.S. primary care populations and settings was assessed. Discrepancies were resolved through consensus discussion.

Additionally, when at least three independent and similar studies were available, pooled effects for relative risks for categorical outcomes and standardized and weighted mean differences for continuous outcomes random-effects models were generated using the inverse-variance weighted method of DerSimonian and Laird. Absolute risk differences were presented for outcomes with signals of benefit or harm. The clinical and methodological heterogeneity of the studies was assessed according to established guidance,^160^ and similarities and differences in populations, tests, treatments, comparators, outcomes, and study designs were assessed qualitatively. Statistical heterogeneity of findings was assessed with the I^2^ statistic; 0 percent to 40 percent might not be important; 30 percent to 60 percent may represent moderate heterogeneity; 50 percent to 90 percent may represent substantial heterogeneity; and 75 percent to 100 percent represents considerable heterogeneity.^161^ All quantitative analyses were conducted using Comprehensive Meta-Analysis (Version 3.3) software.^162^ We considered pooled findings statistically significant when the 95% confidence intervals (CIs) excluded the null value. We assessed the potential for publication bias through visual inspection of a funnel plot when at least 10 studies were included in an analysis.

## U.S. Preventive Services Task Force Involvement

The authors worked with USPSTF liaisons throughout the review process to develop and refine the analytic framework, key questions, and scope of the work. AHRQ staff provided project oversight, reviewed the report, and assisted in conducting an external review of the draft evidence synthesis.

## Expert Review and Public Comment

The draft Research Plan was posted on the USPSTF website for public comment from April 30, 2020, to May 27, 2020. Regarding suggested edits to the KQs, one commenter noted that screening is intended to identify those at increased risk for any of the eligible conditions (anxiety, depression, suicide risk, or a combination), not just those at increased risk of suicide. In response, the USPSTF edited the key questions to remove the qualifier “increased risk of suicide” and instead refers to “suicide risk.” One comment suggested a focus on implementation barriers rather than the effectiveness of screening. Although we agree that these factors are important, the review is intended to support a screening recommendation. Commenters suggested edits to the CQs to improve clarity. In response, we revised CQ 2 to clarify that the term “minimal clinically important differences” refers to the smallest value of benefit to patients. We revised CQ 3 and CQ 4 to specify that the population of interest is children and adolescents. We qualified CQ 5 as being limited to evidence-based treatments and clarified that engagement with care in CQ 6 refers to returning for clinical evaluation and treatment.

Regarding suggested edits to the inclusion and exclusion criteria, one commenter suggested focusing on screen-detected populations in reviewing the treatment literature. Although we agree that for treatment questions, screen-detected populations are ideal, the evidence is likely to be extremely sparse. As a result, we are not restricting treatment studies to screen-detected populations alone. One commenter suggested excluding clomipramine because it is not a first-line therapy; in response, we excluded clomipramine. Some reviewers asked about the exclusion of active comparators for treatment questions. The USPSTF considers comparative effectiveness to be outside of its scope. Commenters suggested several outcomes; in response, we have clarified that we will include validated outcomes for prespecified outcomes for KQ 1 and KQ 4 and have added false alarm and false reassurance to outcomes for KQ 3. Some comments focused on priority populations; the review will report on priority populations defined by age, sex, race/ethnicity, gender identity, and sexuality. Some comments highlighted the importance of context, applicability, type of intervention, and type of disorder. We considered these factors in the analysis, when data were available. A final research plan was posted on the USPSTF’s website on August 13, 2020.

The draft evidence review was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers and was revised based on comments received. Specifically, we added followup data from an included study and revised the abstraction of an existing study. We also revised data on prevalence and burden in the introduction section. The draft evidence review will also be posted for public comment. Revisions will be made based on comments received, and any references suggested by expert or public reviewers will be evaluated for inclusion/exclusion.