# Chapter 1 Introduction

## Scope and Purpose

The United States Preventive Services Task Force (USPSTF) will use this report to issue updated recommendations for screening for suicide risk and depression in children and adolescents and to consider a new recommendation for screening for anxiety in this population. In 2014, the USPSTF concluded there was insufficient evidence to assess the balance of benefits and harms of screening for suicide risk in adolescents, adults, and older adults in primary care (I statement). In 2016, the USPSTF issued a recommendation for screening for major depressive disorder (MDD) in adolescents ages 12 to 18 years, noting that screening should be implemented with adequate systems in place to ensure accurate diagnosis, effective treatment, and appropriate followup (B recommendation).^1^ The USPSTF also concluded that the current evidence was insufficient to assess the balance of benefits and harms of screening for MDD in children ages 11 years or younger (I statement). The current review focuses on evidence for screening for suicide risk, anxiety, and depression in children and adolescents because screening instruments, implementation of screening, and outcomes for these conditions have overlap. Mental health conditions in children and adolescents may present as physical symptoms and may occur concurrently, presenting primary care physicians with opportunities to screen for one or more conditions. The review includes studies of benefits and harms of screening, accuracy of screening, and benefits and harms of treatment.

## Condition Definition

### Suicide

Suicide is defined as a death caused by self-inflicted injurious behavior with the intent to result in death because of the behavior.^2,^ ^3^ Suicidal attempts and ideation occur more frequently than deaths from suicide. Suicide attempts refer to nonfatal, self-directed, and potentially injurious behavior that is intended to result in death. Suicidal ideation refers to thinking about, considering, or planning suicide.^4^ Self harm may occur with or without suicidal intent. Nonsuicidal self-injury (self-harm without the intent to cause one’s own death) may predict^5,^ ^6^ or co-occur^7–10^ with suicidal ideation and behavior. Definitions of self-harm or self-directed violence can vary widely,^2^ and nonsuicidal self-injury may not always be distinguished from self-harm with suicidal intent. A common measure, deliberate self-harm, does not always specify intent^11^ and can also predict suicide attempts.^12^ The scope of this review includes suicide, suicide attempts, suicidal ideation, and deliberate self-harm.

### Anxiety

Although anxiety as a response to stress is normal, anxiety disorders are characterized by greater duration or intensity of impairment. The Diagnostic and Statistical Manual-5 (DSM-5)^13^ recognizes seven different types of anxiety disorders in children and adolescents: generalized anxiety disorder (GAD), social anxiety disorder, panic disorder, agoraphobia, specific phobias, separation anxiety disorder, and selective mutism. Categories that were included under anxiety disorders in previous editions of the DSM but are no longer included as part of DSM-5 anxiety disorders are obsessive-compulsive disorder (OCD), acute stress disorder, and posttraumatic stress disorder. The scope of this review includes studies focusing on one or more anxiety disorders, defined by the DSM criteria at the time of the study, as long as the study did not focus on OCD, acute stress disorder, or posttraumatic stress disorder.

### Depression

Depression is a mood disorder marked by symptoms related to how a person feels, thinks, and goes about their daily activities. According to DSM-5, MDD in children and adolescents is characterized by mild to severe persistent feelings (at least 2 weeks) of sadness or a lack of interest or pleasure in everyday pursuits, irritability, poor concentration, and somatic complaints such as difficulty sleeping, decreased energy, and changes in appetite. The scope of this review includes studies in which the majority of participants had MDD.

## Etiology, Natural History, and Risk Factors

Substantial comorbidity exists between anxiety, depression, and suicide. However, differences in the pattern of overlap indicate that adolescents with depression are more likely to exhibit comorbid anxiety than the converse.^14^ Moreover, evidence (from the Great Smokey Mountains Study) indicated that children who were depressed with comorbid anxiety, specifically GAD, had a higher risk of suicide than children with pure anxiety disorders.^15^ Yet, across all three conditions, adverse childhood experiences influenced the likelihood of suicide, anxiety, or depression. These experiences may arise from a complex and interacting set of familial, peer, or societal factors and may vary by race and ethnicity. Additionally, individual factors, including age, sex, gender identity and sexual orientation, and genetic predisposition, also may serve as risk factors across all the conditions. These mental health conditions have long-term effects that may include chronic mental and physical health conditions, functional impairment, increased risk for substance abuse, and premature mortality.^16–19^

### Suicide

Although young children rarely attempt or die by suicide, they do reveal some preoccupation with death or suicide, either in talk or in play, and these themes are considered to signal major depression in preschool children^20,^ ^21^ and are a significant predictor of future suicidal ideation and other psychiatric disorders.^22^ More commonly, suicidal behaviors first emerge during later childhood and adolescence.^22,^ ^23^ Studies of Canadian^24^ and U.S. adolescents^23^ showed that the prevalence of attempts among ideators was 25.5 percent in the Canadian cohort and 33.9 percent in the U.S. cohort; the gender difference in prevalence was only significant in the U.S. sample. Notably the prevalence of attempts was 3 times as great in those with a plan (60.8%) as in those without a plan (20.4%). A third cohort study found that 20.6 percent of youth who both reported suicidal ideation and reported nonsuicidal self-harm went on to attempt suicide compared with 1.4 percent of youth who did not report either ideation or nonsuicidal self-harm.^25^

The most substantial risk factors for youth suicide are adverse childhood experiences and mental health disorders, including family history of suicide or mental health disorders, previous suicide attempts, life stressors such as interpersonal losses, legal or disciplinary problems, history of trauma, and parent-child conflict.^26–29^ Suicide risk varies by gender or sex and type of behavior (note that some studies may use sex and gender terms interchangeably; the following discussion uses the language in the original publications). Males had a higher rate of suicide (17.9 per 100,000) than females (5.4 per 100,000) in 2017.^30^ However, the risk of suicide attempts was greater in females than males.^31^ Lesbian, gay, bisexual, transgender, and queer (LGBTQ) adolescents exhibit elevated rates of suicide ideation and attempts compared with heterosexual adolescents.^11,^ ^32,^ ^33^ One study of adolescents who identified as LGBTQ found that they were victimized more often by other youth, and peer victimization was associated with suicidal ideation and attempts, suggesting one reason for the higher suicidality rate in this population.^34^

Major depression as a risk for suicide may have a different role in childhood versus adolescence. In one large epidemiologic sample,^35^ suicide attempts in children younger than age 13 years were more strongly related to child maltreatment compared with adolescents for whom suicide attempts were more strongly related to depression. In adolescents, continuity of depression has been found to place youth at greater risk for suicidal ideation, nonsuicidal self-harm, and suicide attempts.^36^ Other factors associated with suicidal ideation and attempts include physical and sexual abuse; bullying; social isolation and loneliness; impulsivity; very high or very low engagement in health behaviors, low concentrations of serotonin metabolism; and variations in genes related to serotonin synthesis, transport, signaling, and catabolism.^11,^ ^24,^ ^37–44^

### Anxiety

Data from the Oregon Adolescent Depression Project reported that the incidence of the first episode of anxiety was higher in childhood (ages 5 to 12.9 years) than in adolescence (ages 13 to 17.9 years), and an anxiety disorder emerging in childhood or adolescence increased the likelihood of future anxiety disorder.^45^ Several reviews of anxiety disorders in children and adolescents reported longitudinal associations of anxiety disorders over time both with the same disorder and other anxiety or depressive disorders, suggesting the heightened risk for secondary depression.^46–48^ The earliest emerging anxiety disorder in childhood is separation anxiety disorder.^49^ Other anxiety disorders with emergence in preschool and early school years include selective mutism and GAD, whereas social anxiety and specific phobias generally develop during the later school years.^50^

Important risks and correlates of anxiety disorders include genetic, personality, and environmental factors. Studies have reported genetic contributions to the development of anxiety.^51–53^ Behavioral inhibition is a risk factor for developing anxiety disorders, particularly social anxiety,^47,^ ^51,^ ^54,^ ^55^ as is harm avoidance.^51,^ ^56^ Attachment difficulties are also associated with social anxiety.^56–58^

Although many factors can contribute to the development of anxiety disorders in children, some studies and reviews have reported links between the development of anxiety disorders and parenting characteristics such as overprotection^49,^ ^51,^ ^52,^ ^59,^ ^60^ and interparental conflict.^52,^ ^60^ As with other psychopathological disorders, adverse environmental conditions such as early parental separation, child maltreatment, and traumatic parental death, as well as poverty and low socioeconomic status (SES), were cited as contributing to the development of anxiety disorders.^46,^ ^53,^ ^59^ Lastly, a higher prevalence of anxiety has been found in youth with low SES compared with youth with higher SES.^53^

### Depression

Although there is evidence that depression can emerge as early as 3 years of age,^61–63^ the first diagnosis of depression is more common in adolescence or adulthood than childhood.^64–66^ However, studies also showed substantial continuity of depression from preschool to school age, with the likelihood of school-age depression almost 3 times as great in children with preschool-onset depression. Studies have also found that adolescents with a diagnosis of depression are more likely to have depression at a later time,^67,^ ^68^ up to 4 times as likely in one study as those with no psychiatric disorder.^67^

Several studies have found substantial comorbidity between depression and other psychiatric disorders. Preschool-age children with depression were also 3.5 times as likely to develop school-age anxiety disorder and 3.7 times as likely to develop school-age attention-deficit/hyperactivity disorder than children without preschool depression.^63^ Children and adolescents with depression had a greater likelihood of having a concurrent anxiety disorder,^65,^ ^69^ about 4 times greater in one cohort.^65^ Other concurrent psychiatric disorders found in children and adolescents with depression include oppositional defiant disorder^67^ and substance use disorder.^65^ Gender-specific comorbidities found in one study^67^ included substance use disorder (males) and conduct disorder (females). Adolescents with past depression were more than twice as likely to have anxiety at a later time point.^67^

Risk factors for depression include individual factors (genetics, biology, affect, cognition, behavior) that interact with social contextual factors at the proximal level (peers, family, school) and distal level (neighborhood, culture, government).^70,^ ^71^ Individual risk factors for depression in youth include genetic predisposition, female gender, and increasing age.^57,^ ^72^ Other risk factors include bullying, either as perpetrators or as victims, adverse life events, early exposure to stress, maltreatment, and an insecure parental relationship.^73–75^ Risk factors are also believed to interact to increase the odds of depression;^66,^ ^74,^ ^76–78^ additionally, maltreatment can reduce the effectiveness of evidence-based interventions.^75^

## Prevalence and Burden

### Suicide

#### Suicide Deaths

Suicide is the second leading cause of death among youth ages 10 to 19 years.^79^ Using the Centers for Disease Control and Prevention’s (CDC’s) Web-based Injury Statistics Query and Reporting System (WISQARS) data from 2019,^80^ a total of 2,744 youth ages 10 to 19 years died by suicide, of which 534 were younger youth (ages 10 to 14 years of age) and 2,2210 were older adolescents (ages 15 to 19 years). This translates to a suicide rate for children and younger adolescents, ages 10 to 14 years, of 2.6 per 100,000. The comparable rate for males and females ages 10 to 14 years was 3.1 per 100,000 and 2.0 per 100,000, respectively. Older adolescents, ages 15 to 19 years, died by suicide at a rate of 10.5 per 100,000, and the rate for males was more than 3 times that of females: 15.8 per 100,000 for males and 5.0 per 100,000 for females. In youths ages 10 to 14 years, White children and younger adolescents have a similar rate of dying by suicide compared with Black children and adolescents of the same age: 1.3 versus 1.4 per 100,000 for White and Black children, respectively; however, the suicide rate among White adolescents is nearly double the rate for Black adolescents: 8.4 per 100,000 and 4.2 per 100.000, respectively. More concerning is the upward trend in suicide rates for Black youth; from 2003 to 2017, the data show that the largest change was in the 15- to 17-year-old group (4.9%) and among females (6.6%).^81^ Overall, American Indian children and adolescents die by suicide at the highest rates: 2.5 per 100,000 and 16.1 per 100,000, in the younger and older age groups, respectively^80^ In 2015, 16 percent of the suicides in youth ages 15 to 17 years were lesbian, gay, bisexual, transgender, and queer or questioning (LGBTQ), and 24 percent of the suicides in children ages 12 through 14 years were LGBTQ children.^82^

#### Suicide Attempts

In 2019, results from the Youth Risk Behaviors Surveillance (YRBS) survey^3^ indicated that 8.9 percent of students (grades 9 to 12) had attempted suicide in the prior 12 months. Prevalence of suicide attempts was highest among female (11.0%), Black (11.8%), and LGBTQ students (23.4%).^83^ The most recent data on suicide behavior in LGBTQ youth is from the 2020 National Survey on LGBTQ Youth Mental Health conducted by the Trevor Project.^84^ This survey found that 20 percent of transgender and binary youth ages 13 to 24 years reported suicide attempts in 2020, and 21 percent of Black LGBTQ youth attempted suicide. In the Profiles of Study Life: Attitudes and Behaviors Survey of Adolescents 11 to 19 years conducted between 2012 and 2015, male transgender adolescents experienced the highest rate of attempted suicide of 50.8 percent, whereas male adolescents irrespective of sexual identity had the lowest prevalence rate, 9.8 percent.^85^

#### Suicidal Ideation

Data from the 2019 YRBS^3,^ ^86^ indicate that 18.8 percent of youth in 9^th^ through 12^th^ grade seriously contemplated attempting suicide, and 15.7 percent made a suicide plan. Students attempting suicide or making plans were more likely to be female, White, or LGBTQ. Data from the 2020 National Survey on LGBTQ Youth Mental Health indicate that 42 percent of LGBTQ youth ages 13 to 24 years seriously contemplated suicide.^84^ In addition, 52 percent of transgender and binary youth seriously considered suicide, whereas the percentage of cisgendered LGBTQ youth who considered suicide is 32 percent. Forty-seven percent of Black LGBTQ youth seriously considered suicide as compared with 39 percent of White LGBTQ youth.

Importantly, two recent studies^87,^ ^88^ found discordant reports of parent and youth reporting of suicidality. Specifically, both studies found that parents were often unaware of their child’s suicidal ideation and/or attempts, and the Jones study^88^ found that youth often denied having suicidal thoughts even though their parents reported suicidality. This discordance in reports between parents and children suggests that children at risk for suicide may go undetected.

### Anxiety

Estimates from the 2020 National Survey of Children’s Health (NSCH) were that 7.8 percent of children ages 3 to 17 years had a current anxiety disorder; 0.7 percent reported severe anxiety.^89^ Reports using the older 2016 NSCH provided comparisons by demographic factors, indicating no statistically significant differences in prevalence rates between males and females.^90^ Anxiety problems were most common among non-Hispanic White children compared with children of other racial/ethnic backgrounds and in older (ages 12 to 17 years) as compared with younger children (ages 3 to 5 years and ages 6 to 11 years). Data from the National Survey on LGBTQ Youth Mental Health indicated that 72 percent of LGBTQ youth reported symptoms of GAD, and 77 percent of transgender and nonbinary youth reported GAD symptoms.^84^

### Depression

The NSCH provides parent-reported diagnosed depression for children ages 3 through 17 years.^89^ In 2020, 3.4 percent of U.S, children were estimated to currently have depression, and 0.3 percent were considered to be severe. Comparisons between groups based on demographic categories that are available from the 2016 NSCH indicated that depression was significantly more common among adolescents ages 13 to 17 years as compared with younger groups and in non-Hispanic Whites as compared with Hispanic and non-Hispanic Black youth.^90^ Other U.S. depression estimates relying on adolescent self-report come from the National Survey on Drug Use and Health (NSDUH).^91^ The NSDUH, an annual survey of children ages 12 to 17 years, reported the prevalence of a major depressive episode (MDE) in the past year and MDE with major impairment. An MDE is defined as follows: in the past 12 months as one or more periods of at least 2 weeks when the youth felt depressed or lost interest or pleasure in daily activities for most of the day, nearly every day as well as problems with sleeping, eating, energy, concentration, self-worth, or having recurrent thoughts of death or recurrent suicidal ideation. An MDE with severe impairment is defined a depression caused severe problems with the youth’s ability to do chores at home, do well at work or school, get along with their family, or have a social life. In the 2019 NSDUH, past-year prevalence of an MDE was estimated as 15.7 percent (or 3.8 million adolescents) and MDE with severe impairment was 11.1 percent (or 2.2 million adolescents). The prevalence of depression in primary care settings may be up to twice as high as in community samples of children and adolescents.^61,^ ^63–65^

## Mental Health Disorders and Racial Disparities

As noted previously, the rate of suicide deaths is highest among American Indian youth^80^ (but may vary by tribe and geographic setting)^92^ and lowest among Black youth when compared with White youth. Previous studies suggested Black youth may have had lower rates of mental health disorders when compared with White youth, but more recent cohorts of Black adolescents or children have reported having a higher prevalence of suicide rates,^80,^ ^93^ increase in suicide attempts^58,^ ^94,^ ^95^ and anxiety disorders^90,^ ^96^ and greater increases in the prevalence of depression than in the past.^96^ Multiple factors, including socioeconomic status, childhood adversity, family structure, and neighborhood effects, may influence patterns of prevalence by race or ethnicity. The effects of racial disparities and structural racism intersect with these factors.^97^ Researchers noted the familial and societal impact of mass incarceration among Black males (rates of imprisonment among Black males increased by 3 times between 1969 and 1999), higher rates of increase in child poverty for Black children, higher rates of unemployment for Black adults, and a decline in the percentage of Black parents with college degrees.^96^ An increase in nonmarital births resulting in increasing prevalence of single-parent households may also play a role in the increase in the prevalence of depression.^96^ For U.S. adults, access to financial (income), physical (home ownership), and social assets (marital status and education) may explain part of the differences in prevalence between non-Hispanic Black and Hispanic persons when compared with White persons.^98^ Whether the relationship for family income holds for children and adolescents requires further research: one study suggested that higher household income may be associated with a higher risk of MDD among African American males, possibly because of the more frequent exposure to racial discrimination and reduced availability of social support from the African American community.^99,^ ^100^ In addition to these larger societal risk factors, other risk factors may include lack of access to health insurance, providers, medication (resulting in lower rates of treatment for non-White populations);^101^ underdiagnosis (e.g., because of implicit clinician bias);^102^ overdiagnosis (e.g., of conduct disorders instead of mood disorders);^103^ and misdiagnosis (because of lack of equivalence in assessment measures).^101,^ ^104^

A culturally informed Adverse Childhood Experiences (ACEs) model posits that racial discrimination is an adverse childhood experience that influences mental and behavioral health in youth. These experiences may be blatant or subtle (e.g., microaggressions), repeated or distinct, time limited or prolonged, but they are all potentially traumatic events that, in the context of historic trauma, structural racism, and biopsychological vulnerability, can worsen mental health outcomes.^105^ When coupled with well-documented lower engagement with mental health services,^106–109^ these higher rates point to a high level of unmet need in Black youth.^110^

Similar patterns of historic trauma, ACEs, and substance abuse may explain higher rates of mental health disorders in American Indian/Alaska Native youth;^92,^ ^111,^ ^112^ specific risk factors and their variation by tribe or geography are less well studied.

## Rationale for Screening and Screening Strategies

Screening for suicide risk, anxiety, and depression is intended to identify these conditions in children and adolescents not already identified as having the condition and then engage them effectively in confirmatory diagnostic evaluations, referrals, followup, or treatments as needed. Research has suggested that about half of adolescents with depression are not diagnosed until adulthood.^113^ Screening may be particularly effective for these mental health conditions given the stigma associated with seeking care for such conditions. Although depression is common, only 2 to 3 percent of adolescents present with a primary psychiatric complaint; many present as physical problems.^114–116^ A longitudinal study of deaths by suicide between 2000 and 2010 across health maintenance organizations in 11 States found that although only 16.3 percent of persons younger than age 20 years who died by suicide had a mental health visit in the 4 weeks before death, 37.9 percent used any healthcare services. In the 52 weeks before death, these rates were even higher for any use of healthcare services at 77.4 percent; 31.8 percent had a mental health visit.^117^ These patterns suggest a role for screening in primary care. However, to realize the benefits of screening, effective treatment must be available that the family and child or adolescent are willing to engage in. Evidence suggests that mental health specialty care completion rates are low for youth referred from general medical settings.^118^ This loss to followup between identification and treatment completion may pose a particular challenge for persons who are screen detected, where the net benefit of treatment may be lower than in persons who present with clinically overt symptoms.

### Screening Strategies

The nature of the target conditions (suicide risk, anxiety, depression) requires patient- or caregiver-reported screening instruments. Although many instruments have been developed to assist with diagnostic evaluation for mental health conditions or broad-based socioemotional behavior and function, not all are feasible for screening in primary care settings because of length. Many instruments that are used for screening for depression and anxiety were initially developed for epidemiologic studies for surveillance or to evaluate response to treatment. Most depression instruments evaluate for common symptoms related to depression and also include one or more items related to suicidal ideation. Anxiety instruments are more heterogenous, some are designed to evaluate for a specific anxiety disorder (e.g., social anxiety disorder), while others are designed to evaluate across the breadth of existing anxiety disorders. Assessments designed to evaluate youth suicide risk typically involve one component related to evaluating current ideation and self-harm behaviors, but also involve an assessment for past attempts and behaviors given the strong correlation between past behaviors and future risk. Instruments designed to screen across conditions may be more efficient than instruments targeting single conditions; however, trans-condition instruments are longer and require more time to administer, reducing feasibility in primary care settings and may be less accurate for any specific condition.

## Treatment Approaches

### Suicide

Therapeutic interventions targeting at-risk youth include psychotherapy and pharmacotherapy.^119,^ ^120^ These therapies seek to reduce suicidal ideation, behaviors, and attempts. Psychotherapeutic approaches may include short-term psychoeducation or longer-term interpersonal psychotherapy, cognitive behavioral therapy (CBT), dialectical behavioral therapy (DBT), mentalization therapy, and trauma-informed therapy. Pharmacotherapy may include antidepressants, antipsychotics, and mood stabilizers. In addition to these treatments, safety planning interventions, which generally include caregivers, may also be designed to reduce the access to or lethality of means of suicide. These therapies may be combined with interventions to address social determinants of health. For example, individually focused interventions that primary care providers can participate in or provide referrals to may seek to educate families of those in crisis about safely storing medications and firearms, distributing gun safety locks, and removing other items that could be used for an attempt.^121,^ ^122^

### Anxiety

Treatments for anxiety disorders includes psychotherapy, pharmacotherapy, and combinations.^123^ CBT is among the most commonly used approach, but other approaches include parent-child interaction therapy, problem-solving therapy, DBT, exposure therapies, hypnosis, social skills training, mindfulness therapy, psychodynamic psychotherapy, family therapy, attention modification program, motivational interviewing, trauma-informed therapy, and eye movement desensitization reprocessing therapy.^124–127^ Duloxetine, a serotonin–norepinephrine reuptake inhibitor (SNRI), is the only Food and Drug Administration (FDA)-approved medication for GAD in children age 7 or older. Pharmacological interventions prescribed on an off-label basis include selective serotonin reuptake inhibitors (SSRIs); other SNRIs; benzodiazepines; tricyclic antidepressants; and other drugs such as mebicarum, buspirone, mirtazapine, and nefazodone.

### Depression

Treatments for MDD includes psychotherapy, pharmacotherapy, and combinations.^128–130^ Different types of psychotherapy are used in treating children and adolescents with depression, but CBT and interpersonal therapy (IPT) have the most evidence supporting their effectiveness.^131–133^ Other types of therapy used clinically for treating depression include supportive psychotherapy, family therapy, psychodynamic therapy, behavioral therapy, DBT, and trauma-informed therapy.^134^ Although several antidepressants are approved for treating MDD in adult populations, fluoxetine is the only medication that the FDA has approved for use in treating MDD in children age 8 years or older. In addition, the FDA has approved escitalopram to treat MDD in adolescents ages 12 to 17 years. Other medications may sometimes be prescribed to children on an off-label basis including sertraline (approved in persons 6 years or older for obsessive-compulsive disorder [OCD]), fluvoxamine (approved in persons 8 years or older for OCD), and clomipramine (approved in persons 10 years or older for OCD).^135^ In 2003, the FDA recommended that paroxetine not be used for treating MDD in children and adolescents because of reports of possible suicidal ideation and suicide attempts in children and adolescents taking paroxetine for depression. In 2004, the FDA issued a public warning about an increased risk of suicidality in children and adolescents treated with all antidepressants. The FDA currently requires these medications to carry a boxed warning about the potential danger of suicidality.

## Clinical Practice in the United States

Evidence is limited on the implementation of routine screening in the United States. One survey of 727 primary care physicians in the United States in 2003 and 2004 found that 76 percent believe in the importance of talking to adolescent patients about their mental health, but only 46 percent said that they always asked their patients about their mental health.^136^ Analysis of data from the 2005 to 2010 National Ambulatory Medical Care and National Hospital Ambulatory Medical Care Survey found that depression screening occurred in as few as 0.2 percent of visits, with variations by race/ethnicity and region. The study reported lower odds of screening among Hispanic patients than White non-Hispanic patients and lower odds in the West compared with the Northeast.^137^ More recent insurance claims data (2010 to 2014) for 12- to 14-year-old adolescents with private insurance also indicated low rates of coding for depression screening at 1.8 percent.^138^ Evidence on the rates of screening for other disorders were also limited and, when available, indicated low rates of screening ranging from 10 percent or less among pediatric emergency medicine physicians^139^ to 23 percent in the primary care setting.^140^

## Recommendations of Other Organizations

### Suicide

Guidelines for screening for suicide are described in Table 1. The American Academy of Family Physicians follows the USPSTF recommendation.^141^ The American Academy of Pediatrics (AAP) recommends universal screening for suicide youth 12 years of age and older and screening when clinically indicated for youth 8 to 12 years of age.^142^ For younger children (younger than age 8), the guidelines recommend assessing for suicidal thought and behaviors if warning signs exist. The American Academy of Child and Adolescent Psychiatry (AACAP) policy statement supports screening for suicide risk across physical and mental health settings.^143^ The Joint Commission recommends that organizations screen all individuals for suicidal ideation using a validated screening tool.^144^

Table 1 Non-USPSTF Guidelines and Recommendations on Screening for Anxiety, Depression, and Suicide Risk for Children and Adolescents

Organization | Recommendation
| Suicide Risk
The American Academy of Child and Adolescent Psychiatry, 2019^143^ | Recommends screening for suicide risk across physical and mental healthcare settings and the urgent identification of and clinical intervention for children and youth at risk for suicide.
American Academy of Pediatrics, Bright Futures, 2022^142^ | Recommends universal screening for youth 12 years or older and screening when clinically indicated for youth 8 to 11 years. For youth under age 8, screening is not indicated but pediatricians should assess for suicidal thought and behaviors if warning signs of suicide risk or parent report of suicidal behaviors are present.
American Academy of Family Physicians, 2017^141^ | Supports the USPSTF recommendation.
The Joint Commission National Patient Safety Goal for Suicide Prevention, 2019^144^ | Organizations should screen all individuals served for suicidal ideation using a validated screening tool and monitor implementation and effectiveness of policies and procedures for screening individuals at risk for suicide and take actions to improve compliance as needed.
| Anxiety
American Academy of Child and Adolescent Psychiatry (AACAP), 2020^145^ | Notes the lack of empirical recommendations on screening for anxiety disorders in children or adolescents and points to freely available screening instruments.
National Institute for Health and Clinical Excellence (NICE), 2017^146^ | Recommends asking children or young people about their feelings of anxiety, fear, avoidance, or distress and conducting comprehensive assessments of those reporting those feelings.
| Depression
Guidelines for Adolescent Depression in Primary Care (GLAD-PC), 2018^147^ | Recommends annual universal depression screening of youth 12 years or older with a formal screening tool, identification of patients at high risk for depression, coordination of depression care, and establishment of a safety plan.
National Institute for Health and Clinical Excellence (NICE), 2019^303^ | Notes that healthcare professionals in primary care settings should be familiar with screening for mood disorders. Healthcare professionals in primary care, schools, and other relevant community settings should be trained to detect symptoms of depression and assess children and young people who may be at risk of depression. Training should include the evaluation of recent and past psychosocial risk factors.
American Academy of Family Physicians, 2017^141^ | Supports the USPSTF recommendation.
| Multicondition
American Academy of Pediatrics (AAP), Bright Futures, 2015^150^ | Recommends screening annually for emotional and behavioral problems for adolescent patients ages 12 years or older.
American College of Obstetricians and Gynecologists, 2017 (reaffirmed in 2020)^151^ | During preventive care visits, all adolescents should be screened for any mental health disorder in a confidential setting (if allowed by the laws of that locality).

Abbreviations: AACAP=American Academy of Child and Adolescent Psychiatry; AAP=American Academy of Pediatrics; AMA=American Medical Association; GLAD-PC=Guidelines for Adolescent Depression in Primary Care; NICE=National Institute for Health and Clinical Excellence; USPSTF=U.S. Preventive Services Task Force.

### Anxiety

AACAP notes the lack of empirically based guidelines on screening but offers resources for screening.^145^ The National Institute for Health and Clinical Excellence (NICE) recommends screening.^146^

### Depression

U.S.-based guideline groups (Guidelines for Adolescent Depression in Primary Care [GLAD-PC, supported by AAP, AACAP, and the American Psychiatric Association]^147^) recommend routine screening for depression. The Canadian Task Force is updating its guidelines,^148^ which earlier rated the evidence as insufficient.^149^

### Multiple Psychiatric Conditions

AAP-Bright Futures^150^ and the American College of Obstetricians and Gynecologists^151^ are consistent in recommending screening for emotional and behavioral issues, with followup diagnostic and treatment services (Table 1).