# Appendix References

1 Data Resource Center for Child & Adolescent Health. Child and Adolescent Health Measurement Initiative. 2018-2019 National Survey of Children’s Health (NSCH) data query. Washington, DC: Data Resource Center for Child and Adolescent Health supported by the U.S. Department of Health and Human Services, Health Resources and Services Administration (HRSA), Maternal and Child Health Bureau (MCHB); n.d. https://www.childhealthdata.org/browse/survey/results?q=7753&r=1. Accessed May 3, 2021.
2 Aalsma MC, Zerr AM, Etter DJ, . Physician intervention to positive depression screens among adolescents in primary care. J Adolesc Health. 2018 Feb;62(2):212–8. doi: 10.1016/j.jadohealth.2017.08.023. PMID: 29174939.29174939
3 Chowdhury T, Champion JD. Outcomes of depression screening for adolescents accessing pediatric primary care-based services. J Pediatr Nurs. 2020 Mar 2;52:25–9. doi: 10.1016/j.pedn.2020.02.036. PMID: 32135479.32135479
4 Farley AM, Gallop RJ, Brooks ES, . Identification and management of adolescent depression in a large pediatric care network. J Dev Behav Pediatr. 2020 Feb/Mar;41(2):85–94. doi: 10.1097/dbp.0000000000000750. PMID: 31651619.31651619
5 Leslie KR, Chike-Harris K. Patient-administered screening tool may improve detection and diagnosis of depression among adolescents. Clin Pediatr (Phila). 2018 Apr;57(4):457–60. doi: 10.1177/0009922817730343. PMID: 28950718.28950718
6 Lewandowski RE, O’Connor B, Bertagnolli A, . Screening for and diagnosis of depression among adolescents in a large health Maintenance organization. Psychiatr Serv. 2016 Jun 1;67(6):636–41. doi: 10.1176/appi.ps.201400465. PMID: 26876655.26876655
7 Rinke ML, German M, Azera B, . Effect of Mental Health Screening and Integrated Mental Health on Adolescent Depression-Coded Visits. Clin Pediatr (Phila). 2019 Apr;58(4):437–45. doi: 10.1177/0009922818821889. PMID: 30623684.30623684
8 Sekhar DL, Ba DM, Liu G, . Major Depressive Disorder Screening Remains Low Even Among Privately Insured Adolescents. J Pediatr. 2019 Jan;204:203–7. doi: 10.1016/j.jpeds.2018.07.086. PMID: 30244990.30244990
9 Sudhanthar S, Thakur K, Sigal Y, . Improving validated depression screen among adolescent population in primary care practice using electronic health records (EHR). BMJ Qual Improv Rep. 2015;4(1)doi: 10.1136/bmjquality.u209517.w3913. PMID: 26734415.26734415
10 Bose J, Zeno R, Warren B, . Implementation of universal adolescent depression screening: quality improvement outcomes. J Pediatr Health Care. 2021 Feb 10doi: 10.1016/j.pedhc.2020.08.004. PMID: 33581996.33581996
11 Chavira DA, Stein MB, Bailey K, . Child anxiety in primary care: prevalent but untreated. Depress Anxiety. 2004;20(4):155–64. doi: 10.1002/da.20039. PMID: 15643639.15643639
12 Etter DJ, McCord A, Ouyang F, . Suicide screening in primary care: use of an electronic screener to assess suicidality and improve provider follow-up for adolescents. J Adolesc Health. 2018 Feb;62(2):191–7. doi: 10.1016/j.jadohealth.2017.08.026. PMID: 29195764.29195764
13 Johnson JG, Harris ES, Spitzer RL, . The patient health questionnaire for adolescents: validation of an instrument for the assessment of mental disorders among adolescent primary care patients. J Adolesc Health. 2002;30(3):196–204. doi: 10.1016/S1054-139X(01)00333-0. PMID: 2002-02042-008.11869927
14 O’Connor S, Ferguson E, Carney T, . The development and evaluation of the Paediatric Index of Emotional Distress (PI-ED). Soc Psychiatry Psychiatr Epidemiol. 2016 Jan;51(1):15–26. doi: 10.1007/s00127-015-1134-y. PMID: 26687238.26687238
15 Christensen KS, Haugen W, Sirpal MK, . Diagnosis of depressed young people—criterion validity of WHO-5 and HSCL-6 in Denmark and Norway. Fam Pract. 2015;32(3):359–63. doi: 10.1093/fampra/cmv011. PMID: 2015-24236-019.25800246
16 Roberts RE, Lewinsohn PM, Seeley JR. Screening for adolescent depression: a comparison of depression scales. J Am Acad Child Adolesc Psychiatry. 1991 Jan;30(1):58–66. doi: 10.1097/00004583-199101000-00009. PMID: 2005065.2005065
17 Canals J, Blade J, Carbajo G, . The Beck Depression Inventory: psychometric characteristics and usefulness in nonclinical adolescents. Eur J Psychol Assess. 2001;17(1):63–8.
18 Garrison CZ, Addy CL, Jackson KL, . The CES-D as a screen for depression and other psychiatric disorders in adolescents. J Am Acad Child Adolesc Psychiatry. 1991 Jul;30(4):636–41. doi: 10.1097/00004583-199107000-00017. PMID: 1890099.1890099
19 Patton GC, Coffey C, Posterino M, . A computerised screening instrument for adolescent depression: population-based validation and application to a two-phase case-control study. Soc Psychiatry Psychiatr Epidemiol. 1999 Mar;34(3):166–72. PMID: 10327843.10327843
20 Stafford AM, Garbuz T, Etter DJ, . The natural course of adolescent depression treatment in the primary care setting. J Pediatr Health Care. 2020 Jan–Feb;34(1):38–46. doi: 10.1016/j.pedhc.2019.07.002. PMID: 31548140.31548140
21 Bailey KA, Chavira DA, Stein MT, . Brief measures to screen for social phobia in primary care pediatrics. J Pediatr Psychol. 2006 Jun;31(5):512–21. doi: 10.1093/jpepsy/jsj044. PMID: 16034004.16034004
22 Chambers D, Simpson L, Hill-Briggs F, . Proceedings of the 8th Annual Conference on the Science of Dissemination and Implementation : Washington, DC, USA. 14-15 December 2015. Implement Sci. 2016 Aug 1;11 Suppl 2(Suppl 2):100. doi: 10.1186/s13012-016-0452-0. PMID: 27490260.27490260
23 Queen AH, Ehrenreich-May J, Hershorin ER. Preliminary validation of a screening tool for adolescent panic disorder in pediatric primary care clinics. Child Psychiatry Hum Dev. 2012 Apr;43(2):171–83. doi: 10.1007/s10578-011-0256-z. PMID: 21938484.21938484
24 Thompson EA, Eggert LL. Using the suicide risk screen to identify suicidal adolescents among potential high school dropouts. J Am Acad Child Adolesc Psychiatry. 1999 Dec;38(12):1506–14. doi: 10.1097/00004583-199912000-00011. PMID: 10596250.10596250
25 Wang Z, Whiteside S, Sim L, . AHRQ comparative effectiveness reviews. Anxiety in Children. Rockville (MD): Agency for Healthcare Research and Quality (US); 2017.
26 Viswanathan M, Kennedy SM, McKeeman J, . Treatment of depression in children and adolescents: a systematic review. AHRQ Comparative Effectiveness Review Number 224. AHRQ Publication No. 20-EHC005-EF. Rockville, MD: Agency for Healthcare Research and Quality; April 2020. PMID: 3229806132298061.
27 Ebrahim S, Vercammen K, Sivanand A, . Minimally important differences in patient or proxy-reported outcome studies relevant to children: a systematic review. Pediatrics. 2017 Mar;139(3):e20160833. doi: 10.1542/peds.2016-0833. PMID: 28196931.28196931
28 Jayadevappa R, Cook R, Chhatre S. Minimal important difference to infer changes in health-related quality of life-a systematic review. J Clin Epidemiol. 2017 Sep;89:188–98. doi: 10.1016/j.jclinepi.2017.06.009. PMID: 28676426.28676426
29 Thissen D, Liu Y, Magnus B, . Estimating minimally important difference (MID) in PROMIS pediatric measures using the scale-judgment method. Qual Life Res. 2016 Jan;25(1):13–23. doi: 10.1007/s11136-015-1058-8. PMID: 26118768.26118768
30 U.S. Food and Drug Administration. Suicidality in children and adolescents being treated with antidepressant medications. Silver Spring, MD: Food and Drug Administration; 2018. https://www.fda.gov/drugs/postmarket-drug-safety-information-patients-and-providers/suicidality-children-and-adolescents-being-treated-antidepressant-medications. Accessed February 15, 2021.
31 Ollendick TH, White SW, Richey J, . Attention bias modification treatment for adolescents with social anxiety disorder. Behav Ther. 2019 Jan;50(1):126–39. doi: 10.1016/j.beth.2018.04.002. PMID: 30661553.30661553
32 Waters AM, Zimmer-Gembeck MJ, Craske MG, . Look for good and never give up: A novel attention training treatment for childhood anxiety disorders. Behav Res Ther. 2015 Oct;73:111–23. doi: 10.1016/j.brat.2015.08.005. PMID: 26310362.26310362
33 Fitzgerald A, Rawdon C, Dooley B. A randomized controlled trial of attention bias modification training for socially anxious adolescents. Behav Res Ther. 2016 Sep;84:1–8. doi: 10.1016/j.brat.2016.06.003. PMID: 27379745.27379745
34 Chang SW, Kuckertz JM, Bose D, . Efficacy of attention bias training for child anxiety disorders: a randomized controlled trial. Child Psychiatry Hum Dev. 2019 Apr;50(2):198–208. doi: 10.1007/s10578-018-0832-6. PMID: 30051155.30051155
35 Pettit JW, Bechor M, Rey Y, . A Randomized Controlled Trial of Attention Bias Modification Treatment in Youth With Treatment-Resistant Anxiety Disorders. J Am Acad Child Adolesc Psychiatry. 2020 Jan;59(1):157–65. doi: 10.1016/j.jaac.2019.02.018. PMID: 30877049.30877049
36 De Lijster JM, Dieleman GC, Utens E, . Online Attention Bias Modification in Combination with Cognitive-Behavioural Therapy for Children and Adolescents with Anxiety Disorders: a Randomised Controlled Trial. Behav Change. 2019doi: 10.1017/bec.2019.8. PMID: CN-01937771.
37 Bar-Haim Y, Morag I, Glickman S. Training anxious children to disengage attention from threat: A randomized controlled trial. J Child Psychol Psychiatry. 2011;52(8):861–9. doi: 10.1111/j.1469-7610.2011.02368.x. PMID: 2011-14641-007.21250993
38 Pergamin-Hight L, Pine DS, Fox NA, . Attention bias modification for youth with social anxiety disorder. J Child Psychol Psychiatry. 2016;57(11):1317–25. doi: 10.1111/jcpp.12599. PMID: 2016-53125-007.27435286
39 Waters AM, Zimmer-Gembeck MJ, Craske MG, . A preliminary evaluation of a home-based, computer-delivered attention training treatment for anxious children living in regional communities. Journal of Experimental Psychopathology. 2016;7(3):511–27. doi: 10.5127/jep.053315. PMID: 2016-58566-015.
40 MacLeod C, Mathews A, Tata P. Attentional bias in emotional disorders. J Abnorm Psychol. 1986 Feb;95(1):15–20. doi: 10.1037//0021-843x.95.1.15. PMID: 3700842.3700842
41 Hancock KM, Swain J, Hainsworth CJ, . Acceptance and commitment therapy versus cognitive behavior therapy for children with anxiety: outcomes of a randomized controlled trial. J Clin Child Adolesc Psychol. 2018 Mar–Apr;47(2):296–311. doi: 10.1080/15374416.2015.1110822. PMID: 26998803.26998803
42 Salzer S, Stefini A, Kronmüller KT, . Cognitive-behavioral and psychodynamic therapy in adolescents with social anxiety disorder: a multicenter randomized controlled trial. Psychother Psychosom. 2018;87(4):223–33. doi: 10.1159/000488990. PMID: 29895001.29895001
43 Dietz LJ, Weinberg RJ, Brent DA, . Family-based interpersonal psychotherapy for depressed preadolescents: examining efficacy and potential treatment mechanisms. J Am Acad Child Adolesc Psychiatry. 2015 Mar;54(3):191–9. doi: 10.1016/j.jaac.2014.12.011. PMID: 25721184.25721184
44 Rossello J, Bernal G. The efficacy of cognitive-behavioral and interpersonal treatments for depression in Puerto Rican adolescents. J Consult Clin Psychol. 1999 Oct;67(5):734–45. PMID: 10535240.10535240
45 Clarke GN, Rohde P, Lewinsohn PM, . Cognitive-behavioral treatment of adolescent depression: efficacy of acute group treatment and booster sessions. J Am Acad Child Adolesc Psychiatry. 1999 Mar;38(3):272–9. doi: 10.1097/00004583-199903000-00014. PMID: 10087688.10087688
46 Tompson MC, Sugar CA, Langer DA, . A randomized clinical trial comparing family-focused treatment and individual supportive therapy for depression in childhood and early adolescence. J Am Acad Child Adolesc Psychiatry. 2017 Jun;56(6):515–23. doi: 10.1016/j.jaac.2017.03.018. PMID: 28545757.28545757
47 Poole LA, Knight T, Toumbourou JW, . A randomized controlled trial of the impact of a family-based adolescent depression intervention on both youth and parent mental health outcomes. J Abnorm Child Psychol. 2018 Jan;46(1):169–81. doi: 10.1007/s10802-017-0292-7. PMID: 28374218.28374218
48 Poole LA, Lewis AJ, Toumbourou JW, . A multi-family group intervention for adolescent depression: The BEST MOOD program. Fam Process. 2017;56(2):317–30. doi: 10.1111/famp.12218. PMID: 2017-25520-002.27156970
49 Brent DA, Holder D, Kolko D, . A clinical psychotherapy trial for adolescent depression comparing cognitive, family, and supportive therapy. Arch Gen Psychiatry. 1997 Sep;54(9):877–85. PMID: 9294380.9294380
50 O’Connor BC, Lewandowski RE, Rodriguez S, . Usual care for adolescent depression from symptom identification through treatment initiation. JAMA Pediatr. 2016 Apr;170(4):373–80. doi: 10.1001/jamapediatrics.2015.4158. PMID: 26832387.26832387
51 Thompson H, Faig W, Gupta N, . Collaborative care for depression of adults and adolescents: measuring the effectiveness of screening and treatment uptake. Psychiatr Serv. 2019 Jul 1;70(7):604–7. doi: 10.1176/appi.ps.201800257. PMID: 31023189.31023189
52 Wright DR, Katon WJ, Ludman E, . Association of Adolescent Depressive Symptoms With Health Care Utilization and Payer-Incurred Expenditures. Acad Pediatr. 2016 Jan–Feb;16(1):82–9. doi: 10.1016/j.acap.2015.08.013. PMID: 26456002.26456002
53 Downey VA, Zun LS. Identifying Undiagnosed Pediatric Mental Illness in the Emergency Department. Pediatr Emerg Care. 2018 Feb;34(2):e21–e3. doi: 10.1097/pec.0000000000001151. PMID: 28441242.28441242
54 Patel A, Watts C, Shiddell S, . Universal adolescent suicide screening in a pediatric urgent care center. Arch Suicide Res. 2018 Jan–Mar;22(1):118–27. doi: 10.1080/13811118.2017.1304303. PMID: 28281893.28281893
55 US Food and Drug Administration. Anafranil® Clomipramine Hydrochloride capsules USP (25 mg, 50 mg, and 75 mg) Silver Spring, MD: US Food and Drug Administration; 2007.
56 US Food and Drug Administration. Highlights of prescribing information. Cymbalta (duloxetine hydrochloride) delayed-release capsules for oral use (reference ID: 2860327). Silver Spring, MD: US Food and Drug Administration; 2004. https://www.accessdata.fda.gov/drugsatfda_docs/label/2010/022516lbl.pdf Accessed April 20, 2021.
57 U.S. Food and Drug Administration. Highlights of prescribing information. Lexapro® (escitalopram oxalate) tablets. Silver Spring, MD: U.S. Food and Drug Administration; 2017. https://www.accessdata.fda.gov/drugsatfda_docs/label/2017/021323s047lbl.pdf. Accessed April 20, 2021.
58 U.S. Food and Drug Administration. Highlights of prescribing information. PROZAC (fluoxetine capsules) for oral use Silver Spring, MD: U.S. Food and Drug Administration; 2017. https://www.accessdata.fda.gov/drugsatfda_docs/label/2017/018936s108lbl.pdf. Accessed April 20, 2021.
59 US Food and Drug Administration. Highlights of prescribing information. Luvox® (fluvoxamine maleate) Tablets for oral administration Silver Spring, MD: US Food and Drug Administration; 2008. https://www.accessdata.fda.gov/drugsatfda_docs/label/2008/022235lbl.pdf. Accessed April 20, 2021.
60 US Food and Drug Administration. Highlights of prescribing information. ZOLOFT (sertraline hydrochloride) tablets, for oral use. Silver Spring, MD: US Food and Drug Administration; 2016. https://www.accessdata.fda.gov/drugsatfda_docs/label/2016/019839S74S86S87_20990S35S44S45lbl.pdf. Accessed April 20, 2021.
61 US Preventive Services Task Force. Procedure Manual. US Preventive Services Task Force; 2021. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual/procedure-manual-appendix-vi-criteria-assessing-internal-validity-individual-studies Accessed August 16, 2022.
62 Harris RP, Helfand M, Woolf SH, . Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001 Apr;20(3 Suppl):21–35. doi: 10.1016/s0749-3797(01)00261-6. PMID: 11306229.11306229
63 Mammarella IC, Donolato E, Caviola S, . Anxiety profiles and protective factors: a latent profile analysis in children. Pers Individ Dif. 2018;124:201–8. doi: 10.1016/j.paid.2017.12.017. PMID: 2018-01016-035.
64 O’Connor E, Senger CA, Henninger M, . US Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Interventions to Prevent Perinatal Depression: A Systematic Evidence Review for the US Preventive Services Task Force. Agency for Healthcare Research and Quality; 2019.
65 Arendt K, Thastum M, Hougaard E. Efficacy of a Danish version of the Cool Kids program: a randomized wait-list controlled trial. Acta Psychiatr Scand. 2016;133(2):109–21. doi: 10.1111/acps.12448. PMID: 2016-00713-002.26016532
66 Asarnow JR, Hughes JL, Babeva KN, . Cognitive-behavioral family treatment for suicide attempt prevention: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2017 Jun;56(6):506–14. doi: 10.1016/j.jaac.2017.03.015. PMID: 28545756.28545756
67 Asbrand J, Heinrichs N, Schmidtendorf S, . Experience versus report: where are changes seen after exposure-based cognitive-behavioral therapy? A randomized controlled group treatment of childhood social anxiety disorder. Child Psychiatry Hum Dev. 2020 Jan 20;51(3):427–41. doi: 10.1007/s10578-019-00954-w. PMID: 31960175.31960175
68 Atkinson SD, Prakash A, Zhang Q, . A double-blind efficacy and safety study of duloxetine flexible dosing in children and adolescents with major depressive disorder. J Child Adolesc Psychopharmacol. 2014 May;24(4):180–9. doi: 10.1089/cap.2013.0146. PMID: 24813026.24813026
69 Baer S, Garland EJ. Pilot study of community-based cognitive behavioral group therapy for adolescents with social phobia. J Am Acad Child Adolesc Psychiatry. 2005 Mar;44(3):258–64. doi: 10.1097/00004583-200503000-00010. PMID: 15725970.15725970
70 Barrett PM, Dadds MR, Rapee RM. Family treatment of childhood anxiety: a controlled trial. J Consult Clin Psychol. 1996 Apr;64(2):333–42. doi: 10.1037//0022-006x.64.2.333. PMID: 8871418.8871418
71 Barrett PM. Evaluation of cognitive-behavioral group treatments for childhood anxiety disorders. J Clin Child Psychol. 1998 Dec;27(4):459–68. doi: 10.1207/s15374424jccp2704_10. PMID: 9866083.9866083
72 Beidel DC, Turner SM, Sallee FR, . SET-C versus fluoxetine in the treatment of childhood social phobia. J Am Acad Child Adolesc Psychiatry. 2007;46(12):1622–32. doi: 10.1097/chi.0b013e318154bb57. PMID: 2007-18374-011.18030084
73 Birmaher B, Axelson DA, Monk K, . Fluoxetine for the treatment of childhood anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2003 Apr;42(4):415–23. doi: 10.1097/01.Chi.0000037049.04952.9f. PMID: 12649628.12649628
74 Black B, Uhde TW. Treatment of elective mutism with fluoxetine: a double-blind, placebo-controlled study. J Am Acad Child Adolesc Psychiatry. 1994 Sep;33(7):1000–6. doi: 10.1097/00004583-199409000-00010. PMID: 7961338.7961338
75 Clarke G, DeBar LL, Pearson JA, . Cognitive behavioral therapy in primary care for youth declining antidepressants: a randomized trial. Pediatrics. 2016 May;137(5):e20151851. doi: 10.1542/peds.2015-1851. PMID: 27244782.27244782
76 Clarke G, Debar L, Lynch F, . A randomized effectiveness trial of brief cognitive-behavioral therapy for depressed adolescents receiving antidepressant medication. J Am Acad Child Adolesc Psychiatry. 2005 Sep;44(9):888–98. PMID: 16113617.16113617
77 Cobham VE, Filus A, Sanders MR. Working with parents to treat anxiety-disordered children: a proof of concept RCT evaluating Fear-less Triple P. Behav Res Ther. 2017 Aug;95:128–38. doi: 10.1016/j.brat.2017.06.004. PMID: 28641122.28641122
78 Cobham VE. Do anxiety-disordered children need to come into the clinic for efficacious treatment? J Consult Clin Psychol. 2012;80(3):465–76. doi: 10.1037/a0028205. PMID: 2012-10793-001.22545740
79 Cornacchio D, Furr JM, Sanchez AL, . Intensive group behavioral treatment (IGBT) for children with selective mutism: a preliminary randomized clinical trial. J Consult Clin Psychol. 2019 Aug;87(8):720–33. doi: 10.1037/ccp0000422. PMID: 31294589.31294589
80 Cottrell DJ, Wright-Hughes A, Collinson M, . Effectiveness of systemic family therapy versus treatment as usual for young people after self-harm: a pragmatic, phase 3, multicentre, randomised controlled trial. Lancet Psychiatry. 2018 Mar;5(3):203–16. doi: 10.1016/s2215-0366(18)30058-0. PMID: 29449180.29449180
81 Diamond GS, Reis BF, Diamond GM, . Attachment-based family therapy for depressed adolescents: a treatment development study. J Am Acad Child Adolesc Psychiatry. 2002 Oct;41(10):1190–6. doi: 10.1097/00004583-200210000-00008. PMID: 12364840.12364840
82 Diamond GS, Wintersteen MB, Brown GK, . Attachment-based family therapy for adolescents with suicidal ideation: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2010 Feb;49(2):122–31. doi: 10.1097/00004583-201002000-00006. PMID: 20215934.20215934
83 Donovan CL, March S. Online CBT for preschool anxiety disorders: a randomised control trial. Behav Res Ther. 2014 Jul;58:24–35. doi: 10.1016/j.brat.2014.05.001. PMID: 24927471.24927471
84 Ehrenreich-May J, Rosenfield D, Queen AH, . An initial waitlist-controlled trial of the unified protocol for the treatment of emotional disorders in adolescents. J Anxiety Disord. 2017 Mar;46:46–55. doi: 10.1016/j.janxdis.2016.10.006. PMID: 27771133.27771133
85 Emslie GJ, Prakash A, Zhang Q, . A double-blind efficacy and safety study of duloxetine fixed doses in children and adolescents with major depressive disorder. J Child Adolesc Psychopharmacol. 2014 May;24(4):170–9. doi: 10.1089/cap.2013.0096. PMID: 24815533.24815533
86 Emslie GJ, Ventura D, Korotzer A, . Escitalopram in the treatment of adolescent depression: a randomized placebo-controlled multisite trial. J Am Acad Child Adolesc Psychiatry. 2009 Jul;48(7):721–9. doi: 10.1097/CHI.0b013e3181a2b304. PMID: 19465881.19465881
87 Emslie GJ, Heiligenstein JH, Wagner KD, . Fluoxetine for acute treatment of depression in children and adolescents: a placebo-controlled, randomized clinical trial. J Am Acad Child Adolesc Psychiatry. 2002 Oct;41(10):1205–15. doi: 10.1097/00004583-200210000-00010. PMID: 12364842.12364842
88 Emslie GJ, Rush AJ, Weinberg WA, . A double-blind, randomized, placebo-controlled trial of fluoxetine in children and adolescents with depression. Arch Gen Psychiatry. 1997 Nov;54(11):1031–7. PMID: 9366660.9366660
89 Flannery-Schroeder EC, Kendall PC. Group and individual cognitive-behavioral treatments for youth with anxiety disorders: A randomized clinical trial. Cognit Ther Res. 2000;24(3):251–78.
90 Fristad MA, Vesco AT, Young AS, . Pilot randomized controlled trial of omega-3 and individual-family psychoeducational psychotherapy for children and adolescents with depression. J Clin Child Adolesc Psychol. 2019;48(sup1):S105–s18. doi: 10.1080/15374416.2016.1233500. PMID: 27819485.27819485
91 Gallagher HM, Rabian BA, McCloskey MS. A brief group cognitive-behavioral intervention for social phobia in childhood. J Anxiety Disord. 2004;18(4):459–79. doi: 10.1016/S0887-6185(03)00027-6. PMID: 2004-14970-002.15149708
92 Ginsburg GS, Pella JE, Pikulski PJ, . School-Based Treatment for Anxiety Research Study (STARS): a randomized controlled effectiveness trial. J Abnorm Child Psychol. 2020 Mar;48(3):407–17. doi: 10.1007/s10802-019-00596-5. PMID: 31749064.31749064
93 Green JM, Wood AJ, Kerfoot MJ, . Group therapy for adolescents with repeated self harm: randomised controlled trial with economic evaluation. BMJ. 2011 Apr 1;342:d682. doi: 10.1136/bmj.d682. PMID: 21459975.21459975
94 Griffiths H, Duffy F, Duffy L, . Efficacy of mentalization-based group therapy for adolescents: the results of a pilot randomised controlled trial. BMC Psychiatry. 2019 Jun 6;19(1):167. doi: 10.1186/s12888-019-2158-8. PMID: 31170947.31170947
95 Hazell PL, Martin G, McGill K, . Group therapy for repeated deliberate self-harm in adolescents: failure of replication of a randomized trial. J Am Acad Child Adolesc Psychiatry. 2009 Jun;48(6):662–70. doi: 10.1097/CHI.0b013e3181aOacec. PMID: 19454922.19454922
96 Hetrick SE, Yuen HP, Bailey E, . Internet-based cognitive behavioural therapy for young people with suicide-related behaviour (Reframe-IT): a randomised controlled trial. Evid Based Ment Health. 2017 Aug;20(3):76–82. doi: 10.1136/eb-2017-102719. PMID: 28701336.28701336
97 Hill RM, Pettit JW. Pilot randomized controlled trial of LEAP: a selective preventive intervention to reduce adolescents’ perceived burdensomeness. J Clin Child Adolesc Psychol. 2019;48:S45–S56. doi: 10.1080/15374416.2016.1188705. PMID: CN-01916512.27532425
98 Hirshfeld-Becker DR, Masek B, Henin A, . Cognitive behavioral therapy for 4- to 7-year-old children with anxiety disorders: a randomized clinical trial. J Consult Clin Psychol. 2010 Aug;78(4):498–510. doi: 10.1037/a0019055. PMID: 20658807.20658807
99 Holmes MC, Donovan CL, Farrell LJ, . The efficacy of a group-based, disorder-specific treatment program for childhood GAD—a randomized controlled trial. Behav Res Ther. 2014 Oct;61:122–35. doi: 10.1016/j.brat.2014.08.002. PMID: 25193003.25193003
100 Hooven C, Walsh E, Pike KC, . Promoting CARE: including parents in youth suicide prevention. Fam Community Health. 2012 Jul–Sep;35(3):225–35. doi: 10.1097/FCH.0b013e318250bcf9. PMID: 22617413.22617413
101 Infantino A, Donovan CL, March S. A randomized controlled trial of an audio-based treatment program for child anxiety disorders. Behav Res Ther. 2016 Apr;79:35–45. doi: 10.1016/j.brat.2016.02.007. PMID: 26950257.26950257
102 Ingul JM, Aune T, Nordahl HM. A randomized controlled trial of individual cognitive therapy, group cognitive behaviour therapy and attentional placebo adolescent social phobia. Psychother Psychosom. 2014;83(1):54–61. doi: 10.1159/000354672. PMID: 2013-41405-007.24281563
103 Ishikawa SI, Kikuta K, Sakai M, . A randomized controlled trial of a bidirectional cultural adaptation of cognitive behavior therapy for children and adolescents with anxiety disorders. Behav Res Ther. 2019 Sep;120:103432. doi: 10.1016/j.brat.2019.103432. PMID: 31299461.31299461
104 Kendall PC, Flannery-Schroeder E, Panichelli-Mindel SM, . Therapy for youths with anxiety disorders: a second randomized clinical trial. J Consult Clin Psychol. 1997 Jun;65(3):366–80. doi: 10.1037//0022-006x.65.3.366. PMID: 9170760.9170760
105 Kendall PC. Treating anxiety disorders in children: results of a randomized clinical trial. J Consult Clin Psychol. 1994;62(1):100.8034812
106 Khanna MS, Kendall PC. Computer-assisted cognitive behavioral therapy for child anxiety: results of a randomized clinical trial. J Consult Clin Psychol. 2010;78(5):737–45. doi: 10.1037/a0019739. PMID: 2010-19874-014.20873909
107 King CA, Gipson PY, Horwitz AG, . Teen options for change: an intervention for young emergency patients who screen positive for suicide risk. Psychiatr Serv. 2015 Jan 1;66(1):97–100. doi: 10.1176/appi.ps.201300347. PMID: 25321886.25321886
108 King CA, Klaus N, Kramer A, . The Youth-Nominated Support Team-Version II for suicidal adolescents: a randomized controlled intervention trial. J Consult Clin Psychol. 2009 Oct;77(5):880–93. doi: 10.1037/a0016552. PMID: 19803568.19803568
109 Last CG, Hansen C, Franco N. Cognitive-behavioral treatment of school phobia. J Am Acad Child Adolesc Psychiatry. 1998 Apr;37(4):404–11. doi: 10.1097/00004583-199804000-00018. PMID: 9549961.9549961
110 Lau W-y, Chan CK-y, Li JC-h, . Effectiveness of group cognitive-behavioral treatment for childhood anxiety in community clinics. Behav Res Ther. 2010;48(11):1067–77. doi: 10.1016/j.brat.2010.07.007. PMID: 2010-16900-001.20696421
111 Luby JL, Barch DM, Whalen D, . A randomized controlled trial of parent-child psychotherapy targeting emotion development for early childhood depression. Am J Psychiatry. 2018 Nov 1;175(11):1102–10. doi: 10.1176/appi.ajp.2018.18030321. PMID: 29921144.29921144
112 Lyneham HJ, Rapee RM. Evaluation of therapist-supported parent-implemented CBT for anxiety disorders in rural children. Behav Res Ther. 2006;44(9):1287–300. doi: 10.1016/j.brat.2005.09.009. PMID: 2006-09968-007.16313883
113 March J, Silva S, Petrycki S, . Fluoxetine, cognitive-behavioral therapy, and their combination for adolescents with depression: Treatment for Adolescents With Depression Study (TADS) randomized controlled trial. JAMA. 2004 Aug 18;292(7):807–20. doi: 10.1001/jama.292.7.807. PMID: 15315995.15315995
114 March S, Spence SH, Donovan CL. The efficacy of an internet-based cognitive-behavioral therapy intervention for child anxiety disorders. J Pediatr Psychol. 2009 Jun;34(5):474–87. doi: 10.1093/jpepsy/jsn099. PMID: 18794187.18794187
115 Mehlum L, Tørmoen AJ, Ramberg M, . Dialectical behavior therapy for adolescents with repeated suicidal and self-harming behavior: a randomized trial. J Am Acad Child Adolesc Psychiatry. 2014 Oct;53(10):1082–91. doi: 10.1016/j.jaac.2014.07.003. PMID: 25245352.25245352
116 Melfsen S, Kühnemund M, Schwieger J, . Cognitive behavioral therapy of socially phobic children focusing on cognition: a randomised wait-list control study. Child Adolesc Psychiatry Ment Health. 2011 Feb 28;5(1):5. doi: 10.1186/1753-2000-5-5. PMID: 21356037.21356037
117 Mufson L, Weissman MM, Moreau D, . Efficacy of interpersonal psychotherapy for depressed adolescents. Arch Gen Psychiatry. 1999 Jun;56(6):573–9. PMID: 10359475.10359475
118 Mufson L, Dorta KP, Wickramaratne P, . A randomized effectiveness trial of interpersonal psychotherapy for depressed adolescents. Arch Gen Psychiatry. 2004 Jun;61(6):577–84. doi: 10.1001/archpsyc.61.6.577. PMID: 15184237.15184237
119 Nauta MH, Scholing A, Emmelkamp PM, . Cognitive-behavioral therapy for children with anxiety disorders in a clinical setting: no additional effect of a cognitive parent training. J Am Acad Child Adolesc Psychiatry. 2003 Nov;42(11):1270–8. doi: 10.1097/01.chi.0000085752.71002.93. PMID: 14566163.14566163
120 Öst L-G, Cederlund R, Reuterskiöld L. Behavioral treatment of social phobia in youth: does parent education training improve the outcome? Behav Res Ther. 2015;67:19–29. doi: 10.1016/j.brat.2015.02.001. PMID: 2015-12473-003.25727679
121 Ougrin D, Boege I, Stahl D, . Randomised controlled trial of therapeutic assessment versus usual assessment in adolescents with self-harm: 2-year follow-up. Arch Dis Child. 2013 Oct;98(10):772–6. doi: 10.1136/archdischild-2012-303200. PMID: 23709314.23709314
122 Perrin S, Bevan D, Payne S, . GAD-specific cognitive behavioral treatment for children and adolescents: a pilot randomized controlled trial. Cognit Ther Res. 2019;43:1051–64. doi: 10.1007/s10608-019-10020-3. PMID: CN-01941262.
123 Pincus DB, May JE, Whitton SW, . Cognitive-behavioral treatment of panic disorder in adolescence. J Clin Child Adolesc Psychol. 2010;39(5):638–49. doi: 10.1080/15374416.2010.501288. PMID: 2010-17041-004.20706917
124 Pine DS, Walkup JT, Labellarte MJ, . Fluvoxamine for the treatment of anxiety disorders in children and adolescents. N Engl J Med. 2001;344(17):1279–85. doi: 10.1056/NEJM200104263441703. PMID: CN-00343009.11323729
125 Pineda J, Dadds MR. Family intervention for adolescents with suicidal behavior: a randomized controlled trial and mediation analysis. J Am Acad Child Adolesc Psychiatry. 2013 Aug;52(8):851–62. doi: 10.1016/j.jaac.2013.05.015. PMID: 23880495.23880495
126 Rapee RM, Abbott MJ, Lyneham HJ. Bibliotherapy for children with anxiety disorders using written materials for parents: a randomized controlled trial. J Consult Clin Psychol. 2006 Jun;74(3):436–44. doi: 10.1037/0022-006x.74.3.436. PMID: 16822101.16822101
127 Richardson LP, Ludman E, McCauley E, . Collaborative care for adolescents with depression in primary care: a randomized clinical trial. JAMA. 2014 Aug 27;312(8):809–16. doi: 10.1001/jama.2014.9259. PMID: 25157724.25157724
128 Rossouw TI, Fonagy P. Mentalization-based treatment for self-harm in adolescents: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2012 Dec;51(12):1304–13.e3. doi: 10.1016/j.jaac.2012.09.018. PMID: 23200287.23200287
129 Rudy BM, Zavrou S, Johnco C, . Parent-led exposure therapy: a pilot study of a brief behavioral treatment for anxiety in young children. J Child Fam Stud. 2017;26(9):2475–84. doi: 10.1007/s10826-017-0772-y. PMID: 2017-22955-001.
130 Rynn MA, Siqueland L, Rickels K. Placebo-controlled trial of sertraline in the treatment of children with generalized anxiety disorder. Am J Psychiatry. 2001 Dec;158(12):2008–14. doi: 10.1176/appi.ajp.158.12.2008. PMID: 11729017.11729017
131 Sánchez-García R, Olivares Rodríguez J. Effectiveness of a program for early detection/intervention in children/adolescents with generalized social phobia. Anales de Psicología. 2009;25(2).
132 Santucci LC, Ehrenreich-May J. A randomized controlled trial of the child anxiety multi-day program (CAMP) for separation anxiety disorder. Child Psychiatry Hum Dev. 2013 Jun;44(3):439–51. doi: 10.1007/s10578-012-0338-6. PMID: 23053618.23053618
133 Schneider S, Blatter-Meunier J, Herren C, . Disorder-specific cognitive-behavioral therapy for separation anxiety disorder in young children: a randomized waiting-list-controlled trial. Psychother Psychosom. 2011;80(4):206–15. doi: 10.1159/000323444. PMID: 2011-23503-003.21494062
134 Shortt AL, Barrett PM, Fox TL. Evaluating the FRIENDS program: a cognitive-behavioral group treatment for anxious children and their parents. J Clin Child Psychol. 2001 Dec;30(4):525–35. doi: 10.1207/s15374424jccp3004_09. PMID: 11708240.11708240
135 Silverman WK, Kurtines WM, Ginsburg GS, . Treating anxiety disorders in children with group cognitive-behaviorial therapy: a randomized clinical trial. J Consult Clin Psychol. 1999 Dec;67(6):995–1003. doi: 10.1037//0022-006x.67.6.995. PMID: 10596522.10596522
136 Smith AM, Flannery-Schroeder EC, Gorman KS, . Parent cognitive-behavioral intervention for the treatment of childhood anxiety disorders: a pilot study. Behav Res Ther. 2014;61:156–61. doi: 10.1016/j.brat.2014.08.010. PMID: 2014-38494-001.25217169
137 Spence SH, Donovan CL, March S, . Generic versus disorder specific cognitive behavior therapy for social anxiety disorder in youth: a randomized controlled trial using internet delivery. Behav Res Ther. 2017 Mar;90:41–57. doi: 10.1016/j.brat.2016.12.003. PMID: 27988427.27988427
138 Spence SH, Holmes JM, March S, . The feasibility and outcome of clinic plus Internet delivery of cognitive-behavior therapy for childhood anxiety. J Consult Clin Psychol. 2006;74(3):614–21. doi: 10.1037/0022-006X.74.3.614. PMID: 2006-08433-020.16822117
139 Spence SH, Donovan C, Brechman-Toussaint M. The treatment of childhood social phobia: the effectiveness of a social skills training-based, cognitive-behavioural intervention, with and without parental involvement. J Child Psychol Psychiatry. 2000 Sep;41(6):713–26. PMID: 11039684.11039684
140 Spence SH, Donovan CL, March S, . A randomized controlled trial of online versus clinic-based CBT for adolescent anxiety. J Consult Clin Psychol. 2011 Oct;79(5):629–42. doi: 10.1037/a0024512. PMID: 21744945.21744945
141 Stjerneklar S, Hougaard E, McLellan LF, . A randomized controlled trial examining the efficacy of an internet-based cognitive behavioral therapy program for adolescents with anxiety disorders. PLoS One. 2019;14(9):e0222485. doi: 10.1371/journal.pone.0222485. PMID: 31532802.31532802
142 Strawn JR, Prakash A, Zhang Q, . A randomized, placebo-controlled study of duloxetine for the treatment of children and adolescents with generalized anxiety disorder. J Am Acad Child Adolesc Psychiatry. 2015 Apr;54(4):283–93. doi: 10.1016/j.jaac.2015.01.008. PMID: 25791145.25791145
143 Strawn JR, Mills JA, Schroeder H, . Escitalopram in adolescents with generalized anxiety disorder: a double-blind, randomized, placebo-controlled study. J Clin Psychiatry. 2020 Aug 25;81(5):20m13396. doi: 10.4088/JCP.20m13396. PMID: 32857933.32857933
144 Tang TC, Jou SH, Ko CH, . Randomized study of school-based intensive interpersonal psychotherapy for depressed adolescents with suicidal risk and parasuicide behaviors. Psychiatry Clin Neurosci. 2009 Aug;63(4):463–70. doi: 10.1111/j.1440-1819.2009.01991.x. PMID: 19531111.19531111
145 Thirlwall K, Cooper PJ, Karalus J, . Treatment of child anxiety disorders via guided parent-delivered cognitive-behavioural therapy: randomised controlled trial. Br J Psychiatry. 2013;203(6):436–44. doi: 10.1192/bjp.bp.113.126698. PMID: CN-00910881.23969483
146 Tillfors M, Andersson G, Ekselius L, . A randomized trial of internet-delivered treatment for social anxiety disorder in high school students. Cogn Behav Ther. 2011;40(2):147–57. doi: 10.1080/16506073.2011.555486. PMID: 2011-14818-007.25155815
147 Topooco N, Berg M, Johansson S, . Chat- and internet-based cognitive-behavioural therapy in treatment of adolescent depression: randomised controlled trial. BJPsych Open. 2018 Jul;4(4):199–207. doi: 10.1192/bjo.2018.18. PMID: 29988969.29988969
148 Topooco N, Byléhn S, Dahlström Nysäter E, . Evaluating the efficacy of internet-delivered cognitive behavioral therapy blended with synchronous chat sessions to treat adolescent depression: randomized controlled trial. J Med Internet Res. 2019 Nov 1;21(11):e13393. doi: 10.2196/13393. PMID: 31682572.31682572
149 Vigerland S, Ljótsson B, Thulin U, . Internet-delivered cognitive behavioural therapy for children with anxiety disorders: a randomised controlled trial. Behav Res Ther. 2016;76:47–56. doi: 10.1016/j.brat.2015.11.006. PMID: 2015-59077-007.26649465
150 Villabø MA, Narayanan M, Compton SN, . Cognitive–behavioral therapy for youth anxiety: an effectiveness evaluation in community practice. J Consult Clin Psychol. 2018;86(9):751–64. doi: 10.1037/ccp0000326. PMID: 2018-41322-004.30138014
151 Wagner KD, Jonas J, Findling RL, . A double-blind, randomized, placebo-controlled trial of escitalopram in the treatment of pediatric depression. J Am Acad Child Adolesc Psychiatry. 2006 Mar;45(3):280–8. doi: 10.1097/01.chi.0000192250.38400.9e. PMID: 16540812.16540812
152 Waite P, Marshall T, Creswell C. A randomized controlled trial of internet-delivered cognitive behaviour therapy for adolescent anxiety disorders in a routine clinical care setting with and without parent sessions. Child Adolesc Ment Health. 2019;24(3):242–50. doi: 10.1111/camh.12311. PMID: CN-01917999.32677216
153 Walkup JT, Albano AM, Piacentini J, . Cognitive behavioral therapy, sertraline, or a combination in childhood anxiety. N Engl J Med. 2008 Dec 25;359(26):2753–66. doi: 10.1056/NEJMoa0804633. PMID: 18974308.18974308
154 Warner CM, Colognori D, Kim RE, . Cognitive-behavioral treatment of persistent functional somatic complaints and pediatric anxiety: an initial controlled trial. Depress Anxiety. 2011 Jul;28(7):551–9. doi: 10.1002/da.20821. PMID: 21681863.21681863
155 Waters AM, Ford LA, Wharton TA, . Cognitive-behavioural therapy for young children with anxiety disorders: comparison of a child + parent condition versus a parent only condition. Behav Res Ther. 2009 Aug;47(8):654–62. doi: 10.1016/j.brat.2009.04.008. PMID: 19457471.19457471
156 Weersing VR, Brent DA, Rozenman MS, . Brief behavioral therapy for pediatric anxiety and depression in primary care: a randomized clinical trial. JAMA Psychiatry. 2017 Jun 1;74(6):571–8. doi: 10.1001/jamapsychiatry.2017.0429. PMID: 28423145.28423145
157 Weihs KL, Murphy W, Abbas R, . Desvenlafaxine versus placebo in a fluoxetine-referenced study of children and adolescents with major depressive disorder. J Child Adolesc Psychopharmacol. 2018 Feb;28(1):36–46. doi: 10.1089/cap.2017.0100. PMID: 29189044.29189044
158 Wergeland GJ, Fjermestad KW, Marin CE, . An effectiveness study of individual vs. group cognitive behavioral therapy for anxiety disorders in youth. Behav Res Ther. 2014 Jun;57:1–12. doi: 10.1016/j.brat.2014.03.007. PMID: 24727078.24727078
159 Wood A, Trainor G, Rothwell J, . Randomized trial of group therapy for repeated deliberate self-harm in adolescents. J Am Acad Child Adolesc Psychiatry. 2001 Nov;40(11):1246–53. doi: 10.1097/00004583-200111000-00003. PMID: 11699797.11699797
160 Wuthrich VM, Rapee RM, Cunningham MJ, . A randomized controlled trial of the Cool Teens CD-ROM computerized program for adolescent anxiety. J Am Acad Child Adolesc Psychiatry. 2012 Mar;51(3):261–70. doi: 10.1016/j.jaac.2011.12.002. PMID: 22365462.22365462
161 Cipriani A, Zhou X, Del Giovane C, . Comparative efficacy and tolerability of antidepressants for major depressive disorder in children and adolescents: a network meta-analysis. Lancet. 2016 Aug 27;388(10047):881–90. doi: 10.1016/s0140-6736(16)30385-3. PMID: 27289172.27289172
162 Canals J, Hernández-Martínez C, Cosi S, . Examination of a cutoff score for the Screen for Child Anxiety Related Emotional Disorders (SCARED) in a non-clinical Spanish population. J Anxiety Disord. 2012 Dec;26(8):785–91. doi: 10.1016/j.janxdis.2012.07.008. PMID: 23023158.23023158
163 Cunha M, Gouveia JP, do Céu Salvador M. Social fears in adolescence: the social anxiety and avoidance scale for adolescents. Eur Psychol. 2008;13(3):197–213. doi: 10.1027/1016-9040.13.3.197. PMID: 2008-13222-006.
164 Garcia-Lopez LJ, Sáez-Castillo AJ, Beidel D, . Brief measures to screen for social anxiety in adolescents. J Dev Behav Pediatr. 2015 Oct;36(8):562–8. doi: 10.1097/dbp.0000000000000213. PMID: 26349070.26349070
165 Gardner W, Lucas A, Kolko DJ, . Comparison of the PSC-17 and alternative mental health screens in an at-risk primary care sample. J Am Acad Child Adolesc Psychiatry. 2007 May;46(5):611–8. doi: 10.1097/chi.0b013e318032384b. PMID: 17450052.17450052
166 Hopper SM, Woo JW, Sharwood LN, . Prevalence of suicidality in asymptomatic adolescents in the paediatric emergency department and utility of a screening tool. Emerg Med Australas. 2012 Oct;24(5):540–6. doi: 10.1111/j.1742-6723.2012.01576.x. PMID: 23039296.23039296
167 Johnson HS, Inderbitzen-Nolan HM, Anderson ER. The social phobia inventory: validity and reliability in an adolescent community sample. Psychol Assess. 2006 Sep;18(3):269–77. doi: 10.1037/1040-3590.18.3.269. PMID: 16953730.16953730
168 Katon W, Russo J, Richardson L, . Anxiety and depression screening for youth in a primary care population. Ambul Pediatr. 2008 May–Jun;8(3):182–8. doi: 10.1016/j.ambp.2008.01.003. PMID: 18501865.18501865
169 Muris P, Merckelbach H, Kindt M, . The utility of Screen for Child Anxiety Related Emotional Disorders (SCARED) as a tool for identifying children at high risk for prevalent anxiety disorders. Anxiety Stress Coping. 2001;14(3):265–83. doi: 10.1080/10615800108248357. PMID: 2002-00834-002.
170 Ranta K, Kaltiala-Heino R, Rantanen P, . Screening social phobia in adolescents from general population: the validity of the Social Phobia Inventory (SPIN) against a clinical interview. Eur Psychiatry. 2007 May;22(4):244–51. doi: 10.1016/j.eurpsy.2006.12.002. PMID: 17346941.17346941
171 Ranta K, Kaltiala-Heino R, Rantanen P, . The Mini-Social Phobia Inventory: psychometric properties in an adolescent general population sample. Compr Psychiatry. 2012 Jul;53(5):630–7. doi: 10.1016/j.comppsych.2011.07.007. PMID: 21944882.21944882
172 Rivera-Riquelme M, Piqueras JA, Cuijpers P. The Revised Mental Health Inventory-5 (MHI-5) as an ultra-brief screening measure of bidimensional mental health in children and adolescents. Psychiatry Res. 2019 Apr;274:247–53. doi: 10.1016/j.psychres.2019.02.045. PMID: 30818147.30818147
173 Tsai CF, Wang SJ, Juang KD, . Use of the Chinese (Taiwan) version of the Social Phobia Inventory (SPIN) among early adolescents in rural areas: reliability and validity study. J Chin Med Assoc. 2009 Aug;72(8):422–9. doi: 10.1016/s1726-4901(09)70399-5. PMID: 19686998.19686998
174 Stein MB, Roy-Byrne PP, McQuaid JR, . Development of a brief diagnostic screen for panic disorder in primary care. Psychosom Med. 1999 May–Jun;61(3):359–64. doi: 10.1097/00006842-199905000-00016. PMID: 10367617.10367617
175 Beck AT, Ward CH, Mendelson M, . An inventory for measuring depression. Arch Gen Psychiatry. 1961 Jun;4:561–71. doi: 10.1001/archpsyc.1961.01710120031004. PMID: 13688369.13688369
176 Olsson G, von Knorring AL. Depression among Swedish adolescents measured by the self-rating scale Center for Epidemiology Studies-Depression Child (CES-DC). Eur Child Adolesc Psychiatry. 1997 Jun;6(2):81–7. PMID: 9257089.9257089
177 Fendrich M, Weissman MM, Warner V. Screening for depressive disorder in children and adolescents: validating the Center for Epidemiologic Studies Depression Scale for Children. Am J Epidemiol. 1990 Mar;131(3):538–51. PMID: 2301363.2301363
178 Radloff LS. The CES-D scale: a self report depression scale for research in the general population. App Psychol Measur. 1977;1:385–401.
179 Lewis G, Pelosi AJ. The manual of CIS-R. London: Institute of Psychiatry; 1992.
180 Olivares J, Garcia-Lopez LJ, Piqueras JA. Escala para la Detección de la Ansiedad Social (EDAS) [Social Anxiety Screening Scale, SASS]. In: Vera-Villaroel P, Oblitas L, eds. Manual de Escalas, & Cuestionarios Iberoamericanos en Psicología Clínica, & de la Salud [Handbook of Iberoamerican scales and tests in Health and Clinical Psychology]. Bogota, Colombia: Psicom Editores; 2005:350.
181 Haavet OR, Sirpal MK, Haugen W, . Diagnosis of depressed young people in primary health care--a validation of HSCL-10. Fam Pract. 2011 Apr;28(2):233–7. doi: 10.1093/fampra/cmq078. PMID: 20937663.20937663
182 Christensen KS, Fink P, Toft T, . A brief case-finding questionnaire for common mental disorders: the CMDQ. Fam Pract. 2005 Aug;22(4):448–57. doi: 10.1093/fampra/cmi025. PMID: 15814580.15814580
183 Masia-Warner C, Storch EA, Pincus DB, . The Liebowitz social anxiety scale for children and adolescents: an initial psychometric investigation. J Am Acad Child Adolesc Psychiatry. 2003 Sep;42(9):1076–84. doi: 10.1097/01.CHI.0000070249.24125.89. PMID: 12960707.12960707
184 Richardson LP, McCauley E, Grossman DC, . Evaluation of the Patient Health Questionnaire-9 Item for detecting major depression among adolescents. Pediatrics. 2010 Dec;126(6):1117–23. doi: 10.1542/peds.2010-0852. PMID: 21041282.21041282
185 Birmaher B, Brent DA, Chiappetta L, . Psychometric properties of the Screen for Child Anxiety Related Emotional Disorders (SCARED): a replication study. J Am Acad Child Adolesc Psychiatry. 1999 Oct;38(10):1230–6. doi: 10.1097/00004583-199910000-00011. PMID: 10517055.10517055
186 Monga S, Birmaher B, Chiappetta L, . Screen for Child Anxiety-Related Emotional Disorders (SCARED): convergent and divergent validity. Depress Anxiety. 2000;12(2):85–91. doi: 10.1002/1520-6394(2000)12:2<85::aid-da4>3.0.co;2-2. PMID: 11091931.11091931
187 Birmaher B, Khetarpal S, Brent D, . The Screen for Child Anxiety Related Emotional Disorders (SCARED): scale construction and psychometric characteristics. J Am Acad Child Adolesc Psychiatry. 1997 Apr;36(4):545–53. doi: 10.1097/00004583-199704000-00018. PMID: 9100430.9100430
188 La Greca AM, Stone WL. Social anxiety scale for children-revised: factor structure and concurrent validity. J Clin Child Psychol. 1993;22(1):17–27. doi: 10.1207/s15374424jccp2201_2
189 La Greca AM, Lopez N. Social anxiety among adolescents: linkages with peer relations and friendships. J Abnorm Child Psychol. 1998 Apr;26(2):83–94. doi: 10.1023/a:1022684520514. PMID: 9634131.9634131
190 Puklek Levpuscek M. Lestvica Socialne Anksioznosti Za Mladostnike (LSAA). Prirocnik. Social anxiety scale for adolescents (SASA). Manual. Ljubljana, Slovenia: Center za psihodiagnosticna sredstva Psychological Test Publishing, Assessment and Consultancy; 2008.
191 Moore KA, Gee DL. The reliability, validity, discriminant and predictive properties of the Social Phobia Inventory (SoPhI). Anxiety Stress Coping. 2003;16:109–17.
192 Garcia-Lopez LJ, Hidalgo MD, Beidel DC, . Brief form of the Social Phobia and Anxiety Inventory (SPAI-B) for adolescents. Eur J Psychol Assess. 2008;24(3):150–6. doi: 10.1027/1015-5759.24.3.150.
193 Connor KM, Davidson JR, Churchill LE, . Psychometric properties of the Social Phobia Inventory (SPIN). New self-rating scale. Br J Psychiatry. 2000 Apr;176:379–86. doi: 10.1192/bjp.176.4.379. PMID: 10827888.10827888
194 Connor KM, Kobak KA, Churchill LE, . Mini-SPIN: a brief screening assessment for generalized social anxiety disorder. Depress Anxiety. 2001;14(2):137–40. doi: 10.1002/da.1055. PMID: 11668666.11668666
195 Seeley-Wait E, Abbott MJ, Rapee RM. Psychometric properties of the mini-social phobia inventory. Prim Care Companion J Clin Psychiatry. 2009;11(5):231–6. doi: 10.4088/PCC.07m00576. PMID: 19956461.19956461
196 Spence SH. Social skills training: enhancing social competence with children and adolescents: Nfer-Nelson; 1995.
197 Topp CW, Østergaard SD, Søndergaard S, . The WHO-5 well-being index: a systematic review of the literature. Psychother Psychosom. 2015;84:167–76.25831962
198 World Health Organization (WHO). Wellbeing measures in primary health care/The Depcare Project. Copenhagen: WHO Regional Office for Europe; 1998.
199 Cottrell DJ, Wright-Hughes A, Collinson M, . A pragmatic randomised controlled trial and economic evaluation of family therapy versus treatment as usual for young people seen after second or subsequent episodes of self-harm: the Self-Harm Intervention - Family Therapy (SHIFT) trial. Health Technol Assess. 2018 Mar;22(12):1–222. doi: 10.3310/hta22120. PMID: 29532784.29532784
200 Cottrell DJ, Wright-Hughes A, Eisler I, . Longer-term effectiveness of systemic family therapy compared with treatment as usual for young people after self-harm: an extended follow up of pragmatic randomised controlled trial. EClinicalMedicine. 2020 Jan;18:100246. doi: 10.1016/j.eclinm.2019.100246. PMID: 31956857.31956857
201 Mehlum L, Ramberg M, Tørmoen AJ, . Dialectical behavior therapy compared with enhanced usual care for adolescents with repeated suicidal and self-harming behavior: outcomes over a one-year follow-up. J Am Acad Child Adolesc Psychiatry. 2016 Apr;55(4):295–300. doi: 10.1016/j.jaac.2016.01.005. PMID: 27015720.27015720
202 Mehlum L, Ramleth RK, Tørmoen AJ, . Long term effectiveness of dialectical behavior therapy versus enhanced usual care for adolescents with self-harming and suicidal behavior. J Child Psychol Psychiatry. 2019 Oct;60(10):1112–22. doi: 10.1111/jcpp.13077. PMID: 31127612.31127612
203 Haga E, Aas E, Grøholt B, . Cost-effectiveness of dialectical behaviour therapy vs. enhanced usual care in the treatment of adolescents with self-harm. Child Adolesc Psychiatry Ment Health. 2018;12:22. doi: 10.1186/s13034-018-0227-2. PMID: 29743941.29743941
204 Ougrin D, Zundel T, Ng A, . Trial of therapeutic assessment in London: randomised controlled trial of therapeutic assessment versus standard psychosocial assessment in adolescents presenting with self-harm. Arch Dis Child. 2011 Feb;96(2):148–53. doi: 10.1136/adc.2010.188755. PMID: 21030367.21030367
205 Albano AM, Comer JS, Compton SN, . Secondary outcomes from the child/adolescent anxiety multimodal study: implications for clinical practice. Evid Based Pract Child Adolesc Ment Health. 2018;3(1):30–41. doi: 10.1080/23794925.2017.1399485. PMID: 30906874.30906874
206 Taylor JH, Lebowitz ER, Jakubovski E, . Monotherapy insufficient in severe anxiety? Predictors and moderators in the child/adolescent anxiety multimodal study. J Clin Child Adolesc Psychol. 2018 Mar–Apr;47(2):266–81. doi: 10.1080/15374416.2017.1371028. PMID: 28956620.28956620
207 Compton SN, Peris TS, Almirall D, . Predictors and moderators of treatment response in childhood anxiety disorders: results from the CAMS trial. J Consult Clin Psychol. 2014 Apr;82(2):212–24. doi: 10.1037/a0035458. PMID: 24417601.24417601
208 Sanchez AL, Comer JS, Coxe S, . The effects of youth anxiety treatment on school impairment: differential outcomes across CBT, sertraline, and their combination. Child Psychiatry Hum Dev. 2019 Dec;50(6):940–9. doi: 10.1007/s10578-019-00896-3. PMID: 31087216.31087216
209 Rynn MA, Walkup JT, Compton SN, . Child/adolescent anxiety multimodal study: evaluating safety. J Am Acad Child Adolesc Psychiatry. 2015 Mar;54(3):180–90. doi: 10.1016/j.jaac.2014.12.015. PMID: 25721183.25721183
210 Gordon-Hollingsworth AT, Becker EM, Ginsburg GS, . Anxiety disorders in Caucasian and African American children: a comparison of clinical characteristics, treatment process variables, and treatment outcomes. Child Psychiatry Hum Dev. 2015;46(5):643–55. doi: 10.1007/s10578-014-0507-x. PMID: 2014-43106-001.25293650
211 Ginsburg GS, Kendall PC, Sakolsky D, . Remission after acute treatment in children and adolescents with anxiety disorders: findings from the CAMS. J Consult Clin Psychol. 2011 Dec;79(6):806–13. doi: 10.1037/a0025933. PMID: 22122292.22122292
212 Osimo EF, Stochl J, Zammit S, . Longitudinal population subgroups of CRP and risk of depression in the ALSPAC birth cohort. Compr Psychiatry. 2020;96:152143. doi: 10.1016/j.comppsych.2019.152143. PMID: 2020-00258-001.31707310
213 Walkup JT, Labellarte MJ, Riddle MA, . Searching for moderators and mediators of pharmacological treatment effects in children and adolescents with anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2003 Jan;42(1):13–21. doi: 10.1097/00004583-200301000-00006. PMID: 12500072.12500072
214 Ginsburg GS, Riddle MA, Davies M. Somatic symptoms in children and adolescents with anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2006 Oct;45(10):1179–87. doi: 10.1097/01.chi.0000231974.43966.6e. PMID: 17003663.17003663
215 Reinblatt SP, dosReis S, Walkup JT, . Activation adverse events induced by the selective serotonin reuptake inhibitor fluvoxamine in children and adolescents. J Child Adolesc Psychopharmacol. 2009;19(2):119–26. doi: 10.1089/cap.2008.040. PMID: 2009-05505-003.19364290
216 Caporino NE, Read KL, Shiffrin N, . Sleep-related problems and the effects of anxiety treatment in children and adolescents. J Clin Child Adolesc Psychol. 2017 Sep–Oct;46(5):675–85. doi: 10.1080/15374416.2015.1063429. PMID: 26467211.26467211
217 Curry J, Rohde P, Simons A, . Predictors and moderators of acute outcome in the Treatment for Adolescents with Depression Study (TADS). J Am Acad Child Adolesc Psychiatry. 2006 Dec;45(12):1427–39. doi: 10.1097/01.chi.0000240838.78984.e2. PMID: 17135988.17135988
218 Emslie G, Kratochvil C, Vitiello B, . Treatment for Adolescents with Depression Study (TADS): safety results. J Am Acad Child Adolesc Psychiatry. 2006 Dec;45(12):1440–55. doi: 10.1097/01.chi.0000240840.63737.1d. PMID: 17135989.17135989
219 Kennard B, Silva S, Vitiello B, . Remission and residual symptoms after short-term treatment in the Treatment of Adolescents with Depression Study (TADS). J Am Acad Child Adolesc Psychiatry. 2006 Dec;45(12):1404–11. doi: 10.1097/01.chi.0000242228.75516.21. PMID: 17135985.17135985
220 Vitiello B, Rohde P, Silva S, . Functioning and quality of life in the Treatment for Adolescents with Depression Study (TADS). J Am Acad Child Adolesc Psychiatry. 2006 Dec;45(12):1419–26. doi: 10.1097/01.chi.0000242229.52646.6e. PMID: 17135987.17135987
221 Sparse whole-genome sequencing identifies two loci for major depressive disorder. Nature. 2015 Jul 30;523(7562):588–91. doi: 10.1038/nature14659. PMID: 26176920.26176920
222 Reynolds WM. 5.17 - Depression. Comprehensive Clinical Psychology. 1998;5:419–61. doi: 10.1016/B0080-4270(73)00135-8.
223 Kuo ES, Stoep AV, Stewart DG. Using the short mood and feelings questionnaire to detect depression in detained adolescents. Assessment. 2005 Dec;12(4):374–83. doi: 10.1177/1073191105279984. PMID: 16244118.16244118
224 Wood A, Kroll L, Moore A, . Properties of the mood and feelings questionnaire in adolescent psychiatric outpatients: a research note. J Child Psychol Psychiatry. 1995 Feb;36(2):327–34. doi: 10.1111/j.1469-7610.1995.tb01828.x. PMID: 7759594.7759594
225 Birleson P. The validity of depressive disorder in childhood and the development of a self-rating scale: a research report. J Child Psychol Psychiatry. 1981 Jan;22(1):73–88. doi: 10.1111/j.1469-7610.1981.tb00533.x. PMID: 7451588.7451588
226 Hamilton A. A rating scale for depression. J Neurol Neurosurg Psychiatry. 1960;23:56–62.14399272
227 Findling RL, Robb A, Bose A. Escitalopram in the treatment of adolescent depression: a randomized, double-blind, placebo-controlled extension trial. J Child Adolesc Psychopharmacol. 2013 Sep;23(7):468–80. doi: 10.1089/cap.2012.0023. PMID: 24041408.24041408
228 McGlinchey EL, Reyes-Portillo JA, Turner JB, . Innovations in practice: The relationship betweensleep disturbances, depression, and interpersonal functioning in treatment for adolescent depression. Child Adolesc Ment Health. 2017 May;22(2):96–9. doi: 10.1111/camh.12176. PMID: 28947892.28947892
229 Brent DA, Porta G, Rozenman MS, . Brief behavioral therapy for pediatric anxiety and depression in primary care: a follow-up. J Am Acad Child Adolesc Psychiatry. 2019 Jul 3doi: 10.1016/j.jaac.2019.06.009. PMID: 31278996.31278996