# Appendix J List of Excluded Studies

List of Exclusion Codes:

- X1: Non-English
- X2: Ineligible population
- X3: Ineligible intervention
- X4: Ineligible comparator
- X5: Ineligible setting
- X6: Ineligible country
- X7: Ineligible study design
- X8: Ineligible publication type
- X9: Ineligible outcome
- X10: Duplicate
- X11: Relevant protocol or ongoing study
- X12: Superseded by full publication
- X13: Poor quality

1 Fluvoxamine for the treatment of anxiety disorders in children and adolescents. The Research Unit on Pediatric Psychopharmacology Anxiety Study Group. N Engl J Med. 2001 Apr 26;344(17):1279–85. doi: 10.1056/nejm200104263441703. PMID: 11323729. Exclusion Code: X10.11323729
2 Children with anxiety do best on combination therapy. Drug Benefit Trends. 2008;20(12):504-. PMID: 2008-19322-002. Exclusion Code: X8.
3 Corrections: (The Lancet Psychiatry (2017) 4 (2)(109-119) (S2215036616303789) (10.1016/S2215-0366(16)30378-9)). The lancet psychiatry. 2017;4(8):582. doi: 10.1016/S2215-0366%2817%2930283-3. PMID: CN-01475235. Exclusion Code: X4.
4 Re: “Desvenlafaxine versus placebo in a Fluoxetine-referenced study of children and adolescents with major depressive disorder: design, definitions, and ongoing challenges for child and adolescent psychopharmacology research” by Strawn JR and Croarkin PE (J Child Adolesc Psychopharmacol 2018;28: (5)363). J Child Adolesc Psychopharmacol. 2019;29(3):245–6. doi: 10.1089/cap.2018.0163. PMID: CN-02001995. Exclusion Code: X2.30874454
5 5.4 Tailoring treatment over time: a clinical trial using measurement-based care within an integrated care pathway. J Am Acad Child Adolesc Psychiatry. 2020;59(10):S274-. doi: 10.1016/j.jaac.2020.07.575. PMID: CN-02207475. Exclusion Code: X9.
6 Changes in firearm and medication storage practices in homes of youths at risk for suicide: results of the SAFETY Study, a clustered, emergency department–based, multisite, stepped-wedge trial. Ann Emerg Med. 2020doi: 10.1016/j.annemergmed.2020.02.007. PMID: CN-02147046. Exclusion Code: X2.
7 Aalsma MC, Zerr AM, Etter DJ, . Physician intervention to positive depression screens among adolescents in primary care. J Adolesc Health. 2018 Feb;62(2):212–8. doi: 10.1016/j.jadohealth.2017.08.023. PMID: 29174939. Exclusion Code: X7.29174939
8 Ab Ghaffar SF, Mohd Sidik S, Ibrahim N, . Effect of a school-based anxiety prevention program among primary school children. Int J Environ Res Public Health. 2019 Dec 5;16(24)doi: 10.3390/ijerph16244913. PMID: 31817328. Exclusion Code: X2.31817328
9 Abbasi Z, Amiri S, Talebi H. The effective comparison between modular cognitive behavioral therapy (MCBT) and child-parent relationship training (CPRT) in children with separation anxiety symptoms. Social Sciences (Pakistan). 2016;11(6):890–902. Exclusion Code: X6.
10 Abotsie G, Cestaro V, Gee B, . Interpersonal counselling for adolescent depression delivered by youth mental health workers without core professional training: a feasibility randomised controlled trial study protocol. Pilot Feasibility Stud. 2020 Dec 10;6(1):191. doi: 10.1186/s40814-020-00733-8. PMID: 33298193. Exclusion Code: X2.33298193
11 Adler Nevo GW, Avery D, Fiksenbaum L, . Eight years later: outcomes of CBT-treated versus untreated anxious children. Brain Behav. 2014 Sep;4(5):765–74. doi: 10.1002/brb3.274. PMID: 25328851. Exclusion Code: X7.25328851
12 Afshari A, Neshat-Doost HT, Maracy MR, . The effective comparison between emotion-focused cognitive behavioral group therapy and cognitive behavioral group therapy in children with separation anxiety disorder. J Res Med Sci. 2014 Mar;19(3):221–7. PMID: 24949029. Exclusion Code: X6.24949029
13 Aguinaldo LD, Sullivant S, Lanzillo EC, . Validation of the ask suicide-screening questions (ASQ) with youth in outpatient specialty and primary care clinics. Gen Hosp Psychiatry. 2021 Jan–Feb;68:52–8. doi: 10.1016/j.genhosppsych.2020.11.006. PMID: 33310014. Exclusion Code: X4.33310014
14 Ahmadi A, Mustaffa MS, Haghdoost AA, . Eclectic approach to anxiety disorders among rural children. Trends Psychiatry Psychother. 2017 Apr–Jun;39(2):88–97. doi: 10.1590/2237-6089-2016-0047. PMID: 28700038. Exclusion Code: X2.28700038
15 Ahmed N, John A, Islam S, . Investigating the feasibility of an enhanced contact intervention in self-harm and suicidal behaviour: a protocol for a randomised controlled trial delivering a Social support and Wellbeing Intervention following Self Harm (SWISH). BMJ Open. 2016 Sep 14;6(9):e012043. doi: 10.1136/bmjopen-2016-012043. PMID: 27630071. Exclusion Code: X3.27630071
16 Alavi A, Sharifi B, Ghanizadeh A, . Effectiveness of cognitive-behavioral therapy in decreasing suicidal ideation and hopelessness of the adolescents with previous suicidal attempts. Iran J Pediatr. 2013 Aug;23(4):467–72. PMID: 24427502. Exclusion Code: X6.24427502
17 Alcázar AIR, Olivares-Olivares PJ, Rodríguez JO. The role of non-specific effects in the psychological treatment of adolescents with social phobia. Anuario de Psicología/The UB Journal of Psychology. 2009;40(1):43–61. Exclusion Code: X1.
18 Alfano CA, Ginsburg GS, Kingery JN. Sleep-related problems among children and adolescents with anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2007;46(2):224–32. doi: 10.1097/01.chi.0000242233.06011.8e. PMID: 2007-01344-010. Exclusion Code: X9.17242626
19 Allen JL, Blatter-Meunier J, Ursprung A, . The separation anxiety daily diary: child version: feasibility and psychometric properties. Child Psychiatry Hum Dev. 2010;41(6):649–62. doi: 10.1007/s10578-010-0194-1. PMID: 2010-21825-006. Exclusion Code: X7.20614179
20 Allen JL, Blatter-Meunier J, Ursprung A, . Maternal daily diary report in the assessment of childhood separation anxiety. J Clin Child Adolesc Psychol. 2010;39(2):252–9. doi: 10.1080/15374410903532619. PMID: 2010-07582-010. Exclusion Code: X9.20390816
21 Amir N, Beard C, Taylor CT, . Attention training in individuals with generalized social phobia: A randomized controlled trial. J Consult Clin Psychol. 2009 Oct;77(5):961–73. doi: 10.1037/a0016685. PMID: 19803575. Exclusion Code: X3.19803575
22 Amoros-Boix M R-AA, Olivares-Olivares PJ. Role of the focus of attention in the treatment of generalized social phobia in adolescents. Anales De Psicologia. 2011;27(3). Exclusion Code: X1.
23 Angold A, Erkanli A, Copeland W, . Psychiatric diagnostic interviews for children and adolescents: a comparative study. J Am Acad Child Adolesc Psychiatry. 2012 May;51(5):506–17. doi: 10.1016/j.jaac.2012.02.020. PMID: 22525957. Exclusion Code: X4.22525957
24 Apsche JA, Bass CK, Houston M-A. A one year study of adolescent males with aggression and problems of conduct and personality: A comparison of MDT and DBT. International Journal of Behavioral Consultation and Therapy. 2006;2(4):544. Exclusion Code: X2.
25 Apter A. Adolescent self-harm: New horizons? J Am Acad Child Adolesc Psychiatry. 2014;53(10):1048–9. doi: 10.1016/j.jaac.2014.07.011. PMID: 2014-41032-008. Exclusion Code: X7.25245347
26 Arándiga AV, Rodríguez, . Competencia social y autoestima en adolescentes con fobia social. . Investigar el cambio curricular en el espacio europeo de educación superior. . 2014:459–79. Exclusion Code: X1.
27 Archer J. Randomised controlled trial: collaborative care improves clinical outcomes for adolescents with depression treated in primary care. Evid Based Med. 2015;20(1):20. doi: 10.1136/ebmed-2014-110108. PMID: CN-01072499. Exclusion Code: X8.25525043
28 Armitage CJ, Rahim WA, Rowe R, . An exploratory randomised trial of a simple, brief psychological intervention to reduce subsequent suicidal ideation and behaviour in patients admitted to hospital for self-harm. Br J Psychiatry. 2016 May;208(5):470–6. doi: 10.1192/bjp.bp.114.162495. PMID: 26743808. Exclusion Code: X2.26743808
29 Asarnow JR. Depression in childhood: one year outcomes of family versus individual treatment. J Am Acad Child Adolesc Psychiatry. 2018;57(10):S289–S90. doi: 10.1016/j.jaac.2018.07.692. PMID: CN-01653013. Exclusion Code: X12.
30 Asarnow JR, Berk M, Bedics J, . Dialectical behavior therapy for suicidal self-harming youths: emotion regulation, mechanisms, and mediators. J Am Acad Child Adolesc Psychiatry. 2021doi: 10.1016/j.jaac.2021.01.016. PMID: CN-02245272. Exclusion Code:
31 Asarnow JR, Berk MS, Bedics J, . Dialectical behavior therapy for suicidal self-harming youth: emotion regulation, mechanisms, and mediators. J Am Acad Child Adolesc Psychiatry. 2021 Feb 1doi: 10.1016/j.jaac.2021.01.016. PMID: 33539915. Exclusion Code: X4.33539915
32 Asarnow JR, Emslie G, Clarke G, . Treatment of selective serotonin reuptake inhibitor-resistant depression in adolescents: predictors and moderators of treatment response. J Am Acad Child Adolesc Psychiatry. 2009 Mar;48(3):330–9. doi: 10.1097/CHI.0b013e3181977476. PMID: 19182688. Exclusion Code: X2.19182688
33 Asarnow JR, Jaycox LH, Duan N, . Effectiveness of a quality improvement intervention for adolescent depression in primary care clinics: a randomized controlled trial. JAMA. 2005 Jan 19;293(3):311–9. doi: 10.1001/jama.293.3.311. PMID: 15657324. Exclusion Code: X2.15657324
34 Asarnow JR, Jaycox LH, Tang L, . Long-term benefits of short-term quality improvement interventions for depressed youths in primary care. Am J Psychiatry. 2009 Sep;166(9):1002–10. doi: 10.1176/appi.ajp.2009.08121909. PMID: 19651711. Exclusion Code: X5.19651711
35 Atkinson S, Thurman L, Ramaker S, . Safety, tolerability, and efficacy of desvenlafaxine in children and adolescents with major depressive disorder: results from two open-label extension trials. CNS Spectr. 2019 Oct;24(5):496–506. doi: 10.1017/s1092852918001128. PMID: 30419989. Exclusion Code: X4.30419989
36 Atkinson SD, Prakash A, Zhang Q, . A double-blind efficacy and safety study of duloxetine flexible dosing in children and adolescents with major depressive disorder. J Child Adolesc Psychopharmacol. 2014 May;24(4):180–9. doi: 10.1089/cap.2013.0146. PMID: 24813026. Exclusion Code: X13.24813026
37 Azadeh SM, Kazemi-Zahrani H, Besharat MA. Effectiveness of acceptance and commitment therapy on interpersonal problems and psychological flexibility in female high school students with social anxiety disorder. Glob J Health Sci. 2015 Jul 12;8(3):131–8. doi: 10.5539/gjhs.v8n3p131. PMID: 26493425. Exclusion Code: X6.26493425
38 Azzopardi C, Greenblatt A, Korczak DJ, . Pediatric hospital screening for suicide risk in adolescents referred for maltreatment. Child Youth Serv Rev. 2020;119doi: 10.1016/j.childyouth.2020.105500. PMID: 2020-97548-001. Exclusion Code: X2.
39 Babeva KN, Klomhaus AM, Sugar CA, . Adolescent suicide attempt prevention: predictors of response to a cognitive-behavioral family and youth centered intervention. Suicide Life Threat Behav. 2020 Feb;50(1):56–71. doi: 10.1111/sltb.12573. PMID: 31350782. Exclusion Code: X7.31350782
40 Baer S, Garland EJ. Pilot study of community-based cognitive behavioral group therapy for adolescents with social phobia. J Am Acad Child Adolesc Psychiatry. 2005 Mar;44(3):258–64. doi: 10.1097/00004583-200503000-00010. PMID: 15725970. Exclusion Code: X13.15725970
41 Baldofski S, Kohls E, Bauer S, . Efficacy and cost-effectiveness of two online interventions for children and adolescents at risk for depression (E.motion trial): study protocol for a randomized controlled trial within the ProHEAD consortium. Trials. 2019 Jan 15;20(1):53. doi: 10.1186/s13063-018-3156-8. PMID: 30646944. Exclusion Code: X2.30646944
42 Ballard ED, Cwik M, Van Eck K, . Identification of at-risk youth by suicide screening in a pediatric emergency department. Prev Sci. 2017 Feb;18(2):174–82. doi: 10.1007/s11121-016-0717-5. PMID: 27678381. Exclusion Code: X2.27678381
43 Ballard ED, Snider SL, Nugent AC, . Active suicidal ideation during clinical antidepressant trials. Psychiatry Res. 2017 Nov;257:303–8. doi: 10.1016/j.psychres.2017.07.065. PMID: 28787656. Exclusion Code: X2.28787656
44 Bansa M, Brown D, DeFrino D, . A little effort can withstand the hardship: fielding an internet-based intervention to prevent depression among urban racial/ethnic minority adolescents in a primary care setting. J Natl Med Assoc. 2018 Apr;110(2):130–42. doi: 10.1016/j.jnma.2017.02.006. PMID: 29580446. Exclusion Code: X2.29580446
45 Barbe RP, Bridge J, Birmaher B, . Suicidality and its relationship to treatment outcome in depressed adolescents. Suicide Life Threat Behav. 2004 Spring;34(1):44–55. PMID: 15106887. Exclusion Code: X4.15106887
46 Barbe RP, Bridge JA, Birmaher B, . Lifetime history of sexual abuse, clinical presentation, and outcome in a clinical trial for adolescent depression. J Clin Psychiatry. 2004 Jan;65(1):77–83. PMID: 14744173. Exclusion Code: X4.14744173
47 Barch DM, Whalen D, Gilbert K, . Neural indicators of anhedonia: predictors and mechanisms of treatment change in a randomized clinical trial in early childhood depression. Biol Psychiatry. 2019 May 15;85(10):863–71. doi: 10.1016/j.biopsych.2018.11.021. PMID: 30583852. Exclusion Code: X9.30583852
48 Bar-Haim Y, Morag I, Glickman S. Training anxious children to disengage attention from threat: A randomized controlled trial. J Child Psychol Psychiatry. 2011;52(8):861–9. doi: 10.1111/j.1469-7610.2011.02368.x. PMID: 2011-14641-007. Exclusion Code: X3.21250993
49 Barnes AJ. Attachment-based family therapy reduces suicidal ideation in adolescents. Evid Based Ment Health. 2011 Feb;14(1):8. doi: 10.1136/ebmh.14.1.8. PMID: 21266605. Exclusion Code: X8.21266605
50 Barrett PM. Evaluation of cognitive-behavioral group treatments for childhood anxiety disorders. J Clin Child Psychol. 1998 Dec;27(4):459–68. doi: 10.1207/s15374424jccp2704_10. PMID: 9866083. Exclusion Code: X13.9866083
51 Beidel DC, Turner SM, Morris TL. Behavioral treatment of childhood social phobia. J Consult Clin Psychol. 2000 Dec;68(6):1072–80. PMID: 11142541. Exclusion Code: X4.11142541
52 Beidel DC, Turner SM, Sallee FR, . SET-C versus fluoxetine in the treatment of childhood social phobia. J Am Acad Child Adolesc Psychiatry. 2007;46(12):1622–32. doi: 10.1097/chi.0b013e318154bb57. PMID: 2007-18374-011. Exclusion Code: X13.18030084
53 Beitchman JH, Kruidenier B, Clegg M. The Children’s Self-Report Rating Scale: screening accuracy and predictive power reconsidered. J Am Acad Child Adolesc Psychiatry. 1987 Jan;26(1):49–52. doi: 10.1097/00004583-198701000-00010. PMID: 3584000. Exclusion Code: X2.3584000
54 Berard R, Fong R, Carpenter DJ, . An international, multicenter, placebo-controlled trial of paroxetine in adolescents with major depressive disorder. J Child Adolesc Psychopharmacol. 2006 Feb–Apr;16(1–2):59–75. doi: 10.1089/cap.2006.16.59. PMID: 16553529. Exclusion Code: X3.16553529
55 Berard RMF, Ahmed N. Hospital Anxiety and Depression Scale (HADS) as a screening instrument in a depressed adolescent and young adult population. Int J Adolesc Med Health. 1995;8(3):157–66. PMID: 1996-04775-001. Exclusion Code: X2.
56 Berg M, Rozental A, de Brun Mangs J, . The role of learning support and chat-sessions in guided internet-based cognitive behavioral therapy for adolescents with anxiety: a factorial design study. Front Psychiatry. 2020;11:503. doi: 10.3389/fpsyt.2020.00503. PMID: 32587533. Exclusion Code: X4.32587533
57 Berg M, Rozental A, Johansson S, . The role of knowledge in internet-based cognitive behavioural therapy for adolescent depression: Results from a randomised controlled study. Internet Interv. 2019 Mar;15:10–7. doi: 10.1016/j.invent.2018.10.001. PMID: 30519531. Exclusion Code: X9.30519531
58 Berge KG, Agdal ML, Vika M, . Treatment of intra-oral injection phobia: a randomized delayed intervention controlled trial among Norwegian 10- to 16-year-olds. Acta Odontol Scand. 2017 May;75(4):294–301. doi: 10.1080/00016357.2017.1297849. PMID: 28270029. Exclusion Code: X2.28270029
59 Bergeron L, Smolla N, Berthiaume C, . Reliability, validity, and clinical utility of the Dominic Interactive for Adolescents-revised (a DSM-5-based self-report screen for mental disorders, borderline personality traits, and suicidality). Can J Psychiatry. 2017 Mar;62(3):211–22. doi: 10.1177/0706743716670129. PMID: 27638424. Exclusion Code: X3.27638424
60 Bernard DL, Calhoun CD, Banks DE, . Making the “C-ACE” for a Culturally-informed Adverse Childhood experiences framework to understand the pervasive mental health impact of racism on Black youth. J Child Adolesc Trauma. 2021 Jun;14(2):233–47. doi: 10.1007/s40653-020-00319-9. PMID: 33986909. Exclusion Code: X7.33986909
61 Bernstein GA, Anderson LK, Hektner JM, . Imipramine compliance in adolescents. J Am Acad Child Adolesc Psychiatry. 2000 Mar;39(3):284–91. doi: 10.1097/00004583-200003000-00009. PMID: 10714047. Exclusion Code: X3.10714047
62 Bernstein GA, Borchardt CM, Perwien AR, . Imipramine plus cognitive-behavioral therapy in the treatment of school refusal. J Am Acad Child Adolesc Psychiatry. 2000 Mar;39(3):276–83. doi: 10.1097/00004583-200003000-00008. PMID: 10714046. Exclusion Code: X3.10714046
63 Bhatta S, Champion JD, Young C, . Outcomes of depression screening among adolescents accessing school-based pediatric primary care clinic services. J Pediatr Nurs. 2018 Jan–Feb;38:8–14. doi: 10.1016/j.pedn.2017.10.001. PMID: 29167086. Exclusion Code: X3.29167086
64 Biederman J. Clonazepam in the treatment of prepubertal children with panic-like symptoms. J Clin Psychiatry. 1987 Oct;48 Suppl:38–42. PMID: 3667548. Exclusion Code: X3.3667548
65 Bierman KL, Heinrichs BS, Welsh JA, . Reducing adolescent psychopathology in socioeconomically disadvantaged children with a preschool intervention: a randomized controlled trial. The American Journal of Psychiatry. 2020 December 10, 2020;178(4):305–12. doi: 10.1176/appi.ajp.2020.20030343. Exclusion Code: X2.33297720
66 Bilek EL, Ehrenreich-May J. An open trial investigation of a transdiagnostic group treatment for children with anxiety and depressive symptoms. Behav Ther. 2012;43(4):887–97. doi: 10.1016/j.beth.2012.04.007. PMID: 2012-27520-008. Exclusion Code: X7.23046789
67 Birmaher B, Waterman GS, Ryan N, . Fluoxetine for childhood anxiety disorders. J Am Acad Child Adolesc Psychiatry. 1994 Sep;33(7):993–9. doi: 10.1097/00004583-199409000-00009. PMID: 7961355. Exclusion Code: X2.7961355
68 Blom EH, Larsson JO, Serlachius E, . The differentiation between depressive and anxious adolescent females and controls by behavioural self-rating scales. J Affect Disord. 2010 May;122(3):232–40. doi: 10.1016/j.jad.2009.07.006. PMID: 19695710. Exclusion Code: X7.19695710
69 Blossom JB, Ginsburg GS, Birmaher B, . Parental and family factors as predictors of threat bias in anxious youth. Cognit Ther Res. 2013;37(4):812–9. doi: 10.1007/s10608-012-9513-0. PMID: 2013-00135-001. Exclusion Code: X7.
70 Bodden DH, Bögels SM, Muris P. The diagnostic utility of the Screen for Child Anxiety Related Emotional Disorders-71 (SCARED-71). Behav Res Ther. 2009 May;47(5):418–25. doi: 10.1016/j.brat.2009.01.015. PMID: 19230863. Exclusion Code: X4.19230863
71 Bodden DH, Dirksen CD, Bögels SM, . Costs and cost-effectiveness of family CBT versus individual CBT in clinically anxious children. Clin Child Psychol Psychiatry. 2008 Oct;13(4):543–64. doi: 10.1177/1359104508090602. PMID: 18927140. Exclusion Code: X4.18927140
72 Bottelier MA, Schrantee AGM, Van Wingen GA, . Treatment with fluoxetine in adolescents may aggravate emotional dysregulation: a power analysis for future studies. European neuropsychopharmacology. 2015;25:S461–S2. PMID: CN-01163210. Exclusion Code: X9.
73 Boudreaux ED, Camargo CA, Jr., Arias SA, . Improving suicide risk screening and detection in the emergency department. Am J Prev Med. 2016 Apr;50(4):445–53. doi: 10.1016/j.amepre.2015.09.029. PMID: 26654691. Exclusion Code: X2.26654691
74 Boylan C, Morgan S, Carthy A, . A randomised controlled trial of a programme for parents and full-time carers of young people with self-harm or suicidal behaviour. Eur Child Adolesc Psychiatry. 2013;22(2):S184-. doi: 10.1007/s00787-013-0423-9. PMID: CN-01006221. Exclusion Code: X2.
75 Boyle MH, Cunningham CE, Georgiades K, . The Brief Child and Family Phone Interview (BCFPI): 2. Usefulness in screening for child and adolescent psychopatholog. J Child Psychol Psychiatry. 2009 Apr;50(4):424–31. doi: 10.1111/j.1469-7610.2008.01971.x. PMID: 19175807. Exclusion Code: X5.19175807
76 Bredemeier K, Spielberg JM, Silton RL, . Screening for depressive disorders using the Mood and Anxiety Symptoms Questionnaire Anhedonic Depression Scale: a receiver-operating characteristic analysis. Psychol Assess. 2010 Sep;22(3):702–10. doi: 10.1037/a0019915. PMID: 20822283. Exclusion Code: X2.20822283
77 Brent D, Emslie G, Clarke G, . Switching to another SSRI or to venlafaxine with or without cognitive behavioral therapy for adolescents with SSRI-resistant depression: the TORDIA randomized controlled trial. JAMA. 2008 Feb 27;299(8):901–13. doi: 10.1001/jama.299.8.901. PMID: 18314433. Exclusion Code: X2.18314433
78 Brent DA, Brunwasser SM, Hollon SD, . Effect of a cognitive-behavioral prevention program on depression 6 years after implementation among at-risk adolescents: a randomized clinical trial. JAMA Psychiatry. 2015 Nov;72(11):1110–8. doi: 10.1001/jamapsychiatry.2015.1559. PMID: 26421861. Exclusion Code: X2.26421861
79 Brent DA, Emslie GJ, Clarke GN, . Predictors of spontaneous and systematically assessed suicidal adverse events in the treatment of SSRI-resistant depression in adolescents (TORDIA) study. Am J Psychiatry. 2009 Apr;166(4):418–26. doi: 10.1176/appi.ajp.2008.08070976. PMID: 19223438. Exclusion Code: X2.19223438
80 Brent DA, Holder D, Kolko D, . A clinical psychotherapy trial for adolescent depression comparing cognitive, family, and supportive therapy. Arch Gen Psychiatry. 1997 Sep;54(9):877–85. PMID: 9294380. Exclusion Code: X13.9294380
81 Brent DA, Kennard BD. Impact of a brief inpatient intervention and suicide safety planning app to decrease suicidal behavior after hospital discharge. J Am Acad Child Adolesc Psychiatry. 2018;57(10):S33-. doi: 10.1016/j.jaac.2018.07.142. PMID: CN-01654953. Exclusion Code: X12.
82 Brent DA, Kolko DJ, Birmaher B, . Predictors of treatment efficacy in a clinical trial of three psychosocial treatments for adolescent depression. J Am Acad Child Adolesc Psychiatry. 1998 Sep;37(9):906–14. doi: 10.1097/00004583-199809000-00010. PMID: 9735610. Exclusion Code: X4.9735610
83 Britton JC, Bar-Haim Y, Clementi MA, . Training-associated changes and stability of attention bias in youth: Implications for Attention Bias Modification Treatment for pediatric anxiety. Dev Cogn Neurosci. 2013;4:52–64. doi: 10.1016/j.dcn.2012.11.001. PMID: 2013-09450-006. Exclusion Code: X4.23200784
84 Brunoni AR, Sampaio-Junior B, Moffa AH, . The Escitalopram versus Electric Current Therapy for Treating Depression Clinical Study (ELECT-TDCS): rationale and study design of a non-inferiority, triple-arm, placebo-controlled clinical trial. Sao Paulo Med J. 2015 May–Jun;133(3):252–63. doi: 10.1590/1516-3180.2014.00351712. PMID: 26176930. Exclusion Code: X2.26176930
85 Brunshaw JM, Szatmari P. The agreement between behaviour checklists and structured psychiatric interviews for children. Can J Psychiatry. 1988 Aug;33(6):474–81. doi: 10.1177/070674378803300608. PMID: 3196999. Exclusion Code: X2.3196999
86 Bunnell BE, Mesa F, Beidel DC. A two-session hierarchy for shaping successive approximations of speech in selective mutism: pilot study of mobile apps and mechanisms of behavior change. Behav Ther. 2018 Nov;49(6):966–80. doi: 10.1016/j.beth.2018.02.003. PMID: 30316494. Exclusion Code: X3.30316494
87 Burke TA, Jacobucci R, Ammerman BA, . Using machine learning to classify suicide attempt history among youth in medical care settings. J Affect Disord. 2020 May 1;268:206–14. doi: 10.1016/j.jad.2020.02.048. PMID: 32174479. Exclusion Code: X3.32174479
88 Busby DR, King CA, Brent D, . Adolescents’ engagement with crisis hotline risk-management services: a report from the Emergency Department Screen for Teen Suicide Risk (ED-STARS) Study. Suicide Life Threat Behav. 2020 Feb;50(1):72–82. doi: 10.1111/sltb.12558. PMID: 31152463. Exclusion Code: X9.31152463
89 Bushnell GA, Stürmer T, Swanson SA, . Dosing of Selective Serotonin Reuptake Inhibitors among children and adults before and after the FDA black-box warning. Psychiatr Serv. 2016 Mar;67(3):302–9. doi: 10.1176/appi.ps.201500088. PMID: 26567938. Exclusion Code: X3.26567938
90 Canals J DE, Carbajo G, Blade J. Prevalence of DSM-III-R and ICD-10 psychiatric disorders in a Spanish population of 18-year-olds. Acta Psychiatr Scand. 1997;96:287–94. Exclusion Code: X3.9350958
91 Canals J M-HC, Fernandez-Ballart J, Domenech E. A longitudinal study of depression in an urban Spanish pubertal population. Eur Child Adolesc Psychiatry. 1995;4:102–11. Exclusion Code: X9.7796248
92 Caporino N. Child/adolescent anxiety multimodal extended long-term study: depression and suicide outcomes. J Am Acad Child Adolesc Psychiatry. 2017;56(10):S318-. doi: 10.1016/j.jaac.2017.07.639. PMID: CN-01452306. Exclusion Code: X9.
93 Caporino NE, Brodman DM, Kendall PC, . Defining treatment response and remission in child anxiety: signal detection analysis using the pediatric anxiety rating scale. J Am Acad Child Adolesc Psychiatry. 2013 Jan;52(1):57–67. doi: 10.1016/j.jaac.2012.10.006. PMID: 23265634. Exclusion Code: X10.23265634
94 Caporino NE, Sakolsky D, Brodman DM, . Establishing clinical cutoffs for response and remission on the Screen for Child Anxiety Related Emotional Disorders (SCARED). J Am Acad Child Adolesc Psychiatry. 2017 Aug;56(8):696–702. doi: 10.1016/j.jaac.2017.05.018. PMID: 28735699. Exclusion Code: X3.28735699
95 Caron EB, Drake KL, Stewart CE, . Intervention adherence and self-efficacy as predictors of child outcomes in school nurse-delivered interventions for anxiety. J Sch Nurs. 2020 May 15:1059840520925522. doi: 10.1177/1059840520925522. PMID: 32410495. Exclusion Code: X4.32410495
96 Cartwright-Hatton S, McNally D, Field AP, . A new parenting-based group intervention for young anxious children: Results of a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2011;50(3):242–51. doi: 10.1016/j.jaac.2010.12.015. PMID: 2011-04926-006. Exclusion Code: X3.21334564
97 Cederlund R, Öst L-G. Psychometric properties of the Social Phobia and Anxiety Inventory-Child version in a Swedish clinical sample. J Anxiety Disord. 2013;27(5):503–11. doi: 10.1016/j.janxdis.2013.06.004. PMID: 2013-31517-009. Exclusion Code: X2.23933599
98 Cervin M, Storch EA, Piacentini J, . Symptom-specific effects of cognitive-behavioral therapy, sertraline, and their combination in a large randomized controlled trial of pediatric anxiety disorders. J Child Psychol Psychiatry. 2020 Apr;61(4):492–502. doi: 10.1111/jcpp.13124. PMID: 31471911. Exclusion Code: X7.31471911
99 Cervin M, Storch EA, Piacentini J, . Symptom-specific effects of cognitive-behavioral therapy, sertraline, and their combination in a large randomized controlled trial of pediatric anxiety disorders. Journal of child psychology & psychiatry. 2020;61(4):492–502. doi: 10.1111/jcpp.13124. PMID: CN-02127722. Exclusion Code:31471911
100 Chanen AM, Jackson HJ, McCutcheon LK, . Early intervention for adolescents with borderline personality disorder using cognitive analytic therapy: randomised controlled trial. Br J Psychiatry. 2008 Dec;193(6):477–84. doi: 10.1192/bjp.bp.107.048934. PMID: 19043151. Exclusion Code: X4.19043151
101 Chang SW, Kuckertz JM, Bose D, . Efficacy of attention bias training for child anxiety disorders: a randomized controlled trial. Child Psychiatry Hum Dev. 2019 Apr;50(2):198–208. doi: 10.1007/s10578-018-0832-6. PMID: 30051155. Exclusion Code: X3.30051155
102 Chapdelaine A, Carrier JD, Fournier L, . Treatment adequacy for social anxiety disorder in primary care patients. PLoS One. 2018;13(11):e0206357. doi: 10.1371/journal.pone.0206357. PMID: 30395608. Exclusion Code: X2.30395608
103 Charkhandeh M, Talib MA, Hunt CJ. The clinical effectiveness of cognitive behavior therapy and an alternative medicine approach in reducing symptoms of depression in adolescents. Psychiatry Res. 2016 May 30;239:325–30. doi: 10.1016/j.psychres.2016.03.044. PMID: 27058159. Exclusion Code: X6.27058159
104 Chavira DA, Stein MB. Combined psychoeducation and treatment with selective serotonin reuptake inhibitors for youth with generalized social anxiety disorder. J Child Adolesc Psychopharmacol. 2002 Spring;12(1):47–54. doi: 10.1089/10445460252943560. PMID: 12014595. Exclusion Code: X3.12014595
105 Chavira DA, Stein MB, Bailey K, . Child anxiety in primary care: prevalent but untreated. Depress Anxiety. 2004;20(4):155–64. doi: 10.1002/da.20039. PMID: 15643639. Exclusion Code: X9.15643639
106 Chen H, Upadhyay N, Lyu N, . Association of primary and behavioral health integrated care upon pediatric mental disorder treatment. Acad Pediatr. 2021 Jun 1doi: 10.1016/j.acap.2021.05.021. PMID: 34087480. Exclusion Code: X7.34087480
107 Chen S. An online solution focused brief therapy for adolescent anxiety during the novel coronavirus disease (COVID-19) pandemic: a structured summary of a study protocol for a randomised controlled trial. Trials. 2020;21(1)doi: 10.1186/s13063-020-04355-6. PMID: CN-02120850. Exclusion Code: X2.
108 Chiappini EA, Gosch E, Compton SN, . In-session involvement in anxious youth receiving CBT with/without medication. J Psychopathol Behav Assess. 2020;42(4):615–26. doi: 10.1007/s10862-020-09810-x. PMID: 2020-39041-001. Exclusion Code: X9.
109 Chorpita BF, Moffitt CE, Gray J. Psychometric properties of the Revised Child Anxiety and Depression Scale in a clinical sample. Behav Res Ther. 2005 Mar;43(3):309–22. doi: 10.1016/j.brat.2004.02.004. PMID: 15680928. Exclusion Code: X5.15680928
110 Chowdhury T, Champion JD. Outcomes of depression screening for adolescents accessing pediatric primary care-based services. J Pediatr Nurs. 2020 Mar 2;52:25–9. doi: 10.1016/j.pedn.2020.02.036. PMID: 32135479. Exclusion Code: X7.32135479
111 Christensen KS, Haugen W, Sirpal MK, . Diagnosis of depressed young people--criterion validity of WHO-5 and HSCL-6 in Denmark and Norway. Fam Pract. 2015 Jun;32(3):359–63. doi: 10.1093/fampra/cmv011. PMID: 25800246. Exclusion Code: X8.25800246
112 Chu BC, Carpenter AL, Wyszynski CM, . Scalable options for extended skill building following Didactic training in Cognitive-Behavioral Therapy for anxious youth: A Pilot Randomized Trial. J Clin Child Adolesc Psychol. 2017 May–Jun;46(3):401–10. doi: 10.1080/15374416.2015.1038825. PMID: 25984590. Exclusion Code: X2.25984590
113 Chu BC, Crocco ST, Esseling P, . Transdiagnostic group behavioral activation and exposure therapy for youth anxiety and depression: Initial randomized controlled trial. Behav Res Ther. 2016 Jan;76:65–75. doi: 10.1016/j.brat.2015.11.005. PMID: 26655958. Exclusion Code: X5.26655958
114 Chutko L, Surushkina SY, Nikishena I, . Treatment of anxiety disorders in school maladaptation with adaptol. Neurosci Behav Physiol. 2011;41(5):520–4. Exclusion Code: X3.
115 Cianchetti C, Faedda N, Pasculli M, . Predictive validity for the clinical diagnosis of a new parent questionnaire, the CABI, compared with CBCL. Clin Child Psychol Psychiatry. 2020 Apr;25(2):507–19. doi: 10.1177/1359104519895056. PMID: 31894698. Exclusion Code: X2.31894698
116 Clarke G, Sheppler CR, Firemark AJ, . Augmenting usual care SSRIs with cognitive behavioral therapy for insomnia to improve depression outcomes in youth: Design of a randomized controlled efficacy-effectiveness trial. Contemp Clin Trials. 2020 Feb 28;91:105967. doi: 10.1016/j.cct.2020.105967. PMID: 32114185. Exclusion Code: X4.32114185
117 Clarke GN, Hornbrook M, Lynch F, . Group cognitive-behavioral treatment for depressed adolescent offspring of depressed parents in a health maintenance organization. J Am Acad Child Adolesc Psychiatry. 2002 Mar;41(3):305–13. doi: 10.1097/00004583-200203000-00010. PMID: 11886025. Exclusion Code: X2.11886025
118 Clément C, Lin J, Stangier U. Efficacy of behavioral experiments in Cognitive Therapy for social anxiety disorder: study protocol for a randomized controlled trial. Trials. 2019 Dec 19;20(1):748. doi: 10.1186/s13063-019-3905-3. PMID: 31856903. Exclusion Code: X4.31856903
119 Cobham VE. Do anxiety-disordered children need to come into the clinic for efficacious treatment? J Consult Clin Psychol. 2012;80(3):465–76. doi: 10.1037/a0028205. PMID: 2012-10793-001. Exclusion Code: X13.22545740
120 Cobham VE, Dadds MR, Spence SH. The role of parental anxiety in the treatment of childhood anxiety. J Consult Clin Psychol. 1998 Dec;66(6):893–905. doi: 10.1037//0022-006x.66.6.893. PMID: 9874902. Exclusion Code: X3.9874902
121 Cohen JR, So FK, Young JF, . Youth depression screening with parent and self-reports: assessing current and prospective depression risk. Child Psychiatry Hum Dev. 2019 Aug;50(4):647–60. doi: 10.1007/s10578-019-00869-6. PMID: 30737605. Exclusion Code: X7.30737605
122 Coker TR, Porras-Javier L, Zhang L, . 4.57 Improved Access to Mental Health Care Using a Telehealth-Enhanced Referral Process in Pediatric Primary Care: a Cluster Randomized Trial. J Am Acad Child Adolesc Psychiatry. 2018;57(10):S222-. doi: 10.1016/j.jaac.2018.09.282. PMID: CN-01653032. Exclusion Code: X2.
123 Colins O, Grisso T, Vahl P, . Standardized screening for mental health needs of detained youths from various ethnic origins: the Dutch Massachusetts Youth Screening Instrument-Second Version (MAYSI-2). Journal of Psychopathology & Behavioral Assessment. 2015;37(3):481–92. doi: 10.1007/s10862-014-9476-4. PMID: 109827440. Language: English. Entry Date: 20150812. Revision Date: 20160831. Publication Type: Journal Article. Exclusion Code: X9.26273126
124 Comer JS, Furr JM, del Busto C, . Therapist-led, internet-delivered treatment for early child social anxiety: a waitlist-controlled evaluation of the iCALM Telehealth Program. Behav Ther. 2021doi: 10.1016/j.beth.2021.01.004. PMID: CN-02276119. Exclusion Code: X3.
125 Compton SN, Grant PJ, Chrisman AK, . Sertraline in children and adolescents with social anxiety disorder: an open trial. J Am Acad Child Adolesc Psychiatry. 2001 May;40(5):564–71. doi: 10.1097/00004583-200105000-00016. PMID: 11349701. Exclusion Code: X4.11349701
126 Conner OL, Siegle GJ, McFarland AM, . Mom—It helps when you’re right here! Attenuation of neural stress markers in anxious youths whose caregivers are present during fMRI. PLoS One. 2012;7(12)doi: 10.1371/journal.pone.0050680. PMID: 2013-12066-001. Exclusion Code: X3.
127 Conway PM, Erlangsen A, Teasdale TW, . Predictive validity of the Columbia-Suicide Severity Rating Scale for short-term suicidal behavior: a Danish study of adolescents at a high risk of suicide. Arch Suicide Res. 2017 Jul 3;21(3):455–69. doi: 10.1080/13811118.2016.1222318. PMID: 27602917. Exclusion Code: X2.27602917
128 Cooper WO, Callahan ST, Shintani A, . Antidepressants and suicide attempts in children. Pediatrics. 2014 Feb;133(2):204–10. doi: 10.1542/peds.2013-0923. PMID: 24394688. Exclusion Code: X4.24394688
129 Cornwall E, Spence SH, Schotte D. The effectiveness of emotive imagery in the treatment of darkness phobia in children. Behav Change. 1996;13(4):223–9. Exclusion Code: X3.
130 Cortez AB, Wilkins J, Handler E, . Multistage adolescent depression screening: a comparison of 11-year-olds to 12-year-olds. Perm J. 2021 May;25doi: 10.7812/tpp/20.233. PMID: 33970080. Exclusion Code: X7.33970080
131 Cosi S, Canals J, Hernández-Martinez C, . Parent-child agreement in SCARED and its relationship to anxiety symptoms. J Anxiety Disord. 2010 Jan;24(1):129–33. doi: 10.1016/j.janxdis.2009.09.008. PMID: 19864109. Exclusion Code: X9.19864109
132 Costello LH, Suh C, Burnett B, . Addressing adolescent depression in primary care: building capacity through psychologist and pediatrician partnership. J Clin Psychol Med Settings. 2019 Nov 20doi: 10.1007/s10880-019-09680-w. PMID: 31749100. Exclusion Code: X4.31749100
133 Cotton S, Kraemer KM, Sears RW, . Mindfulness-based cognitive therapy for children and adolescents with anxiety disorders at-risk for bipolar disorder: A psychoeducation waitlist controlled pilot trial. Early Intervention in Psychiatry. 2020;14(2):211–9. doi: 10.1111/eip.12848. PMID: 2019-37562-001. Exclusion Code: X7.31264800
134 Courtney-Seidler EA, Burns K, Zilber I, . Adolescent suicide and self-injury: deepening the understanding of the biosocial theory and applying dialectical behavior therapy. International Journal of Behavioral Consultation and Therapy. 2014;9(3):35–40. doi: 10.1037/h0101638. PMID: 2019-11792-008. Exclusion Code: X8.
135 Crane ME, Norris LA, Frank HE, . Impact of treatment improvement on long-term anxiety: results from CAMS and CAMELS. J Consult Clin Psychol. 2021 Feb;89(2):126–33. doi: 10.1037/ccp0000523. PMID: 33705168. Exclusion Code: X9.33705168
136 Creswell C, Cruddace S, Gerry S, . Treatment of childhood anxiety disorder in the context of maternal anxiety disorder: a randomised controlled trial and economic analysis. Health Technol Assess. 2015 May;19(38):1–184, vii–viii. doi: 10.3310/hta19380. PMID: 26004142. Exclusion Code: X7.26004142
137 Cuijpers P, Smits N, Donker T, . Screening for mood and anxiety disorders with the five-item, the three-item, and the two-item Mental Health Inventory. Psychiatry Res. 2009 Aug 15;168(3):250–5. doi: 10.1016/j.psychres.2008.05.012. PMID: 19185354. Exclusion Code: X2.19185354
138 Cunha M, Gouveia JP, do Céu Salvador M. Social fears in adolescence: the social anxiety and avoidance scale for adolescents. Eur Psychol. 2008;13(3):197–213. doi: 10.1027/1016-9040.13.3.197. PMID: 2008-13222-006. Exclusion Code: X13.
139 Cwik M, Jay S, Ryan TC, . Lowering the Age Limit in Suicide Risk Screening: Clinical Differences and Screening Form Predictive Ability. J Am Acad Child Adolesc Psychiatry. 2021 May;60(5):537–40. doi: 10.1016/j.jaac.2020.11.025. PMID: 33667604. Exclusion Code: X4.33667604
140 da Costa CZ, de Morais RM, Zanetta DM, . Comparison among clomipramine, fluoxetine, and placebo for the treatment of anxiety disorders in children and adolescents. J Child Adolesc Psychopharmacol. 2013 Dec;23(10):687–92. doi: 10.1089/cap.2012.0110. PMID: 24350814. Exclusion Code: X6.24350814
141 D’Amato G. Chlordiazepoxide in management of school phobia. Dis Nerv Syst. 1962 May;23:292–5. PMID: 13882945. Exclusion Code: X2.13882945
142 Dams J, Kronmuller KT, Leibing E, . Direct costs of social phobia in adolescents and cost-effectiveness of psychotherapy. Psychiatr Prax. 2019;46(3):148–55. doi: 10.1055/a-0733-4999. PMID: CN-01937705. Exclusion Code: X1.30380584
143 Dardas LA. Family functioning moderates the impact of depression treatment on adolescents’ suicidal ideations. Child & Adolescent Mental Health. 2019;24(3):251–8. doi: 10.1111/camh.12323. PMID: 138125078. Language: English. Entry Date: 20190821. Revision Date: 20200122. Publication Type: Article. Exclusion Code: X9.32677215
144 de Groot J, Cobham V, Leong J, . Individual versus group family-focused cognitive-behaviour therapy for childhood anxiety: pilot randomized controlled trial. Aust N Z J Psychiatry. 2007 Dec;41(12):990–7. doi: 10.1080/00048670701689436. PMID: 17999271. Exclusion Code: X3.17999271
145 de Haan A, Petermann F, Meiser-Stedman R, . Psychometric properties of the German version of the Child Post-Traumatic Cognitions Inventory (CPTCI-GER). Child Psychiatry Hum Dev. 2016;47(1):151–8. doi: 10.1007/s10578-015-0552-0. PMID: 2015-23379-001. Exclusion Code: X3.25990307
146 De Lijster JM, Dieleman GC, Utens E, . Online Attention Bias Modification in Combination with Cognitive-Behavioural Therapy for Children and Adolescents with Anxiety Disorders: a Randomised Controlled Trial. Behav Change. 2019doi: 10.1017/bec.2019.8. PMID: CN-01937771. Exclusion Code: X4.
147 de Wilde EJ, van de Looij P, Goldschmeding J, . Self-report of suicidal thoughts and behavior vs. school nurse evaluations in Dutch high-school students. Crisis. 2011;32(3):121–7. doi: 10.1027/0227-5910/a000064. PMID: 21616760. Exclusion Code: X9.21616760
148 Deas D, Randall CL, Roberts JS, . A double-blind, placebo-controlled trial of sertraline in depressed adolescent alcoholics: a pilot study. Hum Psychopharmacol. 2000 Aug;15(6):461–9. doi: 10.1002/1099-1077(200008)15:6<461::aid-hup209>3.0.co;2-j. PMID: 12404308. Exclusion Code: X2.12404308
149 DelBello MP, Hochadel TJ, Portland KB, . A double-blind, placebo-controlled study of selegiline transdermal system in depressed adolescents. J Child Adolesc Psychopharmacol. 2014 Aug;24(6):311–7. doi: 10.1089/cap.2013.0138. PMID: 24955812. Exclusion Code: X3.24955812
150 Desousa DA, Salum GA, Isolan LR, . Sensitivity and specificity of the Screen for Child Anxiety Related Emotional Disorders (SCARED): a community-based study. Child Psychiatry Hum Dev. 2013 Jun;44(3):391–9. doi: 10.1007/s10578-012-0333-y. PMID: 22961135. Exclusion Code: X6.22961135
151 DeVylder JE, Ryan TC, Cwik M, . Screening for suicide risk among youths with a psychotic disorder in a pediatric emergency department. Psychiatr Serv. 2020 Feb 1;71(2):205–8. doi: 10.1176/appi.ps.201900290. PMID: 31795855. Exclusion Code: X5.31795855
152 DeVylder JE, Ryan TC, Cwik M, . Assessment of selective and universal screening for suicide risk in a pediatric emergency department. JAMA Netw Open. 2019 Oct 2;2(10):e1914070. doi: 10.1001/jamanetworkopen.2019.14070. PMID: 31651971. Exclusion Code: X4.31651971
153 Dewis LM, Kirkby KC, Martin F, . Computer-aided vicarious exposure versus live graded exposure for spider phobia in children. J Behav Ther Exp Psychiatry. 2001 Mar;32(1):17–27. doi: 10.1016/s0005-7916(01)00019-2. PMID: 11729943. Exclusion Code: X2.11729943
154 Di Simplicio M, Appiah-Kusi E, Wilkinson P, . Imaginator: a proof-of-concept feasibility trial of a brief imagery-based psychological intervention for young people who self-harm. Suicide Life Threat Behav. 2020 Jun;50(3):724–40. doi: 10.1111/sltb.12620. PMID: 32057131. Exclusion Code: X13.32057131
155 Diamond G, Creed T, Gillham J, . Sexual trauma history does not moderate treatment outcome in Attachment-Based Family Therapy (ABFT) for adolescents with suicide ideation. J Fam Psychol. 2012 Aug;26(4):595–605. doi: 10.1037/a0028414. PMID: 22709259. Exclusion Code: X2.22709259
156 Diamond GM, Diamond GS, Levy S, . Attachment-based family therapy for suicidal lesbian, gay, and bisexual adolescents: a treatment development study and open trial with preliminary findings. Psychotherapy (chicago, ill.). 2012;49(1):62–71. doi: 10.1037/a0026247. PMID: CN-00900412. Exclusion Code: X4.22181026
157 Diamond GS, Reis BF, Diamond GM, . Attachment-based family therapy for depressed adolescents: a treatment development study. J Am Acad Child Adolesc Psychiatry. 2002 Oct;41(10):1190–6. doi: 10.1097/00004583-200210000-00008. PMID: 12364840. Exclusion Code: X13.12364840
158 Dickerson JF, Lynch FL, De Bar L, . Cost-effectiveness of a brief primary care cognitive behavioral therapy intervention for depressed adolescents who decline pharmacotherapy. Journal of mental health policy and economics. 2015;18:S9–S10. PMID: CN-01142724. Exclusion Code: X9.
159 Dickerson JF, Lynch FL, Leo MC, . cost-effectiveness of cognitive behavioral therapy for depressed youth declining antidepressants. Pediatrics. 2018 Feb;141(2)doi: 10.1542/peds.2017-1969. PMID: 29351965. Exclusion Code: X9.29351965
160 Dietz LJ, Marshal MP, Burton CM, . Social problem solving among depressed adolescents is enhanced by structured psychotherapies. J Consult Clin Psychol. 2014 Apr;82(2):202–11. doi: 10.1037/a0035718. PMID: 24491077. Exclusion Code: X4.24491077
161 Dietz LJ, Mufson L, Irvine H, . Family-based interpersonal psychotherapy for depressed preadolescents: an open-treatment trial. Early Interv Psychiatry. 2008 Aug;2(3):154–61. doi: 10.1111/j.1751-7893.2008.00077.x. PMID: 21352148. Exclusion Code: X7.21352148
162 Dietz LJ, Weinberg RJ, Brent DA, . Family-based interpersonal psychotherapy for depressed preadolescents: examining efficacy and potential treatment mechanisms. J Am Acad Child Adolesc Psychiatry. 2015 Mar;54(3):191–9. doi: 10.1016/j.jaac.2014.12.011. PMID: 25721184. Exclusion Code: X4.25721184
163 Do R, Lee S, Kim JS, . Effectiveness and dissemination of computer-based cognitive behavioral therapy for depressed adolescents: Effective and accessible to whom? J Affect Disord. 2021 Mar 1;282:885–93. doi: 10.1016/j.jad.2020.12.177. PMID: 33601732. Exclusion Code: X2.33601732
164 Dobson ET, Strawn JR. Pharmacotherapy for pediatric generalized anxiety disorder: a systematic evaluation of efficacy, safety and tolerability. Paediatr Drugs. 2016 Feb;18(1):45–53. doi: 10.1007/s40272-015-0153-1. PMID: 26660158. Exclusion Code: X9.26660158
165 Donaldson D, Spirito A, Esposito-Smythers C. Treatment for adolescents following a suicide attempt: results of a pilot trial. J Am Acad Child Adolesc Psychiatry. 2005 Feb;44(2):113–20. doi: 10.1097/00004583-200502000-00003. PMID: 15689724. Exclusion Code: X4.15689724
166 Donohue MR, Hoyniak CP, Tillman R, . Callous-unemotional traits as an intervention target and moderator of parent-child interaction therapy-emotion development treatment for preschool depression and conduct problems. J Am Acad Child Adolesc Psychiatry. 2021 May 20doi: 10.1016/j.jaac.2021.03.018. PMID: 33865929. Exclusion Code: X9.33865929
167 Donovan CL, Cobham V, Waters AM, . Intensive group-based CBT for child social phobia: a pilot study. Behav Ther. 2015 May;46(3):350–64. doi: 10.1016/j.beth.2014.12.005. PMID: 25892171. Exclusion Code: X7.25892171
168 Donovan CL, Spence SH, March S. Does an online CBT program for anxiety impact upon sleep problems in anxious youth? J Clin Child Adolesc Psychol. 2017 Mar–Apr;46(2):211–21. doi: 10.1080/15374416.2016.1188700. PMID: 27492674. Exclusion Code: X7.27492674
169 Downey VA, Zun LS. Identifying Undiagnosed Pediatric Mental Illness in the Emergency Department. Pediatr Emerg Care. 2018 Feb;34(2):e21–e3. doi: 10.1097/pec.0000000000001151. PMID: 28441242. Exclusion Code: X7.28441242
170 Dummit ES, 3rd, Klein RG, Tancer NK, . Fluoxetine treatment of children with selective mutism: an open trial. J Am Acad Child Adolesc Psychiatry. 1996 May;35(5):615–21. doi: 10.1097/00004583-199605000-00016. PMID: 8935208. Exclusion Code: X4.8935208
171 Ebesutani C, Bernstein A, Nakamura BJ, . A psychometric analysis of the Revised Child Anxiety and Depression Scale—Parent Version in a clinical sample. J Abnorm Child Psychol. 2010;38(2):249–60. doi: 10.1007/s10802-009-9363-8. PMID: 2010-02865-009. Exclusion Code: X9.19830545
172 Ebesutani C, Korathu-Larson P, Nakamura BJ, . The Revised Child Anxiety and Depression Scale 25-Parent version: Scale development and validation in a school-based and clinical sample. Assessment. 2017 Sep;24(6):712–28. doi: 10.1177/1073191115627012. PMID: 26834091. Exclusion Code: X5.26834091
173 Ebesutani C, Reise SP, Chorpita BF, . The Revised Child Anxiety and Depression Scale-Short version: scale reduction via exploratory bifactor modeling of the broad anxiety factor. Psychol Assess. 2012 Dec;24(4):833–45. doi: 10.1037/a0027283. PMID: 22329531. Exclusion Code: X3.22329531
174 Ebesutani C, Tottenham N, Chorpita B. The Revised Child Anxiety and Depression Scale - Parent version: extended applicability and validity for use with younger youth and children with histories of early-life caregiver neglect. J Psychopathol Behav Assess. 2015 Dec;37(4):705–18. doi: 10.1007/s10862-015-9494-x. PMID: 30364688. Exclusion Code: X7.30364688
175 Ebrahiminejad S, Poursharifi H, Bakhshiour Roodsari A, . The effectiveness of mindfulness-based cognitive therapy on Iranian female adolescents suffering from social anxiety. Iran Red Crescent Med J. 2016 Nov;18(11):e25116. doi: 10.5812/ircmj.25116. PMID: 28191335. Exclusion Code: X5.28191335
176 Eggert LL, Thompson EA, Randell BP, . Preliminary effects of brief school-based prevention approaches for reducing youth suicide--risk behaviors, depression, and drug involvement. J Child Adolesc Psychiatr Nurs. 2002 Apr–Jun;15(2):48–64. doi: 10.1111/j.1744-6171.2002.tb00326.x. PMID: 12083753. Exclusion Code: X5.12083753
177 Elkins RM, Gallo KP, Pincus DB, . Moderators of intensive CBT for adolescent panic disorder: the of fear and avoidance. Child Adolesc Ment Health. 2016 Feb 1;21(1):30–6. doi: 10.1111/camh.12122. PMID: 26929742. Exclusion Code: X4.26929742
178 Emslie GJ, Heiligenstein JH, Hoog SL, . Fluoxetine treatment for prevention of relapse of depression in children and adolescents: a double-blind, placebo-controlled study. J Am Acad Child Adolesc Psychiatry. 2004 Nov;43(11):1397–405. doi: 10.1097/01.chi.0000140453.89323.57. PMID: 15502599. Exclusion Code: X3.15502599
179 Emslie GJ, Heiligenstein JH, Wagner KD, . Fluoxetine for acute treatment of depression in children and adolescents: a placebo-controlled, randomized clinical trial. J Am Acad Child Adolesc Psychiatry. 2002 Oct;41(10):1205–15. doi: 10.1097/00004583-200210000-00010. PMID: 12364842. Exclusion Code: X13.12364842
180 Emslie GJ, Kennard BD, Mayes TL, . Continued effectiveness of relapse prevention cognitive-behavioral therapy following Fluoxetine treatment in youth with major depressive disorder. J Am Acad Child Adolesc Psychiatry. 2015 Dec;54(12):991–8. doi: 10.1016/j.jaac.2015.09.014. PMID: 26598474. Exclusion Code: X7.26598474
181 Emslie GJ, Kennard BD, Mayes TL, . Fluoxetine versus placebo in preventing relapse of major depression in children and adolescents. Am J Psychiatry. 2008 Apr;165(4):459–67. doi: 10.1176/appi.ajp.2007.07091453. PMID: 18281410. Exclusion Code: X2.18281410
182 Emslie GJ, Prakash A, Zhang Q, . A double-blind efficacy and safety study of duloxetine fixed doses in children and adolescents with major depressive disorder. J Child Adolesc Psychopharmacol. 2014 May;24(4):170–9. doi: 10.1089/cap.2013.0096. PMID: 24815533. Exclusion Code: X13.24815533
183 Emslie GJ, Rush AJ, Weinberg WA, . A double-blind, randomized, placebo-controlled trial of fluoxetine in children and adolescents with depression. Arch Gen Psychiatry. 1997 Nov;54(11):1031–7. PMID: 9366660. Exclusion Code: X13.9366660
184 Emslie GJ, Wagner KD, Kutcher S, . Paroxetine treatment in children and adolescents with major depressive disorder: a randomized, multicenter, double-blind, placebo-controlled trial. J Am Acad Child Adolesc Psychiatry. 2006 Jun;45(6):709–19. doi: 10.1097/01.chi.0000214189.73240.63. PMID: 16721321. Exclusion Code: X3.16721321
185 Enns MW, Cox BJ. Psychosocial and clinical predictors of symptom persistence vs remission in major depressive disorder. Can J Psychiatry. 2005 Oct;50(12):769–77. doi: 10.1177/070674370505001206. PMID: 16408525. Exclusion Code: X3.16408525
186 Esbjørn BH, Normann N, Christiansen BM, . The efficacy of group metacognitive therapy for children (MCT-c) with generalized anxiety disorder: An open trial. J Anxiety Disord. 2018 Jan;53:16–21. doi: 10.1016/j.janxdis.2017.11.002. PMID: 29145078. Exclusion Code: X4.29145078
187 Esposito M, Gimigliano F, Barillari MR, . Pediatric selective mutism therapy: a randomized controlled trial. Eur J Phys Rehabil Med. 2017 Oct;53(5):643–50. doi: 10.23736/s1973-9087.16.04037-5. PMID: 27830922. Exclusion Code: X3.27830922
188 Esposito-Smythers C, Spirito A, Kahler CW, . Treatment of co-occurring substance abuse and suicidality among adolescents: a randomized trial. J Consult Clin Psychol. 2011;79(6):728–39. doi: 10.1037/a0026074. PMID: CN-00837414. Exclusion Code: X2.22004303
189 Esposito-Smythers C, Walsh A, Spirito A, . Working with the suicidal client who also abuses substances. Cogn Behav Pract. 2012 May;19(2):245–55. doi: 10.1016/j.cbpra.2010.11.004. PMID: 23209362. Exclusion Code: X2.23209362
190 Etter DJ, McCord A, Ouyang F, . Suicide screening in primary care: use of an electronic screener to assess suicidality and improve provider follow-up for adolescents. J Adolesc Health. 2018 Feb;62(2):191–7. doi: 10.1016/j.jadohealth.2017.08.026. PMID: 29195764. Exclusion Code: X4.29195764
191 Evans L, Haeberlein K, Chang A, . Convergent Validity and Preliminary Cut-Off Scores for the Anxiety and Depression Subscales of the DASS-21 in US Adolescents. Child Psychiatry Hum Dev. 2021 Aug;52(4):579–85. doi: 10.1007/s10578-020-01050-0. PMID: 32816139. Exclusion Code: X4.32816139
192 Evans R, Thirlwall K, Cooper P, . Using symptom and interference questionnaires to identify recovery among children with anxiety disorders. Psychol Assess. 2017 Jul;29(7):835–43. doi: 10.1037/pas0000375. PMID: 27845527. Exclusion Code: X2.27845527
193 Fairbanks JM, Pine DS, Tancer NK, . Open fluoxetine treatment of mixed anxiety disorders in children and adolescents. J Child Adolesc Psychopharmacol. 1997 Spring;7(1):17–29. doi: 10.1089/cap.1997.7.17. PMID: 9192539. Exclusion Code: X4.9192539
194 Fallucco EM, Blackmore ER, Bejarano CM, . Collaborative care: a pilot study of a Child Psychiatry Outpatient Consultation Model for Primary Care Providers. J Behav Health Serv Res. 2017 Jul;44(3):386–98. doi: 10.1007/s11414-016-9513-z. PMID: 27189698. Exclusion Code: X4.27189698
195 Farley AM, Gallop RJ, Brooks ES, . Identification and management of adolescent depression in a large pediatric care network. J Dev Behav Pediatr. 2020 Feb/Mar;41(2):85–94. doi: 10.1097/dbp.0000000000000750. PMID: 31651619. Exclusion Code: X9.31651619
196 Feldhaus CG, Jacobs RH, Watkins ER, . Rumination-focused cognitive behavioral therapy decreases anxiety and increases behavioral activation among remitted adolescents. J Child Fam Stud. 2020;29(7):1982–91. doi: 10.1007/s10826-020-01711-7. PMID: 33737799. Exclusion Code: X2.33737799
197 Ferdinand RF. Validity of the CBCL/YSR DSM-IV scales anxiety problems and affective problems. J Anxiety Disord. 2008;22(1):126–34. doi: 10.1016/j.janxdis.2007.01.008. PMID: 17321103. Exclusion Code: X2.17321103
198 Fernandez Castelao C, Naber K, Altstädt S, . Two dimensions of social anxiety disorder: A pilot study of the Questionnaire for Social Anxiety and Social Competence Deficits for Adolescents. Child Adolesc Psychiatry Ment Health. 2015;9 PMID: 2015-46792-001. Exclusion Code: X7.
199 Fernández-Martínez I, Morales A, Méndez FX, . Spanish Adaptation and Psychometric Properties of the Parent Version of the Short Mood and Feelings Questionnaire (SMFQ-P) in a Non-Clinical Sample of Young School-Aged Children. Span J Psychol. 2020 Nov 5;23:e45. doi: 10.1017/sjp.2020.47. PMID: 33148355. Exclusion Code: X9.33148355
200 Findling RL, Pagano ME, McNamara NK, . The short-term safety and efficacy of fluoxetine in depressed adolescents with alcohol and cannabis use disorders: a pilot randomized placebo-controlled trial. Child Adolesc Psychiatry Ment Health. 2009 Mar 19;3(1):11. doi: 10.1186/1753-2000-3-11. PMID: 19298659. Exclusion Code: X2.19298659
201 Fischer G, Brunner R, Parzer P, . Short-term psychotherapeutic treatment in adolescents engaging in non-suicidal self-injury: a randomized controlled trial. Trials. 2013 Sep 13;14:294. doi: 10.1186/1745-6215-14-294. PMID: 24034810. Exclusion Code: X11.24034810
202 Fitzgerald A, Rawdon C, Dooley B. A randomized controlled trial of attention bias modification training for socially anxious adolescents. Behav Res Ther. 2016 Sep;84:1–8. doi: 10.1016/j.brat.2016.06.003. PMID: 27379745. Exclusion Code: X5.27379745
203 Flamarique I, Santosh P, Zuddas A, . Development and psychometric properties of the Suicidality: Treatment Occurring in Paediatrics (STOP) Suicidality Assessment Scale (STOP-SAS) in children and adolescents. BMC Pediatr. 2016 Dec 13;16(1):213. doi: 10.1186/s12887-016-0751-2. PMID: 27964729. Exclusion Code: X5.27964729
204 Flannery-Schroeder E, Choudhury MS, Kendall PC. Group and individual cognitive-behavioral treatments for youth with anxiety disorders: 1-year follow-up. Cognit Ther Res. 2005;29(2):253–9. doi: 10.1007/s10608-005-3168-z. PMID: 2005-04909-009. Exclusion Code: X4.
205 Flannery-Schroeder EC, Kendall PC. Group and individual cognitive-behavioral treatments for youth with anxiety disorders: A randomized clinical trial. Cognit Ther Res. 2000;24(3):251–78. Exclusion Code: X13.
206 Flatt N, King N. Brief psycho-social interventions in the treatment of specific childhood phobias: A controlled trial and a 1-year follow-up. Behav Change. 2010;27(3):130–53. doi: 10.1375/bech.27.3.130. PMID: 2010-21638-002. Exclusion Code: X2.
207 Forest Laboratories. A randomized, double-blind, placebo-controlled evaluation of the safety and efficacy of citalopram in children and adolescents with depression. Forest Laboratories - Clinical Study Register. 2001(1)PMID: CN-00763823. Exclusion Code: X3.
208 Friedman RA. Antidepressants’ black-box warning--10 years later. N Engl J Med. 2014 Oct 30;371(18):1666–8. doi: 10.1056/NEJMp1408480. PMID: 25354101. Exclusion Code: X3.25354101
209 Fristad MA, Vesco AT, Young AS, . Pilot randomized controlled trial of omega-3 and individual–family psychoeducational psychotherapy for children and adolescents with depression. J Clin Child Adolesc Psychol. 2019;48(Suppl 1):S105–S18. doi: 10.1080/15374416.2016.1233500. PMID: 2019-14393-010. Exclusion Code: X10.27819485
210 Fuentes-Rodriguez G, Saez-Castillo AJ, Garcia-Lopez LJ. Psychometric properties of the social anxiety subscale of the Youth Anxiety Measure for DSM-5 (YAM-5-I-SAD) in a clinical sample of Spanish-speaking adolescents. J Affect Disord. 2018 Aug 1;235:68–71. doi: 10.1016/j.jad.2018.02.035. PMID: 29655076. Exclusion Code: X2.29655076
211 Fujii C, Renno P, McLeod BD, . Intensive cognitive behavioral therapy for anxiety disorders in school-aged children with autism: A preliminary comparison with treatment-as-usual. School Mental Health. 2013;5(1):25–37. Exclusion Code: X2.
212 Gale CK, Millichamp J. Generalised anxiety disorder in children and adolescents. BMJ Clin Evid. 2016 Jan 13;2016PMID: 26763675. Exclusion Code: X7.26763675
213 Gallagher HM, Rabian BA, McCloskey MS. A brief group cognitive-behavioral intervention for social phobia in childhood. J Anxiety Disord. 2004;18(4):459–79. doi: 10.1016/S0887-6185(03)00027-6. PMID: 2004-14970-002. Exclusion Code: X13.15149708
214 Gallo KP, Chan PT, Buzzella BA, . The impact of an 8-day intensive treatment for adolescent panic disorder and agoraphobia on comorbid diagnoses. Behav Ther. 2012 Mar;43(1):153–9. doi: 10.1016/j.beth.2011.05.002. PMID: 22304887. Exclusion Code: X13.22304887
215 Garcia-Lopez L, Moore HT. Validation and Diagnostic Efficiency of the Mini-SPIN in Spanish-Speaking Adolescents. PLoS One. 2015;10(8):e0135862. doi: 10.1371/journal.pone.0135862. PMID: 26317695. Exclusion Code: X5.26317695
216 Garcia-Lopez LJ, Díaz-Castela Mdel M, Muela-Martinez JA, . Can parent training for parents with high levels of expressed emotion have a positive effect on their child’s social anxiety improvement? J Anxiety Disord. 2014 Dec;28(8):812–22. doi: 10.1016/j.janxdis.2014.09.001. PMID: 25265549. Exclusion Code: X3.25265549
217 Gardner W, Lucas A, Kolko DJ, . Comparison of the PSC-17 and alternative mental health screens in an at-risk primary care sample. J Am Acad Child Adolesc Psychiatry. 2007 May;46(5):611–8. doi: 10.1097/chi.0b013e318032384b. PMID: 17450052. Exclusion Code: X13.17450052
218 Garoff FF, Heinonen K, Pesonen A-K, . Depressed youth: treatment outcome and changes in family functioning in individual and family therapy. J Fam Ther. 2012 Feb;34(1):4–23. doi: 10.1111/j.1467-6427.2011.00541.x. PMID: 104634633. Language: English. Entry Date: 20120227. Revision Date: 20150711. Publication Type: Journal Article. Exclusion Code: X4.
219 Garrison CZ JK, Marsteller F, McKeown R, Addy C. A longitudinal study of depressive symptomatology in young adolescents. Am Acad Child Adolesc Psychiatry. 1990;29:581–5. Exclusion Code: X9.
220 Geller B, Cooper TB, Graham DL, . Pharmacokinetically designed double-blind placebo-controlled study of nortriptyline in 6- to 12-year-olds with major depressive disorder. J Am Acad Child Adolesc Psychiatry. 1992 Jan;31(1):34–44. doi: 10.1097/00004583-199201000-00007. PMID: 1537779. Exclusion Code: X3.1537779
221 Geller B, Cooper TB, McCombs HG, . Double-blind, placebo-controlled study of nortriptyline in depressed children using a “fixed plasma level” design. Psychopharmacol Bull. 1989;25(1):101–8. PMID: 2672066. Exclusion Code: X3.2672066
222 Gibbons RD, Brown CH, Hur K, . Suicidal thoughts and behavior with antidepressant treatment: reanalysis of the randomized placebo-controlled studies of fluoxetine and venlafaxine. Arch Gen Psychiatry. 2012 Jun;69(6):580–7. doi: 10.1001/archgenpsychiatry.2011.2048. PMID: 22309973. Exclusion Code: X3.22309973
223 Gibbons RD, Kupfer DJ, Frank E, . Computerized adaptive tests for rapid and accurate assessment of psychopathology dimensions in youth. J Am Acad Child Adolesc Psychiatry. 2019 Aug 26doi: 10.1016/j.jaac.2019.08.009. PMID: 31465832. Exclusion Code: X2.31465832
224 Gil-Bernal F, Hernández-Guzmán L. Cognitive-behavioural treatment in Mexican children with social phobia. Anuario de Psicología/The UB Journal of Psychology. 2009;40(1):89–104. Exclusion Code: X1.
225 Ginsburg GS, Becker KD, Drazdowski TK, . Treating anxiety disorders in inner city schools: Results from a pilot randomized controlled trial comparing CBT and usual care. Child & Youth Care Forum. 2012;41(1):1–19. doi: 10.1007/s10566-011-9156-4. PMID: 2012-02360-001. Exclusion Code: X4.22701295
226 Ginsburg GS, Becker-Haimes EM, Keeton C, . Results from the Child/Adolescent Anxiety Multimodal Extended Long-Term Study (CAMELS): primary anxiety outcomes. J Am Acad Child Adolesc Psychiatry. 2018 Jul;57(7):471–80. doi: 10.1016/j.jaac.2018.03.017. PMID: 29960692. Exclusion Code: X4.29960692
227 Ginsburg GS, Drake KL. School-based treatment for anxious african-american adolescents: a controlled pilot study. J Am Acad Child Adolesc Psychiatry. 2002 Jul;41(7):768–75. doi: 10.1097/00004583-200207000-00007. PMID: 12108800. Exclusion Code: X5.12108800
228 Ginsburg GS, Keeton CP, Drazdowski TK, . The utility of clinicians ratings of anxiety using the Pediatric Anxiety Rating Scale (PARS). Child & Youth Care Forum. 2011;40(2):93–105. doi: 10.1007/s10566-010-9125-3. PMID: 2011-06151-001. Exclusion Code: X2.
229 Gittelman-Klein R, Klein DF. School phobia: diagnostic considerations in the light of imipramine effects. J Nerv Ment Dis. 1973 Mar;156(3):199–215. PMID: 4698665. Exclusion Code: X3.4698665
230 Gladstone T, Terrizzi D, Stinson A, . Effect of internet-based cognitive behavioral humanistic and interpersonal training vs. internet-based general health education on adolescent depression in primary care: a randomized clinical trial. JAMA Netw Open. 2018 Nov;1(7)doi: 10.1001/jamanetworkopen.2018.4278. PMID: 30533601. Exclusion Code: X2.30533601
231 Gladstone TG, Marko-Holguin M, Rothberg P, . An internet-based adolescent depression preventive intervention: study protocol for a randomized control trial. Trials. 2015 May 1;16:203. doi: 10.1186/s13063-015-0705-2. PMID: 25927539. Exclusion Code: X2.25927539
232 GlaxoSmithKline. A double-blind, multicentre placebo controlled study of paroxetine in adolescents with unipolar major depression. 1998. http://cochranelibrary-wiley.com/o/cochrane/clcentral/articles/038/CN-00497038/frame.html. Exclusion Code: X3.
233 Goldbeck L, Ellerkamp T. A randomized controlled trial of multimodal music therapy for children with anxiety disorders. J Music Ther. 2012 Win 2012;49(4):395–413. doi: 10.1093/jmt/49.4.395. PMID: 2013-11365-002. Exclusion Code: X3.23705344
234 Goldney RD. Immediate post intervention effects of two brief youth suicide prevention interventions. Suicide Life Threat Behav. 2002 Winter;32(4):454; author reply -6. PMID: 12501969. Exclusion Code: X8.12501969
235 Goldschmidt K. Tele-mental health for children: using videoconferencing for Cognitive Behavioral Therapy (CBT). J Pediatr Nurs. 2016 Nov–Dec;31(6):742–4. doi: 10.1016/j.pedn.2016.09.001. PMID: 27726971. Exclusion Code: X3.27726971
236 Gonzalez A, Weersing VR, Warnick E, . Cross-ethnic measurement equivalence of the SCARED in an outpatient sample of African American and non-Hispanic White youths and parents. J Clin Child Adolesc Psychol. 2012;41(3):361–9. doi: 10.1080/15374416.2012.654462. PMID: 22397682. Exclusion Code: X2.22397682
237 Goodman R, Ford T, Simmons H, . Using the Strengths and Difficulties Questionnaire (SDQ) to screen for child psychiatric disorders in a community sample. Int Rev Psychiatry. 2003 Feb–May;15(1–2):166–72. doi: 10.1080/0954026021000046128. PMID: 12745328. Exclusion Code: X3.12745328
238 Goodyer IM, Reynolds S, Barrett B, . Cognitive behavioural therapy and short-term psychoanalytical psychotherapy versus a brief psychosocial intervention in adolescents with unipolar major depressive disorder (IMPACT): a multicentre, pragmatic, observer-blind, randomised controlled superiority trial. Lancet Psychiatry. 2017 Feb;4(2):109–19. doi: 10.1016/s2215-0366(16)30378-9. PMID: 27914903. Exclusion Code: X4.27914903
239 Gordon MS, Melvin GA. Do antidepressants make children and adolescents suicidal? J Paediatr Child Health. 2014 Nov;50(11):847–54. doi: 10.1111/jpc.12655. PMID: 24941902. Exclusion Code: X7.24941902
240 Göttken T, White LO, Klein AM, . Short-term psychoanalytic child therapy for anxious children: a pilot study. Psychotherapy (Chic). 2014 Mar;51(1):148–58. doi: 10.1037/a0036026. PMID: 24635002. Exclusion Code: X3.24635002
241 Gottlieb L, Martinovich Z, Meyers KM, . Treatment for depression enhances protection: Findings from the Treatment for Adolescents With Depression Study (TADS). Int J Cogn Ther. 2016;9(1):38–56. doi: 10.1521/ijct_2016_09_02. PMID: 2016-22581-003. Exclusion Code: X9.
242 Graae F, Milner J, Rizzotto L, . Clonazepam in childhood anxiety disorders. J Am Acad Child Adolesc Psychiatry. 1994 Mar–Apr;33(3):372–6. doi: 10.1097/00004583-199403000-00011. PMID: 8169182. Exclusion Code: X3.8169182
243 Greenfield B, Larson C, Hechtman L, . A rapid-response outpatient model for reducing hospitalization rates among suicidal adolescents. Psychiatr Serv. 2002 Dec;53(12):1574–9. doi: 10.1176/appi.ps.53.12.1574. PMID: 12461218. Exclusion Code: X2.12461218
244 Grupp-Phelan J, Stevens J, Boyd S, . Effect of a motivational interviewing-based intervention on initiation of mental health treatment and mental health after an emergency department visit among suicidal adolescents: a randomized clinical trial. JAMA Netw Open. 2019 Dec 2;2(12):e1917941. doi: 10.1001/jamanetworkopen.2019.17941. PMID: 31860104. Exclusion Code: X5.31860104
245 Grupp-Phelan J, Stevens J, Boyd S, . Effect of a motivational interviewing–based intervention on initiation of mental health treatment and mental health after an emergency department visit among suicidal adolescents: a randomized clinical trial. JAMA Network Open. 2019;2(12):e1917941–e. doi: 10.1001/jamanetworkopen.2019.17941. PMID: 140472240. Language: English. Entry Date: 20191226. Revision Date: 20200120. Publication Type: Article. Exclusion Code: X5.31860104
246 Gunlicks-Stoessel M, Westervelt A, Reigstad K, . The role of attachment style in interpersonal psychotherapy for depressed adolescents. Psychother Res. 2019 Jan;29(1):78–85. doi: 10.1080/10503307.2017.1315465. PMID: 28436756. Exclusion Code: X4.28436756
247 Gupta S, Gersing KR, Erkanli A, . Antidepressant regulatory warnings, prescription patterns, suicidality and other aggressive behaviors in major depressive disorder and anxiety disorders. Psychiatr Q. 2016 Jun;87(2):329–42. doi: 10.1007/s11126-015-9389-8. PMID: 26303613. Exclusion Code: X3.26303613
248 Gureje O, Kola L, Oladeji BD, . Responding to the challenge of Adolescent Perinatal Depression (RAPiD): protocol for a cluster randomized hybrid trial of psychosocial intervention in primary maternal care. Trials. 2020 Feb 27;21(1):231. doi: 10.1186/s13063-020-4086-9. PMID: 32106885. Exclusion Code: X11.32106885
249 Hacker KA, Arsenault LN, Williams S, . Mental and behavioral health screening at preventive visits: opportunities for follow-up of patients who are nonadherent with the next preventive visit. J Pediatr. 2011 Apr;158(4):666–71.e2. doi: 10.1016/j.jpeds.2010.09.059. PMID: 21074180. Exclusion Code: X7.21074180
250 Hale Iii WW, Raaijmakers QA, van Hoof A, . Improving screening cut-off scores for DSM-5 adolescent anxiety disorder symptom dimensions with the screen for child anxiety related emotional disorders. Psychiatry J. 2014;2014:517527. doi: 10.1155/2014/517527. PMID: 24829901. Exclusion Code: X5.24829901
251 Halldorsdottir T, Ollendick TH. Long-term outcomes of brief, intensive CBT for specific phobias: the negative impact of ADHD symptoms. J Consult Clin Psychol. 2016 May;84(5):465–71. doi: 10.1037/ccp0000088. PMID: 26900895. Exclusion Code: X2.26900895
252 Hallgren M, Kraepelien M, Öjehagen A, . Physical exercise and internet-based cognitive-behavioural therapy in the treatment of depression: randomised controlled trial. Br J Psychiatry. 2015 Sep;207(3):227–34. doi: 10.1192/bjp.bp.114.160101. PMID: 26089305. Exclusion Code: X2.26089305
253 Hammerton G, Zammit S, Potter R, . Validation of a composite of suicide items from the Mood and Feelings Questionnaire (MFQ) in offspring of recurrently depressed parents. Psychiatry Res. 2014 Apr 30;216(1):82–8. doi: 10.1016/j.psychres.2014.01.040. PMID: 24534124. Exclusion Code: X2.24534124
254 Hampe E, Noble H, Miller LC, . Phobic children one and two years posttreatment. J Abnorm Psychol. 1973 Dec;82(3):446–53. doi: 10.1037/h0035377. PMID: 4770914. Exclusion Code: X2.4770914
255 Hancock KM, Swain J, Hainsworth CJ, . Acceptance and commitment therapy versus cognitive behavior therapy for children with anxiety: outcomes of a randomized controlled trial. J Clin Child Adolesc Psychol. 2018 Mar–Apr;47(2):296–311. doi: 10.1080/15374416.2015.1110822. PMID: 26998803. Exclusion Code: X13.26998803
256 Haugen W, Haavet OR, Sirpal MK, . Identifying depression among adolescents using three key questions: a validation study in primary care. Br J Gen Pract. 2016 Feb;66(643):e65–70. doi: 10.3399/bjgp16X683461. PMID: 26823267. Exclusion Code: X13.26823267
257 Haugland BSM, Haaland Å T, Baste V, . Effectiveness of brief and standard school-based cognitive-behavioral interventions for adolescents with anxiety: a randomized noninferiority study. J Am Acad Child Adolesc Psychiatry. 2020 Apr;59(4):552–64.e2. doi: 10.1016/j.jaac.2019.12.003. PMID: 31926224. Exclusion Code: X2.31926224
258 Haugland BSM, Hysing M, Hoffart A, . Effect of early intervention for anxiety on sleep outcomes in adolescents: a randomized trial. Eur Child Adolesc Psychiatry. 2021 May 7doi: 10.1007/s00787-021-01795-6. PMID: 33961115. Exclusion Code: X2.33961115
259 Hayward C, Varady S, Albano AM, . Cognitive-behavioral group therapy for social phobia in female adolescents: results of a pilot study. J Am Acad Child Adolesc Psychiatry. 2000 Jun;39(6):721–6. doi: 10.1097/00004583-200006000-00010. PMID: 10846306. Exclusion Code: X2.10846306
260 Heiligenstein JH, Hoog SL, Wagner KD, . Fluoxetine 40-60 mg versus fluoxetine 20 mg in the treatment of children and adolescents with a less-than-complete response to nine-week treatment with fluoxetine 10-20 mg: a pilot study. J Child Adolesc Psychopharmacol. 2006 Feb–Apr;16(1–2):207–17. doi: 10.1089/cap.2006.16.207. PMID: 16553541. Exclusion Code: X4.16553541
261 Heinig I, Pittig A, Richter J, . Optimizing exposure-based CBT for anxiety disorders via enhanced extinction: design and methods of a multicentre randomized clinical trial. Int J Methods Psychiatr Res. 2017 Jun;26(2)doi: 10.1002/mpr.1560. PMID: 28322476. Exclusion Code: X4.28322476
262 Herbert JD, Gaudiano BA, Rheingold AA, . Cognitive behavior therapy for generalized social anxiety disorder in adolescents: a randomized controlled trial. J Anxiety Disord. 2009 Mar;23(2):167–77. doi: 10.1016/j.janxdis.2008.06.004. PMID: 18653310. Exclusion Code: X4.18653310
263 Hermans M, Korrelboom K, Visser S. A Dutch version of the Overall Anxiety Severity and Impairment Scale (OASIS): Psychometric properties and validation. J Affect Disord. 2015;172:127–32. doi: 10.1016/j.jad.2014.09.033. PMID: 2014-54092-020. Exclusion Code: X2.25451406
264 Hetrick SE, McKenzie JE, Bailey AP, . New generation antidepressants for depression in children and adolescents: a network meta-analysis. Cochrane Database Syst Rev. 2021 May 24;5(5):Cd013674. doi: 10.1002/14651858.CD013674.pub2. PMID: 34029378. Exclusion Code: X7.34029378
265 Hetrick SE, Yuen HP, Bailey E, . Internet-based cognitive behavioural therapy for young people with suicide-related behaviour (Reframe-IT): a randomised controlled trial. Evid Based Ment Health. 2017 Aug;20(3):76–82. doi: 10.1136/eb-2017-102719. PMID: 28701336. Exclusion Code: X13.28701336
266 Hill RM, Gushanas KL, Alvis L, . Geospatial identification of high youth suicide risk areas via electronic health records: Avenues for research and prevention efforts. Suicide Life Threat Behav. 2021 Apr;51(2):255–62. doi: 10.1111/sltb.12701. PMID: 33876482. Exclusion Code: X3.33876482
267 Hill RM, Oosterhoff B, Do C. Using machine learning to identify suicide risk: a classification tree approach to prospectively identify adolescent suicide attempters. Arch Suicide Res. 2020 Apr–Jun;24(2):218–35. doi: 10.1080/13811118.2019.1615018. PMID: 31079565. Exclusion Code: X3.31079565
268 Hirschtritt ME, Pagano ME, Christian KM, . Moderators of fluoxetine treatment response for children and adolescents with comorbid depression and substance use disorders. J Subst Abuse Treat. 2012 Jun;42(4):366–72. doi: 10.1016/j.jsat.2011.09.010. PMID: 22116008. Exclusion Code: X9.22116008
269 Hishinuma ES, Miyamoto RH, Nishimura ST, . Prediction of anxiety disorders using the state-trait anxiety inventory for multiethnic adolescents. J Anxiety Disord. 2001 Nov–Dec;15(6):511–33. doi: 10.1016/s0887-6185(01)00079-2. PMID: 11764310. Exclusion Code: X3.11764310
270 Ho D. Antidepressants and the FDA’s black-box warning: determining a rational public policy in the absence of sufficient evidence. Virtual Mentor. 2012 Jun 1;14(6):483–8. doi: 10.1001/virtualmentor.2012.14.6.pfor2-1206. PMID: 23351264. Exclusion Code: X3.23351264
271 Högberg C, Billstedt E, Björck C, . Diagnostic validity of the MINI-KID disorder classifications in specialized child and adolescent psychiatric outpatient clinics in Sweden. BMC Psychiatry. 2019 May 9;19(1):142. doi: 10.1186/s12888-019-2121-8. PMID: 31072319. Exclusion Code: X3.31072319
272 Högberg G, Antonuccio DO, Healy D. Suicidal risk from TADS study was higher than it first appeared. Int J Risk Saf Med. 2015;27(2):85–91. doi: 10.3233/jrs-150645. PMID: 26410011. Exclusion Code: X8.26410011
273 Högberg G, Hällström T. Mood regulation focused CBT based on memory reconsolidation, reduced suicidal ideation and depression in youth in a randomised controlled study. Int J Environ Res Public Health. 2018 May 5;15(5)doi: 10.3390/ijerph15050921. PMID: 29734740. Exclusion Code: X2.29734740
274 Holcomb JM, Arauz Boudreau A, Riobueno-Naylor A, . Beyond initial screening: one-year follow-up of adolescents with internalizing problems on the pediatric symptom checklist. J Dev Behav Pediatr. 2021 May 1;42(4):283–90. doi: 10.1097/dbp.0000000000000890. PMID: 33908902. Exclusion Code: X4.33908902
275 Holi MM, Pelkonen M, Karlsson L, . Detecting suicidality among adolescent outpatients: evaluation of trained clinicians’ suicidality assessment against a structured diagnostic assessment made by trained raters. BMC Psychiatry. 2008 Dec 31;8:97. doi: 10.1186/1471-244x-8-97. PMID: 19116040. Exclusion Code: X2.19116040
276 Hooper Weatherly A. Effectiveness of two psychiatric screening tools for adolescent suicide risk. Pediatr Nurs. 2019;45(4):180–3. PMID: 138187839. Language: English. Entry Date: 20190824. Revision Date: 20190827. Publication Type: Article. Exclusion Code: X2.
277 Hopper SM, Woo JW, Sharwood LN, . Prevalence of suicidality in asymptomatic adolescents in the paediatric emergency department and utility of a screening tool. Emerg Med Australas. 2012 Oct;24(5):540–6. doi: 10.1111/j.1742-6723.2012.01576.x. PMID: 23039296. Exclusion Code: X13.23039296
278 Horowitz LM, Bridge JA, Teach SJ, . Ask Suicide-Screening Questions (ASQ): a brief instrument for the pediatric emergency department. Arch Pediatr Adolesc Med. 2012 Dec;166(12):1170–6. doi: 10.1001/archpediatrics.2012.1276. PMID: 23027429. Exclusion Code: X4.23027429
279 Horowitz LM, Mournet AM, Lanzillo E, . Screening pediatric medical patients for suicide risk: is depression screening enough? J Adolesc Health. 2021 Jun;68(6):1183–8. doi: 10.1016/j.jadohealth.2021.01.028. PMID: 33712380. Exclusion Code: X2.33712380
280 Horowitz LM, Wharff EA, Mournet AM, . Validation and feasibility of the ASQ among pediatric medical and surgical inpatients. Hosp Pediatr. 2020 Sep;10(9):750–7. doi: 10.1542/hpeds.2020-0087. PMID: 32826283. Exclusion Code: X5.32826283
281 Horton SE, Hughes JL, King JD, . Preliminary examination of the interpersonal psychological theory of suicide in an adolescent clinical sample. J Abnorm Child Psychol. 2016;44(6):1133–44. doi: 10.1007/s10802-015-0109-5. PMID: 2015-56893-001. Exclusion Code: X3.26667025
282 Horwitz AG, Czyz EK, King CA. Predicting future suicide attempts among adolescent and emerging adult psychiatric emergency patients. J Clin Child Adolesc Psychol. 2015;44(5):751–61. doi: 10.1080/15374416.2014.910789. PMID: 24871489. Exclusion Code: X9.24871489
283 Hudson JL, Newall C, Rapee RM, . The impact of brief parental anxiety management on child anxiety treatment outcomes: a controlled trial. J Clin Child Adolesc Psychol. 2014;43(3):370–80. doi: 10.1080/15374416.2013.807734. PMID: 23845064. Exclusion Code: X4.23845064
284 Hudson JL, Rapee RM, Deveney C, . Cognitive-behavioral treatment versus an active control for children and adolescents with anxiety disorders: a randomized trial. J Am Acad Child Adolesc Psychiatry. 2009 May;48(5):533–44. doi: 10.1097/CHI.0b013e31819c2401. PMID: 19318990. Exclusion Code: X4.19318990
285 Hughes CW, Barnes S, Barnes C, . Depressed Adolescents Treated with Exercise (DATE): a pilot randomized controlled trial to test feasibility and establish preliminary effect sizes. Ment Health Phys Act. 2013 Jun;6(2):119–31. doi: 10.1016/j.mhpa.2013.06.006. PMID: 24244220. Exclusion Code: X4.24244220
286 Idsoe T, Keles S, Olseth AR, . Cognitive behavioral treatment for depressed adolescents: results from a cluster randomized controlled trial of a group course. BMC Psychiatry. 2019 May 22;19(1):155. doi: 10.1186/s12888-019-2134-3. PMID: 31117989. Exclusion Code: X2.31117989
287 Iftene F, Predescu E, Stefan S, . Rational-emotive and cognitive-behavior therapy (REBT/CBT) versus pharmacotherapy versus REBT/CBT plus pharmacotherapy in the treatment of major depressive disorder in youth; a randomized clinical trial. Psychiatry Res. 2015 Feb 28;225(3):687–94. doi: 10.1016/j.psychres.2014.11.021. PMID: 25500320. Exclusion Code: X4.25500320
288 In-Albon T, Dubi K, Rapee RM, . Forced choice reaction time paradigm in children with separation anxiety disorder, social phobia, and nonanxious controls. Behav Res Ther. 2009;47(12):1058–65. doi: 10.1016/j.brat.2009.08.003. PMID: 2009-15906-001. Exclusion Code: X2.19733835
289 In-Albon T, Meyer AH, Schneider S. Separation Anxiety Avoidance Inventory-Child and Parent Version: Psychometric properties and clinical utility in a clinical and school sample. Child Psychiatry Hum Dev. 2013;44(6):689–97. doi: 10.1007/s10578-013-0364-z. PMID: 2013-04319-001. Exclusion Code: X7.23385519
290 Infantino A, Donovan CL, March S. A randomized controlled trial of an audio-based treatment program for child anxiety disorders. Behav Res Ther. 2016 Apr;79:35–45. doi: 10.1016/j.brat.2016.02.007. PMID: 26950257. Exclusion Code: X13.26950257
291 Ingul JM, Aune T, Nordahl HM. A randomized controlled trial of individual cognitive therapy, group cognitive behaviour therapy and attentional placebo adolescent social phobia. Psychother Psychosom. 2014;83(1):54–61. doi: 10.1159/000354672. PMID: 2013-41405-007. Exclusion Code: X13.24281563
292 Ingul JM, Aune T, Nordahl HM. A randomized controlled trial of individual cognitive therapy, group cognitive behaviour therapy and attentional placebo for adolescent social phobia. Psychother Psychosom. 2014;83(1):54–61. doi: 10.1159/000354672. PMID: 24281563. Exclusion Code: X10.24281563
293 Iorfino F, Ho N, Carpenter JS, . Predicting self-harm within six months after initial presentation to youth mental health services: A machine learning study. PLoS One. 2020;15(12):e0243467. doi: 10.1371/journal.pone.0243467. PMID: 33382713. Exclusion Code: X3.33382713
294 Ip P, Chim D, Chan KL, . Effectiveness of a culturally attuned Internet-based depression prevention program for Chinese adolescents: A randomized controlled trial. Depress Anxiety. 2016;33(12):1123–31. doi: 10.1002/da.22554. PMID: 2016-44415-001. Exclusion Code: X5.27618799
295 Isaacs D, Nunn K. Antidepressants and suicide in adolescents. J Paediatr Child Health. 2014;50(10):836–7. doi: 10.1111/jpc.12718. PMID: 2014-42842-022. Exclusion Code: X3.
296 Isacsson G, Ahlner J. Antidepressants and the risk of suicide in young persons--prescription trends and toxicological analyses. Acta Psychiatr Scand. 2014 Apr;129(4):296–302. doi: 10.1111/acps.12160. PMID: 23773187. Exclusion Code: X3.23773187
297 Isacsson G, Ahlner J. Antidepressants and the risk of suicide in young persons—Prescription trends and toxicological analyses. Acta Psychiatr Scand. 2014;129(4):296–302. doi: 10.1111/acps.12160. PMID: 2014-09600-005. Exclusion Code: X3.23773187
298 Ishikawa S, Motomura N, Kawabata Y, . Cognitive behavioural therapy for Japanese children and adolescents with anxiety disorders: a pilot study. Behav Cogn Psychother. 2012 May;40(3):271–85. doi: 10.1017/s1352465811000713. PMID: 22217534. Exclusion Code: X4.22217534
299 Israel P, Diamond GS. Feasibility of attachment based family therapy for depressed clinic-referred Norwegian adolescents. Clin Child Psychol Psychiatry. 2013;18(3):334–50. doi: 10.1177/1359104512455811. PMID: 108668356. Language: English. Entry Date: 20160426. Revision Date: 20160426. Publication Type: Article. Exclusion Code: X4.22930777
300 Ivarsson T, Skarphedinsson G, Andersson M, . The validity of the Screen for Child Anxiety Related Emotional Disorders Revised (SCARED-R) Scale and Sub-Scales in Swedish youth. Child Psychiatry Hum Dev. 2018 Apr;49(2):234–43. doi: 10.1007/s10578-017-0746-8. PMID: 28756556. Exclusion Code: X5.28756556
301 Jacobs RH, Watkins ER, Peters AT, . Targeting ruminative thinking in adolescents at risk for depressive relapse: rumination-focused cognitive behavior therapy in a pilot randomized controlled trial with resting State fMRI. PLoS One. 2016;11(11):e0163952. doi: 10.1371/journal.pone.0163952. PMID: 27880789. Exclusion Code: X2.27880789
302 Jansen M, Bodden DHM, Muris P, . Measuring anxiety in children: the importance of separate mother and father reports. Child Youth Care Forum. 2017;46(5):643–59. doi: 10.1007/s10566-017-9402-5. PMID: 28989266. Exclusion Code: X9.28989266
303 Jansen M, van Doorn MMEM, Lichtwarck-Aschoff A, . Effectiveness of a cognitive-behavioral therapy (CBT) manualized program for clinically anxious children: study protocol of a randomized controlled trial. BMC Psychiatry. 2012;12doi: 10.1186/1471-244X-12-16. PMID: 2012-09160-001. Exclusion Code: X4.
304 Jarbin H, Ivarsson T, Andersson M, . Screening efficiency of the Mood and Feelings Questionnaire (MFQ) and Short Mood and Feelings Questionnaire (SMFQ) in Swedish help seeking outpatients. PLoS One. 2020;15(3):e0230623. doi: 10.1371/journal.pone.0230623. PMID: 32210463. Exclusion Code: X5.32210463
305 Jensen PS, Salzberg AD, Richters JE, . Scales, diagnoses, and child psychopathology: I. CBCL and DISC relationships. J Am Acad Child Adolesc Psychiatry. 1993 Mar;32(2):397–406. doi: 10.1097/00004583-199303000-00022. PMID: 8444770. Exclusion Code: X9.8444770
306 Jensen PS, Watanabe HK, Richters JE, . Scales, diagnoses, and child psychopathology: II. Comparing the CBCL and the DISC against external validators. J Abnorm Child Psychol. 1996 Apr;24(2):151–68. doi: 10.1007/bf01441482. PMID: 8743242. Exclusion Code: X7.8743242
307 Jensen-Doss A, Ehrenreich-May J, Nanda MM, . Community Study of Outcome Monitoring for Emotional Disorders in Teens (COMET): A comparative effectiveness trial of a transdiagnostic treatment and a measurement feedback system. Contemp Clin Trials. 2018 Nov;74:18–24. doi: 10.1016/j.cct.2018.09.011. PMID: 30282056. Exclusion Code: X11.30282056
308 Jeppesen P, Wolf RT, Nielsen SM, . Effectiveness of transdiagnostic cognitive-behavioral psychotherapy compared with management as usual for youth with common mental health problems: a randomized clinical trial. JAMA Psychiatry. 2021 Mar 1;78(3):250–60. doi: 10.1001/jamapsychiatry.2020.4045. PMID: 33355633. Exclusion Code: X2.33355633
309 Joe S, Scott ML, Banks A. What works for adolescent Black males at risk of suicide. Res Soc Work Pract. 2018;28(3):340–5. doi: 10.1177/1049731517702745. PMID: 128090165. Language: English. Entry Date: 20180301. Revision Date: 20180306. Publication Type: Article. Exclusion Code: X7.30546246
310 Johnco CJ, Salloum A, Lewin AB, . Refining clinical judgment of treatment response and symptom remission identification in childhood anxiety using a signal detection analysis on the Pediatric Anxiety Rating Scale. J Child Adolesc Psychopharmacol. 2015 Nov;25(9):674–83. doi: 10.1089/cap.2015.0102. PMID: 26579629. Exclusion Code: X4.26579629
311 Johnson HS, Inderbitzen-Nolan HM, Anderson ER. The social phobia inventory: validity and reliability in an adolescent community sample. Psychol Assess. 2006 Sep;18(3):269–77. doi: 10.1037/1040-3590.18.3.269. PMID: 16953730. Exclusion Code: X13.16953730
312 Johnstone JM, Luty SE, Carter JD, . Childhood neglect and abuse as predictors of antidepressant response in adult depression. Depress Anxiety. 2009;26(8):711–7. doi: 10.1002/da.20590. PMID: 19544315. Exclusion Code: X2.19544315
313 Jonovich SJ, Alpert-Gillis LJ. Impact of pediatric mental health screening on clinical discussion and referral for services. Clin Pediatr (Phila). 2014 Apr;53(4):364–71. doi: 10.1177/0009922813511146. PMID: 24302536. Exclusion Code: X9.24302536
314 Joormann J, Unnewehr S. Eine kontrollierte Studie zur Wirksamkeit einer kognitiv-verhaltenstherapeutischen Gruppentherapie bei Kindern und Jugendlichen mit Sozialer Phobie. Zeitschrift für Klinische Psychologie und Psychotherapie; Forschung und Praxis. 2002;31(4):284–90. Exclusion Code: X1.
315 Julious SA. Efficacy and suicidal risk for antidepressants in paediatric and adolescent patients. Stat Methods Med Res. 2013 Apr;22(2):190–218. doi: 10.1177/0962280211432210. PMID: 22267546. Exclusion Code: X7.22267546
316 Kaess M, Edinger A, Fischer-Waldschmidt G, . Effectiveness of a brief psychotherapeutic intervention compared with treatment as usual for adolescent nonsuicidal self-injury: a single-centre, randomised controlled trial. Eur Child Adolesc Psychiatry. 2020 Jun;29(6):881–91. doi: 10.1007/s00787-019-01399-1. PMID: 31512050. Exclusion Code: X2.31512050
317 Kaess M, Koenig J, Bauer S, . Self-injury: Treatment, Assessment, Recovery (STAR): online intervention for adolescent non-suicidal self-injury - study protocol for a randomized controlled trial. Trials. 2019 Jul 12;20(1):425. doi: 10.1186/s13063-019-3501-6. PMID: 31300065. Exclusion Code: X11.31300065
318 Kaess M, Schnyder N, Michel C, . Twelve-month service use, suicidality and mental health problems of European adolescents after a school-based screening for current suicidality. Eur Child Adolesc Psychiatry. 2020 Dec 15doi: 10.1007/s00787-020-01681-7. PMID: 33320300. Exclusion Code: X9.33320300
319 Kampmann IL, Emmelkamp PM, Hartanto D, . Exposure to virtual social interactions in the treatment of social anxiety disorder: A randomized controlled trial. Behav Res Ther. 2016 Feb;77:147–56. doi: 10.1016/j.brat.2015.12.016. PMID: 26752328. Exclusion Code: X2.26752328
320 Kantor JE, Walker CE, Hays L. A study of the usefulness of Lanyon’s Psychological Screening Inventory with adolescents. J Consult Clin Psychol. 1976 Jun;44(3):313–6. doi: 10.1037//0022-006x.44.3.313. PMID: 932260. Exclusion Code: X3.932260
321 Karabekiroglu K, Karakurt MN, Yuce M, . Fluoxetine for the Treatment of Childhood and Adolescence Social Phobia: Factors playing a role in Efficacy. Klinik Psikofarmakoloji Bülteni-Bulletin of Clinical Psychopharmacology. 2011;21(4):317–24. Exclusion Code: X4.
322 Katon W, Russo J, Richardson L, . Anxiety and depression screening for youth in a primary care population. Ambul Pediatr. 2008 May–Jun;8(3):182–8. doi: 10.1016/j.ambp.2008.01.003. PMID: 18501865. Exclusion Code: X13.18501865
323 Keeton CP, Caporino NE, Kendall PC, . Mood and suicidality outcomes 3–11 years following pediatric anxiety disorder treatment. Depress Anxiety. 2019;36(10):930–40. doi: 10.1002/da.22944. PMID: 2019-44452-001. Exclusion Code: X9.31356713
324 Keeton CP, Ginsburg GS, Drake KL, . Benefits of child-focused anxiety treatments for parents and family functioning. Depress Anxiety. 2013 Sep;30(9):865–72. doi: 10.1002/da.22055. PMID: 23390005. Exclusion Code: X9.23390005
325 Keles S, Idsoe T. Six- and twelve-month follow-up results of a cluster randomized controlled trial of a CBT-based group course. Prev Sci. 2021 May;22(4):409–18. doi: 10.1007/s11121-020-01160-0. PMID: 32889703. Exclusion Code: X2.32889703
326 Keller MB, Ryan ND, Strober M, . Efficacy of paroxetine in the treatment of adolescent major depression: a randomized, controlled trial. J Am Acad Child Adolesc Psychiatry. 2001 Jul;40(7):762–72. doi: 10.1097/00004583-200107000-00010. PMID: 11437014. Exclusion Code: X3.11437014
327 Kendall PC. Treating anxiety disorders in children: results of a randomized clinical trial. J Consult Clin Psychol. 1994;62(1):100. Exclusion Code: X13.8034812
328 Kendall PC, Cummings CM, Villabø MA, . Mediators of change in the Child/Adolescent Anxiety Multimodal Treatment Study. J Consult Clin Psychol. 2016 Jan;84(1):1–14. doi: 10.1037/a0039773. PMID: 26460572. Exclusion Code: X9.26460572
329 Kendall PC, Flannery-Schroeder E, Panichelli-Mindel SM, . Therapy for youths with anxiety disorders: a second randomized clinical trial. J Consult Clin Psychol. 1997 Jun;65(3):366–80. doi: 10.1037//0022-006x.65.3.366. PMID: 9170760. Exclusion Code: X13.9170760
330 Kendall PC, Hudson JL, Gosch E, . Cognitive-behavioral therapy for anxiety disordered youth: A randomized clinical trial evaluating child and family modalities. J Consult Clin Psychol. 2008;76(2):282–97. doi: 10.1037/0022-006X.76.2.282. PMID: 2008-03290-010. Exclusion Code: X4.18377124
331 Kennard BD, Emslie GJ, Mayes TL, . Sequential treatment with fluoxetine and relapse-prevention CBT to improve outcomes in pediatric depression. Am J Psychiatry. 2014 Oct;171(10):1083–90. doi: 10.1176/appi.ajp.2014.13111460. PMID: 24935082. Exclusion Code: X3.24935082
332 Kennard BD, Emslie GJ, Mayes TL, . Cognitive-behavioral therapy to prevent relapse in pediatric responders to pharmacotherapy for major depressive disorder. J Am Acad Child Adolesc Psychiatry. 2008 Dec;47(12):1395–404. doi: 10.1097/CHI.0b013e31818914a1. PMID: 18978634. Exclusion Code: X2.18978634
333 Kennard BD, Mayes TL, Chahal Z, . Predictors and moderators of relapse in children and adolescents with major depressive disorder. J Clin Psychiatry. 2018 Mar/Apr;79(2)doi: 10.4088/JCP.15m10330. PMID: 29474007. Exclusion Code: X9.29474007
334 Kent L, Vostanis P, Feehan C. Detection of major and minor depression in children and adolescents: evaluation of the Mood and Feelings Questionnaire. J Child Psychol Psychiatry. 1997 Jul;38(5):565–73. doi: 10.1111/j.1469-7610.1997.tb01543.x. PMID: 9255700. Exclusion Code: X2.9255700
335 Kerker BD, Chor KH, Hoagwood KE, . Detection and treatment of mental health issues by pediatric PCPs in New York State: an evaluation of Project TEACH. Psychiatr Serv. 2015 Apr 1;66(4):430–3. doi: 10.1176/appi.ps.201400079. PMID: 25828984. Exclusion Code: X9.25828984
336 Kersun LS, Shemesh E. Depression and anxiety in children at the end of life. Pediatr Clin North Am. 2007 Oct;54(5):691–708, xi. doi: 10.1016/j.pcl.2007.06.003. PMID: 17933618. Exclusion Code: X8.17933618
337 Khanna MS, Kendall PC. Computer-assisted cognitive behavioral therapy for child anxiety: results of a randomized clinical trial. J Consult Clin Psychol. 2010;78(5):737–45. doi: 10.1037/a0019739. PMID: 2010-19874-014. Exclusion Code: X13.20873909
338 Kim SM, Han DH, Lee YS, . Combined cognitive behavioral therapy and bupropion for the treatment of problematic on-line game play in adolescents with major depressive disorder. Comput Human Behav. 2012;28(5):1954–9. PMID: CN-00853199. Exclusion Code: X3.
339 King CA, Brent D, Grupp-Phelan J, . Prospective Development and Validation of the Computerized Adaptive Screen for Suicidal Youth. JAMA Psychiatry. 2021 May 1;78(5):540–9. doi: 10.1001/jamapsychiatry.2020.4576. PMID: 33533908. Exclusion Code: X4.33533908
340 King CA, Kramer A, Preuss L, . Youth-Nominated Support Team for Suicidal Adolescents (Version 1): a randomized controlled trial. J Consult Clin Psychol. 2006 Feb;74(1):199–206. doi: 10.1037/0022-006x.74.1.199. PMID: 16551158. Exclusion Code: X2.16551158
341 King CD, Joyce VW, Kleiman EM, . Relevance of the interpersonal theory of suicide in an adolescent psychiatric inpatient population. Psychiatry Res. 2019 Nov;281:112590. doi: 10.1016/j.psychres.2019.112590. PMID: 31634732. Exclusion Code: X9.31634732
342 Kitchen CEW, Tiffin PA, Lewis S, . Innovations in Practice: A randomised controlled feasibility trial of Behavioural Activation as a treatment for young people with depression. Child Adolesc Ment Health. 2020 Jul 28doi: 10.1111/camh.12415. PMID: 32725758. Exclusion Code: X4.32725758
343 Klein AM, Rapee RM, Hudson JL, . Interpretation modification training reduces social anxiety in clinically anxious children. Behav Res Ther. 2015 Dec;75:78–84. doi: 10.1016/j.brat.2015.10.006. PMID: 26580081. Exclusion Code: X4.26580081
344 Klein DN, Arnow BA, Barkin JL, . Early adversity in chronic depression: clinical correlates and response to pharmacotherapy. Depress Anxiety. 2009;26(8):701–10. doi: 10.1002/da.20577. PMID: 19434623. Exclusion Code: X2.19434623
345 Klein RG, Koplewicz HS, Kanner A. Imipramine treatment of children with separation anxiety disorder. J Am Acad Child Adolesc Psychiatry. 1992 Jan;31(1):21–8. doi: 10.1097/00004583-199201000-00005. PMID: 1347039. Exclusion Code: X3.1347039
346 Klein RG, Mannuzza S, Koplewicz HS, . Adolescent depression: controlled desipramine treatment and atypical features. Depress Anxiety. 1998;7(1):15–31. PMID: 9592629. Exclusion Code: X3.9592629
347 Knepley MJ, Kendall PC, Carper MM. An analysis of the Child Behavior Checklist Anxiety Problems Scale’s predictive capabilities. J Psychopathol Behav Assess. 2019 Jun;41(2):249–56. doi: 10.1007/s10862-019-09722-5. PMID: 31666760. Exclusion Code: X2.31666760
348 Kocovski NL, Fleming JE, Blackie RA, . Self-help for social anxiety: Randomized controlled trial comparing a mindfulness and acceptance-based approach with a control group. Behav Ther. 2019;50(4):696–709. doi: 10.1016/j.beth.2018.10.007. PMID: 2018-63223-001. Exclusion Code: X2.31208680
349 Kodal A, Fjermestad K, Bjelland I, . Long-term effectiveness of cognitive behavioral therapy for youth with anxiety disorders. J Anxiety Disord. 2018 Jan;53:58–67. doi: 10.1016/j.janxdis.2017.11.003. PMID: 29195188. Exclusion Code: X4.29195188
350 Kohlhoff J, Morgan S, Briggs N, . Parent-Child Interaction Therapy with Toddlers: A community-based randomized controlled trial with children aged 14-24 months. J Clin Child Adolesc Psychol. 2020 Feb 20:1–16. doi: 10.1080/15374416.2020.1723599. PMID: 32078379. Exclusion Code: X2.32078379
351 Kohtala A, Muotka J, Lappalainen R. What happens after five years?: The long-term effects of a four-session Acceptance and Commitment Therapy delivered by student therapists for depressive symptoms. Journal of Contextual Behavioral Science. 2017;6(2):230–8. doi: 10.1016/j.jcbs.2017.03.003. PMID: 2017-23116-016. Exclusion Code: X2.
352 Kolko DJ, Campo J, Kilbourne AM, . Collaborative care outcomes for pediatric behavioral health problems: A cluster randomized trial. Pediatrics. 2014;133(4):e981–e92. doi: 10.1542/peds.2013-2516. PMID: 2014-12692-007. Exclusion Code: X2.24664093
353 Kozina A. School-based prevention of anxiety using the “My FRIENDS” emotional resilience program: Six-month follow-up. Int J Psychol. 2020 Jan;55 Suppl 1:70–7. doi: 10.1002/ijop.12553. PMID: 30511384. Exclusion Code: X2.30511384
354 Kratochvil C, Emslie G, Silva S, . Acute time to response in the Treatment for Adolescents with Depression Study (TADS). J Am Acad Child Adolesc Psychiatry. 2006 Dec;45(12):1412–8. doi: 10.1097/01.chi.0000237710.73755.14. PMID: 17135986. Exclusion Code: X9.17135986
355 Kratochvil CJ, May DE, Silva SG, . Treatment response in depressed adolescents with and without co-morbid attention-deficit/hyperactivity disorder in the Treatment for Adolescents with Depression Study. J Child Adolesc Psychopharmacol. 2009 Oct;19(5):519–27. doi: 10.1089/cap.2008.0143. PMID: 19877976. Exclusion Code: X4.19877976
356 Krause KR, Bear HA, Edbrooke-Childs J, . Review: What outcomes count? a review of outcomes measured for adolescent depression between 2007 and 2017. J Am Acad Child Adolesc Psychiatry. 2019 Jan;58(1):61–71. doi: 10.1016/j.jaac.2018.07.893. PMID: 30577940. Exclusion Code: X8.30577940
357 Kumara H, Kumar V. Impact of Cognitive Behavior Therapy on anxiety and depression in adolescent students. Journal of Psychosocial Research. 2016;11(1):77–85. PMID: 2016-32553-008. Exclusion Code: X2.
358 Kye CH, Waterman GS, Ryan ND, . A randomized, controlled trial of amitriptyline in the acute treatment of adolescent major depression. J Am Acad Child Adolesc Psychiatry. 1996 Sep;35(9):1139–44. doi: 10.1097/00004583-199609000-00011. PMID: 8824057. Exclusion Code: X3.8824057
359 Langer DA, Wood JJ, Bergman RL, . A multitrait–multimethod analysis of the construct validity of child anxiety disorders in a clinical sample. Child Psychiatry Hum Dev. 2010;41(5):549–61. doi: 10.1007/s10578-010-0187-0. PMID: 2010-16653-007. Exclusion Code: X9.20443053
360 Langley AK, Bergman RL, McCracken J, . Impairment in Childhood Anxiety Disorders: Preliminary Examination of the Child Anxiety Impact Scale-Parent Version. J Child Adolesc Psychopharmacol. 2004 Spr 2004;14(1):105–14. doi: 10.1089/104454604773840544. PMID: 2004-14085-015. Exclusion Code: X9.15142397
361 Langner TS, Gersten JC, McCarthy ED, . A screening inventory for assessing psychiatric impairment in children 6 to 18. J Consult Clin Psychol. 1976 Apr;44(2):286–96. doi: 10.1037//0022-006x.44.2.286. PMID: 1254763. Exclusion Code: X4.1254763
362 Last CG, Hansen C, Franco N. Cognitive-behavioral treatment of school phobia. J Am Acad Child Adolesc Psychiatry. 1998 Apr;37(4):404–11. doi: 10.1097/00004583-199804000-00018. PMID: 9549961. Exclusion Code: X13.9549961
363 Laurent J, Hadler JR, Stark KD. A multiple-stage screening procedure for the identification of childhood anxiety disorders. Sch Psychol Q. 1994 Win 1994;9(4):239–55. doi: 10.1037/h0088291. PMID: 1995-33371-001. Exclusion Code: X2.
364 Le Noury J, Nardo JM, Healy D, . Restoring Study 329: efficacy and harms of paroxetine and imipramine in treatment of major depression in adolescence. BMJ. 2015 Sep 16;351:h4320. doi: 10.1136/bmj.h4320. PMID: 26376805. Exclusion Code: X3.26376805
365 Le Noury J, Nardo JM, Healy D, . Study 329 continuation phase: Safety and efficacy of paroxetine and imipramine in extended treatment of adolescent major depression. Int J Risk Saf Med. 2016 Sep 17;28(3):143–61. doi: 10.3233/jrs-160728. PMID: 27662279. Exclusion Code: X3.27662279
366 Le T, Gobert J. Translating and Implementing a Mindfulness-Based Youth Suicide Prevention Intervention in a Native American Community. Journal of Child & Family Studies. 2015;24(1):12–23. doi: 10.1007/s10826-013-9809-z. PMID: 103870905. Language: English. Entry Date: 20150108. Revision Date: 20150710. Publication Type: Journal Article. Exclusion Code: X4.
367 Lee CS, Williamson LR, Martin SE, . Adverse events in very young children prescribed psychotropic medications: Preliminary findings from an acute clinical sample. J Child Adolesc Psychopharmacol. 2015;25(6):509–13. doi: 10.1089/cap.2015.0034. PMID: 2015-37545-008. Exclusion Code: X2.26262905
368 Lee H, Zerr A, Dickerson JF, . Brief behavioral therapy for anxiety and depression in pediatric primary care: uptake of intervention and community services by ethnic minority families. Journal of the american academy of child and adolescent psychiatry. Conference: 63rd annual meeting of the american academy of child and adolescent psychiatry. United states. Conference start: 20161024. Conference end: 20161029. 2016;55(10 Supplement 1):S181. doi: 10.1016/j.jaac.2016.09.252. PMID: CN-01304638. Exclusion Code: X9.
369 Leenarts LE, Dölitzsch C, Schmeck K, . Relationship between Massachusetts Youth Screening Instrument-second version and psychiatric disorders in youths in welfare and juvenile justice institutions in Switzerland. BMC Psychiatry. 2016 Sep 30;16(1):340. doi: 10.1186/s12888-016-1032-1. PMID: 27716175. Exclusion Code: X3.27716175
370 Leikanger E, Larsson B. One-year stability, change and incidence in anxiety symptoms among early adolescents in the general population. Eur Child Adolesc Psychiatry. 2012 Sep;21(9):493–501. doi: 10.1007/s00787-012-0284-7. PMID: 22562142. Exclusion Code: X3.22562142
371 LeMoult J, Colich N, Joormann J, . Interpretation bias training in depressed adolescents: near- and far-transfer effects. J Abnorm Child Psychol. 2018 Jan;46(1):159–67. doi: 10.1007/s10802-017-0285-6. PMID: 28299526. Exclusion Code: X4.28299526
372 Lepola U, Leinonen E, Koponen H. Citalopram in the treatment of early-onset panic disorder and school phobia. Pharmacopsychiatry. 1996 Jan;29(1):30–2. doi: 10.1055/s-2007-979539. PMID: 8852532. Exclusion Code: X3.8852532
373 Leslie KR, Chike-Harris K. Patient-administered screening tool may improve detection and diagnosis of depression among adolescents. Clin Pediatr (Phila). 2018 Apr;57(4):457–60. doi: 10.1177/0009922817730343. PMID: 28950718. Exclusion Code: X9.28950718
374 Lewandowski RE, O’Connor B, Bertagnolli A, . Screening for and diagnosis of depression among adolescents in a large health Maintenance organization. Psychiatr Serv. 2016 Jun 1;67(6):636–41. doi: 10.1176/appi.ps.201400465. PMID: 26876655. Exclusion Code: X4.26876655
375 Lewis CC, Simons AD, Nguyen LJ, . Impact of childhood trauma on treatment outcome in the Treatment for Adolescents with Depression Study (TADS). J Am Acad Child Adolesc Psychiatry. 2010 Feb;49(2):132–40. doi: 10.1097/00004583-201002000-00007. PMID: 20215935. Exclusion Code: X9.20215935
376 Liber JM, Widenfelt BM, Leeden AJM, . The relation of severity and comorbidity to treatment outcome with cognitive behavioral therapy for childhood anxiety disorders. J Abnorm Child Psychol. 2010;38(5):683–94. doi: 10.1007/s10802-010-9394-1. PMID: 2010-11658-011. Exclusion Code: X4.20180011
377 Lieberman AF, Ghosh Ippen C, P VANH. Child-parent psychotherapy: 6-month follow-up of a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2006 Aug;45(8):913–8. doi: 10.1097/01.chi.0000222784.03735.92. PMID: 16865033. Exclusion Code: X4.16865033
378 Linetzky M, Kahn M, Lazarov A, . Gaze-contingent music reward therapy for clinically anxious 7- to 10-year-olds: An open multiple baseline feasibility study. J Clin Child Adolesc Psychol. 2020;49(5):618–25. doi: 10.1080/15374416.2019.1573685. PMID: 2019-17132-001. Exclusion Code: X3.30908085
379 Lish JD, Weissman MM, Adams PB, . Family psychiatric screening instruments for epidemiologic studies: pilot testing and validation. Psychiatry Res. 1995 Jul 28;57(2):169–80. doi: 10.1016/0165-1781(95)02632-7. PMID: 7480383. Exclusion Code: X3.7480383
380 Lois BH, Urban TH, Wong C, . Integrating Suicide Risk Screening into Pediatric Ambulatory Subspecialty Care. Pediatr Qual Saf. 2020 May–Jun;5(3):e310. doi: 10.1097/pq9.0000000000000310. PMID: 32656472. Exclusion Code: X4.32656472
381 Looyeh MY, Kamali K, Ghasemi A, . Treating social phobia in children through group narrative therapy. The arts in psychotherapy. 2014;41(1):16–20. Exclusion Code: X3.
382 Lorentzen V, Fagermo K, Handegård BH, . A randomized controlled trial of a six-session cognitive behavioral treatment of emotional disorders in adolescents 14-17 years old in child and adolescent mental health services (CAMHS). BMC Psychol. 2020 Mar 14;8(1):25. doi: 10.1186/s40359-020-0393-x. PMID: 32171328. Exclusion Code: X2.32171328
383 Lorenzo-Luaces L, Rodriguez-Quintana N, Bailey AJ. Double trouble: Do symptom severity and duration interact to predicting treatment outcomes in adolescent depression? Behav Res Ther. 2020 Aug;131:103637. doi: 10.1016/j.brat.2020.103637. PMID: 32413595. Exclusion Code: X9.32413595
384 Loucas CE, Sclare I, Stahl D, . Feasibility randomized controlled trial of a one-day CBT workshop (‘DISCOVER’) for 15- to 18-year-olds with anxiety and/or depression in clinic settings. Behav Cogn Psychother. 2020 Mar;48(2):142–59. doi: 10.1017/s1352465819000286. PMID: 31106728. Exclusion Code: X2.31106728
385 Lu L, Mills JA, Li H, . Acute Neurofunctional Effects of Escitalopram in Pediatric Anxiety: A Double-Blind, Placebo-Controlled Trial. J Am Acad Child Adolesc Psychiatry. 2021 Feb 4doi: 10.1016/j.jaac.2020.11.023. PMID: 33548492. Exclusion Code: X9.33548492
386 Luby J. A Randomized Controlled Trial of Parent–Child Psychotherapy in Early Childhood Depression. J Am Acad Child Adolesc Psychiatry. 2018;57(10):S289-. doi: 10.1016/j.jaac.2018.07.691. PMID: CN-01653014. Exclusion Code: X8.
387 Luby J, Lenze S, Tillman R. A novel early intervention for preschool depression: findings from a pilot randomized controlled trial. J Child Psychol Psychiatry. 2012 Mar;53(3):313–22. doi: 10.1111/j.1469-7610.2011.02483.x. PMID: 22040016. Exclusion Code: X4.22040016
388 Luby JL, Gilbert K, Whalen D, . The differential contribution of the components of parent-child interaction therapy emotion development for treatment of preschool depression. J Am Acad Child Adolesc Psychiatry. 2019 Jul 31doi: 10.1016/j.jaac.2019.07.937. PMID: 31376501. Exclusion Code: X9.31376501
389 Luntamo T, Korpilahti-Leino T, Ristkari T, . Internet-assisted cognitive behavioural therapy with telephone coaching for anxious Finnish children aged 10-13 years: study protocol for a randomised controlled trial. BMJ Open. 2021 Jun 23;11(6):e045474. doi: 10.1136/bmjopen-2020-045474. PMID: 34162641. Exclusion Code: X2.34162641
390 Lynch FL, Dickerson JF, Rozenman MS, . Cost-effectiveness of brief behavioral therapy for pediatric anxiety and depression in primary care. JAMA Netw Open. 2021 Mar 1;4(3):e211778. doi: 10.1001/jamanetworkopen.2021.1778. PMID: 33720373. Exclusion Code: X7.33720373
391 Manassis K, Mendlowitz SL, Scapillato D, . Group and individual cognitive-behavioral therapy for childhood anxiety disorders: a randomized trial. J Am Acad Child Adolesc Psychiatry. 2002 Dec;41(12):1423–30. doi: 10.1097/00004583-200212000-00013. PMID: 12447028. Exclusion Code: X3.12447028
392 Mancini C, Van Ameringen M, Oakman JM, . Serotonergic agents in the treatment of social phobia in children and adolescents: a case series. Depress Anxiety. 1999;10(1):33–9. doi: 10.1002/(sici)1520-6394(1999)10:1<33::aid-da6>3.0.co;2-h. PMID: 10499188. Exclusion Code: X7.10499188
393 Mandoki MW, Tapia MR, Tapia MA, . Venlafaxine in the treatment of children and adolescents with major depression. Psychopharmacol Bull. 1997;33(1):149–54. PMID: 9133767. Exclusion Code: X3.9133767
394 March JS, Entusah AR, Rynn M, . A randomized controlled trial of venlafaxine ER versus placebo in pediatric social anxiety disorder. Biol Psychiatry. 2007 Nov 15;62(10):1149–54. doi: 10.1016/j.biopsych.2007.02.025. PMID: 17553467. Exclusion Code: X3.17553467
395 March S, Spence SH, Donovan CL. The efficacy of an internet-based cognitive-behavioral therapy intervention for child anxiety disorders. J Pediatr Psychol. 2009 Jun;34(5):474–87. doi: 10.1093/jpepsy/jsn099. PMID: 18794187. Exclusion Code: X13.18794187
396 Martínez V, Rojas G, Martínez P, . Computer-Assisted Cognitive-Behavioral Therapy to Treat Adolescents With Depression in Primary Health Care Centers in Santiago, Chile: A Randomized Controlled Trial. Front Psychiatry. 2019;10:552. doi: 10.3389/fpsyt.2019.00552. PMID: 31417440. Exclusion Code: X4.31417440
397 Martins Cde S, Motta JV, Quevedo LA, . Comparison of two instruments to track depression symptoms during pregnancy in a sample of pregnant teenagers in Southern Brazil. J Affect Disord. 2015 May 15;177:95–100. doi: 10.1016/j.jad.2015.01.051. PMID: 25754606. Exclusion Code: X6.25754606
398 Martinsen KD, Rasmussen LMP, Wentzel-Larsen T, . Prevention of anxiety and depression in school children: Effectiveness of the transdiagnostic EMOTION program. J Consult Clin Psychol. 2019 Feb;87(2):212–9. doi: 10.1037/ccp0000360. PMID: 30550301. Exclusion Code: X2.30550301
399 Masi G, Toni C, Mucci M, . Paroxetine in child and adolescent outpatients with panic disorder. J Child Adolesc Psychopharmacol. 2001 Summer;11(2):151–7. doi: 10.1089/104454601750284054. PMID: 11436954. Exclusion Code: X3.11436954
400 Masia Warner C, Colognori D, Brice C, . Can school counselors deliver cognitive-behavioral treatment for social anxiety effectively? A randomized controlled trial. J Child Psychol Psychiatry. 2016 Nov;57(11):1229–38. doi: 10.1111/jcpp.12550. PMID: 27002215. Exclusion Code: X4.27002215
401 Mathyssek CM, Olino TM, Hartman CA, . Does the Revised Child Anxiety and Depression Scale (RCADS) measure anxiety symptoms consistently across adolescence? The TRAILS study. Int J Methods Psychiatr Res. 2013 Mar;22(1):27–35. doi: 10.1002/mpr.1380. PMID: 23483654. Exclusion Code: X4.23483654
402 Mayne SL, Hannan C, Davis M, . COVID-19 and adolescent depression and suicide risk screening outcomes. Pediatrics. 2021 Jun 17doi: 10.1542/peds.2021-051507. PMID: 34140393. Exclusion Code: X9.34140393
403 McCarty CA, Zatzick DF, Marcynyszyn LA, . Effect of Collaborative Care on Persistent Postconcussive Symptoms in Adolescents: A Randomized Clinical Trial. JAMA Netw Open. 2021 Feb 1;4(2):e210207. doi: 10.1001/jamanetworkopen.2021.0207. PMID: 33635325. Exclusion Code: X2.33635325
404 McCauley E, Berk MS, Asarnow JR, . Efficacy of Dialectical Behavior Therapy for Adolescents at High Risk for Suicide: A Randomized Clinical Trial. JAMA Psychiatry. 2018 Aug 1;75(8):777–85. doi: 10.1001/jamapsychiatry.2018.1109. PMID: 29926087. Exclusion Code: X4.29926087
405 McGrath PJ, Lingley-Pottie P, Thurston C, . Telephone-based mental health interventions for child disruptive behavior or anxiety disorders: Randomized trials and overall analysis. J Am Acad Child Adolesc Psychiatry. 2011;50(11):1162–72. doi: 10.1016/j.jaac.2011.07.013. PMID: 2011-24630-015. Exclusion Code: X7.22024004
406 McLoone JK, Rapee RM. Comparison of an anxiety management program for children implemented at home and school: Lessons learned. School Mental Health: A Multidisciplinary Research and Practice Journal. 2012;4(4):231–42. doi: 10.1007/s12310-012-9088-7. PMID: 2012-31811-005. Exclusion Code: X5.
407 McNally Keehn RH, Lincoln AJ, Brown MZ, . The Coping Cat program for children with anxiety and autism spectrum disorder: a pilot randomized controlled trial. J Autism Dev Disord. 2013 Jan;43(1):57–67. doi: 10.1007/s10803-012-1541-9. PMID: 22588377. Exclusion Code: X2.22588377
408 Mehlum L. Dialectical behavior therapy (DBT) for adolescents with repeated suicidal behavior - a randomized controlled study. In press. 2012 PMID: CN-01038538. Exclusion Code: X8.
409 Mehlum L, Ramleth RK, Tørmoen AJ, . Long term effectiveness of dialectical behavior therapy versus enhanced usual care for adolescents with self-harming and suicidal behavior. Journal of Child Psychology & Psychiatry. 2019;60(10):1112–22. doi: 10.1111/jcpp.13077. PMID: 138570161. Language: English. Entry Date: 20190914. Revision Date: 20190924. Publication Type: Article. Exclusion Code: X10.31127612
410 Melfsen S, Kühnemund M, Schwieger J, . Cognitive behavioral therapy of socially phobic children focusing on cognition: a randomised wait-list control study. Child Adolesc Psychiatry Ment Health. 2011 Feb 28;5(1):5. doi: 10.1186/1753-2000-5-5. PMID: 21356037. Exclusion Code: X13.21356037
411 Melvin GA, Dudley AL, Gordon MS, . Augmenting Cognitive Behavior Therapy for School Refusal with Fluoxetine: A Randomized Controlled Trial. Child Psychiatry Hum Dev. 2017 Jun;48(3):485–97. doi: 10.1007/s10578-016-0675-y. PMID: 27485100. Exclusion Code: X4.27485100
412 Melvin GA, Finnin L, Taffe J, . Adverse events reported by anxious school refusing adolescents receiving cognitive behavioral therapy with and without fluoxetine. Clin Child Psychol Psychiatry. 2019 Oct;24(4):892–905. doi: 10.1177/1359104518822681. PMID: 30638065. Exclusion Code: X4.30638065
413 Melvin GA, Tonge BJ, King NJ, . A comparison of cognitive-behavioral therapy, sertraline, and their combination for adolescent depression. J Am Acad Child Adolesc Psychiatry. 2006 Oct;45(10):1151–61. doi: 10.1097/01.chi.0000233157.21925.71. PMID: 17003660. Exclusion Code: X4.17003660
414 Mendez X, Orgiles, . . Psychological treatment of the phobia of the dark in a game situation: A controlled essay. . Revista de Psicopatologia y Psicologia Clinica. 2003 Dec;8(3):199–210. PMID: 2004-12003-002. Exclusion Code: X1.
415 Mendlowitz SL, Manassis K, Bradley S, . Cognitive-behavioral group treatments in childhood anxiety disorders: the role of parental involvement. J Am Acad Child Adolesc Psychiatry. 1999 Oct;38(10):1223–9. doi: 10.1097/00004583-199910000-00010. PMID: 10517054. Exclusion Code: X4.10517054
416 Mennin DS, Fresco DM, Heimberg RG, . Screening for social anxiety disorder in the clinical setting: using the Liebowitz Social Anxiety Scale. J Anxiety Disord. 2002;16(6):661–73. doi: 10.1016/s0887-6185(02)00134-2. PMID: 12405524. Exclusion Code: X2.12405524
417 Menzies RG, Clarke JC. A comparison of in vivo and vicarious exposure in the treatment of childhood water phobia. Behav Res Ther. 1993 Jan;31(1):9–15. doi: 10.1016/0005-7967(93)90037-u. PMID: 8093340. Exclusion Code: X2.8093340
418 Michalak J, Probst T, Heidenreich T, . Mindfulness-Based Cognitive Therapy and a Group Version of the Cognitive Behavioral Analysis System of Psychotherapy for Chronic Depression: follow-Up Data of a Randomized Controlled Trial and the Moderating Role of Childhood Adversities. Psychother Psychosom. 2016;85(6):378–80. doi: 10.1159/000447014. PMID: CN-01342394. Exclusion Code: X2.27744451
419 Miché M, Studerus E, Meyer AH, . Prospective prediction of suicide attempts in community adolescents and young adults, using regression methods and machine learning. J Affect Disord. 2020;265:570–8. doi: 10.1016/j.jad.2019.11.093. PMID: 2019-74053-001. Exclusion Code: X3.31786028
420 Miller IW, Camargo CA, Jr., Arias SA, . Suicide Prevention in an Emergency Department Population: The ED-SAFE Study. JAMA Psychiatry. 2017 Jun 1;74(6):563–70. doi: 10.1001/jamapsychiatry.2017.0678. PMID: 28456130. Exclusion Code: X7.28456130
421 Miller LC, Barrett CL, Hampe E, . Comparison of reciprocal inhibition, psychotherapy, and waiting list control for phobic children. J Abnorm Psychol. 1972 Jun;79(3):269–79. doi: 10.1037/h0033224. PMID: 5033367. Exclusion Code: X3.5033367
422 Miniati M, Rucci P, Benvenuti A, . Clinical characteristics and treatment outcome of depression in patients with and without a history of emotional and physical abuse. J Psychiatr Res. 2010 Apr;44(5):302–9. doi: 10.1016/j.jpsychires.2009.09.008. PMID: 19800634. Exclusion Code: X7.19800634
423 Moharreri F, Heydari Yazdi AS. Evaluation of the Effectiveness of the Friends for Life Program on Children’s Anxiety and Depression. Iran J Psychiatry. 2017 Oct;12(4):272–80. PMID: 29472954. Exclusion Code: X6.29472954
424 Moller C, Petermann, . Short- and long-term effects of a cognitive-behavioural training programme for children with social anxiety. [German]. . Verhaltenstherapie. . 2011;21(1):15–22. PMID: 2011134836. Exclusion Code: X1.
425 Möller EL, Majdandžić M, Craske MG, . Dimensional assessment of anxiety disorders in parents and children for DSM-5. Int J Methods Psychiatr Res. 2014;23(3):331–44. doi: 10.1002/mpr.1450. PMID: 2014-25478-001. Exclusion Code: X9.24943058
426 Monga S, Rosenbloom BN, Tanha A, . Comparison of child-parent and parent-only cognitive-behavioral therapy programs for anxious children aged 5 to 7 years: short- and long-term outcomes. J Am Acad Child Adolesc Psychiatry. 2015 Feb;54(2):138–46. doi: 10.1016/j.jaac.2014.10.008. PMID: 25617254. Exclusion Code: X4.25617254
427 Monga S, Young A, Owens M. Evaluating a cognitive behavioral therapy group program for anxious five to seven year old children: a pilot study. Depress Anxiety. 2009;26(3):243–50. doi: 10.1002/da.20551. PMID: 19212972. Exclusion Code: X7.19212972
428 Montgomery LE, Finch AJ, Jr. Validity of two measures of anxiety in children. J Abnorm Child Psychol. 1974 Dec;2(4):293–6. doi: 10.1007/bf00919257. PMID: 4463190. Exclusion Code: X2.4463190
429 Morthorst B, Krogh J, Erlangsen A, . Effect of assertive outreach after suicide attempt in the AID (assertive intervention for deliberate self harm) trial: randomised controlled trial. BMJ. 2012 Aug 22;345:e4972. doi: 10.1136/bmj.e4972. PMID: 22915730. Exclusion Code: X2.22915730
430 Mossman SA, Luft MJ, Schroeder HK, . The Generalized Anxiety Disorder 7-item scale in adolescents with generalized anxiety disorder: Signal detection and validation. Ann Clin Psychiatry. 2017 Nov;29(4):227–34a. PMID: 29069107. Exclusion Code: X2.29069107
431 Mufson L, Weissman MM, Moreau D, . Efficacy of interpersonal psychotherapy for depressed adolescents. Arch Gen Psychiatry. 1999 Jun;56(6):573–9. PMID: 10359475. Exclusion Code: X13.10359475
432 Mufson L, Yanes-Lukin P, Anderson G. A pilot study of Brief IPT-A delivered in primary care. Gen Hosp Psychiatry. 2015 Sep–Oct;37(5):481–4. doi: 10.1016/j.genhosppsych.2015.04.013. PMID: 25997880. Exclusion Code: X7.25997880
433 Muris P, Meesters C, Gobel M. Cognitive coping vs Emotional disclosure in the treatment of anxious children: A pilot-study. Cogn Behav Ther. 2002;31(2):59–67. Exclusion Code: X4.
434 Muris P, Meesters C, van Melick M. Treatment of childhood anxiety disorders: a preliminary comparison between cognitive-behavioral group therapy and a psychological placebo intervention. J Behav Ther Exp Psychiatry. 2002 Sep–Dec;33(3–4):143–58. doi: 10.1016/s0005-7916(02)00025-3. PMID: 12628633. Exclusion Code: X7.12628633
435 Muris P, Merckelbach H, Holdrinet I, . Treating phobic children: effects of EMDR versus exposure. J Consult Clin Psychol. 1998 Feb;66(1):193–8. doi: 10.1037//0022-006x.66.1.193. PMID: 9489274. Exclusion Code: X2.9489274
436 Muris P, Steerneman P. The Revised version of the Screen for Child Anxiety Related Emotional Disorders (SCARED–R): First evidence for its reliability and validity in a clinical sample. Br J Clin Psychol. 2001;40(1):35–44. doi: 10.1348/014466501163463. PMID: 2001-06105-003. Exclusion Code: X2.11317947
437 Mychailyszyn MP, Carper MM, Gibby B. Exploring the occurrence of sudden gains among anxious youth receiving evidence-based cognitive-behavioral therapy. Child Adolesc Ment Health. 2018;23(3):251–7. doi: 10.1111/camh.12254. PMID: 2017-53514-001. Exclusion Code: X9.32677298
438 Myers MG, Stein MB, Aarons GA. Cross validation of the Social Anxiety Scale for Adolescents in a high school sample. J Anxiety Disord. 2002;16(2):221–32. doi: 10.1016/s0887-6185(02)00098-1. PMID: 12194546. Exclusion Code: X9.12194546
439 . Academic impairment and impact of treatments among youth with anxiety disorders. Child & Youth Care Forum; 2015. Springer; 44. Exclusion Code: X9.
440 Nauta MH, Scholing A, Emmelkamp PM, . Cognitive-behavioural therapy for anxiety disordered children in a clinical setting: does additional cognitive parent training enhance treatment effectiveness? Clinical Psychology & Psychotherapy: An International Journal of Theory & Practice. 2001;8(5):330–40. Exclusion Code: X4.
441 Nauta MH, Scholing A, Emmelkamp PM, . Cognitive-behavioral therapy for children with anxiety disorders in a clinical setting: no additional effect of a cognitive parent training. J Am Acad Child Adolesc Psychiatry. 2003 Nov;42(11):1270–8. doi: 10.1097/01.chi.0000085752.71002.93. PMID: 14566163. Exclusion Code: X13.14566163
442 Nauta MH, Scholing A, Rapee RM, . A parent-report measure of children’s anxiety: psychometric properties and comparison with child-report in a clinic and normal sample. Behav Res Ther. 2004 Jul;42(7):813–39. doi: 10.1016/s0005-7967(03)00200-6. PMID: 15149901. Exclusion Code: X2.15149901
443 Navarro MC, Ouellet-Morin I, Geoffroy MC, . Machine Learning Assessment of Early Life Factors Predicting Suicide Attempt in Adolescence or Young Adulthood. JAMA Netw Open. 2021 Mar 1;4(3):e211450. doi: 10.1001/jamanetworkopen.2021.1450. PMID: 33710292. Exclusion Code: X3.33710292
444 Nelson EL. Cognitive behavioral therapy for childhood depression: a comparison of face-to-face and interactive televideo settings. Diss Abstr Int. 2004;65(3-b):1558. PMID: CN-00508148. Exclusion Code: X4.
445 Nemeroff CB, Heim CM, Thase ME, . Differential responses to psychotherapy versus pharmacotherapy in patients with chronic forms of major depression and childhood trauma. Proc Natl Acad Sci U S A. 2003 Nov 25;100(24):14293–6. doi: 10.1073/pnas.2336126100. PMID: 14615578. Exclusion Code: X7.14615578
446 Nemets H, Nemets B, Apter A, . Omega-3 treatment of childhood depression: a controlled, double-blind pilot study. Am J Psychiatry. 2006 Jun;163(6):1098–100. doi: 10.1176/ajp.2006.163.6.1098. PMID: 16741212. Exclusion Code: X3.16741212
447 Niederer D, Vogt L, Staschke V, . Activity trails in the therapy of clinical depression: a randomized controlled equivalence trial. Zeitschrift fur psychosomatische medizin und psychotherapie. 2017;63(2):163–75. doi: 10.13109/zptm.2017.63.2.163. PMID: CN-01410351. Exclusion Code: X1.28585508
448 Ntini I, Vadlin S, Olofsdotter S, . The Montgomery and Åsberg Depression Rating Scale - self-assessment for use in adolescents: an evaluation of psychometric and diagnostic accuracy. Nord J Psychiatry. 2020 Mar 3:1–8. doi: 10.1080/08039488.2020.1733077. PMID: 32125211. Exclusion Code: X5.32125211
449 Núñez D, Arias V, Méndez-Bustos P, . Is a brief self-report version of the Columbia severity scale useful for screening suicidal ideation in Chilean adolescents? Compr Psychiatry. 2019 Jan;88:39–48. doi: 10.1016/j.comppsych.2018.11.002. PMID: 30471550. Exclusion Code: X4.30471550
450 Oar EL, Farrell LJ, Conlon EG, . Patterns of response and remission following a One-Session Treatment for blood-injection-injury phobia in youth. Child Fam Behav Ther. 2017;39(1):43–63. doi: 10.1080/07317107.2016.1268007. PMID: 2017-07104-003. Exclusion Code: X2.
451 Obler M, Terwilliger RF. Pilot study on the effectiveness of systematic desensitization with neurologically impaired children with phobic disorders. J Consult Clin Psychol. 1970 Jun;34(3):314–8. doi: 10.1037/h0029367. PMID: 5523436. Exclusion Code: X2.5523436
452 O’Brien F, Olden N, Migone M, . Group cognitive behavioural therapy for children with anxiety disorder - an evaluation of the ‘Friends for Youth’ programme. Ir J Psychol Med. 2007 Mar;24(1):5–12. doi: 10.1017/s0790966700010065. PMID: 30290497. Exclusion Code: X4.30290497
453 O’Connor BC, Lewandowski RE, Rodriguez S, . Usual care for adolescent depression from symptom identification through treatment initiation. JAMA Pediatr. 2016 Apr;170(4):373–80. doi: 10.1001/jamapediatrics.2015.4158. PMID: 26832387. Exclusion Code: X3.26832387
454 O’Connor E, Gaynes BN, Burda BU, . Screening for and treatment of suicide risk relevant to primary care: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013 May 21;158(10):741–54. doi: 10.7326/0003-4819-158-10-201305210-00642. PMID: 23609101. Exclusion Code: X7.23609101
455 O’Connor K, Bagnell A, McGrath P, . An Internet-Based Cognitive Behavioral Program for Adolescents With Anxiety: Pilot Randomized Controlled Trial. JMIR Ment Health. 2020 Jul 24;7(7):e13356. doi: 10.2196/13356. PMID: 32706720. Exclusion Code: X2.32706720
456 Odgers K, Dargue N, Creswell C, . The limited effect of mindfulness-based interventions on anxiety in children and adolescents: a meta-analysis. Clin Child Fam Psychol Rev. 2020 Sep;23(3):407–26. doi: 10.1007/s10567-020-00319-z. PMID: 32583200. Exclusion Code: X3.32583200
457 O’Dor SL, Washburn J, Howard KR, . Moderators and Predictors of Response After 36 Weeks of Treatment in the Treatment for Adolescents with Depression Study (TADS). Res Child Adolesc Psychopathol. 2021 May 29doi: 10.1007/s10802-021-00828-7. PMID: 34050856. Exclusion Code: X9.34050856
458 O’Keefe VM, Haroz EE, Goklish N, . Employing a sequential multiple assignment randomized trial (SMART) to evaluate the impact of brief risk and protective factor prevention interventions for American Indian Youth Suicide. BMC Public Health. 2019 Dec 12;19(1):1675. doi: 10.1186/s12889-019-7996-2. PMID: 31830933. Exclusion Code: X11.31830933
459 Oldershaw A, Simic M, Grima E, . The effect of cognitive behavior therapy on decision making in adolescents who self-harm: A pilot study. Suicide Life Threat Behav. 2012;42(3):255–65. doi: 10.1111/j.1943-278X.2012.0087.x. PMID: 2012-15581-003. Exclusion Code: X7.22435932
460 Olivares J, García-López L-J, Beidel DC, . Results at long-term among three psychological treatments for adolescents with generalized social phobia (I): Statistical significance. Psicología Conductual. 2002;10(1):147–66. Exclusion Code: X4.
461 Olivares J, Olivares-Olivares PJ, Rosa-Alcázar AI, . The contribution of the therapist’s competence in the treatment of adolescents with generalized social phobia. Psicothema. 2014;26(4):483–9. doi: 10.7334/psicothema2014.69. PMID: 25340895. Exclusion Code: X5.25340895
462 Olivares J, Rosa A, Piqueras J. Early detection and treatment of adolescents with generalized social phobia. Psicothema. 2005;17(1):1–8. Exclusion Code: X1.
463 Olivares R J, Rosa-Alcazar A, . The. The relevance of the individualized attention in the treatment with adolescents under generalized social phobia. International journal of clinical and health psychology. 2006;6(3). Exclusion Code: X1.
464 Olivares-Olivares PJ, Rosa-Alcázar AI, Olivares-Rodríguez J. Does individual attention improve the effect of group treatment of adolescents with social phobia? Int J Clin Health Psychol. 2008;8(2):465–81. Exclusion Code: X4.
465 Ollendick TH, Halldorsdottir T, Fraire MG, . Specific phobias in youth: a randomized controlled trial comparing one-session treatment to a parent-augmented one-session treatment. Behav Ther. 2015 Mar;46(2):141–55. doi: 10.1016/j.beth.2014.09.004. PMID: 25645164. Exclusion Code: X4.25645164
466 Ollendick TH, Öst L-G, Reuterskiöld L, . One-session treatment of specific phobias in youth: A randomized clinical trial in the United States and Sweden. J Consult Clin Psychol. 2009;77(3):504–16. doi: 10.1037/a0015158. PMID: 2009-08093-012. Exclusion Code: X2.19485591
467 Ollendick TH, White SW, Richey J, . Attention bias modification treatment for adolescents with social anxiety disorder. Behav Ther. 2019 Jan;50(1):126–39. doi: 10.1016/j.beth.2018.04.002. PMID: 30661553. Exclusion Code: X3.30661553
468 Orchard F, Apetroaia A, Clarke K, . Cognitive bias modification of interpretation in children with social anxiety disorder. J Anxiety Disord. 2017 Jan;45:1–8. doi: 10.1016/j.janxdis.2016.10.012. PMID: 27866085. Exclusion Code: X3.27866085
469 Ortbandt C, Petermann U. Effects of a cognitive-behavioral training program for children with social anxiety. KINDHEIT UND ENTWICKLUNG. 2009;18(1):21–9. Exclusion Code: X1.
470 Orvati Aziz M, Mehrinejad SA, Hashemian K, . Integrative therapy (short-term psychodynamic psychotherapy & cognitive-behavioral therapy) and cognitive-behavioral therapy in the treatment of generalized anxiety disorder: A randomized controlled trial. Complement Ther Clin Pract. 2020 May;39:101122. doi: 10.1016/j.ctcp.2020.101122. PMID: 32379661. Exclusion Code: X2.32379661
471 Ost LG, Svensson L, Hellström K, . One-Session treatment of specific phobias in youths: a randomized clinical trial. J Consult Clin Psychol. 2001 Oct;69(5):814–24. PMID: 11680558. Exclusion Code: X2.11680558
472 Ougrin D. Adding group psychotherapy to routine care does not improve outcomes in adolescents who repeatedly self-harm. Evid Based Ment Health. 2011 Aug;14(3):84. doi: 10.1136/ebmh.14.3.84. PMID: 21764883. Exclusion Code: X8.21764883
473 Ozyurt G, Gencer O, Ozturk Y, . Is Triple P effective in childhood anxiety disorder? A randomized controlled study. Psychiatry and clinical psychopharmacology. 2018doi: 10.1080/24750573.2018.1483790. PMID: CN-01645872. Exclusion Code: X6.
474 Ozyurt G, Gencer O, Oztürk Y, . Long term effectiveness of Triple P Positive Parenting Program on childhood anxiety disorders: a randomised controlled trial. Eur Neuropsychopharmacol. 2014;24:S613-. PMID: CN-01023721. Exclusion Code: X12.
475 Özyurt G, Gencer Ö, Öztürk Y, . Is triple P positive parenting program effective on anxious children and their parents? 4th month follow up results. J Child Fam Stud. 2016;25(5):1646–55. doi: 10.1007/s10826-015-0343-z. PMID: 2015-57339-001. Exclusion Code: X2.
476 Palitz SA, Caporino NE, McGuire JF, . Defining treatment response and remission in youth anxiety: a signal detection analysis with the Multidimensional Anxiety Scale for Children. J Am Acad Child Adolesc Psychiatry. 2018 Jun;57(6):418–27. doi: 10.1016/j.jaac.2018.03.013. PMID: 29859557. Exclusion Code: X3.29859557
477 Pandya SP. Spiritual counseling program for children with anxiety disorders: a multi-city experiment. J Pastoral Care Counsel. 2018 Mar;72(1):45–57. doi: 10.1177/1542305018761631. PMID: 29623802. Exclusion Code: X6.29623802
478 Papalini S, Lange I, Bakker J, . The predictive value of neural reward processing on exposure therapy outcome: Results from a randomized controlled trial. Prog Neuropsychopharmacol Biol Psychiatry. 2019 Jun 8;92:339–46. doi: 10.1016/j.pnpbp.2019.02.002. PMID: 30763673. Exclusion Code: X2.30763673
479 Parikh R, Michelson D, Malik K, . The effectiveness of a low-intensity problem-solving intervention for common adolescent mental health problems in New Delhi, India: protocol for a school-based, individually randomized controlled trial with an embedded stepped-wedge, cluster randomized controlled recruitment trial. Trials. 2019 Sep 18;20(1):568. doi: 10.1186/s13063-019-3573-3. PMID: 31533783. Exclusion Code: X6.31533783
480 Park CH, Kim GS. A validation study on DAS in the prediction of suicidal risk for adolescents. The Arts in Psychotherapy. 2013;40(1):108–14. doi: 10.1016/j.aip.2012.11.006. PMID: 2013-09132-013. Exclusion Code: X9.
481 Parker AG, Hetrick SE, Jorm AF, . The effectiveness of simple psychological and physical activity interventions for high prevalence mental health problems in young people: A factorial randomised controlled trial. J Affect Disord. 2016 May 15;196:200–9. doi: 10.1016/j.jad.2016.02.043. PMID: 26926659. Exclusion Code: X2.26926659
482 Parr CJ, Cartwright-Hatton S. Social anxiety in adolescents: the effect of video feedback on anxiety and the self-evaluation of performance. Clin Psychol Psychother. 2009 Jan–Feb;16(1):46–54. doi: 10.1002/cpp.599. PMID: 19123484. Exclusion Code: X2.19123484
483 Paschall MJ, Bersamin M. School-based health centers, depression, and suicide risk among adolescents. Am J Prev Med. 2018 Jan;54(1):44–50. doi: 10.1016/j.amepre.2017.08.022. PMID: 29132951. Exclusion Code: X3.29132951
484 Patel A, Watts C, Shiddell S, . Universal adolescent suicide screening in a pediatric urgent care center. Arch Suicide Res. 2018 Jan–Mar;22(1):118–27. doi: 10.1080/13811118.2017.1304303. PMID: 28281893. Exclusion Code: X4.28281893
485 Pauschardt J, Remschmidt H, Mattejat F. Assessing child and adolescent anxiety in psychiatric samples with the Child Behavior Checklist. J Anxiety Disord. 2010 Jun;24(5):461–7. doi: 10.1016/j.janxdis.2010.03.002. PMID: 20362414. Exclusion Code: X5.20362414
486 Pergamin-Hight L, Pine DS, Fox NA, . Attention bias modification for youth with social anxiety disorder. J Child Psychol Psychiatry. 2016;57(11):1317–25. doi: 10.1111/jcpp.12599. PMID: 2016-53125-007. Exclusion Code: X3.27435286
487 Peris TS, Compton SN, Kendall PC, . Trajectories of change in youth anxiety during cognitive—behavior therapy. J Consult Clin Psychol. 2015;83(2):239–52. doi: 10.1037/a0038402, 10.1037/a0038402.supp (Supplemental). PMID: 2014-54663-001. Exclusion Code: X9.25486372
488 Peris TS, Sugar CA, Rozenman MS, . Long-term service use among youths previously treated for anxiety disorder. J Am Acad Child Adolesc Psychiatry. 2021 Apr;60(4):501–12. doi: 10.1016/j.jaac.2020.07.911. PMID: 33301814. Exclusion Code: X9.33301814
489 Perloe A, Esposito-Smythers C, Curby TW, . Concurrent trajectories of change in adolescent and maternal depressive symptoms in the TORDIA study. J Youth Adolesc. 2014 Apr;43(4):612–28. doi: 10.1007/s10964-013-9999-0. PMID: 23975354. Exclusion Code: X2.23975354
490 Perrin S, Last CG. Do childhood anxiety measures measure anxiety? J Abnorm Child Psychol. 1992 Dec;20(6):567–78. doi: 10.1007/bf00911241. PMID: 1487597. Exclusion Code: X5.1487597
491 Peterson BS, West AE, Weisz JR, . A Sequential Multiple Assignment Randomized Trial (SMART) study of medication and CBT sequencing in the treatment of pediatric anxiety disorders. BMC Psychiatry. 2021 Jun 30;21(1):323. doi: 10.1186/s12888-021-03314-y. PMID: 34193105. Exclusion Code: X4.34193105
492 Pettit JW, Bechor M, Rey Y, . A Randomized Controlled Trial of Attention Bias Modification Treatment in Youth With Treatment-Resistant Anxiety Disorders. J Am Acad Child Adolesc Psychiatry. 2020 Jan;59(1):157–65. doi: 10.1016/j.jaac.2019.02.018. PMID: 30877049. Exclusion Code: X2.30877049
493 Phillips R, Spears MR, Montgomery AA, . Could a brief assessment of negative emotions and self-esteem identify adolescents at current and future risk of self-harm in the community? A prospective cohort analysis. BMC Public Health. 2013 Jun 22;13:604. doi: 10.1186/1471-2458-13-604. PMID: 23800153. Exclusion Code: X4.23800153
494 Piacentini J, Bennett S, Compton SN, . 24- and 36-week outcomes for the Child/Adolescent Anxiety Multimodal Study (CAMS). J Am Acad Child Adolesc Psychiatry. 2014;53(3):297–310. doi: 10.1016/j.jaac.2013.11.010. PMID: CN-00982077. Exclusion Code:24565357
495 Pina AA, Silverman WK, Fuentes RM, . Exposure-based cognitive-behavioral treatment for phobic and anxiety disorders: Treatment effects and maintenance for Hispanic/Latino relative to European-American youths. J Am Acad Child Adolesc Psychiatry. 2003;42(10):1179–87. doi: 10.1097/00004583-200310000-00008. PMID: 2003-08377-006. Exclusion Code: X4.14560167
496 Pincus DB, May JE, Whitton SW, . Cognitive-behavioral treatment of panic disorder in adolescence. J Clin Child Adolesc Psychol. 2010;39(5):638–49. doi: 10.1080/15374416.2010.501288. PMID: 2010-17041-004. Exclusion Code: X13.20706917
497 Posner K, Oquendo MA, Gould M, . Columbia Classification Algorithm of Suicide Assessment (C-CASA): classification of suicidal events in the FDA’s pediatric suicidal risk analysis of antidepressants. Am J Psychiatry. 2007;164(7):1035–43. doi: 10.1176/appi.ajp.164.7.1035. PMID: CN-01772061. Exclusion Code: X2.17606655
498 Post P. Impact of child-centered play therapy on the self-esteem, locus of control, and anxiety of at-risk 4th, 5th, and 6th grade students. International Journal of Play Therapy. 1999;8(2):1–18. doi: 10.1037/h0089428. PMID: 2000-13732-001. Exclusion Code: X2.
499 Prochaska JD, Le VD, Baillargeon J, . Utilization of Professional Mental Health Services Related to Population-Level Screening for Anxiety, Depression, and Post-traumatic Stress Disorder Among Public High School Students. Community Ment Health J. 2016 Aug;52(6):691–700. doi: 10.1007/s10597-015-9968-z. PMID: 26733335. Exclusion Code: X3.26733335
500 Putwain DW, Pescod M. Is reducing uncertain control the key to successful test anxiety intervention for secondary school students? Findings from a randomized control trial. Sch Psychol Q. 2018 Jun;33(2):283–92. doi: 10.1037/spq0000228. PMID: 29094957. Exclusion Code: X2.29094957
501 Radomski AD, Bagnell A, Curtis S, . Examining the Usage, User Experience, and Perceived Impact of an Internet-Based Cognitive Behavioral Therapy Program for Adolescents With Anxiety: Randomized Controlled Trial. JMIR Ment Health. 2020 Feb 7;7(2):e15795. doi: 10.2196/15795. PMID: 32022692. Exclusion Code: X2.32022692
502 Randell BP, Eggert LL, Pike KC. Immediate post intervention effects of two brief youth suicide prevention interventions. Suicide Life Threat Behav. 2001 Spring;31(1):41–61. doi: 10.1521/suli.31.1.41.21308. PMID: 11326768. Exclusion Code: X9.11326768
503 Rapee RM. Group treatment of children with anxiety disorders: Outcome and predictors of treatment response. Aust J Psychol. 2000;52(3):125–9. Exclusion Code: X7.
504 Rapee RM, Abbott MJ, Lyneham HJ. Bibliotherapy for children with anxiety disorders using written materials for parents: a randomized controlled trial. J Consult Clin Psychol. 2006 Jun;74(3):436–44. doi: 10.1037/0022-006x.74.3.436. PMID: 16822101. Exclusion Code: X13.16822101
505 Rasing SPA, Stikkelbroek YAJ, den Hollander W, . Pragmatic Quasi-Experimental Controlled Trial Evaluating the Outcomes of Blended CBT Compared to Face-to-Face CBT and Treatment as Usual for Adolescents with Depressive Disorders. Int J Environ Res Public Health. 2021 Mar 17;18(6)doi: 10.3390/ijerph18063102. PMID: 33802913. Exclusion Code: X2.33802913
506 Reardon T, Spence SH, Hesse J, . Identifying children with anxiety disorders using brief versions of the Spence Children’s Anxiety Scale for children, parents, and teachers. Psychol Assess. 2018 Oct;30(10):1342–55. doi: 10.1037/pas0000570. PMID: 29902050. Exclusion Code: X2.29902050
507 Reigada LC, Polokowski AR, Walder DJ, . Treatment for comorbid pediatric gastrointestinal and anxiety disorders: A pilot study of a flexible health sensitive cognitive-behavioral therapy program. Clinical Practice in Pediatric Psychology. 2015;3(4):314. Exclusion Code: X2.
508 Reinblatt SP, Riddle MA. Selective serotonin reuptake inhibitor-induced apathy: a pediatric case series. J Child Adolesc Psychopharmacol. 2006 Feb–Apr;16(1–2):227–33. doi: 10.1089/cap.2006.16.227. PMID: 16553543. Exclusion Code: X4.16553543
509 Renaud J, Birmaher B, Wassick SC, . Use of selective serotonin reuptake inhibitors for the treatment of childhood panic disorder: a pilot study. J Child Adolesc Psychopharmacol. 1999;9(2):73–83. doi: 10.1089/cap.1999.9.73. PMID: 10461817. Exclusion Code: X4.10461817
510 Rengasamy M, Phelps-Tschang J, Simpson M, . 6.50 Reduction of Adolescent Suicide Attempts After Telephone-Based Intervention. J Am Acad Child Adolesc Psychiatry. 2018;57(10):S265-. doi: 10.1016/j.jaac.2018.09.411. PMID: CN-01653031. Exclusion Code: X2.
511 Reyes-Portillo JA, Chin EM, Toso-Salman J, . Using Electronic Health Record Alerts to Increase Safety Planning with Youth At-Risk for Suicide: A Non-randomized Trial. Child & Youth Care Forum. 2018;47(3):391–402. doi: 10.1007/s10566-018-9435-4. PMID: 129180474. Language: English. Entry Date: 20180423. Revision Date: 20190603. Publication Type: Article. Exclusion Code: X7.
512 Reyes-Portillo JA, McGlinchey EL, Yanes-Lukin P, . Does peer and family interpersonal functioning mediate the impact of interpersonal psychotherapy for latino adolescents in regard to suicidal ideation? J Am Acad Child Adolesc Psychiatry. 2016;55(10):S297-. doi: 10.1016/j.jaac.2016.07.264. PMID: CN-01304636. Exclusion Code: X9.
513 Rickhi B, Kania-Richmond A, Moritz S, . Evaluation of a spirituality informed e-mental health tool as an intervention for major depressive disorder in adolescents and young adults - a randomized controlled pilot trial. BMC Complement Altern Med. 2015 Dec 24;15:450. doi: 10.1186/s12906-015-0968-x. PMID: 26702639. Exclusion Code: X2.26702639
514 Rinke ML, German M, Azera B, . Effect of Mental Health Screening and Integrated Mental Health on Adolescent Depression-Coded Visits. Clin Pediatr (Phila). 2019 Apr;58(4):437–45. doi: 10.1177/0009922818821889. PMID: 30623684. Exclusion Code: X9.30623684
515 Ritter B. The group desensitization of children’s snake phobias using vicarious and contact desensitization procedures. Behav Res Ther. 1968 Feb;6(1):1–6. doi: 10.1016/0005-7967(68)90033-8. PMID: 5689466. Exclusion Code: X2.5689466
516 Rizo Martínez LE, Guevara Pérez MÁ, Hernández González M, . A preliminary study of the prevalence of post-traumatic stress disorder, depression and anxiety symptoms in female adolescents maltreatment victims in Mexico. Salud Mental. 2018;41(3):139–44. doi: 10.17711/SM.0185-3325.2018.018. PMID: 2019-01689-005. Exclusion Code: X6.
517 Roaten K, Horowitz LM, Bridge JA, . Universal Pediatric Suicide Risk Screening in a Health Care System: 90,000 Patient Encounters. J Acad Consult Liaison Psychiatry. 2021 Jul–Aug;62(4):421–9. doi: 10.1016/j.jaclp.2020.12.002. PMID: 34219656. Exclusion Code: X4.34219656
518 Roberts V, Joiner R, Russell C, . Mind and Body: an early intervention group programme for adolescents with self-harm thoughts and behaviours. Education & Health. 2019;37(2):46–53. PMID: 137883429. Language: English. Entry Date: 20190807. Revision Date: 20190808. Publication Type: Article. Exclusion Code: X2.
519 Robinson J, Hetrick S, Cox G, . The development of a randomised controlled trial testing the effects of an online intervention among school students at risk of suicide. BMC Psychiatry. 2014 May 27;14:155. doi: 10.1186/1471-244x-14-155. PMID: 24884888. Exclusion Code: X11.24884888
520 Robinson J, Hetrick S, Gook S, . Study protocol: the development of a randomised controlled trial testing a postcard intervention designed to reduce suicide risk among young help-seekers. BMC Psychiatry. 2009 Sep 23;9:59. doi: 10.1186/1471-244x-9-59. PMID: 19775469. Exclusion Code: X11.19775469
521 Robinson J, Yuen HP, Gook S, . Can receipt of a regular postcard reduce suicide-related behaviour in young help seekers? A randomized controlled trial. Early intervention in psychiatry. 2012;6(2):145–52. doi: 10.1111/j.1751-7893.2011.00334.x. PMID: CN-00851791. Exclusion Code: X3.22260366
522 Rodrigues Pereira C, Ensink JBM, Güldner MG, . Effectiveness of a behavioral treatment protocol for selective mutism in children: Design of a randomized controlled trial. Contemp Clin Trials Commun. 2020 Sep;19:100644. doi: 10.1016/j.conctc.2020.100644. PMID: 32875140. Exclusion Code: X11.32875140
523 Roelofs J, Braet C, Rood L, . Norms and screening utility of the Dutch version of the Children’s Depression Inventory in clinical and nonclinical youths. Psychol Assess. 2010 Dec;22(4):866–77. doi: 10.1037/a0020593. PMID: 21133547. Exclusion Code: X2.21133547
524 Rohde P, Clarke GN, Mace DE, . An efficacy/effectiveness study of cognitive-behavioral treatment for adolescents with comorbid major depression and conduct disorder. J Am Acad Child Adolesc Psychiatry. 2004 Jun;43(6):660–8. doi: 10.1097/01.chi.0000121067.29744.41. PMID: 15167082. Exclusion Code: X2.15167082
525 Rohde P, Lewinsohn PM, Seeley JR. Response of depressed adolescents to cognitive-behavioral treatment: do differences in initial severity clarify the comparison of treatments? J Consult Clin Psychol. 1994 Aug;62(4):851–4. PMID: 7962890. Exclusion Code: X4.7962890
526 Rohde P, Seeley JR, Kaufman NK, . Predicting time to recovery among depressed adolescents treated in two psychosocial group interventions. J Consult Clin Psychol. 2006 Feb;74(1):80–8. doi: 10.1037/0022-006X.74.1.80. PMID: 16551145. Exclusion Code: X2.16551145
527 Rojas G, Martínez P, Vöhringer PA, . Comprehensive technology-assisted training and supervision program to enhance depression management in primary care in Santiago, Chile: study protocol for a cluster randomized controlled trial. Trials. 2015 Jul 24;16:311. doi: 10.1186/s13063-015-0845-4. PMID: 26201546. Exclusion Code: X2.26201546
528 Rosa-Alcazar A, Boix M, Olivares-Olivares P. Contributions of cognitive restructuring in the treatment of social phobia in adolescents. Behavioral Psychology/Psicologia Conductual: Revista Internacional Clinica y de la Salud Psicologia Conductual Revista Internacional de Psicologia Clinica de la Salud. 2013;21:6–23. Exclusion Code: X1.
529 Rosa-Alcázar A, Olivares-Rodríguez J, Olivares-Olivares P. The role of planned interaction in the treatment of generalized social phobia. Terapia psicológica. 2007;25(2):205–12. Exclusion Code: X1.
530 Rossello J, Bernal G. The efficacy of cognitive-behavioral and interpersonal treatments for depression in Puerto Rican adolescents. J Consult Clin Psychol. 1999 Oct;67(5):734–45. PMID: 10535240. Exclusion Code: X13.10535240
531 Rossouw T. Mentalisation based treatment for adolescents with self harm: an RCT. Eur Child Adolesc Psychiatry. 2015;24(1 SUPPL. 1):S113. doi: 10.1007/s00787-015-0714-4. PMID: CN-01471379. Exclusion Code: X8.
532 Rossow T. Self harm in adolescence, is MBT the answer?: an RCT. Adolescent psychiatry. 2012;2(1):102. PMID: CN-01033258. Exclusion Code: X8.
533 Rowe SL, French RS, Henderson C, . Decisional support for young people who self-harm: protocol for a feasibility trial. BMJ Open. 2016 Sep 28;6(9):e012161. doi: 10.1136/bmjopen-2016-012161. PMID: 27683517. Exclusion Code: X11.27683517
534 Rueda-Jaimes GE, Castro-Rueda VA, Rangel-Martínez-Villalba AM, . Validity of the Suicidal Behavior Questionnaire-Revised in patients with short-term suicide risk. The European Journal of Psychiatry. 2017;31(4):145–50. doi: 10.1016/j.ejpsy.2017.09.002. PMID: 2019-05498-002. Exclusion Code: X7.
535 Rummel-Kluge C, Dietrich S, Koburger N. Behavioural and cognitive-behavioural therapy based self-help versus treatment as usual for depression in adults and adolescents. Cochrane Database Syst Rev. 2015(6)doi: 10.1002/14651858.CD011744. PMID: CD011744. Exclusion Code: X7.
536 Rynn MA, Walkup JT, Compton SN, . Child/adolescent anxiety multimodal study: evaluating safety. J Am Acad Child Adolesc Psychiatry. 2015;54(3 // () *National Institute of Mental Health*):180–90. doi: 10.1016/j.jaac.2014.12.015. PMID: CN-01077415. Exclusion Code: X9.25721183
537 Rytwinski NK, Fresco DM, Heimberg RG, . Screening for social anxiety disorder with the self-report version of the Liebowitz Social Anxiety Scale. Depress Anxiety. 2009;26(1):34–8. doi: 10.1002/da.20503. PMID: 18781659. Exclusion Code: X2.18781659
538 Saavedra LM, Silverman WK, Morgan-Lopez AA, . Cognitive behavioral treatment for childhood anxiety disorders: Long-term effects on anxiety and secondary disorders in young adulthood. J Child Psychol Psychiatry. 2010;51(8):924–34. doi: 10.1111/j.1469-7610.2010.02242.x. PMID: 2010-14446-008. Exclusion Code: x4.20345838
539 Sælid GA, Nordahl HM. Rational emotive behaviour therapy in high schools to educate in mental health and empower youth health. A randomized controlled study of a brief intervention. Cogn Behav Ther. 2017 Apr;46(3):196–210. doi: 10.1080/16506073.2016.1233453. PMID: 27791532. Exclusion Code: X5.27791532
540 Sakado K, Sato T, Uehara T, . Perceived parenting pattern and response to antidepressants in patients with major depression. J Affect Disord. 1999 Jan–Mar;52(1–3):59–66. doi: 10.1016/s0165-0327(98)00062-7. PMID: 10357018. Exclusion Code: X3.10357018
541 Sakolsky D. Impact of selective serotonin reuptake inhibitor (SSRI) use on suicidal ideation and behavior in child/adolescent anxiety multimodal extended long-term study. J Am Acad Child Adolesc Psychiatry. 2017;56(10):S319-. doi: 10.1016/j.jaac.2017.07.641. PMID: CN-01452262. Exclusion Code: X8.
542 Salari E, Shahrivar Z, Mahmoudi-Gharaei J, . Parent-only Group Cognitive Behavioral Intervention for Children with Anxiety Disorders: A Control Group Study. J Can Acad Child Adolesc Psychiatry. 2018 Apr;27(2):130–6. PMID: 29662524. Exclusion Code: X6.29662524
543 Salazar DM, Ruiz FJ, Ramírez ES, . Acceptance and commitment therapy focused on repetitive negative thinking for child depression: A randomized multiple-baseline evaluation. The Psychological Record. 2020;70(3):373–86. doi: 10.1007/s40732-019-00362-5. PMID: 2020-00665-001. Exclusion Code: X9.
544 Sallee FR, Richman H, Sethuraman G, . Clonidine challenge in childhood anxiety disorder. J Am Acad Child Adolesc Psychiatry. 1998 Jun;37(6):655–62. doi: 10.1097/00004583-199806000-00016. PMID: 9628086. Exclusion Code: X3.9628086
545 Salloum A, Andel R, Lewin AB, . Family accommodation as a predictor of cognitive-behavioral treatment outcome for childhood anxiety. Fam Soc. 2018;99(1):45–55. doi: 10.1177/1044389418756326. PMID: 2018-12524-006. Exclusion Code: X7.
546 Salum GA, Petersen CS, Jarros RB, . Group Cognitive Behavioral Therapy and Attention Bias Modification for Childhood Anxiety Disorders: A Factorial Randomized Trial of Efficacy. J Child Adolesc Psychopharmacol. 2018 Nov;28(9):620–30. doi: 10.1089/cap.2018.0022. PMID: 29969293. Exclusion Code: X6.29969293
547 Sánchez-García R, Olivares J. Intervención temprana en niños y adolescentes con fobia social. Anuario de psicología. 2009;40(1):75–88. Exclusion Code: X1.
548 Santacruz I, Méndez FJ, Sánchez-Meca J. Play therapy applied by parents for children with darkness phobia: Comparison of two programmes. Child Fam Behav Ther. 2006;28(1):19–35. Exclusion Code: X2.
549 Santamarina-Perez P, Mendez I, Singh MK, . Adapted Dialectical Behavior Therapy for Adolescents with a High Risk of Suicide in a Community Clinic: A Pragmatic Randomized Controlled Trial. Suicide Life Threat Behav. 2020 Jan 16doi: 10.1111/sltb.12612. PMID: 31944371. Exclusion Code: X4.31944371
550 Santosh P, Gringras P, Baird G, . Development and psychometric properties of the parent version of the Profile of Neuropsychiatric Symptoms (PONS) in children and adolescents. BMC Pediatr. 2015 May 19;15:62. doi: 10.1186/s12887-015-0376-x. PMID: 25986431. Exclusion Code: X9.25986431
551 Santucci LC, Ehrenreich-May J. A randomized controlled trial of the child anxiety multi-day program (CAMP) for separation anxiety disorder. Child Psychiatry Hum Dev. 2013 Jun;44(3):439–51. doi: 10.1007/s10578-012-0338-6. PMID: 23053618. Exclusion Code: X13.23053618
552 Sayal K, Yates N, Spears M, . Service use in adolescents at risk of depression and self-harm: prospective longitudinal study. Soc Psychiatry Psychiatr Epidemiol. 2014 Aug;49(8):1231–40. doi: 10.1007/s00127-014-0843-y. PMID: 24570203. Exclusion Code: X5.24570203
553 Scharfstein LA, Beidel DC, Finnell LR, . Do pharmacological and behavioral interventions differentially affect treatment outcome for children with social phobia? Behav Modif. 2011 Sep;35(5):451–67. doi: 10.1177/0145445511408590. PMID: 21586501. Exclusion Code: X9.21586501
554 Schilling EA, Aseltine RH, Jr., James A. The SOS Suicide Prevention Program: Further Evidence of Efficacy and Effectiveness. Prev Sci. 2016 Feb;17(2):157–66. doi: 10.1007/s11121-015-0594-3. PMID: 26314868. Exclusion Code: X5.26314868
555 Schleider J, Weisz J. A single-session growth mindset intervention for adolescent anxiety and depression: 9-month outcomes of a randomized trial. J Child Psychol Psychiatry. 2018;59(2):160–70. doi: 10.1111/jcpp.12811. PMID: 2017-41876-001. Exclusion Code: X3.28921523
556 Schleider JL, Ginsburg GS, Keeton CP, . Parental psychopathology and treatment outcome for anxious youth: Roles of family functioning and caregiver strain. J Consult Clin Psychol. 2015;83(1):213–24. doi: 10.1037/a0037935. PMID: 2014-38356-001. Exclusion Code: X9.25222799
557 Schneider S, Blatter-Meunier J, Herren C, . Disorder-specific cognitive-behavioral therapy for separation anxiety disorder in young children: a randomized waiting-list-controlled trial. Psychother Psychosom. 2011;80(4):206–15. doi: 10.1159/000323444. PMID: 2011-23503-003. Exclusion Code: X13.21494062
558 Schneider S, Blatter-Meunier J, Herren C, . The efficacy of a family-based cognitive-behavioral treatment for separation anxiety disorder in children aged 8-13: a randomized comparison with a general anxiety program. J Consult Clin Psychol. 2013 Oct;81(5):932–40. doi: 10.1037/a0032678. PMID: 23607501. Exclusion Code: X4.23607501
559 Schoneveld EA, Malmberg M, Lichtwarck-Aschoff A, . A neurofeedback video game (MindLight) to prevent anxiety in children: A randomized controlled trial. Comput Human Behav. 2016;63:321–33. doi: 10.1016/j.chb.2016.05.005. PMID: 2016-39370-036. Exclusion Code: X2.
560 Schopf K, Mohr C, Lippert MW, . The role of exposure in the treatment of anxiety in children and adolescents: protocol of a systematic review and meta-analysis. Syst Rev. 2020 Apr 27;9(1):96. doi: 10.1186/s13643-020-01337-2. PMID: 32340628. Exclusion Code: X11.32340628
561 Schuppert HM, Giesen-Bloo J, van Gemert TG, . Effectiveness of an emotion regulation group training for adolescents--a randomized controlled pilot study. Clin Psychol Psychother. 2009 Nov–Dec;16(6):467–78. doi: 10.1002/cpp.637. PMID: 19630069. Exclusion Code: X2.19630069
562 Schuppert HM, Timmerman ME, Bloo J, . Emotion regulation training for adolescents with borderline personality disorder traits: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2012 Dec;51(12):1314–23.e2. doi: 10.1016/j.jaac.2012.09.002. PMID: 23200288. Exclusion Code: X2.23200288
563 Schwingel A, Gálvez P, Linares D, . Using a Mixed-Methods RE-AIM Framework to Evaluate Community Health Programs for Older Latinas. J Aging Health. 2017 Jun;29(4):551–93. doi: 10.1177/0898264316641075. PMID: 27079919. Exclusion Code: X2.27079919
564 Sekhar DL, Ba DM, Liu G, . Major Depressive Disorder Screening Remains Low Even Among Privately Insured Adolescents. J Pediatr. 2019 Jan;204:203–7. doi: 10.1016/j.jpeds.2018.07.086. PMID: 30244990. Exclusion Code: X9.30244990
565 Sekhar DL, Pattison KL, Confair A, . Effectiveness of Universal School-Based Screening vs Targeted Screening for Major Depressive Disorder Among Adolescents: A Trial Protocol for the Screening in High Schools to Identify, Evaluate, and Lower Depression (SHIELD) Randomized Clinical Trial. JAMA Netw Open. 2019 Nov 1;2(11):e1914427. doi: 10.1001/jamanetworkopen.2019.14427. PMID: 31675086. Exclusion Code: X5.31675086
566 Seligman LD, Ollendick TH, Langley AK, . The utility of measures of child and adolescent anxiety: A meta-analytic review of the Revised Children’s Anxiety Scale, the State-Trait Anxiety Inventory for Children, and the Child Behavior Checklist. J Clin Child Adolesc Psychol. 2004;33(3):557–65. doi: 10.1207/s15374424jccp3303_13. PMID: 2004-16801-013. Exclusion Code: X9.15271613
567 Serrani Azcurra D. Psychometric validation of the Columbia-Suicide Severity rating scale in Spanish-speaking adolescents. Colomb Med (Cali). 2017 Dec 30;48(4):174–82. doi: 10.25100/cm.v43i4.2294. PMID: 29662259. Exclusion Code: X2.29662259
568 Shand FL, Ridani R, Tighe J, . The effectiveness of a suicide prevention app for indigenous Australian youths: study protocol for a randomized controlled trial. Trials. 2013 Nov 20;14:396. doi: 10.1186/1745-6215-14-396. PMID: 24257410. Exclusion Code: X11.24257410
569 Shippee ND, Mattson A, Brennan R, . Effectiveness in Regular Practice of Collaborative Care for Depression Among Adolescents: A Retrospective Cohort Study. Psychiatr Serv. 2018 May 1;69(5):536–41. doi: 10.1176/appi.ps.201700298. PMID: 29446330. Exclusion Code: X7.29446330
570 Shirk SR, Deprince AP, Crisostomo PS, . Cognitive behavioral therapy for depressed adolescents exposed to interpersonal trauma: an initial effectiveness trial. Psychotherapy (Chic). 2014 Mar;51(1):167–79. doi: 10.1037/a0034845. PMID: 24377410. Exclusion Code: X2.24377410
571 Shirk SR, Gudmundsen G, Kaplinski HC, . Alliance and outcome in cognitive-behavioral therapy for adolescent depression. J Clin Child Adolesc Psychol. 2008 Jul;37(3):631–9. doi: 10.1080/15374410802148061. PMID: 18645753. Exclusion Code: X4.18645753
572 Sigurvinsdóttir AL, Jensínudóttir KB, Baldvinsdóttir KD, . Effectiveness of cognitive behavioral therapy (CBT) for child and adolescent anxiety disorders across different CBT modalities and comparisons: a systematic review and meta-analysis. Nord J Psychiatry. 2020 Apr;74(3):168–80. doi: 10.1080/08039488.2019.1686653. PMID: 31738631. Exclusion Code: X8.31738631
573 Silver J, Barch DM, Klein DN, . A Brief Early Childhood Screening Tool for Psychopathology Risk in Primary Care: The Moderating Role of Poverty. J Pediatr. 2021 Apr 28doi: 10.1016/j.jpeds.2021.04.042. PMID: 33930406. Exclusion Code: X7.33930406
574 Silverman WK, Kurtines WM, Ginsburg GS, . Treating anxiety disorders in children with group cognitive-behaviorial therapy: a randomized clinical trial. J Consult Clin Psychol. 1999 Dec;67(6):995–1003. doi: 10.1037//0022-006x.67.6.995. PMID: 10596522. Exclusion Code: X13.10596522
575 Simeon JG, Ferguson HB. Alprazolam effects in children with anxiety disorders. Can J Psychiatry. 1987 Oct;32(7):570–4. doi: 10.1177/070674378703200712. PMID: 3315169. Exclusion Code: X3.3315169
576 Simon E, Bögels SM, Voncken JM. Efficacy of child-focused and parent-focused interventions in a child anxiety prevention study. J Clin Child Adolesc Psychol. 2011;40(2):204–19. doi: 10.1080/15374416.2011.546039. PMID: 2011-05035-004. Exclusion Code: X5.21391018
577 Simon E, de Hullu E, Bögels S, . Development of ‘learn to dare!’: An online assessment and intervention platform for anxious children. BMC Psychiatry. 2020;20 PMID: 2020-10654-001. Exclusion Code: X11.
578 Simon GE, Coleman KJ, Rossom RC, . Risk of suicide attempt and suicide death following completion of the Patient Health Questionnaire depression module in community practice. J Clin Psychiatry. 2016 Feb;77(2):221–7. doi: 10.4088/JCP.15m09776. PMID: 26930521. Exclusion Code: X2.26930521
579 Siqueland L, Rynn M, Diamond GS. Cognitive behavioral and attachment based family therapy for anxious adolescents: Phase I and II studies. J Anxiety Disord. 2005;19(4):361–81. doi: 10.1016/j.janxdis.2004.04.006. PMID: 15721570. Exclusion Code: X4.15721570
580 Smith AM, Flannery-Schroeder EC, Gorman KS, . Parent cognitive-behavioral intervention for the treatment of childhood anxiety disorders: a pilot study. Behav Res Ther. 2014;61:156–61. doi: 10.1016/j.brat.2014.08.010. PMID: 2014-38494-001. Exclusion Code: X13.25217169
581 Smith L, Jackson SE, Jacob L, . Leisure-Time Sedentary Behavior, Alcohol Consumption, and Sexual Intercourse Among Adolescents Aged 12-15 Years in 19 Countries From Africa, the Americas, and Asia. J Sex Med. 2019 Sep;16(9):1355–63. doi: 10.1016/j.jsxm.2019.06.013. PMID: 31351852. Exclusion Code: X2.31351852
582 Solberg JJ, Deyo-Svendsen ME, Nylander KR, . Collaborative Care Management Associated With Improved Depression Outcomes in Patients With Personality Disorders, Compared to Usual Primary Care. J Prim Care Community Health. 2018 Jan–Dec;9:2150132718773266. doi: 10.1177/2150132718773266. PMID: 29739287. Exclusion Code: X2.29739287
583 Sood ED, Kendall PC. Assessing anxious self-talk in youth: The Negative Affectivity Self-Statement Questionnaire--Anxiety Scale. Cognit Ther Res. 2007;31(5):603–18. doi: 10.1007/s10608-006-9043-8. PMID: 2008-00189-003. Exclusion Code: X5.
584 Soria-Saucedo R, Walter HJ, Cabral H, . Receipt of Evidence-Based Pharmacotherapy and Psychotherapy Among Children and Adolescents With New Diagnoses of Depression. Psychiatr Serv. 2016 Mar;67(3):316–23. doi: 10.1176/appi.ps.201500090. PMID: 26725295. Exclusion Code: X7.26725295
585 Southam-Gerow MA, Weisz JR, Chu BC, . Does cognitive behavioral therapy for youth anxiety outperform usual care in community clinics? An initial effectiveness test. J Am Acad Child Adolesc Psychiatry. 2010 Oct;49(10):1043–52. doi: 10.1016/j.jaac.2010.06.009. PMID: 20855049. Exclusion Code: X4.20855049
586 Spence SH, Donovan C, Brechman-Toussaint M. The treatment of childhood social phobia: the effectiveness of a social skills training-based, cognitive-behavioural intervention, with and without parental involvement. J Child Psychol Psychiatry. 2000 Sep;41(6):713–26. PMID: 11039684. Exclusion Code: X13.11039684
587 Spence SH, Donovan CL, March S, . A randomized controlled trial of online versus clinic-based CBT for adolescent anxiety. J Consult Clin Psychol. 2011 Oct;79(5):629–42. doi: 10.1037/a0024512. PMID: 21744945. Exclusion Code: X13.21744945
588 Spence SH, Donovan CL, March S, . Generic versus disorder specific cognitive behavior therapy for social anxiety disorder in youth: a randomized controlled trial using internet delivery. Behav Res Ther. 2017 Mar;90:41–57. doi: 10.1016/j.brat.2016.12.003. PMID: 27988427. Exclusion Code: X13.27988427
589 Spence SH, Holmes JM, March S, . The feasibility and outcome of clinic plus Internet delivery of cognitive-behavior therapy for childhood anxiety. J Consult Clin Psychol. 2006;74(3):614–21. doi: 10.1037/0022-006X.74.3.614. PMID: 2006-08433-020. Exclusion Code: X13.16822117
590 Steeg S, Kapur N, Webb R, . The development of a population-level clinical screening tool for self-harm repetition and suicide: the ReACT Self-Harm Rule. Psychol Med. 2012 Nov;42(11):2383–94. doi: 10.1017/s0033291712000347. PMID: 22394511. Exclusion Code: X3.22394511
591 Sterling S, Kline-Simon AH, Weisner C, . Pediatrician and Behavioral Clinician-Delivered Screening, Brief Intervention and Referral to Treatment: Substance Use and Depression Outcomes. J Adolesc Health. 2018 Apr;62(4):390–6. doi: 10.1016/j.jadohealth.2017.10.016. PMID: 29396080. Exclusion Code: X9.29396080
592 Stikkelbroek Y, Bodden D. Effectiveness of cognitive behaviours therapy (CBT), in clinically depressed adolescents versus Treatment As Usual (TAU). Eur Child Adolesc Psychiatry. 2015;24(1):S119-. doi: 10.1007/s00787-015-0714-4. PMID: CN-01098690. Exclusion Code: X9.
593 Stikkelbroek Y, Bodden DH, Deković M, . Effectiveness and cost effectiveness of cognitive behavioral therapy (CBT) in clinically depressed adolescents: individual CBT versus treatment as usual (TAU). BMC Psychiatry. 2013 Nov 21;13:314. doi: 10.1186/1471-244x-13-314. PMID: 24261913. Exclusion Code: X11.24261913
594 Stikkelbroek Y, Vink G, Nauta MH, . Effectiveness and moderators of individual cognitive behavioral therapy versus treatment as usual in clinically depressed adolescents: a randomized controlled trial. Sci Rep. 2020 Sep 9;10(1):14815. doi: 10.1038/s41598-020-71160-1. PMID: 32908173. Exclusion Code: X2.32908173
595 St-Jacques J, Bouchard S, Bélanger C. Is virtual reality effective to motivate and raise interest in phobic children toward therapy? A clinical trial study of in vivo with in virtuo versus in vivo only treatment exposure. J Clin Psychiatry. 2010 Jul;71(7):924–31. doi: 10.4088/JCP.08m04822blu. PMID: 20441721. Exclusion Code: X2.20441721
596 Stjerneklar S, Hougaard E, Thastum M. Guided internet-based cognitive behavioral therapy for adolescent anxiety: Predictors of treatment response. Internet Interv. 2019 Mar;15:116–25. doi: 10.1016/j.invent.2019.01.003. PMID: 30792963. Exclusion Code: X7.30792963
597 Storch EA, Salloum A, King MA, . A randomized controlled trial in community mental health centers of computer-assisted cognitive behavioral therapy versus treatment as ususal for children with anxiety. Depress Anxiety. 2015 Nov;32(11):843–52. doi: 10.1002/da.22399. PMID: 26366886. Exclusion Code: X4.26366886
598 Storch EA, Salloum A, King MA, . A randomized controlled trial in community mental health centers of computer-assisted cognitive behavioral therapy versus treatment as usual for children with anxiety. Depress Anxiety. 2015;32(11):843–52. doi: 10.1002/da.22399. PMID: 2015-42406-001. Exclusion Code: X10.26366886
599 Strawn J, Mills J, Schroeder H, . Escitalopram in adolescents with generalized anxiety disorder: a double-blind, randomized, placebo-controlled study with pharmacogenomic and pharmacokinetic measures. Neuropsychopharmacology. 2019;44:88–9. doi: 10.1038/s41386-019-0545-y. PMID: CN-02120126. Exclusion Code: X9.
600 Strawn JR, Mills JA, Croarkin PE. Switching Selective Serotonin Reuptake Inhibitors in Adolescents with Selective Serotonin Reuptake Inhibitor-Resistant Major Depressive Disorder: Balancing Tolerability and Efficacy. J Child Adolesc Psychopharmacol. 2019 May;29(4):250–5. doi: 10.1089/cap.2018.0145. PMID: 30810350. Exclusion Code: X2.30810350
601 Strawn JR, Mills JA, Schroeder HK, . 5.27 A randomized, placebo-controlled study of Escitalopram in adolescents with generalized anxiety disorder. J Am Acad Child Adolesc Psychiatry. 2019;58(10):S254-. doi: 10.1016/j.jaac.2019.08.341. PMID: CN-01999038. Exclusion Code: X10.
602 Strawn JR, Welge JA, Wehry AM, . Efficacy and tolerability of antidepressants in pediatric anxiety disorders: a systematic review and meta-analysis. Depress Anxiety. 2015 Mar;32(3):149–57. doi: 10.1002/da.22329. PMID: 25449861. Exclusion Code: X7.25449861
603 Strunk CM, King KA, Vidourek RA, . Effectiveness of the surviving the teens® suicide prevention and depression awareness program: An impact evaluation utilizing a comparison group. Health Educ Behav. 2014;41(6):605–13. doi: 10.1177/1090198114531774. PMID: 2014-49127-005. Exclusion Code: X2.24786795
604 Stulmaker HL, Ray DC. Child-centered play therapy with young children who are anxious: A controlled trial. Child Youth Serv Rev. 2015;57:127–33. doi: 10.1016/j.childyouth.2015.08.005. PMID: 2015-42972-016. Exclusion Code: X2.
605 Su C, Aseltine R, Doshi R, . Machine learning for suicide risk prediction in children and adolescents with electronic health records. Transl Psychiatry. 2020 Nov 26;10(1):413. doi: 10.1038/s41398-020-01100-0. PMID: 33243979. Exclusion Code: X3.33243979
606 Sudhanthar S, Thakur K, Sigal Y, . Improving validated depression screen among adolescent population in primary care practice using electronic health records (EHR). BMJ Qual Improv Rep. 2015;4(1)doi: 10.1136/bmjquality.u209517.w3913. PMID: 26734415. Exclusion Code: X9.26734415
607 Suveg C, Hudson JL, Brewer G, . Cognitive-behavioral therapy for anxiety-disordered youth: secondary outcomes from a randomized clinical trial evaluating child and family modalities. J Anxiety Disord. 2009 Apr;23(3):341–9. doi: 10.1016/j.janxdis.2009.01.003. PMID: 19216048. Exclusion Code: X4.19216048
608 Swan AJ, Kendall PC, Olino T, . Results from the Child/Adolescent Anxiety Multimodal Longitudinal Study (CAMELS): Functional outcomes. J Consult Clin Psychol. 2018 Sep;86(9):738–50. doi: 10.1037/ccp0000334. PMID: 30138013. Exclusion Code: X7.30138013
609 Swart J, Apsche J. A comparative study of mode deactivation therapy (MDT) as an effective treatment of adolescents with suicidal and non-suicidal self-injury behaviors. International Journal of Behavioral Consultation and Therapy. 2014;9(3):47–52. doi: 10.1037/h0101640. PMID: 2019-11792-010. Exclusion Code: X2.
610 Takagaki K, Okamoto Y, Jinnin R, . Enduring effects of a 5-week behavioral activation program for subthreshold depression among late adolescents: an exploratory randomized controlled trial. Neuropsychiatr Dis Treat. 2018;14:2633–41. doi: 10.2147/ndt.s172385. PMID: 30349261. Exclusion Code: X2.30349261
611 Thabrew H, Stasiak K, Bavin LM, . Validation of the Mood and Feelings Questionnaire (MFQ) and Short Mood and Feelings Questionnaire (SMFQ) in New Zealand help-seeking adolescents. Int J Methods Psychiatr Res. 2018 Sep;27(3):e1610. doi: 10.1002/mpr.1610. PMID: 29465165. Exclusion Code: X2.29465165
612 Thompson EA, Eggert LL, Randell BP, . Evaluation of indicated suicide risk prevention approaches for potential high school dropouts. Am J Public Health. 2001 May;91(5):742–52. doi: 10.2105/ajph.91.5.742. PMID: 11344882. Exclusion Code: X5.11344882
613 Thompson H, Faig W, Gupta N, . Collaborative care for depression of adults and adolescents: measuring the effectiveness of screening and treatment uptake. Psychiatr Serv. 2019 Jul 1;70(7):604–7. doi: 10.1176/appi.ps.201800257. PMID: 31023189. Exclusion Code: X9.31023189
614 Tighe J, Shand F, Ridani R, . Ibobbly mobile health intervention for suicide prevention in Australian Indigenous youth: a pilot randomised controlled trial. BMJ Open. 2017 Jan 27;7(1):e013518. doi: 10.1136/bmjopen-2016-013518. PMID: 28132007. Exclusion Code: X2.28132007
615 Tillfors M, Andersson G, Ekselius L, . A randomized trial of internet-delivered treatment for social anxiety disorder in high school students. Cogn Behav Ther. 2011;40(2):147–57. doi: 10.1080/16506073.2011.555486. PMID: 2011-14818-007. Exclusion Code: X13.25155815
616 Timbremont B, Braet C, Dreessen L. Assessing depression in youth: relation between the Children’s Depression Inventory and a structured interview. J Clin Child Adolesc Psychol. 2004 Mar;33(1):149–57. doi: 10.1207/s15374424jccp3301_14. PMID: 15028549. Exclusion Code: X2.15028549
617 Tompson MC, Sugar CA, Asarnow JR. Family-focused treatment for childhood depressive disorders versus individual supportive treatment: results of a randomized clinical trial. J Am Acad Child Adolesc Psychiatry. 2016;55(10):S335-. doi: 10.1016/j.jaac.2016.07.403. PMID: CN-01304707. Exclusion Code: X12.
618 Topooco N, Berg M, Johansson S, . Chat- and Internet-based cognitive–behavioural therapy in treatment of adolescent depression: Randomised controlled trial. BJPsych Open. 2018;4(4):199–207. doi: 10.1192/bjo.2018.18. PMID: 2019-80313-001. Exclusion Code: X10.29988969
619 Topooco NW, Andersson G. Digital cognitive-behavioral therapy in the treatment of adolescent depression: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2017;56(10):S299–S300. doi: 10.1016/j.jaac.2017.09.411. PMID: CN-01452302. Exclusion Code: X10.
620 Torres Soler C, Olofsdotter S, Vadlin S, . Diagnostic accuracy of the Montgomery-Åsberg Depression Rating Scale parent report among adolescent psychiatric outpatients. Nord J Psychiatry. 2018 Apr;72(3):184–90. doi: 10.1080/08039488.2017.1414873. PMID: 29258381. Exclusion Code: X2.29258381
621 Toth SL, Handley ED, Manly JT, . The Moderating Role of Child Maltreatment in Treatment Efficacy for Adolescent Depression. J Abnorm Child Psychol. 2020 Oct;48(10):1351–65. doi: 10.1007/s10802-020-00682-z. PMID: 32696103. Exclusion Code: X4.32696103
622 Treadwell KR, Kendall PC. Self-talk in youth with anxiety disorders: states of mind, content specificity, and treatment outcome. J Consult Clin Psychol. 1996 Oct;64(5):941–50. doi: 10.1037//0022-006x.64.5.941. PMID: 8916623. Exclusion Code: X4.8916623
623 Trebatická J, Hradečná Z, Böhmer F, . Emulsified omega-3 fatty-acids modulate the symptoms of depressive disorder in children and adolescents: a pilot study. Child Adolesc Psychiatry Ment Health. 2017;11:30. doi: 10.1186/s13034-017-0167-2. PMID: 28690672. Exclusion Code: X3.28690672
624 Trentini C, Pagani M, Fania P, . Neural processing of emotions in traumatized children treated with Eye Movement Desensitization and Reprocessing therapy: a hdEEG study. Front Psychol. 2015;6:1662. doi: 10.3389/fpsyg.2015.01662. PMID: 26594183. Exclusion Code: X2.26594183
625 Trowell J, Joffe I, Campbell J, . Childhood depression: a place for psychotherapy. An outcome study comparing individual psychodynamic psychotherapy and family therapy. Eur Child Adolesc Psychiatry. 2007 Apr;16(3):157–67. doi: 10.1007/s00787-006-0584-x. PMID: 17200793. Exclusion Code: X4.17200793
626 Tsvieli N, Nir-Gottlieb O, Lifshitz C, . Therapist interventions associated with productive emotional processing in the context of attachment-based family therapy for depressed and suicidal adolescents. Fam Process. 2020;59(2):428–44. doi: 10.1111/famp.12445. PMID: 143653552. Language: English. Entry Date: 20200611. Revision Date: 20210601. Publication Type: Article. Exclusion Code: X7.30908627
627 Tulbure BT, Andersson G, Sălăgean N, . Religious versus conventional internet-based cognitive behavioral therapy for depression. J Relig Health. 2018 Oct;57(5):1634–48. doi: 10.1007/s10943-017-0503-0. PMID: 29067598. Exclusion Code: X2.29067598
628 Turgeon L, Chartrand E. Reliability and validity of the Revised Children’s Manifest Anxiety Scale in a French-Canadian sample. Psychol Assess. 2003 Sep;15(3):378–83. doi: 10.1037/1040-3590.15.3.378. PMID: 14593838. Exclusion Code: X9.14593838
629 Tze-Chun T, Shih-Yin H. Efficacy of school-based interpersonal psychotherapy to adolescents of early detected depressive and suicide ideations: randomized control study. Early intervention in psychiatry [abstracts of the 7th international conference on early psychosis - early psychoses: a lifetime perspective. 29 nov - 1 dec 2010; amsterdam, netherlands]. 2010 PMID: CN-00851153. Exclusion Code: X5.
630 Valla JP, Bergeron L, Smolla N. The Dominic-R: a pictorial interview for 6- to 11-year-old children. J Am Acad Child Adolesc Psychiatry. 2000 Jan;39(1):85–93. doi: 10.1097/00004583-200001000-00020. PMID: 10638071. Exclusion Code: X7.10638071
631 van Gastel W, Ferdinand RF. Screening capacity of the Multidimensional Anxiety Scale for Children (MASC) for DSM-IV anxiety disorders. Depress Anxiety. 2008;25(12):1046–52. doi: 10.1002/da.20452. PMID: 18833579. Exclusion Code: X5.18833579
632 van Lang ND, Ferdinand RF, Oldehinkel AJ, . Concurrent validity of the DSM-IV scales Affective Problems and Anxiety Problems of the Youth Self-Report. Behav Res Ther. 2005 Nov;43(11):1485–94. doi: 10.1016/j.brat.2004.11.005. PMID: 16159590. Exclusion Code: X3.16159590
633 Van Meter AR, Algorta GP, Youngstrom EA, . Assessing for suicidal behavior in youth using the Achenbach System of Empirically Based Assessment. Eur Child Adolesc Psychiatry. 2018 Feb;27(2):159–69. doi: 10.1007/s00787-017-1030-y. PMID: 28748484. Exclusion Code: X3.28748484
634 Van Roy B, Kristensen H, Groholt B, . Prevalence and characteristics of significant social anxiety in children aged 8-13 years: a Norwegian cross-sectional population study. Soc Psychiatry Psychiatr Epidemiol. 2009 May;44(5):407–15. doi: 10.1007/s00127-008-0445-7. PMID: 19015797. Exclusion Code: X7.19015797
635 van Starrenburg ML, Kuijpers RC, Hutschemaekers GJ, . Effectiveness and underlying mechanisms of a group-based cognitive behavioural therapy-based indicative prevention program for children with elevated anxiety levels. BMC Psychiatry. 2013 Jul 5;13:183. doi: 10.1186/1471-244x-13-183. PMID: 23827009. Exclusion Code: X2.23827009
636 van Starrenburg ML, Kuijpers RC, Kleinjan M, . Effectiveness of a Cognitive Behavioral Therapy-Based Indicated Prevention Program for Children with Elevated Anxiety Levels: a Randomized Controlled Trial. Prev Sci. 2017 Jan;18(1):31–9. doi: 10.1007/s11121-016-0725-5. PMID: 27822663. Exclusion Code: X2.27822663
637 Van Steensel F, Dirksen C, Bögels S. Cost-effectiveness of cognitive-behavioral therapy versus treatment as usual for anxiety disorders in children with autism spectrum disorder. Res Autism Spectr Disord. 2014;8(2):127–37. Exclusion Code: X2.
638 Van Voorhees B, Gladstone TRG, Sobowale K, . 24-Month Outcomes of Primary Care Web-Based Depression Prevention Intervention in Adolescents: Randomized Clinical Trial. J Med Internet Res. 2020 Oct 28;22(10):e16802. doi: 10.2196/16802. PMID: 33112254. Exclusion Code: X2.33112254
639 VanWinkle K, Kaur S, Parsh B. Screening adolescents for suicide risk. Nursing. 2020 Feb;50(2):19–20. doi: 10.1097/01.NURSE.0000615112.62845.3e. PMID: 31977801. Exclusion Code: X8.31977801
640 Verhulst FC, van der Ende J, Ferdinand RF, . The prevalence of DSM-III-R diagnoses in a national sample of Dutch adolescents. Arch Gen Psychiatry. 1997 Apr;54(4):329–36. doi: 10.1001/archpsyc.1997.01830160049008. PMID: 9107149. Exclusion Code: X9.9107149
641 Viana AG, Rabian B, Beidel DC. Self-report measures in the study of comorbidity in children and adolescents with social phobia: research and clinical utility. J Anxiety Disord. 2008 Jun;22(5):781–92. doi: 10.1016/j.janxdis.2007.08.005. PMID: 17888622. Exclusion Code: X7.17888622
642 Vigerland S, Ljótsson B, Thulin U, . Internet-delivered cognitive behavioural therapy for children with anxiety disorders: a randomised controlled trial. Behav Res Ther. 2016;76:47–56. doi: 10.1016/j.brat.2015.11.006. PMID: 2015-59077-007. Exclusion Code: X13.26649465
643 Villabø MA, Narayanan M, Compton SN, . Cognitive-behavioral therapy for youth anxiety: an effectiveness evaluation in community practice. J Consult Clin Psychol. 2018 Sep;86(9):751–64. doi: 10.1037/ccp0000326. PMID: 30138014. Exclusion Code: X10.30138014
644 Wagner G, Zeiler M, Waldherr K, . Mental health problems in Austrian adolescents: a nationwide, two-stage epidemiological study applying DSM-5 criteria. Eur Child Adolesc Psychiatry. 2017 Dec;26(12):1483–99. doi: 10.1007/s00787-017-0999-6. PMID: 28540609. Exclusion Code: X9.28540609
645 Wagner G, Zeiler M, Waldherr K, . Mental health problems in Austrian adolescents: A nationwide, two-stage epidemiological study applying DSM-5 criteria. Eur Child Adolesc Psychiatry. 2017;26(12):1483–99. doi: 10.1007/s00787-017-0999-6. PMID: 2017-23400-001. Exclusion Code: X9.28540609
646 Wagner KD, Robb AS, Findling RL, . A randomized, placebo-controlled trial of citalopram for the treatment of major depression in children and adolescents. Am J Psychiatry. 2004 Jun;161(6):1079–83. doi: 10.1176/appi.ajp.161.6.1079. PMID: 15169696. Exclusion Code: X3.15169696
647 Walkup J. The child/adolescent anxiety multimodal trial. Eur Child Adolesc Psychiatry. 2013;22(2):S165-. doi: 10.1007/s00787-013-0423-9. PMID: CN-01006225. Exclusion Code: X8.
648 Walkup J, Labellarte M, Riddle MA, . Treatment of pediatric anxiety disorders: an open-label extension of the research units on pediatric psychopharmacology anxiety study. J Child Adolesc Psychopharmacol. 2002 Fall;12(3):175–88. doi: 10.1089/104454602760386879. PMID: 12427292. Exclusion Code: X4.12427292
649 Wang Z, Whiteside S, Sim L, . AHRQ comparative effectiveness reviews. Anxiety in Children. Rockville (MD): Agency for Healthcare Research and Quality (US); 2017. Exclusion Code: X7.
650 Waraan L, Rognli EW, Czajkowski NO, . Effectiveness of attachment-based family therapy compared to treatment as usual for depressed adolescents in community mental health clinics. Child Adolesc Psychiatry Ment Health. 2021 Feb 12;15(1):8. doi: 10.1186/s13034-021-00361-x. PMID: 33579332. Exclusion Code: X4.33579332
651 Waraan L, Rognli EW, Czajkowski NO, . Efficacy of attachment-based family therapy compared to treatment as usual for suicidal ideation in adolescents with MDD. Clin Child Psychol Psychiatry. 2021 Apr;26(2):464–74. doi: 10.1177/1359104520980776. PMID: 33349055. Exclusion Code: X4.33349055
652 Warner CM, Colognori D, Kim RE, . Cognitive-behavioral treatment of persistent functional somatic complaints and pediatric anxiety: an initial controlled trial. Depress Anxiety. 2011 Jul;28(7):551–9. doi: 10.1002/da.20821. PMID: 21681863. Exclusion Code: X13.21681863
653 Waseem M, Diaz-Guerrero RJ, Cosme R, . Do all children with suicidal ideation receive a significant psychiatric intervention? Pediatr Int. 2015 Jun;57(3):381–4. doi: 10.1111/ped.12527. PMID: 25330120. Exclusion Code: X7.25330120
654 Waters AM, Ford LA, Wharton TA, . Cognitive-behavioural therapy for young children with anxiety disorders: comparison of a child + parent condition versus a parent only condition. Behav Res Ther. 2009 Aug;47(8):654–62. doi: 10.1016/j.brat.2009.04.008. PMID: 19457471. Exclusion Code: X13.19457471
655 Waters AM, Pittaway M, Mogg K, . Attention training towards positive stimuli in clinically anxious children. Dev Cogn Neurosci. 2013 Apr;4:77–84. doi: 10.1016/j.dcn.2012.09.004. PMID: 23063461. Exclusion Code: X4.23063461
656 Waters AM, Zimmer-Gembeck MJ, Craske MG, . Look for good and never give up: A novel attention training treatment for childhood anxiety disorders. Behav Res Ther. 2015 Oct;73:111–23. doi: 10.1016/j.brat.2015.08.005. PMID: 26310362. Exclusion Code: X3.26310362
657 Waters AM, Zimmer-Gembeck MJ, Craske MG, . A preliminary evaluation of a home-based, computer-delivered attention training treatment for anxious children living in regional communities. Journal of Experimental Psychopathology. 2016;7(3):511–27. doi: 10.5127/jep.053315. PMID: 2016-58566-015. Exclusion Code: X3.
658 Watson DR, Garfinkel SN, Gould van Praag C, . Computerized Exposure Therapy for Spider Phobia: Effects of Cardiac Timing and Interoceptive Ability on Subjective and Behavioral Outcomes. Psychosom Med. 2019 Jan;81(1):90–9. doi: 10.1097/psy.0000000000000646. PMID: 30300237. Exclusion Code: X2.30300237
659 Weihs KL, Murphy W, Abbas R, . Desvenlafaxine versus placebo in a fluoxetine-referenced study of children and adolescents with major depressive disorder. J Child Adolesc Psychopharmacol. 2018 Feb;28(1):36–46. doi: 10.1089/cap.2017.0100. PMID: 29189044. Exclusion Code: X13.29189044
660 Weisz JR, Bearman SK, Ugueto AM, . Testing Robustness of Child STEPs Effects with Children and Adolescents: A Randomized Controlled Effectiveness Trial. J Clin Child Adolesc Psychol. 2019 Sep 13:1–14. doi: 10.1080/15374416.2019.1655757. PMID: 31517543. Exclusion Code: X2.31517543
661 Weitkamp K, Daniels JK, Baumeister-Duru A, . Effectiveness trial of psychoanalytic psychotherapy for children and adolescents with severe anxiety symptoms in a naturalistic treatment setting. British Journal of Psychotherapy. 2018;34(2):300–18. doi: 10.1111/bjp.12363. PMID: 2018-18129-012. Exclusion Code: X3.
662 Wergeland GJ, Fjermestad KW, Marin CE, . An effectiveness study of individual vs. group cognitive behavioral therapy for anxiety disorders in youth. Behav Res Ther. 2014 Jun;57:1–12. doi: 10.1016/j.brat.2014.03.007. PMID: 24727078. Exclusion Code: X13.24727078
663 Whalen DJ, Gilbert KE, Luby JL. Changes in self-reported and observed parenting following a randomized control trial of parent-child interaction therapy for the treatment of preschool depression. J Child Psychol Psychiatry. 2021 Jan;62(1):86–96. doi: 10.1111/jcpp.13263. PMID: 32469454. Exclusion Code: X9.32469454
664 Wharff EA, Ginnis KM, Ross AM. Family-based crisis intervention with suicidal adolescents in the emergency room: a pilot study. Soc Work. 2012 Apr;57(2):133–43. doi: 10.1093/sw/sws017. PMID: 23038875. Exclusion Code: X5.23038875
665 White SW, Capriola-Hall NN, Wieckowski AT, . Change in gaze-based attention bias in adolescents with social anxiety disorder. Cog Emot. 2019;33(8):1736–44. doi: 10.1080/02699931.2019.1598938. PMID: 2019-18278-001. Exclusion Code: X3.
666 Wilkinson PO, Goodyer IM. The effects of cognitive-behavioural therapy on mood-related ruminative response style in depressed adolescents. Child Adolesc Psychiatry Ment Health. 2008 Jan 29;2(1):3. doi: 10.1186/1753-2000-2-3. PMID: 18230146. Exclusion Code: X4.18230146
667 Willging CE, Green AE, Ramos MM. Implementing school nursing strategies to reduce LGBTQ adolescent suicide: a randomized cluster trial study protocol. Implement Sci. 2016 Oct 22;11(1):145. doi: 10.1186/s13012-016-0507-2. PMID: 27770819. Exclusion Code: X11.27770819
668 Wolff JC, Garcia A, Kelly LM, . Feasibility of decision rule-based treatment of comorbid youth: A pilot randomized control trial. Behav Res Ther. 2020 Aug;131:103625. doi: 10.1016/j.brat.2020.103625. PMID: 32353635. Exclusion Code: X4.32353635
669 Wolk CB, Jager-Hyman S, Marcus SC, . Developing implementation strategies for firearm safety promotion in paediatric primary care for suicide prevention in two large US health systems: a study protocol for a mixed-methods implementation study. BMJ Open. 2017 Jun 24;7(6):e014407. doi: 10.1136/bmjopen-2016-014407. PMID: 28647722. Exclusion Code: X3.28647722
670 Wong DFK, Ng TK, Zhuang XY, . Cognitive-behavior therapy with and without parental involvement for anxious Chinese adolescents: A randomized controlled trial. J Fam Psychol. 2020;34(3):353–63. doi: 10.1037/fam0000585. PMID: 2019-46165-001. Exclusion Code: X2.31414865
671 Wood JJ, Piacentini JC, Bergman RL, . Concurrent validity of the anxiety disorders section of the Anxiety Disorders Interview Schedule for DSM-IV: child and parent versions. J Clin Child Adolesc Psychol. 2002 Sep;31(3):335–42. doi: 10.1207/s15374424jccp3103_05. PMID: 12149971. Exclusion Code: X2.12149971
672 Wright B, Tindall L, Hargate R, . Computerised cognitive behavioural therapy for depression in adolescents: 12-month outcomes of a UK randomised controlled trial pilot study. Bjpsych open. 2020;6(1)doi: 10.1192/bjo.2019.91. PMID: CN-02205438. Exclusion Code: X2.
673 Wright B, Tindall L, Hargate R, . Computerised cognitive-behavioural therapy for depression in adolescents: 12-month outcomes of a UK randomised controlled trial pilot study. BJPsych Open. 2019 Dec 12;6(1):e5. doi: 10.1192/bjo.2019.91. PMID: 31829300. Exclusion Code: X2.31829300
674 Wright B, Tindall L, Littlewood E, . Computerised cognitive-behavioural therapy for depression in adolescents: feasibility results and 4-month outcomes of a UK randomised controlled trial. BMJ Open. 2017 Jan 27;7(1):e012834. doi: 10.1136/bmjopen-2016-012834. PMID: 28132000. Exclusion Code: X2.28132000
675 Wright DR, Haaland WL, Ludman E, . The Costs and Cost-effectiveness of Collaborative Care for Adolescents With Depression in Primary Care Settings: A Randomized Clinical Trial. JAMA Pediatr. 2016 Nov 1;170(11):1048–54. doi: 10.1001/jamapediatrics.2016.1721. PMID: 27654449. Exclusion Code: X9.27654449
676 Wright DR, Katon WJ, Ludman E, . Association of Adolescent Depressive Symptoms With Health Care Utilization and Payer-Incurred Expenditures. Acad Pediatr. 2016 Jan–Feb;16(1):82–9. doi: 10.1016/j.acap.2015.08.013. PMID: 26456002. Exclusion Code: X9.26456002
677 Wright-Hughes A, Graham E, Farrin A, . Self-Harm Intervention: Family Therapy (SHIFT), a study protocol for a randomised controlled trial of family therapy versus treatment as usual for young people seen after a second or subsequent episode of self-harm. Trials. 2015 Nov 4;16:501. doi: 10.1186/s13063-015-1007-4. PMID: 26537599. Exclusion Code: X11.26537599
678 Wuthrich VM, Rapee RM, Cunningham MJ, . A randomized controlled trial of the Cool Teens CD-ROM computerized program for adolescent anxiety. J Am Acad Child Adolesc Psychiatry. 2012 Mar;51(3):261–70. doi: 10.1016/j.jaac.2011.12.002. PMID: 22365462. Exclusion Code: X13.22365462
679 Xavier A, Otero P, Blanco V, . Efficacy of a problem-solving intervention for the indicated prevention of suicidal risk in young Brazilians: Randomized controlled trial. Suicide Life Threat Behav. 2019 Dec;49(6):1746–61. doi: 10.1111/sltb.12568. PMID: 31237377. Exclusion Code: X6.31237377
680 Yang W, Zhang JX, Ding Z, . Attention Bias Modification Treatment for Adolescents With Major Depression: A Randomized Controlled Trial. J Am Acad Child Adolesc Psychiatry. 2016 Mar;55(3):208–18.e2. doi: 10.1016/j.jaac.2015.12.005. PMID: 26903254. Exclusion Code: X6.26903254
681 Yang X, Stewart SM. The Beck Depression Inventory-II as a screening tool of depression in the Chinese adolescent population in Hong Kong: A validation study using the Composite International Diagnostic Interview as the gold standard. Asian J Psychiatr. 2020 Aug;52:102125. doi: 10.1016/j.ajp.2020.102125. PMID: 32388053. Exclusion Code: X13.32388053
682 Yang Y, Dillon EC, Li M, . Primary care provider utilization and satisfaction with a health system navigation program for adolescents with behavioral health needs. Transl Behav Med. 2019 May 16;9(3):549–59. doi: 10.1093/tbm/ibz049. PMID: 31094446. Exclusion Code: X9.31094446
683 Yap MBH, Mahtani S, Rapee RM, . A Tailored Web-Based Intervention to Improve Parenting Risk and Protective Factors for Adolescent Depression and Anxiety Problems: Postintervention Findings From a Randomized Controlled Trial. J Med Internet Res. 2018 Jan 19;20(1):e17. doi: 10.2196/jmir.9139. PMID: 29351895. Exclusion Code: X2.29351895
684 Yee AM, Algorta GP, Youngstrom EA, . Unfiltered Administration of the YMRS and CDRS-R in a Clinical Sample of Children. J Clin Child Adolesc Psychol. 2015;44(6):992–1007. doi: 10.1080/15374416.2014.915548. PMID: 24885078. Exclusion Code: X2.24885078
685 Yen CF, Chen YM, Cheng JW, . Effects of cognitive-behavioral therapy on improving anxiety symptoms, behavioral problems and parenting stress in Taiwanese children with anxiety disorders and their mothers. Child Psychiatry Hum Dev. 2014 Jun;45(3):338–47. doi: 10.1007/s10578-013-0403-9. PMID: 24002227. Exclusion Code: X4.24002227
686 Yen S, Ranney ML, Krek M, . Skills to enhance positivity in suicidal adolescents: Results from a pilot randomized clinical trial. J Posit Psychol. 2020;15(3):348–61. doi: 10.1080/17439760.2019.1615105. PMID: 142382324. Language: English. Entry Date: 20200401. Revision Date: 20200413. Publication Type: Article. Exclusion Code: X5.32884576
687 Yen S, Spirito A, Weinstock LM, . Coping long term with active suicide in adolescents: Results from a pilot randomized controlled trial. Clin Child Psychol Psychiatry. 2019 Oct;24(4):847–59. doi: 10.1177/1359104519843956. PMID: 31064203. Exclusion Code: X2.31064203
688 Young J, Mufson L, Gillham JE, . The depression prevention initiative: effects on depression symptoms and diagnoses. Journal of the american academy of child and adolescent psychiatry. Conference: 63rd annual meeting of the american academy of child and adolescent psychiatry. United states. Conference start: 20161024. Conference end: 20161029. 2016;55(10 Supplement 1):S334–S5. doi: 10.1016/j.jaac.2016.07.402. PMID: CN-01472683. Exclusion Code: X12.
689 Youngstrom EA, Van Meter A, Frazier TW, . Developing and validating short forms of the parent general behavior inventory mania and depression scales for rating youth mood symptoms. J Clin Child Adolesc Psychol. 2020;49(2):162–77. doi: 10.1080/15374416.2018.1491006. PMID: 2018-36704-001. Exclusion Code: X2.30040496
690 Zhou X, Qin B, Whittington C, . Comparative efficacy and tolerability of first-generation and newer-generation antidepressant medications for depressive disorders in children and adolescents: study protocol for a systematic review and network meta-analysis. BMJ Open. 2015 Sep 9;5(9):e007768. doi: 10.1136/bmjopen-2015-007768. PMID: 26353868. Exclusion Code: X11.26353868
691 Zhou Y, Arend J, Mufson L, . Change in dysfunctional attitudes and attachment in interpersonal psychotherapy for depressed adolescents. Psychother Res. 2021 Feb;31(2):258–66. doi: 10.1080/10503307.2020.1756513. PMID: 32351173. Exclusion Code: X4.32351173
692 Zwier KJ, Rao U. Buspirone use in an adolescent with social phobia and mixed personality disorder (cluster A type). J Am Acad Child Adolesc Psychiatry. 1994 Sep;33(7):1007–11. doi: 10.1097/00004583-199409000-00011. PMID: 7961339. Exclusion Code: X3.7961339