# Appendix I Additional Evidence Tables

Appendix I Table 1 Anxiety Diagnostic Test Accuracy Studies: Study Characteristics (KQ 2)

Appendix I Table 2 Suicide Risk Harms of Screening Studies: Study Characteristics (KQ 3)

Appendix I Table 3 Suicide Risk Harms of Screening Studies: Population Characteristics (KQ 3)

Appendix I Table 4 Suicide Risk Harms of Screening Studies: Outcomes (KQ 3)

Appendix I Table 5 Suicide Risk Treatment Studies: Study Characteristics (KQ 4 & KQ 5)

Appendix I Table 6 Suicide Risk Treatment Studies: Population Characteristics (KQ 4 & KQ 5)

Appendix I Table 7 Suicide Risk Treatment Studies: Suicide Death Outcomes (KQ 4)

Appendix I Table 8 Suicide Risk Treatment Studies: Suicide Attempts or Episode of Deliberate Self-Harm Outcomes (KQ 4)

Appendix I Table 9 Suicide Risk Treatment Studies: Suicide-Related Hospitalization or Emergency Department Use Outcomes (KQ 4)

Appendix I Table 10 Suicide Risk Treatment Studies: Measures of Suicide Risk Outcomes (KQ 4)

Appendix I Table 11 Suicide Risk Treatment Studies: Anxiety-Related Outcomes (KQ 4)

Appendix I Table 12 Suicide Risk Treatment Studies: Depression-Related Outcomes (KQ 4)

Appendix I Table 13 Suicide Risk Treatment Studies: Response and Remission Outcomes (KQ 4)

Appendix I Table 14 Suicide Risk Treatment Studies: Functioning Outcomes (KQ 4)

Appendix I Table 15 Suicide Risk Treatment Studies: Subgroups (KQ 4)

Appendix I Table 16 Suicide Risk Treatment Studies: Harms (KQ 5)

Appendix I Table 17 Anxiety Treatment Studies: Study Characteristics (KQ 4 & KQ 5)

Appendix I Table 18 Anxiety Treatment Studies: Population Characteristics (KQ 4)

Appendix I Table 19 Anxiety Treatment Studies: Anxiety-Related Outcomes (KQ 4)

Appendix I Table 21 Anxiety Treatment Studies: Response, Remission, and Loss of Diagnosis (KQ 4)

Appendix I Table 21 Anxiety Treatment Studies: Response, Remission, and Loss of Diagnosis (KQ 4)

Appendix I Table 22 Anxiety Treatment Studies: Functioning Outcomes (KQ 4)

Appendix I Table 23 Anxiety Treatment Studies: Suicide-Related Harms and Suicide-Related Withdrawal (KQ 5)

Appendix I Table 24 Anxiety Treatment Studies: Harms (KQ 5)

Appendix I Table 25 Depression Treatment Studies: Characteristics (KQ 4 & KQ 5)

Appendix I Table 26 Depression Treatment Studies: Population Characteristics (KQ 4 & KQ 5)

Appendix I Table 27 Depression Treatment Studies: Depression-Related Outcomes (KQ 4)

Appendix I Table 28 Depression Treatment Studies: Anxiety-Related Outcomes (KQ 4)

Appendix I Table 29 Depression Treatment Studies: Response, Remission, and Loss of Diagnosis (KQ 4)

Appendix I Table 30 Depression Treatment Studies: Functioning Outcomes (KQ 4)

Appendix I Table 31 Depression Treatment Studies: Suicide-Related Harms and Suicide-Related Withdrawal (KQ 5)

Appendix I Table 32 Depression Treatment Studies: Harms (KQ 5)

Appendix I Table 33 Depression Studies: Characteristics of Systematic Reviews, Meta-Analyses, or Network Meta-Analyses (KQ 5)

Appendix I Table 34 Depression Studies: Results of Systematic Reviews, Meta-Analyses, or Network Meta-Analyses (KQ 5)

Appendix I Table 35 Anxiety or Depression Treatment Studies: Study Characteristics (KQ 4 & KQ 5)

Appendix I Table 36 Anxiety or Depression Treatment Studies: Population Characteristics (KQ 4 & KQ 5)

Appendix I Table 37 Anxiety or Depression Treatment Studies: Anxiety-Related Outcomes (KQ 4)

Appendix I Table 38 Anxiety or Depression Treatment Studies: Depression-Related Outcomes (KQ 4)

Appendix I Table 39 Anxiety or Depression Treatment Studies: Response, Remission, and Loss of Diagnosis Outcomes (KQ 5)

Appendix I Table 40 Anxiety or Depression Treatment Studies: Functioning Outcomes (KQ 4)