# Appendix H Results of Treatment for Off-Target Conditions and Symptoms

## Overview

Appendix H includes a synthesis of results for symptoms other than those directly targeted by the intervention, specifically, anxiety and depression for suicide risk interventions; depression for anxiety interventions; and anxiety for depression interventions.

## Suicide Risk

### Results: Anxiety Symptoms

#### Psychotherapy vs. Treatment as Usual or Attention Control

Three studies reported on the effects of suicide or self-harm interventions on anxiety symptoms at the end of treatment (1 month to 12 weeks).^94,^ ^100,^ ^144^ Studies compared MBT,^94^ IPT-A-IN,^144^ child interview with counseling,^100^ parent sessions,^100^ or child interview with counseling plus parent sessions^100^ with TAU. Two of the interventions^94,^ ^144^ were high contact (>3 sessions), and one intervention^100^ was low contact (<3 sessions). The results could not be pooled because of differences in measures; the findings were mixed. Reported anxiety measures included the RCADS,^94^ BAI,^144^ and four individual anxiety items (e.g., “I feel uneasy or anxious”).^100^ Study sample sizes ranged from 53 to 615. Statistically significant improvement in anxiety symptoms was reported for the treatment arms of the IPT-A-IN (11.94 vs. 25.45, p<0.001),^144^ child interview with counseling (rate of change: −0.683 vs. −0.440, p<0.05), and child interview with counseling plus parent sessions (rate of change at 1 month: −0.849 vs. −0.440, p<0.001)^100^ at the end of treatment. No significant differences were reported on the RCADS at the end of treatment between MBT and TAU.^94^ One study of child interview with counseling plus parent sessions continued to report statistically significant differences between arms at 1 month in addition to 2.5 months and continued to find statistically significant differences between arms.^100^

### Results: Depression Symptoms

#### Psychotherapy vs. Treatment as Usual or Attention Control

Thirteen studies reported on the effects of suicide or self-harm interventions on depression symptoms at the end of treatment (2 weeks to 12 months).^80,^ ^82,^ ^93–95,^ ^97,^ ^100,^ ^107,^ ^108,^ ^115,^ ^128,^ ^144,^ ^159,^ ^199–203^ Included studies compared family therapy,^80,^ ^199,^ ^200^ attachment-based therapy,^82^ group psychotherapy,^93,^ ^95^ MBT,^94^ internet-based CBT,^97^ child interview with counseling,^100^ parent sessions,^100^ child interview with counseling plus parent sessions,^100^ youth-nominated support team,^108^ motivational interviewing,^107^ DBT,^115,^ ^201–203^ mentalization-based treatment,^128^ IPT-A-IN,^144^ and developmental group therapy.^159^ Overall nine trials^80,^ ^82,^ ^93–95,^ ^115,^ ^128,^ ^144,^ ^159,^ ^199–203^ examined high-contact interventions (>3 sessions), and four trials^97,^ ^100,^ ^107,^ ^108^ examined limited-contact interventions (<3 sessions). Twelve studies compared intervention with TAU,^80,^ ^82,^ ^93–95,^ ^100,^ ^107,^ ^108,^ ^115,^ ^128,^ ^144,^ ^159,^ ^199–203^ and one study compared intervention with attention control.^97^ Studies reported on a variety of instruments including the BDI-II, CDRS-R, CES-D, MADRS, MFQ, RCADS, RCADS-2-SF, and SMFQ. Study sample sizes ranged from 49 to 832. The most commonly reported measure was the MFQ.

Five studies reported on the MFQ^93,^ ^95,^ ^128,^ ^159^ or SMFQ at the end of treatment. The MFQ is a 13-item self-report measure with a range of 0 to 68. A cutoff of 28/29 discriminates between adolescents with major depression and those with subthreshold depression or with no depressive disorder. Posttreatment MFQ scores in the intervention arms ranged from 21.9 to 30.91, while scores in the control arm ranged from 23.4 to 32.38. The SMFQ is a 13-item self-report measure with a range of 0 to 26. A general cutoff of 8 discriminates between children and adolescents with clinical depression. For one study that reported an SMFQ score, the posttreatment mean score in the intervention arm was 10.2, while the mean score in the control arm was 12.6. Of these five studies, the standardized mean difference was −0.17 (Appendix H Figure 1, 95% CI, −0.43 to 0.09; N=633, I^2^=52%). One study of group psychotherapy continued to find no statistically significant differences between group psychotherapy and routine care at 12 months.^93^ A study of group therapy continued to find no statistically significant differences between group therapy and routine care at 12 months.^95^

Seven studies reported on other depression measures (BDI-II, CDRS-R, RCADS, RCADS-2-SF, and MFQ) at the end of treatment (2 weeks to 12 months).^80,^ ^82,^ ^94,^ ^97,^ ^107,^ ^108,^ ^128,^ ^144,^ ^199,^ ^200,^ ^221^ Three studies reported statistically significant differences between groups; one on the BDI-II (19.97 vs. 31.58, p<0.001),^144^ one on the MFQ (9.26 vs. 11.54, p<0.05),^128^ and one on RADS-2-SF (25.38 vs. 30.87, p<0.01) favoring intervention.^107^ One study^100^ reported that child interview with counseling and the combination of child interview with counseling plus parent sessions significantly improved CES-D scores compared with TAU (rate of change: −0.951 vs. −0.685, p<0.01; rate of change: −1.021 vs. −0.685, p<0.01). Within the same study, parent-only sessions did not significantly improve depression scores. Six studies reported no statistically significant differences between intervention and TAU; of these, two reported on the CDRS-R;^80,^ ^108,^ ^199,^ ^200^ one each reported on the BDI-II,^82^ RCADS-MD,^94^ and RADS-2.^97^ Five studies reported on the CDRS-R,^80,^ ^199,^ ^200^ BDI-II,^82^ MFQ,^93^ RCADS-MD,^94^ and RADS-2^97^ at posttreatment and additional followups (8 weeks to 18 months) and continued to find no statistically significant differences between intervention and TAU.

One study reported on remission of depression symptoms based on the BDI-II.^82^ Remission was defined as a BDI-II score ≤ 9. The study reported no statistically significant differences between attachment-based therapy and enhanced usual care at the end of treatment (12 weeks, OR 2.70; 95% CI, 1.03 to 17.07; p=0.06) or at 24 weeks (OR, 2.21; 95% CI, 0.76 to 6.42; p=0.14).

## Anxiety

### Results: Depression Symptoms

#### Psychotherapy vs. Wait-List Controls, Treatment as Usual, or Placebo

In addition to reporting on anxiety symptom outcomes, 10 studies reported on depression symptoms.^65,^ ^70,^ ^103,^ ^112,^ ^120,^ ^122,^ ^141,^ ^145,^ ^152,^ ^153,^ ^205–211^ Four studies reported CDI outcomes at the end of treatment (data were reported at 8 to 16 weeks from baseline).^70,^ ^103,^ ^112,^ ^120^ CDI total scores ranged from 0 to 54 with a cutoff of 17 to 19 indicating a clinically relevant level of depressive symptoms.^222^ Three studies had two active arms compared with the wait-list condition: telephone vs. email vs. client initiated “on their own,”^112^ child focused vs. child and parent focused^120,^ ^212^ or child plus family focused.^70^ Posttreatment scores in the CBT arms ranged from 4.1 to 14.6, while scores in the wait-list arm ranged from 6.8 to 19.1. The pooled mean difference, averaging across multiple study arms in studies with more than one active arm, was −2.80 (Appendix H Figure 2, 95% CI, −4.74 to −0.86; N=280; k=4; I^2^=0%).

Four studies reported child-rated short-MFQ scores at the end of treatment (data were reported at 10 to 17 weeks from baseline).^65,^ ^141,^ ^145,^ ^152^ Child-rated short-MFQ scores ranged from 0 to 26^223^ with a cutoff of 10 to 12 commonly used to indicate the presence of depression. One study had two active arms compared with a wait-list condition: brief vs. full CBT.^145^ Posttreatment scores in the CBT arms ranged from 3.0 to 8.1, while scores in the wait-list arm ranged from 5.2 to 7.8. The pooled mean difference, averaging across multiple study arms with more than one active arm,^145^ was −1.14 (Appendix H Figure 3, 95% CI, −2.35 to 0.06; N=379; k=4; I^2^=4%).

The same four studies also reported on parent-rated short-MFQ measures, but the respondent (mother vs. father) varied by study.^65,^ ^141,^ ^145,^ ^152^ Two studies reported separately on ratings from mothers and fathers,^65,^ ^141^ and two reported a single rating for parents.^145,^ ^152^ Posttreatment scores in the CBT arm ranged from 2.0 to 7.2, while scores in the wait-list arm ranged from 4.9 to 9.5. The pooled mean difference, averaging across multiple study arms with more than one active arm and across parental measures, was −1.89 (Appendix H Figure 4, 95% CI, −3.04 to −0.74; N=367; k=4; I^2^=0%).

Two studies reported child-rated MFQ outcomes at the end of treatment (data were reported at 10 to 12 weeks from baseline).^122,^ ^153,^ ^205–211^ Child-rated MFQ^224^ scores ranged from 0 to 66 with a cutoff score of 27 to 29 commonly used to indicate the presence of depression. Posttreatment scores ranged from 4.6 to 6.9 in the CBT arms, while scores in the wait-list arms ranged from 6.4 to 25.4. One study^122^ reported a statistically significant difference between arms favoring CBT (effect size partial eta squared=0.40, p<0.001). The other study did not find a statistically significant difference.^153,^ ^205–211,^ ^216^ The same two studies reported parent-rated MFQ outcomes at the end of treatment.^122,^ ^153,^ ^205–211^ Posttreatment scores ranged from 4.1 to 10.1 in the CBT arm, while scores in the wait-list arm ranged from 8.0 to 20.9. One study reported statistically significant differences between arms favoring CBT (effect size partial eta squared=0.19, p<0.01).^122^ The second study did not report a statistically significant difference.^153,^ ^205–211^

One study reported DSRS outcomes at the end of treatment (data were reported at 8 or 16 weeks from baseline).^103^ Child-rated DSRS scores ranged from 0 to 36 with a cutoff score of 16 used to indicate depression.^225^ No statistical difference was found on the DSRS.

#### Pharmacotherapy vs. Placebo

In addition to reporting on anxiety symptom outcomes, two sertraline studies (N=22 and N=209) reported on three different measures of depression symptoms at the end of treatment: clinician-rated HAM-D, parent-rated MFQ, and child-rated MFQ.^130,^ ^153,^ ^205–211,^ ^216^ The results were consistent for HAM-D and parent-rated MFQ in reporting statistically significant benefits for sertraline. One study found a statistically significant difference in HAM-D scores at 9 weeks from baseline when compared with placebo (4.0 vs. 11.5, p<0.001).^130^ A HAM-D score of less than 8 is generally^226^ considered to be within the normal range. The second study found a statistically significant difference in parent-rated MFQ scores at 12 weeks from baseline when compared with placebo (5.0 vs. 8.0, p<0.001) but no differences in child-rated MFQ scores. An MFQ score of 12 or higher may indicate depression.^205^ Both arms reported MFQ scores of 13 or higher in both arms at baseline and scores below 12 at followup.^205^

#### Combination Therapy (Sertraline Plus CBT) vs. Placebo

One study reported on outcomes comparing sertraline plus CBT with placebo.^153,^ ^205–211,^ ^216^ The study reported parent and youth-reported MFQ scores.^205^ Results varied by respondent. Parent-reported measures at followup favored combination therapy (4.1±7.2 vs. 8.0 ±7.5, adjusted p<0.001); youth measures were not statistically significantly different.

## Depression

### Results: Anxiety Symptoms

#### Psychotherapy vs. Wait-List Controls, Treatment as Usual, Attention Control, or Placebo

Two studies of internet-delivered CBT compared with placebo reported two measures of anxiety symptoms, the BAI and SIAS. Neither found a statistically significant difference between internet-delivered CBT and placebo at 8 weeks.^147,^ ^148^

#### Pharmacotherapy vs. Placebo

None of the included studies reported anxiety outcomes.

#### Combination Therapy (Fluoxetine Plus CBT) vs. Placebo

The study did not report anxiety outcomes.

#### Collaborative Care vs. Treatment as Usual

The study did not report anxiety outcomes.

Appendix H Figure 1 Depression Symptoms for Suicide and Self-Harm Interventions: Pooled Estimates of Effect

Abbreviations: CI=confidence interval; MFQ=Mood and Feelings Questionnaire; SMFQ=Short Mood and Feelings Questionnaire.

This figure displays a pooled estimate and standardized differences in means for depression symptoms for suicide and self-harm interventions in five trials. The standardized difference in means at 6 months was −0.030 with a 95 percent confidence interval of −0.240 to 0.180 in the Green, 2011 study. The standardized difference in means at 8 weeks was −0.125 with a 95 percent confidence interval of −0.591 to 0.341 in the Hazell, 2009 study. The standardized difference in means at 71 weeks was −0.309 with a 95 percent confidence interval of −0.759 to 0.140 in the Melhlum, 2014 study. The standardized difference in means at 12 months was −0.646 with a 95 percent confidence interval of −1.096 to −0.196 in the Rossouw, 2012 study. The standardized difference in means at 7 months was 0.239 with a 95 percent confidence interval of −0.287 to 0.765 in the Wood, 201 study. The pooled standardized difference in means was −0.168 with a 95 percent confidence interval of −0.427 to 0.091.

Appendix H Figure 2 Children’s Depression Inventory Scores for CBT for Anxiety in Children and Adolescents

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval.

This figure displays a pooled estimate and differences in means for depression inventory scores for CBT for anxiety in children and adolescents in four trials. The difference in means (comparison: combined) was −2.500 with a 95 percent confidence interval of −5.185 to 0.185 in the Barrett, 1996 study. The difference in means (comparison: individual child+parent in-person CBT) was −4.410 with a 95 percent confidence interval of −9.411 to 0.591 in the Ishikawa, 2019 study. The difference in means (comparison: combined) was −2.047 with a 95 percent confidence interval of −6.640 to 2.547 in the Lyneham, 2006 study. The difference in means (comparison: combined) was −3.150 with a 95 percent confidence interval of −8.169 to 1.869 in the Ost, 2015 study. The pooled difference in means was −2.804 with a 95 percent confidence interval of −4.743 to −0.864.

Appendix H Figure 3 Short Mood and Feelings Questionnaire-Child for CBT for Anxiety in Children and Adolescents

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval.

This figure displays a pooled estimate and differences in means for short mood and feelings questionnaire-child for CBT for anxiety in children and adolescents in four trials. The difference in means (comparison: group child+parent in-person CBT) was −2.23 with a 95 percent confidence interval of −3.96 to −0.50 in the Arendt, 2016 study. The difference in means (comparison: individual child-focused internet CBT) was 0.29 with a 95 percent confidence interval of −3.40 to 3.98 in the Stjerneklar, 2019 study. The difference in means (comparison: combined) was −0.09 with a 95 percent confidence interval of −2.13 to 1.96 in the Thirlwall, 2013 study. The difference in means (comparison: individual child+parent internet CBT) was −1.22 with a 95 percent confidence interval of −4.63 to 2.19 in the Waite, 2019 study. The pooled difference in means was −1.14 with a 95 percent confidence interval of −2.35 to 0.06.

Appendix H Figure 4 Short Mood and Feelings Questionnaire-Parent, Mother, or Father for CBT for Anxiety in Children and Adolescents

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval.

This figure displays a pooled estimate and differences in means for short mood and feelings questionnaire-parent, mother or father for CBT for anxiety in children and adolescents in four trials. The difference in means (comparison: individual child-focused internet CBT, combined) was −2.67 with a 95 percent confidence interval of −4.50 to −0.83 in the Arendt, 2016 study. The difference in means (comparison: individual child-focused internet CBT, combined) was −1.56 with a 95 percent confidence interval of −4.38 to 1.27 in the Stjerneklar, 2019 study. The difference in means (comparison: combined, S-MFQ-P) was −1.59 with a 95 percent confidence interval of −3.58 to 0.40 in the Thirlwall, 2013 study. The difference in means (comparison: individual child+parent internet CBT, S-MFQ-P) was −0.38 with a 95 percent confidence interval of −4.01 to 3.25 in the Waite, 2019 study. The pooled difference in means was −1.89 with a 95 percent confidence interval of −3.04 to −0.74.

Appendix H Table 1 Psychotherapy vs. Wait-List Controls, Treatment as Usual, Attention Control, or Placebo for Depression in Children: Anxiety Symptom Improvement Scales

Treatment (Condition) | Author, Year | Mean Age (SD) | Intervention and Duration | Outcome Measure | Time Point (Weeks) | Treatment N | Treatment Mean Score (SD) | Placebo N | Placebo Mean Score (SD) | Between-Group Difference | Between-Group P-Value
Internet-based individual CBT vs. attention control | Topooco et al, 2018^147^ | IG1: 17.2 (1.0); CG: 16.9 (1.1) | Internet-based CBT with 8 skill-based modules plus weekly 30-minute chat sessions with therapist over 8 weeks | BAI | 8 weeks | 33 | 20.6 (9.0) | 37 | 19.4 (8.6) | 1.20 | N=NS
Internet-based individual CBT vs. attention control | Topooco et al, 2018^147^ | IG1: 17.2 (1.0); CG: 16.9 (1.1) | Internet-based CBT with 8 skill-based modules plus weekly 30-minute chat sessions with therapist over 8 weeks | SIAS | 8 weeks | 33 | 39.3 (13.8) | 37 | 41.4 (11.8) | −2.10 | N=NS
Internet-based individual CBT vs. attention control | Topooco et al, 2019^148^ | IG1: 17.5 (1.1); CG: 17.5 (1.2) | Internet-based CBT with 8 skill-based modules plus weekly 45-minute chat sessions with therapist over 8 weeks | BAI | 8 weeks | 35 | 16.6 (10.3) | 35 | 20.0 (9.3) | −3.40 | p=NS
Internet-based individual CBT vs. attention control | Topooco et al, 2019^148^ | IG1: 17.5 (1.1); CG: 17.5 (1.2) | Internet-based CBT with 8 skill-based modules plus weekly 45-minute chat sessions with therapist over 8 weeks | SIAS | 8 weeks | 35 | 35.4 (19.0) | 35 | 35.1 (14.3) | 0.30 | p=NS

Abbreviations: BAI=Beck Anxiety Inventory; CBT=cognitive behavioral therapy; CG=control group; IG=intervention group; N=number; NS=not significant; SD=standard error; SIAS=Social Interaction Anxiety Scale; vs.=versus.