# Appendix G Meta-Analyses Figures

Appendix G Figure 1 Suicide Risk Interventions vs. Treatment as Usual or Attention Control: Suicide-Related Hospitalization or Emergency Department Use

Abbreviations: A&E=accident and emergency; CI=confidence interval; ER=emergency room; vs. versus.

The figure displays a forest plot of the risk ratio for suicide risk interventions vs treatment as usual or attention control for suicide-related hospitalizations or emergency department use in three trials. The risk ratio for hospital attendance at 18 months was 1.151 with a 95 percent confidence interval of 0.918 to 1.444 in the Cottrell, 2018 study. The risk ratio for ER visit due to self-harm at 19 weeks was 0.390 with a 95 percent confidence interval of 0.080 to 1.888 in the Melhlum, 2014 study. The risk ratio for self-harm accident and emergency presentation at 2 years was 0.756 with a 95 percent confidence interval of 0.317 to 1.799 in the Ougrin, 2013 study. Meta-analysis of these three trials resulted in a risk ratio of 0.998 with a 95 percent confidence interval of 0.665 to 1.498.

Appendix G Figure 2 Suicide Risk Interventions vs. Treatment as Usual or Attention Control: Mean Number of Self-Harm Events

Abbreviations: CI=confidence interval; vs. versus.

The figure displays a forest plot of the difference in means for suicide risk interventions vs treatment as usual or attention control for mean number of self-harm events in three trials. The difference in means for mean number of self-harm events at 12 to 18 months was −0.200 with a 95 percent confidence interval of −0.574 to 0.174 in the Cottrell, 2018 study. The difference in means for mean number of self-harm events at 19 weeks was −13.500 with a 95 percent confidence interval of −26.782 to −0.218 in the Melhlum, 2016 study. The difference in means for mean number of self-harm events at 7 months was −1.200 with a 95 percent confidence interval of −2.373 to −0.027 in the Wood, 2001 study. Meta-analysis of these three trials resulted in a difference in means of −0.762 with a 95 percent confidence interval of −2.154 to 0.631.

Appendix G Figure 3 Suicide Risk Interventions vs. Treatment as Usual or Attention Control: Proportion With Self-Harm Events

Abbreviations: CI=confidence interval; vs. versus.

The figure displays a forest plot of the risk ratio for suicide risk interventions vs treatment as usual or attention control for proportion with self-harm events in five trials. The risk ratio for deliberate self-harm at 12 to 18 months was 1.08 with a 95 percent confidence interval of 0.96 to 1.20 in the Cottrell, 2018 study. The risk ratio for self-harm resulting in injury at 12 months was 0.50 with a 95 percent confidence interval of 0.05 to 5.47 in the Green, 2011 study. The risk ratio for repetition of self-harm at 6 to 12 months was 1.25 with a 95 percent confidence interval of 0.97 to 1.60 in the Hazell, 2009 study. The risk ratio for deliberate self-harm at 7 months was 0.65 with a 95 percent confidence interval of 0.49 to 0.85 in the Rossouw, 2012 study. The risk ratio for repeating self-harm at 7 months was 0.19 with a 95 percent confidence interval of 0.05 to 0.81 in the Wood, 2001 study. Meta-analysis of these five trials resulted in a risk ratio of 0.88 with a 95 percent confidence interval of 0.63 to 1.24.

Appendix G Figure 4 Suicide Risk Interventions vs. Treatment as Usual or Attention Control: Suicide Symptoms (Beck Hopelessness Scale)

Abbreviations: BHS=Beck Hopelessness Scale; CI=confidence interval; vs. versus.

The figure displays a forest plot of the difference in means for suicide risk interventions vs treatment as usual or attention control for suicide symptoms, Beck Hopelessness Scale (BHS) in four trials. The difference in means for BHS at 6 weeks was −0.980 with a 95 percent confidence interval of −2.110 to 0.150 in the King, 2009 study. The difference in means for BHS at 2 months was −2.980 with a 95 percent confidence interval of −6.130 to 0.170 in the King, 2015 study. The difference in means for BHS at 19 weeks was −2.830 with a 95 percent confidence interval of −5.859 to 0.199 in the Melhlum, 2014 study. The difference in means for BHS at 6 weeks was −4.680 with a 95 percent confidence interval of −8.145 to −1.215 in the Tang, 2009 study. Meta-analysis of these four trials resulted in a difference in means of −2.354 with a 95 percent confidence interval of −4.060 to −0.648.

Appendix G Figure 5 Suicide Risk Interventions vs. Treatment as Usual or Attention Control: Suicide Symptoms (Suicidal Ideation Questionnaire or Suicidal Ideation Questionnaire-Junior)

Abbreviations: CI=confidence interval; SIQ=Suicidal Ideation Questionnaire; SIQ-Jr=Suicidal Ideation Questionnaire-Junior; vs. versus.

The figure displays a forest plot of the standardized difference in means for suicide risk interventions vs treatment as usual or attention control for suicide symptoms, Suicidal Ideation Questionnaire (SIQ) or Suicidal Ideation Questionnaire-Junior (SIQ-JR) in seven trials. The standardized difference in means for SIQ-JR at 12 weeks was −0.793 with a 95 percent confidence interval of −1.295 to −0.291 in the Diamond, 2010 study. The standardized difference in means for SIQ at 6 months was 0.002 with a 95 percent confidence interval of −0.208 to 0.211 in the Green, 2011 study. The standardized difference in means for SIQ at 8 weeks was −0.060 with a 95 percent confidence interval of −0.526 to 0.405 in the Hazell, 2009 study. The standardized difference in means for SIQ-JR at 6 weeks was −0.195 with a 95 percent confidence interval of −0.380 to −0.009 in the King, 2009 study. The standardized difference in means for SIQ-JR at 2 months was −0.163 with a 95 percent confidence interval of −0.742 to 0.417 in the King, 2015 study. The standardized difference in means for SIQ-JR at 71 weeks was −0.374 with a 95 percent confidence interval of −0.830 to 0.083 in the Melhlum, 2014 study. The standardized difference in means for SIQ at 7 months was 0.154 with a 95 percent confidence interval of −0.375 to 0.683 in the Wood, 2001 study. Meta-analysis of these seven trials resulted in a standardized difference in means of −0.176 with a 95 percent confidence interval of −0.361 to 0.008.

Appendix G Figure 6 Suicide Risk Interventions vs. Treatment as Usual or Attention Control: Functional Status (Health of the Nation Outcome Scales for Children and Adolescents)

Abbreviations: CI=confidence interval; HoNOSCA=Health of the Nation Outcome Scales for Children and Adolescents; vs. versus.

The figure displays a forest plot of the difference in means for suicide risk interventions vs treatment as usual or attention control for functional status, Health of the Nation Outcome Scales for Children and Adolescents (HoNOSCA) in four trials. The difference in means for HoNOSCA at 6 months was −0.400 with a 95 percent confidence interval of −1.695 to 0.895 in the Green, 2011 study. The difference in means for HoNOSCA at 8 weeks was 1.770 with a 95 percent confidence interval of −2.640 to 6.180 in the Hazell, 2009 study. The difference in means for HoNOSCA at posttreatment was −4.160 with a 95 percent confidence interval of −7.643 to −0.677 in the Pineda, 2013 study. The difference in means for HoNOSCA at 7 months was 1.500 with a 95 percent confidence interval of −1.612 to 4.612 in the Wood, 2001 study. Meta-analysis of these four trials resulted in a difference in means of −0.398 with a 95 percent confidence interval of −2.554 to 1.757.

Appendix G Figure 7 Suicide Risk Interventions vs. Treatment as Usual or Attention Control: Functional Status (Clinical Global Assessment Scale)

Abbreviations: CGAS=Children’s Global Assessment Scale; CI=confidence interval; vs. versus.

The figure displays a forest plot of the difference in means for suicide risk interventions vs treatment as usual or attention control for functional status, Children’s Global Assessment Scale (CGAS) in three trials. The difference in means for CGAS at 8 weeks was −2.050 with a 95 percent confidence interval of −7.453 to 3.353 in the Hazell, 2009 study. The difference in means for CGAS at 71 weeks was 1.460 with a 95 percent confidence interval of −4.427 to 7.347 in the Melhlum, 2014 study. The difference in means for CGAS at 3 months was 4.500 with a 95 percent confidence interval of −0.887 to 9.887 in the Ougrin, 2013 study. Meta-analysis of these three trials resulted in a difference in means of 1.302 with a 95 percent confidence interval of −2.515 to 5.118.

Appendix G Figure 8 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Anxiety Symptoms (ADIS-Clinician Severity Ratings)

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; GAD=general anxiety disorder; TAU=treatment as usual; vs. versus.

The figure displays a forest plot of the difference in means for anxiety CBT interventions vs treatment as usual or attention control for anxiety symptoms, ADIS-Clinician Severity Ratings in 11 trials. The difference in means for primary diagnosis (comparison: group child+parent in-person CBT) was −3.29 with a 95 percent confidence interval of −4.15 to −2.43 in the Arendt, 2016 study. The difference in means for primary diagnosis (comparison: group parent-only in-person CBT) was −1.70 with a 95 percent confidence interval of −2.72 to −0.68 in the Cobham, 2017 study. The difference in means for combined diagnosis (comparison: group child+parent in-person CBT) was −0.00 with a 95 percent confidence interval of −0.75 to 0.75 in the Cornacchio, 2019 study. The difference in means for all diagnoses (comparison: individual parent-focused internet CBT) was −1.27 with a 95 percent confidence interval of −2.46 to −0.08 in the Donovan, 2014 study. The difference in means for GAD (comparison: group child-focused in-person CBT) was −2.62 with a 95 percent confidence interval of −3.31 to −1.93 in the Holmes, 2014 study. The difference in means for primary diagnosis (comparison: individual child+parent in-person CBT) was −2.92 with a 95 percent confidence interval of −4.32 to −1.52 in the Ishikawa, 2019 study. The difference in means for social phobia (comparison: combined) was −2.48 with a 95 percent confidence interval of −3.23 to −1.73 in the Ost, 2015 study. The difference in means for GAD (comparison: individual child+parent in-person+internet CBT) was −3.80 with a 95 percent confidence interval of −4.92 to −2.68 in the Perrin, 2019 study. The difference in means for all diagnoses (comparison: individual parent-led in-person CBT) was −1.84 with a 95 percent confidence interval of −3.25 to −0.43 in the Rudy, 2017 study. The difference in means for primary diagnosis (comparison: individual child-focused internet CBT) was −1.26 with a 95 percent confidence interval of −2.45 to −0.07 in the Stjerneklar, 2019 study. The difference in means for primary diagnosis (comparison: individual child+parent internet CBT) was −0.97 with a 95 percent confidence interval of −2.18 to 0.24 in the Waite, 2019 study. Meta-analysis of these 11 trials resulted in a difference in means of −2.01 with a 95 percent confidence interval of −2.74 to −1.29.

Appendix G Figure 9 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Anxiety Symptoms (Clinical Global Impressions-Severity)

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; TAU=treatment as usual; vs. versus.

The figure displays a forest plot of the difference in means for anxiety CBT interventions vs treatment as usual or attention control for anxiety symptoms, Clinical Global Impressions-Severity in three trials. The difference in means for (comparison: individual child-focused in-person CBT) was −0.18 with a 95 percent confidence interval of −0.58 to 0.22 in the Ginsburg, 2020 study. The difference in means (comparison: individual parent-led in-person CBT) was −1.33 with a 95 percent confidence interval of −2.01 to −0.65 in the Rudy, 2017 study. The difference in means (comparison: individual child-focused in-person CBT) was −0.50 with a 95 percent confidence interval of −0.87 to −0.13 in the Walkup, 2008 study. Meta-analysis of these three trials resulted in a difference in means of −0.60 with a 95 percent confidence interval of −1.14 to −0.06.

Appendix G Figure 10 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Anxiety Symptoms (Multidimensional Anxiety Scale)

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; vs. versus.

The figure displays a forest plot of the difference in means for anxiety CBT interventions vs treatment as usual or attention control for anxiety symptoms, Multidimensional Anxiety Scale, in three trials. The difference in means (comparison: individual child-focused in-person CBT) was −2.00 with a 95 percent confidence interval of −5.05 to 1.05 in the Albano, 2018 study. The difference in means (comparison: combined) was −15.20 with a 95 percent confidence interval of −25.44 to −4.96 in the Ost, 2015 study. The difference in means (comparison: combined)was −3.25 with a 95 percent confidence interval of −7.63 to 1.14 in the Villabo, 2018 study. Meta-analysis of these three trials resulted in a difference in means of −4.66 with a 95 percent confidence interval of −9.66 to 0.34.

Appendix G Figure 11 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Anxiety Symptoms (Revised Children’s Manifest Anxiety Scale)

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; vs. versus.

The figure displays a forest plot of the difference in means for anxiety CBT interventions vs treatment as usual or attention control for anxiety symptoms, Revised Children’s Manifest Anxiety Scale, in three trials. The difference in means (comparison: combined) was −3.80 with a 95 percent confidence interval of −7.10 to −0.50 in the Barrett, 1996 study. The difference in means (comparison: combined) was −5.78 with a 95 percent confidence interval of −9.81 to −1.76 in the Lyneham, 2006 study. The difference in means (comparison: group child+parent in-person CBT)was −1.20 with a 95 percent confidence interval of −1.96 to −0.44 in the Shortt, 2001. Meta-analysis of these three trials resulted in a difference in means of −3.08 with a 95 percent confidence interval of −5.91 to −0.24.

Appendix G Figure 12 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Anxiety Symptoms (Social Phobia and Anxiety Inventory for Children)

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; vs. versus.

The figure displays a forest plot of the standardized difference in means for anxiety CBT interventions vs treatment as usual or attention control for anxiety symptoms, Social Phobia and Anxiety Inventory for Children in four trials. The standardized difference in means (comparison: group child-focused in-person CBT) was −0.59 with a 95 percent confidence interval of −1.08 to −0.10 in the Ashbrand, 2020 study. The standardized difference in means (comparison: combined) was −0.74 with a 95 percent confidence interval of −1.40 to −0.07 in the Ost, 2015 study. The standardized difference in means (comparison: combined) was −2.63 with a 95 percent confidence interval of −3.36 to −1.89 in the Sanchez-Garcia, 2009 study. The standardized difference in means (comparison: individual child-focused in-person CBT) was −0.75 with a 95 percent confidence interval of −1.94 to −0.35 in the Salzar, 2018 study. Meta-analysis of these four trials resulted in a standardized difference in means of −1.14 with a 95 percent confidence interval of −1.94 to −0.35.

Appendix G Figure 13 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Anxiety Symptoms (Spence Children’s Anxiety Scale-Child Rating)

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; vs. versus.

The figure displays a forest plot of the difference in means for anxiety CBT interventions vs treatment as usual or attention control for anxiety symptoms, Spence Children’s Anxiety Scale-Child Rating in nine trials. The difference in means (comparison: group child+parent in-person CBT) was −10.98 with a 95 percent confidence interval of −16.62 to −5.34 in the Arendt, 2016 study. The difference in means (comparison: group parent-only in-person CBT) was −7.70 with a 95 percent confidence interval of −14.10 to −1.30 in the Cobham, 2017 study. The difference in means (comparison: group child-focused in-person CBT) was −5.96 with a 95 percent confidence interval of −19.10 to 7.18 in the Holmes, 2014 study. The difference in means (comparison: individual child+parent in-person CBT) was −7.67 with a 95 percent confidence interval of −18.09 to 2.75 in the Ishikawa, 2019 study. The difference in means (comparison: group child+parent in-person CBT) was −14.20 with a 95 percent confidence interval of −21.28 to −7.12 in the Lau, 2010 study. The difference in means (comparison: combined) was −11.60 with a 95 percent confidence interval of −22.40 to −0.79 in the Lyneham, 2006 study. The difference in means (comparison: individual child-focused internet CBT) was −8.31 with a 95 percent confidence interval of −17.23 to 0.61 in the Stjerneklar, 2019 study. The difference in means (comparison: combined) was −0.17 with a 95 percent confidence interval of −6.68 to 6.35 in the Thirlwall, 2013 study. The difference in means (comparison: individual child+parent internet CBT) was −3.11 with a 95 percent confidence interval of −11.82 to 5.60 in the Waite, 2019 study. Meta-analysis of these nine trials resulted in a difference in means of −7.81 with a 95 percent confidence interval of −10.99 to −4.63.

Appendix G Figure 14 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Anxiety Symptoms (Spence Children’s Anxiety Scale-Parent Rating)

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; SCAS-Parent=Spence Children’s Anxiety Scale-Parent-rated; vs. versus.

The figure displays a forest plot of the difference in means for anxiety CBT interventions vs treatment as usual or attention control for anxiety symptoms, Spence Children’s Anxiety Scale-Parent Rating in nine trials. The difference in means (comparison: group child+parent in-person CBT) was −11.93 with a 95 percent confidence interval of −17.55 to −6.31 in the Arendt, 2016 study. The difference in means (comparison: group parent-only in-person CBT) was −10.70 with a 95 percent confidence interval of −16.90 to −4.50 in the Cobham, 2017 study. The difference in means (comparison: group child-focused in-person CBT) was −1.53 with a 95 percent confidence interval of −8.60 to 5.54 in the Holmes, 2014 study. The difference in means (comparison: individual child+parent in-person CBT) was −2.15 with a 95 percent confidence interval of −9.34 to 5.04 in the Ishikawa, 2019 study. The difference in means (comparison: group child+parent in-person CBT) was −7.70 with a 95 percent confidence interval of −13.93 to −1.47 in the Lau, 2010 study. The difference in means (comparison: combined) was −12.72 with a 95 percent confidence interval of −21.49 to −3.95 in the Lyneham, 2006 study. The difference in means (comparison: individual child-focused internet CBT) was −8.19 with a 95 percent confidence interval of −16.22 to −0.16 in the Stjerneklar, 2019 study. The difference in means (comparison: combined) was −1.85 with a 95 percent confidence interval of −6.84 to 3.15 in the Thirlwall, 2013 study. The difference in means (comparison: individual child+parent internet CBT) was 4.19 with a 95 percent confidence interval of −5.41 to 13.79 in the Waite, 2019 study. Meta-analysis of these nine trials resulted in a difference in means of −6.06 with a 95 percent confidence interval of −9.57 to −2.56.

Appendix G Figure 15 Anxiety Pharmacotherapy Interventions vs. Placebo: Anxiety Symptoms (Clinical Global Impressions-Severity)

Abbreviation: CI=confidence interval; vs. versus.

The figure displays a forest plot of the difference in means for anxiety pharmacotherapy interventions vs placebo for anxiety symptoms, Clinical Global Impressions-Severity in four trials. The difference in means (comparison: Sertraline) was −1.50 with a 95 percent confidence interval of −2.00 to −1.00 in the Rynn, 2001 study. The difference in means (comparison: Duloxetine) was −0.50 with a 95 percent confidence interval of −0.78 to −0.22 in the Strawn, 2015 study. The difference in means (comparison: Escitalopram) was −0.80 with a 95 percent confidence interval of −0.94 to −0.66 in the Strawn, 2020 study. The difference in means (comparison: Sertraline) was −0.80 with a 95 percent confidence interval of −1.18 to −0.42 in the Walkup, 2008 study. Meta-analysis of these four trials resulted in a difference in means of −0.84 with a 95 percent confidence interval of −1.13 to −0.55.

Appendix G Figure 16 Anxiety Pharmacotherapy Interventions vs. Placebo: Anxiety Symptoms (Pediatric Anxiety Rating Scale)

Abbreviation: CI=confidence interval; vs. versus.

The figure displays a forest plot of the difference in means for anxiety pharmacotherapy interventions vs placebo for anxiety symptoms, Pediatric Anxiety Rating Scale in five trials. The difference in means (comparison: Fluoxetine) was −2.20 with a 95 percent confidence interval of −4.65 to 0.25 in the Birmaher, 2003 study. The difference in means (comparison: Fluvoxamine) was −6.90 with a 95 percent confidence interval of −9.08 to −4.72 in the Pine, 2001 study. The difference in means (comparison: Duloxetine) was −2.80 with a 95 percent confidence interval of −4.19 to −1.41 in the Strawn, 2015 study. The difference in means (comparison: Escitalopram) was −5.13 with a 95 percent confidence interval of −5.79 to −4.47 in the Strawn, 2020 study. The difference in means (comparison: Sertraline) was −2.80 with a 95 percent confidence interval of −4.56 to −1.04 in the Walkup, 2008 study. Meta-analysis of these five trials resulted in a difference in means of −4.00 with a 95 percent confidence interval of −5.54 to −2.46.

Appendix G Figure 17 Anxiety CBT Interventions vs. Treatment as Usual: Response (Clinical Global Impressions-Improvements Scores ≤2)

Abbreviation: CI=confidence interval; TAU=treatment as usual; vs. versus.

The figure displays a forest plot of the risk ratios for anxiety CBT interventions vs treatment as usual for response, Clinical Global Impressions-Improvements Score <=2, in six trials. The risk ratio (comparison: Group child+parent in-person CBT) was 16.00 with a 95 percent confidence interval of 1.00 to 256.54 in the Cornacchio, 2009 study. The risk ratio (comparison: individual child-focused in-person CBT) was 1.15 with a 95 percent confidence interval of 0.80 to 1.65 in the Ginsburg, 2010 study. The risk ratio (comparison: individual child+parent in-person CBT) was 1.97 with a 95 percent confidence interval of 1.06 to 3.63 in the Hirshfield-Becker, 2010 study. The risk ratio (comparison: individual parent-led in-person CBT) was 17.76 with a 95 percent confidence interval of 1.17 to 269.93 in the Rudy, 2017 study. The risk ratio (comparison: individual child-focused in-person CBT) was 2.52 with a 95 percent confidence interval of 1.65 to 3.86 in the Walkup, 2008 study. The risk ratio (comparison: individual parent-led in-person CBT) was 1.33 with a 95 percent confidence interval of 0.66 to 2.69 in the Waite, 2019 study. Meta-analysis of these six trials resulted in a risk ratio of 1.89 with a 95 percent confidence interval of 1.17 to 3.05.

Appendix G Figure 18 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Remission (Clinically Significant Change in Spence Children’s Anxiety Scale)

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; vs. versus.

The figure displays a forest plot of the risk ratios for anxiety CBT interventions vs treatment as usual or attention control for remission, clinically significant change in Spence Children’s Anxiety Scale, in four trials. The risk ratio (comparison: Group child+parent in-person CBT) was 3.80 with a 95 percent confidence interval of 1.68 to 8.56 in the Arendt, 2016 study. The risk ratio (comparison: individual child+parent in-person CBT) was 1.49 with a 95 percent confidence interval of 0.80 to 2.78 in the Ishikawa, 2019 study. The risk ratio (comparison: combined) was 2.44 with a 95 percent confidence interval of 1.06 to 5.64 in the Lyneham, 2006 study. The risk ratio (comparison: individual child-focused internet CBT) was 7.33 with a 95 percent confidence interval of 1.73 to 31.17 in the Stjerneklar, 2019 study. Meta-analysis of these four trials resulted in a risk ratio of 2.68 with a 95 percent confidence interval of 1.48 to 4.88

Appendix G Figure 19 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Loss of All Anxiety Diagnoses

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; TAU=treatment as usual; vs. versus.

The figure displays a forest plot of the risk ratios for anxiety CBT interventions vs treatment as usual or attention control for loss of all anxiety diagnoses in 15 trials. The risk ratio (comparison: Group child+parent in-person CBT) was 8.46 with a 95 percent confidence interval of 2.74 to 26.13 in the Arendt, 2016 study. The risk ratio (comparison: individual child-focused or child+family in-person CBT) was 2.68 with a 95 percent confidence interval of 1.32 to 5.47 in the Barrett, 1996 study. The risk ratio (comparison: individual+group child + parent in-person CBT) was 11.38 with a 95 percent confidence interval of 1.56 to 83.26 in the Cobham, 2017 study. The risk ratio (comparison: individual+group child in-person CBT) was 1.35 with a 95 percent confidence interval of 0.58 to 3.14 in the Donovan, 2014 study. The risk ratio (comparison: individual child-focused in-person CBT) was 1.95 with a 95 percent confidence interval of 1.25 to 3.03 in the Ginsburg, 2011 study. The risk ratio (comparison: individual child-focused internet CBT) was 1.00 with a 95 percent confidence interval of 0.67 to 1.48 in the Ginsburg, 2020 study. The risk ratio (comparison: individual parent-guided in-person+telephone brief CBT) was 2.94 with a 95 percent confidence interval of 1.25 to 6.94 in the Hirschfeld-Becker, 2010 study. The risk ratio (comparison: group child+parent in-person CBT) was 7.76 with a 95 percent confidence interval of 0.43 to 140.24 in the Holmes, 2014 study. The risk ratio (comparison: individual parent-guided inperson+telephone full CBT) was 3.85 with a 95 percent confidence interval of 0.46 to 32.08 in the Ishikawa, 2019 study. The risk ratio (comparison: individual child+parent internet CBT) was 33.00 with a 95 percent confidence interval of 2.11 to 515.02 in the Perrin, 2019 study. The risk ratio (comparison: individual child+parent in-person CBT) was 11.50 with a 95 percent confidence interval of 1.64 to 80.72 in the Shortt, 2001 study. The risk ratio (comparison: individual child+parent in-person CBT) was 9.67 with a 95 percent confidence interval of 1.26 to 74.13 in the Stjerneklar, 2019 study. The risk ratio (comparison: combined) was 2.05 with a 95 percent confidence interval of 0.84 to 5.03 in the Thirwall, 2013 study. The risk ratio (comparison: combined) was 7.69 with a 95 percent confidence interval of 2.48 to 23.84 in the Villabo, 2018 study. The risk ratio (comparison: group parent-only in-person CBT) was 2.01 with a 95 percent confidence interval of 0.68 to 5.97 in the Waite, 2019 study. Meta-analysis of these 15 trials resulted in a risk ratio of 3.09 with a 95 percent confidence interval of 1.98 to 4.80.

Appendix G Figure 20 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Loss of Primary Anxiety Diagnosis

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; TAU=treatment as usual; vs. versus.

The figure displays a forest plot of the risk ratios for anxiety CBT interventions vs treatment as usual for loss of primary anxiety diagnosis in 13 trials. The risk ratio (comparison: Group child+parent in-person CBT) was 8.81 with a 95 percent confidence interval of 3.36 to 23.11 in the Arendt, 2016 study. The risk ratio (comparison: group parent-only in-person CBT) was 3.98 with a 95 percent confidence interval of 1.67 to 9.48 in the Cobham, 2017 study. The risk ratio (comparison: group child-parent in-person CBT) was 3.19 with a 95 percent confidence interval of 0.14 to 72.45 in the Cornacchio, 2019 study. The risk ratio (comparison: individual parent-focused internet CBT) was 1.50 with a 95 percent confidence interval of 0.66 to 3.39 in the Donovan, 2014 study. The risk ratio (comparison: individual child-focused in-person CBT) was 0.93 with a 95 percent confidence interval of 0.67 to 1.30 in the Ginsburg, 2020 study. The risk ratio (comparison: group child-focused in-person CBT) was 21.10 with a 95 percent confidence interval of 1.32 to 337.22 in the Holmes, 2014 study. The risk ratio (comparison: individual child+parent in-person CBT) was 4.17 with a 95 percent confidence interval of 1.35 to 12.89 in the Ishikawa, 2019 study. The risk ratio (comparison: combined) was 6.55 with a 95 percent confidence interval of 1.68 to 25.57 in the Ost, 2015 study. The risk ratio (comparison: individual child+parent in-person+internet CBT) was 33.00 with a 95 percent confidence interval of 2.11 to 515.02 in the Perrin, 2019 study. The risk ratio (comparison: individual child-focused internet CBT) was 2.50 with a 95 percent confidence interval of 1.03 to 6.10 in the Stjerneklar, 2019 study. The risk ratio (comparison: combined) was 1.77 with a 95 percent confidence interval of 1.03 to 3.02 in the Thirwall, 2013 study. The risk ratio (comparison: combined) was 4.15 with a 95 percent confidence interval of 2.02 to 8.56 in the Villabo, 2018 study. The risk ratio (comparison: individual child+parent internet CBT) was 1.72 with a 95 percent confidence interval of 0.78 to 3.76 in the Waite, 2019 study. Meta-analysis of these 13 trials resulted in a risk ratio of 3.02 with a 95 percent confidence interval of 1.84 to 4.95.

Appendix G Figure 21 Anxiety Pharmacotherapy Interventions vs. Placebo: Response (Clinical Global Impressions-Improvements Scores ≤2)

Abbreviations: CI=confidence interval; vs.=versus.

The figure displays a forest plot of the risk ratios for anxiety pharmacotherapy interventions vs placebo for response, Clinical Global Impressions-Improvements Scores <= 2, in five trials. The risk ratio (comparison: Fluoxetine) was 1.74 with a 95 percent confidence interval of 1.04 to 2.89 in the Birmaher, 2003 study. The risk ratio (comparison: Fluoxetine) was 1.13 with a 95 percent confidence interval of 0.38 to 3.32 in the Black, 1994 study. The risk ratio (comparison: Sertraline) was 10.00 with a 95 percent confidence interval of 1.53 to 65.41 in the Rynn, 2001 study. The risk ratio (comparison: Escitalopram) was 2.56 with a 95 percent confidence interval of 1.20 to 5.49 in the Strawn, 2020 study. The risk ratio (comparison: Sertraline) was 2.32 with a 95 percent confidence interval of 1.50 to 3.57 in the Walkup, 2008 study. Meta-analysis of these five trials resulted in a risk ratio of 2.11 with a 95 percent confidence interval of 1.50 to 2.98.

Appendix G Figure 22 Anxiety CBT Intervention vs. Treatment as Usual or Attention Control: Functioning (Children’s Anxiety Impact Scale)

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; TAU=treatment as usual; vs.=versus.

The figure displays a forest plot of the difference in means for anxiety CBT interventions vs treatment as usual or attention control for functioning, Children’s Anxiety Impact Scale in three trials. The difference in means (comparison: combined) was −5.38 with a 95 percent confidence interval of −10.35 to −0.40 in the Thirwall, 2013 study. The difference in means (comparison: individual child+parent internet CBT) was 3.97 with a 95 percent confidence interval of −5.78 to 13.72 in the Waite, 2019 study. The difference in means (comparison: individual in-person child-focused CBT) was −1.70 with a 95 percent confidence interval of −4.57 to 1.17 in the Walkup, 2008 study. Meta-analysis of these four trials resulted in a difference in means of −2.23 with a 95 percent confidence interval of −5.88 to 1.43.

Appendix G Figure 23 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Functioning (Children’s Global Assessment Scale)

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; TAU=treatment as usual; vs.=versus.

The figure displays a forest plot of the difference in means for anxiety CBT interventions vs treatment as usual or attention control for functioning, Children’s Global Assessment Scale, in eight trails. The difference in means (comparison: group child+parent in-person CBT) was 1.10 with a 95 percent confidence interval of −2.37 to 4.57 in the Cornacchio, 2019 study. The difference in means (comparison: individual parent-focused internet CBT) was 5.06 with a 95 percent confidence interval of −0.66 to 10.78 in the Donovan, 2014 study. The difference in means (comparison: group child-focused in-person CBT) was 12.77 with a 95 percent confidence interval of 6.62 to 18.92 in the Holmes, 2014 study. The difference in means (comparison: individual in-person child-focused CBT) was 1.76 with a 95 percent confidence interval of −2.51 to 6.03 in the Ginsburg, 2020 study. The difference in means (comparison: individual child+ parent in-person+internet CBT) was 22.70 with a 95 percent confidence interval of 17.82 to 27.58 in the Perrin, 2019 study. The difference in means (comparison: combined) was 9.62 with a 95 percent confidence interval of 6.53 to 12.70 in the Villabo, 2018 study. The difference in means (comparison: individual child+parent internet CBT) was 4.30 with a 95 percent confidence interval of −2.65 to 11.25 in the Waite, 2019 study. The difference in means (comparison: individual in-person child-focused CBT) was 3.70 with a 95 percent confidence interval of 0.78 to 6.62 in the Walkup, 2008 study. Meta-analysis of these eight trials resulted in a difference in means of 7.54 with a 95 percent confidence interval of 2.84 to 12.23.

Appendix G Figure 24 Anxiety Pharmacotherapy Intervention vs. Placebo: Functioning (Children’s Global Assessment Scale)

Abbreviation: CI=confidence interval; vs.=versus.

The figure displays a forest plot of the difference in means for anxiety pharmacotherapy interventions vs placebo for functioning, Children’s Global Assessment Scale, in three trials. The difference in means (comparison: Sertraline) was −1.50 with a 95 percent confidence interval of −2.00 to −1.00 in the Rynn, 2001 study. The difference in means (comparison: Fluoxetine) was 9.10 with a 95 percent confidence interval of 3.13 to 15.07 in the Birmaher, 2003 study. The difference in means (comparison: Sertraline) was 4.90 with a 95 percent confidence interval of 1.86 to 7.94 in the Walkup, 2008 study. The difference in means (comparison: Duloxetine) was 4.50 with a 95 percent confidence interval of 1.73 to 7.08 in the Strawn, 2015 study. Meta-analysis of these three trials resulted in a difference in means of 5.14 with a 95 percent confidence interval of 3.21 to 7.08.

Appendix G Figure 25 Depression Psychotherapy Interventions vs. Attention Control, Treatment as Usual, or Wait-List: Depression Symptoms (Beck Depression Inventory [BDI] or BDI II)

Abbreviations: BDI=Beck Depression Inventory; BDI-II=Beck Depression Inventory, version 2; CBT=cognitive behavioral therapy; CI=confidence interval; vs.=versus.

The figure displays a forest plot of the standardized difference in means for depression psychotherapy interventions vs attention control, treatment as usual, or wait-list for depression symptoms, Beck Depression Inventory (BDI) or BDI II, in four trials. The standardized difference in means for BDI (comparison: combined) was −0.42 with a 95 percent confidence interval of −0.93 to 0.09 in the Clarke, 1999 study. The standardized difference in means for BDI-II (comparison: internet based individual CBT) was −0.70 with a 95 percent confidence interval of −1.19 to −0.22 in the Topooco, 2018 study. The standardized difference in means for BDI-II (comparison: internet based individual CBT) was −0.81 with a 95 percent confidence interval of −1.30 to −0.32 in the Topooco, 2019 study. The standardized difference in means for BDI (comparison: interpersonal psychotherapy) was −0.37 with a 95 percent confidence interval of −0.87 to 0.13 in the Mufson, 2004 study. Meta-analysis of these four trials resulted in a standardized difference in means of −0.58 with a 95 percent confidence interval of −0.83 to −0.34.

Appendix G Figure 26 Depression Psychotherapy Interventions vs. Treatment as Usual or Wait-List: Depression Symptoms (Hamilton Depression Rating Scale)

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; vs.=versus.

The figure displays a forest plot of the difference in means for depression psychotherapy interventions vs treatment as usual or wait-list for depression symptoms, Hamilton Depression Rating Scale, in three trials. The difference in means (comparison: individual in-person youth CBT) was −1.60 with a 95 percent confidence interval of −4.25 to 1.05 in the Clarke, 2005 study. The difference in means (comparison: combined) was −2.05 with a 95 percent confidence interval of −5.32 to 1.22 in the Clarke, 1999 study. The difference in means (comparison: interpersonal psychotherapy) was −4.10 with a 95 percent confidence interval of −8.16 to −0.04 in the Mufson, 2004 study. Meta-analysis of these three trials resulted in a difference in means of −2.25 with a 95 percent confidence interval of −4.09 to −0.42.

Appendix G Figure 27 Depression Psychotherapy Interventions vs. Treatment as Usual, Placebo, or Wait-List: Depression Symptoms (Children’s Depression Rating Scale-Revised)

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; vs.=versus.

The figure displays a forest plot of the difference in means for depression psychotherapy interventions vs treatment as usual, placebo or wait-list for depression symptoms, Children’s Depression Rating Scale-Revised, in three trials. The difference in means (comparison: individual in-person youth CBT) was 1.90 with a 95 percent confidence interval of −1.04 to 4.84 in the Clarke, 2016 study. The difference in means (comparison: individual in-person CBT) was 0.29 with a 95 percent confidence interval of −1.97 to 2.55 in the March, 2004 study. The difference in means (comparison: family CBT) was −1.00 with a 95 percent confidence interval of −7.57 to 5.57 in the Fristad, 2019 study. Meta-analysis of these three trials resulted in a difference in means of 0.76 with a 95 percent confidence interval of −0.97 to 2.48.

Appendix G Figure 28 Depression Pharmacotherapy Interventions vs. Placebo: Depression Symptoms (Children’s Depression Rating Scale-Revised)

Abbreviation: CI=confidence interval; vs.=versus.

The figure displays a forest plot of the difference in means for depression pharmacotherapy interventions vs placebo for depression symptoms, Children’s Depression Rating Scale-Revised, in three trials. The difference in means (comparison: Fluoxetine) was −5.47 with a 95 percent confidence interval of −7.60 to −3.34 in the March, 2004 study. The difference in means (comparison: Escitalopram) was −3.30 with a 95 percent confidence interval of −6.11 to −0.49 in the Emslie, 2009 study. The difference in means (comparison: Escitalopram) was −1.70 with a 95 percent confidence interval of −4.98 to 1.58 in the Wagner, 2006 study. Meta-analysis of these three trials resulted in a difference in means of −3.76 with a 95 percent confidence interval of −5.95 to −1.57.

Appendix G Figure 29 Depression Psychotherapy Interventions vs. Attention Control, Wait-List, or Placebo: Loss of Diagnosis

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; vs.=versus.

The figure displays a forest plot of the risk ratios for depression psychotherapy interventions vs attention control, wait-list or placebo for loss of diagnosis in four trials. The risk ratio at 8 weeks (comparison: CBT) was 1.38 with a 95 percent confidence interval of 0.90 to 2.12 in the Clarke, 1999 study. The risk ratio at 12 weeks (comparison: CBT) was 1.01 with a 95 percent confidence interval of 0.80 to −1.28 in the TADS study (Kennard, 2006). The risk ratio at 8 weeks (comparison: CBT) was 4.46 with a 95 percent confidence interval of 2.07 to 9.63 in the Topooco, 2018 study. The risk ratio at 8 weeks (comparison: CBT) was 2.07 with a 95 percent confidence interval of 1.01 to 4.24 in the Topooco, 2019 study. Meta-analysis of these four trials resulted in a risk ratio of 1.73 with a 95 percent confidence interval of 1.00 to 3.00.

Appendix G Figure 30 Depression Pharmacotherapy Interventions vs. Placebo: Remission (Children’s Depression Rating Scale-Revised ≤28)

Abbreviation: CI=confidence interval; vs.=versus.

The figure displays a forest plot of the risk ratios for depression pharmacotherapy interventions vs placebo for remission, Children’s Depression Rating Scale-Revised <=28, in three trials. The risk ratio at 8 weeks (comparison: Escitalopram) was 1.17 with a 95 percent confidence interval of 0.88 to 1.54 in the Emslie, 2009 study. The risk ratio at 8 weeks (comparison: Escitalopram) was 1.21 with a 95 percent confidence interval of 0.90 to 1.61 in the Wagner, 2006 study. The risk ratio at 12 weeks (comparison: Fluoxetine) was 1.35 with a 95 percent confidence interval of 0.79 to 2.31 in the TADS study (Kennard, 2006). Meta-analysis of these three trials resulted in a risk ratio of 1.20 with a 95 percent confidence interval of 1.00 to 1.45.

Appendix G Figure 31 Depression Psychotherapy Interventions vs. Wait-List or Placebo: Functioning (Children’s Global Assessment Scale)

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; vs.=versus.

The figure displays a forest plot of the difference in means for depression psychotherapy interventions vs wait-list or placebo for functioning, Children’s Global Assessment Scale, in four trials. The difference in means (comparison: individual in-person youth CBT) was −3.00 with a 95 percent confidence interval of −0.16 to 6.16 in the Clarke, 2005 study. The difference in means (comparison: individual in-person youth CBT) was −1.77 with a 95 percent confidence interval of −4.57 to 1.03 in the Clarke, 2016 study. The difference in means (comparison: individual in-person CBT) was 0.70 with a 95 percent confidence interval of −2.48 to 3.88 in the March, 2004 study. The difference in means (comparison: interpersonal psychotherapy) was 7.20 with a 95 percent confidence interval of 0.64 to 13.76 in the Mufson, 2004 study. Meta-analysis of these four trials resulted in a difference in means of 1.52 with a 95 percent confidence interval of −1.54 to 4.58.

Appendix G Figure 32 Depression Pharmacotherapy Interventions vs. Placebo: Functioning (Children’s Global Assessment Scale)

Abbreviation: CI=confidence interval; vs.=versus.

The figure displays a forest plot of the difference in means for depression pharmacotherapy interventions vs placebo for functioning, Children’s Global Assessment Scale, in three trials. The difference in means (comparison: Fluoxetine) was 2.70 with a 95 percent confidence interval of −0.56 to 5.96 in the March, 2004 study. The difference in means (comparison: Escitalopram) was 2.20 with a 95 percent confidence interval of −0.93 to 5.33 in the Emslie, 2009 study. The difference in means (comparison: Escitalopram) was 2.90 with a 95 percent confidence interval of −0.17 to 5.97 in the Wagner, 2006 study. Meta-analysis of these three trials resulted in a difference in means of 2.60 with a 95 percent confidence interval of 0.78 to 4.42.

Appendix G Figure 33 Anxiety CBT Interventions vs. Wait-List or Placebo: Withdrawal Due to Adverse Events

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; vs.=versus.

The figure displays a forest plot of the risk ratios for anxiety CBT interventions vs wait-list or placebo for withdrawal due to adverse events in four trials. The risk ratio (comparison: individual child+parent in-person internet CBT) was 3.00 with a 95 percent confidence interval of 0.13 to 69.52 in the Perrin, 2019 study. The risk ratio (comparison: individual internet child-focused CBT) was 0.38 with a 95 percent confidence interval of 0.02 to 9.05 in the Stjerneklar, 2019 study. The risk ratio (comparison: individual child+parent internet CBT) was 0.13 with a 95 percent confidence interval of 0.01 to 2.53 in the Waite, 2019 study. The risk ratio (comparison: individual in-person CBT) was 0.18 with a 95 percent confidence interval of 0.01 to 4.45 in the Walkup, 2008 study. Meta-analysis of these four trials resulted in a risk ratio of 0.39 with a 95 percent confidence interval of 0.08 to 1.87.

Appendix G Figure 34 Anxiety Pharmacotherapy Interventions vs. Placebo: Withdrawal Due to Adverse Events

Abbreviation: CI=confidence interval; vs.=versus.

The figure displays a forest plot of the risk ratios for anxiety pharmacotherapy interventions vs placebo for withdrawal due to adverse events in five trials. The risk ratio (comparison: Fluoxetine) was 13.00 with a 95 percent confidence interval of 0.76 to 222.75 in the Birmaher, 2003 study. The risk ratio (comparison: Fluvoxamine) was 5.16 with a 95 percent confidence interval of 0.62 to 42.93 in the Pine, 2001 study. The risk ratio (comparison: Duloxetine) was 1.18 with a 95 percent confidence interval of 0.41 to 3.43 in the Strawn, 2015 study. The risk ratio (comparison: Escitalopram) was 0.96 with a 95 percent confidence interval of 0.06 to 14.55 in the Strawn, 2020 study. The risk ratio (comparison: Sertraline) was 0.19 with a 95 percent confidence interval of 0.01 to 4.64 in the Walkup, 2008 study. Meta-analysis of these five trials resulted in a risk ratio of 1.72 with a 95 percent confidence interval of 0.57 to 5.18.