# Appendix F Detailed Outcome Tables

Appendix F Table 1 Suicide Risk Interventions vs. Treatment as Usual or Attention Control: Suicide-Related Hospitalizations or Emergency Department Use, Suicide Attempts, and Episodes of Deliberate Self-Harm

Treatment (Condition) | Author, Year | Mean Age (Years) | Dose and Duration | Outcome Measure | Time Point (Weeks) | Treatment N | Number of Events (%) | Placebo N | Number of Events (%) | Between-Group P Value
Family CBT | Asarnow et al, 2017^66^ | 15 | 12 weeks | Percentage with SA | 3 months | 20 | 0 (0) | 22 | 4 (18) | 0.01
Family CBT | Asarnow et al, 2017^66^ | 15 | 12 weeks | NSSI | 3 months | 20 | Probabilities of survival without (SE); 0.55 (0.11) | 22 | Probabilities of survival without (SE); 0.43 (0.14) | 0.054
Family Therapy | Cottrell et al, 2018^80^; Cottrell et al, 2018^199^; Cottrell et al, 2018^200^ | 14 | 6-7 sessions over; 6 months | Self-harm events per participant | 36 months | 415 | Mean (SD); 1.0 (2.19) | 417 | Mean (SD); 1.2 (3.22) | NR
Family Therapy | Cottrell et al, 2018^80^; Cottrell et al, 2018^199^; Cottrell et al, 2018^200^ | 14 | 6-7 sessions over; 6 months | SASII self-harm event | 12 to 18 months | 415 | 202 (75) | 417 | 147 (70) | NR
Family Therapy | Cottrell et al, 2018^80^; Cottrell et al, 2018^199^; Cottrell et al, 2018^200^ | 14 | 6-7 sessions over; 6 months | Hospital attendance for self-harm event | 12 months | 415 | NR | 417 | NR | 0.56
Group psycho-therapy | Green et al, 2011^93^ | 12 to 14 years, N (%); IG1: 69 (38); CG: 70 (38); 15 to 17 years, N (%); IG1: 114 (62); CG: 113 (62) | 6 weeks followed by boosters until participants felt better | Frequency of self-harm | 0-6 months | 181 | Frequency; 4.6 | 181 | Frequency; 4.4 | 0.91
Group psycho-therapy | Green et al, 2011^93^ | 12 to 14 years, N (%); IG1: 69 (38); CG: 70 (38); 15 to 17 years, N (%); IG1: 114 (62); CG: 113 (62) | 6 weeks followed by boosters until participants felt better | Mild severity of self-harm | 6-12 months | 178 | 68 (38) | 180 | 76 (42) | NS
Group psycho-therapy | Green et al, 2011^93^ | 12 to 14 years, N (%); IG1: 69 (38); CG: 70 (38); 15 to 17 years, N (%); IG1: 114 (62); CG: 113 (62) | 6 weeks followed by boosters until participants felt better | Marked Problem of self-harm | 6-12 months | 178 | 24 (13) | 180 | 21 (12) | NS
Group psycho-therapy | Green et al, 2011^93^ | 12 to 14 years, N (%); IG1: 69 (38); CG: 70 (38); 15 to 17 years, N (%); IG1: 114 (62); CG: 113 (62) | 6 weeks followed by boosters until participants felt better | Severe Severity of self-harm | 6-12 months | 178 | 11(6) | 180 | 13 (7) | NS
Group psycho-therapy | Green et al, 2011^93^ | 12 to 14 years, N (%); IG1: 69 (38); CG: 70 (38); 15 to 17 years, N (%); IG1: 114 (62); CG: 113 (62) | 6 weeks followed by boosters until participants felt better | Self-harm resulting in injury | 6-12 months | 180 | 1 (0.05) | 180 | 2 (1.1) | NR
Group MBT | Griffiths et al, 2019^94^ | 16 | 12 sessions over 12 weeks | Self-Harm subscale (RTSHI) | 12 weeks | 22 | Mean (SD); 26.00 (12.57) | 26 | Mean (SD); 12 (12.28) | NS
Group MBT | Griffiths et al, 2019^94^ | 16 | 12 sessions over 12 weeks | RTSHI Total | 12 weeks | 22 | Mean (SD); 38.78 (19.65) | 26 | Mean (SD); 36.00 (18.80) | NS
Group MBT | Griffiths et al, 2019^94^ | 16 | 12 sessions over 12 weeks | Self-harm ED presentation | 12 weeks | 22 | Mean (range); 0.36 (0 to 2) | 26 | Mean (range); 0.23 (0 to 2) | NS
Group therapy | Hazell et al, 2009^95^ | 14 | 6+ sessions over 12 months | Engaged in repetition of self-harm | 8 weeks | 34 | 30 (88) | 34 | 24 (71) | 0.07
Developmental Group Therapy | Wood et al, 2001^159^ | 14 | Median of 8 group sessions and 2.5 indiviual sessions over 6 months | Number of episodes of deliberate self-harm | 7 months | 32 | Mean (95% CI); 0.6 (0.3 to 0.9) | 31 | Mean (95% CI); 1.8 (0.6 to 3.0) | NR
Developmental Group Therapy | Wood et al, 2001^159^ | 14 | Median of 8 group sessions and 2.5 indiviual sessions over 6 months | Number of persons repeating self-harm | 7 months | 32 | 2 (6) | 31 | 10 (32) | OR, 6.3 (1.4 to 28.7)
Individual and Family DBT | Mehlum et al, 2014^115^; Mehlum et al, 2016^201^; Mehlum et al, 2019^202^; Haga et al, 2018^203^ | 16 | 1 weekly individual session, 1 weekly multifamily skills training, and family sessions and telephone coaching outside of sessions as needed, over 19 weeks | Self-harm episode | 19 weeks | 39 | Mean (95% CI); 9.0 (4.8 to 13.2) | 38 | Mean (95% CI); 22.5 (11.4 to 33.5) | 0.05
Individual and Family DBT | Mehlum et al, 2014^115^; Mehlum et al, 2016^201^; Mehlum et al, 2019^202^; Haga et al, 2018^203^ | 16 | 1 weekly individual session, 1 weekly multifamily skills training, and family sessions and telephone coaching outside of sessions as needed, over 19 weeks | Admitted to hospital due to self-harm | 19 weeks | 39 | 1 (2) | 38 | 2 (5) | NS
Individual and Family DBT | Mehlum et al, 2014^115^; Mehlum et al, 2016^201^; Mehlum et al, 2019^202^; Haga et al, 2018^203^ | 16 | 1 weekly individual session, 1 weekly multifamily skills training, and family sessions and telephone coaching outside of sessions as needed, over 19 weeks | ER visit due to self-harm | 19 weeks | 39 | 2 (5) | 38 | 5 (13) | NS
Therapeutic assessment | Ougrin et al, 2013^121^; Ougrin, 2011^204^ | 16 | 1 session | One or more presentation to A&E with self-harm | 2 years | 35 | 7 (20) | 34 | 9 (26) | 0.53
Individual and family MBT | Rossouw et al, 2012^128^ | 15 | Weekly sessions over 12 months | Self-harm (RTSHI) | 12 months | 40 | Log mean (SE); 1.33 (0.22) | 40 | Log mean (SE); 2.01 (0.21) | <0.01
Individual and family MBT | Rossouw et al, 2012^128^ | 15 | Weekly sessions over 12 months | At least one incident of self-harm | 12 months | 40 | 22 (56) | 40 | 33 (83) | 0.01
Youth-nominated support team | King et al, 2009^108^ | 16 | 1 session and phone contact over flexible time period | Suicide attempt | 12 months | 175 | 29 (17) | 171 | 35 (20) | 0.51

Abbreviations: A&E=accident and emergency; CBT=cognitive behavioral therapy; CG=control group; CI=confidence interval; DBT=dialectical behavioral therapy; ED=emergency department; ER=emergency room; IG=intervention group; MBT=mentalization-based therapy; N=number; NR=not reported; NS=not significant; NSSI=non-suicidal self-injury; OR=odds ratio; RTSHI=Risk-Taking and Self-Harm Inventory for Adolescents; SA=suicide attempt; SASII=Suicide Attempt Self-Injury Interview; SD=standard deviation; SE=standard error.

Appendix F Table 2 Suicide Risk Interventions vs. Treatment as Usual or Attention Control: Suicide Symptoms

Treatment (Condition) | Author, Year | Mean Age (Years) | Dose and Duration | Outcome Measure | Time Point (Weeks) | Treatment N | Treatment Score (SD/SE) | Placebo N | Placebo Score (SD/SE) | Between-Group Difference | Between-Group P Value
Family CBT | Asarnow et al, 2017^66^ | 15 | 12 weeks | Percent with suicide attempts | | 20 | NR | 22 | NR | NA | NA
Family Therapy | Cottrell et al, 2018^80^; Cottrell et al, 2018^199^; Cottrell et al, 2018^200^ | 14 | 6-7 sessions over; 6 months | BSS | 12 months | 415 | 0.26 (0.05) | 417 | 0.36 (0.05) | OR (95% CI): 0.64 (0.44 to 0.94) | 0.024
Family Therapy | Cottrell et al, 2018^80^; Cottrell et al, 2018^199^; Cottrell et al, 2018^200^ | 14 | 6-7 sessions over; 6 months | HSFC | 12 months | 415 | 4.8 (0.40) | 417 | 5.1 (0.43) | Mean difference: −0.3 (−1.1 to 0.4) | 0.38
Family Therapy | Cottrell et al, 2018^80^; Cottrell et al, 2018^199^; Cottrell et al, 2018^200^ | 14 | 6-7 sessions over; 6 months | CDRS-R | 12 months | 248 | 33.2(1.46) | 189 | 33.9(1.57) | Mean difference: −0.6 (−3.1 to 1.9) | 0.62
Family Therapy | Cottrell et al, 2018^80^; Cottrell et al, 2018^199^; Cottrell et al, 2018^200^ | 14 | 6-7 sessions over; 6 months | PQ-LES | 12 months | 415 | 49.9 (1.12) | 417 | 48.8 (1.13) | Mean difference: 1.1 (−0.5 to 2.7) | 0.18
Family Therapy | Cottrell et al, 2018^80^; Cottrell et al, 2018^199^; Cottrell et al, 2018^200^ | 14 | 6-7 sessions over; 6 months | GHQ | 12 months | 415 | 12.8 (0.61) | 417 | 13.5 (0.65) | Mean difference: −0.7 (−1.8 to 0.3) | 0.19
Attachment-Based Family Therapy | Diamond et al, 2010^82^ | 15 | 5 to 8 sessions over 12 weeks | SIQ-Jr | 12 weeks | 35 | 5.2 (1.6-8.8) | 31 | 16.2 (10.1-22.2) | NR | NR
Attachment-Based Family Therapy | Diamond et al, 2010^82^ | 15 | 5 to 8 sessions over 12 weeks | SSI | 12 weeks | 35 | 69.2 (50.2-88.2) | 31 | 34.6 (15.0-54.2) | NR | NR
Attachment-Based Family Therapy | Diamond et al, 2010^82^ | 15 | 5 to 8 sessions over 12 weeks | BDI-II | 12 weeks | 35 | 12.6 (8.0-17.2) | 31 | 18.5 (12.9-24.0) | NR | NR
Group psychotherapy | Green et al, 2011^93^ | 12 to 14 years, N (%); IG1: 69 (38); CG: 70 (38); 15 to 17 years, N (%); IG1: 114 (62); CG: 113 (62) | 6 weeks followed by boosters until participants felt better | SIQ | 6 months | 171 | 61.5 (45.5) | 9 | 59.9 (48.4) | 0.07 (−8.60 to 8.75) | 0.99
Group psychotherapy | Green et al, 2011^93^ | 12 to 14 years, N (%); IG1: 69 (38); CG: 70 (38); 15 to 17 years, N (%); IG1: 114 (62); CG: 113 (62) | 6 weeks followed by boosters until participants felt better | MFQ | 6 months | 171 | 28.5 (16.1) | 178 | 27.6 (16.5) | −0.44 (−3.49 to 2.61) | 0.78
Group psychotherapy | Green et al, 2011^93^ | 12 to 14 years, N (%); IG1: 69 (38); CG: 70 (38); 15 to 17 years, N (%); IG1: 114 (62); CG: 113 (62) | 6 weeks followed by boosters until participants felt better | HoNOSCA | 6 months | 172 | 12.2 (6.3) | 180 | 12.6(6.1) | −0.55 (−1.64 to 0.54) | 0.32
Group MBT | Griffiths et al, 2019^94^ | 16 | 12 sessions over 12 weeks | RCADS MD | 12 weeks | 22 | 20.39 (4.74) | 26 | 18.15 (6.57) | | NS
Group therapy | Hazell et al, 2009^95^ | 14 | 6+ sessions over 12 months | SIQ | 8 weeks | 34 | 74.11 (41.75) | 37 | 76.40 (54.28) | | p=0.80
Group therapy | Hazell et al, 2009^95^ | 14 | 6+ sessions over 12 months | MFQ | 8 weeks | 34 | 30.91 (17.25) | 37 | 32.38 (19.94) | | p=0.60
Group therapy | Hazell et al, 2009^95^ | 14 | 6+ sessions over 12 months | CGAS | 8 weeks | 25 | 58.54 (8.70) | 25 | 60.59 (10.69)
Group therapy | Hazell et al, 2009^95^ | 14 | 6+ sessions over 12 months | HoNOSCA | 8 weeks | 26 | 16.77 (7.12) | 29 | 15.00 (9.28)
Group therapy | Hazell et al, 2009^95^ | 14 | 6+ sessions over 12 months | SDQ | 8 weeks | 33 | 17.66 (6.58) | 37 | 18.89 (7.16)
Developmental Group Therapy | Wood et al, 2001^159^ | 14 | Median of 8 group sessions and 2.5 indiviual sessions over 6 months | SIQ | 7 months | 28 | 47.3 (50.5) | 27 | 39.7 (46.7) | 7.5 (−18.8 to 33.9)
Developmental Group Therapy | Wood et al, 2001^159^ | 14 | Median of 8 group sessions and 2.5 indiviual sessions over 6 months | MFQ | 7 months | 29 | 18.8 (16.0) | 27 | 15.3 (13.0) | 3.5 (−4.4 to 11.3)
Developmental Group Therapy | Wood et al, 2001^159^ | 14 | Median of 8 group sessions and 2.5 indiviual sessions over 6 months | HoNOSCA | 7 months | 31 | 8.4 (6.4) | 31 | 6.9 (6.1) | 1.5 (−1.7 to 4.7) | NR
Individual internet CBT | Hill et al, 2019^97^ | 17 | 2 sessions 1 week apart | BSS | 2 weeks | 41 | 2.05 (3.27) | 39 | 4.49 (6.01) | | 0.12
Individual internet CBT | Hill et al, 2019^97^ | 17 | 2 sessions 1 week apart | RADS-2 | 2 weeks | 41 | 23.12 (4.50) | 39 | 24.64 (5.90) | | 0.45
Interpersonal psychotherapy | Tang et al, 2009^144^ | 15 | 2 weekly sessions and weekly phone call, over 6 weeks | BHS | 6 weeks | 35 | 7.74 (5.29) | 38 | 12.42 (4.08) | | P<0.01
Interpersonal psychotherapy | Tang et al, 2009^144^ | 15 | 2 weekly sessions and weekly phone call, over 6 weeks | BSS | 6 weeks | 35 | 8.97 (10.77) | 38 | 16.29 (7.99) | | P<0.01
Interpersonal psychotherapy | Tang et al, 2009^144^ | 15 | 2 weekly sessions and weekly phone call, over 6 weeks | BDI-II | 6 weeks | 35 | 19.97 (14.68) | 38 | 31.58 (12.01) | | P<0.001
Individual and Family DBT | Mehlum et al, 2014^115^; Mehlum et al, 2016^201^; Mehlum et al, 2019^202^; Haga et al, 2018^203^ | 16 | 1 weekly individual session, 1 weekly multifamily skills training, and family sessions and telephone coaching outside of sessions as needed, over 19 weeks | SIQ-Jr | 71 weeks | 38 | 20.45 (19.15) | 37 | 22.05 (21.86) | Between-group difference in slope: 0.15 | 0.110
Individual and Family DBT | Mehlum et al, 2014^115^; Mehlum et al, 2016^201^; Mehlum et al, 2019^202^; Haga et al, 2018^203^ | 16 | 1 weekly individual session, 1 weekly multifamily skills training, and family sessions and telephone coaching outside of sessions as needed, over 19 weeks | BHS | 19 weeks | 39 | 6.23 (5.30) | 38 | 9.06 (6.53) | Between-group difference in slope: −0.13 | 0.071
Individual and Family DBT | Mehlum et al, 2014^115^; Mehlum et al, 2016^201^; Mehlum et al, 2019^202^; Haga et al, 2018^203^ | 16 | 1 weekly individual session, 1 weekly multifamily skills training, and family sessions and telephone coaching outside of sessions as needed, over 19 weeks | SMFQ | 19 weeks | 39 | 10.19 (5.04) | 38 | 12.58 (6.62) | −0.10 | 0.179
Individual and Family DBT | Mehlum et al, 2014^115^; Mehlum et al, 2016^201^; Mehlum et al, 2019^202^; Haga et al, 2018^203^ | 16 | 1 weekly individual session, 1 weekly multifamily skills training, and family sessions and telephone coaching outside of sessions as needed, over 19 weeks | MADRS | 19 weeks | 39 | 12.29 (7.52) | 38 | 15.76 (8.14) | −0.22 | P=0.019
Individual and Family DBT | Mehlum et al, 2014^115^; Mehlum et al, 2016^201^; Mehlum et al, 2019^202^; Haga et al, 2018^203^ | 16 | 1 weekly individual session, 1 weekly multifamily skills training, and family sessions and telephone coaching outside of sessions as needed, over 19 weeks | CGAS | 71 weeks | 38 | 65.68 (11.81) | 37 | 64.22 (14.13) | Between-group difference in slope: 0.03 | 0.067
Individual and family MBT | Rossouw et al, 2012^128^ | 15 | Weekly sessions over 12 months | MFQ | 12 months | 40 | 9.26 (1.27) | 40 | 11.54 (1.14) | | P<0.05
Motivational interviewing | King et al, 2015^107^ | 18 | 1 session | SIQ-Jr | 2 months | 24 | 21.46 (17.4) | 22 | 24.28 (17.3) | | NS
Motivational interviewing | King et al, 2015^107^ | 18 | 1 session | BHS | 2 months | 24 | 5.66 (5.2) | 22 | 8.64 (5.7) | | NS
Motivational interviewing | King et al, 2015^107^ | 18 | 1 session | RADS-2-SF | 2 months | 24 | 25.38 (4.7) | 22 | 30.87 (4.0) | | P<0.01
Therapeutic assessment | Ougrin et al, 2013^121^; Ougrin, 2011^204^ | 16 | 1 session | | | 35 | | 35
Therapeutic assessment | Ougrin et al, 2013^121^; Ougrin, 2011^204^ | 16 | 1 session | CGAS | 3 months | 35 | 64.6 (12.9) | 35 | 60.1 (9.9) | 4.49 (−0.98 to 9.96) | NR
Youth-Nominated Support Team | King et al, 2009^108^ | 16 | 1 session and weeky telephone contact, 1 session and phone contact over flexible time period | BHS | 6 weeks | NR | 6.82 (NR) | NR | 7.80 (NR) | | 0.09
Youth-Nominated Support Team | King et al, 2009^108^ | 16 | 1 session and weeky telephone contact, 1 session and phone contact over flexible time period | SIQ-Jr | 6 weeks | NR | 25.55 (NR) | NR | 29.71 (NR) | | 0.04
Youth-Nominated Support Team | King et al, 2009^108^ | 16 | 1 session and weeky telephone contact, 1 session and phone contact over flexible time period | CDRS-R | 6 weeks | NR | 39.6 (NR) | NR | 40.80 (NR) | | 0.40
Youth-Nominated Support Team | King et al, 2009^108^ | 16 | 1 session and weeky telephone contact, 1 session and phone contact over flexible time period | CAFAS | 3 months | 168 | 15.20 (NR) | 174 | 15.77 (NR) | | 0.58
RAP-P | Pineda et al, 2013^125^ | 15 | 4 sessions over 4 to 8 weeks | ASQ-R, | Post-treatment | 22 | 8.73 (4.88) | 18 | 11.89 (5.47) | | p=0.05
RAP-P | Pineda et al, 2013^125^ | 15 | 4 sessions over 4 to 8 weeks | HoNOSCA | Post-treatment | 22 | 13.45 (5.89) | 18 | 17.61 (5.20) | | p<0.01
Promoting Care, Assess, Respond, Empower | Hooven et al, 2012^100^ | 16 | C-Care, 1 session, 2 hours total; P-CARE, 2 sessions, 2 hours total; C-Care plus P-CARE, 1 child session, 2 hours total; 2 parent sessions, 2 hours total | Suicide Ideation | 1 month | 153; 155; 164 | IG1 Rate of change: −1.131; IG2 Rate of change: −1.033; IG2 Rate of change: −1.451 | 143 | −0.917 | NA | G1 and G2 vs. CG: NS; G3 vs. CG: P<0.001
Promoting Care, Assess, Respond, Empower | Hooven et al, 2012^100^ | 16 | C-Care, 1 session, 2 hours total; P-CARE, 2 sessions, 2 hours total; C-Care plus P-CARE, 1 child session, 2 hours total; 2 parent sessions, 2 hours total | Direct Suicide Threat | 1 month | 153; 155; 164 | IG1 Rate of change: −0.443; IG2 Rate of change: −0.294; IG2 Rate of change: −0.556 | 143 | −0.318 | NA | G1 and G2 vs. CG: NS; G3 vs. CG: P<0.05
Promoting Care, Assess, Respond, Empower | Hooven et al, 2012^100^ | 16 | C-Care, 1 session, 2 hours total; P-CARE, 2 sessions, 2 hours total; C-Care plus P-CARE, 1 child session, 2 hours total; 2 parent sessions, 2 hours total | CES-D | 1 month | 153 | −0.951 | 143 | −0.685 | NA | P<0.01
Promoting Care, Assess, Respond, Empower | Hooven et al, 2012^100^ | 16 | C-Care, 1 session, 2 hours total; P-CARE, 2 sessions, 2 hours total; C-Care plus P-CARE, 1 child session, 2 hours total; 2 parent sessions, 2 hours total | CES-D | 1 month | 155 | −0.815 | 143 | −0.685 | NA | NS
Promoting Care, Assess, Respond, Empower | Hooven et al, 2012^100^ | 16 | C-Care, 1 session, 2 hours total; P-CARE, 2 sessions, 2 hours total; C-Care plus P-CARE, 1 child session, 2 hours total; 2 parent sessions, 2 hours total | CES-D | 1 month | 164 | −1.021 | 143 | −0.685 | NA | P<0.01

Abbreviations: ASQ-R=Adolescent Suicide Questionnaire–Revised; BDI-II=Beck Depression Inventory, version 2; BHS=Beck Hopelessness Scale; BSS=Beck Scale for Suicide Ideation; C-Care=Counselors Care, Assess, Respond, Empower; CAFAS=Child and Adolescent Functional Assessment Scale; CBT=cognitive behavioral therapy; CDRS-R=Children’s Depression Rating Scale-Revised; CES-D=Center for Epidemiological Studies-Depression; CG=control group; CGAS=Children’s Global Assessment Scale; CI=confidence interval; DBT=dialectical behavioral therapy; G=group; GHQ=General Health Questionnaire, 12 questions; HSFC=Hopelessness Scale for Children; HoNOSCA=Health of the Nation Outcome Scales for Children and Adolescents; HSFC=Hopelessness Scale for Children; IG=intervention group; IG=intervention group; MADRS=Montgomery–Åsberg Depression Rating Scale; MBT=mentalization-based therapy; MFQ=mood & feelings questionnaire; N=number; NA=not applicable; NR=not reported; NS=not significant; OR=odds ratio; P-Care=Parents-Counselors Care, Assess, Respond, Empower; PQ-LES=Pediatric Quality of Life Enjoyment and Satisfaction Questionnaire; RADS-2=Reynolds Adolescent Depression Scale, 2nd Edition; RADS-2-SF=Reynolds Adolescent Depression Scale, 2nd Edition: Short Form; RAP-P=Resourceful Adolescent Parent Program; RCADS MD=Revised Children’s Anxiety and Depression Scale-Depression; SD=standard deviation; SDQ=Strengths and Difficulties Questionnaire; SE=standard error; SIQ=Suicidal Ideation Questionnaire; SIQ-Jr=Suicidal Ideation Questionnaire-Junior; SMFQ=Short Mood and Feelings Questionnaire; SSI=Scale for Suicidal Ideation; vs.=versus.

Appendix F Table 3 Anxiety CBT Interventions vs. Wait-List, Treatment as Usual, or Placebo: Anxiety Symptoms

Treatment (Condition) | Author, Year | Mean Age (Years) | Intervention and Duration | Outcome Measure | Time Point (Weeks) | Treatment N | Treatment Score (SD/SE) | Placebo; N | Placebo; Score (SD/SE) | Between-Group Difference | Between-Group P Value
Group CBT | Arendt et al, 2016^65^ | 11.8 | Manualized group CBT program (Cool Kids), 10 weeks | ADIS CSR primary diagnosis | 10 | 56 | 2.16 (SD: 2.59) | 53 | 5.45 (SD: 1.90) | Partial eta squared=0.35 | <0.001
Group CBT | Arendt et al, 2016^65^ | 11.8 | Manualized group CBT program (Cool Kids), 10 weeks | ADIS CSR all diagnosis | 10 | 56 | 5.21 (SD: 5.19) | 53 | 10.75 (SD: 5.63) | Partial eta squared=0.22 | <0.001
Group CBT | Arendt et al, 2016^65^ | 11.8 | Manualized group CBT program (Cool Kids), 10 weeks | SCAS-youth | 10 | 56 | 21.57 (SD: 14.42) | 53 | 32.55 (SD: 15.64) | Partial eta squared=0.18 | <0.001
Group CBT | Arendt et al, 2016^65^ | 11.8 | Manualized group CBT program (Cool Kids), 10 weeks | SCAS-P mother | 10 | 56 | 22.25 (SD: 12.59) | 53 | 37.04 (SD: 16.95) | Partial eta squared=0.24 | <0.001
Group CBT | Arendt et al, 2016^65^ | 11.8 | Manualized group CBT program (Cool Kids), 10 weeks | SCAS-P father | 10 | 56 | 23.56 (SD: 13.87) | 53 | 32.63 (SD: 16.17) | Partial eta squared=0.19 | <0.001
Group CBT | Asbrand et al, 2020^67^ | 11.3 | Exposure-based group CBT, 12 weeks | SPAI-C | 12 | 31 | NR | 36 | NR | F(2,116.6)=5.87 | 0.004
Group CBT | Asbrand et al, 2020^67^ | 11.3 | Exposure-based group CBT, 12 weeks | SASC-R child | 12 | 31 | NR | 36 | NR | F(2,115.6)=1.16 | 0.316
Group CBT | Asbrand et al, 2020^67^ | 11.3 | Exposure-based group CBT, 12 weeks | SASC-R parent | 12 | 31 | NR | 36 | NR | F(2,114.4)=1.01 | 0.366
Group CBT | Cornacchio et al, 2019^79^ | 6.6 | Group CBT program that relies on the early child format of Parent Child Interaction Therapy, 5 days | ADIS CSR selective mutism | 4 | 14 | 4.2 (SD: 0.9) | 15 | 4.6 (SD: 0.7) | Effect size Cohen’s d=−0.50 | >0.05
Group CBT | Cornacchio et al, 2019^79^ | 6.6 | Group CBT program that relies on the early child format of Parent Child Interaction Therapy, 5 days | ADIS CSR social anxiety | 4 | 14 | 4.0 (SD: 0.8) | 15 | 4.0 (SD: 0.8) | Effect size Cohen’s d=−0.50 | >0.05
Group CBT | Cornacchio et al, 2019^79^ | 6.6 | Group CBT program that relies on the early child format of Parent Child Interaction Therapy, 5 days | SMQ-P home subscale | 4 | 14 | 2.2 (SD: 0.4) | 15 | 1.7 (SD: 0.7) | Cohen’s d=0.36 | >0.05
Group CBT | Cornacchio et al, 2019^79^ | 6.6 | Group CBT program that relies on the early child format of Parent Child Interaction Therapy, 5 days | SMQ-P social subscale | 4 | 14 | 1.2 (SD: 0.6) | 15 | 0.7 (SD: 0.7) | Cohen’s d=0.58 | <0.05
Group CBT | Holmes et al, 2014^99^ | 9.6 | Group CBT program termed “No Worries!” that utilizes the A-B-C model, 10 weeks | ADIS-C/P CSR | 10 | 17 | 3.59 (SD: 1.3) | 19 | 6.21 (SD: 0.79) | Partial-eta squared=0.43 | <0.001
Group CBT | Holmes et al, 2014^99^ | 9.6 | Group CBT program termed “No Worries!” that utilizes the A-B-C model, 10 weeks | SCAS-P GAD symptoms | 10 | 20 | NR | 22 | NR | Partial eta squared=0.09 | 0.048
Group CBT | Holmes et al, 2014^99^ | 9.6 | Group CBT program termed “No Worries!” that utilizes the A-B-C model, 10 weeks | SCAS-P GAD symptoms | 10 | 17 | 6.17 (SD: 2.71) | 19 | 6.84 (2.29) | NR | 0.053
Group CBT | Holmes et al, 2014^99^ | 9.6 | Group CBT program termed “No Worries!” that utilizes the A-B-C model, 10 weeks | SCAS-P total symptoms | 10 | 17 | 29.94 (SD: 12.70) | 19 | 31.47 (SD: 8.79) | NR | P=NS
Group CBT | Holmes et al, 2014^99^ | 9.6 | Group CBT program termed “No Worries!” that utilizes the A-B-C model, 10 weeks | SCAS-C GAD symptoms | 10 | 17 | 7.41 (SD: 4.65) | 19 | 8.42 (SD: 4.56) | NR | P=NS
Group CBT | Holmes et al, 2014^99^ | 9.6 | Group CBT program termed “No Worries!” that utilizes the A-B-C model, 10 weeks | SCAS-C total symptoms | 10 | 17 | 34.88 (SD: 20.25) | 19 | 40.84 (SD: 19.93) | NR | P=NS
Group CBT | Lau et al, 2010^110^ | 8 years 7 months | Coping Cat CBT group-treatment program, 11 weeks | SCAS-C | 13 | 24 | 24.6 (SD: 10.5) (9.7 decrease from baseline) | 21 | 38.8 (SD: 13.7) (1.8 increase from baseline) | Effect size partial eta squared=0.27 | <0.001
Group CBT | Lau et al, 2010^110^ | 8 years 7 months | Coping Cat CBT group-treatment program, 11 weeks | SCAS-P | 13 | 24 | 28.8 (SD: 10.3) (decrease 4.2 from baseline); | 21 | 36.5 (SD: 11.0) (increase 1.3 from baseline) | Effect size partial eta squared=0.11 | <0.05
Group CBT | Sanchez-Garcia et al, 2009^131^ | 11.91 | Group CBT referred to as Intervencion en Adolescentes con Fobia Social, 12 weeks | SPAI-C | 12 | IG1: 28; IG2: 29 | IG1: 15.45 (SD: 7.77);; IG2: 12.75 (SD: 8.03); | 25 | 30.80 (SD: 5.75) | IG1 vs. CG: effect size=2.23; IG2 vs. CG: effect size=2.51 | IG1 vs. CG <0.001; IG2 vs. CG <0.001
Group CBT | Sanchez-Garcia et al, 2009^131^ | 11.91 | Group CBT referred to as Intervencion en Adolescentes con Fobia Social, 12 weeks | SPAI-C | 24 | IG1: 28; IG2: 29 | IG1:11.91 (SD: 6.03); IG2: 13.21 (SD: 8.55) | 25 | 27.64 (SD: 4.01) | IG1 vs. CG: effect size=3.04; IG2 vs. CG effect size=2.08 | IG1 vs. CG <0.001; IG2 vs. CG <0.001
Group CBT | Sanchez-Garcia et al, 2009^131^ | 11.91 | Group CBT referred to as Intervencion en Adolescentes con Fobia Social, 12 weeks | SASC-R | 12 | IG1: 28; IG2: 29 | IG1: 15.89 (SD: 6.81); IG2: 11.45 (SD: 6.48) | 25 | 35.36 (SD: 5.33) | IG1 vs. CG: effect size=3.16; IG2 vs. CG effect size=3.94 | IG1 vs. CG <0.001; IG2 vs. CG <0.001
Group CBT | Sanchez-Garcia et al, 2009^131^ | 11.91 | Group CBT referred to as Intervencion en Adolescentes con Fobia Social, 12 weeks | SASC-R | 24 | IG1: 28; IG2: 29 | IG1:12.14 (SD: 6.86); IG2: 12.24 (SD: 7.34) | 25 | 38.80 (SD: 6.71) | IG1 vs. CG: effect size=2.44; IG2 vs. CG effect size=2.90 | <0.001; IG2 vs. CG <0.001
Individual CBT | Barrett et al, 1996^70^ | 9.3 | Individual CBT using using Coping Koala Workbook, 12 weeks | RCMAS | 12 | 28 | IG1: 9.0 (6.8); IG2: 6.6 (4.6) | 23 | 11.6 (SD: 6.0) | NR | IG1 vs. CG: P=NS IG2 vs. CG: P=NS
Individual CBT | Barrett et al, 1996^70^ | 9.3 | Individual CBT using using Coping Koala Workbook, 12 weeks | FSSCR | 12 | 28 | IG1: 119.9 (26.0); IG2: 114.2 (20.2) | 23 | 134.3 (SD: 32.6) | NR | IG1 vs. CG: P=NS; IG2 vs. CG: P=NS
Individual CBT | Ginsburg et al, 2020^92^ | 10.9 | Individual CBT consisting of 7 core modules, 12 weeks | CGI-S | 12 | 148 | 3.97 | 68 | 4.15 | NR | 0.38
Individual CBT | Ginsburg et al, 2020^92^ | 10.9 | Individual CBT consisting of 7 core modules, 12 weeks | CGI-S | 52 | 148 | 3.61 | 68 | 3.41 | NR | 0.34
Individual CBT | Ginsburg et al, 2020^92^ | 10.9 | Individual CBT consisting of 7 core modules, 12 weeks | | 12 | 148 | 20.25 | 68 | 21.72 | Cohen’s d=0.29 | 0.05
Individual CBT | Ginsburg et al, 2020^92^ | 10.9 | Individual CBT consisting of 7 core modules, 12 weeks | SCARED-P | 52 | 148 | 17.74 | 68 | 15.12 | NR | 0.44
Individual CBT | Ginsburg et al, 2020^92^ | 10.9 | Individual CBT consisting of 7 core modules, 12 weeks | SCARED-C | 12 | 148 | 22.82 | 68 | 23.65 | NR | 0.87
Individual CBT | Ginsburg et al, 2020^92^ | 10.9 | Individual CBT consisting of 7 core modules, 12 weeks | SCARED-C | 52 | 148 | 19.63 | 68 | 20.54 | NR | 0.65
Individual CBT | Perrin et al, 2019^122^ | 13.4; | Individual, GAD-specific CBT, 10 weeks | ADIS GAD severity | 10 | 20 | 1.9 (SD: 2.3) | 20 | 5.7 (SD: 1.1) | Effect size partial eta squared=0.54 | <0.001
Individual CBT | Perrin et al, 2019^122^ | 13.4; | Individual, GAD-specific CBT, 10 weeks | SCARED-R-C (anxiety) | 10 | 20 | 15.2 (SD: 12.5) | 20 | 46.3 (SD: 15.9) | Effect size partial eta squared=0.53 | <0.001
Individual CBT | Perrin et al, 2019^122^ | 13.4; | Individual, GAD-specific CBT, 10 weeks | SCARED-R-P (anxiety) | 10 | 20 | 18.9 (SD: 12.4) | 20 | 38.2 (SD: 14.9) | Effect size partial eta squared=0.37 | <0.001
Individual CBT | Perrin et al, 2019^122^ | 13.4; | Individual, GAD-specific CBT, 10 weeks | SCARED-R-C (GAD) | 10 | 20 | 4.6 (SD: 5.2) | 20 | 12.9 (SD: 4.2) | Effect size partial eta squared=0.47 | <0.001
Individual CBT | Perrin et al, 2019^122^ | 13.4; | Individual, GAD-specific CBT, 10 weeks | SCARED-R-P (GAD) | 10 | 20 | 6.5 (SD: 4.3) | 20 | 11.2 (SD: 4.7) | Effect size partial eta squared=0.24 | <0.001
Individual CBT | Perrin et al, 2019^122^ | 13.4; | Individual, GAD-specific CBT, 10 weeks | PSWQ-C | 10 | 20 | 10.6 (SD: 12.2) | 20 | 31.1 (SD: 7.2) | Effect size partial eta squared=0.4 | <0.001
Individual CBT | Salzer et al, 2018^42^ | 17.4 | Individual CBT focused on reducing self-focused attentional and safety behaviors, 31 weeks | LSAS-CA change from baseline | Post-treatment | 34 | NR | 39 | NR | Effect size Cohen’s d (95% CI); 0.61 (0.14 to 1.08) | 0.0112
Individual CBT | Salzer et al, 2018^42^ | 17.4 | Individual CBT focused on reducing self-focused attentional and safety behaviors, 31 weeks | SPAI change from baseline | Post-treatment | 34 | NR | 39 | NR | Effect size Cohen’s d (95% CI); 0.75 (0.27 to 1.22) | 0.0021
Individual CBT | Villabo et al, 2018^150^ | 10.5 | Individual CBT using the Coping Cat manual, 12 weeks | MASC-child | 12 | IG1: 55; IG2: 55 | IG1:48.61 (SE 1.48); IG2: 48.8 (SE: 1.65) | 55 | 51.95 (SE: 1.60) | Effect size Hedges g (95% CI); IG1 vs CG: 0.28 (0.10 to 0.65); IG2 vs CG: 0.26 (0.12 to 0.64) | IG1 vs CG: P=NS; IG2 vs. CG: P=NS
Individual CBT | Villabo et al, 2018^150^ | 10.5 | Individual CBT using the Coping Cat manual, 12 weeks | MASC-parent | 12 | IG1: 55; IG2: 55 | IG1: 47.25 (SE: 2.58); IG2: 49.72 (SE: 2.46) | 55 | 50.86 (SE: 2.45) | Effect size Hedges g (95% CI); IG1 vs. CG: 0.20 (0.18 to 0.61); IG2 vs. CG: 0.06 (−0.34 to 0.48) | IG1 vs CG: P=NS; IG2 vs. CG: P=NS
Individual CBT, Sertraline, Individual CBT+Sertraline | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | Individual CBT using Coping Cat program adapted for child’s age and length of the study, 12 weeks | PARS change from baseline | 12 | IG1: 139; IG2: 133; IG3: 140 | IG1: 10.8 (SD: 5.9); IG2: 9.8 (SD: 6.2); IG3: 7.4 (SD: 6.0) | 76 | 12.6 (SD: 6.3) | IG1 vs. CG: Effect size Hedge’s g (95% CI): 0.31 (0.02 to 0.59); IG2 vs. CG: Effect size Hedges g (95% CI): 0.45 (0.17 to 0.74); IG3 vs. CG: Effect size Hedge’s g (95% CI): 0.86 (0.56 to 1.15) | IG1 vs. CG: P=0.01; IG2 vs. CG: P=NS; IG3 vs. CG: P=NS
Individual CBT, Sertraline, Individual CBT+Sertraline | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | Individual CBT using Coping Cat program adapted for child’s age and length of the study, 12 weeks | CGI-S change from baseline | 12 | IG1: 139; IG2: 133; IG3: 140 | IG1: 3.3 (SD: 1.3); IG2: 3.0 (SD: 1.3); IG3: 2.4 (SD: 1.3) | 76 | 3.8 (SD: 1.4) | NR | NR
Individual CBT, Sertraline, Individual CBT+Sertraline | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | Individual CBT using Coping Cat program adapted for child’s age and length of the study, 12 weeks | MASC-C | 12 | IG1: 139; IG2: 133; IG3: 140 | IG1: 40.9 (SD: 10.4); IG2: 38.2 (SD: 10.7); IG3: 39.5 (10.8) | 76 | 42.9 (SD: 11.8) | IG2 vs. CG: b=−4.68, t=−2.80 | IG2 vs. CG: adjusted P=0.03; All other comparisons not statistically significant, P NR
Individual CBT, Sertraline, Individual CBT+Sertraline | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | Individual CBT using Coping Cat program adapted for child’s age and length of the study, 12 weeks | MASC-P | 12 | IG1: 139; IG2: 133; IG3: 140 | IG1: 42.1 (SD: 16.1); IG2: 37.9 (SD: 17.3); IG3: 33.4 (SD: 16.9) | 76 | 49.1 (SD: 16.9) | IG1 vs. CG: b=−7.0, t=−2.9; IG2 vs. CG: b=−11.1, t=−4.4; IG3 vs. CG: b=−15.7, t=−6.4 | IG1 vs. CG; adjusted P<0.001; IG2 vs. CG; adjusted P<0.001; IG3 vs. CG: adjusted P<0.001
Individual CBT, Sertraline, Individual CBT+Sertraline | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | Individual CBT using Coping Cat program adapted for child’s age and length of the study, 12 weeks | SCARED-C | 12 | IG1: 139; IG2: 133; IG3: 140 | IG1: 12.4 (SD: 11.4); IG2: 9.3 (SD: 11.9); IG3: 9.4 (SD: 11.6) | 76 | 13.8 (SD: 12.1) | NR | No statistically significant differences between arms, P NR;
Individual CBT, Sertraline, Individual CBT+Sertraline | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | Individual CBT using Coping Cat program adapted for child’s age and length of the study, 12 weeks | SCARED-P | 12 | IG1: 139; IG2: 133; IG3: 140 | IG1: 16.9 (SD: 11.2); IG2: 11.0 (SD: 11.7); IG3: 9.6 (SD: 11.4) | 76 | 19.5 (SD: 11.8) | IG1 vs. CG: NR; IG2 vs. CG: b=−7.9, t=−4.7; IG3 vs. CG: b=−9.8, t=−5.9 | IG1 vs. CG: adjusted P=0.26; IG2 vs. CG: adjusted P<0.001; IG3 vs. CG: adjusted P<0.001
Individual CBT, Sertraline, Individual CBT+Sertraline | Ost et al, 2015^212^ | 11.6 | Individual weekly sessions and social skills group weekly sessions for the child and parent training about SocAD, 12 weeks | CSR change from baseline | 12 | IG1: 16; IG2: 16 | IG1: 3.25 (SD: 0.39); IG2: 3.69 (SD: 1.66) | 23 | 5.95 (SD: 1.15) | F=26.6 | <0.001; IG1 vs. CG: P=sig, NR, favoring IG1; IG2 vs. CG: P=sig, NR, favoring IG2
Individual CBT, Sertraline, Individual CBT+Sertraline | Ost et al, 2015^212^ | 11.6 | Individual weekly sessions and social skills group weekly sessions for the child and parent training about SocAD, 12 weeks | SPAI-C change from baseline | 12 | IG1: 16; IG2: 16 | IG1: 12.5 (SD: 8.9); IG2: 19.1 (SD: 12.0) | 23 | 22.8 (SD: 9.4) | F=5.0 | <0.05; IG1 vs. CG: P=sig, NR, favoring IG1; IG2 vs. CG: P=sig, NR, favoring IG2
Individual CBT, Sertraline, Individual CBT+Sertraline | Ost et al, 2015^212^ | 11.6 | Individual weekly sessions and social skills group weekly sessions for the child and parent training about SocAD, 12 weeks | MASC change from baseline | 12 | IG1: 16; IG2: 16 | IG1: 35.8 (SD: 16.0); IG2: 43.2 (SD: 18.1) | 23 | 54.7 (SD: 15.3) | F=4.6 | <0.05; IG1 vs. CG: P=sig, NR, favoring IG1; IG2 vs. CG: P=NS
Individual CBT, Sertraline, Individual CBT+Sertraline | Ost et al, 2015^212^ | 11.6 | Individual weekly sessions and social skills group weekly sessions for the child and parent training about SocAD, 12 weeks | CDI change from baseline | 12 | IG1: 16; IG2: 16 | IG1: 6.4 (SD: 6.1); IG2: 9.3 (SD: 9.7) | 23 | 11.0 (SD: 7.7) | F=1.2 | P=NS
Individual CBT, Sertraline, Individual CBT+Sertraline | Ost et al, 2015^212^ | 11.6 | Individual weekly sessions and social skills group weekly sessions for the child and parent training about SocAD, 12 weeks | SPAI-P change from baseline | 12 | IG1: 16; IG2: 16 | IG1: 19.8 (SD: 10.7); IG2: 24.6 (SD: 12.5) | 23 | 29.8 (SD: 8.7) | F=4.2; | <0.05; IG1 vs. CG: P=sig, NR, favoring IG1; IG2 vs. CG: P=NS
Individual CBT, Sertraline, Individual CBT+Sertraline | Ost et al, 2015^212^ | 11.6 | Individual weekly sessions and social skills group weekly sessions for the child and parent training about SocAD, 12 weeks | FSSCR change from baseline | 12 | IG1: 16; IG2: 16 | IG1: 109.1 (SD: 23.7); IG2: 117.3 (SD: 30.2) | 23 | 119.3 (SD: 32.6) | F=0.8 | >0.05; IG1 vs. CG: P=NS; IG2 vs. CG: P=NS
Internet CBT | Donovan et al, 2014^83^ | 4.1 | Online individual parent-focused CBT, 8 weeks | CSR | 8 | 23 | 3.4 (SD: 2.4) | 27 | 4.7 (SD: 2.0) | Partial eta squared=0.176 (mITT); 0.188 (ITT) | 0.002 (mITT); 0.001 (ITT)
Internet CBT | Donovan et al, 2014^83^ | 4.1 | Online individual parent-focused CBT, 8 weeks | PAS | 8 | 19 | 30.0 (SD: 14.7) | 29 | 40.2 (SD: 17.0) | Partial eta-squared=0.131; 0.066 (mITT) | 0.011 (mITT); 0.66 (ITT)
Internet CBT | Stjerneklar et al, 2019^141^ | 15 | Internet CBT based on Cool Kids and Chilled anxiety management program, 14 weeks | ADIS-DSM IV CSR (primary diagnosis) change from baseline | 14 | 35 | NR | 35 | NR | Cohen’s d=0.65; | 0.022
Internet CBT | Stjerneklar et al, 2019^141^ | 15 | Internet CBT based on Cool Kids and Chilled anxiety management program, 14 weeks | ADIS-DSM-IV CSR (all anxiety diagnoses) change from baseline | 14 | 35 | NR | 35 | NR | Cohen’s d=0.83 | 0.002
Internet CBT | Stjerneklar et al, 2019^141^ | 15 | Internet CBT based on Cool Kids and Chilled anxiety management program, 14 weeks | SCAS-C change from baseline | 14 | 35 | NR | 35 | NR | Cohen’s d=0.68 | <0.001
Internet CBT | Stjerneklar et al, 2019^141^ | 15 | Internet CBT based on Cool Kids and Chilled anxiety management program, 14 weeks | SCAS-M change from baseline | 14 | 35 | NR | 35 | NR | Cohen’s d=1.12 | <0.001
Internet CBT | Stjerneklar et al, 2019^141^ | 15 | Internet CBT based on Cool Kids and Chilled anxiety management program, 14 weeks | SCAS-F change from baseline | 14 | 35 | NR | 35 | NR | Cohen’s d=0.46 | 0.011
Internet CBT | Waite et al, 2019^152^ | 14.7 | Internet CBT with accompanying parent sessions for half the group and no parent sessions for the other half, 10 weeks | CSR change from baseline | 17 | 30 | 3.89 (SD: 2.58) | 30 | 4.86 (SD: 2.19) | Effect size=0.05 (95% CI, 0.00 to 0.19) | NR
Internet CBT | Waite et al, 2019^152^ | 14.7 | Internet CBT with accompanying parent sessions for half the group and no parent sessions for the other half, 10 weeks | SCAS-C change from baseline | 17 | 30 | 30.35 (SD: 19.17) | 30 | 33.46 (SD: 15.01) | Effect size=0.05 (95% CI, 0.00 to 0.20) | NR
Internet CBT | Waite et al, 2019^152^ | 14.7 | Internet CBT with accompanying parent sessions for half the group and no parent sessions for the other half, 10 weeks | SCAS-P change from baseline | 17 | 30 | 33.12 (SD: 21.70) | 30 | 28.93 (SD: 15.79) | Effect size=0.06 (95% CI, 0.00 to 0.21) | NR
Parent-only CBT | Cobham et al, 2017^77^ | 9.3 | Parent-only group-based CBT sessions, 6 weeks | ADIS-CSR | 6 | 33 | 3.7 (SD: 2.6) | 29 | 5.4 (SD: 1.1) | NR | <0.001
Parent-only CBT | Cobham et al, 2017^77^ | 9.3 | Parent-only group-based CBT sessions, 6 weeks | SCAS-M | 6 | 33 | 20.1 (SD: 4.9) | 29 | 32.3 (SD: 11.9) | NR | <0.001
Parent-only CBT | Cobham et al, 2017^77^ | 9.3 | Parent-only group-based CBT sessions, 6 weeks | SCAS-F | 6 | 33 | 21.4 (SD: 14.4) | 29 | 30.6 (SD: 15.2) | NR | 0.53
Parent-only CBT | Cobham et al, 2017^77^ | 9.3 | Parent-only group-based CBT sessions, 6 weeks | SCAS-C | 6 | 33 | 34.4 (SD: 13.9) | 29 | 42.1 (SD: 11.5) | NR | <0.01
Parent-only and parent-child CBT | Hirshfeld-Becker et al, 2010^98^ | 5.4 | Being Brave manualized CBT intervention with parent-only and parent-child sessions, 6 months | CGI-I SocAD score | 24 | 19 | 2.42 (SD: 0.96) | 20 | 3.40 (SD: 1.05) | Hedge’s g=0.95 (95% CI, 0.29 to 1.62) | <0.01
Parent-only and parent-child CBT | Hirshfeld-Becker et al, 2010^98^ | 5.4 | Being Brave manualized CBT intervention with parent-only and parent-child sessions, 6 months | CGI-I S SepAD score | 24 | 12 | 1.67 (SD: 0.98) | 13 | 2.46 (SD: 0.88) | Hedge’s g=0.82 (95% CI, 0.01 to 1.64) | 0.045
Parent-only and parent-child CBT | Hirshfeld-Becker et al, 2010^98^ | 5.4 | Being Brave manualized CBT intervention with parent-only and parent-child sessions, 6 months | CGI-I GAD score | 24 | 12 | 2.17 (SD: 0.83) | 12 | 2.58 (SD: 1.38) | NR | 0.38
Parent-only and parent-child CBT | Hirshfeld-Becker et al, 2010^98^ | 5.4 | Being Brave manualized CBT intervention with parent-only and parent-child sessions, 6 months | CGI-I specific phobia score | 24 | 15 | 1.87 (SD: 1.30) | 15 | 2.87 (SD: 1.19) | Hedge’s g=0.78 (95% CI, 0.04 to 1.52) | 0.037
Parent-only and parent-child CBT | Hirshfeld-Becker et al, 2010^98^ | 5.4 | Being Brave manualized CBT intervention with parent-only and parent-child sessions, 6 months | CGI-I agoraphobia score | 24 | 9 | 2.22 (SD: 0.83) | 11 | 2.55 (SD: 1.45) | NR | 0.58
Parent-child CBT | Ishikawa et al, 2019^103^ | 10.9 | Japanese Anxiety Children/Adolescents Cognitive Behavior; Therapy program, 8 weeks, with up to 3 subsequent booster sessions until 6 months after completion of therapy | SCAS-C | 8 or 16 (post-treatment) | 25 | 28.28 (SE: 3.55) | 24 | 35.95 (SE: 3.97) | NR | P=NS
Parent-child CBT | Ishikawa et al, 2019^103^ | 10.9 | Japanese Anxiety Children/Adolescents Cognitive Behavior; Therapy program, 8 weeks, with up to 3 subsequent booster sessions until 6 months after completion of therapy | ADIS-DSM-IV CSR on primary diagnosis | 8 or 16 (post-treatment | 25 | 3.08 (SE: 0.50) | 24 | 6.0 (SE: 0.51) | NR | <0.001 favoring CBT
Parent-child CBT | Ishikawa et al, 2019^103^ | 10.9 | Japanese Anxiety Children/Adolescents Cognitive Behavior; Therapy program, 8 weeks, with up to 3 subsequent booster sessions until 6 months after completion of therapy | SCAS-P | 8 or 16 (post-treatment | 25 | 25.42 (SE: 2.57) | 24 | 27.57 (SE: 2.62) | NR | <0.01 favoring CBT
Parent-guided CBT supported by telephone | Lyneham et al, 2006^112^ | 9.4 | Parent-guided CBT supported by telephone using self-help book (Helping Your Anxious Child: A Step by Step Guide for Parents) and a workbook companion, 12 weks | ADIS CSR (sum of all anxiety disorders) | 12 | IG1: 28; IG2: 21; IG3: 29 | NR | 22 | NR | IG1 vs. CG: Effect size cohen’s d=2.19; IG2 vs. CG: Effect size cohen’s d=1.57; IG3 vs. CG: Effect size cohen’s d=0.80; Across all groups: Eta squared=0.49 | IG1 vs. CG: <0.01; IG2 vs. CG: <0.01; IG3 vs. CG: <0.01; Across all groups: <0.01
Parent-guided CBT supported by telephone | Lyneham et al, 2006^112^ | 9.4 | Parent-guided CBT supported by telephone using self-help book (Helping Your Anxious Child: A Step by Step Guide for Parents) and a workbook companion, 12 weks | SCAS-M | 12 | IG1: 28; IG2: 21; IG3: 29 | IG1: 39.50 (SD: 14.94) pretreatment; 20.36 (SD: 16.04) 12 weeks; IG2: 36.00 (SD: 14.57) pretreatment;; 21.29 (SD: 14.28) 12 weeks; IG3: 34.97 (SD: 15.50) pretreatment; 22.97 (SD: 15.20) 12 weeks | 22 | 39.23 (SD: 13.89) pretreatment; 37.77 (SD: 15.26) 12 weeks | NR | NR
Parent-guided CBT supported by telephone | Lyneham et al, 2006^112^ | 9.4 | Parent-guided CBT supported by telephone using self-help book (Helping Your Anxious Child: A Step by Step Guide for Parents) and a workbook companion, 12 weks | SCAS-F | 12 | IG1: 28; IG2: 21; IG3: 29 | IG1: 32.46 (SD: 14.48) pretreatment; 22.50 (SD: 13.48) 12 weeks; IG2: 26.47 (SD: 9.91) pretreatment; 18.76 (SD: 10.37) 12 weeks; IG3: 29.80 (SD: 16.90) pretreatment; 19.60 (SD: 13.45) 12 weeks | 22 | 28.33 (SD: 17.68) pre-treatment; 29.50 (SD: 18.39) 12 weeks | NR | NR
Parent-guided CBT supported by telephone | Lyneham et al, 2006^112^ | 9.4 | Parent-guided CBT supported by telephone using self-help book (Helping Your Anxious Child: A Step by Step Guide for Parents) and a workbook companion, 12 weks | SCAS-C | 12 | IG1: 28; IG2: 21; IG3: 29 | IG1: 43.54 (SD: 16.65) pretreatment; 23.79 (SD: 14.84) 12 weeks; IG2: 35.90 (SD: 12.13) pretreatment; 24.86 (SD: 12.94) 12 weeks; IG3: 35.17 (SD: 20.66) pretreatment; 25.79 (SD: 19.51) 12 weeks | 22 | 37.77 (SD: 20.36) pretreatment; 36.41 (SD: 21.87) 12 weeks | NR | NR
Parent-guided CBT supported by telephone | Lyneham et al, 2006^112^ | 9.4 | Parent-guided CBT supported by telephone using self-help book (Helping Your Anxious Child: A Step by Step Guide for Parents) and a workbook companion, 12 weks | RCMAS-C | 12 | IG1: 28; IG2: 21; IG3: 29 | IG1: 17.25 (SD: 5.72) pretreatment; 10.89 (SD: 6.55) 12 weeks; IG2: 14.14 (SD: 6.35) pretreatment; 8.67 (SD: 6.21) 12 weeks; IG3: 14.17 (SD: 7.48) pretreatment; 10.28 (SD: 7.66) 12 weeks | 22 | 15.59 (SD: 7.57) pretreatment; 15.73 (SD: 7.30) 12 weeks | NR | NR
Parent-delivered CBT | Rudy et al, 2017^129^ | 5.36 | Exposure therapy first led by a therapist and then led by a parent, 5 weeks | ADIS CSR | 5 | 12 | 2.72 (SD: 1.56) | 10 | 4.56 (SD: 1.81) | Effect size d=2.39 | 0.009
Parent-delivered CBT | Rudy et al, 2017^129^ | 5.36 | Exposure therapy first led by a therapist and then led by a parent, 5 weeks | CGI-S | 5 | 12 | 2.00 (SD: 0.89) | 10 | 3.33 (SD: 0.71) | Effect size d=2.75 | <0.001
Parent-delivered CBT | Rudy et al, 2017^129^ | 5.36 | Exposure therapy first led by a therapist and then led by a parent, 5 weeks | PARS | 5 | 12 | 9.72 (SD: 4.76) | 10 | 15.78 (SD: 3.35) | Effect size d=3.18 | 0.046
Parent-delivered CBT | Thirlwall et al, 2013^145^ | NR, participants ages 7 to 12 years | Parent-delivered CBT with a self-help book, 8 weeks | SCAS-P | 12 | IG1: 38; IG2: 42 | IG1: 24.16 (SD: 12.93); IG2: 20.45 (SD: 11.52) | 46 | 24.15 (SD: 11.36) | NR | IG1 vs. CG: P=NS; IG2 vs. CG: P=NS
Parent-delivered CBT | Thirlwall et al, 2013^145^ | NR, participants ages 7 to 12 years | Parent-delivered CBT with a self-help book, 8 weeks | SCAS-C | 12 | IG1: 40; IG2: 47 | IG1: 30.00 (SD: 12.6); IG2: 28.47 (SD: 20.0) | 57 | 29.40 (SD: 16.28) | NR | IG1 vs. CG: P=NS; IG2 vs. CG: P=NS
Family-based CBT | Shortt et al, 2001^134^ | 7.9 | Family Based Cognitive Behavioral therapy sessions termed “FRIENDS,” adapted from Coping Koala Workbook, 10 weeks | RCMAS | 10 | 53 | 8.6 (SD: 0.97) | 12 | 9.8 (SD: 2.0) | Eta squared=0.10 | <0.05
Family-based CBT | Shortt et al, 2001^134^ | 7.9 | Family Based Cognitive Behavioral therapy sessions termed “FRIENDS,” adapted from Coping Koala Workbook, 10 weeks | DISCAP CSR | 10 | 48 | 1.06 (SD: 0.24) | 16 | 4.13 (SD: 0.41) | Eta squared=0.46 | <0.001

Abbreviations: ADIS-C/P=Anxiety Disorders Interview Schedule for DSM-IV for Children-Children/Parents; ADIS CSR=Anxiety Disorders Interview Schedule clinician severity ratings; ADIS-DSM=Anxiety and Related Disorders Interview Schedule--Diagnostic and Statistical Manual; CBT=cognitive behavioral therapy; CDI=Children’s Depression Inventory; CG=control group; CGI-I=Clinical Global Impressions-Improvement; CGI-S=Clinical Global Impressions-Severity; CI=confidence interval; CSR=Clinician Severity Rating; DISCAP=Diagnostic Interview Schedule for Children, Adolescents, and Parents; DSM IV=Diagnostic and Statistical Manual of Mental Disorders, 4th Edition; FSSCR=Fear Survey Schedule for Children-Revised; GAD=general anxiety disorder; IG=intervention group; ITT=intention to treat; LSAS-CA=Liebowitz Social Anxiety Scale for Children and Adolescents; MASC-child=Multidimensional Anxiety Scale for Children; MASC-parent=Multidimensional Anxiety Scale for Parents; mITT=modified intent to treat; N=number; NR=not reported; NS=not significant; PARS=Pediatric Anxiety Rating Scale; PAS=Preschool Anxiety Scale; PSWQ-C=Penn State Worry Questionnaire for Children; RCMAS=Revised Children’s Manifest Anxiety Scale; RCMAS-C=Revised Children’s Manifest Anxiety Scale; SASC-R=Social Anxiety Scale for Children-Revised; SCARED-C=Screen for Anxiety Related Emotional Disorders for Children; SCARED-P=Screen for Anxiety Related Emotional Disorders-Parents; SCAS-C=Spence Children’s Anxiety Scale-Child-rated; SCAS-P=Spence Children’s Anxiety Scale-Parent-rated; SCAS-R Child=Spence Children’s Anxiety Scale Revised-Child-rated; SCAS-R=Spence Children’s Anxiety Scale Revised-Parent-rated; SD=standard deviation; SE=standard error; SepAD=separation anxeity disorder; SMQ-P=Selective Mutism Questionnaire-Parent; SocAD=social anxiety disorder; SPAI-C=Social Phobia and Anxiety Inventory for Children; SPAI-P=Social Phobia and Anxiety Inventory for Children for Parents; vs.=versus.

Appendix F Table 4 Anxiety Pharmacotherapy Interventions vs. Placebo: Anxiety Symptoms

Treatment (Condition) | Author, Year | Mean Age (Years) | Dose | Outcome Measure | Time Point (Weeks) | Treatment N | Treatment Score (SD/SE) | Placebo N | Placebo Score (SD/SE) | Between-Group Difference | Between-Group P Value
Duloxetine (GAD) | Strawn et al, 2015^142^ | 12.4 | Flexibly dosed duloxetine (30–120 mg/d) | Change in PARS (severity for GAD) | 10 | 135 | −9.7 (SE: 0.5) | 137^*^ | −7.1 (SE: 0.5) | NR | ≤0.001^†^
Duloxetine (GAD) | Strawn et al, 2015^142^ | 12.4 | Flexibly dosed duloxetine (30–120 mg/d) | Change in PARS severity total score | 10 | 135 | −9.2 (SE: 0.5) | 137^*^ | −6.4 (SE: 0.5) | NR | ≤0.001^†^
Duloxetine (GAD) | Strawn et al, 2015^142^ | 12.4 | Flexibly dosed duloxetine (30–120 mg/d) | Change in CGI-S | 10 | 135 | −1.9 (SE: 0.1) | 137^*^ | −1.4 (0.1) | NR | ≤0.001^†^
Escitalopram (GAD) | Strawn et al, 2020^143^ | 14.8 | Forced titration to 15 mg/d, then flexible titration to 20 mg/d | Change in PARS | 8 | 26 | −8.65 (SD: 1.31) | 25 | −3.52 (SD: 1.06) | NR | 0.005^†^
Escitalopram (GAD) | Strawn et al, 2020^143^ | 14.8 | Forced titration to 15 mg/d, then flexible titration to 20 mg/d | CGI-S | 8 | 26 | 2.8 (SD: 0.3) | 25 | 3.6 (SD: 0.2) | NR | <0.001^†^
Fluoxetine (any anxiety disorder) | Birmaher et al, 2003^73^ | 11.8 | 10 mg/d, after first week, up to 20 mg/d | SCARED-C | 12 | 37 | 11.7 (SD: 12.4) | 37 | 12.10 (SD: 7.3) | NR | 0.03^†^
Fluoxetine (any anxiety disorder) | Birmaher et al, 2003^73^ | 11.8 | 10 mg/d, after first week, up to 20 mg/d | SCARED-P | 12 | 37 | 16.3 (SD: 12.7) | 37 | 22 (SD: 12.3) | NR | 0.04^†^
Fluoxetine (any anxiety disorder) | Birmaher et al, 2003^73^ | 11.8 | 10 mg/d, after first week, up to 20 mg/d | PARS | 12 | 37 | 7.1 (SD: 5.9) | 37 | 9.3 (SD: 4.8) | NR | 0.007^†^ (0.08 for post-test differences)
Fluvoxamine (GAD, SepAD, or SocAD) | Pine et al, 2001^124^; Walkup et al, 2001^213^; Ginsburg et al, 2006^214^; Reinblatt et al, 2009^215^ | 10.4 | 50 mg/d, then increase 50 mg/w to max. 300 mg/d in adolescents (13-17 years) and 250 mg/d in children ≤12 years of age | PARS | 8 | 63 | 9.0 (SD: 7.0) | 65 | 15.9 (SD: 5.3) | NR | <0.001^†^
Sertraline (GAD) | Rynn et al, 2001^130^ | 11.7 | 25 mg/d for the first week and 50 mg/d for weeks 2 to 9 | HAM-A | 9 | 11 | 7.8 (SD: 5.7) | 11 | 21.0 (SD: 7.8) | NR | <0.001^†^
Sertraline (GAD) | Rynn et al, 2001^130^ | 11.7 | 25 mg/d for the first week and 50 mg/d for weeks 2 to 9 | CGI-S | 9 | 11 | 2.4 (SD: 0.8) | 11 | 3.9 (SD: 0.3) | NR | <0.001^†^
Sertraline (GAD) | Rynn et al, 2001^130^ | 11.7 | 25 mg/d for the first week and 50 mg/d for weeks 2 to 9 | CGI-I | 9 | 11 | 2.1 (SD: 1.1) | 11 | 3.5 (SD: 0.7) | NR | 0.001
Sertraline (GAD) | Rynn et al, 2001^130^ | 11.7 | 25 mg/d for the first week and 50 mg/d for weeks 2 to 9 | ADIS CSR-C | 9 | 11 | 2.7 (SD: 2.0) | 11 | 4.6 (SD: 2.0) | NR | 0.11^‡^
Sertraline (GAD) | Rynn et al, 2001^130^ | 11.7 | 25 mg/d for the first week and 50 mg/d for weeks 2 to 9 | ADIS CSR-P | 9 | 11 | 2.6 (SD: 1.7) | 11 | 4.9 (SD: 2.0) | NR | <0.007^‡^
Sertraline (GAD) | Rynn et al, 2001^130^ | 11.7 | 25 mg/d for the first week and 50 mg/d for weeks 2 to 9 | RCMAS | 9 | 11 | 8.9 (SD: 7.0) | 11 | 14.6 (SD: 8.2) | NR | <0.02^‡^
Sertraline (GAD) | Rynn et al, 2001^130^ | 11.7 | 25 mg/d for the first week and 50 mg/d for weeks 2 to 9 | MASC | 9 | 11 | 35.7 (SD: 17.2) | 11 | 56.4 (SD: 16.3) | NR | <0.03^‡^
Sertraline (GAD, SepAD, or SocAD) | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Caporino et al, 2017^216^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | 25mg/d, up to 200 mg/d by 8th week | PARS | 12 | 133 | 9.8 (SD: 6.2) | 76 | 12.6 (SD: 6.3) | Hedge’s g (95% CI): 0.45 (0.17 to 0.74) | NS
Sertraline (GAD, SepAD, or SocAD) | | 10.7 | 25mg/d, up to 200 mg/d by 8th week | CGI-S | 12 | 133 | 3.0 (SD: 1.3) | 76 | 3.8 (1.4) | NR | CIs of individual treatments do not overlap
Sertraline (GAD, SepAD, or SocAD) | | 10.7 | 25mg/d, up to 200 mg/d by 8th week | MASC-C | 12 | 133 | 38.2 (SD: 10.7) | 76 | 42.9 (11.8) | b=−4.68, t=−2.80 | 0.03
Sertraline (GAD, SepAD, or SocAD) | | 10.7 | 25mg/d, up to 200 mg/d by 8th week | MASC-P | 12 | 133 | 37.9 (SD: 17.3) | 76 | 49.1 (16.9) | b=−11.1, t=−4.4 | <0.001
Sertraline (GAD, SepAD, or SocAD) | | 10.7 | 25mg/d, up to 200 mg/d by 8th week | SCARED-C | 12 | 133 | 9.3 (SD: 11.9) | 76 | 13.8 (12.1) | NR | p=NS, p=NR
Sertraline (GAD, SepAD, or SocAD) | | 10.7 | 25mg/d, up to 200 mg/d by 8th week | SCARED-P | 12 | 133 | 11.0 (SD: 11.7) | 76 | 19.5 (11.8) | NR | <0.001

* N randomized=137, N analyzed=133. Conversion of standard error to standard deviation based on N analyzed.

† Difference in change from baseline to followup.

‡ Difference at followup.

Abbreviations: ADIS=Anxiety Disorders Interview Schedule; ADIS-CSR=Anxiety Disorders Interview Schedule Clinician Severity Rating CGI=Clinical Global Impressions; CI=confidence interval; CSR-C=clinical severity score-child-rated; CSR-P= clinical severity score-parent-rated; GAD=generalized anxiety disorder; HAM-A=Hamilton Anxiety Rating Scale; MASC=Multidimensional Anxiety Scale for Children; N=number; NR=not reported; NS=not statistically significant; PARS=Pediatric Anxiety Rating Scale; RCMAS=Revised Children’s Manifest Anxiety Scale; SCARED-C=Screen for Anxiety Related Emotional Disorders Child version; SCARED-P=Screen for Anxiety Related Emotional Disorders – Parent version; SD=standard deviation; SE=standard error; SepAD=separation anxiety disorder; SocAD=social anxiety disorder; vs.=versus.

Appendix F Table 5 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Response

Treatment (Condition) | Author, Year, Trial Number | Mean Age | Duration | Outcome Measure | Time Point (Weeks) | Treatment N | N (%) | Placebo N | N (%) | Effect measure (95% CI), p value
Group child+parent in-person CBT | Cornacchio et al, 2019^79^ | 6.6 | 5 days | CGI-I≤2 | 4 | 14 | 7 (50) | 15 | 0 (0) | (−0.58), P≤0.01
Individual child-focused in-person CBT | Ginsburg et al, 2020^92^ | 10.9 | 12 weeks | CGI-I≤2 | 12 | 148 | NR (42.1) | 68 | NR (36.7) | P=0.34
Individual child-focused in-person CBT | Salzer et al, 2018^42^; ISRCTN 22752528 | 17.4 | 31 weeks | LSAS-CA ≥31% reduction in total score | Post-treatment | 34 | NR (66) | 39 | NR (20) | (2.17 to 28.86), P=0.006
Individual child-focused in-person CBT | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Caporino et al, 2017^216^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | 12 weeks | CGI-I ≤2 | 12 | 139 | 83 (59.7) | 76 | 18 (23.7) | (2.5 to 9.0), P<0.001
Individual child-focused internet CBT | Stjerneklar et al, 2019^141^; NCT02535403 | 15 | 14 weeks | Clinically reliable change in SCAS-C | 14 | 32 | 22 (69) | 31 | 8 (26) | P=0.001
Individual child-focused internet CBT | Stjerneklar et al, 2019^141^; NCT02535403 | 15 | 14 weeks | Clinically reliable change in SCAS-M | 14 | 35 | 24 (69) | 32 | 7 (22) | P<0.001
Individual child-focused internet CBT | Stjerneklar et al, 2019^141^; NCT02535403 | 15 | 14 weeks | Clinically reliable change in SCAS-F | 14 | 25 | 9 (35) | 27 | 5 (19) | P=0.156
Individual child+parent in-person CBT | Hirshfeld-Becker et al, 2010^98^ | 5.4 | 6 months | CGI-I ≤2 | 6 months | 34 | 20 (59) | 30 | 9 (30) | P=0.016
Individual parent-led in-person CBT | Rudy et al, 2017^129^; NCT02051192 | 5.36 | 5 weeks | CGI-I ≤2 | 5 | 12 | 10 (83.3) | 10 | 0 (0.0) | P<0.001
Internet delivered CBT with and without parent sessions | Waite et al, 2019^152^; ISRCTN79652741 | 14.7 | 10 weeks | CGI ≤2 | 17 | 30 | 12 (40.0) | 30 | 9 (30.0) | (0.53-4.53)

Abbreviations: CBT=cognitive behavioral therapy; CGI-I=Clinical Global Impressions-Improvement; CI=confidence interval; LSAS-CA=Liebowitz Social Anxiety Scale for Children and Adolescents; NR=not reported; SCAS-C=Spence Children’s Anxiety Scale-Child-rated; SCAS-F=Spence Children’s Anxiety Scale -Father; SCAS-M=Spence Children’s Anxiety Scale -Mother; vs.=versus.

Appendix F Table 6 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Remission

Treatment (Condition) | Author, Year | Mean Age | Duration | Outcome Measure | Time Point (Weeks) | Treatment N | N (%) | Placebo N | N (%) | Effect Measure (95% CI), p value
Individual child-focused in-person CBT | Salzer et al, 2018^42^; ISRCTN 22752528 | 17.4 | 31 weeks | LSAS-CA ≤30 | Post-treatment | 32 | NR (47) | 36 | NR (6) | (1.85 to 114.95), P=0.0009
Individual child-focused in-person CBT | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Caporino et al, 2017^216^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | 12 weeks | CGI-S ≤2 | 12 | 139 | 50 (35.9) | 76 | 21 (27.1) | (0 to 3.53), P=0.49
Individual child-focused in-person CBT | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Caporino et al, 2017^216^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | 12 weeks | CGI-I=1 | 12 | 139 | 28 (20.4) | 76 | 11 (15.0) | (0 to 4.78), P=0.61
Individual child+parent in-person CBT | Ishikawa et al, 2019^103^ | 10.9 | 8 weeks | SCAS-C; clinically significant change | 2 or 4 months | 25 | 14 (56.0) | 24 | 9 (37.5) | P=0.20
Individual child+parent in-person CBT | Ishikawa et al, 2019^103^ | 10.9 | 8 weeks | SCAS-P; clinically significant change | 2 or 4 months | 25 | 8 (32.0) | 24 | 5 (20.83) | P=0.38
Individual child+parent in-person CBT | Ishikawa et al, 2019^103^ | 10.9 | 8 weeks | DSRS; clinically significant change | 2 or 4 months | 25 | 9 (36.0) | 24 | 5 (20.83) | P=0.24
Individual child+parent in-person CBT | Ishikawa et al, 2019^103^ | 10.9 | 8 weeks | CDI; clinically significant change | 2 or 4 months | 25 | 10 (40.0) | 24 | 4 (16.67) | P=0.07
Individual child-focused internet CBT | Stjerneklar et al, 2019^141^; NCT02535403 | 15 | 14 weeks | SCAS-C; Clinically significant change | 14 | 32 | 14 (44) | 31 | 2 (6) | P=0.001
Individual child-focused internet CBT | Stjerneklar et al, 2019^141^; NCT02535403 | 15 | 14 weeks | SCAS-M; Clinically significant change | 14 | 35 | 9 (26) | 32 | 2 (6) | P=0.032
Individual child-focused internet CBT | Stjerneklar et al, 2019^141^; NCT02535403 | 15 | 14 weeks | SCAS-F; Clinically significant change | 14 | 25 | 1 (4) | 27 | 2 (7) | P=1.00
IG1: Individual child+parent telephone CBT; IG2: Individual child+parent email CBT; IG3: Individual child+parent client-initiated CBT | Lyneham et al, 2006^112^; NR | 9.4 | 12 weeks | SCAS-C normal range | 12 | IG1: 28; IG2: 21; IG3: 29 | IG1: NR (62); IG2: NR (57); IG3: NR (50) | 22 | NR (23) | Any IG vs. CG: P<0.05
Individual parent-led in-person CBT | Rudy et al, 2017^129^; NCT02051192 | 5.36 | 5 weeks | ADIS-CSR <4 | 5 | 12 | 8 (66.7) | 10 | 1 (10.0) | P=0.011
Group child+parent in-person CBT | Arendt et al, 2016^65^ | 11.8 | 10 weeks | Clinically significant change in SCAS-C | 10 | 56 | 24 (42.9) | 53 | 6 (11.3) | P≤0.001
Group child+parent in-person CBT | Arendt et al, 2016^65^ | 11.8 | 10 weeks | Clinically significant change in SCAS-M | 10 | 56 | 29 (51.8) | 53 | 6 (11.3) | P≤0.001
Group child+parent in-person CBT | Arendt et al, 2016^65^ | 11.8 | 10 weeks | Clinically significant change in SCAS-F | 10 | 56 | 23 (41.8) | 53 | 5 (9.8) | P≤0.001

Abbreviations: ADIS=Anxiety Disorders Interview Schedule for DSM-IV for Children; ADIS-CSR=Anxiety Disorders Interview Schedule for DSM-IV for Children Clinician Severity Rating; CBT=cognitive behavioral therapy; CDI=Children’s Depression Inventory; CG=control group; CGI-I=Clinical Global Impressions-Improvement; CGI-S=Clinical Global Impressions-Severity; CI=confidence interval; DSRS=Depression Self-Rating Scale; IG=intervention group; LSAS-CA=Liebowitz Social Anxiety Scale for Children and Adolescents; N=number; NR=not reported; SCAS-C=Spence Children’s Anxiety Scale-Child-rated; SCAS-F=Spence Children’s Anxiety Scale-Child-rated-Female; SCAS-M=Spence Children’s Anxiety Scale-Child-rated-Male; SCAS-P=Spence Children’s Anxiety Scale-Parent-rated; vs.=versus.

Appendix F Table 7 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Loss of Diagnosis

Treatment (Condition) | Author, Year | Mean Age | Duration | Outcome Measure | Time Point (Weeks) | Treatment N | N (%) | Placebo N | N (%) | Effect Measure (95% CI), p value
Group child-focused in-person CBT | Holmes et al, 2014^99^; ACTRN12612000061831 | 9.6 | 10 weeks | ADIS-C/P; absence of GAD diagnosis | 10 | 17 | NR (52.9) | 19 | NR (0) | P<0.001
Group child-focused in-person CBT | Holmes et al, 2014^99^; ACTRN12612000061831 | 9.6 | 10 weeks | ADIS-C/P; absence of any anxiety diagnosis | 10 | 17 | NR (17.6) | 19 | NR (0) | P=0.056
Group child+parent in-person CBT | Arendt et al, 2016^65^ | 11.8 | 10 weeks | ADIS-C/P; free of primary diagnosis | 10 | 56 | 37 (66.1) | 53 | 4 (7.5) | P<0.001
Group child+parent in-person CBT | Arendt et al, 2016^65^ | 11.8 | 10 weeks | ADIS-C/P; free of all anxiety diagnoses | 10 | 56 | 27 (48.2) | 53 | 3 (5.7) | P<0.001
Group child+parent in-person CBT | Cornacchio et al, 2019^79^ | 6.6 | 5 days | ADIS/C-P; Loss of selective mutism diagnosis | 4 | 14 | 1 (7.1) | 15 | 0 (0) | (0.19), P=1.00
Group child+parent in-person CBT | Lau et al, 2010^110^; NR | 8 years 7 months | 11 weeks | K-SADS; presence of anxiety diagnosis or symptoms | 13 | 24 | 16 (67) | 21 | 21 (100) | P<0.01
Group child+parent in-person CBT | Lau et al, 2010^110^; NR | 8 years 7 months | 11 weeks | K-SADS; absence of anxiety diagnosis or subclinical symptoms | 13 | 24 | 8 (33) | 21 | 0 (0) | NR
Group child+parent in-person CBT | Shortt et al, 2001^134^ | 7.9 | 10 weeks | DISCAP; anxiety free diagnosis | 10 | 48 | 33 (69) | 16 | 1 (6) | P<0.001
Individual child-focused in-person CBT | Barrett et al, 1996^70^ | 9.4 | 12 weeks | ADIS; no longer meeting criteria for current anxiety disorder | 12 | IG1/2: 53 | 37 (69.8) | 23 | 6 (26.0) | P<0.05
Individual child-focused in-person CBT | Ginsburg et al, 2020^92^ | 10.9 | 12 weeks | ADIS; no anxiety disorder | 12 | 148 | NR (34.9) | 68 | NR (35.0) | P=0.67
Individual child-focused in-person CBT (continued) | Ginsburg et al, 2020^92^ | 10.9 | 12 weeks | ADIS; loss of primary anxiety disorder | 12 | 148 | NR (40.5) | 68 | NR (43.4) | P=0.61
Individual child-focused in-person CBT | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Caporino et al, 2017^216^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | 12 weeks | ADIS-C/P; loss of anxiety diagnosis | 12 | 139 | 64 (46.2) | 76 | 18 (23.7) | (1.03 to 4.79), P=0.05
Individual child-focused internet CBT | Stjerneklar et al, 2019^141^; NCT02535403 | 15 | 14 weeks | ADIS; free of primary anxiety diagonsis | 14 | 35 | 14 (40) | 32 | 5 (16) | P=0.027
Individual child-focused internet CBT | Stjerneklar et al, 2019^141^; NCT02535403 | 15 | 14 weeks | ADIS; free of any anxiety diagnosis | 14 | 35 | 10 (29) | 32 | 1 (3) | P=0.005
Individual child + parent in-person + internet CBT | Perrin et al, 2019^122^; ISRCTN50951795 | 13.4 | 10 weeks | ADIS; presence of GAD | 10 | 20 | 4 (20) | 20 | 20 (100) | P<0.001
Individual child + parent in-person + internet CBT | Perrin et al, 2019^122^; ISRCTN50951795 | 13.4 | 10 weeks | ADIS; presence of comorbid disorder | 10 | 20 | 1 (5) | 20 | 11 (55) | P<0.001
Individual child + parent in-person + internet CBT | Perrin et al, 2019^122^; ISRCTN50951795 | 13.4 | 10 weeks | ADIS; recovery from all disorders | 10 | 20 | 16 (80) | 20 | 0 (0) | P<0.000
Individual child + parent in-person CBT | Hirshfeld-Becker et al, 2010^98^ | 5.4 | 6 months | SCID; absence of anxiety diagnosis | 6 months | 34 | 17 (50) | 30 | 5 (17) | P<0.01
Individual child + parent in-person CBT | Ishikawa et al, 2019^103^ | 10.9 | 8 weeks | ADIS; free of principal diagnosis | 2 or 4 months | 26 | 13 (50.0) | 25 | 3 (12.0) | P<0.01
Individual child + parent in-person CBT | Ishikawa et al, 2019^103^ | 10.9 | 8 weeks | ADIS; free of any diagnosis | 2 or 4 months | 26 | 4 (15.38) | 25 | 1 (4.0) | NS
Individual child+parent internet CBT | Waite et al, 2019^152^; ISRCTN79652741 | 14.7 | 10 weeks | ADIS-C/P; remission of primary anxiety diagnosis | 17 weeks | 30 | 12 (40.0) | 30 | 7 (23.3) | (0.72 to 6.70)
Individual child+parent internet CBT | Waite et al, 2019^152^; ISRCTN79652741 | 14.7 | 10 weeks | ADIS-C/P; remission of all anxiety diagnoses | 17 weeks | 30 | 8 (26.7) | 30 | 4 (13.3) | (0.63 to 8.92)
Parent-guided CBT supported by telephone | Lyneham et al, 2006^112^; NR | 9.4 | 12 weeks | ADIS; loss of prinicpal anxiety disorder | 12 | IG1: 28; IG2: 21; IG3: 29 | NR | 22 | NR | Any IG vs. CG, P<0.01
Parent-guided CBT supported by telephone | Lyneham et al, 2006^112^; NR | 9.4 | 12 weeks | ADIS; loss of any anxiety disorder | 12 | IG1: 28; IG2: 21; IG3: 29 | NR | 22 | NR | Any IG vs. CG, P<0.01
Individual and group CBT, parent training | Ost et al, 2015^120^ | 11.6 | 12 weeks | ADIS; no longer fufilling criteria for social phobia | 12 months | IG1: 16; IG2: 16 | IG1: 9 (56); IG2: 10 (62) | 23 | 2 (9) | IG1 vs. CG: P≤0.001; IG2 vs. CG: P≤0.001
Individual CBT | Villabo et al, 2018^150^; NR | 10.5 | 12 weeks | ADIS; loss of primary anxiety diagnosis | 12 | IG1: 44; IG2: 52 | IG1: NR (52); IG2: NR (65) | 51 | NR (14) | IG1 vs CG: (21 to 56), P<0.001; IG2 vs CG: (35 to 68), P<0.001
Individual CBT | Villabo et al, 2018^150^; NR | 10.5 | 12 weeks | ADIS; loss of all anxiety disorders | 12 | IG1: 44; IG2: 52 | IG1: NR (38); IG2: NR (56) | 51 | NR (6) | IG1 vs CG: (16 to 47), P<0.001; IG2 vs CG: (34 to 65), P<0.001
Parent-delivered CBT full CBT | Thirlwall et al, 2013^145^; ISRCTN92977593 | NR; participants ages 7 to 12 years | 8 weeks | ADIS; loss of primary diagnosis | 12 | 46 | IG1: 18 (39); IG2: 25 (50) | 63 | 16 (25) | IG1 vs. CG: (0.89 to 2.74), P=0.119; IG2 vs. CG: (1.14 to 2.99), P=0.013
Parent-delivered CBT full CBT | Thirlwall et al, 2013^145^; ISRCTN92977593 | NR; participants ages 7 to 12 years | 8 weeks | ADIS; loss of any diagnosis | 12 | 46 | IG1: 7 (15); IG2: 17 (34) | 63 | 7 (11) | IG1 vs CG: (0.56 to 3.88), P=0.433; IG2 vs CG: (1.40 to 7.01), P=0.006
Group parent-only in-person CBT | Cobham et al, 2017^77^; ACTRN12615000514505 | 9.3 | 6 weeks | ADIS; absence of primary diagnosis | 6 | 31 | 20 (64.5) | 29 | 5 (16.2) | (0.259 to 0.709), P<0.001
Group parent-only in-person CBT | Cobham et al, 2017^77^; ACTRN12615000514505 | 9.3 | 6 weeks | ADIS; absence of any diagnosis | 6 | 31 | 12 (38.7) | 29 | 1 (3.4) | (0.47 to 0.82), P<0.001
Individual parent-focused internet CBT | Donovan et al, 2014^83^; ACTRN12612000139875 | 4.1 | 8 weeks | ADIS; absence of primary diagnosis | 8 | 23 | 9 (39) | 27 | 7 (26) | P=0.318
Individual parent-focused internet CBT | Donovan et al, 2014^83^; ACTRN12612000139875 | 4.1 | 8 weeks | ADIS; absencse of any diagnosis | 8 | 23 | 8 (35) | 27 | 7 (26) | P=0.496

Abbreviations: ADIS=Anxiety Disorders Interview Schedule for DSM-IV for Children; ADIS-C/P=Anxiety Disorders Interview Schedule for DSM-IV for Children-Children/Parents; CBT=cognitive behavioral therapy; CG=control group; CI=confidence interval; DISCAP=Diagnostic Interview Schedule for Children, Adolescents, and Parents; GAD=general anxiety disorder; IG=intervention group; K-SADS=Schedule for Affective Disorders and Schizophrenia for School-Age Children; lifetime version; N=number; NR=not reported; NS=not significant; SCID=structured clinical interview; vs.=versus.

Appendix F Table 8 Anxiety Pharmacotherapy vs. Placebo for Anxiety in Children: Response

Treatment (Condition) | Author, Year | Mean Age | Dose (md/day) | Outcome Measure | Time Point (Weeks) | Treatment N | N (%) | Placebo N | N (%) | Effect Measure (95% CI), p Value
Escitalopram (GAD) | Strawn et al, 2020^143^ | 14.8 | Forced titration to 15 mg/d, then flexible titration to 20 mg/d, 8 weeks | CGI-I score ≤2 | 8 | 26 | 16 (62) | 25 | 6 (24) | NR; P=0.0039
Fluoxetine (GAD, SepAD, or social phobia) | Birmaher et al, 2003^73^ | 11.8 | Fluoxetine 10 mg/day, after first week increasing to 20 mg/day if tolerated | CGI-I score ≤2 | 12 | 36 | 22 (61) | 37 | 13 (35) | Effect size=0.26; P=0.03
Fluoxetine (selective mutism) | Black et al, 1994^74^ | 8.5 | Fluoxetine 0.2 mg/kg for 1 week, then 0.4 mg/kg for 1 week, then 0.6 mg/kg for 10 weeks | CGI-I score ≤2 | 12 | 6 | 3 (50) | 9 | 4 (44.4) | NR; P=NS
Sertraline (GAD) | Rynn, 2001^130^ | 11.7 | 25 mg for the first week and 50 mg for weeks 2 to 9, 9 weeks | CGI-I score ≤2 | 9 | 11 | 10 (91) | 11 | 1 (9) | NR; P<0.0001
Sertraline (GAD, SepAD, or SocAD) | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Caporino et al, 2017^216^; Sanchez, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^; NCT00052078 | 10.7 | 25 mg/day, up to 200 mg/day by 8th week, for 12 weeks | CGI-I score ≤2 | 12 | 133 | 73 (54.9) | 76 | 18 (23.7) | OR: 3.9 (3.0 to 5.9), P<0.001

Abbreviations: CGI-I=Clinical Global Impressions-Improvement; CI=confidence interval; GAD=general anxiety disorder; N=number; NR=not reported; NS=not significant; OR=odds ratio; SepAD=separation anxiety disorder; SocAD=social anxiety disorder; vs.=versus.

Appendix F Table 9 Anxiety Pharmacotherapy Interventions vs. Placebo: Remission

Treatment (Condition) | Author, Year | Mean Age | Dose (md/day) | Outcome Measure | Time Point (Weeks) | Treatment N | N (%) | Placebo N | N (%) | Effect Measure (95% CI), p Value
Duloxetine (GAD) | Strawn et al, 2015^142^ | 12.4 | Flexibly dosed duloxetine (30–120 mg/d) | CGI-S score ≤2 | 10 | 135 | (54) | 133 | (35) | NR; P≤0.02
Duloxetine (GAD) | Strawn et al, 2015^142^ | 12.4 | Flexibly dosed duloxetine (30–120 mg/d) | CGI-I score=1 | 10 | 135 | (50) | 133 | (34) | NR; P≤0.05
Sertraline (GAD) | Rynn et al, 2001^130^ | 11.7 | 25 mg for the first week and 50 mg for weeks 2 to 9, 9 weeks | CGI-I score=1 | 9 | 11 | 2 (18) | 11 | 0 (0) | NR; P=0.28
Sertraline (GAD, SepAD, or SocAD) | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^;; Caporino et al, 2017^216^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^; NCT00052078 | 10.7 | 25 mg/day, up to 200 mg/day by 8th week, for 12 weeks | CGI-S score ≤2 | 12 | 133 | 62 (46.3) | 76 | 21 (27.1) | OR: 2.55 (0 to 5.48), P=0.29
Sertraline (GAD, SepAD, or SocAD) | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^;; Caporino et al, 2017^216^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^; NCT00052078 | 10.7 | 25 mg/day, up to 200 mg/day by 8th week, for 12 weeks | CGI-I score=1 | 12 | 133 | 45 (33.9) | 76 | 11 (15.0) | OR: 3.56 (0 to 9.53), P=0.39
Sertraline (GAD, SepAD, or SocAD) | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^;; Caporino et al, 2017^216^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^; NCT00052078 | 10.7 | 25 mg/day, up to 200 mg/day by 8th week, for 12 weeks | Loss of anxiety diagnosis | 12 | 133 | 61 (45.9) | 76 | 18 (23.7) | OR: 2.84 (1.01 to 4.67), P=0.05

Abbreviations: CGI-I=Clinical Global Impressions-Improvement; CGI-S=Clinical Global Impressions-Severity; CI=confidence interval; GAD=general anxiety disorder; N=number; NR=not reported; OR=odds ratio; SepAD=separation anxiety disorder; SocAD=social anxiety disorder; vs.=versus.

Appendix F Table 10 Anxiety CBT Interventions vs. Treatment as Usual or Attention Control: Functioning or Quality of Life

Treatment (Condition) | Author, Year | Mean Age (Years) | Intervention and Duration | Outcome Measure | Time Point (Weeks) | Treatment N | Treatment Score (SD/SE) | Placebo N | Placebo Score (SD/SE) | Between-Group Difference | Between-Group P Value
Group CBT | Arendt et al, 2016^65^ | 11.8 | Manualized group CBT program (Cool Kids), 10 weeks | CALIS youth | 10 | 56 | 7.55 (SD: 6.46) | 53 | 10.94 (SD: 7.20) | Partial eta squared=0.06 | 0.008
Group CBT | Arendt et al, 2016^65^ | 11.8 | Manualized group CBT program (Cool Kids), 10 weeks | CALIS mother | 10 | 56 | 10.61 (SD: 7.28) | 53 | 17.94 (SD: 9.07) | Partial eta squared=0.14 | <0.001
Group CBT | Arendt et al, 2016^65^ | 11.8 | Manualized group CBT program (Cool Kids), 10 weeks | CALIS father | 10 | 56 | 10.96 (SD: 7.72) | 53 | 17.14 (SD: 9.16) | Partial eta squared=0.11; F=12 | <0.001
Group CBT | Cornacchio et al, 2019^79^ | 6.6 | Group CBT program that relies on the early child format of Parent Child Interaction Therapy, 5 days | CGAS | 4 | 14 | 53.6 (SD: 4.6) | 15 | 52.5 (SD: 4.9) | Effect size Cohen’s d=0.73 | <0.1
Group CBT | Holmes et al, 2014^99^ | 9.6 | Group CBT program termed “No Worries!” that utilizes the A-B-C model, 10 weeks | CGAS | 10 | 17 | 63.82 (SD: 11.03) | 19 | 51.05 (SD: 7.66) | Partial eta squared=0.15 | 0.02
Group CBT | Holmes et al, 2014^99^ | 9.6 | Group CBT program termed “No Worries!” that utilizes the A-B-C model, 10 weeks | Pediatric QOL Inventory-C | 10 | 17 | 76.09 (SD: 15.17) | 19 | 66.88 (SD: 12.03) | NR | NS
Group CBT | Holmes et al, 2014^99^ | 9.6 | Group CBT program termed “No Worries!” that utilizes the A-B-C model, 10 weeks | Pediatric QOL Inventory-P | 10 | 17 | 79.17 (SD: 14.16) | 19 | 75.34 (SD: 11.74) | NR | NS
Individual CBT | Ginsburg et al, 2020^92^ | 10.9 | Individual CBT consisting of 7 core modules, 12 weeks | CGAS | 12 | 148 | 55.98 | 68 | 54.22 | NR | 0.42
Individual CBT | Ginsburg et al, 2020^92^ | 10.9 | Individual CBT consisting of 7 core modules, 12 weeks | CGAS | 52 | 148 | 58.92 | 68 | 59.22 | NR | 0.63
Individual CBT | Perrin et al, 2019^122^ | 13.4 | Individual, GAD-specific CBT, 10 weeks | CGAS | 10 | 20 | 82.1 (SD: 8.9) | 20 | 59.4 (SD: 6.7) | Effect size partial eta squared=0.70 | <0.001
Individual CBT | Perrin et al, 2019^122^ | 13.4 | Individual, GAD-specific CBT, 10 weeks | PQ-LES-Q | 10 | 20 | 60.8 (SD: 10.7) | 20 | 48.7 (SD: 9.4) | Effect size partial eta squared=0.23 | <0.01
Individual CBT | Villabo et al, 2018^150^ | 10.5 | Individual CBT using the Coping Cat manual, 12 weeks | CGAS | 12 | IG1: 44; IG2: 52 | IG1: 62.52 (SE: 1.17); IG2: 62.81 (SE: 1.10) | 51 | 53.05 (SE: 1.09) | Effect size Hedge’s g (95% CI); IG1 vs CG: 1.01 (0.68 to 1.35); IG2 vs CG: 1.04 (0.72 to 1.37) | IG1 vs CG <0.001; IG2 vs CG <0.001
Individual CBT, Sertraline, Individual CBT + Sertraline | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | Individual CBT using Coping Cat program adapted for child’s age and length of the study, 12 weeks | CGAS | 12 | IG1: 139; IG2: 133; IG3: 140 | IG1: 63.8 (SD: 10.2); IG2: 65.0 (SD: 10.7); IG3: 68.6 (SD: 10.4) | 76 | 60.1 (SD: 10.9) | All active treatments noted to be superior to placebo | NR
Individual CBT, Sertraline, Individual CBT + Sertraline | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | Individual CBT using Coping Cat program adapted for child’s age and length of the study, 12 weeks | CAIS-C | 12 | IG1: 139; IG2: 133; IG3: 140 | IG1: 9.1 (SD: 10.7); IG2: 7.7 (SD: 11.3); IG3: 8.1 (SD: 11.0) | 76 | 11.2 (SD: 11.5) | No statistically significant differences between arms | NR
Individual CBT, Sertraline, Individual CBT + Sertraline | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | Individual CBT using Coping Cat program adapted for child’s age and length of the study, 12 weeks | CAIS-P | 12 | IG1: 139; IG2: 133; IG3: 140 | IG1: 13.5 (SD: 10.0); IG2: 9.1 (SD: 10.5); IG3: 7.4 (SD: 10.2) | 76 | 15.2 (SD: 10.7) | IG2 vs. CG: b=−6.1, t=−4.0; IG3 vs. CG: b=−7.7, t=−5.2 | IG1 vs. CG: adjusted P=0.27; IG2 vs. CG: adjusted P<0.001; IG3 vs. CG: adjusted P<0.001
Individual CBT, Sertraline, Individual CBT + Sertraline | Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^ | 10.7 | Individual CBT using Coping Cat program adapted for child’s age and length of the study, 12 weeks | Sleep-related problems | 12 | IG1: 139; IG2: 133; IG3: 140 | NR | 76 | NR | Active treatments resulted in significantly greater reductions in sleep problems than placebo related to separation, as reported by parents (F=6.52, p=0.01, η^2^=0.01) but not by children No significant treatment type x time interactions for parent- or child-rated dysregulated Sleep | Significantly greater reductions in sleep problems than placebo related to separation, P=0.01
Individual and group CBT, parent training | Ost et al, 2015^120^ | 11.6 | Individual weekly sessions and social skills group weekly sessions for the child and parent training about SocAD, 12 weeks | Change in QOLI-C from baseline | 12 | IG1: 16; IG2: 16 | IG1: 3.85 (SD: 1.84); IG2: 3.46 (SD: 1.63) | 23 | 2.89 (SD: 1.40) | F=4.1 | <0.05; IG1 vs. CG=NS; IG2 vs. CG=NS
Internet CBT | Donovan et al, 2014^83^ | 4.1 | Online individual parent-focused CBT, 8 weeks | CGAS | 8 | 23 | 66.9 (SD: 10.6) | 27 | 61.9 (SD: 10.0) | Partial eta squared=0.115 | 0.016
Internet CBT | Stjerneklar et al, 2019^141^ | 15 | Internet CBT based on Cool Kids and Chilled anxiety management program, 14 weeks | WHO-5 change from baseline | 14 | 35 | NR | 35 | NR | Effect size Cohen’s d=0.04 | 0.945
Internet CBT | Stjerneklar et al, 2019^141^ | 15 | Internet CBT based on Cool Kids and Chilled anxiety management program, 14 weeks | CALIS-C change from baseline | 14 | 35 | NR | 35 | NR | Effect size Cohen’s d=0.21 | 0.254
Internet CBT | Stjerneklar et al, 2019^141^ | 15 | Internet CBT based on Cool Kids and Chilled anxiety management program, 14 weeks | CALIS-M change from baseline | 14 | 35 | NR | 35 | NR | Effect size Cohen’s d=0.93 | <0.001
Internet CBT | Stjerneklar et al, 2019^141^ | 15 | Internet CBT based on Cool Kids and Chilled anxiety management program, 14 weeks | CALIS-F change from baseline | 14 | 35 | NR | 35 | NR | Effect size Cohen’s d=0.20 | 0.227
Internet CBT | Waite et al, 2019^152^ | 14.7 | Internet CBT with accompanying parent sessions for half the group and no parent sessions for the other half, 10 weeks | CGAS change from baseline | 17 | 30 | 59.48 (SD: 14.87) | 30 | 55.18 (SD: 12.48) | Effect size (95% CI) 0.04 (0.00 to 0.18) | NR
Internet CBT | Waite et al, 2019^152^ | 14.7 | Internet CBT with accompanying parent sessions for half the group and no parent sessions for the other half, 10 weeks | CAIS-C change from baseline | 17 | 30 | 18.04 (SD: 16.97) | 30 | 17.59 (SD: 13.09) | Effect size (95% CI) 0.01 (0.00 to 0.12) | NR
Internet CBT | Waite et al, 2019^152^ | 14.7 | Internet CBT with accompanying parent sessions for half the group and no parent sessions for the other half, 10 weeks | CAIS-P change from baseline | 17 | 30 | 23.60 (SD: 21.81) | 30 | 19.63 (SD: 16.34) | Effect size (95% CI) 0.04 (0.00 to 0.19) | NR
Parent-delivered CBT | Thirlwall et al, 2013^145^ | NR, participants ages 7 to 12 years | Parent-delivered CBT with a self-help book, 8 weeks | CAIS-P | 12 | IG1: 39; IG2: 41 | IG1: 13.97 (SD: 14.64); IG2: 6.39 (SD: 6.29) | 48 | 15.56 (SD: 12.31) | IG1 vs. CG: NR; IG2 vs. CG: difference in change from baseline, −5.56 (95% CI, −9.40 to −1.73) | IG1 vs. CG: P=NS; IG2 vs. CG=0.0045

Abbreviations: CAIS-C=Child Anxiety Impact Scale; CAIS-P=Child Anxiety Impact Scale-Parent; CALIS=Child Anxiety Life Interference Scale; CALIS-C=Child Anxiety Life Interference Scale-Child; CALIS-F=Child Anxiety Life Interference Scale-Father; CALIS-M=Child Anxiety Life Interference Scale-Mother; CBT=cognitive behavioral therapy; CG=control group; CGAS=Children’s Global Assessment Scale; CI=confidence interval; GAD=general anxiety disorder; IG=intervention group; N=number; NR=not reported; NS=not significant; PQ-LES-Q=Pediatric Quality of Life Enjoyment and Satisfaction Questionnaire ; QOL=quality of life; SD=standard deviation; SocAD=social anxiety disorder; vs.=versus; WHO-5=World Health Organization Five Item Well-being Index.

Appendix F Table 11 Anxiety Interventions: Subgroup Analyses for Benefits

Author, Year, Registry Number | Treatment Interventions and Comparators | Qualitative Results
Walkup et al, 2008^153^; Albano et al, 2018^205^; Taylor et al 2018^206^; Compton et al, 2014^207^; Sachez et al, 2019^208^; Rynn et al, 2015^209^; Gordon-Hollingsworth et al, 2015^210^; Ginsburg et al, 2011^211^; NCT00052078 | IG1: Individual child-focused in-person CBT (N=139); IG2: Sertraline (N=133); IG3: CBT + sertraline (N=140); CG: Placebo (N=76) | At post-treatment, anxiety severity as measured by independent evaluators (PARS) was significantly higher for participants of Hispanic ethnicity receiving CBT. Parent-rated anxiety severity (SCARED-P) was significantly higher for participants of Hispanic ethnicity receiving sertraline.; After accounting for treatment engagement and other demographic factors, there were no statistically significant differences in response, remission, or relapse based on race.; At post-treatment, parent-reported anxiety-related school impairment (CAIS) was significantly lower among male participants receiving either sertraline or sertraline in combination with CBT. There were no statistically significant sex effects based on youth-reported anxiety-related school impairment (CAIS).; At post-treatment, age was not a statistically significant moderator of the effect of treatment on any outcome.; The rate of overall AEs was significantly higher in children than in adolescents who received sertraline. The rate of total psychiatric AEs was significantly higher in children compared with adolescents across all treatment arms. The rate of total physical AEs was not significantly different between children and adolescents.
Shortt et al, 2001^134^ | IG1: Group child+parent in-person CBT (N=54); CG: Wait-list (N=17) | Age and sex were not significant moderators of clinician’s severity ratings (DISCAP) or self-report measures (RCMAS).
Ginsburg et al, 2020^92^ | IG1: Individual child-focused in-person CBT (N=148); CG: TAU (N=68) | At post-treatment, age significantly moderated the effect of treatment on response status, indicating that beneficial effects of treatment were strongest for older participants. No moderation effects were observed at 1-year followup.
Strawn et al, 2015^142^; NCT01226511 | IG1: Duloxetine (N=135); CG: Placebo (N=137) | Age and sex were not significant moderators of GAD severity (PARS).
Pine et al, 2001^124^; Walkup et al, 2001^213^; Ginsburg et al, 2006^214^; Reinblatt et al, 2009^215^ | IG1: Fluvoxamine (N=63); CG: Placebo (N=65) | Age, sex, and race were not significant moderators of treatment effects on any outcome.
Barrett et al, 1996^70^ | IG1: Individual child-focused CBT (N=28); IG2: Child+Parent CBT (N=25); CG: Wait-list (N=26) | At post-treamtment and 1-year followup, female and younger (7 to 10 years) participants who received child and parent-focused CBT had significantly higher rates of loss of diagnosis (ADIS) compared with those who received child-focused CBT.There were no significant differences across treament conditions at post-treatment or followup for male or older (11 to 14 years) participants.

Abbreviations: ADIS=Anxiety Disorders Interview Schedule; AE=adverse event; CAIS=Child Anxiety Impact Scale; CBT=cognitive behavioral therapy; CG=control group; DISCAP=Diagnostic Interview Schedule for Children, Adolescents, and Parents; GAD=general anxiety disorder; IG=intervention group; PARS=Pediatric Anxiety Rating Scale; RCMAS=Revised Children’s Manifest Anxiety Scale; SCARED-P=Screen for Anxiety Related Emotional Disorders-Parents; TAU=treatment as usual.

Appendix F Table 12 Anxiety Interventions: Suicide-Related Harms for Anxiety Pharmacotherapy Studies (KQ 5)

Treatment (Condition) | Author, Year | Mean Age | Dose (md/day) | Outcome Measure | Time Point (Weeks) | Treatment N | N (%) | Placebo N | N (%) | Effect Measure (95% CI), P-Value
Duloxetine (GAD) | Strawn et al, 2015^142^ | 12.4 | Flexibly dosed duloxetine (30–120 mg/d) | Suicidal ideation | 10 | 135 | 1 (1) | 137 | 0 (0) | p=NR
Escitalopram (GAD) | Strawn et al, 2020^143^ | 14.8 | Forced titration to 15 mg/d, then flexible titration to 20 mg/d, 8 weeks | Aborted suicide attempt | 8 | 26 | 1 (3.8) | 25 | 0 (0) | p=NR
Escitalopram (GAD) | Strawn et al, 2020^143^ | 14.8 | Forced titration to 15 mg/d, then flexible titration to 20 mg/d, 8 weeks | Self-injurious behavior | 8 | 26 | 2 (7.7) | 25 | 1 (4.0) | p=NR
Escitalopram (GAD) | Strawn et al, 2020^143^ | 14.8 | Forced titration to 15 mg/d, then flexible titration to 20 mg/d, 8 weeks | Worsening of suicide-related harms | 8 | 26 | 6 (23.1) | 25 | 2 (8.0) | p=NR
Escitalopram (GAD) | Strawn et al, 2020^143^ | 14.8 | Forced titration to 15 mg/d, then flexible titration to 20 mg/d, 8 weeks | Emergence or worsening of suicidality | 8 | 26 | NR | 25 | NR | p=0.449
Sertraline (GAD, separation anxiety disorder, social anxiety disorder) | Walkup et al, 2008^153^ | 10.7 | 25 mg/day, up to 200 mg/day by 8th week, for 12 weeks | Suicidal attempts | 12 | 133 | 0 (0) | 76 | 0 (0) | p=NR
Sertraline (GAD, separation anxiety disorder, social anxiety disorder) | Walkup et al, 2008^153^ | 10.7 | 25 mg/day, up to 200 mg/day by 8th week, for 12 weeks | Suicidal ideation | 12 | 133 | 0 (0) | 76 | 1 (1.3) | p=NR
Sertraline (GAD, separation anxiety disorder, social anxiety disorder) | Walkup et al, 2008^153^ | 10.7 | 25 mg/day, up to 200 mg/day by 8th week, for 12 weeks | Self-harm behavior without suicidal attempt | 12 | 133 | 1 (0.8) | 76 | 0 (0) | p=NR

Abbreviations: CI=confidence interval; GAD=general anxiety disorder; KQ=key question; N=number; NR=not reported

Appendix F Table 13 Anxiety Interventions: Other Adverse Events for Anxiety Pharmacotherapy Studies (KQ 5)

Treatment (Condition) | Author, Year | Mean Age | Dose (md/day) | Outcome Measure | Time Point (Weeks) | Treatment N | N (%) | Placebo N | N (%) | Effect Measure (95% CI), P-Value
Fluoxetine (Any) | Birmaher et al, 2003^73^ | 11.8 | 10 mg/d, after first week, up to 20 mg/d, 12 weeks | GI events | 12 | 35 | Not calculable (44) | 32 | Not calculable (22) | p=0.04
Fluoxetine (Any) | Birmaher et al, 2003^73^ | 11.8 | 10 mg/d, after first week, up to 20 mg/d, 12 weeks | Neurological complaints (headaches, drowsiness), | 2 | 36 | 16 (44) | 36 | 5 (14) | p=0.04
Fluoxetine (Any) | Birmaher et al, 2003^73^ | 11.8 | 10 mg/d, after first week, up to 20 mg/d, 12 weeks | Excitement, giddiness, or disinhibition | 12 | 36 | 7 (19) | 36 | 4 (11) | p=NS
Fluvoxamine (GAD, separation anxiety disorder, or social anxiety disorder) | Pine et al, 2001^124^; Walkup et al, 2001^213^; Ginsburg et al, 2006^214^; Reinblatt et al, 2009^215^ | 10.4 | 50 mg/d, then 50 mg/w to max. 300 mg/d in adolescents and 250 mg/d in children <12 years of age, 8 weeks | Abdominal discomfort | 8 | 63 | 31 (49) | 65 | 18 (28) | p=0.02
Fluvoxamine (GAD, separation anxiety disorder, or social anxiety disorder) | Pine et al, 2001^124^; Walkup et al, 2001^213^; Ginsburg et al, 2006^214^; Reinblatt et al, 2009^215^ | 10.4 | 50 mg/d, then 50 mg/w to max. 300 mg/d in adolescents and 250 mg/d in children <12 years of age, 8 weeks | Headache, increased motor activity, insomnia, nasal congestion, drowsiness, nausea, diarrhea, influenza, or upper respiratory infection | 8 | 63 | NR | 65 | NR | p=NS
Sertraline (GAD) | Rynn, 2001^130^ | 11.7 | 25 mg for the first week and 50 mg for weeks 2 to 9, 9 weeks | Dizziness | 9 | 11 | 2 (18) | 11 | 7 (64.4) | p<0.08
Sertraline (GAD) | Rynn, 2001^130^ | 11.7 | 25 mg for the first week and 50 mg for weeks 2 to 9, 9 weeks | Nausea | 9 | 11 | Not calculable (5) | 11 | 6 (55) | p<0.06
Sertraline (GAD) | Rynn, 2001^130^ | 11.7 | 25 mg for the first week and 50 mg for weeks 2 to 9, 9 weeks | Stomach pain | 9 | 11 | 2 (18) | 11 | 7 (64) | p<0.08
Sertraline (GAD) | Rynn, 2001^130^ | 11.7 | 25 mg for the first week and 50 mg for weeks 2 to 9, 9 weeks | Dry mouth | 9 | 11 | 6 (55) | 11 | 3 (27) | p=0.39
Sertraline (GAD) | Rynn, 2001^130^ | 11.7 | 25 mg for the first week and 50 mg for weeks 2 to 9, 9 weeks | Drowsiness | 9 | 11 | 8 (73) | 11 | 5 (45) | p=0.39
Sertraline (GAD) | Rynn, 2001^130^ | 11.7 | 25 mg for the first week and 50 mg for weeks 2 to 9, 9 weeks | Leg spasms | 9 | 11 | 4 (36) | 11 | 1 (9) | p=0.31
Sertraline (GAD) | Rynn, 2001^130^ | 11.7 | 25 mg for the first week and 50 mg for weeks 2 to 9, 9 weeks | Restlessness | 9 | 11 | 6 (55) | 11 | 3 (27) | p=0.39
Duloxetine (GAD) | Strawn et al, 2015^142^ | 12.4 | Flexibly dosed duloxetine (30–120 mg/d) | Treatment-emergent AEs | 10 | 135 | 106 (78.5) | 137 | 90 (65.7) | p=0.22
Escitalopram (GAD) | Strawn et al, 2020^143^ | 14.8 | Forced titration to 15 mg/d, then flexible titration to 20 mg/d, 8 weeks | Bruising | 8 | 26 | 4 (15) | 25 | 0 (0) | p=0.06
Escitalopram (GAD) | Strawn et al, 2020^143^ | 14.8 | Forced titration to 15 mg/d, then flexible titration to 20 mg/d, 8 weeks | Other AEs reported by system organ class | 8 | 26 | Varies by outcome | 25 | Varies by outcome | p=NS
Sertraline (GAD, separation anxiety disorder, or social anxiety disorder) | Walkup et al, 2008^153^ | 10.7 | 25 mg/day, up to 200 mg/day by 8th week, for 12 weeks. | Homicidal ideation | 12 | 133 | 2 (1.5) | 76 | 0 (0) | p=NS
Sertraline (GAD, separation anxiety disorder, or social anxiety disorder) | Walkup et al, 2008^153^ | 10.7 | 25 mg/day, up to 200 mg/day by 8th week, for 12 weeks. | Homidical attempts | 12 | 133 | 0 (0) | 76 | 0 (0) | p=NS
Sertraline (GAD, separation anxiety disorder, or social anxiety disorder) | Walkup et al, 2008^153^ | 10.7 | 25 mg/day, up to 200 mg/day by 8th week, for 12 weeks. | Any physical AEs | 12 | 133 | 56 (50.4) | 76 | 35 (46.1) | p=NS
Sertraline (GAD, separation anxiety disorder, or social anxiety disorder) | Walkup et al, 2008^153^ | 10.7 | 25 mg/day, up to 200 mg/day by 8th week, for 12 weeks. | Any psychiatric AEs | 12 | 133 | 23 (17.3) | 76 | 10 (13.2) | p=NS

Abbreviations: AE=adverse event; CI=confidence interval; GAD=general anxiety disorder; GI=gastrointestinal; KQ=key question; N=number; NR=not reported; NS=not significant.

Appendix F Table 14 Depression Psychotherapy Interventions vs. Wait-List Controls, Treatment as Usual, Attention Control, or Placebo: Depression Symptoms

Treatment (Condition) | Author, Year | Mean Age (SD) | Intervention and Duration | Outcome Measure | Time Point (Weeks) | Treatment N | Treatment Mean Score (SD) | Placebo N | Placebo Mean Score (SD) | Between-Group Difference | Between-Group P Value
Individual in-person youth CBT vs. TAU | Clarke et al, 2016^75^ | 14.6 (1.7) | 4 to 8 therapist delivered sessions (duration not specified) | CDRS-R | 52 weeks | 106 | 30.14 (11.26) | 106 | 28.24 (10.54) | −2.25^*^ | P=0.04
Individual in-person youth CBT vs. TAU | Clarke et al, 2016^75^ | 14.6 (1.7) | 4 to 8 therapist delivered sessions (duration not specified) | CDRS-R | 104 weeks | 106 | 28.11 (9.88) | 106 | 29.17 (10.79) | −1.30^*^ | P=0.36
Individual in-person youth CBT vs. TAU | Clarke et al, 2016^75^ | 14.6 (1.7) | 4 to 8 therapist delivered sessions (duration not specified) | CES-D (youth reported) | 52 weeks | 106 | 22.59 (7.00) | 106 | 22.51 (7.43) | −2.88^*^ | P<0.005
Individual in-person youth CBT vs. TAU | Clarke et al, 2016^75^ | 14.6 (1.7) | 4 to 8 therapist delivered sessions (duration not specified) | CES-D | 104 weeks | 106 | 21.46 (7.44) | 106 | 21.91 (6.95) | −0.32^*^ | P=0.62
Individual in-person youth CBT vs. TAU | Clarke et al, 2005^76^ | 15.3 (1.6) | 5 to 9 therapist delivered sessions (duration not specified) | CES-D | 52 weeks | 53 | 11.5 (11.0) | 50 | 14.9 (10.1) | −3.40 | p=0.07
Individual in-person youth CBT vs. TAU | Clarke et al, 2005^76^ | 15.3 (1.6) | 5 to 9 therapist delivered sessions (duration not specified) | HAM-D | 52 weeks | 53 | 4.9 (7.1) | 50 | 6.5 (6.6) | −1.60 | p=0.32
Individual in-person CBT vs. Placebo | March et al, 2004^113^ | 14.6 (1.5) | 15 therapist delivered sessions plus 2 parent-only sessions over 12 weeks | CDRS-R | 6 weeks | 111 | 44.63 (8.30) | 112 | 44.90 (7.32) | −0.27 | NR
Individual in-person CBT vs. Placebo | March et al, 2004^113^ | 14.6 (1.5) | 15 therapist delivered sessions plus 2 parent-only sessions over 12 weeks | CDRS-R | 12 weeks | 111 | 42.06 (9.18) | 112 | 41.77 (7.99) | 0.29 | P=0.97
Individual in-person CBT vs. Placebo | March et al, 2004^113^ | 14.6 (1.5) | 15 therapist delivered sessions plus 2 parent-only sessions over 12 weeks | RADS | 6 weeks | 111 | 69.10 (13.59) | 112 | 69.43 (10.94) | −0.33 | NR
Individual in-person CBT vs. Placebo | March et al, 2004^113^ | 14.6 (1.5) | 15 therapist delivered sessions plus 2 parent-only sessions over 12 weeks | RADS | 12 weeks | 111 | 67.96 (14.18) | 112 | 66.68 (11.41) | 1.28 | P=0.94
Family CBT vs. Placebo | Fristad et al, 2019^90^ | IG1: 11.7 (2.1); CG: 11.1 (2.4) | Family-based therapy with CBT techniques with parent at beginning and end of session over 12 weeks | CDRS-R | 12 weeks | 18 | 30 (9) | 18 | 31 (11) | −1.00 | p=0.88
Group in-person CBT vs. wait-list | Clarke et al, 1999^45^ | 16.2 (1.3) Completers | Group CBT (Adolescent Coping with Depression Course), over 8 weeks plus weekly meetings | BDI | 8 weeks | 37 | 10.1 (9.1) | 27 | 16.0 (11.2) | −5.90 | P<0.01
Group in-person CBT vs. wait-list | Clarke et al, 1999^45^ | 16.2 (1.3) Completers | Group CBT (Adolescent Coping with Depression Course), over 8 weeks plus weekly meetings | HAM-D | 8 weeks | 37 | 4.6 (4.8) | 27 | 7.7 (7.0) | −3.10 | P=NS
Group in-person CBT + parent sessions vs. wait-list | Clarke et al, 1999^45^ | 16.2 (1.3) Completers | Group CBT (Adolescent Coping with Depression Course), plus 8 weekly 2-hour parent sessions (6 separate, 2 held jointly with adolescent group) over 8 weeks | BDI | 8 weeks | 32 | 13.3 (10.9) | 27 | 16.0 (11.2) | −2.70 | P<0.01
Group in-person CBT + parent sessions vs. wait-list | Clarke et al, 1999^45^ | 16.2 (1.3) Completers | Group CBT (Adolescent Coping with Depression Course), plus 8 weekly 2-hour parent sessions (6 separate, 2 held jointly with adolescent group) over 8 weeks | HAM-D | 8 weeks | 32 | 6.7 (7.1) | 27 | 7.7 (7.0) | −1.00 | P=NS
Internet-based individual CBT vs. attention control | Topooco et al, 2018^147^ | IG1: 17.2 (1.0); CG: 16.9 (1.1) | Internet-based CBT with 8 skill-based modules plus weekly 30-minute chat sessions with therapist over 8 weeks | BDI-II | 8 weeks | 33 | 19.9 (7.2) | 37 | 25.2 (7.8) | −5.30 | p<0.05
Internet-based individual CBT vs. attention control | Topooco et al, 2018^147^ | IG1: 17.2 (1.0); CG: 16.9 (1.1) | Internet-based CBT with 8 skill-based modules plus weekly 30-minute chat sessions with therapist over 8 weeks | PHQ-9 | 8 weeks | 33 | 9.7 (2.9) | 37 | 10.8 (3.0) | −1.10 | p=NS
Internet-based individual CBT vs. attention control | Topooco et al, 2019^148^ | IG1: 17.5 (1.1); CG: 17.5 (1.2) | Internet-based CBT with 8 skill-based modules plus weekly 45-minute chat sessions with therapist over 8 weeks | BDI-II | 8 weeks | 35 | 16.0 (11.3) | 35 | 24.8 (10.4) | −8.80 | p<0.001
Internet-based individual CBT vs. attention control | Topooco et al, 2019^148^ | IG1: 17.5 (1.1); CG: 17.5 (1.2) | Internet-based CBT with 8 skill-based modules plus weekly 45-minute chat sessions with therapist over 8 weeks | MFQ | 8 weeks | 35 | 24.3 (12.8) | 35 | 31.0 (9.8) | −6.70 | p<0.01
Interpersonal psychotherapy vs. TAU | Mufson et al, 2004^118^ | 15.1 (1.9) | Manualized IPT-A during 12 sessions in a 12- to 16-week period | BDI | 12 weeks | 34 | 8.4 (11.0) | 29 | 12.3 (9.7) | −3.90 | p=0.04
Interpersonal psychotherapy vs. TAU | Mufson et al, 2004^118^ | 15.1 (1.9) | Manualized IPT-A during 12 sessions in a 12- to 16-week period | CGI-I | 12 weeks | 34 | 2.3 (1.3) | 29 | 3.1 (1.6) | −0.80 | p=0.03
Interpersonal psychotherapy vs. TAU | Mufson et al, 2004^118^ | 15.1 (1.9) | Manualized IPT-A during 12 sessions in a 12- to 16-week period | CGI-S | 12 weeks | 34 | 2.4 (1.3) | 29 | 3.0 (1.4) | −0.60 | p=0.03
Interpersonal psychotherapy vs. TAU | Mufson et al, 2004^118^ | 15.1 (1.9) | Manualized IPT-A during 12 sessions in a 12- to 16-week period | HAM-D | 12 weeks | 34 | 8.7 (8.0) | 29 | 12.8 (8.4) | −4.10 | p=0.01
Interpersonal psychotherapy vs. TAU | Mufson et al, 2004^118^ | 15.1 (1.9) | Manualized IPT-A during 12 sessions in a 12- to 16-week period | HAM-D | 16 weeks | 34 | 6.9 (NR) | 29 | 10.6 (NR) | −3.70 | P=0.01
Parent Child Interaction Therapy-Emotion Development (PCIT-ED) vs. wait-list | Luby et al, 2018^111^ | IG1: 5.1 (1.0); CG: 5.3 (1.1) | Manualized PCIT-ED sessions to teach parent followed by coaching parent-child interactions using a bug-in-the-ear device over 18 weeks | K-SADS-EC MDD core score | Change at 18 weeks | 114 | NR | 115 | NR | Mean difference (SE); −2.34 (0.26) | p<0.0001
Parent Child Interaction Therapy-Emotion Development (PCIT-ED) vs. wait-list | Luby et al, 2018^111^ | IG1: 5.1 (1.0); CG: 5.3 (1.1) | Manualized PCIT-ED sessions to teach parent followed by coaching parent-child interactions using a bug-in-the-ear device over 18 weeks | PFC-scale | Change at 18 weeks | 114 | NR | 115 | NR | Adjusted mean difference (SE); −11.91 (1.29) | p<0.0001

* Across 0 to 52 weeks, not a comparison at 52 weeks.

Abbreviations: BDI=Beck Depression Inventory; BDI-II=Beck Depression Inventory, version 2; CBT=cognitive behavioral therapy; CDRS-R=Children’s Depression Rating Scale-Revised; CES-D=Center for Epidemiological Studies-Depression; CG=control group; CGI-I=Clinical Global Impressions-Improvement; CGI-S=Clinical Global Impressions-Severity; HAM-D=Hamilton Depression Rating Scale; IG=intervention group; IPT-A=interpersonal psychotherapy for depressed adolescents; K-SADS-EC=Schedule For Affective Disorders And Schizophrenia For School-Age Children-Early Childhood version; MDD=major depressive disorder; MFQ=mood & feelings questionnaire; N=number; NR=not reported; NS=not significant; PCIT-ED=Parent Child Interaction Therapy-Emotion Development; PFC=Preschool Feelings Checklist; PHQ-9=Patient Health Questionnaire, 9 question; RADS=Reynolds Adolescent Depression Scale; SD=standard deviation; TAU=treatment as usual; vs.=versus.

Appendix F Table 15 Depression Pharmacotherapy Interventions vs. Placebo: Depression Symptoms

Treatment (Condition) | Author, Year | Mean Age (SD) | Dose (md/day) | Outcome Measure | Time Point (Weeks) | Treatment N | Treatment Mean Score (SD) | Placebo N | Placebo Mean Score (SD) | Between-Group Difference | Between-Group P Value
Escitalopram vs. placebo | Emslie, 2009^86^ | IG1: 14.7 (1.6); CG: 14.5 (1.5) | 10 to 20 mg | Change in CDRS-R | 8 weeks | 129 | −22.1 (SEM: 1.22) | 132 | −18.8 (SEM: 1.27) | −3.3 | 0.022
Escitalopram vs. placebo | Emslie, 2009^86^ | IG1: 14.7 (1.6); CG: 14.5 (1.5) | 10 to 20 mg | Change in CGI-I | 8 weeks | 129 | 2.2 (SEM: 0.11) | 132 | 2.6 (SEM: 0.11) | −0.4 | 0.008
Escitalopram vs. placebo | Emslie, 2009^86^ | IG1: 14.7 (1.6); CG: 14.5 (1.5) | 10 to 20 mg | CGI-S | 8 weeks | 129 | −1.8 (SEM: 0.11) | 132 | −1.4 (SEM: 0.12) | −0.4 | 0.007
Escitalopram vs. placebo | Wagner, 2006^151^ | 12.3 (3.0) | 10 to 20 mg | Change in CDRS-R | 8 weeks | 154 | −21.9 (NR) | 157 | −20.2 (NR) | −1.7 | 0.31
Escitalopram vs. placebo | Wagner, 2006^151^ | 12.3 (3.0) | 10 to 20 mg | Change in CGI-I | 8 weeks | 154 | 2.3 (NR) | 157 | 2.5 (NR) | −0.2 | 0.169
Escitalopram vs. placebo | Wagner, 2006^151^ | 12.3 (3.0) | 10 to 20 mg | Change in CGI-S | 8 weeks | 154 | −1.6 (NR) | 157 | −1.3 (NR) | −0.3 | 0.057
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Change in CDRS-R | 6 weeks | 109 | 39.8 (7.37) | 112 | 44.9 (7.32) | −5.1 | NR
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Change in CDRS-R | 12 weeks | 109 | 36.3 (8.18) | 112 | 41.8 (7.99) | −5.5 | 0.10
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Change in RADS | 6 weeks | 109 | 63.4 (12.44) | 112 | 69.4 (10.94) | −6.0 | NR
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Change in RADS | 12 weeks | 109 | 60.6 (13.07) | 112 | 66.7 (11.41) | −6.1 | 0.34

Abbreviations: CDRS-R=Children’s Depression Rating Scale-Revised; CG=control group; CGI-I=Clinical Global Impressions-Improvement; CGI-S=Clinical Global Impressions-Severity; IG=intervention group; N=number; NR=not reported; RADS=Reynolds Adolescent Depression Scale; SD=standard deviation; SEM=standard error of the mean; vs.=versus.

Appendix F Table 16 Depression Pharmacotherapy + Psychotherapy Intervention vs. Placebo: Depression Symptoms

Treatment (condition) | Author, Year | Mean Age (SD) | Dose (md/day) | Outcome Measure | Time Point (Weeks) | Treatment N | Treatment Mean Score (SD) | Placebo N | Placebo Score (SD/SE) | Between-Group Difference | Between-Group P Value
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Change in CDRS-R | 6 weeks | 107 | 38.10 (7.78) | 112 | 44.9 (7.32) | −6.80 | NR
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Change in CDRS-R | 12 weeks | 107 | 33.79 (8.24) | 112 | 41.8 (7.99) | −8.01 | P=0.001
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Change in RADS | 6 weeks | 107 | 60.90 (11.59) | 112 | 69.4 (10.94) | −8.50 | NR
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Change in RADS | 12 weeks | 107 | 56.95 (12.24) | 112 | 66.7 (11.41) | −9.75 | P=0.001

Abbreviations: CDRS-R=Children’s Depression Rating Scale-Revised; N=number; NR=not reported; SD=standard deviation; SE=standard error; vs.=versus.

Appendix F Table 17 Depression Collaborative Care Intervention vs. Treatment as Usual: Depression Symptoms

Treatment (Condition) | Author, Year | Mean Age (SD) | Intervention and duration | Outcome Measure | Time Point (Weeks) | Treatment N | Treatment Mean Score (95% CI) | Placebo N | Placebo Mean Score (95% CI) | Between-Group Difference | Between-Group P Value
Collaborative care vs. enhanced usual care | Richardson et al, 2014^127^ | 15.3 (1.3) | Choice of treatment (antidepressant, brief CBT, or both), and followup over 12 months | CDRS-R | 6 months | 50 | NR | 51 | NR | Mean difference between groups (95% CI); −8.5 (−13.4 to −3.6) | P=0.001
Collaborative care vs. enhanced usual care | Richardson et al, 2014^127^ | 15.3 (1.3) | Choice of treatment (antidepressant, brief CBT, or both), and followup over 12 months | CDRS-R | 12 months | 50 | 27.5 (23.8 to 31.1) | 51 | 34.6 (30.6 to 38.6) | Mean difference between groups (95% CI); −9.4 (−15.0 to −3.8) | P=0.001

Abbreviations: CBT=cognitive behavioral therapy; CDRS-R=Children’s Depression Rating Scale-Revised; CI=confidence interval; N=number; SD=standard deviation vs.=versus.

Appendix F Table 18 Depression Psychotherapy Interventions vs. Wait-List Control, Treatment as Usual, Attention Control, or Placebo: Response, Remission, and Loss of Diagnosis

Treatment (Condition) | Author, Year | Mean Age (SD) | Intervention and Duration | Outcome Measure | Time Point (Weeks) | Treatment N | N (%; 95% CI) | Placebo N | N (%; 95% CI) | Effect Measure (95% CI), p value
Individual in-person youth CBT vs. TAU | Clarke et al, 2016^75^ | 14.6 (1.7) | 4 to 8 therapist delivered sessions (duration not specified) | MDD response^*^ | 52 weeks | 106 | 90 (90.9) | 106 | 87 (87.9) | OR: 1.39 (95% CI, 1.03 to 1.87)
Individual in-person youth CBT vs. TAU | Clarke et al, 2016^75^ | 14.6 (1.7) | 4 to 8 therapist delivered sessions (duration not specified) | MDD Response^*^ | 104 weeks | 106 | 93 (93.9) | 106 | 93 (93.9) | OR: 1.38 (95% CI, 1.03 to 1.84)
Individual in-person youth CBT vs. TAU | Clarke et al, 2016^75^ | 14.6 (1.7) | 4 to 8 therapist delivered sessions (duration not specified) | MDD Recovery^†^ | 52 weeks | 106 | 79 (79.8) | 106 | 68 (68.7) | OR: 1.60 (95% CI, 1.15 to 2.21)
Individual in-person youth CBT vs. TAU | Clarke et al, 2016^75^ | 14.6 (1.7) | 4 to 8 therapist delivered sessions (duration not specified) | MDD Recovery^†^ | 104 weeks | 106 | 88 (88.9) | 106 | 78 (78.8) | OR: 1.59 (95% CI, 1.17 to 2.17)
Individual in-person CBT vs. Placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 15 therapist delivered sessions plus 2 parent-only sessions over 12 weeks | CGI ≥2 | 12 weeks | 111 | 43.2 (34 to 52) | 112 | 34.8 (26 to 44) | p=0.20
Individual in-person CBT vs. Placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 15 therapist delivered sessions plus 2 parent-only sessions over 12 weeks | CDRS-R score ≤28 | 12 weeks | 111 | 14 (16) | 112 | 19 (17) | OR: 0.9 (0.44 to 1.88); P=0.80
Individual in-person CBT vs. Placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | Loss of MDD diagnosis based on K-SADS-P/L | 12 weeks | NR | (61.1) | NR | (60.4) | OR: 1.0 (0.52 to 1.77); P=0.89
Family CBT vs. placebo | Fristad et al, 2019^90^ | IG1: 11.7 (2.1); CG: 11.1 (2.4) | Family-based therapy with CBT techniques with parent at beginning and end of session over 12 weeks | CDRS-R score ≤28 | 12 weeks | 18 | 11 (61) | 18 | 10 (56) | p=NS
Group in-person CBT vs. wait-list | Clarke et al, 1999^45^ | 16.2 (1.3) Completers | Group CBT (Adolescent Coping With Depression Course), over 8 weeks plus weekly meetings | Absence of MDD/dysthymia diagnoses | 8 weeks | 37 | 24 (64.9) | 27 | 13 (48.1) | IG1/IG2 vs. CG, 1 tailed P<0.05 Cohen’s h=0.38 OR: 2.15 (90% CI, 1.01 to 4.59)
Group in-person CBT + parent sessions vs. wait-list | Clarke et al, 1999^45^ | 16.2 (1.3) Completers | Group CBT (Adolescent Coping With Depression Course), plus 8 weekly 2-hour parent sessions (6 separate, 2 held jointly with adolescent group) over 8 week | Absence of MDD/dysthymia diagnoses | 8 weeks | 32 | 22 (68.8) | 27 | 13 (48.1)
Internet-based individual CBT vs. attention control | Topooco et al, 2018^147^ | IG1: 17.2 (1.0); CG: 16.9 (1.1) | Internet-based CBT with 8 skill-based modules plus weekly 30-minute chat sessions with therapist over 8 weeks | BDI-II ≥30% decrease | 8 weeks | 33 | 20 (60.6) | 37 | 12 (32.4) | p<0.05
Internet-based individual CBT vs. attention control | Topooco et al, 2018^147^ | IG1: 17.2 (1.0); CG: 16.9 (1.1) | Internet-based CBT with 8 skill-based modules plus weekly 30-minute chat sessions with therapist over 8 weeks | BDI-II ≥50% decrease | 8 weeks | 33 | 14 (42.4) | 37 | 5 (13.5) | p<0.01
Internet-based individual CBT vs. attention control | Topooco et al, 2018^147^ | IG1: 17.2 (1.0); CG: 16.9 (1.1) | Internet-based CBT with 8 skill-based modules plus weekly 30-minute chat sessions with therapist over 8 weeks | Loss of MDD diagnosis | 8 weeks | 33 | 20 (71.4) | 37 | 4 (16.0) | p<0.001
Internet-based individual CBT vs. attention control | Topooco et al, 2019^148^ | IG1: 17.5 (1.1); CG: 17.5 (1.2) | Internet-based CBT with 8 skill-based modules plus weekly 45-minute chat sessions with therapist over 8 weeks | BDI-II ≥30% decrease | 8 weeks | 35 | NR | 35 | NR | p=0.004
Internet-based individual CBT vs. attention control | Topooco et al, 2019^148^ | IG1: 17.5 (1.1); CG: 17.5 (1.2) | Internet-based CBT with 8 skill-based modules plus weekly 45-minute chat sessions with therapist over 8 weeks | BDI-II ≥13 | 8 weeks | 35 | NR | 35 | NR | p=0.004
Internet-based individual CBT vs. attention control | Topooco et al, 2019^148^ | IG1: 17.5 (1.1); CG: 17.5 (1.2) | Internet-based CBT with 8 skill-based modules plus weekly 45-minute chat sessions with therapist over 8 weeks | BDI-II ≥10 | 8 weeks | 35 | NR | 35 | NR | p=0.004
Internet-based individual CBT vs. attention control | Topooco et al, 2019^148^ | IG1: 17.5 (1.1); CG: 17.5 (1.2) | Internet-based CBT with 8 skill-based modules plus weekly 45-minute chat sessions with therapist over 8 weeks | Clinically significant improvement (2 SD below pre-treatment BDI-II mean) | 8 weeks | 35 | 16 (46) | 35 | 4 (11) | p=0.001
Internet-based individual CBT vs. attention control | Topooco et al, 2019^148^ | IG1: 17.5 (1.1); CG: 17.5 (1.2) | Internet-based CBT with 8 skill-based modules plus weekly 45-minute chat sessions with therapist over 8 weeks | No longer met MDD criteria | 8 weeks | 27 | 15 (56) | 26 | 7 (27) | p=0.03
Interpersonal psychotherapy vs. TAU | Mufson et al, 2004^118^ | 15.1 (1.9) | Manualized IPT-A during 12 sessions in a 12- to 16-week period | HAM-D score ≤6 | 12 weeks | 34 | 17 (50) | 29 | 10 (34) | p=NR
Interpersonal psychotherapy vs. TAU | Mufson et al, 2004^118^ | 15.1 (1.9) | Manualized IPT-A during 12 sessions in a 12- to 16-week period | BDI score ≤9 | 12 weeks | 34 | 25 (74) | 29 | 15 (52) | p=0.048
Parent Child Interaction Therapy-Emotion Development (PCIT-ED) vs. wait-list | Luby et al, 2018^111^ | IG1: 5.1 (1.0); CG: 5.3 (1.1) | Manualized PCIT-ED sessions to teach parent followed by coaching parent-child interactions using a bug-in-the-ear device over 18 weeks | K-SADS-EC MDD diagnosis for all participants, multiply imputed | Change at 18 weeks | 114 | NR | 115 | NR | aOR^ǂ^ (95% CI) CG vs. IG1: 9.52 (8.44 to 10.74); P<0.0001
Parent Child Interaction Therapy-Emotion Development (PCIT-ED) vs. wait-list | Luby et al, 2018^111^ | IG1: 5.1 (1.0); CG: 5.3 (1.1) | Manualized PCIT-ED sessions to teach parent followed by coaching parent-child interactions using a bug-in-the-ear device over 18 weeks | K-SADS-EC MDD diagnosis for completers | Change at 18 weeks | 100 | 68 (75) | 91 | 22 (22) | aOR (95% CI), CG vs. IG1: 12.15 (5.95 to 24.82); P<0.0001

* Major depression diagnostic response defined as ≥8 weeks below the threshold of 5 or more MD symptoms necessary for full diagnosis but where full recovery has not yet occurred.

† Recovery defined as ≥8 weeks of no or minimal symptoms (K-SADS Diagnostic Status Rating ≤1-2) and little or no impairment.

ǂ Controlled for baseline characteristics, gender, and baseline externalizing disorder.

Abbreviations: aOR=adjusted odds ratio; BDI=Beck Depression Inventory; BDI-II=Beck Depression Inventory, version 2; CBT=cognitive behavioral therapy; CDRS-R=Children’s Depression Rating Scale-Revised; CG=control group; CGI=Clinical Global Impressions; CI=confidence interval; IG=intervention group; HAM-D=Hamilton Rating Scale for Depression; IG=intervention group; IPT-A=interpersonal psychotherapy for depressed adolescents; K-SADS-EC=Schedule for Affective Disorders and Schizophrenia for School-Age Children-version; K-SADS-PL=Schedule For Affective Disorders And Schizophrenia For School-Age Children-Present and Lifetime Version; MDD=major depressive disorder; N=number; NR=not reported; NS=not significant; PCIT-ED=Parent Child Interaction Therapy-Emotion Development; SD=standard deviation; TAU=treatment as usual; vs=versus.

Appendix F Table 19 Depression Pharmacotherapy Interventions vs. Placebo for Depression in Children: Remission and Loss of Diagnosis

Treatment (Condition) | Author, Year | Mean Age | Dose (mg/day) | Outcome Measure | Time Point (Weeks) | Treatment N | N (%; 95% CI) | Placebo N | N (%; 95% CI) | Effect Measure (95% CI), p Value
Escitalopram vs. placebo | Emslie, 2009^86^ | IG1: 14.7 (1.6); CG: 14.5 (1.5) | 10 to 20 mg | CDRS-R ≤28 | 8 weeks | 154 | 64 (41.6) | 157 | 56 (35.7) | 0.15
Escitalopram vs. placebo | Wagner, 2006^151^ | 12.3 (3.0) | 10 to 20 mg | CDRS-R ≤28 | 8 weeks | 129 | 59 (45.7) | 132 | 50 (37.9) | 0.32
Escitalopram vs. placebo | Wagner, 2006^151^ | 12.3 (3.0) | 10 to 20 mg | CGI-I ≤2 | 8 weeks | 129 | 81 (62.8) | 132 | 69 (52.3) | 0.14
Fluoxetine vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | CDRS-R score ≤28 | 12 weeks | 109 | 25 (23) | 112 | 19 (17) | 1.5 (0.74 to 2.88); P=0.28
Fluoxetine vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | CGI-I ≤2 | 12 weeks | 109 | 60.6 (51 to 70) | 112 | 34.8 (26 to 44) | P=0.001
Fluoxetine vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Loss of MDD diagnosis based on K-SADS-P/L | 12 weeks | NR | 78.6% | NR | 60.4% | P=0.007

Abbreviations: CDRS-R=Children’s Depression Rating Scale-Revised; CG=control group; CGI-I=Clinical Global Impressions-Improvement; CI=confidence interval; IG=intervention group; K-SADS-PL=Schedule For Affective Disorders And Schizophrenia For School-Age Children-Present and Lifetime Version; MDD=major depressive disorder; N=number; NR=not reported; vs.=versus.

Appendix F Table 20 Depression Pharmacotherapy + Psychotherapy Intervention vs. Placebo: Response, Remission, and Loss of Diagnosis

Treatment (Condition) | Author, Year | Mean Age | Dose (mg/day) | Outcome Measure | Time Point (Weeks) | Treatment N | N (%; 95% CI) | Placebo N | N (%; 95% CI) | Effect Measure (95% CI), p Value
Fluoxetine | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | CDRS-R score ≤28 | 12 weeks | 107 | 40 (37) | 112 | 19 (17) | 3.0 (1.58 to 5.79); P=0.0009
Fluoxetine | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | CGI-I ≤2 | 12 weeks | 107 | 71.0 (62 to 80) | 112 | 34.8 (26 to 44) | P=0.001
Fluoxetine | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Loss of MDD diagnosis based on K-SADS-P/L | 12 weeks | NR | 85.3% | NR | 60.4% | 4.1 (2.00 to 8.44); P=0.0001

Abbreviations: CDRS-R=Children’s Depression Rating Scale-Revised; CGI-I=Clinical Global Impressions-Improvement; CI=confidence interval; K-SADS-PL=Schedule for Affective Disorders and Schizophrenia for School-Age Children-present and lifetime version; MDD=major depressive disorder; N=number; NR=not reported; vs.=versus.

Appendix F Table 21 Depression Collaborative Care Intervention vs. Treatment as Usual: Response, Remission, and Loss of Diagnosis

Treatment (Condition) | Author, Year | Mean Age (SD) | Intervention and Duration | Outcome Measure | Time Point (Weeks) | Treatment N | N (%; 95% CI) | Placebo N | N (%; 95% CI) | Effect Measure (95% CI), p Value
Collaborative care vs. enhanced usual care | Richardson et al, 2014^127^ | 15.3 (1.3) | Choice of treatment (antidepressant, brief CBT, or both), and followup over 12 months | ≥50% reduction in CDRS-R | 6 months | 50 | NR (48.4^*^) | 51 | NR (23.4^*^) | OR (95% CI): 3.1 (1.2 to 7.9), P=0.02
Collaborative care vs. enhanced usual care | Richardson et al, 2014^127^ | 15.3 (1.3) | Choice of treatment (antidepressant, brief CBT, or both), and followup over 12 months | ≥50% reduction in CDRS-R | 12 months | 50 | NR (67.6^*^) | 51 | NR (38.6^*^) | OR (95% CI): 3.3 (1.4 to 8.2), P=0.009
Collaborative care vs. enhanced usual care | Richardson et al, 2014^127^ | 15.3 (1.3) | Choice of treatment (antidepressant, brief CBT, or both), and followup over 12 months | PHQ-9 <5 | 6 months | 50 | NR (36.6^*^) | 51 | NR (10.2^*^) | OR (95% CI): 5.2 (1.6 to 17.3), P=0.007
Collaborative care vs. enhanced usual care | Richardson et al, 2014^127^ | 15.3 (1.3) | Choice of treatment (antidepressant, brief CBT, or both), and followup over 12 months | PHQ-9 <5 | 12 months | 50 | NR (50.4^*^) | 51 | NR (20.7^*^) | OR (95% CI): 3.9 (1.5 to 10.6), P=0.007

* Imputed % based on 20 multiple imputations.

Abbreviations: CBT=cognitive behavioral therapy; CDRS-R=Children’s Depression Rating Scale-Revised; CI=confidence interval; N=number; NR=not reported; OR=odds ratio; PHQ-9=Patient Health Questionnaire-9; SD=standard deviation; vs.=versus.

Appendix F Table 22 Depression Collaborative Care Intervention vs. Treatment as Usual: Response, Remission, and Loss of Diagnosis

Treatment (Condition) | Author, Year | Mean Age (SD) | Intervention and Duration | Outcome Measure | Time Point (Weeks) | Treatment N | N (%; 95% CI) | Placebo N | N (%; 95% CI) | Between-Group Difference | Between-Group P Value
Collaborative care vs. enhanced usual care | Richardson et al, 2014^127^ | 15.3 (1.3) | Choice of treatment (antidepressant, brief CBT, or both), and followup over 12 months | CIS | 6 months | 50 | NR | 51 | NR | −4.4 (−8.4 to −0.5) | p=0.03; (A priori threshold for secondary outcomes of P ≤0.01)
Collaborative care vs. enhanced usual care | Richardson et al, 2014^127^ | 15.3 (1.3) | Choice of treatment (antidepressant, brief CBT, or both), and followup over 12 months | CIS | 12 months | 50 | 16.3 (13.8 to 18.8) | 51 | 13.4 (10.8 to 15.9) | −4.3 (−8.3 to −0.3) | p=0.04; (A priori threshold for secondary outcomes of P ≤0.01)

Abbreviations: CBT=cognitive behavioral therapy; CI=confidence interval; CIS=Columbia Impairment Scale; N=number;=standard deviation; vs.=versus.

Appendix F Table 23 Depression Psychotherapy vs. Wait-List Controls, Treatment as Usual, Attention Control, or Placebo: Functioning or Quality of Life (Continuous)

Treatment (Condition) | Author, Year | Mean Age (SD) | Intervention and Duration | Outcome Measure | Time Point (Weeks) | Treatment N | Treatment Mean Score (SD) | Placebo N | Placebo Mean Score (SD) | Between-Group Difference | P value
Individual in-person youth CBT vs. TAU | Clarke et al, 2016^75^ | 14.6 (1.7) | 4 to 8 therapist-delivered sessions (duration not specified) | CGAS | 52 weeks | 106 | 72.33 (9.97) | 106 | 74.10 (10.81) | 4.2 (95% CI, 1.55 to 6.86) | P<0.007 favoring CBT
Individual in-person youth CBT vs. TAU | Clarke et al, 2016^75^ | 14.6 (1.7) | 4 to 8 therapist-delivered sessions (duration not specified) | CGAS | 104 weeks | 106 | 76.86 (11.03) | 106 | 76.45 (11.09) | 0.13 (95% CI, −2.08 to 2.34) | P=0.21
Individual in-person youth CBT vs. TAU | Clarke et al, 2016^75^ | 14.6 (1.7) | 4 to 8 therapist-delivered sessions (duration not specified) | PEDS-QL | 52 weeks | 106 | 75.40 (14.57) | 106 | 76.94 (12.43) | 0.55 (95% CI, −3.21 to 4.31) | P=0.73
Individual in-person youth CBT vs. TAU | Clarke et al, 2016^75^ | 14.6 (1.7) | 4 to 8 therapist-delivered sessions (duration not specified) | PEDS-QL | 104 weeks | 106 | 75.40 (14.57) | 106 | 76.94 (12.43) | 1.05 (95% CI, −2.27 to 4.36) | P=0.90
Individual in-person youth CBT vs. TAU | Clarke et al, 2005^76^ | 15.3 (1.6) | 5 to 9 therapist-delivered sessions (duration not specified) | CGAS | 52 weeks | 53 | 71.4 (8.7) | 50 | 68.4 (7.6) | NR | P=0.22
Individual in-person youth CBT vs. TAU | Clarke et al, 2005^76^ | 15.3 (1.6) | 5 to 9 therapist-delivered sessions (duration not specified) | SF-12 MCS | 52 weeks | 53 | 45.4 (9.3) | 50 | 43.1 (10.2) | NR | P=0.04
Individual in-person youth CBT vs. TAU | Clarke et al, 2005^76^ | 15.3 (1.6) | 5 to 9 therapist-delivered sessions (duration not specified) | SF-12 PCS | 52 weeks | 53 | 49.0 (5.8) | 50 | 48.1 (8.5) | NR | P=0.84
Individual in-person CBT vs. placebo pill | March et al, 2004^113^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | CGAS | 6 weeks | 111 | 56.7 (9.66) | 112 | 57.0 (9.22) | NR | NR
Individual in-person CBT vs. placebo pill | March et al, 2004^113^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | CGAS | 12 weeks | 111 | 60.0 (11.47) | 112 | 59.3 (12.72) | NR | P=0.3805
Individual in-person CBT vs. placebo pill | March et al, 2004^113^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | CGAS | Change at 12 weeks | 111 | 9.7 (12.12) | 112 | 9.9 (12.38) | NR | P=NS
Individual in-person CBT vs. placebo pill | March et al, 2004^113^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | HoNOSCA | 12 weeks | 111 | 11.7 (6.09) | 112 | 11.2 (6.15) | NR | p=0.3344
Individual in-person CBT vs. placebo pill | March et al, 2004^113^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | HoNOSCA | Change in 12 weeks | 111 | −3.6 (5.58) | | −4.2 (5.71) | NR | p=NR
Individual in-person CBT vs. placebo pill | March et al, 2004^113^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | PQ-LES-Q | 12 weeks | 111 | 47.4 (10.84) | 112 | 48.2 (9.91) | NR | p=0.4630
Individual in-person CBT vs. placebo pill | March et al, 2004^113^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | PQ-LES-Q | Change in 12 weeks | 111 | 4.2 (10.01) | 112 | 5.2 (10.16) | NR | p=NS
Group in-person CBT vs. wait-list | Clarke et al, 1999^45^ | 16.2 (1.3) Completers | Group CBT (Adolescent Coping with Depression Course), over 8 weeks plus weekly meetings | GAF | 8 weeks | 37 | 71.0 (11.7) | 27 | 64.5 (11.8) | NR | IG1/IG2 vs. CG P<0.05; effect size=0.54
Group in-person CBT + parent sessions vs. wait-list | Clarke et al, 1999^45^ | 16.2 (1.3) Completers | Group CBT (Adolescent Coping with Depression Course), plus 8 weekly 2-hour parent sessions (6 separate, 2 held jointly with adolescent group) over 8 weeks | GAF | 8 weeks | 32 | 69.9 (14.9) | 27 | 64.5 (11.8) | NR | IG1/IG2 vs. CG P<0.05; effect size=0.54
Interpersonal psycho-therapy vs. TAU | Mufson et al, 2004^118^ | 15.1 (1.9) | Manualized IPT-A during 12 sessions in a 12- to 16-week period | CGAS | 12 weeks | 34 | 66.7 (13.0) | 29 | 59.5 (13.5) | NR | p=0.04, effect size 0.54
Interpersonal psycho-therapy vs. TAU | Mufson et al, 2004^118^ | 15.1 (1.9) | Manualized IPT-A during 12 sessions in a 12- to 16-week period | CGAS | 16 weeks | 33 | NR | 29 | NR | NR | p=0.06, effect size NR
Interpersonal psycho-therapy vs. TAU | Mufson et al, 2004^118^ | 15.1 (1.9) | Manualized IPT-A during 12 sessions in a 12- to 16-week period | SAS-SR Overal | 12 weeks | 34 | 2.23 (0.66) | 29 | 2.59 (0.67) | NR | p=0.01, effect size 0.55 Repeated measures ANOVA time x treatment interaction P=0.003
PCIT-ED vs. wait-list | Luby et al, 2018^111^ | IG1: 5.1 (1.0); CG: 5.3 (1.1) | Manualized PCIT-ED sessions to teach parent followed by coaching parent-child interactions using a bug-in-the-ear device over 18 weeks | CGAS | Change to 18 weeks | 114 | NR | 115 | NR | Adjusted^*^ mean difference (SE) 20.5 (2.3) | p<0.0001
PCIT-ED vs. wait-list | Luby et al, 2018^111^ | IG1: 5.1 (1.0); CG: 5.3 (1.1) | Manualized PCIT-ED sessions to teach parent followed by coaching parent-child interactions using a bug-in-the-ear device over 18 weeks | PECFAS/CAFAS | Change to 18 weeks | 114 | NR | 115 | NR | Adjusted mean difference (SE) 3.19 (0.46) | p<0.0001

* Controlled for baseline characteristics, gender, and baseline externalizing disorder.

Abbreviations: ANOVA=analysis of variance; CAFAS=Child and Adolescent Functional Assessment Scale; CBT=cognitive behavioral therapy; CG=control group; CGAS=Children’s Global Assessment Scale; CI=confidence interval; GAF=Global Assessment of Functioning; HoNOSCA=Health of the Nation Outcome Scales for Children and Adolescents; IG=intervention group; IPT-A=intensive interpersonal psychotherapy for depressed adolescents; N=number; NR=not reported; NS=not significant; PCIT-ED=Parent Child Interaction Therapy-Emotion Development; PFC=Preschool Feelings Checklist; Preschool and Early Childhood Functional Assessment Scale/Child and Adolescent Functional Assessment Scale; PEDS-QL= Pediatric Quality of Life Inventory; PQ-LES-Q=Pediatric Quality of Life Enjoyment and Satisfaction Questionnaire; SAS-SR=Social Adjustment Scale–Self-Report; SD=standard deviation; SE=standard error; SF-12 MCS=Short-Form 12 Mental Component Score; SF-12 PCS=Short-Form 12 Physical Component Score; TAU=treatment as usual; vs.=versus.

Appendix F Table 24 Depression Psychotherapy vs. Placebo: Functioning (Categorical)

Treatment (Condition) | Author, Year | Mean Age (SD) | Intervention and Duration | Outcome Measure | Time Point (Weeks) | Treatment N | N (%; 95% CI) | Placebo N | N (%; 95% CI) | Effect Measure (95% CI), p Value
Individual in-person CBT vs. placebo pill | March et al, 2004^113^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | C-GAS >70 | 12 weeks | 111 | 15 (13.5) | 112 | 21 (18.7) | P=NS

Abbreviations: CBT=cognitive behavioral therapy; CGAS=Children’s Global Assessment Scale; CI=confidence interval; N=number; NS=not significant; SD=standard deviation; vs.=versus.

Appendix F Table 25 Depression Pharmacotherapy Interventions vs. Placebo: Functioning (Continuous)

Treatment (Condition) | Author, Year | Mean Age (SD) | Dose (mg/day) | Outcome Measure | Time Point (Weeks) | Treatment N | Treatment Score (SD/SE) | Placebo N | Placebo Score (SD/SE) | Between-Group Difference | Between-Group P Value
Escitalopram vs. placebo | Emslie, 2009^86^ | IG1: 14.7 (1.6); CG: 14.5 (1.5) | 10 to 20 mg | Change in CGAS | 8 weeks | 154 | 14.9 (SE: 1.11) | 157 | 12.7 (SE: 1.15) | LSMD=2.169 (−0.439 to 4.777) | 0.103
Escitalopram vs. placebo | Wagner, 2006^151^ | 12.3 (3.0) | 10 to 20 mg | Change in CGAS | 8 weeks | 129 | 15.6 | 132 | 12.7 | 2.9 | 0.065
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | CGAS | 6 weeks | 109 | 59.9 (SD: `10.58) | 112 | 57.0 (SD: 9.22) | 2.9 | NR
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | CGAS | 12 weeks | 109 | 62.1 (SD: 11.91) | 112 | 59.3 (SD: 12.72) | 2.8 | P=0.0381
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Change in CGAS | 12 weeks | 109 | 12.6 (SD: 12.31) | 112 | 9.9 (SD: 12.38) | 2.7 | P=NS
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | HoNOSCA | 12 weeks | 109 | 10.9 (SD: 6.35) | 112 | 11.2 (SD: 6.15) | −0.3 | P=0.3344
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Change in HoNOSCA | 12 weeks | 109 | −5.1 (SD: 5.74) | 112 | −4.2 (SD: 5.71) | −0.9 | P=NS
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | PQ-LES-Q | 12 weeks | 109 | 51.2 (SD: 10.43) | 112 | 48.2 (SD: 9.91) | 3.0 | 0.7215
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Change in PQ-LES-Q | 12 weeks | 109 | 6.6 (SD: 10.23) | 112 | 5.2 (SD: 10.16) | 1.4 | P=NS

Abbreviations: CG=control group; CGAS=Children’s Global Assessment Scale; HoNOSCA=Health of the Nation Outcome Scales for Children and Adolescents; IG=intervention group; LSMD=least-square mean difference; NR=not reported; NS=not significant; PQ-LES-Q=Pediatric Quality of Life Enjoyment and Satisfaction Questionnaire; SD=standard deviation; SE=standard error; vs.=versus.

Appendix F Table 26 Depression Pharmacotherapy Intervention vs. Placebo: Functioning (Categorical)

Treatment | Author, Year | Mean Age | Dose (mg/day) | Outcome Measure | Time Point (Weeks) | Treatment N | N (%; 95% CI) | Placebo N | N (%; 95% CI) | Effect Measure (95% CI), p Value
Fluoxetine vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Rate of nonimpaired patients (C-GAS >70) | 12 weeks | 109 | 22 (20.2) | 112 | 21 (18.7) | P=NS

Abbreviations: CGAS=Children’s Global Assessment Scale; CI=confidence interval; N=number; NS=not significant; vs.=versus.

Appendix F Table 27 Depression Pharmacotherapy + Psychotherapy Intervention vs. Placebo: Functioning (Continuous)

Treatment | Author, Year | Mean Age (SD) | Dose (mg/day) | Outcome Measure | Time Point (Weeks) | Treatment N | Treatment Score (SD) | Placebo N | Placebo Score (SD/SE) | Between-Group Difference | Between-Group P Value
Fluoxetine + CBT vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | CGAS | 6 weeks | 107 | 62.4 (11.2) | 112 | 57.0 (9.22) | 5.4 | NR
Fluoxetine + CBT vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | CGAS | 12 weeks | 107 | 66.6 (11.91) | 112 | 59.3 (12.72) | 7.3 | P<0.0001
Fluoxetine + CBT vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Change in CGAS | 12 weeks | 107 | 16.7 (12.31) | 112 | 9.9 (12.38) | 6.8 | P<0.0001
Fluoxetine + CBT vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | HoNOSCA | 12 weeks | 107 | 9.5 (5.97) | 112 | 11.2 (6.15) | −1.7 | P=0.0393
Fluoxetine + CBT vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Change in HoNOSCA | 12 weeks | 107 | −6.3 (5.69) | 112 | −4.2 (5.71) | −2.1 | P<0.01
Fluoxetine + CBT vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | PQ-LES-Q | 12 weeks | 107 | 54.7 (11.21) | 112 | 48.2 (9.91) | 6.5 | P<0.0001
Fluoxetine + CBT vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Change in PQ-LES-Q | 12 weeks | 107 | 9.6 (10.14) | 112 | 5.2 (10.16) | 4.4 | p<0.0001

Abbreviations: CBT=cognitive behavioral therapy; CGAS=Children’s Global Assessment Scale; HoNOSCA=Health of the Nation Outcome Scales for Children and Adolescents; N=number; NR=not reported; PQ-LES-Q=Pediatric Quality of Life Enjoyment and Satisfaction Questionnaire; SD=standard deviation; SE=standard error; vs.=versus.

Appendix F Table 28 Depression Pharmacotherapy + Psychotherapy Intervention vs. Placebo: Functioning (Categorical)

Treatment | Author, Year | Mean Age | Dose (mg/day) | Outcome Measure | Time Point (Weeks) | Treatment N | N (%; 95% CI) | Placebo N | N (%; 95% CI) | Effect Measure (95% CI), p Value
Fluoxetine + CBT vs. placebo | March, 2004^113^ | 14.6 (1.5) | 10 to 40 mg | Rate of nonimpaired patients (C-GAS >70) | 12 weeks | 107 | 37 (34.6) | 112 | 19 (17) | P=0.009

Abbreviations: CBT=cognitive behavioral therapy; CGAS=Children’s Global Assessment Scale; CI=confidence interval; N=number; vs.=versus.

Appendix F Table 29 Depression Interventions: Subgroup Analyses for Benefits

Author, Year, Registry Number | Treatment Interventions and Comparators | Qualitative Results
Clarke et al, 1999^45^ | IG1: Child-focused Group CBT (N=45); IG2: Child + Parent Group CBT (N=42); CG: Wait-list (N=36) | At posttreatment, sex was not a significant moderator of recovery rates.
March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^; NCT00006286 | IG1: Fluoxetine+CBT (N=107); IG2: Fluoxetine (N=109); IG3: Child + Parent CBT (N=111); CG: Placebo (N=112) | At posttreatment, age was significant moderator of clinician-rated symptom severity (CDRS-R), indicating adolescents younger than 16 years of age improved more than adolescents who were 16 or older across treatment conditions.; At posttreatment, age, gender, and race/ethnicity were not significant moderators of clinician-rated (CGAS, HoNOSCA) and self-reported (PQ-LES-Q) functioning.
Wagner et al, 2006^151^ | IG1: Escitalopram (N=132); CG: Placebo (N=136) | At posttreatment, age significantly moderated the effect of treatment on clinician-rated symptom severity (CGI-S), symptom improvement (CGI-I), and overall functioning (CGAS), indicating that treatment was effective in adolescents (12 to 17 years) but not in children (6 to 11 years).

Abbreviations: CBT=cognitive behavioral therapy; CG=control group; CGAS=Children’s Global Assessment Scale; CGI-I=Clinical Global Impressions-Improvement; IG=intervention group; N=number; PQ-LES-Q=Pediatric Quality of Life Enjoyment and Satisfaction Questionnaire.

Appendix F Table 30 Depression Psychotherapy Interventions vs. Placebo: Suicide-Related Outcomes (Continuous)

Treatment (Condition) | Author, Year | Mean Age (SD) | Intervention and Duration | Outcome Measure | Time Point | Treatment N | Treatment Score (SD) | Placebo N | Placebo Score (SD/SE) | Between-Group P Value
Individual in-person CBT vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | SIQ-Jr | 6 weeks | 111 | 13.18 (11.34) | 112 | 16.85 (11.70) | NR
Individual in-person CBT vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | SIQ-Jr | 12 weeks | 111 | 11.40 (10.44) | 112 | 15.01 (11.05) | P=0.76

Abbreviations: CBT=cognitive behavioral therapy; N=number; NR=not reported; SD=standard deviation; SE=standard error; SIQ-Jr=Suicidal Ideation Questionnaire-Junior; vs.=versus.

Appendix F Table 31 Depression Psychotherapy Interventions vs. Treatment as Usual or Placebo: Suicide-Related Outcomes (Categorical)

Treatment (Condition) | Author, Year | Mean Age (SD) | Intervention and Duration | Outcome Measure | Time Point | Treatment N | N (%) | Placebo N | N (%) | Effect Measure (95% CI), p Value
Individual in-person youth CBT vs. TAU | Clarke et al, 2016^75^ | 14.6 (1.7) | 4 to 8 therapist-delivered sessions (duration not specified) | Suicidal behavior assessed by K-SADS interview | 52 weeks | 106 | 5 (5.8) | 106 | 2 (2.4) | RR: 2.50 (0.50 to 12.60)
Individual in-person youth CBT vs. TAU | Clarke et al, 2016^75^ | 14.6 (1.7) | 4 to 8 therapist-delivered sessions (duration not specified) | Suicidal behavior assessed by K-SADS interview | 104 weeks | 106 | 1 (1.1) | 106 | 1 (1.1) | RR: 1.00 (0.06 to 15.78)
Individual in-person CBT vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | Suicide-related AEs determined by Columbia Classification Algorithm | 12 weeks | 111 | 5 (4.50) | 112 | 4 (3.57)^113^; Also reported as 3 (2.7%)^218^ | RR: 1.26 (0.35 to 4.57); RR: 1.68 (0.41 to 6.87)
Individual in-person CBT vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | Suicide attempts | 12 weeks | 111 | 1 (0.90%) | 112 | 0 (0) | NR

Abbreviations: AE=adverse event; CBT=cognitive behavioral therapy; CI=confidence interval; K-SADS=Schedule for Affective Disorders and Schizophrenia for School-Age Children; N=number; NR=not reported; RR=relative risk; SD=standard deviation; TAU=treatment as usual; vs.=versus.

Appendix F Table 32 Depression Pharmacotherapy Interventions vs. Placebo: Suicide-Related Outcomes (Continuous)

Treatment (Condition) | Author, Year | Mean Age (SD) | Dose (mg/day) | Outcome Measure | Time Point | Treatment N | Treatment Score (SD) | Placebo N | Placebo Score (SD/SE) | Between-Group Difference | Effect Measure (95% CI), p Value
Escitalopram vs. placebo | Emslie, 2009^86^ | IG1: 14.7 (1.6); CG: 14.5 (1.5) | 10 to 20 mg | Change in SIQ-Jr | 8 weeks | 155 | −4.6 (SEM, 12.0) | 157 | −2.9 (10.2) | −1.7 | 0.29
Escitalopram vs. placebo | Emslie, 2009^86^ | IG1: 14.7 (1.6); CG: 14.5 (1.5) | 10 to 20 mg | Change in MC-SSRS (worsening suicidal behavior) | 8 weeks | 155 | 2 (SEM, 1.5) | 157 | 3 (2.3) | −1.0 | NR
Escitalopram vs. placebo | Emslie, 2009^86^ | IG1: 14.7 (1.6); CG: 14.5 (1.5) | 10 to 20 mg | Change in MC-SSRS (increase in suicidal ideation) | 8 weeks | 155 | 12 (SEM, 9.4) | 157 | 12 (9.2) | 0 | NR
Fluoxetine vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Change in SIQ-Jr | 6 weeks | 109 | 16.20 (12.42) | 112 | 16.85 (11.70) | −0.65 | NR
Fluoxetine vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Change in SIQ-Jr | 12 weeks | 109 | 14.44 (11.13) | 112 | 15.01 (11.05) | −0.57 | 0.36^*^

* Means adjusted for both fixed (treatment and time) and random (participant and site) effects derived from linear random coefficient model.

Abbreviations: CG=placebo group; CI=confidence interval; IG1=active drug group; MC-SSRS= Modified Columbia Suicide Severity Rating Scale; N=number; SD=standard deviation; SE=standard error; SEM=standard error of the mean; SIQ-Jr=Suicidal Ideation Questionnaire-Junior; vs.=versus.

Appendix F Table 33 Depression Pharmacotherapy Interventions vs. Placebo: Suicide-Related Outcomes (Categorical)

Treatment (Condition) | Author, Year | Mean Age (SD) | Dose (mg/day) | Outcome Measure | Time Point | Treatment N | N (%) | Placebo N | N (%) | Effect Measure (95% CI), p Value
Escitalopram vs. placebo | Emslie, 2009^86^ | IG1: 14.7 (1.6); CG: 14.5 (1.5) | 10 to 20 mg | Self-harm related AE (other than suicidality) | 8 weeks | 155 | 6 (3.9) | 157 | 6 (3.8) | NR
Escitalopram vs. placebo | Wagner, 2006^151^ | 12.3 (3.0) | 10 to 20 mg | Potential suicide-related events | 8 weeks | 131 | 1 (7.8) | 133 | 2 (1.5) | NR
Fluoxetine vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Suicide-related AEs determined by Columbia Classification Algorithm | 12 weeks | 109 | 9 (8.26)^113^; Also reported as 10 (9.2)^218^ | 112 | 4 (3.57)^113^; Also reported as 3 (2.7)^218^ | RR: 2.31 (0.73 to 7.29); RR: 3.43 (0.97 to 12.11)
Fluoxetine vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Suicide attempts | 12 weeks | 109 | 2 (1.83) | 112 | 0 (0) | NR

Abbreviations: AE=adverse event; CG=placebo group; CI=confidence interval; IG1=active drug group; N=number; NR=not reported; RR=relative risk; SD=standard deviation; vs.=versus.

Appendix F Table 34 Depression Pharmacotherapy + Psychotherapy Intervention vs. Placebo: Suicide-Related Outcomes (Continuous)

Treatment (Condition) | Author, Year | Mean Age (SD) | Dose (mg/day) | Outcome Measure | Time Point | Treatment N | Treatment Score (SD/SE) | Placebo N | Placebo Score (SD/SE) | Between-Group Difference | Between-Group P Value
Fluoxetine + CBT vs placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Change in SIQ-Jr | 6 weeks | 107 | 14.31 (12.58) | 112 | 16.85 (11.70) | −0.65 | NR
Fluoxetine + CBT vs placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Change in SIQ-Jr | 12 weeks | 107 | 11.79 (11.69) | 112 | 15.01 (11.05) | −0.57 | 0.02^*^

* Supplemental between-group comparisons of means at 12 weeks; P=NS.

Abbreviations: CBT=cognitive behavioral therapy; N=number; NS=not significant; SD=standard deviation; SE=standard error; SIQ-Jr=Suicidal Ideation Questionnaire-Junior; vs.=versus.

Appendix F Table 35 Depression Pharmacotherapy + Psychotherapy Intervention vs. Placebo: Suicide-Related Outcomes (Categorical)

Treatment (Condition) | Author, Year | Mean Age (SD) | Dose (mg/day) | Outcome Measure | Time Point | Treatment N | N (%) | Placebo N | N (%) | Effect Measure (95% CI), p Value
Fluoxetine + CBT vs placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Suicide-related AEs determined by Columbia Classification Algorithm | 12 weeks | 107 | 6 (5.61)^113^; Also reported as 5 (4.7)^218^ | 112 | 4 (3.57)^113^; Also reported as 3 (2.7)^218^ | RR (95% CI): IG vs. CG: 1.57 (0.46 to 5.41); RR (95% CI): IG vs. CG: 1.75 (0.43 to 7.12)
Fluoxetine + CBT vs placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Suicide attempts | 12 weeks | 107 | 4 (3.7%) | 112 | 0 (0) | NR

Abbreviations: AE=adverse event; CBT=cognitive behavioral therapy; CG=control group; CI=confidence interval; IG=intervention group; N=number; NR=not reported; RR=relative risk; SD=standard deviation; vs.=versus.

Appendix F Table 36 Depression Psychotherapy vs. Placebo Intervention: Adverse Events and Serious Adverse Events

Treatment (Condition) | Author, Year | Mean Age (SD) | Intervention and Duration | Outcome Measure | Time Point (Weeks) | Treatment N | N (%) | Placebo N | N (%) | Effect Measure (95% CI), p Value
Individual in-person CBT vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | Physical AEs requiring medical attention or causing dysfunction | 12 weeks | 111 | 9 (8.1) | 112 | 34 (30.4) | NR
Individual in-person CBT vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | Any psychiatric-related AEs | 12 weeks | 111 | 1 (1) | 112 | 9 (9.8) | NR
Individual in-person CBT vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | Serious AEs | 12 weeks | 111 | 5 (4.50) | 112 | 6 (5.36) | OR (95% CI): 0.8 (0.25 to 2.81)
Individual in-person CBT vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 15 therapist-delivered sessions plus 2 parent-only sessions over 12 weeks | Serious psychiatric-related AEs | 12 weeks | 111 | 0 (0) | 112 | 1 (0.89), mania | NR

Abbreviations: AE=adverse event; CBT=cognitive behavioral therapy; CI=confidence interval; N=number; NR=not reported; OR=odds ratio; SD=standard deviation; vs.=versus.

Appendix F Table 37 Depression Pharmacotherapy Interventions vs. Placebo: Adverse Events and Serious Adverse Events

Treatment (Condition) | Author, Year | Mean Age (SD) | Dose (mg/day) | Outcome Measure | Time Point (Weeks) | Treatment N | N (%) | Placebo N | N (%) | Between-Group P Value
Escitalopram vs. placebo | Emslie, 2009^86^ | IG1: 14.7 (1.6); CG: 14.5 (1.5) | 10 to 20 mg | Total AEs | 8 weeks | 155 | 121 (78.1) | 157 | 118 (75.2) | NR
Escitalopram vs. placebo | Emslie, 2009^86^ | IG1: 14.7 (1.6); CG: 14.5 (1.5) | 10 to 20 mg | SAEs | 8 weeks | 155 | 4 (2.6), 1 sexual assault, 1 self-injurious behavior, 1 suicidal ideation, 1 irritability | 157 | 2 (1.3) (1 suicidal tendency, 1 aggravated depression) | NR
Escitalopram vs. placebo | Wagner, 2006^151^ | 12.3 (3.0) | 10 to 20 mg | Any AE | 8 weeks | 131 | 90 (68.7) | 133 | 90 (67.7) | p=0.90
Fluoxetine vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Physical AEs requiring medical attention or causing dysfunction | 12 weeks | 109 | 35 (32.1) | 112 | 34 (30.4) | NR
Fluoxetine vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Any psychiatric-related AEs | 12 weeks | 109 | 20 (21.0) | 112 | 9 (9.8) | NR
Fluoxetine vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | SAEs | 12 weeks | 109 | 13 (11.93) | 112 | 6 (5.36) | OR (95% CI): 2.4 (0.87 to 6.54)
Fluoxetine vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Serious psychiatric-related AEs | 12 weeks | 109 | 1 (0.92), worsening depression | 112 | 1 (0.89), mania | NR

Abbreviations: AE=adverse event; CBT=cognitive behavioral therapy; CI=confidence interval; N=number; NR=not reported; OR=odds ratio; SAE=serious adverse event; SD=standard deviation; vs.=versus.

Appendix F Table 38 Depression Pharmacotherapy + Psychotherapy Intervention vs. Placebo: Adverse Events and Serious Adverse Events

Treatment (Condition) | Author, Year | Mean Age (SD) | Dose (mg/day) | Outcome Measure | Time Point (Weeks) | Treatment N | Treatment Score (SD) | Placebo N | Placebo Score (SD/SE) | Between-Group P Value
Fluoxetine + CBT vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Physical AEs requiring medical attention or causing dysfunction | 12 weeks | 107 | 37 (34.5) | 112 | 34 (30.4) | NR
Fluoxetine + CBT vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Any psychiatric-related AEs | 12 weeks | 107 | 12 (15) | 112 | 9 (9.8) | NR
Fluoxetine + CBT vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | SAEs | 12 weeks | 107 | 9 (8.41) | 112 | 6 (5.36) | OR (95% CI): 1.6 (0.56 to 4.72)
Fluoxetine + CBT vs. placebo | March et al, 2004^113^; Curry et al, 2006^217^; Emslie et al, 2006^218^; Kennard et al, 2006^219^; Vitiello et al, 2006^220^ | 14.6 (1.5) | 10 to 40 mg | Serious psychiatric-related AEs | 12 weeks | 107 | 0 (0) | 112 | 1 (0.89), mania | NR

Abbreviations: AE=adverse event; CBT=cognitive behavioral therapy; CI=confidence interval; N=number; NR=not reported; OR=odds ratio; SD=standard deviation; SE=standard error; vs.=versus.