# Appendix E Index Screening Tests and Reference Standards

Appendix E Table 1 Screening Instruments for Anxiety and Depression Used in Test Accuracy Studies (KQ 2)

Instrument | Full Name | Description | Scoring, Range | Studies Using Instrument
ANS^174^ | Autonomic Nervous System Questionnaire | 5-item self-report measuring panic symptoms in the past 6 months. The first two items directly ask whether in the past 6 months the respondent has ever had a sudden spell or an attack of feeling frightened, anxious, or very uneasy and/or a spell or an attack with the heart racing, feeling faint, or an inability to catch one’s breath. A “no” response to both questions is considered a negative screen. Items 3–5 for those who answered yes to one or two of the first questions ask about spontaneity, frequency, and anticipatory worry about panic attacks. | Each item on a 3-point scale (not at all worried, somewhat worried, or very worried). The total score range is 0 to 5. | Queen et al, 2012^23^
BDI^175^ | Beck Depression Inventory | A 21-item scale that measures cognitive, behavioral, affective, and somatic components of depression symptoms. Items comprise four statements rated from 0 to 3 in terms of intensity. Respondents are asked to report the one that most accurately describes their own feelings. This original version of the inventory has largely been replaced by the BDI-II. | Score <10 minimal depression, 10 to 18 mild to moderate depression, 19 to 29 moderate to severe depression, and 30 to 36 severe depression. | Canals et al, 2001;^17^ Roberts et al, 1991^16^
CES-D^18,^ ^176–178^ | Center for Epidemiologic Studies-Depression | A 20-item self- or interviewer-administered scale that assess past-week symptoms. Respondents asked to indicate frequency of past-week symptoms as “rarely or none of the time” (scored as 0), “some or a little of the time” (scored as 1), “occasionally or a moderate amount of time” (scored as 2), and “most or all of the time” (scored as 3). A version modified for children is referred to as the CES-DC. | Scores range from 0 to 60. Higher scores indicate worse symptoms; a score of 16 or higher is considered positive for depression. | Garrison et al, 1991^18^; Roberts et al, 1991^16^
CIS-R^179^ | Clinical Interview Schedule Revised | A computerized branched questionnaire to assess symptoms of depression and anxiety in nonclinical populations. It includes 14 subscales specific to the frequency, severity, persistence, and intrusiveness of common symptoms. | A screen is positive if it fulfills the algorithm for ICD-10 depressive disorder. | Patton et al, 1999^19^
EDAS^180^ | Escala para la Deteccion de Ansiedad Socia | A 26-item youth report that measures social anxiety. Items assess fear of speaking or acting in ways that would be embarrassing, youths’ social avoidance, distress, and interference. Administration time is 16 minutes. | Two items are dichotomous, and the remaining items are on a 5-point scale (0 to 4). The nondichotomous items are summed for the total score ranging from 24 to 120. | Garcia-Lopez et al, 2015^164^
HSCL^181,^ ^182^ | Hopkins Symptom Checklist | A 10- or 6-item depression subscale derived from the Symptom Checklist-90. Items asking about troublesome feelings with responses scored as no (1), slightly (2), much (3), and very much (4). | Score ranges from 10 to 40 for the 10-item version. A score of 16 was considered the optimal threshold for screening in the initial validation study. | Christensen et al, 2015^15^
LSAS-CA^183^ | The Liebowitz Social Anxiety Scale for Children and Adolescents | A youth-reported 24-item scale to measure social anxiety appropriate for children and adolescents. The screener assesses total fear, fear of social interaction, fear of performance, total avoidance, avoidance of social interaction, and performance avoidance. Administration time is 12 minutes. | The screener uses a 4-point Likert scale (0 to 3). Total scores range from 0 to 72. | Garcia-Lopez et al, 2015^164^
MHI-5 | Mental Health Index | The MHI-5 is a 5-item version of the 38-item MHI. The 5 items pertain to mood in the past month. | Originally designed as a 6-point Likert scale, modified to 4-point Likert scale. Total scores range from 0 to 15. Higher scores indicate better mental health. | Rivera-Riquera et al, 2018^172^
PHQ-A^184^ | Patient Health Questionnaire-Adolescents | Derived from the original PRIME-MD screening questionnaire and clinical interview; PHQ-A is a 67-item self-administered questionnaire that can be administered in 5 minutes or less to assess anxiety and depressive disorders. Clinicians quickly review completed questionnaires and apply diagnostic algorithms, which appear at the bottom of the printed page. The instrument is used to screen for panic disorder and GAD among other psychiatric disorders including depression and substance use. | NR | Johnson et al, 2002^13^
PI-ED | Paediatric Index of Emotional Distress – Total Scale; Anxiety Subscale; Depression Subscale | A brief, self-report screening tool based on HADS to measure 16 anxiety and depression symptoms that is suitable for children and adolescents ages 8 to 16 years. Items are scored on a 4-point scale from 3 to 0 (always, a lot of the time, sometimes, not at all). Includes a total score, an anxiety subscale, and a depression subscale. | Items are scored on a 4-point scale, 0 to 3 from “always” to “not at all.” Total score ranges from 0 to 21. | O’Connor et al, 2016^14^
SCARED^185–187^ | Screen for Anxiety Related Emotional Disorders | 41-Item parent and child self-report measure used to screen for anxiety disorders in children ages 8 to 18 years. A total score is available as well as for the following scales: GAD, separation anxiety disorder, panic disorder, and social anxiety disorder. Administration time is 10 minutes. A 10-item short form is also available. | Each item is rated on a 3-point scale ranging from 0 to 2 (“almost never,” “sometimes,” “often”). Score ranges from 0 to 82. Total score >25 may indicate anxiety disorder; subscale scores also available (panic: score of 7 or more; GAD: score of 9 or more; social anxiety: score of 8 or more; separation anxiety: score of 5 or more). | Bailey et al, 2006^21^; Canals et al, 2012^162^; Muris et al, 2001^169^
SAS^188,^ ^189^ | Social Anxiety Scale | An 18-item screener plus four filler items used to assess social anxiety in children in relation to peers. It includes three scales: Fear of Negative Evaluation, Social Avoidance and Distress-Specific to New Peers and New Situations, and General Social Avoidance and Distress. Includes both a child and adult report version. The SAS for Adolescents (SAS-A) is a revision of the SAS to make it developmentally appropriate for adolescents. SAS-A includes 18 items and same three scales with both an adolescent and parent version. | Each item on a 5-point scale (“not at all” to “all the time”). Total score ranges from 18 to 90. | Bailey et al, 2006^21^; Garcia-Lopez et al, 2015^164^
SASA^190^ | Social Anxiety Scale for Adolescents (Slovenian measure) | 28-item instrument measuring social anxiety with two scales: one measuring fears, worries, and anticipation of a negative peer evaluation and the second assessing social tension/relaxation, speech or behavior inhibition, and readiness to exposure in social situations. Administration time is 12 minutes. | All items are on a 5-point scale. The total score ranges from 28 to 140. | Garcia-Lopez et al, 2015^164^
SoPhI^191^ | Social Phobia Inventory | A 21-item scale to assess social anxiety using DSM-IV criteria, including an item assessing duration of symptoms (social anxiety must be present for at least 6 months). Administration time is 10 minutes. | All items are rated on a 5-point scale, with the total score ranging from 21 to 105. | Garcia-Lopez et al, 2015^164^
SPAI-B^192^ | Social Phobia and Anxiety Inventory - Brief | 16-item scale measuring social anxiety in adolescents. The screener assesses cognitive, somatic, and behavioral symptoms. Administration time is 9 minutes. | Each item is rated on a 5-point Likert scale. The total ranges from 0 to 64. | Garcia-Lopez et al, 2015^164^
SPIN^193^; Mini-SPIN^194,^ ^195^ | Social Phobia Inventory/Mini Social Phobia Inventory | 17 items measuring behavioral, physiological, and cognitive symptomatology associated with social anxiety; fear in social situations; avoidance of performing in social situations; and physiological discomfort in social situations. Time to administer is 8 minutes. The MiniSPIN is a 3-item version of the scale measuring avoidance and fear of embarrassment. | Each item is rated on a 5-point 0 to 4 scale (“not at all” to “extremely”), with a total score ranging from 0 to 68 for the full instrument and from 0 to 12 for the Mini SPIN. | Garcia-Lopez et al, 2015^164^; Ranta et al, 2007^170^; Ranta et al, 2012^171^; Tsai et al, 2009^173^
SWQ^196^ | Social Worries Questionnaire | 10-Item parent-report screener to assess social anxiety symptomatology in youth ages 8 to 17 years. It measures the degree to which the youth avoids or worries about particular social situations. | Each item on a 3-point scale (not true to mostly true). Total scores range from 0 to 20. | Bailey et al, 2006^21^
WHO-5^197,^ ^198^ | World Health Organization Five Item Well-Being Index | A 5-item scale asking about feelings in the past 2 weeks derived from a subscale developed from the Short-Form 36 (SF-36). Response categories are all of the time (5), most of the time (4), more than half of the time (3), less than half of the time (2), some of the time (1), and at no time (0). | This scale is generally converted to a scale of 0 to 100 by multiplying the sum score by 4. Higher scores represent more well-being. | Christensen et al, 2015^15^

Abbreviations: ANS=Autonomic Nervous System Questionnaire; BDI=Beck Depression Inventory; CES=Center for Epidemiological Studies; DSM-IV=Diagnostic and Statistical Manual of Mental Disorders, 4th Edition; EDAS=escala para la deteccion de ansiedad socia; GAD=generalized anxiety disorder; HADS=Hospital Anxiety and Depression Scale; HSCL13=Hopkins Symptom Checklist-13; ICD-10=International Classification of Diseases, Tenth Revision; KQ=key question; LSAS-CA=Liebowitz Social Anxiety Scale for Children and Adolescents; MHI=Mental Health Index; MiniSPIN=Mini-Social Phobia Inventory; NR=not reported; PHQ-A=Patient Health Questionnaire-Adolescent; PI-ED=Pediatric Index of Emotional Distress; PRIME-MD=Primary Care Evaluation of Mental Disorders; SAS=Social Anxiety Scale; SAS-A=Social Anxiety Scale for Adolescents; SCARED=Screen for Anxiety Related Emotional Disorders; SF-36=Short Form (36) Health Survey; WHO-5=World Health Organization Five Item Well-being Index.

Appendix E Table 2 Reference Standard Instruments for Anxiety Test Accuracy Studies (KQ 2)

Reference Measure | Description | Studies Using Reference Measure
Anxiety Disorders Interview Schedule for DSM: Child and Parent Version (ADIS C/P) | A semi-structured interview designed to diagnosis anxiety disorders as well as depression and behavioral disorders based on DSM criteria for children and adolescents. | Bailey et al, 2006;^21^ Garcia-Lopez et al, 2015;^164^ Queen et al, 2012;^23^ Rivera-Riquelme et al, 2019^172^
Composite International Diagnostic Interview (CIDI) | A comprehensive, structured interview designed to be used by trained lay interviewers for the assessment of mental disorders according to the definitions and criteria of ICD-10 and DSM. | Christensen et al, 2015;^15^ Patton et al, 1999^19^
Computerized Diagnostic Schedule for Children (C-DISC) | A structured diagnostic instrument that can be self-completed. It covers diagnoses for anxiety disorders, mood disorders, disruptive disorders, and miscellaneous disorders. | O’Connor et al, 2016^14^
Diagnostic clinical interview | Diagnostic clinical interview with mental health professional that includes items from the Structured Clinical Interview for DSM-III-R, PRIME-MD Clinical Evaluation Guide, and DSM-IV Global Assessment of Functioning. | Johnson et al, 2002^13^
Measure of Adolescent Potential for Suicide (MAPS) Clinical Interview | Includes direct suicide ratings (DSR) recorded during the interview, which are determined by the frequency and intrusiveness of suicidal thoughts, levels of suicide plans/preparation/intent, lethality of prior attempts, and present vs. past suicide threat. Ratings on each domain range from 0 (not at all or low lethality) to 6 (very serious or high lethality) with overall score the average of 4 ratings. High suicide risk defined as the upper 20th percentile cut-point of the DSR. | Thompson et al, 1999^24^
Mini-Neuropsychiatric Interview for Kids (MINI-Kid) | A structured diagnostic interview for children and adolescents based on DSM and ICD-10 criteria that is used to diagnose 23 Axis 1 disorders. | Canals et al, 2012;^162^ Tsai et al, 2009^173^
Schedule for affective Disorders and Schizophrenia for School-Age Children- Present and Lifetime Version (K-SADs-PL) | A semi-structured clinical interview that covers 32 DSM child and adolescent diagnoses including both MDD and anxiety disorders such as panic disorder, SepAD, SocAD, and GAD. | Ranta et al, 2007;^170^ Ranta et al, 2012;^171^ Roberts et al, 1991;^16^ Garrison et al, 1991^18^
Schedules for Clinical Assessment in Neuropsychiatry (SCAN) | A semi-structured diagnostic interview aligned to ICD-10 and DSM criteria. | Canals et al, 2001;^17^
Structured Clinical Interview for DSM-IV for Children (K-SCID) | K-SCID for DSM-IV generates DSM-IV diagnoses on children, with probe questions to facilitate assessing whether diagnostic criteria are met. | Muris et al, 2001^169^

Abbreviations: ADIS=Anxiety Disorders Interview Schedule; C-DISC=Computerized Diagnostic Schedule for Children; CIDI=Composite International Diagnostic Interview; DSM=Diagnostic and Statistical Manual of Mental Disorders; DSR=direct suicide ratings; GAD=generalized anxiety disorder; ICD-10=International Classification of Diseases, Tenth Revision; KQ=key question; K-SAD=Schedule for Affective Disorders and Schizophrenia for School-Age Children; MAPS=Measure of Adolescent Potential for Suicide; MDD=major depressive disorder; MINI-Kid=MINI international neuropsychiatric interview for kids; PRIME-MD=Primary Care Evaluation of Mental Disorders; SepAD=separation anxiety disorder; SocAD=social anxiety disorder.