# Appendix D U.S. Preventive Services Task Force Quality Rating Criteria

## Randomized, Controlled Trials and Cohort Studies

### Criteria

- Initial assembly of comparable groups
- Randomized, controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements that are equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

### Definition of Ratings Based on Above Criteria

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.
Poor: | Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Sources: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force, 2015 ;^61^ Harris et al, 2001.^62^

## Systematic Reviews

### Criteria

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance (especially important for systematic reviews)

### Definition of Ratings Based on Above Criteria

- Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions
- Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies
- Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies

Sources: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force, 2015 ;^61^ Harris et al, 2001.^62^

Appendix D Table 1 Individual Study Quality Assessment of Harms of Screening Studies Based on Cochrane RoB 2.0 (KQ 3)

Author, Year | Domain 1 RoB | Domain 2 RoB | Domain 3 RoB | Domain 4 RoB | Domain 5 RoB | Overall RoB Harms | Harms Comments
Gould et al, 2005^63^ | Some concerns | Low | Low | Low | Some concerns | Some concerns | Method of randomization not reported, minimal baseline characteristics reported to assess adequacy of randomization; no trial registration or study protocol cited to determine whether analysis conducted was prespecified.
Robinson et al, 2011^64^ | Some concerns | Low | Some concerns | Low | Some concerns | Some concerns | No baseline characteristics provided to assess adequacy of randomization; between 20% and 40% of students had missing data and unclear how missing data are related to outcome of distress; no trial registration or evidence of a prespecified analysis plan.

Appendix D Table 2 Individual Study Quality Assessment of Treatment Studies Based on Cochrane RoB 2.0 (KQ 4 & KQ 5)

Author, Year | Domain 1 RoB | Domain 2 RoB | Domain 3 RoB | Domain 4 RoB | Domain 5 RoB | Overall RoB Efficacy | Efficacy Comments | Harms RoB | Harms Comments
Arendt et al, 2016^65^ | Low | Some concerns | Low | Low | Low | Some concerns | No blinding possible. | Not Applicable
Asarnow et al, 2017^66^ | Low | Low | Some concerns | Low | Some concerns | Some concerns | Some differential attrition but reasonable sensitivity analyses conducted to demonstrate likely not a major concern; pilot study without clearly specified primary outcome or timepoint with multiple analyses conducted. | Not Applicable
Asbrand et al, 2020^67^ | Low | Some concerns | Low | Some concerns | Some concerns | Some concerns | Wait-list control so participants and interventionists were not masked and PROs were used. | Not Applicable
Atkinson et al, 2014^68^ | Low | Low | High | Low | Low | High | High and differential attrition. | High | High and differential attrition
Baer et al, 2005^69^ | High | High | Low | High | Low | High | | Not Applicable
Barrett et al, 1996^70^ | Some concerns | Some concerns | Some concerns | Low | Low | Some concerns | Potential for bias from attrition. | Not Applicable
Barrett et al, 1998^71^ | Some concerns | High | Low | Low | Low | High | | Not Applicable
Beidel et al, 2007^72^ | Some concerns | High | High | High | Low | High | | Not Applicable
Birmaher et al, 2003^73^ | Some concerns | Some concerns | Some concerns | Some concerns | Low | Some concerns | Differential attrition for side effects (disinhibition), potentially risking effective unmasking during outcome assessment, but the study notes that participants and staff had the same rate of accurate guesses of treatment across all arms. | Some concerns
Black et al, 1994^74^ | Some concerns | Low | Low | Some concerns | Low | Some concerns | | Not Applicable
Brent et al, 1997^49^ | Some concerns | High | High | High | Low | High | No patient or provider blinding, unknown outcome assessor blinding, high attrition, several in the study should have been ineligible. | High | High and possibly differential attrition, unblinded outcome assessors, participants and clinicians not blinded
Clarke et al, 2016^75^ | Some concerns | Some concerns | Low | Low | Low | Some concerns | Patient and provider not blinded; patients, parents, and clinical personnel awareness of treatment could influence outcomes. | Some concerns
Clarke et al, 2005^76^ | Some concerns | Some concerns | Some concerns | Low | Low | Some concerns | No allocation concealment and patients and providers not blinded. | Not Applicable
Clarke et al, 1999^45^ | Some concerns | Some concerns | High | Some concerns | Low | Some concerns | Randomization and allocation concealment not reported; patients not blinded, awareness of intervention could influence outcomes; high attrition and unknown differential attrition. | Not Applicable | Moderate attrition, no details on randomization or allocation concealment or blinding, awareness of intervention could influence outcomes
Cobham et al, 2017^77^ | Some concerns | Low | Low | Low | Low | Some concerns | | Not Applicable
Cobham et al, 2012^78^ | High | Some concerns | Low | Low | Some concerns | High | No allocation concealment. | Not Applicable
Cornacchio et al, 2019^79^ | Low | Some concerns | Low | Low | Low | Some concerns | Participants and therapists aware of treatment status. | Not Applicable
Cottrell et al, 2018^80^ | Low | Low | Low | Low | Low | Low | | Not Applicable
Diamond et al, 2002^81^ | Some concerns | Some concerns | Low | Some concerns | High | High | Awareness of intervention could influence outcomes. | High
Diamond et al, 2010^82^ | Low | Low | Low | Some concerns | Low | Some concerns | Outcome assessors not masked but administered PROs, not clinical interviews. Masking of intervention to patients and caregivers not feasible. | Not Applicable
Donovan et al, 2014^83^ | Low | Some concerns | High | Low | Low | Some concerns | Some concerns for all outcomes other than PAS, high ROB for PAS. | Not Applicable
Ehrenreich-May et al, 2017^84^ | Some concerns | Some concerns | Low | Some concerns | Some concerns | Some concerns | No information about randomization or allocation concealment; masking of participants and outcome assessment of PROs not feasible and wait-list control group, no prespecified analysis plan. | Not Applicable
Emslie et al, 2014^85^ | Low | Low | Some concerns | Low | Low | High | High and differential attrition. | High | High and differential attrition
Emslie et al, 2009^86^ | Some concerns | Low | Low | Low | Low | Some concerns | Awareness of the intervention could influence outcomes. No allocation concealment and patients and providers not blinded. | Not Applicable
Emslie et al, 2002^87^ | Some concerns | Low | High | Low | Low | High | High and differential attrition with LOCF for ITT without further investigation, no sensitivity analysis. Possible imbalance at baseline. | Not Applicable
Emslie et al, 1997^88^ | Some concerns | Low | High | Some concerns | Low | High | High and differential attrition. | High | High and differential attrition
Flannery-Schroeder et al, 2000^89^ | Some concerns | High | Low | High | Low | High | | Not Applicable
Fristad et al, 2019^90^ | Low | Some concerns | Low | Low | Low | Some concerns | Therapy not masked. | Low
Gallagher et al, 2004^91^ | Some concerns | High | Some concerns | High | Low | High | | Not Applicable
Ginsburg et al, 2020^92^ | Low | Low | Some concerns | Low | Some concerns | Some concerns | Nearly a quarter of data was missing at post treatment for some measures, imputed; no prespecified analysis plan. | Not Applicable
Green et al, 2011^93^ | Low | Low | Low | Low | Low | Low | Masking of intervention to participants and caregivers not feasible. | Not Applicable
Griffiths et al, 2019^94^ | Low | Low | Some concerns | Low | Some concerns | Some concerns | Some concerns for ED presentation for self-harm outcome; high concerns for all other outcomes because of >50% missing data at post treatment and beyond. | High | 5 AEs reported but no description of the events, only that they weren’t related to the study. Also not reported by group.
Hancock et al, 2018^41^ | Low | Some concerns | High | Low | Low | High | Differential attrition that likely influenced the results. | Not Applicable
Hazell et al, 2009^95^ | Low | Low | Low | Low | Low | Low | Masking of intervention to patients and caregivers not feasible. | Not Applicable
Hetrick et al, 2017^96^ | Low | Low | High | Low | Low | High | High concerns from differential and high attrition with no analysis of impact of missing data. | Not Applicable
Hill et al, 2019^97^ | Low | Low | Low | Low | Some concerns | Low | | Not Applicable
Hirshfeld-Becker et al, 2010^98^ | Low | Some concerns | Some concerns | Low | Low | Some concerns | | Not Applicable
Holmes et al, 2014^99^ | Some concerns | Some concerns | Low | Some concerns | Low | Some concerns | | Not Applicable
Hooven et al, 2012^100^ | Some concerns | Some concerns | Some concerns | Some concerns | Some concerns | Some concerns | No information about randomization, allocation concealment and minimal information about baseline characteristics; masking of caregivers not feasible and mostly PROs used, unclear whether some measures used are valid and reliable; attrition not reported by group; no prespecified analysis plan. | High
Infantino et al, 2016^101^ | Some concerns | High | Low | High | Low | High | | Not Applicable
Ingul et al, 2014^102^ | Low | Low | High | Low | Low | High | High attrition. | Not Applicable
Ishikawa et al, 2019^103^ | Low | Some concerns | Low | Low | Low | Some concerns | Some concerns due to fact that assignment to treatment is not masked. | Not Applicable
Kendall et al, 1997^104^ | Some concerns | High | High | High | Low | High | | Not Applicable
Kendall et al, 1994^105^ | Some concerns | High | Some concerns | High | Low | High | | Not Applicable
Khanna et al, 2010^106^ | High | High | Low | High | Low | High | | Not Applicable
King et al, 2015^107^ | Some concerns | Low | Low | Low | Some concerns | Some concerns | Some concerns because method of randomization not reported, unclear whether allocation concealment was adequate, minimal baseline characteristics presented to judge adequacy of randomization, no prespecified analysis plan. | Not Applicable
King et al, 2009^108^ | Low | Low | Some concerns | Low | Low | Some concerns | Modest attrition, unclear masking of participants and interventionists. | Not Applicable
Last et al, 1998^109^ | Some concerns | High | High | High | Low | High | | Not Applicable
Lau et al, 2010^110^ | Some concerns | Some concerns | Low | Some concerns | Some concerns | Some concerns | | Not Applicable
Luby et al, 2018^111^ | Some concerns | Some concerns | Low | Some concerns | Some concerns | Some concerns | Wait-list control prevented masking of participants and interventionists and PROs used; no prespecified analysis plan. | Not Applicable
Lyneham et al, 2006^112^ | Some concerns | Some concerns | Low | Some concerns | Low | Some concerns | | Not Applicable
March et al, 2004^113^ | Some concerns | Some concerns | Some concerns | Low | Low | Some concerns | High attrition, unclear allocation status, no patient blinding in some groups. | Some concerns | High attrition but no differential attrition, no specified outcome blinding or patient/intervention provider blinding reported.
March et al, 2009^114^ | Some concerns | High | Low | High | Low | High | | Not Applicable
Mehlum et al, 2014^115^ | Low | Low | Low | Low | Low | Low | | Not Applicable
Melfsen et al, 2011^116^ | Some concerns | High | High | High | Low | High | | Not Applicable
Mufson et al, 1999^117^ | Some concerns | Some concerns | High | Low | Low | High | Not blinded, high attrition, very large differential attrition. | High | High and differential attrition, awareness of intervention could influence outcomes
Mufson et al, 2004^118^ | Low | Low | Low | Low | Some concerns | Some concerns | No prespecified analysis plan. | Not Applicable
Nauta et al, 2003^119^ | High | Some concerns | Low | Some concerns | Some concerns | High | Did not follow an accepted strategy for randomization and allocation concealment, excluded some participants from being assigned to wait-list condition and baseline imbalances between the two active treatment groups, masking not feasible and use of PROs, no information about whether clinical outcome assessors were masked, no prespecified analysis plan. | Not Applicable
Öst et al, 2015^120^ | Low | Low | Some concerns | Some concerns | Low | Some concerns | | Not Applicable
Ougrin et al, 2013^121^ | Some concerns | Some concerns | Low | Low | Some concerns | Some concerns | Masking of clinicians not feasible, allocation concealment not possible and unclear whether clinicians were involved in recruitment; long term outcomes not part of original trial analysis plan. | Not Applicable
Perrin et al, 2019^122^ | Low | Low | Low | Some concerns | Low | Some concerns | | Not Applicable
Pincus et al, 2010^123^ | High | Some concerns | Low | Some concerns | Some concerns | High | Potential for randomization issues. | Not Applicable
Pine et al, 2001^124^ | Some concerns | Low | Some concerns | Low | Low | Some concerns | Potential for attrition bias. | Some concerns
Pineda et al, 2013^125^ | Low | Some concerns | Low | Low | Low | Some concerns | Masking not feasible. | Not Applicable
Rapee et al, 2006^126^ | Some concerns | High | High | High | Low | High | | Not Applicable
Richardson et al, 2014^127^ | Low | Low | Low | Low | Low | Low | | Low
Rossello et al, 1999^44^ | Some concerns | Some concerns | High | High | Some concerns | High | No ITT analyses conducted; randomization method not reported; blinding of assessors not reported; no group differences reported at baseline other than for outcomes so do not know how groups may have differed on sociodemographic characteristics, etc., and analyses were not adjusted. High and differential attrition. | Not Applicable
Rossouw et al, 2012^128^ | Low | Some concerns | Low | Low | Low | Some concerns | Treatment not masked (not feasible). | Some concerns | Treatment not masked (not feasible).
Rudy et al, 2017^129^ | Some concerns | Low | Low | Low | Some concerns | Some concerns | No information about method of randomization and allocation concealment and some imbalances at baseline that may be due to small sample size; no prespecified analysis plan. | Not Applicable
Rynn et al, 2001^130^ | Some concerns | Low | Low | Low | Low | Some concerns | | Not Applicable
Salzer et al, 2018^42^ | Low | Some concerns | Some concerns | Low | Low | Some concerns | High attrition and inability to blind participants or therapists. | Low
Sánchez-García et al, 2009^131^ | Some concerns | Some concerns | Low | Some concerns | Some concerns | Some concerns | Insufficient information to rate most domains. | Not Applicable
Santucci et al, 2013^132^ | Low | High | Low | High | Some concerns | High | | Not Applicable
Schneider et al, 2011^133^ | Some concerns | High | Low | High | Low | High | | Not Applicable
Pineda et al, 2013^125^ | Low | Some concerns | Low | Low | Low | Some concerns | Masking not feasible. | Not Applicable
Rapee et al, 2006^126^ | Some concerns | High | High | High | Low | High | | Not Applicable
Richardson et al, 2014^127^ | Low | Low | Low | Low | Low | Low | | Low
Rossello et al, 1999^44^ | Some concerns | Some concerns | High | High | Some concerns | High | No ITT analyses conducted; randomization method not reported; blinding of assessors not reported; no group differences reported at baseline other than for outcomes so do not know how groups may have differed on sociodemographic characteristics, etc., and analyses were not adjusted. High and differential attrition. | Not Applicable
Rossouw et al, 2012^128^ | Low | Some concerns | Low | Low | Low | Some concerns | Treatment not masked (not feasible). | Some concerns | Treatment not masked (not feasible).
Rudy et al, 2017^129^ | Some concerns | Low | Low | Low | Some concerns | Some concerns | No information about method of randomization and allocation concealment and some imbalances at baseline that may be due to small sample size; no prespecified analysis plan. | Not Applicable
Rynn et al, 2001^130^ | Some concerns | Low | Low | Low | Low | Some concerns | | Not Applicable
Salzer et al, 2018^42^ | Low | Some concerns | Some concerns | Low | Low | Some concerns | High attrition and inability to blind participants or therapists. | Low
Sánchez-García et al, 2009^131^ | Some concerns | Some concerns | Low | Some concerns | Some concerns | Some concerns | Insufficient information to rate most domains. | Not Applicable
Santucci et al, 2013^132^ | Low | High | Low | High | Some concerns | High | | Not Applicable
Schneider et al, 2011^133^ | Some concerns | High | Low | High | Low | High | | Not Applicable
Rynn et al, 2001^130^ | Some concerns | Low | Low | Low | Low | Some concerns | | Not Applicable
Salzer et al, 2018^42^ | Low | Some concerns | Some concerns | Low | Low | Some concerns | High attrition and inability to blind participants or therapists. | Low
Sánchez-García et al, 2009^131^ | Some concerns | Some concerns | Low | Some concerns | Some concerns | Some concerns | Insufficient information to rate most domains. | Not Applicable
Santucci et al, 2013^132^ | Low | High | Low | High | Some concerns | High | | Not Applicable
Schneider et al, 2011^133^ | Some concerns | High | Low | High | Low | High | | Not Applicable
Shortt et al, 2001^134^ | Some concerns | Low | Low | Some concerns | Low | Some concerns | No information on randomization and blinding of outcome assessors. | Some concerns
Silverman et al, 1999^135^ | Some concerns | Some concerns | High | Low | Low | High | Potential for attrition bias. | Not Applicable
Smith et al, 2014^136^ | Some concerns | Some concerns | High | Low | Low | High | Potential for attrition bias. | Not Applicable
Spence et al, 2017^137^ | Some concerns | High | Some concerns | High | Some concerns | High | | Not Applicable
Spence et al, 2006^138^ | Some concerns | High | Low | High | Low | High | | Not Applicable
Spence et al, 2000^139^ | Low | High | Low | High | Low | High | | Not Applicable
Spence et al, 2011^140^ | Some concerns | High | High | High | Low | High | | Not Applicable
Stjerneklar et al, 2019^141^ | Low | Some concerns | Low | Low | Low | Some concerns | Wait list control and no masking. Nothing reported on masking of assessors. However, in the discussion it does say that the masking of assessors was broken. | Not Applicable
Strawn et al, 2015^142^ | Low | Low | Some concerns | Low | Low | Some concerns | 77% attrition, ITT analyses performed. | Some concerns
Strawn et al, 2020^143^ | Low | Low | Some concerns | Low | Low | Some concerns | | Low
Tang et al, 2009^144^ | Some concerns | Some concerns | Some concerns | Low | Some concerns | Some concerns | Methods of randomization and allocation concealment not reported, no information about how many participants were analyzed or missing data; no prespecified analysis plan. | Not Applicable
Thirlwall et al, 2013^145^ | Low | Some concerns | Some concerns | Low | Low | Some concerns | Differential attrition, but sensitivity analyses suggest no difference. | Not Applicable
Tillfors et al, 2011^146^ | Some concerns | Some concerns | High | Some concerns | Low | High | Potential for differential attrition, lack of information on randomization, allocation concealment, and blinding. | Not Applicable
Topooco et al, 2018^147^ | Some concerns | Low | Low | Some concerns | Low | Some concerns | Risk of bias of outcome measurements showed some concern. | Low
Topooco et al, 2019^148^ | Low | Some concerns | Some concerns | Some concerns | Low | Some concerns | Some concerns for assignment to intervention and some concerns for measurement of outcome. | Low
Vigerland et al, 2016^149^ | Some concerns | High | Low | High | Low | High | | Not Applicable
Villabø et al, 2018^150^ | Low | Some concerns | Some concerns | Low | Some concerns | Some concerns | Youth and therapists aware of assignment; no information regarding whether trial analyzed in accordance with prespecified plan; no information about trial registry. | Not Applicable
Wagner et al, 2006^151^ | Some concerns | Some concerns | High | Some concerns | Low | Some concerns | High attrition but no differential attrition, no specified outcome blinding or patient/intervention provider blinding reported. | Some concerns | High overall attrition.
Waite et al, 2019^152^ | Some concerns | Some concerns | Some concerns | Some concerns | Low | Some concerns | Wait-list and no masking and missing data. | Low
Walkup et al, 2008^153^ | Low | Some concerns | Low | Low | Low | Some concerns | Participants assigned to combined sertraline and CBT were aware of their sertraline assignment. | Some Concerns | Participants assigned to combined sertraline and CBT were aware of their sertraline assignment
Warner et al, 2011^154^ | Some concerns | High | Low | High | Low | High | | Not Applicable
Waters et al, 2009^155^ | Some concerns | Some concerns | High | Low | Low | High | | Not Applicable
Weersing et al, 2017^156^ | Some concerns | Some concerns | Some concerns | Some concerns | Low | Some concerns | Masking of intervention not feasible. Potential for bias from differential attrition and issues with blinding in outcome assessment. | Not Applicable
Weihs et al, 2018^157^ | Some concerns | Low | Some concerns | Some concerns | Low | High | Unclear methods of randomization and allocation concealment, how ITT was done, whether outcome assessors were blinded. | Some concerns | Unclear methods of randomization and allocation concealment, how ITT was done, whether outcome assessors were blinded.
Wergeland et al, 2014^158^ | Some concerns | High | Low | High | Low | High | Potential for bias in randomization and outcome assessment. | Not Applicable
Wood et al, 2001^159^ | Low | Low | Low | Low | Low | Low | No information on missing data or how it was handled. | Not Applicable
Wuthrich et al, 2012^160^ | Some concerns | High | Low | High | Low | High | | Not Applicable

Abbreviations: AE=adverse event; CBT=cognitive behavioral therapy; ED=emergency department; ITT=intent to treat; LOCF=last observation carried forward; PAS=Preschool Anxiety Scale; PRO=patient-reported outcome; ROB\RoB=risk of bias.

Appendix D Table 3 Individual Study Quality Assessment of Meta-Analysis on the Risk of Bias Assessment Tool for Systematic Reviews (ROBIS)

Author Year | Study Eligibility Concern | Identification and Selection of Studies Concern | Data Collection and Study Appraisal Concern | Synthesis and Findings Concern | Risk of Bias
Cipriani et al, 2016^161^ | Low | Low | Low | Low | Low

Abbreviations: ROBIS=Risk of Bias Assessment Tool for Systematic Reviews.

Appendix D Table 4 Individual Study Quality Assessment of Diagnostic Accuracy Studies Based on the QUADAS-2 Tool Part 1

Author Year | Did the study adequately describe methods of patient selection? | Did the study describe the index test and describe how it was conducted and interpreted? | Did the study describe the reference standard and how it was conducted and interpreted? | Did the study describe any patients who did not receive the index test(s) and/or reference standard or who were excluded from the 2×2 table? | Did the study describe included patients (prior testing, presentation, use of index test and setting)? | Did the study describe the time interval and any interventions between index test(s) and reference standard?
Bailey et al, 2006^21^ | Yes | Yes | Yes | Yes | Yes | No
Canals et al, 2001^17^ | Yes | Yes | Yes | No | Yes | Yes
Canals et al, 2012^162^ | Yes | Yes | Yes | Yes | Yes | Yes
Christensen et al, 2015^15^ | Yes | Yes | Yes | Yes | Yes | Yes
Cunha et al, 2008^163^ | Yes | Yes | Yes | Yes | Yes | Unclear
Garcia-Lopez et al, 2015^164^ | Yes | Yes | Yes | Yes | Yes | No
Gardner et al, 2007^165^ | Yes | Yes | Yes | Unclear | Yes | Yes
Hopper et al, 2012^166^ | Yes | Yes | Yes | Yes | Yes | No
Johnson et al, 2002^13^ | Yes | Yes | Yes | Yes | Yes | Yes
Johnson et al, 2006^167^ | Yes | Yes | Yes | No | Yes | Yes
Katon et al, 2008^168^ | Yes | Yes | Yes | Yes | Yes | Yes
Muris et al, 2001^169^ | Yes | Yes | Yes | No | Yes | Yes
O’Connor et al, 2016^14^ | Yes | Yes | Yes | No | Yes | Yes
Patton et al, 1999^19^ | Yes | Yes | Yes | No | Yes | No
Queen et al, 2012^23^ | Yes | Yes | Yes | Yes | Yes | Yes
Ranta et al, 2007^170^ | Yes | Yes | Yes | Unclear | Yes | Yes
Ranta et al, 2012^171^ | Yes | Yes | Yes | Yes | Yes | Yes
Rivera-Riquelme et al, 2019^172^ | Yes | Yes | Unclear | Unclear | Yes | Yes
Roberts et al, 1991^16^ | Yes | Yes | Yes | Yes | Yes | Yes
Thompson et al, 1999^24^ | Yes | Yes | Yes | No | Yes | No
Tsai et al, 2009^173^ | Yes | Yes | Yes | Yes | Yes | Yes
Patton et al, 1999^19^ | Yes | Yes | Yes | No | Yes | Yes

Abbreviations: QUADAS-2=Quality Assessment of Diagnostic Accuracy Studies.

Appendix D Table 5 Individual Study Quality Assessment of Diagnostic Accuracy Studies Based on the QUADAS-2 Tool Part 2

Author Year | Was a consecutive or random sample of patients enrolled? | Were the index test results interpreted without knowledge of the results of the reference standard? | Is the reference standard likely to correctly classify the target condition? | Was there an appropriate interval between index test(s) and reference standard? | Was a case-control design avoided? | If a threshold was used, was it prespecified?
Bailey et al, 2006^21^ | Yes | Unclear | Yes | Unclear | Yes | No
Canals et al, 2001^17^ | Yes | Yes | Yes | Yes | Yes | No
Canals et al, 2012^162^ | No | Yes | Yes | Yes | Unclear | Yes
Christensen et al, 2015^15^ | Yes | Yes | Yes | Yes | Yes | No
Cunha et al, 2008^163^ | Unclear | Yes | Yes | Unclear | Yes | No
Garcia-Lopez et al, 2015^164^ | No | Unclear | Yes | Unclear | Yes | No
Gardner et al, 2007^165^ | No | Yes | Yes | Yes | Yes | Yes
Hopper et al, 2012^166^ | Yes | Yes | Yes | Unclear | Yes | No
Johnson et al, 2002^13^ | Yes | No | Yes | Yes | Yes | No
Johnson et al, 2006^167^ | Yes | Unclear | Unclear | Yes | Yes | Yes
Katon et al, 2008^168^ | Yes | Yes | Yes | Yes | Yes | Yes
Muris et al, 2001^169^ | No | Unclear | Yes | Yes | Yes | Yes
O’Connor et al, 2016^14^ | Yes | No | Unclear | Yes | Yes | No
Patton et al, 1999^19^ | Yes | Yes | Yes | Unclear | Yes | Unclear
Queen et al, 2012^23^ | Yes | Unclear | Yes | Yes | Yes | No
Ranta et al, 2007^170^ | Yes | Yes | Yes | Yes | Yes | Yes
Ranta et al, 2012^171^ | Yes | Unclear | Yes | Yes | Yes | Yes
Rivera-Riquelme et al, 2019^172^ | Yes | Yes | Yes | Yes | Yes | Yes
Roberts et al, 1991^16^ | Unclear | Yes | Yes | Unclear | Yes | No
Thompson et al, 1999^24^ | Yes | Yes | Yes | Unclear | Yes | Unclear
Tsai et al, 2009^173^ | Yes | Unclear | Yes | Yes | Yes | Unclear
Patton et al, 1999^19^ | Yes | Yes | Unclear | Yes | Yes | Unclear

Abbreviations: QUADAS-2=Quality Assessment of Diagnostic Accuracy Studies.

Appendix D Table 6 Individual Study Quality Assessment of Diagnostic Accuracy Studies Based on the QUADAS-2 Tool Part 3

Author Year | Were the reference standard results interpreted without knowledge of the results of the index test? | Did all patients receive a reference standard? | Did the study avoid inappropriate exclusions? | Did all patients receive the same reference standard? | Were all patients included in the analysis?
Bailey et al, 2006^21^ | Unclear | Yes | Yes | Yes | Yes
Canals et al, 2001^17^ | Yes | No | Yes | Yes | No
Canals et al, 2012^162^ | Yes | Yes | Unclear | Yes | Yes
Christensen et al, 2015^15^ | Yes | Yes | Yes | Yes | Unclear
Cunha et al, 2008^163^ | Yes | Yes | No | Yes | Yes
Garcia-Lopez et al, 2015^164^ | Unclear | Yes | Yes | Yes | Yes
Gardner et al, 2007^165^ | Yes | No | No | Yes | No
Hopper et al, 2012^166^ | Yes | No | Yes | Yes | No
Johnson et al, 2002^13^ | No | Yes | Yes | Yes | No
Johnson et al, 2006^167^ | No | No | Yes | No | No
Katon et al, 2008^168^ | Yes | Yes | Yes | Yes | No
Muris et al, 2001^169^ | Unclear | Yes | No | Yes | Yes
O’Connor et al, 2016^14^ | No | Yes | Yes | Yes | Yes
Patton et al, 1999^19^ | Unclear | No | Yes | Yes | No
Queen et al, 2012^23^ | Unclear | Yes | Yes | Yes | Yes
Ranta et al, 2007^170^ | Yes | No | Yes | Yes | No
Ranta et al, 2012^171^ | Unclear | Yes | Yes | Yes | Yes
Rivera-Riquelme et al, 2019^172^ | Yes | No | Yes | Yes | No
Roberts et al, 1991^16^ | Yes | Yes | Yes | Yes | Yes
Thompson et al, 1999^24^ | Unclear | No | Yes | Yes | No
Tsai et al, 2009^173^ | Unclear | Yes | Yes | Yes | Yes
Patton et al, 1999^19^ | Unclear | Yes | Yes | Yes | No

Abbreviations: QUADAS-2=Quality Assessment of Diagnostic Accuracy Studies.

Appendix D Table 7 Individual Study Quality Assessment of Diagnostic Accuracy Studies Based on the QUADAS-2 Tool, Part 4

Author Year | Could the selection of patients have introduced bias? | Could the conduct or interpretation of the index test have introduced bias? | Could the reference standard, its conduct, or interpretation have introduced bias? | Could the patient flow have introduced bias? | Are there concerns that the included patients do not match the review question?
Bailey et al, 2006^21^ | Unclear | Unclear | Unclear | Unclear | Unclear
Canals et al, 2001^17^ | No | Unclear | No | No | No
Canals et al, 2012^162^ | Yes | No | No | No | Yes
Christensen et al, 2015^15^ | No | Unclear | No | No | No
Cunha et al, 2008^163^ | Yes | Unclear | No | Unclear | Unclear
Garcia-Lopez et al, 2015^164^ | Unclear | Unclear | Unclear | Unclear | No
Gardner et al, 2007^165^ | Yes | No | No | Yes | Yes
Hopper et al, 2012^166^ | No | Unclear | No | Unclear | No
Johnson et al, 2002^13^ | Unclear | Yes | Yes | Yes | No
Johnson et al, 2006^167^ | No | Unclear | Yes | Yes | No
Katon et al, 2008^168^ | No | No | No | Unclear | No
Muris et al, 2001^169^ | Yes | Unclear | Unclear | No | No
O’Connor et al, 2016^14^ | No | Yes | Yes | No | Unclear
Patton et al, 1999^19^ | No | Unclear | Unclear | Unclear | No
Queen et al, 2012^23^ | Unclear | Yes | Unclear | No | No
Ranta et al, 2007^170^ | No | No | No | Unclear | No
Ranta et al, 2012^171^ | No | Unclear | Unclear | No | No
Rivera-Riquelme et al, 2019^172^ | No | No | No | Unclear | No
Roberts et al, 1991^16^ | Unclear | Unclear | No | Unclear | No
Thompson et al, 1999^24^ | No | Unclear | Unclear | Unclear | No
Tsai et al, 2009^173^ | No | Unclear | Unclear | Unclear | Yes
Patton et al, 1999^19^ | No | Unclear | Unclear | No | No

Abbreviations: QUADAS-2=Quality Assessment of Diagnostic Accuracy Studies.

Appendix D Table 8 Individual Study Quality Assessment of Diagnostic Accuracy Studies Based on the QUADAS-2 Tool Part 5

Author Year | Are there concerns that the index test, its conduct, or interpretation differ from the review question? | Are there concerns that the target condition as defined by the reference standard does not match the review question? | Overall Study Quality | Rationale for Overall Rating
Bailey et al, 2006^21^ | No | No | Fair | Only 99 participants (from the 1,470 that were randomly selected to participate) completed the full study so applicability uncertain. Blinding of index test and reference test results not reported, interval between testing NR, index test thresholds not prespecified.
Canals et al, 2001^17^ | No | No | Fair | Thresholds for index test were not prespecified.
Canals et al, 2012^162^ | No | No | Fair | Spectrum bias possible given the way the sample was selected (high and low scorers on the SCARED instrument administered the prior year).
Christensen et al, 2015^15^ | No | No | Fair | Index test thresholds not prespecified.
Cunha et al, 2008^163^ | No | No | Poor | Selection into this analysis based on results of prior tests/evaluations as part of a larger study, participants with and without diagnoses were selected, this analysis excluded all participants with a diagnosis of ADHD or other mood disorder, index test thresholds not prespecified, interval between index and reference test not specified.
Garcia-Lopez et al, 2015^164^ | No | No | Fair | Sample assembled based on scoring above a threshold on index test and then a random sample of those who scored below threshold; blinding of index test and referent tests not reported, interval of administration between index and reference test not reported, thresholds not prespecified.
Gardner et al, 2007^165^ | No | No | Poor | Sample was derived from a separate study that screened persons for entry into a study of anxiety and abdominal pain and mood disorders and mental health service use; thus, only children who screened positive on the SMFQ or SCARED were included thus high likelihood of spectrum bias. Children who did not screen positive did not receive a reference test, so sensitivity and specificity in an unselected primary care population cannot be determined.
Hopper et al, 2012^166^ | No | No | Fair | Index threshold not specified; interval between index and reference test NR; only a sample of the entire screened population received a reference test, but the sample selected appears to represent the spectrum of scores.
Johnson et al, 2002^13^ | No | No | Poor | Only a small proportion of those eligible actually participated in the study so although recruitment was consecutive, potential for selection bias. Several thresholds evaluated for index text, unclear timing between index screening test and clinical interview. Interviewers not masked to results of index text. Of 373 who agreed to participate, only 294 were included (78.9%), and no information is provided on those who were missing from the sample. The information on the index and reference standard were collected by the same interviewer during the telephone call, so the interviewer had knowledge of the index test and reference standard results.
Johnson et al, 2006^167^ | No | No | Poor | Only patients who had a positive screen received a clinical interview to confirm risk for suicide.
Katon et al, 2008^168^ | No | No | Fair | Participants with an interval between index and reference test of more than 18 days were excluded from the analysis.
Muris et al, 2001^169^ | No | No | Fair | Inappropriate exclusions of patients for the analysis; recruitment methods NR; whether results of index and reference tests were masked was NR.
O’Connor et al, 2016^14^ | No | No | Poor | Same interviewer administered the index test and reference standard so results not masked, thresholds for index test not prespecified, unclear that lay administers of reference standard with high school degree and 12 hours of training is equivalent to a clinician interview and diagnosis. Study specifically recruited children with asthma in addition to healthy children, so applicability to general population is uncertain.
Patton et al, 1999^19^ | No | No | Fair | Index test threshold seems to have been based on normative data; unclear whether reference test interviewers were blinded to the index test results; unclear interval between index and reference test; only a sample of participants from the full sample were selected to receive the reference test and unclear how that sample was selected; however, it appears the sample did include participants from the low and high spectrum of scores.
Queen et al, 2012^23^ | No | No | Fair | Thresholds for index test were not prespecified, unclear whether results of index and referent test were blinded, sample was enriched with some persons from specialty mental health settings.
Ranta et al, 2007^170^ | No | No | Fair | Not all screened persons received the reference test; all those who screened positive received reference test plus 2 participants who screened negative were selected randomly for the reference test for each person that screened positive.
Ranta et al, 2012^171^ | No | No | Fair | Blinding of index and reference test not reported, index test thresholds not prespecified.
Rivera-Riquelme et al, 2019^172^ | No | No | Fair | Only a sample of participants matched on sex scoring in the low and medium score ranges received the reference standard and were included in the analysis.
Roberts et al, 1991^16^ | No | No | Fair | Selection based on initial screening test scores, included all subjects above a prespecified threshold, and a random selection of participants from below the threshold; index test thresholds not prespecified, interval between index and reference test up to a month.
Thompson et al, 1999^24^ | Unclear | Unclear | Fair | Unclear threshold for MHI index test; interval between index and reference standard not specified; only a random sample of all persons screened received diagnostic reference standard.
Tsai et al, 2009^173^ | No | No | Fair | Index test did not have prespecified thresholds used, unclear whether index test was blinded to results of reference test.
Patton et al, 1999^19^ | Unclear | No | Fair | Unclear whether SRS thresholds for the risk group was established a priori, unclear whether interviewers were blinded to results of the SRS; two possible reference standards used (direct suicide risk, clinical risk assessment); SRS was embedded in larger survey so unclear how its validity may be different if used as a stand-alone instrument.

Abbreviations: ADHD=attention deficit hyperactivity disorder; MHI=Mental Health Index; NR=not reported; QUADAS-2=Quality Assessment of Diagnostic Accuracy Studies; SCARED=Screen for Anxiety Related Emotional Disorders; SMFQ=Short Mood and Feelings Questionnaire; SRS=Suicide Risk Screen.