# Appendix C Inclusion and Exclusion Criteria

Appendix C Table 1 Inclusion and Exclusion Criteria

Criteria | Include | Exclude
Condition definition | Major depressive disorder, as defined by DSM criteria (present in at least 50% of the enrolled study population); Anxiety disorders include generalized anxiety disorder, social anxiety disorder, panic disorder, agoraphobia, separation anxiety disorder, and selective mutism; Definitions for increased risk of suicide may vary by study but may include suicidal ideation (suicidal thoughts or plan for suicide), history of suicide attempts (nonfatal, self-directed, and potentially injurious behavior that is intended to result in death), and deliberate self-harm; Included studies may address these conditions individually or in combination | Other mental health disorders (e.g., obsessive compulsive disorder, posttraumatic stress disorder, psychotic disorders, bipolar disorder, cyclothymia, adjustment disorder with depressed mood), persistent depressive disorder/dysthymia, disruptive mood dysregulation disorder, premenstrual dysphoric disorder, substance/medication-induced depressive disorder, depressive disorder due to another medical condition, and depression not otherwise specified; substance/medication-induced anxiety disorder, anxiety disorder due to another medical condition, and anxiety not otherwise specified
Population | KQs 1–3: Children and adolescents (mean age ≤18 years). Studies may include:; - Unselected primary care population; - Primary care patients without known depression, anxiety disorders, or increased risk of suicide (including deliberate self-harm); - Comparable community-based population; KQs 4, 5: Children and adolescents (age ≤18 years) with major depressive disorder, anxiety disorders, or increased risk of suicide; A priori priority populations of interest include by age (children vs. adolescents), race/ethnicity, sex, gender identity, and sexuality | - Adults (age ≥19 years); - Studies in which more than 50% of the population are age 19 years or older; - Studies limited to populations that are not broadly generalizable to primary care populations (e.g., populations with mental health conditions other than anxiety, depression, and increased suicide risk); persons with treatment-resistant depression or anxiety; persons in residential, institutional, or inpatient settings; persons with developmental disorders (e.g., autism spectrum disorder, ADHD); persons in the midst of a suicidal crisis that are identified through their use of healthcare services related to a suicide attempt (e.g., in the emergency department); studies that require patients to have a specific clinical condition for enrollment (e.g., cancer, chronic illness, epilepsy)
Interventions | KQs 1–3: Screening interventions with or without additional provider or patient-facing elements such as referral support, treatment guidelines, symptoms monitoring, and standardized treatment. Screening tools must be brief standardized instruments designed to identify persons with major depressive disorder, anxiety disorders, or an increased risk of suicide; self-report with or without parental report, clinician administered, or electronically delivered (<5 minutes if clinician administered, <15 minutes if self-administered) instruments are eligible; KQs 4, 5 (depression and suicide):; - Counseling (e.g., psychotherapy, psychoeducation, suicide means restriction); - Care delivery models targeting improved mental health outcomes (e.g., collaborative care, care management); - Pharmacotherapy agents approved for pediatric use (e.g., duloxetine, fluoxetine, escitalopram, sertraline, fluvoxamine), generally first-line; - Include combination therapies; KQs 4, 5 (anxiety):; - Cognitive behavioral therapy (including exposure therapy)^*^; - Include eligible psychotherapy studies regardless of mode of intervention; - Pharmacotherapy agents approved for pediatric use (e.g., clonidine, duloxetine, fluoxetine, escitalopram, sertraline, fluvoxamine), generally first-line; - Include combination therapies | KQs 1–3: Studies reporting on a screening instrument that does not have established validity and scoring mechanism or thresholds for use within clinical practice; KQs 4, 5 (all disorders): Other treatment modalities (e.g., exercise, light therapy, transcranial magnetic nerve stimulation, electroshock treatment, diet and herbal supplements such as St. John’s wort and other complementary and alternative medicine, social marketing, policy, system-level interventions, or adjunctive agents to enhance the effects of antidepressants); Interventions involving components that could not be replicated in most healthcare settings, including environmental components (media messages, public signage), interventions on groups in closed (preexisting) social networks (e.g., in daycares, schools), or those requiring the parent to have the target condition; Pharmacotherapeutic agents that are not FDA approved for pediatric use (e.g., paroxetine, vortioxetine); KQs 4, 5 (anxiety): Psychotherapy other than cognitive behavioral therapy
Comparators | KQs 1, 3 (screening): Usual care/no screening; KQ 2 (depression and anxiety): Clinical diagnosis based on structured clinical interview by qualified professional using standard diagnostic criteria in place at the time of the study (e.g., DSM-IV or DSM-5); KQ 2 (suicide): Assessment of increased suicide risk based on clinical interview by qualified professional; KQs 4, 5 (psychotherapy and care delivery):; - No intervention; - Wait-list control (i.e., delayed treatment); - Attention control (i.e., receives interpersonal interaction but no other elements of the active intervention); - Usual care (e.g., referral to treatment, non-standardized treatment, or unclear treatment services); KQs 4, 5 (suicide risk only): Treatment as usual (the provision of standard treatment services not governed by a study protocol, but at a duration and level of intensity consistent with active treatment interventions) are also eligible; KQs 4, 5 (pharmacotherapy): Placebo (including placebo along with psychotherapy, when compared with the active agent plus the same psychotherapy intervention (e.g., CBT plus placebo vs. CBT plus medication would be eligible) | KQs 1, 3: No comparator; KQ 2: Another screening instrument, non-standardized clinical diagnosis (i.e., diagnosis not made based on existing DSM criteria at the time of the study); KQs 4, 5: No comparator, active intervention (i.e., comparative effectiveness) (e.g., medication X vs. medication Y would not be eligible. CBT plus medication X vs. CBT plus medication Y would not be eligible); KQ 4, 5 (anxiety and depression): Treatment as usual comparator groups where the comparator group receives standard treatment services that involve a reasonably standardized active intervention provided outside of a study protocol are not eligible
Outcomes | KQs 1, 4:; - Depression or anxiety symptoms, remission or diagnosis, or response; - Suicide deaths, suicide attempts and deliberate self-harm, or suicidal ideation; - All-cause mortality; - Quality of life measured using validated scales or instruments; - Functioning (using validated scales or instruments, days of missed school); KQ 2:; - Sensitivity, specificity, or data to calculate one or both; - Negative predictive value, positive predictive value, area under the curve/ area under the receiver operating characteristic/receiver operating characteristic, diagnostic odds/likelihood ratios, Youden’s index; KQ 3:; - False alarm; - False reassurance; KQs 3, 5:; - Treatment avoidance; - Deterioration in patient-provider relationship; - Labeling or stigma; - Inappropriate/unnecessary treatment; KQ 5 (pharmacotherapy only):; - Serious adverse effects; - Withdrawals due to adverse effects; - Suicidality | All KQs: All other outcomes
Outcome assessment timing | No minimum followup | Not applicable
Setting | KQs 1–3:; Recruitment of participants from:; - Primary care settings (e.g., pediatrics, family medicine, or school-based health clinics); - Virtual or community settings such as schools, if population comparable to general primary care (i.e., focus on “healthy” children or adolescents, or broad spectrum of medical and mental health conditions in rates comparable to primary care setting)^†^; - General emergency departments; KQs 4, 5:; Treatment in:; - Primary care or specialty clinics, including school-based health clinics; - Virtual or community-based settings; - General EDs are eligible for recruitment of patients to an intervention; however, interventions delivered solely/entirely within an ED setting are not eligible | KQ 1: Studies conducting school-wide or community-wide screening are not eligible.; KQs 1–3:; - Referred or established patients at mental health clinics; - Inpatient/residential facilities; - Correctional facilities; - Psychiatric emergency departments; KQs 4, 5:; Treatment in:; - Correctional facilities; - Schools involving school-wide interventions; - Inpatient/residential facilities; - Psychiatric emergency departments
Study design | KQs 1, 3: RCTs, CCTs; KQ 2: Studies of diagnostic test accuracy^ǂ^; KQ 3: RCTs, CCTs, observational studies; KQ 4: RCTs; KQ 5:; - RCTs; - Systematic reviews of comparative cohort and case-control observational studies; - Harms of pharmacotherapy only: large (>1,000 participants) comparative cohort and case-control observational studies published after identified systematic reviews that include observational studies | All other study designs; KQ 2: Psychometric development and internal (e.g., split sample) validation studies of new instruments; case-control studies (i.e., designs that limit the study sample to only those with and without known mental health symptoms); KQs 1–4: Systematic reviews of RCTs (reviews will only be used to identify relevant studies)
Study geography | Primary studies that primarily take place in countries categorized as “Very High” on the 2019 Human Development Index (as defined by the United Nations Development Programme) | Reviews in which >50% of included studies take place in countries not categorized as “Very High” on the Human Development Index
Publication language | English | Any language other than English
Quality rating | Fair- or good-quality studies | Poor-quality studies

* We summarized the effect of other non-CBT interventions for anxiety as a contextual question, using a best-evidence approach.

† We intended to restrict inclusion of school-based recruitment to studies conducting the screening in other settings (e.g., mental health clinics) but on review of studies, elected to include all studies using a school-based recruitment because of the difficulty of ascertaining the location of screening in some studies.

ǂ We cataloged all studies reporting on instruments that otherwise meet all eligibility criteria, but our synthesis will focus on the instruments that are reported in more than one study.

Abbreviations: ADHD=attention deficit hyperactivity disorder; AUC=area under the curve; AUROC=area under the receiver operating characteristic; CBT=cognitive behavioral therapy; CCT=controlled, clinical trial; DSM=Diagnostic and Statistical Manual of Mental Disorders; ED=emergency department; FDA=U.S. Food and Drug Administration; KQ=key question; NPV=negative predictive value; PPV=positive predictive value; RCT=randomized, controlled trial; ROC=receiver operating characteristic.