# Appendix B Search Strategies

## MEDLINE^®^ via PubMed

Suicide Risk: January 1, 2012, through April 28, 2020

Anxiety: January 1, 2017 to April 28, 2020

Depression: June 1, 2012 to April 28, 2020

Search | Query | Results
1 | “Depressive Disorder”[MeSH] OR “Depressive Disorder, Major”[MeSH] OR Depression[MeSH] OR depress*[Title/Abstract] OR depression[Title/Abstract] OR depressive[Title/Abstract] OR depressed[Title/Abstract] OR “Dysthymic Disorder”[Mesh] OR dysthymia OR dysthymic OR “Persistent Depressive Disorder”[ALL FIELDS] | 496,379
2 | Mass Screening[MeSH] OR screen[tiab] OR screening[tiab] OR screened[tiab] OR screens[tiab] OR “case finding”[tiab] OR casefinding[tiab] OR “beck depression inventory” OR “beck depression inventories” OR “Center for Epidemiologic Studies Depression Scale”[All Fields] OR “Center for Epidemiologic Studies Depression Scales”[All Fields] OR “depression inventory”[tiab] OR “depression inventories”[tiab] OR “depression scale”[tiab] OR “depression scales”[tiab] OR “depression rating scale”[tiab] OR “depression rating scales”[tiab] OR Kutcher*[tiab] OR “mood and feelings questionnaire”[All Fields] OR “mood and feelings questionnaires”[All Fields] OR “Patient Health Questionnaire-Adolescent Version”[All Fields] OR Reynold*[tiab] OR “self report rating scale”[All Fields] OR “self report rating scales”[All Fields] OR BDI[tiab] OR CES-D[tiab] OR ChilD-S[tiab] OR DesTeen[tiab] OR MFQ-SF[tiab] OR PHQ-2[tiab] OR PHQ-A[tiab] OR RCDS[tiab] | 862,015
3 | #1 AND #2 | 69,492
4 | #1 AND #2 Filter: from 2015 - 2020 | 26,844
5 | #1 AND #2 Filter: English, from 2015 - 2020 | 26,092
6 | #1 AND #2 Filter: English, Child: birth-18 years, from 2015 - 2020 | 4,688
7 | adolescen*[tiab] OR boys[tiab] OR child*[tiab] OR children[tiab] OR girls[tiab] OR pediatric[tiab] OR paediatric*[tiab] OR teen[tiab] OR teens[tiab] OR teenage[tiab] OR teenaged[tiab] OR teenager*[tiab] OR toddler*[tiab] | 1,737,521
8 | #5 AND #7 | 4,576
9 | #6 OR #8 | 6,839
10 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case reports”[pt] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR congress[pt] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] or horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | 10,206,468
11 | #9 NOT #10 | 6,741
12 | “Anti-Anxiety Agents”[Mesh] OR “Antidepressive Agents”[MeSH] OR “Serotonin Uptake Inhibitors”[MeSH] OR “Tranquilizing Agents”[Mesh] OR antidepressant*[tiab] OR “antidepressives”[tiab] OR “antidepressive agents”[tiab] OR “antidepressive drug”[tiab] OR “antidepressive drugs”[tiab] OR “norepinephrine reuptake inhibitor”[all fields] OR “norepinephrine reuptake inhibitors”[all fields] OR “selective serotonin reuptake inhibitor”[tiab] OR “selective serotonin reuptake inhibitors”[tiab] OR ssri[tiab] OR ssris[tiab] OR “serotonin norepinephrine reuptake inhibitor”[All Fields] OR “serotonin norepinephrine reuptake inhibitors”[All Fields] OR snri*[All Fields] OR “TCA antidepressants”[All Fields] OR “tricyclic antidepressant”[All Fields] OR “tricyclic antidepressants”[All Fields] OR anafranil[All Fields] OR celexa[tiab] OR Citalopram[MeSH] OR citalopram[tiab] OR clomipramine[MeSH] OR clomipramine[tiab] OR “duloxetine”[Mesh] OR duloxetine[tiab] OR escitalopram[tiab] OR Fluoxetine[MeSH] OR fluoxetine[tiab] OR Fluvoxamine[MeSH] OR fluvoxamine[tiab] OR ketamine[MeSH] OR ketamine[tiab] OR Lexapro[tiab] OR “Lithium Compounds/therapeutic use”[Mesh] OR lithium[tiab] OR luvox[tiab] OR Sertraline[MeSH] OR sertraline[tiab] OR Zoloft[tiab] | 246,639
13 | #1 AND #12 | 68,565
16 | “Behavior Therapy”[MeSH] OR “Cognitive Behavioral Therapy”[Mesh] OR “Combined Modality Therapy”[Mesh] OR Counseling[MeSH] OR “Delivery of Health Care, Integrated”[Mesh] OR “Directive Counseling”[MeSH] OR “Family Therapy”[MeSH] OR “Parents/education”[MeSH] OR “Patient Care Management”[Mesh] OR “Problem Solving”[MeSH] OR Psychotherapy[MeSH] OR “Psychotherapy, Group”[MeSH] OR “Risk Reduction Behavior”[Mesh] OR “Self-Help Groups”[MeSH] OR (behavior*[tiab] AND (therap*[tiab] or treatment*[tiab] OR intervention*[tiab])) OR CBT[tiab] OR (cognitive[tiab] AND (therap*[tiab] OR treatment*[tiab] OR intervention*[tiab])) OR “care delivery”[tiab] OR “care management”[tiab] OR “collaborative care”[tiab] OR “combination therapy”[tiab] OR “combined modality”[tiab] OR counsel*[tiab] OR “delivery of care”[tiab] OR “dialectical behavior therapy”[All fields] OR “family therapy”[tiab] OR “family support”[tiab] OR interpersonal therap*[tiab] OR interpersonal intervention*[tiab] OR “means restriction”[tiab] OR “means restrictions”[All Fields] OR “mentalization therapy”[All fields] OR (parent*[tiab] AND education[tiab]) OR “problem solving”[tiab] OR “psychoeducation”[tiab] OR psychotherap*[tiab] OR (risk*[tiab] AND reduc*[tiab]) OR “self help”[tiab] | 2,120,901
17 | #1 AND #16 | 99,177
18 | #13 OR #17 | 148,472
19 | #13 OR #17 Filter: from 2015 - 2020 | 44,779
20 | #13 OR #17 Filter: English, from 2015 - 2020 | 43,229
21 | #13 OR #17 Filter: English, Child: birth-18 years, from 2015 - 2020 | 6,611
22 | #20 AND #7 | 6,389
23 | #21 OR #22 | 9,511
24 | #23 NOT #10 | 8,910
25 | “cochrane database syst rev”[ta] OR “systematic review”[ti] OR “meta-analysis”[pt] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “systematic literature review”[ti] OR (“systematic review”[tiab] AND review[pt]) OR “this systematic review”[tw] OR “umbrella review”[tiab] | 270,232
26 | #24 AND #25 | 543
27 | #24 NOT #26 | 8,367
29 | “Anxiety Disorders”[Mesh] OR “Anxiety”[Mesh] OR agoraphobia OR anxiety[ti] OR “generalized anxiety disorder” OR mutism OR “panic disorder” OR phobia* OR “separation anxiety disorder” OR “social anxiety disorder” | 169,198
30 | “Mass Screening”[MeSH] OR screen[tiab] OR screening[tiab] OR screened[tiab] OR screens[tiab] OR “case finding”[tiab] OR casefinding[tiab] OR “Children’s Manifest Anxiety Scale”[All Fields] OR “Multidimensional Anxiety Scale for Children”[All Fields] OR “Pediatric Anxiety Rating Scale”[All Fields] OR “Revised Children’s Manifest Anxiety Scale”[All Fields] OR “Screen for Child Anxiety Related Disorders”[All Fields] OR “Spence’s Children’s Anxiety Scale”[All Fields] OR “State-Trait Anxiety Inventory for Children”[All Fields] OR “Youth Anxiety Measure for DSM-5”[All Fields] OR MASC[tiab] OR “MASC-2 SR”[All Fields] OR MASC-10[tiab] OR PARS[tiab] OR RCMAS[tiab] OR SCARED[tiab] OR SCAS[tiab] OR SCAS-8[tiab] OR STAIC[tiab] OR STAIC-S[tiab] OR YAM-5[tiab] | 802,488
31 | #29 AND #30 | 8,121
32 | #29 AND #30 Filter: English | 7,694
33 | #29 AND #30 Filter: English, Child: birth-18 years | 2,684
34 | #32 AND #7 | 1,992
35 | #33 OR #34 | 3,092
36 | #35 NOT #10 | 3,010
37 | #29 AND #12 | 16,939
39 | #29 AND #16 | 45,405
40 | #37 OR #39 | 56,846
41 | #37 OR #39 Filter: English | 50,283
42 | #37 OR #39 Filter: English, from 2017 - 2020 | 8,320
43 | #37 OR #39 Filter: English, Child: birth-18 years, from 2017 - 2020 | 1,986
44 | #42 AND #7 | 1,818
45 | #43 OR #44 | 2,619
46 | #45 NOT #10 | 2,389
47 | #46 AND #25 | 147
48 | #46 NOT #47 | 2,242
49 | “Suicide”[Mesh] OR “Suicide, Attempted”[Mesh] OR “Suicide, Completed”[Mesh] OR “Suicidal Ideation”[Mesh] OR parasuicid*[ti] OR “self harm”[ti] OR “Self-Injurious Behavior”[Mesh] OR suicid*[ti] | 77,404
50 | “Mass Screening”[MeSH] OR screen[tiab] OR screening[tiab] OR screened[tiab] OR screens[tiab] OR “case finding”[tiab] OR casefinding[tiab] OR “Adapted-SAD PERSONS”[All Fields] OR “Beck Hopelessness Scale”[All Fields] OR “Beck Scale for Suicide Ideation”[All Fields] OR “Center for Epidemiologic Studies-Depression Scale”[All Fields] OR “Child Suicide Assessment”[All Fields] OR “Columbia Suicide Severity Rating Scale”[All Fields] OR “Columbia Teen Screen”[All Fields] OR “Firestone Assessment of Self-Destructive Thoughts”[All Fields] OR “Harkavy Asnis Suicide Survey”[All Fields] OR “Inventory for Suicidal Ideation”[All Fields] OR “Multi-attitude Suicide Tendency Scale for Adolescents”[All Fields] OR “Paykel Suicide Items”[All Fields] OR “Positive and Negative Suicide Ideation Inventory”[All Fields] OR “Scale for Suicide Ideation”[All Fields] OR “Self-harm behavior questionnaire”[All Fields] OR “Suicide Behaviors Questionnaire”[All Fields] OR “Suicidal Ideation Questionnaire”[All Fields] OR “Suicidality Occurring in Paediatrics-Suicidality Assessment Scale”[All Fields] OR “Suicide Assessment Five-Step Evaluation and Triage”[All Fields] OR “Suicide Probability Scale”[All Fields] OR BSI[tiab] OR CES-D[tiab] OR CSA[tiab] OR C-SSSR[tiab] OR CTS[tiab] OR HASS-II[tiab] OR ISO-30[tiab] OR PANSI[tiab] OR SSI[tiab] OR SHBQ[tiab] OR SBQ-14[tiab] OR SBQ-C[tiab] OR SIQ[tiab] OR SIQ-Junior[tiab] OR STOP-SAS[tiab] OR SAFE-T[tiab] OR SPS[tiab] OR SRS[tiab] | 837,759
51 | #49 AND #50 | 3,485
52 | #49 AND #50 Filter: English | 3,320
53 | (“2012/06/01”[Date - Publication] : “2020/12/31”[Date - Publication]) Filter: English | 8,460,381
54 | #52 AND #53 | 1,951
55 | #52 AND #53 Filter: Child: birth-18 years | 681
56 | #54 AND#7 | 235
57 | #55 OR #56 | 810
58 | #57 NOT #10 | 786
59 | #49 AND #12 | 4,971
60 | #49 AND #16 | 15,458
61 | #59 OR #60 | 18,818
62 | #59 OR #60 Filter: English | 16,713
63 | #62 AND #53 Filter: English | 6,314
64 | #62 AND #53 Filter: English, Child: birth-18 years | 2,143
65 | #63 AND #7 | 1,511
66 | #64 OR #65 | 2,569
67 | #66 NOT #10 | 2,403
68 | #67 AND #25 | 102
69 | #67 NOT #68 | 2,301
70 | “Pediatric Symptom Checklist-17” OR PSC[tiab] OR “Revised Children’s Anxiety and Depression Scale”[All Fields] OR RCADS[tiab] OR RCADS-25[tiab] OR “Strength and Difficulties Questionnaires”[All Fields] OR SDQ[tiab] | 8,116
71 | (#1 OR #29 OR #49) AND #70 | 432
72 | (#1 OR #29 OR #49) AND #70 Filter: English | 421
73 | (#1 OR #29 OR #49) AND #70 Filter: English, Child: birth-18 years | 231
74 | #72 AND #7 | 284
75 | #73 OR #74 | 306
76 | #75 NOT #10 | 300

## Cochrane Library

Suicide Risk: January 1, 2012, through April 28, 2020

Anxiety: January 1, 2017 to April 28, 2020

Depression: June 1, 2012 to April 28, 2020

Search | Query | Results
1 | [mh “Depressive Disorder”] or [mh “Depressive Disorder, Major”] or [mh Depression] or depress*:ti,ab or depression:ti,ab or depressive:ti,ab or depressed:ti,ab or [mh “Dysthymic Disorder”] or dysthymia:ti,ab,kw or dysthymic:ti,ab,kw or “Persistent Depressive Disorder”:ti,ab,kw | 75575
2 | [mh “Mass Screening”] OR screen:ti,ab OR screening:ti,ab OR screened:ti,ab OR screens:ti,ab OR “case finding”:ti,ab OR casefinding:ti,ab OR “beck depression inventory” OR “beck depression inventories” OR “Center for Epidemiologic Studies Depression Scale”:ti,ab,kw OR “Center for Epidemiologic Studies Depression Scales”:ti,ab,kw OR “depression inventory”:ti,ab OR “depression inventories”:ti,ab OR “depression scale”:ti,ab OR “depression scales”:ti,ab OR “depression rating scale”:ti,ab OR “depression rating scales”:ti,ab OR Kutcher*:ti,ab OR “mood and feelings questionnaire”:ti,ab,kw OR “mood and feelings questionnaires”:ti,ab,kw OR “Patient Health Questionnaire-Adolescent Version”:ti,ab,kw OR Reynold*:ti,ab OR “self report rating scale”:ti,ab,kw OR “self report rating scales”:ti,ab,kw OR BDI:ti,ab OR CES-D:ti,ab OR ChilD-S:ti,ab OR DesTeen:ti,ab OR MFQ-SF:ti,ab OR PHQ-2:ti,ab OR PHQ-A:ti,ab OR RCDS:ti,ab | 82010
3 | #1 AND #2 | 20931
4 | Address:pt OR “autobiography”:pt OR “bibliography”:pt OR “biography”:pt OR “case control” OR “case report” OR “case reports” OR “case series” OR “comment”:pt OR “comment on” OR congress:pt OR “cross-sectional” OR “dictionary”:pt OR “directory”:pt OR “editorial”:pt OR “festschrift”:pt OR “historical article”:pt OR “interview”:pt OR lecture:pt OR “legal case”:pt OR “legislation”:pt OR letter:pt OR “news”:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR “retrospective cohort” OR ([mh “Animals”] NOT [mh “Humans”]) OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae | 64667
5 | #3 NOT #4 | 20194
6 | MeSH descriptor: [Child] explode all trees | 2623
7 | MeSH descriptor: [Infant] explode all trees | 16136
8 | MeSH descriptor: [Adolescent] explode all trees | 101062
9 | adolescen*:ti,ab OR boys:ti,ab OR child*:ti,ab OR children:ti,ab OR girls:ti,ab OR pediatric:ti,ab OR paediatric*:ti,ab OR teen:ti,ab OR teens:ti,ab OR teenage:ti,ab OR teenaged:ti,ab OR teenager*:ti,ab OR toddler*:ti,ab | 146691
10 | #6 OR #7 OR #8 OR #9 | 235130
11 | #5 AND #10 | 3330
12 | [mh “Anti-Anxiety Agents”] OR [mh “Antidepressive Agents”] OR [mh “Serotonin Uptake Inhibitors”] OR [mh “Tranquilizing Agents”] OR antidepressant*:ti,ab OR “antidepressives”:ti,ab OR “antidepressive agents”:ti,ab OR “antidepressive drug”:ti,ab OR “antidepressive drugs”:ti,ab OR “norepinephrine reuptake inhibitor”:ti,ab,kw OR “norepinephrine reuptake inhibitors”:ti,ab,kw OR “selective serotonin reuptake inhibitor”:ti,ab OR “selective serotonin reuptake inhibitors”:ti,ab OR ssri:ti,ab OR ssris:ti,ab OR “serotonin norepinephrine reuptake inhibitor”:ti,ab,kw OR “serotonin norepinephrine reuptake inhibitors”:ti,ab,kw OR snri*:ti,ab,kw OR “TCA antidepressants”:ti,ab,kw OR “tricyclic antidepressant”:ti,ab,kw OR “tricyclic antidepressants”:ti,ab,kw OR anafranil:ti,ab,kw OR celexa:ti,ab OR [mh Citalopram] OR citalopram:ti,ab OR [mh clomipramine] OR clomipramine:ti,ab OR [mh duloxetine] OR duloxetine:ti,ab OR escitalopram:ti,ab OR [mh Fluoxetine] OR fluoxetine:ti,ab OR [mh Fluvoxamine] OR fluvoxamine:ti,ab OR [mh ketamine] OR ketamine:ti,ab OR Lexapro:ti,ab OR [mh “Lithium Compounds”/TU] OR lithium:ti,ab OR luvox:ti,ab OR [mh Sertraline] OR sertraline:ti,ab OR Zoloft:ti,ab | 35486
13 | #1 AND #12 | 16373
14 | [mh “Behavior Therapy”] OR [mh “Cognitive Behavioral Therapy”] OR [mh “Combined Modality Therapy”] OR [mh Counseling] OR [mh “Delivery of Health Care, Integrated”] OR [mh “Directive Counseling”] OR [mh “Family Therapy”] OR [mh “Parents”/ED] OR [mh “Patient Care Management”] OR [mh “Problem Solving”] OR [mh Psychotherapy] OR [mh “Psychotherapy, Group”] OR [mh “Risk Reduction Behavior”] OR [mh “Self-Help Groups”] OR (behavior*:ti,ab AND (therap*:ti,ab or treatment*:ti,ab OR intervention*:ti,ab)) OR CBT:ti,ab OR (cognitive:ti,ab AND (therap*:ti,ab OR treatment*:ti,ab OR intervention*:ti,ab)) OR “care delivery”:ti,ab OR “care management”:ti,ab OR “collaborative care”:ti,ab OR “combination therapy”:ti,ab OR “combined modality”:ti,ab OR counsel*:ti,ab OR “delivery of care”:ti,ab OR “dialectical behavior therapy”:ti,ab,kw OR “family therapy”:ti,ab OR “family support”:ti,ab OR interpersonal therap*:ti,ab OR interpersonal intervention*:ti,ab OR “means restriction”:ti,ab OR “means restrictions”:ti,ab,kw OR “mentalization therapy”:ti,ab,kw OR (parent*:ti,ab AND education:ti,ab) OR “problem solving”:ti,ab OR “psychoeducation”:ti,ab OR psychotherap*:ti,ab OR (risk*:ti,ab AND reduc*:ti,ab) OR “self help”:ti,ab | 242343
15 | #1 AND #14 | 29310
16 | #13 OR #15 | 4188
17 | #16 AND #10 | 7668
18 | #17 NOT (clinicaltrials or trialsearch):so | 5975
19 | #11 NOT (clinicaltrials or trialsearch):so | 2345
20 | [mh “Anxiety Disorders”] OR [mh “Anxiety”] OR agoraphobia OR anxiety:ti OR “generalized anxiety disorder” OR mutism OR “panic disorder” OR phobia* OR “separation anxiety disorder” OR “social anxiety disorder” | 23453
21 | [mh “Mass Screening”] OR screen:ti,ab OR screening:ti,ab OR screened:ti,ab OR screens:ti,ab OR “case finding”:ti,ab OR casefinding:ti,ab OR “Children’s Manifest Anxiety Scale”:ti,ab,kw OR “Multidimensional Anxiety Scale for Children”:ti,ab,kw OR “Pediatric Anxiety Rating Scale”:ti,ab,kw OR “Revised Children’s Manifest Anxiety Scale”:ti,ab,kw OR “Screen for Child Anxiety Related Disorders”:ti,ab,kw OR “Spence’s Children’s Anxiety Scale”:ti,ab,kw OR “State-Trait Anxiety Inventory for Children”:ti,ab,kw OR “Youth Anxiety Measure for DSM-5”:ti,ab,kw OR MASC:ti,ab OR “MASC-2 SR”:ti,ab,kw OR MASC-10:ti,ab OR PARS:ti,ab OR RCMAS:ti,ab OR SCARED:ti,ab OR SCAS:ti,ab OR SCAS-8:ti,ab OR STAIC:ti,ab OR STAIC-S:ti,ab OR YAM-5:ti,ab | 66544
22 | #20 AND #21 | 1372
23 | #22 AND #10 | 503
24 | #23 NOT (clinicaltrials or trialsearch):so | 345
25 | #20 AND (#12 OR #14) | 12437
26 | #25 AND #10 | 3535
27 | #26 NOT (clinicaltrials or trialsearch):so | 3022
28 | [mh “Suicide”] OR [mh “Suicide, Attempted”] OR [mh “Suicide, Completed”] OR [mh “Suicidal Ideation”] OR parasuicid*:ti OR “self harm”:ti OR [mh “Self-Injurious Behavior”] OR suicid*:ti | 2323
29 | [mh “Mass Screening”] OR screen:ti,ab OR screening:ti,ab OR screened:ti,ab OR screens:ti,ab OR “case finding”:ti,ab OR casefinding:ti,ab OR “Adapted-SAD PERSONS”:ti,ab,kw OR “Beck Hopelessness Scale”:ti,ab,kw OR “Beck Scale for Suicide Ideation”:ti,ab,kw OR “Center for Epidemiologic Studies-Depression Scale”:ti,ab,kw OR “Child Suicide Assessment”:ti,ab,kw OR “Columbia Suicide Severity Rating Scale”:ti,ab,kw OR “Columbia Teen Screen”:ti,ab,kw OR “Firestone Assessment of Self-Destructive Thoughts”:ti,ab,kw OR “Harkavy Asnis Suicide Survey”:ti,ab,kw OR “Inventory for Suicidal Ideation”:ti,ab,kw OR “Multi-attitude Suicide Tendency Scale for Adolescents”:ti,ab,kw OR “Paykel Suicide Items”:ti,ab,kw OR “Positive and Negative Suicide Ideation Inventory”:ti,ab,kw OR “Scale for Suicide Ideation”:ti,ab,kw OR “Self-harm behavior questionnaire”:ti,ab,kw OR “Suicide Behaviors Questionnaire”:ti,ab,kw OR “Suicidal Ideation Questionnaire”:ti,ab,kw OR “Suicidality Occurring in Paediatrics-Suicidality Assessment Scale”:ti,ab,kw OR “Suicide Assessment Five-Step Evaluation and Triage”:ti,ab,kw OR “Suicide Probability Scale”:ti,ab,kw OR BSI:ti,ab OR CES-D:ti,ab OR CSA:ti,ab OR C-SSSR:ti,ab OR CTS:ti,ab OR HASS-II:ti,ab OR ISO-30:ti,ab OR PANSI:ti,ab OR SSI:ti,ab OR SHBQ:ti,ab OR SBQ-14:ti,ab OR SBQ-C:ti,ab OR SIQ:ti,ab OR SIQ-Junior:ti,ab OR STOP-SAS:ti,ab OR SAFE-T:ti,ab OR SPS:ti,ab OR SRS:ti,ab | 72731
30 | #28 AND #29 | 336
31 | #30 AND #10 | 118
32 | #31 NOT (clinicaltrials or trialsearch):so | 85
33 | #28 AND (#12 OR #14) | 1577
34 | #33 AND #10 | 527
35 | #34 NOT (clinicaltrials or trialsearch):so | 427

## Psychinfo

Suicide Risk: January 1, 2012, through April 30, 2020

Anxiety: January 1, 2017 to April 30, 2020

Depression: June 1, 2012 to April 30, 2020

# | Query | Limiters/Expanders | Results
S1 | DE “Depression (Emotion)” OR DE “Major Depression” OR DE “Anaclitic Depression” OR DE “Dysthymic Disorder” OR DE “Reactive Depression” OR DE “Recurrent Depression” OR DE “Treatment Resistant Depression” OR depressive OR depression OR depressed OR dysthymic OR dysthymia | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 360,288
S2 | DE “Health Screening” OR DE “Screening Tests” OR screen OR screening OR screened OR screens OR “case finding” OR casefinding OR “beck depression inventory” OR “beck depression inventories” OR “Center for Epidemiologic Studies Depression Scale” OR “Center for Epidemiologic Studies Depression Scales” OR “depression inventory” OR “depression inventories” OR “depression scale” OR “depression scales” OR “depression rating scale” OR “depression rating scales” OR Kutcher* OR “mood and feelings questionnaire” OR “mood and feelings questionnaires” OR “Patient Health Questionnaire-Adolescent Version” OR Reynold* OR “self report rating scale” OR “self report rating scales” OR BDI OR CES-D OR ChilD-S OR DesTeen OR MFQ-SF OR PHQ-2 OR PHQ-A OR RCDS | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 230,416
S3 | S1 AND S2 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 128,078
S4 | S3 | Limiters - Publication Year: 2015-2020; English; Language: English; Population Group: Human; Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 38,863
S5 | S4 | Limiters - Age Groups: Childhood (birth-12 yrs), Adolescence (13-17 yrs); Search modes - Boolean/Phrase | 7,802
S6 | PZ Abstract Collection OR PZ Bibliography OR PZ Clarification OR PZ Column/Opinion OR BK Conference Proceedings OR PZ Comment/Reply OR PZ Dissertation OR PT Dissertation Abstract OR PZ Editorial OR PT Enclyclopedia OR PZ Encyclopedia Entry OR PZ Interview OR PZ Letter OR PZ Obituary OR PZ Poetry OR “case control” OR “case report” OR “case reports” OR “case series” OR “comment on” OR “cross-sectional” OR “retrospective cohort” OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 1,120,371
S7 | S5 NOT S6 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 6,788
S8 | DE “Tranquilizing Drugs” OR DE “Antidepressant Drugs” OR DE “Serotonin Norepinephrine Reuptake Inhibitors” OR DE “Serotonin Reuptake Inhibitors” OR antidepressant* OR “antidepressives” OR “antidepressive agents” OR “antidepressive drug” OR “antidepressive drugs” OR “norepinephrine reuptake inhibitor” OR “norepinephrine reuptake inhibitors” OR “selective serotonin reuptake inhibitor” OR “selective serotonin reuptake inhibitors” OR ssri OR ssris OR “serotonin norepinephrine reuptake inhibitor” OR “serotonin norepinephrine reuptake inhibitors” OR snri* OR “TCA antidepressants” OR “tricyclic antidepressant” OR “tricyclic antidepressants” OR anafranil OR celexa OR DE “Citalopram” OR citalopram OR DE “Chlorimipramine” OR clomipramine OR duloxetine OR escitalopram OR DE “Fluoxetine” OR fluoxetine OR DE “Fluvoxamine” OR fluvoxamine OR DE “Ketamine” OR ketamine OR Lexapro OR lithium OR luvox OR DE “Sertraline” OR sertraline OR Zoloft | Search modes - Boolean/Phrase | 71,843
S9 | S1 AND S8 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 42,787
S10 | DE “Behavior Therapy” OR DE “Cognitive Behavior Therapy” OR DE “Counseling” OR DE “Community Counseling” OR DE “Cross Cultural Counseling” OR DE “Educational Counseling” OR DE “Group Counseling” OR DE “Microcounseling” OR DE “Psychotherapeutic Counseling” OR (TX integrated AND DE “Health Care Delivery”) OR DE “Family Therapy” OR DE “Strategic Family Therapy” OR DE “Interpersonal Psychotherapy” OR DE “Mentalization” OR DE “Psychoeducation” OR DE “Structural Family Therapy” OR (DE “Parents” AND TX education) OR DE “Treatment Planning” OR DE “Caring Behaviors” OR DE “Problem Solving” OR DE “Psychotherapy” OR DE “Group Psychotherapy” OR DE “Self-Help Techniques” OR (behavior* AND (therap* or treatment* OR intervention*)) OR CBT OR (cognitive AND (therap* OR treatment* OR intervention*)) OR “care delivery” OR “care management” OR “collaborative care” OR “combination therapy” OR “combined modality” OR counsel* OR “delivery of care” OR “dialectical behavior therapy” OR “family therapy” OR “family support” OR interpersonal therap* OR interpersonal intervention* OR “means restriction” OR “means restrictions” OR “mentalization therapy” OR (parent* AND education) OR “problem solving” OR “psychoeducation” OR psychotherap* OR (risk* AND reduc*) OR “self help” | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 1,084,659
S11 | S1 AND S10 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 131,338
S12 | S9 OR S11 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 157,878
S13 | S12 | Limiters - Publication Year: 2015-2020; English; Language: English; Age Groups: Childhood (birth-12 yrs), Adolescence (13-17 yrs); Population Group: Human; Search modes - Boolean/Phrase | 6,570
S14 | S13 NOT S6 | Search modes - Boolean/Phrase | 5,405
S15 | | Limiters - Methodology: - Systematic Review, META ANALYSIS, METASYNTHESIS; Search modes - Boolean/Phrase | 43,300
S16 | S14 AND S15 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 165
S17 | S14 NOT S16 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 5,240
S18 | DE “Agoraphobia” OR DE “Anxiety” OR DE “Anxiety Disorders” OR DE “Generalized Anxiety Disorder” OR DE “Mutism” OR DE “Elective Mutism” OR DE “Obsessive Compulsive Disorder” OR DE “Panic Attack” OR DE “Panic Disorder” OR DE “Phobias” OR DE “Separation Anxiety” OR DE “Separation Anxiety Disorder” OR DE “Social Anxiety” OR DE “Social Phobia” OR DE “Trichotillomania” OR agoraphobia OR TI anxiety OR “generalized anxiety disorder” OR mutism OR “panic disorder” OR phobia* OR “separation anxiety disorder” OR “social anxiety disorder” | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 147,222
S19 | DE “Health Screening” OR DE “Screening Tests” OR screen OR screening OR screened OR screens OR “case finding” OR casefinding OR “Children’s Manifest Anxiety Scale” OR “Multidimensional Anxiety Scale for Children” OR “Pediatric Anxiety Rating Scale” OR “Revised Children’s Manifest Anxiety Scale” OR “Screen for Child Anxiety Related Disorders” OR “Spence’s Children’s Anxiety Scale” OR “State-Trait Anxiety Inventory for Children” OR “Youth Anxiety Measure for DSM-5” OR MASC OR “MASC-2 SR” OR MASC-10 OR PARS OR RCMAS OR SCARED OR SCAS OR SCAS-8 OR STAIC OR STAIC-S OR YAM-5 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 135,018
S20 | S18 AND S19 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 9,564
S21 | S20 | Limiters - English; Language: English; Age Groups: Childhood (birth-12 yrs), Adolescence (13-17 yrs); Population Group: Human; Search modes - Boolean/Phrase | 3,977
S22 | S21 NOT S6 | Limiters - English; Language: English; Age Groups: Childhood (birth-12 yrs), Adolescence (13-17 yrs); Population Group: Human; Search modes - Boolean/Phrase | 3,377
S23 | S18 AND (S8 OR S10) | Search modes - Boolean/Phrase | 62,758
S24 | S23 | Limiters - Publication Year: 2017-2020; English; Language: English; Age Groups: Childhood (birth-12 yrs), Adolescence (13-17 yrs); Population Group: Human; Search modes - Boolean/Phrase | 1,687
S25 | S24 NOT S6 | Search modes - Boolean/Phrase | 1,434
S26 | S25 | Limiters - Methodology: - Systematic Review, META ANALYSIS, METASYNTHESIS; Search modes - Boolean/Phrase | 55
S27 | S25 NOT S26 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 1,379
S28 | DE “Attempted Suicide” OR DE “Head Banging” OR DE “Self-Inflicted Wounds” OR DE “Self-Injurious Behavior” OR DE “Self-Mutilation” OR DE “Self-Poisoning” OR DE “Suicidal Ideation” OR DE “Suicidality” OR DE “Suicide” OR parasuicid*:ti OR “self harm”:ti OR suicid*:ti | Search modes - Boolean/Phrase | 47,432
S29 | DE “Health Screening” OR DE “Screening Tests” OR screen OR screening OR screened OR screens OR “case finding” OR casefinding OR “Adapted-SAD PERSONS” OR “Beck Hopelessness Scale” OR “Beck Scale for Suicide Ideation” OR “Center for Epidemiologic Studies-Depression Scale” OR “Child Suicide Assessment” OR “Columbia Suicide Severity Rating Scale” OR “Columbia Teen Screen” OR “Firestone Assessment of Self-Destructive Thoughts” OR “Harkavy Asnis Suicide Survey” OR “Inventory for Suicidal Ideation” OR “Multi-attitude Suicide Tendency Scale for Adolescents” OR “Paykel Suicide Items” OR “Positive and Negative Suicide Ideation Inventory” OR “Scale for Suicide Ideation” OR “Self-harm behavior questionnaire” OR “Suicide Behaviors Questionnaire” OR “Suicidal Ideation Questionnaire” OR “Suicidality Occurring in Paediatrics-Suicidality Assessment Scale” OR “Suicide Assessment Five-Step Evaluation and Triage” OR “Suicide Probability Scale” OR BSI OR CES-D OR CSA OR C-SSSR OR CTS OR HASS-II OR ISO-30 OR PANSI OR SSI OR SHBQ OR SBQ-14 OR SBQ-C OR SIQ OR SIQ-Junior OR STOP-SAS OR SAFE-T OR SPS OR SRS | Search modes - Boolean/Phrase | 145,902
S30 | S28 AND S29 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 5,110
S31 | S30 | Limiters - Published Date: 20120601-20201231; English; Language: English; Age Groups: Childhood (birth-12 yrs), Adolescence (13-17 yrs); Population Group: Human; Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 784
S32 | S31 NOT S6 | Limiters - Published Date: 20120601-20201231; English; Language: English; Age Groups: Childhood (birth-12 yrs), Adolescence (13-17 yrs); Population Group: Human; Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 639
S33 | S28 AND (S8 OR S10) | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 21,608
S34 | S33 | Limiters - Published Date: 20120601-20201231; English; Language: English; Age Groups: Childhood (birth-12 yrs), Adolescence (13-17 yrs); Population Group: Human; Search modes - Boolean/Phrase | 2,063
S35 | S34 NOT S6 | Search modes - Boolean/Phrase | 1,632
S36 | S35 | Limiters - Methodology: - Systematic Review, META ANALYSIS, METASYNTHESIS; Search modes - Boolean/Phrase | 39
S37 | S35 NOT S36 | Search modes - Boolean/Phrase | 1,593
S38 | “Pediatric Symptom Checklist-17” OR PSC OR “Revised Children’s Anxiety and Depression Scale” OR RCADS OR RCADS-25 OR “Strength and Difficulties Questionnaires” OR SDQ | Search modes - Boolean/Phrase | 2,378
S39 | (S1 OR S18 OR S28) AND S38 | Search modes - Boolean/Phrase | 523
S40 | S39 | Limiters - English; Language: English; Age Groups: Childhood (birth-12 yrs), Adolescence (13-17 yrs); Population Group: Human; Search modes - Boolean/Phrase | 345
S41 | S40 NOT S6 | Search modes - Boolean/Phrase | 281

## Psychinfo

Suicide Risk: January 1, 2012, through April 30, 2020

Anxiety: NA

Depression: NA

# | Query | Limiters/Expanders | Results
S1 | (MH “Suicide+”) OR TI parasuicid*OR TI “self harm” OR (MH “Self-Injurious Behavior”) OR TI suicid* | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 38,801
S2 | | Limiters - Published Date: 20120601-20201231; English Language; Exclude MEDLINE records; Human; Age Groups: Infant, Newborn: birth-1 month, Infant: 1-23 months, Child, Preschool: 2-5 years, Child: 6-12 years, Adolescent: 13-18 years; Language: English; Search modes - Boolean/Phrase | 150,128
S3 | S1 AND S2 | Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 1,855
S4 | PT Biography OR PT Cartoon OR PT Commentary OR PT Directories OR PT Editorial OR PT Games OR PT Glossary OR PT Interview OR PT Legal Case OR PT Letter OR PT Obituary OR PT Poetry OR “comment on” OR “cross-sectional” OR “retrospective cohort” OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae | Search modes - Boolean/Phrase | 1,348,371
S5 | S3 NOT S4 | Search modes - Boolean/Phrase | 1,507
S6 | (MH “Health Screening”) OR TI screen OR AB screen OR TI screening OR AB screening OR TI screened OR AB screened OR TI screens OR AB screens OR TI “case finding” OR AB “case finding” OR TI casefinding OR AB casefinding OR “Adapted-SAD PERSONS” OR “Beck Hopelessness Scale” OR “Beck Scale for Suicide Ideation” OR “Center for Epidemiologic Studies-Depression Scale” OR “Child Suicide Assessment” OR “Columbia Suicide Severity Rating Scale” OR “Columbia Teen Screen” OR “Firestone Assessment of Self-Destructive Thoughts” OR “Harkavy Asnis Suicide Survey” OR “Inventory for Suicidal Ideation” OR “Multi-attitude Suicide Tendency Scale for Adolescents” OR “Paykel Suicide Items” OR “Positive and Negative Suicide Ideation Inventory” OR “Scale for Suicide Ideation” OR “Self-harm behavior questionnaire” OR “Suicide Behaviors Questionnaire” OR “Suicidal Ideation Questionnaire” OR “Suicidality Occurring in Paediatrics-Suicidality Assessment Scale” OR “Suicide Assessment Five-Step Evaluation and Triage” OR “Suicide Probability Scale” OR TI BSI OR AB BSI OR TI CES-D OR AB CES-D OR TI CSA OR AB CSA OR TI C-SSSR OR AB C-SSSR OR TI CTS OR AB CTS OR TI HASS-II OR AB HASS-II OR TI ISO-30 OR AB ISO-30 OR TI PANSI OR AB PANSI OR TI SSI OR AB SSI OR TI SHBQ OR AB SHBQ OR TI SBQ-14 OR AB SBQ-14 OR TI SBQ-C OR AB SBQ-C OR TI SIQ OR AB SIQ OR TI SIQ-Junior OR AB SIQ-Junior OR TI STOP-SAS OR AB STOP-SAS OR TI SAFE-T OR AB SAFE-T OR TI SPS OR AB SPS OR TI SRS OR AB SRS | Search modes - Boolean/Phrase | 212,836
S7 | S5 AND S6 | Search modes - Boolean/Phrase | 163
S8 | (MH “Antianxiety Agents+”) OR (MH “Antidepressive Agents+”) OR (MH “Serotonin Uptake Inhibitors+”) OR (MH “Tranquilizing Agents+”) OR TI antidepressant* OR AB antidepressant* OR TI antidepressives OR AB antidepressives OR TI “antidepressive agents” OR AB “antidepressive agents” OR TI “antidepressive drug” OR AB “antidepressive drug” OR “antidepressive drugs” OR “antidepressive drugs” OR “norepinephrine reuptake inhibitor” OR “norepinephrine reuptake inhibitors” OR “selective serotonin reuptake inhibitor” OR “selective serotonin reuptake inhibitors” OR TI ssri OR AB ssri OR TI ssris OR AB ssris OR “serotonin norepinephrine reuptake inhibitor” OR “serotonin norepinephrine reuptake inhibitors” OR snri* OR “TCA antidepressants” OR “tricyclic antidepressant” OR “tricyclic antidepressants” OR anafranil OR celexa OR citalopram OR clomipramine OR duloxetine OR escitalopram OR fluoxetine OR fluvoxamine OR ketamine OR Lexapro OR lithium OR luvox OR sertraline OR Zoloft | Search modes - Boolean/Phrase | 71,793
S9 | S5 AND S8 | Search modes - Boolean/Phrase | 44
S10 | (MH “Behavior Therapy+”) OR (MH “Cognitive Therapy+”) OR (MH “Combined Modality Therapy+”) OR (MH “Counseling+”) OR (MH “Health Care Delivery, Integrated”) OR (MH “Family Therapy”) OR (MH “Patient Care/AM/MT/NU/OG/ST”) OR (MH “Problem Solving+”) OR (MH “Psychotherapy+”) OR (MH “Psychotherapy, Group+”) OR (MH “Support Groups+”) OR (behavior* AND (therap* or treatment* OR intervention*)) OR CBT OR (cognitive AND (therap* OR treatment* OR intervention*)) OR “care delivery” OR “care management” OR “collaborative care” OR “combination therapy” OR “combined modality” OR counsel* OR “delivery of care” OR “dialectical behavior therapy” OR “family therapy” OR “family support” OR interpersonal therap* OR interpersonal intervention* OR “means restriction” OR “means restrictions” OR “mentalization therapy” OR (parent* AND education) OR “problem solving” OR “psychoeducation” OR psychotherap* OR (risk* AND reduc*) OR “self help” | Search modes - Boolean/Phrase | 777,586
S11 | S5 AND S10 | Search modes - Boolean/Phrase | 590
S12 | S9 OR S11 | Search modes - Boolean/Phrase | 616
S13 | S12 | Limiters - Publication Type: Meta Analysis, Meta Synthesis, Systematic Review; Expanders - Apply equivalent subjects; Search modes - Boolean/Phrase | 49
S14 | S12 NOT S13 | Search modes - Boolean/Phrase | 567