# Appendix A Contextual Questions

## CQ 1 What is the diagnostic yield from screening for anxiety, depression, or increased suicide risk in typical primary care settings?

Given the seriousness of unmet mental health needs in youth, identification of depression, anxiety, and risk for suicide is critical. With nearly half of all youth birth to 17 years having access to healthcare in a medical home,^1^ primary care is a logical place for detecting these conditions in youth. Recent research has begun to examine the extent of screening for mental health disorders in pediatric primary care as well as the outcomes of screening, including diagnosis and referral. In addition to studies included for the key question on screening test accuracy (KQ 2), we examined recent literature on screening in primary care for depression (n=11),^2–10^ anxiety (n=1),^11^ or suicide (n=2)^4,^ ^12^ to describe the outcomes following a positive screening. Some of these studies reported on more than the focal mental health condition.

Screening for depression. The studies included for KQ 2 (screening test accuracy)^13–19^ each examined the prevalence of depression. However, only three of the seven studies recruited youth from primary care;^13^ in these three studies the prevalence of depression across varied populations ranged from 8.2 percent to 11 percent. We included seven additional studies that did not meet criteria for KQ 2 studies of accuracy but that had relevant information for examining the outcome of depression screening in primary care settings.^2–4,^ ^6,^ ^9,^ ^10,^ ^20^ Only one of these studies^10^ provided data that permitted us to calculate the prevalence of depression. Thus, we report the positive predictive value (PPV) to describe the yield of diagnosing depression following a positive screen.

Appendix A Table 1 details the outcome of a positive screen reported in these studies, all of which included one of the PHQ versions (i.e., PHQ-A, PHQ-9, PHQ-9M). Three studies^6,^ ^10,^ ^20^ reported the diagnosis of depression following a positive screen, and two of these studies^6,^ ^10^ found that depression diagnoses increased after implementing an intervention designed to improve the rate of depression screening. The Bose study^10^ found that the rate of depression diagnoses went from 1 percent before their intervention to 13 percent afterward and to 39 percent of those with a positive screen.^10^ Although the rate of diagnosed depression did not increase in the Lewandowski study, the number of adolescents (134) diagnosed with depression tripled over the three waves of the study; in the last year of their study, the rate of depression diagnosis following a positive screen was 36 percent.^6^ Importantly, neither the Bose nor Lewandowski studies had control groups. The Stafford study reported that of the adolescents who had a positive screen, 71 percent received a diagnosis of depression.^20^ One additional study,^2^ reported that 20% of the youth who screened positive on the PHQ-9 were not depressed as indicated on medical chart abstraction, but it is not clear whether they or the remaining 80% underwent a formal depression diagnosis. Although the remainder of the studies^2–4,^ ^9,^ ^10,^ ^20^ did not diagnose depression directly, they made referrals to mental health providers, which may have included diagnosis along with service provision. However, this is unknown.

Screening for anxiety. Among the 10 studies included for KQ 2 (screening test accuracy), only four recruited youth in primary care settings.^13,^ ^21–23^ The prevalence of anxiety disorders across varied populations in these four studies ranged from 2.5 percent to 13 percent. Only one additional study reported on implementation of a screening program in primary care that was designed to detect anxiety disorders and mental health utilization.^11^ Although the study administered the SCARED and SAS screeners as well as clinical interviews via telephone, the investigators did not report any data that examined the rate of anxiety disorders in relation to screening data. Prevalence rates determined from the interviews with 190 parents using the ADIS were 3.2 percent for GAD, 6.8 percent for a social anxiety disorder, and 16.8 percent for any anxiety disorder. The detection rates from screening and rates of anxiety disorder from a clinical interview were similar, but the positive predictive value of the two screening measures is unknow, because, as noted above, the investigators did not report any data that examined the rate of anxiety disorders in relation to screening.

Screening for suicide. In the single study included for KQ 2 (screening test accuracy), the prevalence of high suicide risk among a population of potential high school dropouts recruited from seven high schools in the Pacific Northwest region of the United States was between 19 and 22 percent depending on the reference standard used.^24^ Two studies that were not eligible for inclusion in KQ 2, because they did not have an eligible comparator, provided additional information about detection of persons at high risk for suicide in primary care^4,^ ^12^ The Etter study screened for suicidality with a single question as well as for depression using the PHQ-9.^12^ In the sample of over 2,134 youth, 131 (6%) endorsed suicidality. Providers documented followup actions for all but 20 of the youth. Of the remaining 109 youth, providers indicated that 93 were not suicidal after provider assessment, suggesting that of those who endorsed the suicidality question, 15 percent were at high risk for suicide. The Farley study,^4^ which was primarily a study to assess identification and management of adolescent depression in a large pediatric care network, administered the PHQ-9 along with two optional suicide risk questions. They found that 597 (8.6%) of the 6,923 adolescents completing the screener were flagged for suicide risk, but they did not examine followup for this group, other than to report that all but 230 (17%) had elevated depression scores on the PHQ. They did report that 15 of the 1,797 youth with elevated PHQ depression scores were deemed to be at high risk of suicide, and they followed emergency procedures for these youth. If these youth were part of the 498 with elevated scores who were also flagged for suicide risk, then the rate of high suicide risk in those who endorsed suicide questions is 3 percent; however, there is no information about the 99 adolescents flagged for suicide risk who had PHQ scores in the normal range.

The takeaway from this group of studies is that few studies conducted in primary care address the prevalence of anxiety, depression, or elevated risk of suicide or the rates of diagnosing these disorders after a positive screen.

## CQ 2 What are the minimal clinically important differences (the smallest value of benefit to patients) for symptoms and functioning on the most common instruments used to measure response to treatment of depression, anxiety, or suicide risk?

Recent systematic reviews on anxiety^25^ and depression^26^ have noted the lack of research in minimal clinically important differences. A supplemental search of PubMed for this systematic review yielded no relevant citations for children with depression, anxiety, or suicide risk; systematic reviews on the topic also confirmed the lack of evidence.^27^ The depression review relied on distribution-based methods (that is, methods based on statistical properties of the distribution of outcome measures^28^) for judging minimal clinically important differences, due to the lack of anchor-based methods (that is, methods based on direct questioning of patients, providers, or caregivers). Distribution-based methods do not account for patient preferences^28^ or identify any particular values for minimal clinically important differences (MCID); rather, they indicate that values above and below prespecified units of standard deviations are likely not important or not minimal.^29^ In the absence of these MCID values, information about the established thresholds for the outcome measures offers some basis for judging whether the results are clinically meaningful. Tables 5, 6, 7, 9, 11, 13, and 15 in the main report lists these thresholds for pooled analyses along with a range of values for the treatment and comparison arms.

## CQ 3 What are the U.S. Food and Drug Administration boxed warnings for pharmacotherapy for the treatment of depression, anxiety, or suicide risk in children and adolescents?

The current Food and Drug Administration (FDA) boxed warning, contraindications, pediatric warnings, and pediatric use statements for all drugs included in this review are shown below in Appendix A Table 2. The FDA issued a boxed warning for children and adolescents for all antidepressants in 2004 based on an FDA-conducted pooled analysis that found increased risk of suicidality when pooling across all antidepressants and all indications.^30^ All drugs used in studies included in this review were selective serotonin reuptake inhibitors (SSRIs) and carry a boxed warning stating that there is “[i]ncreased risk of suicidal thinking and behavior in children, adolescents, and young adults taking antidepressants for major depressive disorder (MDD) and other psychiatric disorders.” Some warnings contain extra guidance stating that prescribers should “monitor for worsening and emergence of suicidal thoughts and behaviors.”

SSRIs as a class may be associated with a higher risk of serious adverse events among adolescents and children with MDD and with a higher risk of withdrawal due to adverse events among adolescents with MDD. A 2020 comparative effectiveness review found paroxetine, which was excluded from this current USPSTF review update because it is not FDA approved for children or adolescents, may be associated with a higher risk of suicidal ideation or behaviors in adolescents with MDD. The evidence from the comparative effectiveness review was insufficient for other SSRIs as a drug class across populations and depressive disorders for outcomes related to suicide.^26^

The FDA has approved two SSRIs to treat MDD in children or adolescents (fluoxetine for children age 8 years or older and escitalopram for adolescents ages 12 to 17 years).

## CQ 4 What psychotherapies other than cognitive behavioral therapy are used to treat anxiety in children?

CBT has the largest evidence base for treatment of anxiety disorders in children. Several other less well-studied interventions have been evaluated for treating anxiety in children and adolescents.

Nine RCTs reported on attention bias modification treatment (ABMT) as a psychotherapy to treat anxiety disorders in children and adolescents.^31–39^ ABMT is based on the theory that attention training toward positive stimuli can reduce anxiety. The protocol uses a computerized dot-probe task to assess the individual’s threat bias and then to treat the bias by systematically redirecting attention away from the threat stimuli.^40^ Across this body of evidence, two RCTs^32,^ ^39^ found some benefit for treatment of anxiety disorders with ABMT,^32,^ ^39^ while six RCTs^31,^ ^33–38^ found no significant benefit of the intervention in decreasing anxiety.

Other interventions to treat anxiety in children have a smaller evidence base. One RCT^41^ compared 10 weeks of acceptance and commitment therapy (ACT) to CBT to wait-list control in 193 children with anxiety disorder diagnoses and found that ACT and CBT were both superior to wait-list control and gains were maintained at 3 months post treatment. ACT and CBT produced similar outcomes. Psychodynamic psychotherapy is another intervention that has been less well studied, but one RCT^42^ was found comparing psychodynamic psychotherapy treatment (PDT) to CBT and wait-list control in 107 adolescents with social anxiety disorder ages 14 through 20 years. Both PDT and CBT were superior to wait-list control.

## CQ 5 What is the effectiveness of evidence-based treatment in children and adolescents with persistent depressive disorder and depressive disorders not otherwise specified?

The recent AHRQ Effective Health Care systematic review on the effectiveness of treatment for depression in children and adolescents noted that the evidence base is sparse for persons with persistent depressive disorder (PDD) and depressive disorders not otherwise specified (DDNOS) and varies by age and disorder.^26^ This review found insufficient evidence to evaluate the effectiveness of pharmacological treatments for PDD or DDNOS among children and adolescents. Regarding nonpharmacological approaches, family therapy and CBT compared with wait-list or active control may improve symptoms, response, and functional status among children or adolescents with PDD or DDNOS. The strength of evidence for all outcomes is low. The rest of this section describes studies that were included for this evidence based on the AHRQ EHC review.^26^

One RCT^43^ with medium risk of bias compared family-based interpersonal therapy (IPT) with active control in children (ages 7 to 12 years) with a range of depressive disorders including PDD and DDNOS in a 14-week intervention. Family-based IPT improved clinician-, self-, and parent-reported depressive symptoms. The mean difference on the clinician-reported scale (CDRS-R) was −0.50 (95% CI, −2.48 to 0.10). The mean difference on the self-reported Mood and Feelings Questionnaire for Children (MFQ-C) was −6.50 (95% CI, −7.85 to 5.15). The mean difference on the parent-reported Mood and Feelings Questionnaire (MFQ-P) was −5.60 (95% CI, −6.49 to 4.71). The authors of the AHRQ EHC review concluded that the evidence was insufficient to judge the effectiveness of family-based IPT when compared with active control for remission.^26^

Two RCTs, one with high risk of bias^44^ and one with some^45^ risk-of-bias concerns, compared CBT with wait-list control among adolescents with a range of depressive disorders including PDD. The duration of the intervention spanned 8^45^ to 12^44^ weeks. Compared with wait-list control, CBT improved self-reported depressive symptoms (mean difference [Beck Depression Inventory (BDI)], −5.90 [95% CI, −10.89 to −0.92]) and improved clinician-reported functional impairment (mean difference [Global Assessment of Functioning (GAF)], 6.5 [95% CI, 0.68 to 12.32]). The authors of the AHRQ EHC review concluded that the evidence was insufficient to judge whether there were improvements noted in clinician- or parent-reported depressive symptoms, recovery, or response.^26^

Three RCTs, two with some risk-of-bias concerns^46–48^ and a third with high risk of bias,^49^ that included children and adolescents (ages 7 to 18 years) compared family therapy with active control in studies that were 8 to 16 weeks long. Compared with active control, one study^46^ found that family therapy showed higher rates of adequate clinical depression response with a 50 percent reduction in CDRS-R scores from baseline to posttreatment (risk difference, 179/1,000 [95% CI, 25 more cases to 333 more cases]). The authors of the AHRQ EHC review concluded that the evidence was insufficient to evaluate the effectiveness of family therapy and active control for clinician- or self-reported depressive symptoms, depression response, remission, recurrence, and clinician- or self-reported functional impairment.^26^

The existing evidence base offers limited indication of benefit for children and adolescents with PDD or DDNOS. The lack of evidence on pharmacological treatments and on the effects of interventions in children stand out as gaps and may serve as areas for future research. In addition, new research should establish minimally important differences to help understand the trade-offs between benefits and harms. Well-designed trials will contribute to a stronger body of evidence and greater certainty in the estimate of effectiveness.

Our update search for the USPSTF review update yielded no additional relevant citations to this contextual question.

## CQ 6 What proportion of children and adolescents who screen positive for depression, anxiety, or increased suicide risk engage with care (i.e., return for clinical evaluation and treatment)?

We identified five studies that addressed followup for those screening positive for depression.^4,^ ^50–52^ One retrospective chart review of three large healthcare systems (two health maintenance organization and one network of community health centers) found that of 4,612 adolescents newly screened positive for depression in primary care, 854 (19%) received no followup visit of any type within the following 3 months. Of those who did have at least one visit, 824 (22%) did not have depression symptoms addressed. The remaining 2,934 (78%) were started on therapy (n=1,315), antidepressant medication (n=891), or combined therapy (n=728). Of those started on antidepressants, 356 (40%) did not have a followup within 3 months.^50^

Another study of 16-year-old patients screened for depression with the PHQ-9M at one of 31 sites of a large pediatric primary care practice found an association between more severe depression and increased likelihood to followup.^4^ Of 466 patients with a PHQ-9M score of 11 to 27, 349 (75.4%) had followup of some type (depression diagnosis, behavioral health referral, medication, or repeated PHQ-9) within the following year.^4^ Of the 1,331 patients screening positive for more mild depression (PHQ-9M score of 5 to 10), only 530 (39.9%) had followup of some sort.^4^

One study of 10 primary care clinics screening for depression using PHQ-2/PHQ-9 found that of the 796 patients with a PHQ-9 score of 10 or more, 638 were referred to behavioral health treatment and only 370 (58%) engaged in such treatment.^51^

One study of adolescents screening for psychiatric illness (oppositional defiant disorder, attention deficit hyperactivity disorder, depression, suicide, anxiety, separation, and others) using the Mini International Neuropsychiatric Interview (MINI) screener in an emergency room found that 200 screened positive.^53^ All who screened positive were given a referral to a mental health provider, and less than 2 percent of those patients had followed up with a mental health provider when asked during telephone followup after 6 weeks.^53^

Only one identified study looked at followup rates of those screening positive for suicide, in this case from an urgent care clinic setting. Patients 12 years or older were routinely screened by nursing using a two-question screener. If positive, a social worker administered the Columbia Suicide Severity Rating Scale (C-SSRS). Of 75 adolescents screening positive on the C-SSRS, 10 were admitted into psychiatric inpatient care, four were admitted to medical inpatient units, one left against medical advice, one was transferred to the emergency department, and 59 were referred to mental health professionals. Of those 59 referred to mental health professionals, it is not documented how many actually accessed care.^54^

No identified studies examined followup after screening positive for anxiety.

Taken together, these studies suggest that many adolescents who screen positive for depression in primary care will engage in treatment of some type and will be more likely to followup if screening positive for more severe depression. While not definitive, these studies suggest that likelihood of following up may be higher if screened in primary care rather than emergency department settings. This may be a factor of continuity, of primary care or mental health access and availability, or of other unseen factors.

Appendix A Table 1 Outcomes of Depression Screening

Study | N | Screener | Positive Screen | Depression Diagnoses | Referral
Aalsma et al, 2018^2^ | 2,038 | PHQ-2 then PHQ-9 | 303 (15%) | NA | 128 (42%)
Bose et al, 2021^10^ | 73 | PHQ-A (cutoff ≥5) | 29 (40%) | 12 (45%)^*^ | 9.2%^†^
Chowdhury et al, 2020^3^ | 1,213 | PHQ-9 (cutoff ≥5) | 96 (8%) | NA | 42 (44%)
Farley et al, 2020^4^ | 10,713 | PHQ-9M (cutoff ≥5) | 1,797 (17%) | NA | 449 (25%)
Lewandowski et al, 2016^6^ | 2,283 | PHQ-9 | 435 (19%) | 134 (36%)^ǂ^ | NA
Stafford et al, 2020^20^ | 80^§^ | PHQ-2 then PHQ-9 (cutoff ≥9) | 80^§^ | 57 (74%)^ǁ^ | 10 (12%)
Sudhanthar et al, 2015^9^ | NA | PHQ-2 then PHQ-9 | NA | NA | 38% increase^¶^

* No information provided regarding diagnostic procedure for depression.

† The number of individuals who were referred and what the 9.2% represents were unclear.

ǂ Of those with incident-positive PHQ-9.

§ Study only included adolescents who screened positive for depression.

ǁ Of those who were managed in primary care.

¶ No n’s were reported.

Abbreviations: NA=not available; PHQ=Patient Health Questionnaire.

Appendix A Table 2 FDA Boxed Warnings for Medication Included in Updated Review of Screening for Anxiety, Depression, and Suicide Risk in Children and Adolescents

Name of Drug | Date Searched | Date on FDA Label | Boxed Warning | Contraindications | Pediatric Warnings | Pediatric Use Statements
Clomipramine^55^ | April 27, 2021 | March 2019 | Yes | History of hypersensitivity to clomipramine or other tricyclic antidepressants, use of MAOIs, use of linezolid or intravenous methylene blue, and those in acute recovery period from myocardial infarction. | None | Clomipramine hydrochloride is not approved for use in pediatric patients except for patients with obsessive compulsive disorder (OCD).
Duloxetine^56^ | February 9, 2021 | December 2008 | Yes | It should not be used concomitantly or in close temporal proximity with a MAOI or in patients with uncontrolled narrow-angle glaucoma. | Increased risk of suicidal thinking and behavior in children, adolescents, and young adults taking antidepressants for MDD and other psychiatric disorders. | Not approved for use in pediatric patients.
Escitalopram^57^ | February 11, 2021 | January 2017 | Yes | It should not be used concomitantly or within 14 days of an MAOI. It should not be used concomitantly with linezolid, intravenous methylene blue, or pimozide, or in patients with known hypersensitivity to escitalopram or citalopram or any of the inactive ingredients. | Increased risk of suicidal thinking and behavior in children, adolescents, and young adults taking antidepressants for MDD and other psychiatric disorders. | Approved for acute and maintenance treatment of MDD in adolescents ages 12 to 17 years; Not approved for use in patients younger than 12 years. Safety and effectiveness have not been established in pediatric patients younger than 18 years with generalized anxiety disorder.
Fluoxetine^58^ | February 11, 2021 | January 2017 | Yes | It should not be used concomitantly or within 5 weeks of an MAOI or thioridazine. It should not be used concomitantly with linezolid, intravenous methylene blue, or pimozide. If used in combination with olanzapine, the contraindications for Symbyax should also be observed. | Increased risk of suicidal thinking and behavior in children, adolescents, and young adults taking antidepressants for MDD and other psychiatric disorders. Monitor for worsening and emergence of suicidal thoughts and behaviors. | Approved for use in pediatric patients with MDD and OCD.; Safety and effectiveness in patients younger than 8 years with MDD and younger than 7 years with OCD have not been established. Safety and effectiveness in combination with olanzapine in patients younger than 10 years for depressive episodes associated with bipolar I disorder have not been established.
Fluvoxamine^59^ | February 11, 2021 | April 2008 | Yes | It should not be used concomitantly or within 14 days of an MAOI. It should not be used concomitantly with tizanidine, thioridazine, alosetron, or pimozide. | Increased risk of suicidal thinking and behavior in children, adolescents, and young adults taking antidepressants for MDD and other psychiatric disorders. | Not approved for use in pediatric patients except those with OCD.
Sertraline^60^ | February 11, 2021 | December 2016 | Yes | It should not be used concomitantly or within 14 days of an MAOI. It should not be used concomitantly with pimozide or disulfiram (oral solution only) or in patients with known hypersensitivity to sertraline or excipients. | Increased risk of suicidal thoughts and behaviors in pediatric and young adult patients. Closely monitor for clinical worsening and emergence of suicidal thoughts and behaviors. | Safety and effectiveness in pediatric patients other than those with OCD have not been established.

Abbreviations: FDA=Food and Drug Administration; MAOI=monoamine oxidase inhibitor; MDD=major depressive disorder; OCD=obsessive compulsive disorder.

Appendix A Table 3 Screening and Engagement With Care

Study # | Screening Tool | Setting | Diagnosis(es) Addressed in Followup Statistics | Followup Rates
O’Connor et al, 2016^50^ | PHQ-9 | 3 healthcare centers | Depression | Of 4,612 screened positive or newly diagnosed with depression, 854 (19%) did not engage in followup of any kind.; Of the 891 started on antidepressants at followup, 356 (40%) had no subsequent followup within 3 months.
Farley et al, 2020^4^ | PHQ-9M | 31 sites of pediatric primary care practice in U.S. mid-Atlantic region | Depression | 466 had PHQ-9M score 11–27; 349 (75.4%) had followup of some type in the following year; 1,331 had score of 5–10; 530 (39.9%) had mental health followup of some type
Thompson et al, 2018^51^ | PHQ-2/PHQ-9 | 10 primary care clinics | Depression | Of 796 that had a PHQ-9 of 10 or above, 638 were referred to additional services, of which 370 (58%) were engaged in treatment
Downey et al, 2018^53^ | MINI | Emergency department | Suicide, depression, ODD, ADHD, anxiety, separation | 41% of 200 children screened positive for some sort of psychiatric illness. All were referred to mental health provider and <2% of patients had followed up when asked via telephone followup in 6 weeks
Patel et al, 2018^54^ | 2-question screener, followed by C-SSRS by social worker | Urgent care | Suicide | Of 75 positive C-SSRS screens, 10 psychiatric admissions, 4 medical admissions, 1 left against medical advice, 1 transfer to emergency department, and 59 were referred to mental health (with no indication from this study of followup from there)

Abbreviations: ADHD=attention-deficit/hyperactivity disorder; C-SSRS=Columbia Suicide Severity Rating Scale; MINI= Mini International Neuropsychiatric Interview; ODD=oppositional defiant disorder; PHQ=Patient Health Questionnaire; PHQ-2=Patient Health Questionnaire-2 questions; PHQ-9=Patient Health Questionnaire-9 questions; PHQ-9M= Patient Health Questionnaire-9 questions Modified; U.S.=United States.