# References

1 US Preventive Services Task Force, Bibbins-Domingo K, Grossman DC, . Screening for obstructive sleep apnea in adults: US Preventive Services Task Force recommendation statement. JAMA. 2017 Jan 24;317(4):407–14. doi: 10.1001/jama.2016.20325. PMID: 28118461.28118461
2 Osman AM, Carter SG, Carberry JC, . Obstructive sleep apnea: current perspectives. Nat Sci Sleep. 2018;10:21–34. doi: 10.2147/NSS.S124657. PMID: 29416383.29416383
3 Faber J, Faber C, Faber AP. Obstructive sleep apnea in adults. Dental Press J Orthod. 2019 Aug 1;24(3):99–109. doi: 10.1590/2177-6709.24.3.099-109.sar. PMID: 31390456.31390456
4 Veasey SC, Rosen IM. Obstructive sleep apnea in adults. N Engl J Med. 2019 Apr 11;380(15):1442–9. doi: 10.1056/NEJMcp1816152. PMID: 30970189.30970189
5 Stansbury RC, Strollo PJ. Clinical manifestations of sleep apnea. J Thorac Dis. 2015 Sep;7(9):E298–310. doi: 10.3978/j.issn.2072-1439.2015.09.13. PMID: 26543619.26543619
6 Kapur VK, Auckley DH, Chowdhuri S, . Clinical practice guideline for diagnostic testing for adult obstructive sleep apnea: an American Academy of Sleep Medicine clinical practice guideline. J Clin Sleep Med. 2017 Mar 15;13(3):479–504. doi: 10.5664/jcsm.6506. PMID: 28162150.28162150
7 Berry R, Brooks R, Gamaldo C, . The AASM Manual for the Scoring of Sleep and Associated Events: Rules, Terminology and Technical Specifications, Version 2.3. American Academy of Sleep Medicine. Darien, Illinois: 2016.
8 Neelapu BC, Kharbanda OP, Sardana HK, . Craniofacial and upper airway morphology in adult obstructive sleep apnea patients: A systematic review and meta-analysis of cephalometric studies. Sleep Med Rev. 2017 Feb;31:79–90. doi: 10.1016/j.smrv.2016.01.007. PMID: 27039222.27039222
9 Eckert DJ. Phenotypic approaches to obstructive sleep apnoea - New pathways for targeted therapy. Sleep Med Rev. 2018 Feb;37:45–59. doi: 10.1016/j.smrv.2016.12.003. PMID: 28110857.28110857
10 Jara SM, Weaver EM. Association of palatine tonsil size and obstructive sleep apnea in adults. Laryngoscope. 2018 Apr;128(4):1002–6. doi: 10.1002/lary.26928. PMID: 29205391.29205391
11 Schorr F, Kayamori F, Hirata RP, . Different craniofacial characteristics predict upper airway collapsibility in Japanese-Brazilian and White men. Chest. 2016 Mar;149(3):737–46. doi: 10.1378/chest.15-0638. PMID: 26291487.26291487
12 Lyons MM, Bhatt NY, Pack AI, . Global burden of sleep-disordered breathing and its implications. Respirology. 2020 Jul;25(7):690–702. doi: 10.1111/resp.13838. PMID: 32436658.32436658
13 Framnes SN, Arble DM. The bidirectional relationship between obstructive sleep apnea and metabolic disease. Front Endocrinol (Lausanne). 2018;9:440. doi: 10.3389/fendo.2018.00440. PMID: 30127766.30127766
14 Gaines J, Vgontzas AN, Fernandez-Mendoza J, . Obstructive sleep apnea and the metabolic syndrome: the road to clinically-meaningful phenotyping, improved prognosis, and personalized treatment. Sleep Med Rev. 2018 Dec;42:211–9. doi: 10.1016/j.smrv.2018.08.009. PMID: 30279095.30279095
15 Banhiran W, Junlapan A, Assanasen P, . Physical predictors for moderate to severe obstructive sleep apnea in snoring patients. Sleep Breath. 2014 Mar;18(1):151–8. doi: 10.1007/s11325-013-0863-y. PMID: 23703693.23703693
16 Bixler EO, Vgontzas AN, Lin HM, . Prevalence of sleep-disordered breathing in women: effects of gender. Am J Respir Crit Care Med. 2001 Mar;163(3 Pt 1):608–13. doi: 10.1164/ajrccm.163.3.9911064. PMID: 11254512.11254512
17 Bixler EO, Vgontzas AN, Ten Have T, . Effects of age on sleep apnea in men: I. Prevalence and severity. Am J Respir Crit Care Med. 1998 Jan;157(1):144–8. doi: 10.1164/ajrccm.157.1.9706079. PMID: 9445292.9445292
18 Duran J, Esnaola S, Rubio R, . Obstructive sleep apnea-hypopnea and related clinical features in a population-based sample of subjects aged 30 to 70 yr. Am J Respir Crit Care Med. 2001 Mar;163(3 Pt 1):685–9. doi: 10.1164/ajrccm.163.3.2005065. PMID: 11254524.11254524
19 Gungor AY, Turkkahraman H, Yilmaz HH, . Cephalometric comparison of obstructive sleep apnea patients and healthy controls. Eur J Dent. 2013 Jan;7(1):48–54. PMID: 23408768.23408768
20 Lowe AA, Ono T, Ferguson KA, . Cephalometric comparisons of craniofacial and upper airway structure by skeletal subtype and gender in patients with obstructive sleep apnea. Am J Orthod Dentofacial Orthop. 1996 Dec;110(6):653–64. doi: 10.1016/s0889-5406(96)80043-6. PMID: 8972813.8972813
21 Myers KA, Mrkobrada M, Simel DL. Does this patient have obstructive sleep apnea? The Rational Clinical Examination systematic review. JAMA. 2013 Aug 21;310(7):731–41. doi: 10.1001/jama.2013.276185. PMID: 23989984.23989984
22 Newman AB, Foster G, Givelber R, . Progression and regression of sleep-disordered breathing with changes in weight: the Sleep Heart Health Study. Arch Intern Med. 2005 Nov 14;165(20):2408–13. doi: 10.1001/archinte.165.20.2408. PMID: 16287771.16287771
23 Peppard PE, Young T, Palta M, . Longitudinal study of moderate weight change and sleep-disordered breathing. JAMA. 2000 Dec 20;284(23):3015–21. doi: 10.1001/jama.284.23.3015. PMID: 11122588.11122588
24 Somers VK, White DP, Amin R, . Sleep apnea and cardiovascular disease: an American Heart Association/American College of Cardiology Foundation Scientific Statement from the American Heart Association Council for High Blood Pressure Research Professional Education Committee, Council on Clinical Cardiology, Stroke Council, and Council on Cardiovascular Nursing. In collaboration with the National Heart, Lung, and Blood Institute National Center on Sleep Disorders Research (National Institutes of Health). Circulation. 2008 Sep 2;118(10):1080–111. doi: 10.1161/CIRCULATIONAHA.107.189375. PMID: 18725495.18725495
25 Tishler PV, Larkin EK, Schluchter MD, . Incidence of sleep-disordered breathing in an urban adult population: the relative importance of risk factors in the development of sleep-disordered breathing. JAMA. 2003 May 7;289(17):2230–7. doi: 10.1001/jama.289.17.2230. PMID: 12734134.12734134
26 White DP, Younes MK. Obstructive sleep apnea. Compr Physiol. 2012 Oct;2(4):2541–94. doi: 10.1002/cphy.c110064. PMID: 23720258.23720258
27 Young T, Finn L, Austin D, . Menopausal status and sleep-disordered breathing in the Wisconsin Sleep Cohort Study. Am J Respir Crit Care Med. 2003 May 1;167(9):1181–5. doi: 10.1164/rccm.200209-1055OC. PMID: 12615621.12615621
28 Young T, Palta M, Dempsey J, . The occurrence of sleep-disordered breathing among middle-aged adults. N Engl J Med. 1993 Apr 29;328(17):1230–5. doi: 10.1056/NEJM199304293281704. PMID: 8464434.8464434
29 Young T, Peppard PE, Gottlieb DJ. Epidemiology of obstructive sleep apnea: a population health perspective. Am J Respir Crit Care Med. 2002 May 1;165(9):1217–39. doi: 10.1164/rccm.2109080. PMID: 11991871.11991871
30 Young T, Peppard PE, Taheri S. Excess weight and sleep-disordered breathing. J Appl Physiol (1985). 2005 Oct;99(4):1592–9. doi: 10.1152/japplphysiol.00587.2005. PMID: 16160020.16160020
31 Young T, Shahar E, Nieto FJ, . Predictors of sleep-disordered breathing in community-dwelling adults: the Sleep Heart Health Study. Arch Intern Med. 2002 Apr 22;162(8):893–900. doi: 10.1001/archinte.162.8.893. PMID: 11966340.11966340
32 Conway SG, Roizenblatt SS, Palombini L, . Effect of smoking habits on sleep. Braz J Med Biol Res. 2008 Aug;41(8):722–7. doi: 10.1590/s0100-879x2008000800014. PMID: 18797708.18797708
33 Hoflstein V. Relationship between smoking and sleep apnea in clinic population. Sleep. 2002 Aug 1;25(5):519–24. PMID: 12150318.12150318
34 Kang K, Seo JG, Seo SH, . Prevalence and related factors for high-risk of obstructive sleep apnea in a large korean population: results of a questionnaire-based study. J Clin Neurol. 2014 Jan;10(1):42–9. doi: 10.3988/jcn.2014.10.1.42. PMID: 24465262.24465262
35 Kashyap R, Hock LM, Bowman TJ. Higher prevalence of smoking in patients diagnosed as having obstructive sleep apnea. Sleep Breath. 2001 Dec;5(4):167–72. doi: 10.1007/s11325-001-0167-5. PMID: 11868156.11868156
36 Lofaso F, Coste A, d’Ortho MP, . Nasal obstruction as a risk factor for sleep apnoea syndrome. Eur Respir J. 2000 Oct;16(4):639–43. doi: 10.1034/j.1399-3003.2000.16d12.x. PMID: 11106205.11106205
37 Peppard PE, Austin D, Brown RL. Association of alcohol consumption and sleep disordered breathing in men and women. J Clin Sleep Med. 2007 Apr 15;3(3):265–70. PMID: 17561593.17561593
38 Scanlan MF, Roebuck T, Little PJ, . Effect of moderate alcohol upon obstructive sleep apnoea. Eur Respir J. 2000 Nov;16(5):909–13. doi: 10.1183/09031936.00.16590900. PMID: 11153591.11153591
39 Wetter DW, Young TB, Bidwell TR, . Smoking as a risk factor for sleep-disordered breathing. Arch Intern Med. 1994 Oct 10;154(19):2219–24. PMID: 7944843.7944843
40 Gottlieb DJ, Punjabi NM. Diagnosis and management of obstructive sleep apnea: a review. JAMA. 2020 Apr 14;323(14):1389–400. doi: 10.1001/jama.2020.3514. PMID: 32286648.32286648
41 Caples SM, Gami AS, Somers VK. Obstructive sleep apnea. Ann Intern Med. 2005 Feb 1;142(3):187–97. doi: 10.7326/0003-4819-142-3-200502010-00010. PMID: 15684207.15684207
42 Peppard PE, Young T, Barnet JH, . Increased prevalence of sleep-disordered breathing in adults. Am J Epidemiol. 2013 May 1;177(9):1006–14. doi: 10.1093/aje/kws342. PMID: 23589584.23589584
43 Ford ES, Wheaton AG, Cunningham TJ, . Trends in outpatient visits for insomnia, sleep apnea, and prescriptions for sleep medications among US adults: findings from the National Ambulatory Medical Care survey 1999-2010. Sleep. 2014 Aug 1;37(8):1283–93. doi: 10.5665/sleep.3914. PMID: 25083008.25083008
44 Benjafield AV, Ayas NT, Eastwood PR, . Estimation of the global prevalence and burden of obstructive sleep apnoea: a literature-based analysis. Lancet Respir Med. 2019 Aug;7(8):687–98. doi: 10.1016/S2213-2600(19)30198-5. PMID: 31300334.31300334
45 Young T, Skatrud J, Peppard PE. Risk factors for obstructive sleep apnea in adults. JAMA. 2004 Apr 28;291(16):2013–6. doi: 10.1001/jama.291.16.2013. PMID: 15113821.15113821
46 Dudley KA, Patel SR. Disparities and genetic risk factors in obstructive sleep apnea. Sleep Med. 2016 Feb;18:96–102. doi: 10.1016/j.sleep.2015.01.015. PMID: 26428843.26428843
47 Balk EM, Moorthy D, Obadan NO, . Diagnosis and Treatment of Obstructive Sleep Apnea in Adults Agency for Healthcare Research and Quality. Rockville, MD: Quality AfHRa; Jul 2011.
48 Knauert M, Naik S, Gillespie MB, . Clinical consequences and economic costs of untreated obstructive sleep apnea syndrome. World J Otorhinolaryngol Head Neck Surg. 2015 Sep;1(1):17–27. doi: 10.1016/j.wjorl.2015.08.001. PMID: 29204536.29204536
49 Horstmann S, Hess CW, Bassetti C, . Sleepiness-related accidents in sleep apnea patients. Sleep. 2000 May 1;23(3):383–9. PMID: 10811382.10811382
50 Young T, Blustein J, Finn L, . Sleep-disordered breathing and motor vehicle accidents in a population-based sample of employed adults. Sleep. 1997 Aug;20(8):608–13. doi: 10.1093/sleep/20.8.608. PMID: 9351127.9351127
51 Wu H, Yan-Go F. Self-reported automobile accidents involving patients with obstructive sleep apnea. Neurology. 1996 May;46(5):1254–7. doi: 10.1212/wnl.46.5.1254. PMID: 8628462.8628462
52 Teran-Santos J, Jimenez-Gomez A, Cordero-Guevara J. The association between sleep apnea and the risk of traffic accidents. Cooperative Group Burgos-Santander. N Engl J Med. 1999 Mar 18;340(11):847–51. doi: 10.1056/NEJM199903183401104. PMID: 10080847.10080847
53 George CF, Nickerson PW, Hanly PJ, . Sleep apnoea patients have more automobile accidents. Lancet. 1987 Aug 22;2(8556):447. doi: 10.1016/s0140-6736(87)90974-3. PMID: 2887740.2887740
54 Findley LJ, Unverzagt ME, Suratt PM. Automobile accidents involving patients with obstructive sleep apnea. Am Rev Respir Dis. 1988 Aug;138(2):337–40. doi: 10.1164/ajrccm/138.2.337. PMID: 3195832.3195832
55 George CF, Smiley A. Sleep apnea & automobile crashes. Sleep. 1999 Sep 15;22(6):790–5. PMID: 10505825.10505825
56 Quan SF, Wright R, Baldwin CM, . Obstructive sleep apnea-hypopnea and neurocognitive functioning in the Sleep Heart Health Study. Sleep Med. 2006 Sep;7(6):498–507. doi: 10.1016/j.sleep.2006.02.005. PMID: 16815753.16815753
57 Kerner NA, Roose SP. Obstructive sleep apnea is linked to depression and cognitive impairment: evidence and potential mechanisms. Am J Geriatr Psychiatry. 2016 Jun;24(6):496–508. doi: 10.1016/j.jagp.2016.01.134. PMID: 27139243.27139243
58 Bubu OM, Andrade AG, Umasabor-Bubu OQ, . Obstructive sleep apnea, cognition and Alzheimer’s disease: a systematic review integrating three decades of multidisciplinary research. Sleep Med Rev. 2020 Apr;50:101250. doi: 10.1016/j.smrv.2019.101250. PMID: 31881487.31881487
59 Sjosten N, Vahtera J, Salo P, . Increased risk of lost workdays prior to the diagnosis of sleep apnea. Chest. 2009 Jul;136(1):130–6. doi: 10.1378/chest.08-2201. PMID: 19318680.19318680
60 Omachi TA, Claman DM, Blanc PD, . Obstructive sleep apnea: a risk factor for work disability. Sleep. 2009 Jun;32(6):791–8. doi: 10.1093/sleep/32.6.791. PMID: 19544756.19544756
61 Accattoli MP, Muzi G, dell’Omo M, . [Occupational accidents, work performance and obstructive sleep apnea syndrome (OSAS)]. G Ital Med Lav Ergon. 2008 Jul–Sep;30(3):297–303. PMID: 19069234.19069234
62 Moyer CA, Sonnad SS, Garetz SL, . Quality of life in obstructive sleep apnea: a systematic review of the literature. Sleep Med. 2001 Nov;2(6):477–91. doi: 10.1016/s1389-9457(01)00072-7. PMID: 14592263.14592263
63 Marin JM, Carrizo SJ, Vicente E, . Long-term cardiovascular outcomes in men with obstructive sleep apnoea-hypopnoea with or without treatment with continuous positive airway pressure: an observational study. Lancet. 2005 Mar 19–25;365(9464):1046–53. doi: 10.1016/S0140-6736(05)71141-7. PMID: 15781100.15781100
64 Yeboah J, Redline S, Johnson C, . Association between sleep apnea, snoring, incident cardiovascular events and all-cause mortality in an adult population: MESA. Atherosclerosis. 2011 Dec;219(2):963–8. doi: 10.1016/j.atherosclerosis.2011.08.021. PMID: 22078131.22078131
65 Shahar E, Whitney CW, Redline S, . Sleep-disordered breathing and cardiovascular disease: cross-sectional results of the Sleep Heart Health Study. Am J Respir Crit Care Med. 2001 Jan;163(1):19–25. doi: 10.1164/ajrccm.163.1.2001008. PMID: 11208620.11208620
66 Javaheri S, Parker TJ, Liming JD, . Sleep apnea in 81 ambulatory male patients with stable heart failure. Types and their prevalences, consequences, and presentations. Circulation. 1998 Jun 2;97(21):2154–9. doi: 10.1161/01.cir.97.21.2154. PMID: 9626176.9626176
67 Le Jemtel TH, Jelic S. Seek and treat obstructive sleep apnea in heart failure. J Am Coll Cardiol. 2007 Apr 17;49(15):1632–3. doi: 10.1016/j.jacc.2006.11.049. PMID: 17433954.17433954
68 Sin DD, Fitzgerald F, Parker JD, . Risk factors for central and obstructive sleep apnea in 450 men and women with congestive heart failure. Am J Respir Crit Care Med. 1999 Oct;160(4):1101–6. doi: 10.1164/ajrccm.160.4.9903020. PMID: 10508793.10508793
69 Ferrier K, Campbell A, Yee B, . Sleep-disordered breathing occurs frequently in stable outpatients with congestive heart failure. Chest. 2005 Oct;128(4):2116–22. doi: 10.1378/chest.128.4.2116. PMID: 16236863.16236863
70 Schafer H, Koehler U, Ewig S, . Obstructive sleep apnea as a risk marker in coronary artery disease. Cardiology. 1999;92(2):79–84. doi: 10.1159/000006952. PMID: 10702648.10702648
71 Phillips BG, Somers VK. Sleep disordered breathing and risk factors for cardiovascular disease. Curr Opin Pulm Med. 2002 Nov;8(6):516–20. doi: 10.1097/00063198-200211000-00006. PMID: 12394160.12394160
72 Sanner BM, Konermann M, Doberauer C, . Sleep-disordered breathing in patients referred for angina evaluation-association with left ventricular dysfunction. Clin Cardiol. 2001 Feb;24(2):146–50. doi: 10.1002/clc.4960240209. PMID: 11214745.11214745
73 Gami AS, Pressman G, Caples SM, . Association of atrial fibrillation and obstructive sleep apnea. Circulation. 2004 Jul 27;110(4):364–7. doi: 10.1161/01.CIR.0000136587.68725.8E. PMID: 15249509.15249509
74 Jehan S, Farag M, Zizi F, . Obstructive sleep apnea and stroke. Sleep Med Disord. 2018;2(5):120–5. PMID: 30680373.30680373
75 Yaggi HK, Concato J, Kernan WN, . Obstructive sleep apnea as a risk factor for stroke and death. N Engl J Med. 2005 Nov 10;353(19):2034–41. doi: 10.1056/NEJMoa043104. PMID: 16282178.16282178
76 Nieto FJ, Young TB, Lind BK, . Association of sleep-disordered breathing, sleep apnea, and hypertension in a large community-based study. Sleep Heart Health Study. JAMA. 2000 Apr 12;283(14):1829–36. doi: 10.1001/jama.283.14.1829. PMID: 10770144.10770144
77 Richert A, Ansarin K, Baran AS. Sleep apnea and hypertension: pathophysiologic mechanisms. Semin Nephrol. 2002 Jan;22(1):71–7. PMID: 11785071.11785071
78 Ruttanaumpawan P, Nopmaneejumruslers C, Logan AG, . Association between refractory hypertension and obstructive sleep apnea. J Hypertens. 2009 Jul;27(7):1439–45. doi: 10.1097/HJH.0b013e32832af679. PMID: 19421073.19421073
79 Sjostrom C, Lindberg E, Elmasry A, . Prevalence of sleep apnoea and snoring in hypertensive men: a population based study. Thorax. 2002 Jul;57(7):602–7. doi: 10.1136/thorax.57.7.602. PMID: 12096203.12096203
80 Young T, Palta M, Dempsey J, . Burden of sleep apnea: rationale, design, and major findings of the Wisconsin Sleep Cohort study. WMJ. 2009 Aug;108(5):246–9. PMID: 19743755.19743755
81 Einhorn D, Stewart DA, Erman MK, . Prevalence of sleep apnea in a population of adults with type 2 diabetes mellitus. Endocr Pract. 2007 Jul–Aug;13(4):355–62. doi: 10.4158/EP.13.4.355. PMID: 17669711.17669711
82 Punjabi NM, Shahar E, Redline S, . Sleep-disordered breathing, glucose intolerance, and insulin resistance: the Sleep Heart Health Study. Am J Epidemiol. 2004 Sep 15;160(6):521–30. doi: 10.1093/aje/kwh261. PMID: 15353412.15353412
83 Shaw JE, Punjabi NM, Wilding JP, . Sleep-disordered breathing and type 2 diabetes: a report from the International Diabetes Federation Taskforce on Epidemiology and Prevention. Diabetes Res Clin Pract. 2008 Jul;81(1):2–12. doi: 10.1016/j.diabres.2008.04.025. PMID: 18544448.18544448
84 Vgontzas AN, Bixler EO, Chrousos GP. Metabolic disturbances in obesity versus sleep apnoea: the importance of visceral obesity and insulin resistance. J Intern Med. 2003 Jul;254(1):32–44. doi: 10.1046/j.1365-2796.2003.01177.x. PMID: 12823641.12823641
85 Jehan S, Zizi F, Pandi-Perumal SR, . Obstructive sleep apnea and obesity: implications for public health. Sleep Med Disord. 2017;1(4)PMID: 29517065.29517065
86 Mazzotti DR, Keenan BT, Lim DC, . Symptom subtypes of obstructive sleep apnea predict incidence of cardiovascular outcomes. Am J Respir Crit Care Med. 2019 Aug 15;200(4):493–506. doi: 10.1164/rccm.201808-1509OC. PMID: 30764637.30764637
87 Waldman LT, Parthasarathy S, Villa KF, . Understanding the burden of illness of excessive daytime sleepiness associated with obstructive sleep apnea: a qualitative study. Health Qual Life Outcomes. 2020 May 7;18(1):128. doi: 10.1186/s12955-020-01382-4. PMID: 32381095.32381095
88 Chung F, Yegneswaran B, Liao P, . STOP questionnaire: a tool to screen patients for obstructive sleep apnea. Anesthesiology. 2008 May;108(5):812–21. doi: 10.1097/ALN.0b013e31816d83e4. PMID: 18431116.18431116
89 Chung F, Subramanyam R, Liao P, . High STOP-Bang score indicates a high probability of obstructive sleep apnoea. Br J Anaesth. 2012 May;108(5):768–75. doi: 10.1093/bja/aes022. PMID: 22401881.22401881
90 Netzer NC, Stoohs RA, Netzer CM, . Using the Berlin Questionnaire to identify patients at risk for the sleep apnea syndrome. Ann Intern Med. 1999 Oct 5;131(7):485–91. doi: 10.7326/0003-4819-131-7-199910050-00002. PMID: 10507956.10507956
91 Johns MW. A new method for measuring daytime sleepiness: the Epworth sleepiness scale. Sleep. 1991 Dec;14(6):540–5. doi: 10.1093/sleep/14.6.540. PMID: 1798888.1798888
92 Jonas DE, Amick HR, Feltner C, . Screening for Obstructive Sleep Apnea in Adults: An Evidence Review for the US Preventive Services Task Force Agency for Healthcare Research and Quality. Rockville, MD: Agency for Healthcare Research and Quality; 2017.
93 Iber C, Ancoli-Israel S, Chesson A, . The AASM manual for the scoring of sleep and associated events: rules, terminology and technical specifications American Academy of Sleep Medicine. Westchester, IL: 2007.
94 Collop NA, Anderson WM, Boehlecke B, . Clinical guidelines for the use of unattended portable monitors in the diagnosis of obstructive sleep apnea in adult patients. Portable Monitoring Task Force of the American Academy of Sleep Medicine. J Clin Sleep Med. 2007 Dec 15;3(7):737–47. PMID: 18198809.18198809
95 Patil SP, Ayappa IA, Caples SM, . Treatment of adult obstructive sleep apnea with positive airway pressure: an American Academy of Sleep Medicine clinical practice guideline. J Clin Sleep Med. 2019 Feb 15;15(2):335–43. doi: 10.5664/jcsm.7640. PMID: 30736887.30736887
96 Qaseem A, Holty JE, Owens DK, . Management of obstructive sleep apnea in adults: a clinical practice guideline from the American College of Physicians. Ann Intern Med. 2013 Oct 1;159(7):471–83. doi: 10.7326/0003-4819-159-7-201310010-00704. PMID: 24061345.24061345
97 Javaheri S, Caref EB, Chen E, . Sleep apnea testing and outcomes in a large cohort of Medicare beneficiaries with newly diagnosed heart failure. Am J Respir Crit Care Med. 2011 Feb 15;183(4):539–46. doi: 10.1164/rccm.201003-0406OC. PMID: 20656940.20656940
98 Kezirian EJ, Maselli J, Vittinghoff E, . Obstructive sleep apnea surgery practice patterns in the United States: 2000 to 2006. Otolaryngol Head Neck Surg. 2010 Sep;143(3):441–7. doi: 10.1016/j.otohns.2010.05.009. PMID: 20723785.20723785
99 Kent D, Stanley J, Aurora RN, . Referral of adults with obstructive sleep apnea for surgical consultation: an American Academy of Sleep Medicine clinical practice guideline. J Clin Sleep Med. 2021 Dec 1;17(12):2499–505. doi: 10.5664/jcsm.9592. PMID: 34351848.34351848
100 Mold JW, Quattlebaum C, Schinnerer E, . Identification by primary care clinicians of patients with obstructive sleep apnea: a practice-based research network (PBRN) study. J Am Board Fam Med. 2011 Mar–Apr;24(2):138–45. doi: 10.3122/jabfm.2011.02.100095. PMID: 21383212.21383212
101 Sánchez-Quiroga M, Corral J, Gómez-de-Terreros FJ, . Primary care physicians can comprehensively manage patients with sleep apnea. A noninferiority randomized controlled trial. Am J Respir Crit Care Med. 2018 Sep 1;198(5):648–56. doi: 10.1164/rccm.201710-2061OC. PMID: 29664672.29664672
102 Aurora RN, Quan SF. Quality measure for screening for adult obstructive sleep apnea by primary care physicians. J Clin Sleep Med. 2016 Aug 15;12(8):1185–7. doi: 10.5664/jcsm.6064. PMID: 27397659.27397659
103 U.S. Department of Veterans Affairs. VA/DoD Clinical Practice Guidelines: The Management of Chronic Insomnia Disorder and Obstructive Sleep Apnea (Insomnia/OSA). 2019. https://www.healthquality.va.gov/guidelines/CD/insomnia/index.asp.
104 United Nations Development Programme. Human Development Report 2020 Published for the United Nations Development Program. 0969–4501. New York, NY: 2020.
105 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011 Oct 18;155(8):529–36. doi: 10.7326/0003-4819-155-8-201110180-00009. PMID: 22007046.22007046
106 Shea BJ, Grimshaw JM, Wells GA, . Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007 Feb 15;7:10. doi: 10.1186/1471-2288-7-10. PMID: 17302989.17302989
107 West SL, Gartlehner G, Mansfield AJ, . Comparative Effectiveness Review Methods: Clinical Heterogeneity Agency for Healthcare Research and Quality. Report No. 10-EHC070-EF. Rockville, MD: 2010. https://www.ncbi.nlm.nih.gov/pubmed/21433337
108 StataCorp. StataCorp. Stata statistical software: release 16.0: StataCorp LP; 2019.
109 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002 Jun 15;21(11):1539–58. doi: 10.1002/sim.1186. PMID: 12111919.12111919
110 Higgins JP, Thompson SG, Deeks JJ, . Measuring inconsistency in meta-analyses. BMJ. 2003 Sep 6;327(7414):557–60. doi: 10.1136/bmj.327.7414.557. PMID: 12958120.12958120
111 Higgins J, Green S. Cochrane Handbook for Systematic Reviews of Interventions: the cochrane collaboration The Cochrane Collaboration. London: March 2011.
112 Hrubos-Strom H, Randby A, Namtvedt SK, . A Norwegian population-based study on the risk and prevalence of obstructive sleep apnea. The Akershus Sleep Apnea Project (ASAP). J Sleep Res. 2011 Mar;20(1 pt 2):162–70. doi: 10.1111/j.1365-2869.2010.00861.x. PMID: 20561172.20561172
113 Morales CR, Hurley S, Wick LC, . In-home, self-assembled sleep studies are useful in diagnosing sleep apnea in the elderly. Sleep. 2012 Nov 1;35(11):1491–501. doi: 10.5665/sleep.2196. PMID: 23115398.23115398
114 Gurubhagavatula I, Fields BG, Morales CR, . Screening for severe obstructive sleep apnea syndrome in hypertensive outpatients. J Clin Hypertens (Greenwich). 2013 Apr;15(4):279–88. doi: 10.1111/jch.12073. PMID: 23551728.23551728
115 Edmonds PJ, Gunasekaran K, Edmonds LC. Neck grasp predicts obstructive sleep apnea in type 2 diabetes mellitus. Sleep Disord. 2019;2019:3184382. doi: 10.1155/2019/3184382. PMID: 31355009.31355009
116 Jorge C, Benítez I, Torres G, . The STOP-Bang and Berlin questionnaires to identify obstructive sleep apnoea in Alzheimer’s disease patients. Sleep Med. 2019 May;57:15–20. doi: 10.1016/j.sleep.2019.01.033. PMID: 30897451.30897451
117 Shin C, Baik I. Evaluation of a modified STOP-BANG questionnaire for sleep apnea in adults from the Korean general population. Sleep Med Res. 2021;12(1):28–35. doi: 10.17241/SMR.2020.00808.
118 Selvanathan J, Waseem R, Peng P, . Simple screening model for identifying the risk of sleep apnea in patients on opioids for chronic pain. Reg Anesth Pain Med. 2021doi: 10.1136/rapm-2020-102388.
119 Farney RJ, Walker BS, Farney RM, . The STOP-Bang equivalent model and prediction of severity of obstructive sleep apnea: relation to polysomnographic measurements of the apnea/hypopnea index. J Clin Sleep Med. 2011 Oct 15;7(5):459–65B. doi: 10.5664/JCSM.1306. PMID: 22003340.22003340
120 Maislin G, Pack AI, Kribbs NB, . A survey screen for prediction of apnea. Sleep. 1995 Apr;18(3):158–66. doi: 10.1093/sleep/18.3.158. PMID: 7610311.7610311
121 Lloyd-Jones DM. Cardiovascular risk prediction: basic concepts, current status, and future directions. Circulation. 2010 Apr 20;121(15):1768–77. doi: 10.1161/CIRCULATIONAHA.109.849166. PMID: 20404268.20404268
122 Hosmer DW, Lemeshow S. Applied Logistic Regression. New York, NY: John Wiley & Sons; 2000.
123 de Vries GE, Wijkstra PJ, Houwerzijl EJ, . Cardiovascular effects of oral appliance therapy in obstructive sleep apnea: a systematic review and meta-analysis. Sleep Med Rev. 2018 Aug;40:55–68. doi: 10.1016/j.smrv.2017.10.004. PMID: 29195726.29195726
124 Labarca G, Schmidt A, Dreyse J, . Efficacy of continuous positive airway pressure (CPAP) in patients with obstructive sleep apnea (OSA) and resistant hypertension (RH): systematic review and meta-analysis. Sleep Med Rev. 2021 Aug;58:101446. doi: 10.1016/j.smrv.2021.101446. PMID: 33607443.33607443
125 Patil SP, Ayappa IA, Caples SM, . Treatment of adult obstructive sleep apnea with positive airway pressure: an American Academy of Sleep Medicine systematic review, meta-analysis, and GRADE assessment. J Clin Sleep Med. 2019 Feb 15;15(2):301–34. doi: 10.5664/jcsm.7638. PMID: 30736888.30736888
126 Zhang D, Luo J, Qiao Y, . Continuous positive airway pressure therapy in non-sleepy patients with obstructive sleep apnea: results of a meta-analysis. J Thorac Dis. 2016 Oct;8(10):2738–47. doi: 10.21037/jtd.2016.09.40. PMID: 27867549.27867549
127 Barbe F, Mayoralas LR, Duran J, . Treatment with continuous positive airway pressure is not effective in patients with sleep apnea but no daytime sleepiness. a randomized, controlled trial. Ann Intern Med. 2001 Jun 5;134(11):1015–23. doi: 10.7326/0003-4819-134-11-200106050-00007. PMID: 11388814.11388814
128 Arias MA, Garcia-Rio F, Alonso-Fernandez A, . Obstructive sleep apnea syndrome affects left ventricular diastolic function: effects of nasal continuous positive airway pressure in men. Circulation. 2005 Jul 19;112(3):375–83. doi: 10.1161/CIRCULATIONAHA.104.501841. PMID: 16009798.16009798
129 Campos-Rodriguez F, Grilo-Reina A, Perez-Ronchel J, . Effect of continuous positive airway pressure on ambulatory BP in patients with sleep apnea and hypertension: a placebo-controlled trial. Chest. 2006 Jun;129(6):1459–67. doi: 10.1378/chest.129.6.1459. PMID: 16778262.16778262
130 Chasens ER, Korytkowski M, Sereika SM, . Improving activity in adults with diabetes and coexisting obstructive sleep apnea. West J Nurs Res. 2014 Mar;36(3):294–311. doi: 10.1177/0193945913500567. PMID: 23976778.23976778
131 Chong MS, Ayalon L, Marler M, . Continuous positive airway pressure reduces subjective daytime sleepiness in patients with mild to moderate Alzheimer’s disease with sleep disordered breathing. J Am Geriatr Soc. 2006 May;54(5):777–81. doi: 10.1111/j.1532-5415.2006.00694.x. PMID: 16696743.16696743
132 Coughlin SR, Mawdsley L, Mugarza JA, . Cardiovascular and metabolic effects of CPAP in obese males with OSA. Eur Respir J. 2007 Apr;29(4):720–7. doi: 10.1183/09031936.00043306. PMID: 17251237.17251237
133 Duran-Cantolla J, Aizpuru F, Montserrat JM, . Continuous positive airway pressure as treatment for systemic hypertension in people with obstructive sleep apnoea: randomised controlled trial. BMJ. 2010 Nov 24;341:c5991. doi: 10.1136/bmj.c5991. PMID: 21106625.21106625
134 Egea CJ, Aizpuru F, Pinto JA, . Cardiac function after CPAP therapy in patients with chronic heart failure and sleep apnea: a multicenter study. Sleep Med. 2008 Aug;9(6):660–6. doi: 10.1016/j.sleep.2007.06.018. PMID: 17904420.17904420
135 Haensel A, Norman D, Natarajan L, . Effect of a 2 week CPAP treatment on mood states in patients with obstructive sleep apnea: a double-blind trial. Sleep Breath. 2007 Dec;11(4):239–44. doi: 10.1007/s11325-007-0115-0. PMID: 17503102.17503102
136 Hoyos CM, Killick R, Yee BJ, . Cardiometabolic changes after continuous positive airway pressure for obstructive sleep apnoea: a randomised sham-controlled study. Thorax. 2012 Dec;67(12):1081–9. doi: 10.1136/thoraxjnl-2011-201420. PMID: 22561530.22561530
137 Hui DS, To KW, Ko FW, . Nasal CPAP reduces systemic blood pressure in patients with obstructive sleep apnoea and mild sleepiness. Thorax. 2006 Dec;61(12):1083–90. doi: 10.1136/thx.2006.064063. PMID: 16928705.16928705
138 Jenkinson C, Davies RJ, Mullins R, . Comparison of therapeutic and subtherapeutic nasal continuous positive airway pressure for obstructive sleep apnoea: a randomised prospective parallel trial. Lancet. 1999 Jun 19;353(9170):2100–5. doi: 10.1016/S0140-6736(98)10532-9. PMID: 10382693.10382693
139 Hack M, Davies RJ, Mullins R, . Randomised prospective parallel trial of therapeutic versus subtherapeutic nasal continuous positive airway pressure on simulated steering performance in patients with obstructive sleep apnoea. Thorax. 2000 Mar;55(3):224–31. doi: 10.1136/thorax.55.3.224. PMID: 10679542.10679542
140 Jones A, Vennelle M, Connell M, . The effect of continuous positive airway pressure therapy on arterial stiffness and endothelial function in obstructive sleep apnea: a randomized controlled trial in patients without cardiovascular disease. Sleep Med. 2013 Dec;14(12):1260–5. doi: 10.1016/j.sleep.2013.08.786. PMID: 24210600.24210600
141 Kushida CA, Nichols DA, Holmes TH, . Effects of continuous positive airway pressure on neurocognitive function in obstructive sleep apnea patients: the Apnea Positive Pressure Long-term Efficacy Study (APPLES). Sleep. 2012 Dec 1;35(12):1593–602. doi: 10.5665/sleep.2226. PMID: 23204602.23204602
142 Batool-Anwar S, Goodwin JL, Kushida CA, . Impact of continuous positive airway pressure (CPAP) on quality of life in patients with obstructive sleep apnea (OSA). J Sleep Res. 2016 Dec;25(6):731–8. doi: 10.1111/jsr.12430. PMID: 27242272.27242272
143 Lam JC, Lam B, Yao TJ, . A randomised controlled trial of nasal continuous positive airway pressure on insulin sensitivity in obstructive sleep apnoea. Eur Respir J. 2010 Jan;35(1):138–45. doi: 10.1183/09031936.00047709. PMID: 19608589.19608589
144 Lee IS, Bardwell WA, Kamat R, . A model for studying neuropsychological effects of sleep intervention: the effect of 3-week continuous positive airway pressure treatment. Drug Discov Today Dis Models. 2011 Winter;8(4):147–54. doi: 10.1016/j.ddmod.2011.10.001. PMID: 22140396.22140396
145 Loredo JS, Ancoli-Israel S, Kim EJ, . Effect of continuous positive airway pressure versus supplemental oxygen on sleep quality in obstructive sleep apnea: a placebo-CPAP-controlled study. Sleep. 2006 Apr;29(4):564–71. doi: 10.1093/sleep/29.4.564. PMID: 16676791.16676791
146 Marshall NS, Neill AM, Campbell AJ, . Randomised controlled crossover trial of humidified continuous positive airway pressure in mild obstructive sleep apnoea. Thorax. 2005 May;60(5):427–32. doi: 10.1136/thx.2004.032078. PMID: 15860720.15860720
147 Melehan KL, Hoyos CM, Hamilton GS, . Randomized trial of CPAP and vardenafil on erectile and arterial function in men with obstructive sleep apnea and erectile dysfunction. J Clin Endocrinol Metab. 2018 Apr 1;103(4):1601–11. doi: 10.1210/jc.2017-02389. PMID: 29409064.29409064
148 Montserrat JM, Ferrer M, Hernandez L, . Effectiveness of CPAP treatment in daytime function in sleep apnea syndrome: a randomized controlled study with an optimized placebo. Am J Respir Crit Care Med. 2001 Aug 15;164(4):608–13. doi: 10.1164/ajrccm.164.4.2006034. PMID: 11520724.11520724
149 Neikrug AB, Liu L, Avanzino JA, . Continuous positive airway pressure improves sleep and daytime sleepiness in patients with Parkinson disease and sleep apnea. Sleep. 2014 Jan 1;37(1):177–85. doi: 10.5665/sleep.3332. PMID: 24470706.24470706
150 Nguyen PK, Katikireddy CK, McConnell MV, . Nasal continuous positive airway pressure improves myocardial perfusion reserve and endothelial-dependent vasodilation in patients with obstructive sleep apnea. J Cardiovasc Magn Reson. 2010 Sep 3;12:50. doi: 10.1186/1532-429X-12-50. PMID: 20815898.20815898
151 Pepperell JC, Ramdassingh-Dow S, Crosthwaite N, . Ambulatory blood pressure after therapeutic and subtherapeutic nasal continuous positive airway pressure for obstructive sleep apnoea: a randomised parallel trial. Lancet. 2002 Jan 19;359(9302):204–10. doi: 10.1016/S0140-6736(02)07445-7. PMID: 11812555.11812555
152 Kohler M, Pepperell JC, Casadei B, . CPAP and measures of cardiovascular risk in males with OSAS. Eur Respir J. 2008 Dec;32(6):1488–96. doi: 10.1183/09031936.00026608. PMID: 18653654.18653654
153 Phillips CL, Yee BJ, Marshall NS, . Continuous positive airway pressure reduces postprandial lipidemia in obstructive sleep apnea: a randomized, placebo-controlled crossover trial. Am J Respir Crit Care Med. 2011 Aug 1;184(3):355–61. doi: 10.1164/rccm.201102-0316OC. PMID: 21527567.21527567
154 Robinson GV, Smith DM, Langford BA, . Continuous positive airway pressure does not reduce blood pressure in nonsleepy hypertensive OSA patients. Eur Respir J. 2006 Jun;27(6):1229–35. doi: 10.1183/09031936.06.00062805. PMID: 16455835.16455835
155 Siccoli MM, Pepperell JC, Kohler M, . Effects of continuous positive airway pressure on quality of life in patients with moderate to severe obstructive sleep apnea: data from a randomized controlled trial. Sleep. 2008 Nov;31(11):1551–8. doi: 10.1093/sleep/31.11.1551. PMID: 19014075.19014075
156 Smith LA, Vennelle M, Gardner RS, . Auto-titrating continuous positive airway pressure therapy in patients with chronic heart failure and obstructive sleep apnoea: a randomized placebo-controlled trial. Eur Heart J. 2007 May;28(10):1221–7. doi: 10.1093/eurheartj/ehm131. PMID: 17470670.17470670
157 Weaver TE, Mancini C, Maislin G, . Continuous positive airway pressure treatment of sleepy patients with milder obstructive sleep apnea: results of the CPAP Apnea Trial North American Program (CATNAP) randomized clinical trial. Am J Respir Crit Care Med. 2012 Oct 1;186(7):677–83. doi: 10.1164/rccm.201202-0200OC. PMID: 22837377.22837377
158 West SD, Nicoll DJ, Wallace TM, . Effect of CPAP on insulin resistance and HbA1c in men with obstructive sleep apnoea and type 2 diabetes. Thorax. 2007 Nov;62(11):969–74. doi: 10.1136/thx.2006.074351. PMID: 17557769.17557769
159 West SD, Kohler M, Nicoll DJ, . The effect of continuous positive airway pressure treatment on physical activity in patients with obstructive sleep apnoea: a randomised controlled trial. Sleep Med. 2009 Oct;10(9):1056–8. doi: 10.1016/j.sleep.2008.11.007. PMID: 19427263.19427263
160 Ballester E, Badia JR, Hernandez L, . Evidence of the effectiveness of continuous positive airway pressure in the treatment of sleep apnea/hypopnea syndrome. Am J Respir Crit Care Med. 1999 Feb;159(2):495–501. doi: 10.1164/ajrccm.159.2.9804061. PMID: 9927363.9927363
161 Banghøj AM, Krogager C, Kristensen PL, . Effect of 12-week continuous positive airway pressure therapy on glucose levels assessed by continuous glucose monitoring in people with type 2 diabetes and obstructive sleep apnoea; a randomized controlled trial. Endocrinol Diabetes Metab. 2021;4(2):e00148. doi: 10.1002/edm2.148. PMID: 33855195.33855195
162 Barbe F, Duran-Cantolla J, Capote F, . Long-term effect of continuous positive airway pressure in hypertensive patients with sleep apnea. Am J Respir Crit Care Med. 2010 Apr 1;181(7):718–26. doi: 10.1164/rccm.200901-0050OC. PMID: 20007932.20007932
163 Barbe F, Duran-Cantolla J, Sanchez-de-la-Torre M, . Effect of continuous positive airway pressure on the incidence of hypertension and cardiovascular events in nonsleepy patients with obstructive sleep apnea: a randomized controlled trial. JAMA. 2012 May 23;307(20):2161–8. doi: 10.1001/jama.2012.4366. PMID: 22618923.22618923
164 Barnes M, McEvoy RD, Banks S, . Efficacy of positive airway pressure and oral appliance in mild to moderate obstructive sleep apnea. Am J Respir Crit Care Med. 2004 Sep 15;170(6):656–64. doi: 10.1164/rccm.200311-1571OC. PMID: 15201136.15201136
165 Campos-Rodriguez F, Queipo-Corona C, Carmona-Bernal C, . Continuous positive airway pressure improves quality of life in women with obstructive sleep apnea. A randomized controlled trial. Am J Respir Crit Care Med. 2016 Nov 15;194(10):1286–94. doi: 10.1164/rccm.201602-0265OC. PMID: 27181196.27181196
166 Craig SE, Kohler M, Nicoll D, . Continuous positive airway pressure improves sleepiness but not calculated vascular risk in patients with minimally symptomatic obstructive sleep apnoea: the MOSAIC randomised controlled trial. Thorax. 2012 Dec;67(12):1090–6. doi: 10.1136/thoraxjnl-2012-202178. PMID: 23111478.23111478
167 Dalmases M, Solé-Padullés C, Torres M, . Effect of CPAP on cognition, brain function, and structure among elderly patients with OSA: a randomized pilot study. Chest. 2015 Nov;148(5):1214–23. doi: 10.1378/chest.15-0171. PMID: 26065720.26065720
168 Engleman HM, Martin SE, Deary IJ, . Effect of continuous positive airway pressure treatment on daytime function in sleep apnoea/hypopnoea syndrome. Lancet. 1994 Mar 5;343(8897):572–5. doi: 10.1016/s0140-6736(94)91522-9. PMID: 7906330.7906330
169 Engleman HM, Martin SE, Deary IJ, . Effect of CPAP therapy on daytime function in patients with mild sleep apnoea/hypopnoea syndrome. Thorax. 1997 Feb;52(2):114–9. doi: 10.1136/thx.52.2.114. PMID: 9059469.9059469
170 Engleman HM, Martin SE, Kingshott RN, . Randomised placebo controlled trial of daytime function after continuous positive airway pressure (CPAP) therapy for the sleep apnoea/hypopnoea syndrome. Thorax. 1998 May;53(5):341–5. doi: 10.1136/thx.53.5.341. PMID: 9708223.9708223
171 Engleman HM, Kingshott RN, Wraith PK, . Randomized placebo-controlled crossover trial of continuous positive airway pressure for mild sleep Apnea/Hypopnea syndrome. Am J Respir Crit Care Med. 1999 Feb;159(2):461–7. doi: 10.1164/ajrccm.159.2.9803121. PMID: 9927358.9927358
172 Faccenda JF, Mackay TW, Boon NA, . Randomized placebo-controlled trial of continuous positive airway pressure on blood pressure in the sleep apnea-hypopnea syndrome. Am J Respir Crit Care Med. 2001 Feb;163(2):344–8. doi: 10.1164/ajrccm.163.2.2005037. PMID: 11179104.11179104
173 Gottlieb DJ, Punjabi NM, Mehra R, . CPAP versus oxygen in obstructive sleep apnea. N Engl J Med. 2014 Jun 12;370(24):2276–85. doi: 10.1056/NEJMoa1306766. PMID: 24918372.24918372
174 Lewis EF, Wang R, Punjabi N, . Impact of continuous positive airway pressure and oxygen on health status in patients with coronary heart disease, cardiovascular risk factors, and obstructive sleep apnea: A Heart Biomarker Evaluation in Apnea Treatment (HEARTBEAT) analysis. Am Heart J. 2017 Jul;189:59–67. doi: 10.1016/j.ahj.2017.03.001. PMID: 28625382.28625382
175 Jackson ML, Tolson J, Schembri R, . Does continuous positive airways pressure treatment improve clinical depression in obstructive sleep apnea? A randomized wait-list controlled study. Depress Anxiety. 2021 May;38(5):498–507. doi: 10.1002/da.23131. PMID: 33368782.33368782
176 Jackson ML, Tolson J, Bartlett D, . Clinical depression in untreated obstructive sleep apnea: examining predictors and a meta-analysis of prevalence rates. Sleep Med. 2019 Oct;62:22–8. doi: 10.1016/j.sleep.2019.03.011. PMID: 31525678.31525678
177 Lam B, Sam K, Mok WY, . Randomised study of three non-surgical treatments in mild to moderate obstructive sleep apnoea. Thorax. 2007 Apr;62(4):354–9. doi: 10.1136/thx.2006.063644. PMID: 17121868.17121868
178 Lim W, Bardwell WA, Loredo JS, . Neuropsychological effects of 2-week continuous positive airway pressure treatment and supplemental oxygen in patients with obstructive sleep apnea: a randomized placebo-controlled study. J Clin Sleep Med. 2007 Jun 15;3(4):380–6. PMID: 17694727.17694727
179 Lui MMS, Mak JCW, Chong PWC, . Circulating adipocyte fatty acid-binding protein is reduced by continuous positive airway pressure treatment for obstructive sleep apnea-a randomized controlled study. Sleep Breath. 2020 Sep;24(3):817–24. doi: 10.1007/s11325-019-01893-5. PMID: 31372823.31372823
180 Martinez-Garcia MA, Capote F, Campos-Rodriguez F, . Effect of CPAP on blood pressure in patients with obstructive sleep apnea and resistant hypertension: the HIPARCO randomized clinical trial. JAMA. 2013 Dec 11;310(22):2407–15. doi: 10.1001/jama.2013.281250. PMID: 24327037.24327037
181 Martínez-García M, Chiner E, Hernández L, . Obstructive sleep apnoea in the elderly: role of continuous positive airway pressure treatment. Eur Respir J. 2015 Jul;46(1):142–51. doi: 10.1183/09031936.00064214. PMID: 26022945.26022945
182 Masa JF, Corral J, Alonso ML, . Efficacy of different treatment alternatives for obesity hypoventilation syndrome. Pickwick Study. Am J Respir Crit Care Med. 2015 Jul 1;192(1):86–95. doi: 10.1164/rccm.201410-1900OC. PMID: 25915102.25915102
183 McArdle N, Douglas NJ. Effect of continuous positive airway pressure on sleep architecture in the sleep apnea-hypopnea syndrome: a randomized controlled trial. Am J Respir Crit Care Med. 2001 Oct 15;164(8 pt 1):1459–63. doi: 10.1164/ajrccm.164.8.2008146. PMID: 11704596.11704596
184 McMillan A, Bratton DJ, Faria R, . Continuous positive airway pressure in older people with obstructive sleep apnoea syndrome (PREDICT): a 12-month, multicentre, randomised trial. Lancet Respir Med. 2014 Oct;2(10):804–12. doi: 10.1016/S2213-2600(14)70172-9. PMID: 25172769.25172769
185 Peker Y, Glantz H, Eulenburg C, . Effect of positive airway pressure on cardiovascular outcomes in coronary artery disease patients with nonsleepy obstructive sleep apnea. The RICCADSA Randomized Controlled Trial. Am J Respir Crit Care Med. 2016 Sep 1;194(5):613–20. doi: 10.1164/rccm.201601-0088OC. PMID: 26914592.26914592
186 Balcan B, Thunström E, Strollo PJ, Jr., . Continuous positive airway pressure treatment and depression in adults with coronary artery disease and nonsleepy obstructive sleep apnea. A secondary analysis of the RICCADSA Trial. Ann Am Thorac Soc. 2019 Jan;16(1):62–70. doi: 10.1513/AnnalsATS.201803-174OC. PMID: 30130421.30130421
187 Celik Y, Thunström E, Strollo PJ, . Continuous positive airway pressure treatment and anxiety in adults with coronary artery disease and nonsleepy obstructive sleep apnea in the RICCADSA trial. Sleep Medicine. 2021;77:96–103. doi: 10.1016/j.sleep.2020.11.034. PMID: 33341644.33341644
188 Ponce S, Pastor E, Orosa B, . The role of CPAP treatment in elderly patients with moderate obstructive sleep apnoea: a multicentre randomised controlled trial. Eur Respir J. 2019 Aug;54(2)doi: 10.1183/13993003.00518-2019. PMID: 31164429.31164429
189 Redline S, Adams N, Strauss ME, . Improvement of mild sleep-disordered breathing with CPAP compared with conservative therapy. Am J Respir Crit Care Med. 1998 Mar;157(3 pt 1):858–65. doi: 10.1164/ajrccm.157.3.9709042. PMID: 9517603.9517603
190 Ruttanaumpawan P, Gilman MP, Usui K, . Sustained effect of continuous positive airway pressure on baroreflex sensitivity in congestive heart failure patients with obstructive sleep apnea. J Hypertens. 2008 Jun;26(6):1163–8. doi: 10.1097/HJH.0b013e3282fb81ed. PMID: 18475154.18475154
191 Kaneko Y, Floras JS, Usui K, . Cardiovascular effects of continuous positive airway pressure in patients with heart failure and obstructive sleep apnea. N Engl J Med. 2003 Mar 27;348(13):1233–41. doi: 10.1056/NEJMoa022479. PMID: 12660387.12660387
192 Salord N, Fortuna AM, Monasterio C, . A randomized controlled trial of continuous positive airway pressure on glucose tolerance in obese patients with obstructive sleep apnea. Sleep. 2016 Jan 1;39(1):35–41. doi: 10.5665/sleep.5312. PMID: 26350474.26350474
193 Shaw JE, Punjabi NM, Naughton MT, . The effect of treatment of obstructive sleep apnea on glycemic control in type 2 diabetes. Am J Respir Crit Care Med. 2016 Aug 15;194(4):486–92. doi: 10.1164/rccm.201511-2260OC. PMID: 26926656.26926656
194 Tomfohr LM, Ancoli-Israel S, Loredo JS, . Effects of continuous positive airway pressure on fatigue and sleepiness in patients with obstructive sleep apnea: data from a randomized controlled trial. Sleep. 2011 Jan 1;34(1):121–6. doi: 10.1093/sleep/34.1.121. PMID: 21203367.21203367
195 Wimms AJ, Kelly JL, Turnbull CD, . Continuous positive airway pressure versus standard care for the treatment of people with mild obstructive sleep apnoea (MERGE): a multicentre, randomised controlled trial. Lancet Respir Med. 2020 Apr;8(4):349–58. doi: 10.1016/s2213-2600(19)30402-3. PMID: 31806413.31806413
196 Zhao YY, Wang R, Gleason KJ, . Effect of continuous positive airway pressure treatment on health-related quality of life and sleepiness in high cardiovascular risk individuals with sleep apnea: Best Apnea Interventions for Research (BestAIR) Trial. Sleep. 2017 Apr 1;40(4)doi: 10.1093/sleep/zsx040. PMID: 28419387.28419387
197 Ng SSS, Chan TO, To KW, . Continuous positive airway pressure for obstructive sleep apnoea does not improve asthma control. Respirology. 2018 Nov;23(11):1055–62. doi: 10.1111/resp.13363. PMID: 29992713.29992713
198 Celik Y, Yapici-Eser H, Balcan B, . Association of excessive daytime sleepiness with the Zung self-rated depression subscales in adults with coronary artery disease and obstructive sleep apnea. Diagnostics. 2021;11(7):1176. doi: 10.3390/diagnostics11071176. PMID: 34203553.34203553
199 Traaen GM, Aakerøy L, Hunt TE, . Effect of continuous positive airway pressure on arrhythmia in atrial fibrillation and sleep apnea: a randomized controlled trial. Am J Respir Crit Care Med. 2021 May 3doi: 10.1164/rccm.202011-4133OC. PMID: 33938787.33938787
200 Wallstrom S, Balcan B, Thunstrom E, . CPAP and health-related quality of life in adults with coronary artery disease and nonsleepy obstructive sleep apnea in the RICCADSA trial. J Clin Sleep Med. 2019 Sep 15;15(9):1311–20. doi: 10.5664/jcsm.7926. PMID: 31538602.31538602
201 Weinstock TG, Wang X, Rueschman M, . A controlled trial of CPAP therapy on metabolic control in individuals with impaired glucose tolerance and sleep apnea. Sleep. 2012 May 1;35(5):617–25B. doi: 10.5665/sleep.1816. PMID: 22547887.22547887
202 Ware JE, Jr., Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. 1992 Jun;30(6):473–83. PMID: 1593914.1593914
203 Wyrwich KW, Tierney WM, Babu AN, . A comparison of clinically important differences in health-related quality of life for patients with chronic lung disease, asthma, or heart disease. Health Serv Res. 2005 Apr;40(2):577–91. doi: 10.1111/j.1475-6773.2005.00373.x. PMID: 15762908.15762908
204 Patel S, Kon SSC, Nolan CM, . The Epworth Sleepiness Scale: minimum clinically important difference in obstructive sleep apnea. Am J Respir Crit Care Med. 2018 Apr 1;197(7):961–3. doi: 10.1164/rccm.201704-0672LE. PMID: 28961021.28961021
205 Crook S, Sievi NA, Bloch KE, . Minimum important difference of the Epworth Sleepiness Scale in obstructive sleep apnoea: estimation from three randomised controlled trials. Thorax. 2019 Apr;74(4):390–6. doi: 10.1136/thoraxjnl-2018-211959. PMID: 30100576.30100576
206 Aarab G, Lobbezoo F, Hamburger HL, . Oral appliance therapy versus nasal continuous positive airway pressure in obstructive sleep apnea: a randomized, placebo-controlled trial. Respiration. 2011;81(5):411–9. doi: 10.1159/000319595. PMID: 20962502.20962502
207 Nikolopoulou M, Aarab G, Ahlberg J, . Oral appliance therapy versus nasal continuous positive airway pressure in obstructive sleep apnea: a randomized, placebo-controlled trial on temporomandibular side-effects. Clin Exp Dent Res. 2020 Aug;6(4):400–6. doi: 10.1002/cre2.288. PMID: 32246748.32246748
208 Andren A, Hedberg P, Walker-Engstrom ML, . Effects of treatment with oral appliance on 24-h blood pressure in patients with obstructive sleep apnea and hypertension: a randomized clinical trial. Sleep Breath. 2013 May;17(2):705–12. doi: 10.1007/s11325-012-0746-7. PMID: 22821223.22821223
209 Bloch KE, Iseli A, Zhang JN, . A randomized, controlled crossover trial of two oral appliances for sleep apnea treatment. Am J Respir Crit Care Med. 2000 Jul;162(1):246–51. doi: 10.1164/ajrccm.162.1.9908112. PMID: 10903249.10903249
210 Durán-Cantolla J, Crovetto-Martínez R, Alkhraisat MH, . Efficacy of mandibular advancement device in the treatment of obstructive sleep apnea syndrome: a randomized controlled crossover clinical trial. Med Oral Patol Oral Cir Bucal. 2015 Sep 1;20(5):e605–e15. doi: 10.4317/medoral.20649. PMID: 26241460.26241460
211 Naismith SL, Winter VR, Hickie IB, . Effect of oral appliance therapy on neurobehavioral functioning in obstructive sleep apnea: a randomized controlled trial. J Clin Sleep Med. 2005 Oct 15;1(4):374–80. PMID: 17564405.17564405
212 Gotsopoulos H, Chen C, Qian J, . Oral appliance therapy improves symptoms in obstructive sleep apnea: a randomized, controlled trial. Am J Respir Crit Care Med. 2002 Sep 1;166(5):743–8. doi: 10.1164/rccm.200203-208OC. PMID: 12204875.12204875
213 Gotsopoulos H, Kelly JJ, Cistulli PA. Oral appliance therapy reduces blood pressure in obstructive sleep apnea: a randomized, controlled trial. Sleep. 2004 Aug 1;27(5):934–41. doi: 10.1093/sleep/27.5.934. PMID: 15453552.15453552
214 Johnston CD, Gleadhill IC, Cinnamond MJ, . Mandibular advancement appliances and obstructive sleep apnoea: a randomized clinical trial. Eur J Orthod. 2002 Jun;24(3):251–62. doi: 10.1093/ejo/24.3.251. PMID: 12143089.12143089
215 Quinnell TG, Bennett M, Jordan J, . A crossover randomised controlled trial of oral mandibular advancement devices for obstructive sleep apnoea-hypopnoea (TOMADO). Thorax. 2014 Oct;69(10):938–45. doi: 10.1136/thoraxjnl-2014-205464. PMID: 25035126.25035126
216 Gagnadoux F, Pépin JL, Vielle B, . Impact of mandibular advancement therapy on endothelial function in severe obstructive sleep apnea. Am J Respir Crit Care Med. 2017 May 1;195(9):1244–52. doi: 10.1164/rccm.201609-1817OC. PMID: 28128967.28128967
217 Marklund M, Carlberg B, Forsgren L, . Oral appliance therapy in patients with daytime sleepiness and snoring or mild to moderate sleep apnea: a randomized clinical trial. JAMA Intern Med. 2015 Aug;175(8):1278–85. doi: 10.1001/jamainternmed.2015.2051. PMID: 26030264.26030264
218 Petri N, Svanholt P, Solow B, . Mandibular advancement appliance for obstructive sleep apnoea: results of a randomised placebo controlled trial using parallel group design. J Sleep Res. 2008 Jun;17(2):221–9. doi: 10.1111/j.1365-2869.2008.00645.x. PMID: 18482111.18482111
219 Malow BA, Foldvary-Schaefer N, Vaughn BV, . Treating obstructive sleep apnea in adults with epilepsy: a randomized pilot trial. Neurology. 2008 Aug 19;71(8):572–7. doi: 10.1212/01.wnl.0000323927.13250.54. PMID: 18711110.18711110
220 Redline S. Effects of treatment of sleep apnea on metabolic syndrome National Institutes of Health, National Center for Research Resources, Beth Israel Deaconess Medical Center and Case Western Reserve University. Bethesda, MD: 2014. http://ClinicalTrials.gov/show/NCT01385995
221 Goehring C, Perrier A, Morabia A. Spectrum bias: a quantitative and graphical analysis of the variability of medical diagnostic test performance. Stat Med. 2004 Jan 15;23(1):125–35. doi: 10.1002/sim.1591. PMID: 14695644.14695644
222 Mulherin SA, Miller WC. Spectrum bias or spectrum effect? Subgroup variation in diagnostic test evaluation. Ann Intern Med. 2002 Oct 1;137(7):598–602. doi: 10.7326/0003-4819-137-7-200210010-00011. PMID: 12353947.12353947
223 Jelinek M. Spectrum bias: why generalists and specialists do not connect. Evid Based Med. 2008 Oct;13(5):132–3. doi: 10.1136/ebm.13.5.132. PMID: 18836102.18836102
224 Lachs MS, Nachamkin I, Edelstein PH, . Spectrum bias in the evaluation of diagnostic tests: lessons from the rapid dipstick test for urinary tract infection. Ann Intern Med. 1992 Jul 15;117(2):135–40. doi: 10.7326/0003-4819-117-2-135. PMID: 1605428.1605428
225 Willis BH. Spectrum bias—why clinicians need to be cautious when applying diagnostic test studies. Fam Pract. 2008 Oct;25(5):390–6. doi: 10.1093/fampra/cmn051. PMID: 18765409.18765409
226 Qaseem A, Dallas P, Owens DK, . Diagnosis of obstructive sleep apnea in adults: a clinical practice guideline from the American College of Physicians. Ann Intern Med. 2014 Aug 5;161(3):210–20. doi: 10.7326/M12-3187. PMID: 25089864.25089864
227 Johns M, Hocking B. Daytime sleepiness and sleep habits of Australian workers. Sleep. 1997 Oct;20(10):844–9. doi: 10.1093/sleep/20.10.844. PMID: 9415943.9415943
228 Johns MW. Sensitivity and specificity of the Multiple Sleep Latency Test (MSLT), the maintenance of wakefulness test and the Epworth Sleepiness Scale: failure of the MSLT as a gold standard. J Sleep Res. 2000 Mar;9(1):5–11. doi: 10.1046/j.1365-2869.2000.00177.x. PMID: 10733683.10733683
229 Randomized trial of modafinil for the treatment of pathological somnolence in narcolepsy. US Modafinil in Narcolepsy Multicenter Study Group. Ann Neurol. 1998 Jan;43(1):88–97. doi: 10.1002/ana.410430115. PMID: 9450772.9450772
230 Kingshott RN, Vennelle M, Coleman EL, . Randomized, double-blind, placebo-controlled crossover trial of modafinil in the treatment of residual excessive daytime sleepiness in the sleep apnea/hypopnea syndrome. Am J Respir Crit Care Med. 2001 Mar;163(4):918–23. doi: 10.1164/ajrccm.163.4.2005036. PMID: 11282766.11282766
231 Puhan MA, Suarez A, Lo Cascio C, . Didgeridoo playing as alternative treatment for obstructive sleep apnoea syndrome: randomised controlled trial. BMJ. 2006 Feb 4;332(7536):266–70. doi: 10.1136/bmj.38705.470590.55. PMID: 16377643.16377643
232 Holty JE. External expert review of screening for obstructive sleep apnea in adults draft report; discussion section. Electronic correspondence with USPSTF and RTI UNC-EPC. 2015.
233 Medical Advisory Secretariat. Oral appliances for obstructive sleep apnea: an evidence-based analysis. Ontario Health Technology Assessment Series. 2009;9(5).
234 Miletin MS, Hanly PJ. Measurement properties of the Epworth Sleepiness Scale. Sleep Med. 2003 May;4(3):195–9. doi: 10.1016/s1389-9457(03)00031-5. PMID: 14592321.14592321
235 Smith SS, Oei TP, Douglas JA, . Confirmatory factor analysis of the Epworth Sleepiness Scale (ESS) in patients with obstructive sleep apnoea. Sleep Med. 2008 Oct;9(7):739–44. doi: 10.1016/j.sleep.2007.08.004. PMID: 17921053.17921053
236 Baldwin CM, Griffith KA, Nieto FJ, . The association of sleep-disordered breathing and sleep symptoms with quality of life in the Sleep Heart Health Study. Sleep. 2001 Feb 1;24(1):96–105. doi: 10.1093/sleep/24.1.96. PMID: 11204058.11204058
237 Howard ME, Desai AV, Grunstein RR, . Sleepiness, sleep-disordered breathing, and accident risk factors in commercial vehicle drivers. Am J Respir Crit Care Med. 2004 Nov 1;170(9):1014–21. doi: 10.1164/rccm.200312-1782OC. PMID: 15317672.15317672
238 Vongpatanasin W. Resistant hypertension: a review of diagnosis and management. JAMA. 2014 Jun 4;311(21):2216–24. doi: 10.1001/jama.2014.5180. PMID: 24893089.24893089
239 Bisognano JD, Bakris G, Nadim MK, . Baroreflex activation therapy lowers blood pressure in patients with resistant hypertension: results from the double-blind, randomized, placebo-controlled rheos pivotal trial. J Am Coll Cardiol. 2011 Aug 9;58(7):765–73. doi: 10.1016/j.jacc.2011.06.008. PMID: 21816315.21816315
240 Esler MD, Krum H, Sobotka PA, . Renal sympathetic denervation in patients with treatment-resistant hypertension (The Symplicity HTN-2 Trial): a randomised controlled trial. Lancet. 2010 Dec 4;376(9756):1903–9. doi: 10.1016/S0140-6736(10)62039-9. PMID: 21093036.21093036
241 Chobanian AV, Bakris GL, Black HR, . The seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA. 2003 May 21;289(19):2560–72. doi: 10.1001/jama.289.19.2560. PMID: 12748199.12748199
242 Luyster FS. Impact of Obstructive Sleep Apnea and Its Treatments on Partners: A Literature Review. J Clin Sleep Med. 2017 Mar 15;13(3):467–77. doi: 10.5664/jcsm.6504. PMID: 28095973.28095973
243 Wozniak DR, Lasserson TJ, Smith I. Educational, supportive and behavioural interventions to improve usage of continuous positive airway pressure machines in adults with obstructive sleep apnoea. Cochrane Database Syst Rev. 2014 Jan 8(1):CD007736. doi: 10.1002/14651858.CD007736.pub2. PMID: 24399660.24399660
244 Silva GE, Vana KD, Goodwin JL, . Identification of patients with sleep disordered breathing: comparing the four-variable screening tool, STOP, STOP-Bang, and Epworth Sleepiness Scales. J Clin Sleep Med. 2011 Oct 15;7(5):467–72. doi: 10.5664/JCSM.1308. PMID: 22003341.22003341
245 Villa MP, Brasili L, Ferretti A, . Oropharyngeal exercises to reduce symptoms of OSA after AT. Sleep Breath. 2015 Mar;19(1):281–9. doi: 10.1007/s11325-014-1011-z. PMID: 24859614.24859614
246 Guimaraes KC, Drager LF, Genta PR, . Effects of oropharyngeal exercises on patients with moderate obstructive sleep apnea syndrome. Am J Respir Crit Care Med. 2009 May 15;179(10):962–6. doi: 10.1164/rccm.200806-981OC. PMID: 19234106.19234106
247 Kohler M, Bloch KE, Stradling JR. The role of the nose in the pathogenesis of obstructive sleep apnoea and snoring. Eur Respir J. 2007 Dec;30(6):1208–15. doi: 10.1183/09031936.00032007. PMID: 18055705.18055705
248 Koutsourelakis I, Minaritzoglou A, Zakynthinos G, . The effect of nasal tramazoline with dexamethasone in obstructive sleep apnoea patients. Eur Respir J. 2013 Oct;42(4):1055–63. doi: 10.1183/09031936.00142312. PMID: 23397296.23397296
249 Acar M, Cingi C, Sakallioglu O, . The effects of mometasone furoate and desloratadine in obstructive sleep apnea syndrome patients with allergic rhinitis. Am J Rhinol Allergy. 2013 Jul–Aug;27(4):e113–6. doi: 10.2500/ajra.2013.27.3921. PMID: 23883803.23883803
250 Ho V, Crainiceanu CM, Punjabi NM, . Calibration model for apnea-hypopnea indices: impact of alternative criteria for hypopneas. Sleep. 2015 Dec 1;38(12):1887–92. doi: 10.5665/sleep.5234. PMID: 26564122.26564122
251 Redline S, Kapur VK, Sanders MH, . Effects of varying approaches for identifying respiratory disturbances on sleep apnea assessment. Am J Respir Crit Care Med. 2000 Feb;161(2 Pt 1):369–74. doi: 10.1164/ajrccm.161.2.9904031. PMID: 10673173.10673173
252 Weaver TE, Crosby RD, Bron M, . 0612 using multiple anchor-based and distribution-based estimates to determine the Minimal Important Difference (MID) for the FOSQ-10. Sleep. 2018;41(suppl 1):A227–A. doi: 10.1093/sleep/zsy061.611.
253 Flemons WW, Reimer MA. Development of a disease-specific health-related quality of life questionnaire for sleep apnea. Am J Respir Crit Care Med. 1998 Aug;158(2):494–503. doi: 10.1164/ajrccm.158.2.9712036. PMID: 9700127.9700127
254 Ramar K, Dort LC, Katz SG, . Clinical practice guideline for the treatment of obstructive sleep apnea and snoring with oral appliance therapy: an update for 2015. J Clin Sleep Med. 2015 Jul 15;11(7):773–827. doi: 10.5664/jcsm.4858. PMID: 26094920.26094920
255 National Institute for Health and Clinical Excellence (NICE). NICE technology appraisal guidance 139: Continuous positive airway pressure for the treatment of obstructive sleep apnoea/hypopnoea syndrome [Internet]. London, UK: National Institute for Health and Clinical Excellence; 2008. www.nice.org.uk/TA139.
256 Chung F, Memtsoudis SG, Ramachandran SK, . Society of Anesthesia and Sleep Medicine guidelines on preoperative screening and assessment of adult patients with obstructive sleep apnea. Anesth Analg. 2016 Aug;123(2):452–73. doi: 10.1213/ANE.0000000000001416. PMID: 27442772.27442772
257 Rosen IM, Kirsch DB, Chervin RD, . Clinical use of a home sleep apnea test: an American Academy of Sleep Medicine position statement. J Clin Sleep Med. 2017 Oct 15;13(10):1205–7. doi: 10.5664/jcsm.6774. PMID: 28942762.28942762
258 National Institute for Health and Clinical Excellence (NICE). Obstructive sleep apnoea/hypopnoea syndrome and obesity hypoventilation syndrome in over 16s. London, UK: National Institute for Health and Clinical Excellence; 2020. https://www.nice.org.uk/guidance/indevelopment/gid-ng10098.
259 Saglam-Aydinatay B, Uysal S, Taner T. Facilitators and barriers to referral compliance among dental patients with increased risk of obstructive sleep apnea. Acta Odontol Scand. 2018 Mar;76(2):86–91. doi: 10.1080/00016357.2017.1386797. PMID: 28984173.28984173
260 Shaw R, McKenzie S, Taylor T, . Beliefs and attitudes toward obstructive sleep apnea evaluation and treatment among blacks. J Natl Med Assoc. 2012 Nov–Dec;104(11–12):510–9. doi: 10.1016/s0027-9684(15)30217-0. PMID: 23560353.23560353
261 Gordon A, Wu SJ, Munns N, . Untreated sleep apnea: an analysis of administrative data to identify risk factors for early nonadherence. J Clin Sleep Med. 2018 Aug 15;14(8):1303–13. doi: 10.5664/jcsm.7260. PMID: 30092889.30092889
262 Bakhai SY, Nigam M, Saeed M, . Improving OSA screening and diagnosis in patients with hypertension in an academic safety net primary care clinic: quality improvement project. BMJ Open Qual. 2017;6(2):e000105. doi: 10.1136/bmjoq-2017-000105. PMID: 29435504.29435504
263 Hayes SM, Murray S, Castriotta RJ, . (Mis) perceptions and interactions of sleep specialists and generalists: obstacles to referrals to sleep specialists and the multidisciplinary team management of sleep disorders. J Clin Sleep Med. 2012 Dec 15;8(6):633–42. doi: 10.5664/jcsm.2252. PMID: 23243396.23243396
264 Boulet LP, Bourbeau J, Skomro R, . Major care gaps in asthma, sleep and chronic obstructive pulmonary disease: a road map for knowledge translation. Can Respir J. 2013 Jul–Aug;20(4):265–9. doi: 10.1155/2013/496923. PMID: 23936884.23936884
265 Ioja S, Chasens ER, Ng J, . Obstructive sleep apnea in adults with type 1 and type 2 diabetes: perspectives from a quality improvement initiative in a university-based diabetes center. BMJ Open Diabetes Res Care. 2017;5(1):e000433. doi: 10.1136/bmjdrc-2017-000433. PMID: 28878943.28878943
266 Showalter L, O’Keefe C. Implementation of an obstructive sleep apnea screening tool with hypertensive patients in the primary care clinic. J Am Assoc Nurse Pract. 2019 Mar;31(3):184–8. doi: 10.1097/JXX.0000000000000124. PMID: 30589754.30589754
267 Rodgers B. Breaking through limbo: experiences of adults living with obstructive sleep apnea. Behav Sleep Med. 2014;12(3):183–97. doi: 10.1080/15402002.2013.778203. PMID: 23570652.23570652
268 Borsini E, Blanco M, Bosio M, . “Diagnosis of sleep apnea in network” respiratory polygraphy as a decentralization strategy. Sleep Science. 2016;9(3):244–8. doi: 10.1016/j.slsci.2016.10.009.28123669
269 Spagnuolo CM, McIsaac M, Dosman J, . Distance to specialist medical care and diagnosis of obstructive sleep apnea in rural Saskatchewan. Can Respir J. 2019;2019:1683124. doi: 10.1155/2019/1683124. PMID: 30733845.30733845
270 Zhang C, Berger M, Malhotra A, . Portable diagnostic devices for identifying obstructive sleep apnea among commercial motor vehicle drivers: considerations and unanswered questions. Sleep. 2012 Nov 1;35(11):1481–9. doi: 10.5665/sleep.2194. PMID: 23115397.23115397
271 Mendonca F, Mostafa SS, Ravelo-Garcia AG, . Devices for home detection of obstructive sleep apnea: a review. Sleep Med Rev. 2018 Oct;41:149–60. doi: 10.1016/j.smrv.2018.02.004. PMID: 30149930.30149930
272 Garg N, Rolle AJ, Lee TA, . Home-based diagnosis of obstructive sleep apnea in an urban population. J Clin Sleep Med. 2014 Aug 15;10(8):879–85. doi: 10.5664/jcsm.3960. PMID: 25126034.25126034
273 Sleep-related breathing disorders in adults: recommendations for syndrome definition and measurement techniques in clinical research. The Report of an American Academy of Sleep Medicine Task Force. Sleep. 1999 Aug 1;22(5):667–89. PMID: 10450601.10450601
274 Xie C, Zhu R, Tian Y, . Association of obstructive sleep apnoea with the risk of vascular outcomes and all-cause mortality: a meta-analysis. BMJ Open. 2017 Dec 22;7(12):e013983. doi: 10.1136/bmjopen-2016-013983. PMID: 29275335.29275335
275 Dong JY, Zhang YH, Qin LQ. Obstructive sleep apnea and cardiovascular risk: meta-analysis of prospective cohort studies. Atherosclerosis. 2013 Aug;229(2):489–95. doi: 10.1016/j.atherosclerosis.2013.04.026. PMID: 23684511.23684511
276 Loke YK, Brown JW, Kwok CS, . Association of obstructive sleep apnea with risk of serious cardiovascular events: a systematic review and meta-analysis. Circ Cardiovasc Qual Outcomes. 2012 Sep 1;5(5):720–8. doi: 10.1161/CIRCOUTCOMES.111.964783. PMID: 22828826.22828826
277 Pan L, Xie X, Liu D, . Obstructive sleep apnoea and risks of all-cause mortality: preliminary evidence from prospective cohort studies. Sleep Breath. 2016 Mar;20(1):345–53. doi: 10.1007/s11325-015-1295-7. PMID: 26779904.26779904
278 Wang X, Ouyang Y, Wang Z, . Obstructive sleep apnea and risk of cardiovascular disease and all-cause mortality: a meta-analysis of prospective cohort studies. Int J Cardiol. 2013 Nov 5;169(3):207–14. doi: 10.1016/j.ijcard.2013.08.088. PMID: 24161531.24161531
279 Zhao E, Chen S, Du Y, . Association between sleep apnea hypopnea syndrome and the risk of atrial fibrillation: a meta-analysis of cohort study. Biomed Res Int. 2018;2018:5215868. doi: 10.1155/2018/5215868. PMID: 29581977.29581977
280 Leng Y, McEvoy CT, Allen IE, . Association of sleep-disordered breathing with cognitive function and risk of cognitive impairment: a systematic review and meta-analysis. JAMA Neurol. 2017 Oct 1;74(10):1237–45. doi: 10.1001/jamaneurol.2017.2180. PMID: 28846764.28846764
281 US Preventive Services Task Force. Procedure Manual US Preventive Services Task Force. Rockville, MD: 2015. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual
282 Baird T, Theal R, Gleeson S, . Detailed polysomnography in Australian Vietnam veterans with and without posttraumatic stress disorder. J Clin Sleep Med. 2018 Sep 15;14(9):1577–86. doi: 10.5664/jcsm.7340. PMID: 30176975.30176975
283 Bartolucci ML, Bortolotti F, Corazza G, . Effectiveness of different mandibular advancement device designs in obstructive sleep apnoea therapy: a systematic review of randomised controlled trials with meta-analysis. J Oral Rehabil. 2021 Apr;48(4):469–86. doi: 10.1111/joor.13077. PMID: 32805753.32805753
284 Green M, Ken-Dror G, Fluck D, . Meta-analysis of changes in the levels of catecholamines and blood pressure with continuous positive airway pressure therapy in obstructive sleep apnea. J Clin Hypertens (Greenwich). 2021 Jan;23(1):12–20. doi: 10.1111/jch.14061. PMID: 32970922.32970922
285 Ilea A, Timuș D, Höpken J, . Oral appliance therapy in obstructive sleep apnea and snoring - systematic review and new directions of development. Cranio. 2019 Oct 5:1–12. doi: 10.1080/08869634.2019.1673285. PMID: 31588866.31033422
286 Rossi A, Lo Giudice A, Di Pardo C, . Clinical evidence in the treatment of obstructive sleep apnoea with oral appliances: a systematic review. Int J Dent. 2021;2021:6676158. doi: 10.1155/2021/6676158. PMID: 34035815.34035815
287 Aarab G, Arcache P, Lavigne GJ, . The effects of mandibular advancement appliance therapy on jaw-closing muscle activity during sleep in patients with obstructive sleep apnea: a 3-6 months follow-up. J Clin Sleep Med. 2020 Sep 15;16(9):1545–53. doi: 10.5664/jcsm.8612. PMID: 32501212.32501212
288 Baillieul S, Wuyam B, Pérennou D, . A randomized sham-controlled trial on the effect of continuous positive airway pressure treatment on gait control in severe obstructive sleep apnea patients. Sci Rep. 2021 Apr 29;11(1):9329. doi: 10.1038/s41598-021-88642-5. PMID: 33927278.33927278
289 Bigini EG, Chasens ER, Conley YP, . DNA methylation changes and improved sleep quality in adults with obstructive sleep apnea and diabetes. BMJ Open Diabetes Res Care. 2019;7(1):e000707. doi: 10.1136/bmjdrc-2019-000707. PMID: 31798891.31798891
290 Caples SM, Mansukhani MP, Friedman PA, . The impact of continuous positive airway pressure treatment on the recurrence of atrial fibrillation post cardioversion: a randomized controlled trial. Int J Cardiol. 2019 Mar 1;278:133–6. doi: 10.1016/j.ijcard.2018.11.100. PMID: 30522886.30522886
291 Schwarz EI, Furian M, Schlatzer C, . Nocturnal cerebral hypoxia in obstructive sleep apnoea: a randomised controlled trial. Eur Respir J. 2018 May;51(5)doi: 10.1183/13993003.00032-2018. PMID: 29700104.29700104