# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Justin Mills, MD, MPH, AHRQ Medical Officer; Tracy Wolff, MD, MPH, Scientific Director, USPSTF Division, AHRQ; current and former members of the U.S. Preventive Services Task Force; expert reviewers Sean M. Caples, DO, MS, Mayo Clinic; Jon-Erik C. Holty, MD, MS, Stanford University; Paul E. Peppard, PhD, MS, University of Wisconsin-Madison; Federal partners from the Centers for Disease Control and Prevention; National Heart, Lung, and Blood Institute; National Institute of Dental and Craniofacial Research; National Institute on Minority Health and Health Disparities; and National Institutes of Health’s Office of Research on Women’s Health; Staci Rachman, BA, and Sharon Barrell, MA, editors; Loraine Monroe and Teyonna Downing, publications specialists; and Carol Woodell, BSPH, and Roberta Wines, MPH, former and current RTI International–University of North Carolina EPC Project Managers, respectively.