# Chapter 4 Discussion

## Summary of Evidence

Table 4 provides a summary of findings for this evidence review. This table is organized by KQ, then by questionnaire, prediction tool, test, or intervention and provides a summary of outcomes with a description of their precision, quality, and applicability.

Table 4 Summary of Evidence for Screening and Treatment of Obstructive Sleep Apnea

Key Question (KQ) | Questionnaire, Prediction Tool, Test, or Intervention | Number of Studies and Study Design (Total Sample Size) by Test or Outcome | Summary of Findings by Test or Outcome | Consistency Precision | Reporting Bias | Study Quality | Body of Evidence Limitations | Overall Strength of Evidence | Applicability
KQ 1. Benefits of screening | NA | No eligible study identified | NA | NA | NA | NA | NA | Insufficient | NA
KQ 2. Accuracy of screening question-naires, clinical prediction tools, and multistep screening approaches | BQ | 2 cross-sectional (563) | Varies by OSA threshold (AHI cut point); Sn range: 37% to 94%; Sp range: 0% to 84% | Unknown: studies used different reference test thresholds; Unknown: one reporting CIs (precise) and one not reporting CIs | Undetected | Fair | Studies enrolled different populations; one with risk of bias due to attrition bias and spectrum bias, and one (enrolling U.S. adults with DM2) with small sample size and risk of bias due to unclear methods for calculating accuracy of OSA categories | Insufficient | Unclear, one study enrolling general population of Norway and one enrolling U.S. adults with DM2
KQ 2. Accuracy of screening question-naires, clinical prediction tools, and multistep screening approaches | STOP-BANG Questionnaire | 2 cross-sectional (245) | Varies by OSA threshold (AHI cut point); Sn range: 87% to 94%; Sp range: 0% to 38% | Unknown: studies used different reference test thresholds; Unknown: one reporting CIs (precise) and one not reporting CIs | Undetected | Fair | Studies enrolled different populations, one with DM2 and one who used opioids for chronic pain. Both studies had a moderate risk of bias due to lack of clarity related to screening and reference standard interpreted separately; unclear methods for calculating accuracy of OSA categories | Insufficient | Persons with DM2 and using opioids for chronic pain
KQ 2. Accuracy of screening question-naires, clinical prediction tools, and multistep screening approaches | Modified STOP-BANG^*^ | 1 cross-sectional (91) | Sn and Sp (95% CI); AHI >30: 61 (47 to 74; 76 (59 to 89) | Unknown, single study; Imprecise | Undetected | Fair | Single study with risk of bias due to patient selection | Insufficient | Persons with AD
KQ 2. Accuracy of screening question-naires, clinical prediction tools, and multistep screening approaches | Modified STOP-BANG^†^ | 1 cross-sectional (199) | Sn and Sp (95% CI); AHI ≥5: 93 (88 to 96); 32 (24 to 37); AHI ≥15: 95 (88 to 99); 23 (19 to 25); AHI >30: 100 (89 to 100; 21 (19 to 21) | Unknown, single study; Precise | Undetected | Fair | Risk of bias due to unclear methods for calculating accuracy by OSA severity category | Insufficient | Persons using opioids for chronic pain
KQ 2. Accuracy of screening question-naires, clinical prediction tools, and multistep screening approaches | MVAP score (for severe OSAS) | 2 cross-sectional (702) | For severe OSAS (AHI ≥30 and ESS >10) using MVAP cutoff 0.48 to 0.49: Sn (95% CI): 90% (NR) to 91.5% (NR); Sp (95% CI): 43.9% (NR) to 64.4% (NR); AUC (95% CI): 0.68 (0.67 to 0.70) to 0.78 (0.71 to 0.85) | Inconsistent (1 with inadequate discrimination; 1 with reasonable discrimination); Imprecise | Undetected | Fair | Concern for spectrum bias in both studies; risk of attrition bias in 1 | Insufficient | Populations with high prevalence of OSAS (≥25%); only 1 study reported % with any OSA (80%); studies included Medicare recipients and adults with HTN
KQ 2. Accuracy of screening question-naires, clinical prediction tools, and multistep screening approaches | MVAP score (for any OSAS) | 1 cross-sectional (250) | For any OSAS (AHI ≥5 and ESS >10): Sn (95% CI): 69.4% (NR); Sp (95% CI): 56.5% (NR); AUC (95% CI): 0.614 (NR) | Unknown; Imprecise | Undetected | Fair | Concern for spectrum bias; risk of attrition bias | Insufficient | Populations with high prevalence of OSAS; studies included Medicare recipients and adults with HTN
KQ 2. Accuracy of screening question-naires, clinical prediction tools, and multistep screening approaches | MVAP score followed by unattended HST (for severe OSAS) | 2 cross-sectional (702) | For severe OSAS (AHI ≥30 and ESS >10) using home-based AHI of 15 or 18: Sn (95% CI): 88.2% to 90.9% (NR); Sp (95% CI): 71.6% to 75.7% (NR); AUCs: 0.799 (0.777 to 0.822) and 0.833 (0.765 to 0.902) | Consistent; Precise | Undetected | Fair | Concern for spectrum bias in both studies; risk of attrition bias in one | Low | Populations with high prevalence of OSAS; studies included Medicare recipients and adults with HTN
KQ 2. Accuracy of screening question-naires, clinical prediction tools, and multistep screening approaches | MVAP score followed by unattended HST (for any OSAS) | 1 cross-sectional (250) | For any OSAS (AHI ≥5 and ESS >10): Sn (95% CI): 80.5% (NR); Sp (95% CI): 54.0% (NR); AUC (95% CI): 0.672 (NR) | Unknown; Imprecise | Undetected | Fair | Concern for spectrum bias; risk of attrition bias | Insufficient | Populations with high prevalence of OSAS; studies included Medicare recipients and adults with HTN
KQ 3. Harms associated with screening or subsequent diagnostic testing | NA | No eligible study identified | NA | NA | NA | NA | NA | Insufficient | NA
KQ 4. Efficacy of treatment for improving intermediate outcomes | PAP | AHI: 2 SRs: 1 focused on any OSA severity (11 RCTs, 832) participants) and 1 limited to nonsleepy populations (3 RCTs, 1,541 participants); BP: 3 SRs: 1 focused on any OSA severity (12 RCTs, 1,919 participants), 1 limited to nonsleepy populations (5 RCTs, 1,541 participants), and 1 limited to populations with resistant HTN (23 RCTs; 4,905 participants) | AHI, pooled mean difference:; Any OSA severity: −23.41 (−28.51 to −18.30); I^2^=93%; Nonsleepy populations:-15.57 (−29.32 to −1.82); I^2^=87.2%; Daytime BP, pooled mean difference:; Any severity, SBP: −2.76 (−4.31 to −1.20); I^2^=5%; DBP: −1.98 (−3.02 to −0.93); I^2^=4%^‡^; Nonsleepy populations, SBP: −0.51 (−3.39 to 2.38); I^2^=84%; DBP: −0.92 (−1.39 to −0.46); I^2^=0.0%; Populations with resistant HTN:; Mean 24-hour SBP: −5.06 (−7.98 to −2.13); Mean 24-hour DBP: −4.21 (−6.50 to −1.93) | Consistent for AHI and BP; Precise for AHI and BP; imprecise for BP in pooled estimate limited to nonsleepy populations | Undetected | Good^‡^ | Most trials were ≤12 weeks; estimates associated with significant heterogeneity | Mod for AHI; Mod for BP in overall (any) OSA populations and populations with resistant HTN, low for BP in nonsleepy populations | Referral population with known OSA
KQ 4. Efficacy of treatment for improving intermediate outcomes | MAD | BP: 1 SR: 11 RCTs (469) | BP: No statistically significant reduction in daytime, nighttime, or 24-hour BP measures | Consistent; Imprecise | Undetected | Good^ǁ^ | Variations in BP treatment at baseline and limited followup (1–3 months) | Low | Referral population with known OSA
KQ 5. Efficacy of treatment for improving health outcomes | PAP | Mortality: 31 RCTs (2,673); ESS: 47 RCTs (7,024); SF-36 PCS: 13 RCTs (2,031); SF-36 MCS: 15 RCTs (2,345); Sleep-related QOL (SAQLI, FOSQ, or QSQ): 17 RCTs (3,083); CV events: 8 RCTs (1,529) | Mortality: No event (27 RCTs) or 1 event (2 RCTs) at ≤12 weeks; no significant difference at 24 weeks (1 RCT: 2 vs. 2), median of 4 years (1 RCT: 8 vs. 3), or median of 5 years; ESS: −2.33 (95% CI, −2.75 to −1.90); SF-36 PCS: PAP vs. any comparator: mean difference, 1.53 (95% CI, 0.29 to 2.77); SF-36 MCS: PAP vs. any comparator: mean difference, 2.20 (95% CI, 0.95 to 3.44); SAQLI or FOSQ: PAP vs. any comparator: SMD, 0.30 (95% CI, 0.19 to 0.42); CV events: Overall, too few events were observed to draw conclusions | Mortality and CV events: Consistent for studies of relatively short duration (≤12–24 weeks), unknown for longer duration; Imprecise; ESS: Consistent, precise; SF-36 PCS, MCS: Mostly consistent, Imprecise; Sleep-related QOL: Consistent, precise | Detected for SF-36 outcomes (6 RCTs reported individual SF-36 domains only); Undetected for all other outcomes | 7 Good; 54 Fair | Study duration may be insufficient to determine benefit for many health outcomes; small number of total events observed across studies for some outcomes (e.g., mortality, CV events) | Moderate for sleep-related QOL and ESS, low for general health-related QOL; insufficient for other health outcomes | Referral population with known OSA
KQ 5. Efficacy of treatment for improving health outcomes | MAD | Mortality: 4 RCTs (245); ESS: 10 RCTs (1,540); SF-36 total: 1 RCT (97); SF-36 PCS: 2 RCTs (183); SF-36 MCS: 2 RCTs (183); Sleep-related QOL: 3 RCTs (256) | ESS: Pooled mean difference, −1.67 (95% CI, −2.09 to −1.25); 1 death in no-treatment group in one 4-week RCT (n=93); mixed results for QOL measures | ESS: Consistent; Precise; Other outcomes: Inconsistent or unknown consistency; Imprecise | Undetected for most; suspected for QOL measures | 2 Good; 10 Fair | Short study durations (1–12 weeks), small number of studies reporting the outcomes and too few events (for mortality and MVAs) | Moderate for ESS; insufficient for other outcomes | Referral population with known OSA
KQ 6. Harms associated with treatment | PAP | 10 RCTs (2,064) | Overall, 1% to 47% had specific adverse events while using PAP. Commonly reported harms were oral or nasal dryness, eye or skin irritation, and rash | Consistent; Imprecise | Undetected, but sparse reporting of harms | Fair | High heterogeneity in reporting and findings | Low | Referral population with known OSA
KQ 6. Harms associated with treatment | MAD | 10 RCTs (684) | Overall, 17% to 74% had any harms while using MADs. Commonly reported harms were oral or nasal dryness, excess salivation, oral mucosal/dental/jaw symptoms | Inconsistent; Imprecise | Undetected, but sparse reporting of harms | Fair | High amount of heterogeneity in reporting and findings; most trials reported harms over a relatively short duration | Low | Referral population with known OSA

* Modified STOP-BANG (age older than 70 years; BMI ≥26 kg/m^2^; neck circumference >26.5 cm).

† Modified STOP-BANG (age 5–64 years 1 point, >65 years 2 points; and waist circumference >85, snoring; observed apnea; high blood pressure; BMI >25 kg/m^2^ each 1 point).

‡ Pooled estimates were similar for nighttime and 24-hour BP outcomes and for subgroup analyses of populations with HTN and resistant HTN.

ǁ Study quality rating refers to quality of the SR, not the quality of individual trials included by the reviews.

Abbreviations: AHI=apnea-hypopnea index; AUC=area under the curve; BMI=body mass index; BP=blood pressure; BQ=Berlin Questionnaire; CBV=cerebrovascular; CI=confidence interval; CV=cardiovascular; DBP=diastolic blood pressure; DM2=type 2 diabetes; ESS=Epworth Sleepiness Scale; EQ-5D=European Quality of Life Scale; FOSQ=Functional Outcomes of Sleep Questionnaire; HST=home sleep testing; HTN=hypertension; KQ=key question; MAD=mandibular advancement device; MCS=mental component summary score; mod=moderate; MVA=motor vehicle accident; MVAP=Multivariable Apnea Prediction; NR=not reported; OSA=obstructive sleep apnea; OSAS=obstructive sleep apnea syndrome; PAP=positive airway pressure; PCS=physical component summary score; PSG=polysomnography; QOL=quality of life; QSQ=Quebec Sleep Questionnaire; RCT=randomized, controlled trial; SAQLI=Sleep Apnea Quality of Life Index; SBP=systolic blood pressure; SF-36=Medical Outcome Short-Form (36-Item) Health Survey; SMD=standardized mean difference; Sn=sensitivity; Sp=specificity; SR=systematic review; vs.=versus.

### Evidence for Benefits and Harms of Screening for OSA

We did not identify any eligible study directly evaluating the benefits or harms of screening for OSA compared with those of no screening. Potential harms include overdiagnosis and overtreatment for asymptomatic persons with OSA (AHI ≥5) who never would have had symptoms of OSA or adverse health outcomes from OSA. Other potential harms include costs associated with referrals and additional testing (e.g., future PSG for follow-up care). Furthermore, we found no study evaluating the effect of OSA screening on psychological outcomes such as distress due to labeling or stigma.

Appendix A Contextual Question 1 describes potential barriers to undergoing diagnostic testing for OSA, which are important considerations for both screening and detection of persons at risk for OSA during routine care (in the absence of a formal screening program). Studies assessing why persons referred to a sleep lab did not follow up highlight the following reasons: misconceptions about OSA (e.g., lack of understanding of the disease, such as conflating snoring with OSA), work responsibilities, and financial and transportation difficulties. Some evidence suggests that patients with signs and symptoms of OSA such as snoring or gasping and sleepiness are more likely to be adherent to sleep testing than patients without symptoms. Other potential barriers include structural factors, such as geographical distance from specialists and sleep study centers, and factors specific to healthcare providers (e.g., inexperience with OSA leading to under recognition of obvious signs/symptoms that may benefit from diagnostic testing for OSA).

### Screening Questionnaires and Clinical Prediction Tools

We found very few eligible studies evaluating the accuracy of questionnaires or prediction tools for distinguishing persons in the general population who are more or less likely to have OSA. No approach was assessed by more than two included studies. Although four studies^115–118^ assessed the STOP-BANG, only two of them^115,^ ^118^ examined the STOP-BANG without modifications or additional screeners. Findings from these two studies were consistent; both found very good sensitivity but poor specificity. Two studies that modified the STOP-BANG^116,^ ^117^ found modest sensitivity and specificity. The other studies assessing the STOP-BANG used different scoring criteria to determine a positive screening test. The only screening approach suggesting possible accuracy evaluated by two studies was the MVAP score followed by unattended HST for detecting severe OSAS (AHI ≥30 and ESS >10). The AUC was approximately 0.8, with a sensitivity around 90 percent and a specificity ranging from 72 to 76 percent.^113,^ ^114^ Although using the MVAP score followed by unattended HST may have promise for screening, the evidence was limited by potential spectrum bias^221–225^ due to oversampling of high-risk participants and of those with OSA and OSAS, which may substantially overestimate the accuracy of using this approach to screen for OSA in the general population. Such overestimation was illustrated by a study evaluating the BQ, which reported a reduction in sensitivity from 79 to 37 percent after adjusting for bias in the sampling procedure to report estimated screening properties for the general population.^112^ The included studies evaluating MVAP enrolled populations with a high prevalence of OSAS (≥25%),^113,^ ^114^ OSA (AHI ≥5 for 80% of participants, and mean AHI of 22.5),^114^ and sleepiness (74%).^113^ In addition, no study prospectively measured calibration, which is often assessed by plotting the predicted risk versus the observed event rate,^121^ and no study assessed the clinical utility for improving health outcomes. Two included studies evaluating the BQ and STOP-BANG enrolled different populations and found inconsistent results.

We included fewer studies evaluating questionnaires or clinical prediction tools than some previously published reviews and guidelines,^21,^ ^47,^ ^226^ primarily because of our requirement to include studies that enrolled asymptomatic adults or adults with unrecognized symptoms of OSA; referral populations (e.g., to sleep clinics) were not eligible. Previous reviews and guidelines focused generally on diagnostic testing (of adults with symptoms suggestive of disordered sleep) rather than on screening (of asymptomatic persons with OSA or those with unrecognized symptoms of OSA). Nevertheless, these reviews and guidelines generally reported low overall quality/strength of evidence for questionnaires and prediction tools.

### Benefits and Harms of Treatment for OSA

Our review found consistent evidence from good- and fair-quality RCTs that PAP reduces excessive sleepiness and may improve general health–related QOL and sleep-related QOL. However, benefit associated with PAP for both general health-related QOL and sleep-related QOL measures falls short of the range considered an MCID (Table 3), and the clinical significance of the 2-point mean reduction on the ESS is somewhat uncertain. For excessive sleepiness, our data suggest a clinically significant reduction in most included trials because 85 percent of the trials in our meta-analysis for ESS with mean baseline ESS scores of 10 or greater (indicating EDS) reported mean endpoint ESS scores in the normal range of less than 10^227,^ ^228^ for the PAP groups (mean endpoint ESS <8). However, the threshold for a clinically significant change in ESS is somewhat uncertain. Although recent SRs noted that experts consider a 1-point change in ESS clinically significant,^47^ other sources suggest a 2- to 3-point change^204,^ ^205^ or greater change—one of at least 3 or 4 points—should be the clinically significant threshold for its sample size calculations or interpretation of findings.^229–231^ Also, the American College of Chest Physicians’ outcome experts evaluating the ESS informally stated that a clinically significant change in the ESS probably is at least 3 points and cited a specific example that a reduction of 1 point (e.g., from 3 [high] to 2 [moderate]) on two out of seven ESS domains was unlikely to be clinically relevant.^232^ Regardless of the clinically significant threshold level, the subjective nature of the ESS creates potential bias in trials of treatment (e.g., overreporting of improvements in sleepiness after receiving treatment), and some authors have raised concerns about its construct validity (i.e., authors have expressed uncertainty regarding whether it is an accurate measure of sleepiness).^233–235^ Multiple studies have reported associations between sleepiness and health outcomes, although many of them did not use the ESS to measure sleepiness. One study that used the nationwide population-based Sleep Heart Health Study (SHHS)^236^ (5,816 participants; mean age, 63 years; 52.5% women) reported that EDS was associated strongly with reduced QOL after adjusting for confounding variables (e.g., age, ethnicity) for both sexes. Sleepiness has also been linked to MVAs in multiple observational studies.^50,^ ^52,^ ^237^ A cross-sectional study of 913 employed adults from the general U.S. population (enrolled in the WSCS) found that men and women with an AHI greater than 15 were significantly more likely to have had multiple MVAs over the past 5 years (OR, 7.3 [95% CI, 1.8 to >25]; adjusted for age, miles driven, and sex) using State records for MVA history (retrospectively).^50^ This study was limited by its retrospective design and potential confounding. Considering education and usual alcohol consumption did not alter the OR. However, none of its measures of perceived sleepiness (including those derived from the ESS) was significantly related to accident occurrence. A cross-sectional study of 2,342 Australian commercial vehicle drivers found that the sleepiest 5 percent of drivers (based on the ESS) had about twice the odds of having experienced a self-reported MVA during the previous 3 years (OR, 1.91 [95% CI, 1.09 to 3.35]) and an even greater odds of having experienced multiple MVAs during the same period (OR, 2.67 [95% CI, 1.29 to 5.52]).^237^

For BP reduction (KQ 4), recent systematic reviews found that MAD and PAP are associated with a reduction in BP of 2 to 3 mm Hg, and one review limited to populations with resistant hypertension found a slightly higher mean reduction (5 mm Hg). Some experts suggest that a difference of more than 9/10 mm Hg (SBP/DBP) is clinically meaningful for patients.^238–240^ However, guidelines have suggested that across a population, a smaller reduction in SBP (2 to 3 mm Hg) could result in a clinically significant reduction in CV mortality (reduction of 4% to 5% for CHD and 6% to 8% for stroke).^241^ Even though MAD and PAP have been shown to reduce mean BP, no trials to date have shown a significant reduction in mortality or CVD.

We found that MADs also reduce excessive sleepiness, although the magnitude of effects was generally less than that with PAP, and BP reduction was not established based on a recent review.^123^ Although we did not evaluate head-to-head studies (e.g., those directly comparing MADs with PAP), previous comparative effectiveness reviews examining head-to-head trials reported smaller effect sizes for reducing AHI with MADs than with PAP.^47^

Evidence on most health outcomes was limited (i.e., too few RCTs reported on outcomes or too few events occurred to evaluate the effectiveness of PAP for reducing mortality, CV events, or MVAs). As summarized in Appendix A Contextual Question 2, there is a relatively large body of observational evidence supporting an association between severe OSA (AHI ≥30) and increased risk of many adverse health outcomes, including CV events, mortality, and cognitive impairment. Some studies suggest that the risk of such outcomes increases with each level of OSA severity, which may indicate a dose-response effect; however, this finding is not consistent across all studies or outcomes. Lastly, findings of increased risk associated with severe OSA are the strongest among male populations; however, it is difficult to assess if these relationships do not hold for female populations or if they are due to more sparse evidence on female populations. Observational studies focused on this association are limited, however, primarily due to potential confounding.

Reporting of harms from treatment in the included studies was sparse. Most did not report information about harms. In general, the adverse events related to PAP treatment were likely short-lived and could be alleviated by discontinuing treatment with PAP or by supplementing PAP with additional interventions. Common adverse events included oral or nasal dryness, eye or skin irritation, and rash. Common adverse effects from MADs included oral or nasal dryness, excessive salivation, and jaw discomfort. No included study reported on psychosocial harms of treatment, such as disruption of partner sleeping (e.g., because of the noise of PAP). Such adverse effects may limit patient adherence to treatment. However, a recent review of the effect of treatment for OSA reported several studies in which partners of patients treated with PAP indicated better quality of sleep and reduced sleep disturbance.^242^ A wide range (from 30% to 85%) of adherence to usage recommendations for PAP has been reported.^243^ An SR for AHRQ’s Effective Healthcare Program reported that cohort studies with multivariable analyses for predictors of nonadherence show that 14 to 32 percent of patients discontinue treatment with PAP over 4 years and patients use PAP for an average of 5 hours per night; data on adherence to treatment with MADs were too limited to provide adherence rates.^47^ This review also found that the AHI and the ESS are independent predictors of PAP adherence.^47^ A recent Cochrane SR of 33 studies (2,047 participants) found low- to moderate-quality evidence that three types of interventions can increase PAP usage in PAP-naive participants with moderate to severe OSAS.^243^ These included supportive interventions that encourage persons to continue to use PAP machines, short-term educational interventions, and behavioral therapy. However, they noted that trials did not assess persons who have struggled to adhere to treatment, and the impact of improved PAP usage on daytime sleepiness, QOL, and long-term CV risks remains unclear.

## Limitations

No studies were identified comparing screened and unscreened populations, which limits our ability to make conclusions about the direct benefit or harms of screening for OSA in primary care settings. Therefore, we attempted to review literature that might establish an indirect chain of evidence from multiple questions that link screening to health outcomes (KQs 2 through 6). For the first question in that indirect pathway (KQ 2), we found limited evidence that one screening approach (MVAP followed by unattended HST) might be useful to screen for severe OSAS, but the evidence was limited by potential spectrum bias, and no study prospectively assessed calibration or clinical utility for improving health outcomes. Studies of other screening questionnaires were heterogeneous in terms of enrolled populations and found inconsistent results.

We required studies to use in-laboratory PSG as the reference standard for KQ 2. This is similar to the approach used in previous SRs. For KQ 2, this resulted in exclusion of a large study from the SHHS that included 4,770 community participants and that reported on the STOP, STOP-BANG, and ESS questionnaires. This study reported a sensitivity from 39 (ESS ≥11) to 87 percent (STOP-BANG) and specificity from 43 (STOP-BANG) to 71 percent (ESS) for predicting moderate to severe OSA (RDI ≥15).^244^ NLR ranged from 0.3 to 0.85, indicating minimal to small decreases in the likelihood of disease, and PLR ranged from 1.4 to 1.5, indicating a minimal increase in the likelihood of disease.

We did not evaluate the accuracy of individual physical examination findings. We required questionnaires or clinical prediction tools to have multiple factors because previous SRs have found limited utility of individual findings. A previous review of clinical examination accuracy, which was not limited to asymptomatic patients with OSA or those with unrecognized symptoms of OSA, found that (among individual symptoms or signs) the most useful observation for identifying patients with OSA was nocturnal choking or gasping, imparting a small increase in the likelihood of disease (summary likelihood ratio, 3.3 [95% CI, 2.1 to 4.6]) when the diagnosis was established by an AHI of 10 or greater.^21^ This review found that many symptoms and signs provide limited information in determining the likelihood of OSA.^21^

We did not evaluate every possible outcome or intervention for OSA. We chose the outcomes that are most commonly reported and most potentially clinically meaningful. Our review was limited to interventions considered first-line treatments for persons with newly detected OSA (PAP and MAD). We did not include interventions that are primarily offered to persons who do not benefit from or tolerate PAP or MAD. We did not evaluate some treatments that may have potential benefits, such as oropharyngeal exercises,^245,^ ^246^ playing the didgeridoo, or using nasal steroids for treating allergic rhinitis (or similar treatments that might secondarily improve OSA by treating another condition).^247–249^ Nevertheless, previous reviews and clinical practice guidelines suggest that the potential benefits of such treatments are limited or uncertain.^47,^ ^96^ We limited eligible study designs to RCTs for evaluating treatment benefits, which possibly excluded some studies that might provide useful evidence for certain treatments, although such evidence has a higher risk of bias because of potential selection bias and confounding.

Some of our meta-analyses of RCTs evaluating the benefits of PAP (KQ 5) found substantial statistical heterogeneity. We did not find a clear explanation for the statistical heterogeneity, but possible explanations include variation in PAP devices (e.g., machines, masks, humidifiers, filters, cushions), participant characteristics (e.g., studies with a lower baseline mean AHI finding smaller effect sizes because of ceiling effects), apnea and hypopnea definitions, adherence, study duration, study methods, or chance. Definitions of apnea and hypopnea vary in published studies. For example, various cut points for oxygen desaturation are used to define hypopnea; some studies define hypopnea as requiring either oxygen desaturation or an EEG arousal, and some studies do not clearly define hypopnea. A publication from the SHHS demonstrated the potential impact of variation in hypopnea definitions on the prevalence of OSA, reporting that varying the definition in an otherwise healthy older population increased the prevalence from roughly 50 percent (using the Centers for Medicare & Medicaid Services’ definition of 4% oxygen desaturation) to greater than 80 percent (using the AASM’s 2012 definition of either 3% oxygen desaturation or an EEG arousal).^250,^ ^251^ We did not abstract detailed information about apnea and hypopnea definitions from each study and did not conduct subgroup analyses or meta-regression to explore the specific contribution of every possible factor that may explain some of the statistical heterogeneity identified by our meta-analyses. Regardless of the cause of the statistical heterogeneity, the vast majority of trials that included participants with EDS at baseline (ESS ≥10) reported mean endpoint ESS scores well into the normal range (<8) for the PAP-treated groups.

## Future Research Needs

To better understand the potential effectiveness of screening for OSA, RCTs of asymptomatic persons with OSA (or those with unrecognized symptoms of OSA) that directly compare screening with no screening and assess health outcomes (i.e., trials that address KQ 1, the overarching question) are needed. To better determine the accuracy of screening questionnaires and clinical prediction tools when used in the general population (related to KQ 2), additional studies are needed; such studies should aim to include a representative community population, to avoid spectrum bias, and to further evaluate promising screening approaches (e.g., MVAP followed by unattended HST) as well as other approaches assessed in similar populations for which we found few studies, such as the BQ and STOP-BANG Questionnaire. Trials of treatment (PAP and MAD) that enroll participants who are screen-detected from primary care settings are needed; results of trials that enrolled participants referred for OSA symptoms and other sleep complaints may not be applicable to populations who would be screen-detected. In addition, trials of common treatments that evaluate whether treatments improve other health outcomes (except for sleep-related QOL), such as CV events, are needed.

## Conclusion

The clinical utility of potential screening tools is uncertain. Although screening with MVAP followed by unattended HST may accurately distinguish persons in the general population who are more or less likely to have OSA, current data are limited by potential spectrum bias, with an oversampling of high-risk participants and those with OSA and OSAS. Further, we found no study that prospectively evaluated screening questionnaires or clinical prediction tools to report the calibration or the clinical utility for improving health outcomes. Other eligible screening questionnaires (BQ and STOP-BANG) were evaluated by two studies each and found inconsistent results. Treatment with PAP and MADs improve intermediate outcomes—PAP effectively reduces AHI to a normal or near-normal level and reduces BP; MADs also reduce AHI and BP, although the magnitudes of effects were generally less than those with PAP. Although consistent observational evidence has established that persons with severe or moderate to severe OSA die at twice the rate of that of controls, trials of PAP and other treatments have not satisfactorily evaluated whether treatment reduces mortality or improves most other health outcomes, barring evidence of possible benefit for reduction in EDS and improved sleep-related QOL.